# References

1 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 4th, Text Revision ed. Washington, DC. 2000.
2 Kessler RC, McGonagle KA, Zhao S, et al. Lifetime and 12-month prevalence of DSM-III-R psychiatric disorders in the United States. Results from the National Comorbidity Survey. Arch Gen Psychiatry. Jan. 1994;51(1):8-19. [pmid: 8279933].
3 Kessler RC, Berglund P, Demler O, et al. The epidemiology of major depressive disorder: results from the National Comorbidity Survey Replication (NCS-R). JAMA. 2003;289(23):3095-105. [pmid: 12813115].
4 Greenberg PE, Kessler RC, Birnbaum HG, et al. The economic burden of depression in the United States: how did it change between 1990 and 2000?. J Clin Psychiatry. Dec. 2003;64(12):1465-75. [pmid: 14728109].
5 Birnbaum HG, Ben-Hamadi R, Greenberg PE, et al. Determinants of direct cost differences among US employees with major depressive disorders using antidepressants. Pharmacoeconomics. 2009;27(6):507-17. [pmid: 19640013].
6 Olfson M, Marcus SC. National patterns in antidepressant medication treatment. Arch Gen Psychiatry. Aug. 2009;66(8):848-56. [pmid: 19652124].
7 Williams JW, Mulrow CD, Chiquette E, et al. A systematic review of newer pharmacotherapies for depression in adults: evidence report summary. Ann Intern Med. May. 2. 2000;132(9):743-56. [pmid: 10787370].
8 Geddes JR, Freemantle N, Mason J, et al. Selective serotonin reuptake inhibitors (SSRIs) versus other antidepressants for depression. The Cochrane Library (Cochrane Review). 2006.
9 Berkrot B. US prescription drug sales hit $300 bln in 2009. Reuters. 2010.
10 Maj J, Palider W, Rawlow. Trazodone, a central serotonin antagonist and agonist. J Neural Transm. 1979;44(3):237-48. [pmid: 438809].
11 Stefanini E, Fadda F, Medda L, et al. Selective inhibition of serotonin uptake by trazodone, a new antidepressant agent. Life Sci. Jun. 15. 1976;18(12):1459-65. [pmid: 940426].
12 Gartlehner G, Hansen RA, Thieda P, et al. Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression. Comparative Effectiveness Review No. 7. AHRQ Publication No 07-EHC007-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2007.
13 Kupfer DJ. Long-term treatment of depression. J Clin Psychiatry. May. 1991;52(Suppl):28-34. [pmid: 1903134].
14 Qaseem A, Snow V, Denberg TD, et al. Using second-generation antidepressants to treat depressive disorders: a clinical practice guideline from the American College of Physicians. Ann Intern Med. Nov. 18. 2008;149(10):725-33. [pmid: 19017591].
15 American Psychiatric Association. Practice guideline for the treatment of patients with major depressive disorder. 2010/10/01 ed. PsychiatryOnline. 2010.
16 Depression Guideline Panel. Depression in primary care: Volume 2, Treatment of major depression. AHCPR Publication No. 93-0550. Rockville, MD. US DHHS, Public Health Service, Agency for Health Care Policy and Research. 1993.
17 Hoagwood K, Hibbs E, Brent D, et al. Introduction to the special section: efficacy and effectiveness in studies of child and adolescent psychotherapy. J Consult Clin Psychol. Oct. 1995;63(5):683-7. [pmid: 7593860].
18 Gartlehner G, Hansen RA, Nissman D, et al. A simple and valid tool distinguished efficacy from effectiveness studies. J Clin Epidemiol. Oct. 2006;59(10):1040-8. [pmid: 16980143].
19 Hansen RA, Moore CG, Dusetzina SB, et al. Controlling for drug dose in systematic review and meta-analysis: a case study of the effect of antidepressant dose. Med Decis Making. Jan-Feb. 2009;29(1):91-103. [pmid: 19141788].
20 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective healthcare program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
21 Chapman A, Morgan LC, Gartlehner G. Semi-automating the manual literature search for systematic reviews increases efficiency. HILJ. 2009;27(1):22-7.
22 Ioannidis JPA, Evans SJW, GÃ¸tzsche PC, et al. Better Reporting of Harms in Randomized Trials: An Extension of the CONSORT Statement. Ann Intern Med. November. 16. 2004. 2004;141(10):781-8. [pmid: 15545678].
23 Balk EM, Lau J, Bonis PA. Reading and critically appraising systematic reviews and meta-analyses: a short primer with a focus on hepatology. J Hepatol. Oct. 2005;43(4):729-36. [pmid: 16120472].
24 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
25 Centre for Reviews and Dissemination. Systematic reviews: CRD's guidance for undertaking reviews in health care. York. University of York. 2009.
26 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173. [pmid: 14499048].
27 Jansen JP, Crawford B, Bergman G, et al. Bayesian meta-analysis of multiple treatment comparisons: an introduction to mixed treatment comparisons. Value Health. Sep-Oct. 2008;11(5):956-64. [pmid: 18489499].
28 Lu G, Ades AE. Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med. Oct. 30. 2004;23(20):3105-24. [pmid: 15449338].
29 Glenny AM, Altman DG, Song F, et al. Indirect comparisons of competing interventions. Health Technol Assess. Jul. 2005;9(26):1-34. iii. iv. [pmid: 16014203].
30 Eli Lilly and Company. Duloxetine Versus Placebo and Paroxetine in the Acute Treatment of Major Depression, Study Group A. Clinical Study Summary: Study F1J-MC-HMAT. 2004. www.clinicalstudyresults.org/documents/company-study_170_0.pdf. August 24, 2006.
31 Boulenger JP, Huusom AK, Florea I, et al. A comparative study of the efficacy of long-term treatment with escitalopram and paroxetine in severely depressed patients. Curr Med Res Opin. Jul. 2006;22(7):1331-41. [pmid: 16834832].
32 Blumenthal JA, Babyak MA, Doraiswamy PM, et al. Exercise and pharmacotherapy in the treatment of major depressive disorder. Psychosom Med. Sep-Oct. 2007;69(7):587-96. [pmid: 17846259].
33 Burke WJ, Gergel I, Bose A. Fixed-dose trial of the single isomer SSRI escitalopram in depressed outpatients. J Clin Psychiatry. Apr. 2002;63(4):331-6. [pmid: 12000207].
34 Colonna L, Andersen HF, Reines EH. A randomized, double-blind, 24-week study of escitalopram (10 mg/day) versus citalopram (20 mg/day) in primary care patients with major depressive disorder. Curr Med Res Opin. Oct. 2005;21(10):1659-68. [pmid: 16238906].
35 Lepola UM, Loft H, Reines EH. Escitalopram (10-20 mg/day) is effective and well tolerated in a placebo-controlled study in depression in primary care. Int Clin Psychopharmacol. Jul. 2003;18(4):211-7. [pmid: 12817155].
36 Moore N, Verdoux H, Fantino B. Prospective, multicentre, randomized, double-blind study of the efficacy of escitalopram versus citalopram in outpatient treatment of major depressive disorder. Int Clin Psychopharmacol. May. 2005;20(3):131-7. [pmid: 15812262].
37 FDA Center for Drug Evaluation and Research. Statistical Review of NDA 21-323 (Escitalopram Oxalate). 2001. www.accessdata.fda.gov/drugsatfda_docs/nda/2002/21-323.pdf_Lexapro_Medr_P1.pdf.
38 Yevtushenko VY, Belous AI, Yevtushenko YG, et al. Efficacy and tolerability of escitalopram versus citalopram in major depressive disorder: a 6-week, multicenter, prospective, randomized, double-blind, active-controlled study in adult outpatients. Clin Ther. Nov. 2007;29(11):2319-32. [pmid: 18158074].
39 Patris M, Bouchard JM, Bougerol T, et al. Citalopram versus fluoxetine: a double-blind, controlled, multicentre, phase III trial in patients with unipolar major depression treated in general practice. Int Clin Psychopharmacol. Jun. 1996;11(2):129-36. [pmid: 8803650].
40 Haffmans PM, Timmerman L, Hoogduin CA. Efficacy and tolerability of citalopram in comparison with fluvoxamine in depressed outpatients: a double-blind, multicentre study. The LUCIFER Group Int Clin Psychopharmacol. Sep. 1996;11(3):157-64. [pmid: 8923094].
41 Ekselius L, von Knorring L, Eberhard G. A double-blind multicenter trial comparing sertraline and citalopram in patients with major depression treated in general practice. Int Clin Psychopharmacol. Nov. 1997;12(6):323-31. [pmid: 9547134].
42 Kasper S, de Swart H, Friis Andersen H. Escitalopram in the treatment of depressed elderly patients. Am J Geriatr Psychiatry. Oct. 2005;13(10):884-91. [pmid: 16223967].
43 Mao PX, Tang YL, Jiang F, et al. Escitalopram in major depressive disorder: a multicenter, randomized, double-blind, fixed-dose, parallel trial in a Chinese population. Depress Anxiety. 2008;25(1):46-54. [pmid: 17149753].
44 Baldwin DS, Cooper JA, Huusom AK, et al. A double-blind, randomized, parallel-group, flexible-dose study to evaluate the tolerability, efficacy and effects of treatment discontinuation with escitalopram and paroxetine in patients with major depressive disorder. Int Clin Psychopharmacol. May. 2006;21(3):159-69. [pmid: 16528138].
45 Ventura D, Armstrong EP, Skrepnek GH, et al. Escitalopram versus sertraline in the treatment of major depressive disorder: a randomized clinical trial. Curr Med Res Opin. Feb. 2007;23(2):245-50. [pmid: 17288677].
46 Dalery J, Honig A. Fluvoxamine versus fluoxetine in major depressive episode: a double-blind randomised comparison. Hum Psychopharmacol. Jul. 2003;18(5):379-84. [pmid: 12858325].
47 Rapaport M, Coccaro E, Sheline Y, et al. A comparison of fluvoxamine and fluoxetine in the treatment of major depression. J Clin Psychopharmacol. Oct. 1996;16(5):373-8. [pmid: 8889909].
48 Cassano GB, Puca F, Scapicchio PL, et al. Paroxetine and fluoxetine effects on mood and cognitive functions in depressed nondemented elderly patients. J Clin Psychiatry. May. 2002;63(5):396-402. [pmid: 12019663].
49 Chouinard G, Saxena B, Belanger MC, et al. A Canadian multicenter, double-blind study of paroxetine and fluoxetine in major depressive disorder. J Affect Disord. Jul. 1999;54(1-2):39-48. [pmid: 10403145].
50 De Wilde J, Spiers R, Mertens C, et al. A double-blind, comparative, multicentre study comparing paroxetine with fluoxetine in depressed patients. Acta Psychiatr Scand. Feb. 1993;87(2):141-5. [pmid: 8447241].
51 Fava M, Amsterdam JD, Deltito JA, et al. A double-blind study of paroxetine, fluoxetine, and placebo in outpatients with major depression. Ann Clin Psychiatry. Dec. 1998;10(4):145-50. [pmid: 9988054].
52 Gagiano CA. A double blind comparison of paroxetine and fluoxetine in patients with major depression. Br J Clin Res. 1993;4:145-52.
53 Schone W, Ludwig M. A double-blind study of paroxetine compared with fluoxetine in geriatric patients with major depression. J Clin Psychopharmacol. Dec. 1993;13(6 Suppl 2):34S-9S. [pmid: 8106654].
54 Tignol J. A double-blind, randomized, fluoxetine-controlled, multicenter study of paroxetine in the treatment of depression. J Clin Psychopharmacol. Dec. 1993;13(6 Suppl 2):18S-22S. [pmid: 8106650].
55 Fava M, Hoog SL, Judge RA, et al. Acute efficacy of fluoxetine versus sertraline and paroxetine in major depressive disorder including effects of baseline insomnia. J Clin Psychopharmacol. Apr. 2002;22(2):137-47. [pmid: 11910258].
56 Bennie EH, Mullin JM, Martindale JJ. A double-blind multicenter trial comparing sertraline and fluoxetine in outpatients with major depression. J Clin Psychiatry. Jun. 1995;56(6):229-37. [pmid: 7775364].
57 Boyer P, Danion JM, Bisserbe JC, et al. Clinical and economic comparison of sertraline and fluoxetine in the treatment of depression. A 6-month double-blind study in a primary-care setting in France. Pharmacoeconomics. Jan. 1998;13(1 Pt 2):157-69. [pmid: 10184835].
58 Newhouse PA, Krishnan KR, Doraiswamy PM, et al. A double-blind comparison of sertraline and fluoxetine in depressed elderly outpatients. J Clin Psychiatry. Aug. 2000;61(8):559-68. [pmid: 10982198].
59 Finkel SI, Richter EM, Clary CM, et al. Comparative efficacy of sertraline vs. fluoxetine in patients age 70 or over with major depression. Am J Geriatr Psychiatry. Summer. 1999;7(3):221-7. [pmid: 10438693].
60 Sechter D, Troy S, Paternetti S, et al. A double-blind comparison of sertraline and fluoxetine in the treatment of major depressive episode in outpatients. Eur Psychiatry. Mar. 1999;14(1):41-8. [pmid: 10572324].
61 Van Moffaert M, Bartholome F, Cosyns P, et al. A controlled comparison of sertraline and fluoxetine in acute and continuation treatment of major depression. Human Psychopharmacol. 1995;10:393-405.
62 Kiev A, Feiger A. A double-blind comparison of fluvoxamine and paroxetine in the treatment of depressed outpatients. J Clin Psychiatry. Apr. 1997;58(4):146-52. [pmid: 9164424].
63 Ushiroyama T, Ikeda A, Ueki M. Evaluation of double-blind comparison of fluvoxamine and paroxetine in the treatment of depressed outpatients in menopause transition. J Med. 2004;35(1-6):151-62. [pmid: 18084873].
64 Nemeroff CB, Ninan PT, Ballenger J, et al. Double-blind multicenter comparison of fluvoxamine versus sertraline in the treatment of depressed outpatients. Depression. 1995;3(4):163-9.
65 Rossini D, Serretti A, Franchini L, et al. Sertraline versus fluvoxamine in the treatment of elderly patients with major depression: a double-blind, randomized trial. J Clin Psychopharmacol. Oct. 2005;25(5):471-5. [pmid: 16160624].
66 Aberg-Wistedt A, Agren H, Ekselius L, et al. Sertraline versus paroxetine in major depression: clinical outcome after six months of continuous therapy. J Clin Psychopharmacol. Dec. 2000;20(6):645-52. [pmid: 11106136].
67 Leinonen E, Skarstein J, Behnke K, et al. Efficacy and tolerability of mirtazapine versus citalopram: a double-blind, randomized study in patients with major depressive disorder. Nordic Antidepressant Study Group. Int Clin Psychopharmacol. Nov. 1999;14(6):329-37. [pmid: 10565799].
68 Allard P, Gram L, Timdahl K, et al. Efficacy and tolerability of venlafaxine in geriatric outpatients with major depression: a double-blind, randomised 6-month comparative trial with citalopram. Int J Geriatr Psychiatry. Dec. 2004;19(12):1123-30. [pmid: 15526307].
69 Khan A, Bose A, Alexopoulos GS, et al. Double-blind comparison of escitalopram and duloxetine in the acute treatment of major depressive disorder. Clin Drug Investig. 2007;27(7):481-92. [pmid: 17563128].
70 Nierenberg AA, Greist JH, Mallinckrodt CH, et al. Duloxetine versus escitalopram and placebo in the treatment of patients with major depressive disorder: onset of antidepressant action, a non-inferiority study. Curr Med Res Opin. Feb. 2007;23(2):401-16. [pmid: 17288694].
71 Wade A, Gembert K, Florea I. A comparative study of the efficacy of acute and continuation treatment with escitalopram versus duloxetine in patients with major depressive disorder. Curr Med Res Opin. Jul. 2007;23(7):1605-14. [pmid: 17559755].
72 Bielski RJ, Ventura D, Chang CC. A double-blind comparison of escitalopram and venlafaxine extended release in the treatment of major depressive disorder. J Clin Psychiatry. Sep. 2004;65(9):1190-6. [pmid: 15367045].
73 Montgomery SA, Huusom AK, Bothmer J. A randomised study comparing escitalopram with venlafaxine XR in primary care patients with major depressive disorder. Neuropsychobiology. 2004;50(1):57-64. [pmid: 15179022].
74 Goldstein DJ, Mallinckrodt C, Lu Y, et al. Duloxetine in the treatment of major depressive disorder: a double-blind clinical trial. J Clin Psychiatry. Mar. 2002;63(3):225-31. [pmid: 11926722].
75 Hong CJ, Hu WH, Chen CC, et al. A double-blind, randomized, group-comparative study of the tolerability and efficacy of 6 weeks' treatment with mirtazapine or fluoxetine in depressed Chinese patients. J Clin Psychiatry. Aug. 2003;64(8):921-6. [pmid: 12927007].
76 Versiani M, Moreno R, Ramakers-van Moorsel CJ, et al. Comparison of the effects of mirtazapine and fluoxetine in severely depressed patients. CNS Drugs. 2005;19(2):137-46. [pmid: 15697327].
77 Wheatley DP, van Moffaert M, Timmerman L, et al. Mirtazapine: efficacy and tolerability in comparison with fluoxetine in patients with moderate to severe major depressive disorder. Mirtazapine-Fluoxetine Study Group. J Clin Psychiatry. Jun. 1998;59(6):306-12. [pmid: 9671343].
78 Alves C, Cachola I, Brandao J. Efficacy and tolerability of venlafaxine and fluoxetine in outpatients with major depression. Primary Care Psychiatry. 1999;5(2):57-63.
79 Costa e Silva J. Randomized, double-blind comparison of venlafaxine and fluoxetine in outpatients with major depression. J Clin Psychiatry. Jul. 1998;59(7):352-7. [pmid: 9714263].
80 De Nayer A, Geerts S, Ruelens L, et al. Venlafaxine compared with fluoxetine in outpatients with depression and concomitant anxiety. Int J Neuropsychopharmacol. Jun. 2002;5(2):115-20. [pmid: 12135535].
81 Dierick M, Ravizza L, Realini R, et al. A double-blind comparison of venlafaxine and fluoxetine for treatment of major depression in outpatients. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1996;20(1):57-71. [pmid: 8861177].
82 Nemeroff CB, Thase ME. A double-blind, placebo-controlled comparison of venlafaxine and fluoxetine treatment in depressed outpatients. J Psychiatr Res. 2007;41(3-4):351-9. Epub 2005 Sep 12. [pmid: 16165158].
83 Rudolph RL, Feiger AD. A double-blind, randomized, placebo-controlled trial of once-daily venlafaxine extended release (XR) and fluoxetine for the treatment of depression. J Affect Disord. Dec. 1999;56(2-3):171-81. [pmid: 10701474].
84 Silverstone PH, Ravindran A. Once-daily venlafaxine extended release (XR) compared with fluoxetine in outpatients with depression and anxiety. Venlafaxine XR 360 Study Group. J Clin Psychiatry. Jan. 1999;60(1):22-8. [pmid: 10074873].
85 Tzanakaki M, Guazzelli M, Nimatoudis I, et al. Increased remission rates with venlafaxine compared with fluoxetine in hospitalized patients with major depression and melancholia. Int Clin Psychopharmacol. Jan. 2000;15(1):29-34. [pmid: 10836283].
86 Tylee A, Beaumont G, Bowden MW, et al. A double-blind, randomized, 12-week comparison study of the safety and efficacy of venlafaxine and fluoxetine in moderate to severe major depression in general practice. Primary Care Psychiatry. 1997;3(1):51-8.
87 Detke MJ, Wiltse CG, Mallinckrodt CH, et al. Duloxetine in the acute and long-term treatment of major depressive disorder: a placebo- and paroxetine-controlled trial. Eur Neuropsychopharmacol. Dec. 2004;14(6):457-70. [pmid: 15589385].
88 Perahia DG, Wang F, Mallinckrodt CH, et al. Duloxetine in the treatment of major depressive disorder: a placebo- and paroxetine-controlled trial. Eur Psychiatry. Sep. 2006;21(6):367-78. [pmid: 16697153].
89 Lee P, Shu L, Xu X, et al. Once-daily duloxetine 60 mg in the treatment of major depressive disorder: multicenter, double-blind, randomized, paroxetine-controlled, non-inferiority trial in China, Korea, Taiwan and Brazil. Psychiatry Clin Neurosci. Jun. 2007;61(3):295-307. [pmid: 17472599].
90 Benkert O, Szegedi A, Kohnen R. Mirtazapine compared with paroxetine in major depression. J Clin Psychiatry. Sep. 2000;61(9):656-63. [pmid: 11030486].
91 Blier P, Gobbi G, Turcotte JE, et al. Mirtazapine and paroxetine in major depression: a comparison of monotherapy versus their combination from treatment initiation. Eur Neuropsychopharmacol. Jul. 2009;19(7):457-65. [pmid: 19345072].
92 Schatzberg AF, Kremer C, Rodrigues HE, et al. Double-blind, randomized comparison of mirtazapine and paroxetine in elderly depressed patients. Am J Geriatr Psychiatry. Sep-Oct. 2002;10(5):541-50. [pmid: 12213688].
93 Ballus C, Quiros G, De Flores T, et al. The efficacy and tolerability of venlafaxine and paroxetine in outpatients with depressive disorder or dysthymia. Int Clin Psychopharmacol. Jan. 2000;15(1):43-8. [pmid: 10836286].
94 McPartlin GM, Reynolds A, Anderson C, et al. A comparison of once-daily venlafaxine XR and paroxetine in depressed outpatients treated in general practice. Primary Care Psychiatry. 1998;4(3):127-32.
95 Owens MJ, Krulewicz S, Simon JS, et al. Estimates of serotonin and norepinephrine transporter inhibition in depressed patients treated with paroxetine or venlafaxine. Neuropsychopharmacology. Dec. 2008;33(13):3201-12. [pmid: 18418363].
96 Behnke K, Sogaard J, Martin S, et al. Mirtazapine orally disintegrating tablet versus sertraline: a prospective onset of action study. J Clin Psychopharmacol. Aug. 2003;23(4):358-64. [pmid: 12920411].
97 Mehtonen OP, Sogaard J, Roponen P, et al. Randomized, double-blind comparison of venlafaxine and sertraline in outpatients with major depressive disorder. Venlafaxine 631 Study Group. J Clin Psychiatry. Feb. 2000;61(2):95-100. [pmid: 10732656].
98 Shelton RC, Haman KL, Rapaport MH, et al. A randomized, double-blind, active-control study of sertraline versus venlafaxine XR in major depressive disorder. J Clin Psychiatry. Nov. 2006;67(11):1674-81. [pmid: 17196045].
99 Sir A, D'Souza RF, Uguz S, et al. Randomized trial of sertraline versus venlafaxine XR in major depression: efficacy and discontinuation symptoms. J Clin Psychiatry. Oct. 2005;66(10):1312-20. [pmid: 16259546].
100 Coleman CC, King BR, Bolden-Watson C, et al. A placebo-controlled comparison of the effects on sexual functioning of bupropion sustained release and fluoxetine. Clin Ther. Jul. 2001;23(7):1040-58. [pmid: 11519769].
101 Feighner JP, Gardner EA, Johnston JA, et al. Double-blind comparison of bupropion and fluoxetine in depressed outpatients. J Clin Psychiatry. Aug. 1991;52(8):329-35. [pmid: 1907963].
102 Gillin JC, Rapaport M, Erman MK, et al. A comparison of nefazodone and fluoxetine on mood and on objective, subjective, and clinician-rated measures of sleep in depressed patients: a double-blind, 8-week clinical trial. J Clin Psychiatry. May. 1997;58(5):185-92. [pmid: 9184611].
103 Beasley CM Jr, Dornseif BE, Pultz JA, et al. Fluoxetine versus trazodone: efficacy and activating-sedating effects. J Clin Psychiatry. Jul. 1991;52(7):294-9. [pmid: 2071559].
104 Perry PJ, Garvey MJ, Kelly MW, et al. A comparative trial of fluoxetine versus trazodone in outpatients with major depression. J Clin Psychiatry. Aug. 1989;50(8):290-4. [pmid: 2668259].
105 Kennedy SH, Fulton KA, Bagby RM, et al. Sexual function during bupropion or paroxetine treatment of major depressive disorder. Can J Psychiatry. Mar. 2006;51(4):234-42. [pmid: 16629348].
106 Weihs KL, Settle EC Jr, Batey SR, et al. Bupropion sustained release versus paroxetine for the treatment of depression in the elderly. J Clin Psychiatry. Mar. 2000;61(3):196-202. [pmid: 10817105].
107 Baldwin DS, Hawley CJ, Abed RT, et al. A multicenter double-blind comparison of nefazodone and paroxetine in the treatment of outpatients with moderate-to-severe depression. J Clin Psychiatry. Suppl 2. 1996;57:46-52. [pmid: 8626363].
108 Hicks JA, Argyropoulos SV, Rich AS, et al. Randomised controlled study of sleep after nefazodone or paroxetine treatment in outpatients with depression. Br J Psychiatry. Jun. 2002;180:528-35. [pmid: 12042232].
109 Kasper S, Olivieri L, Di Loreto G, et al. A comparative, randomised, double-blind study of trazodone prolonged-release and paroxetine in the treatment of patients with major depressive disorder. Curr Med Res Opin. Aug. 2005;21(8):1139-46. [pmid: 16083521].
110 Coleman CC, Cunningham LA, Foster VJ, et al. Sexual dysfunction associated with the treatment of depression: a placebo-controlled comparison of bupropion sustained release and sertraline treatment. Ann Clin Psychiatry. Dec. 1999;11(4):205-15. [pmid: 10596735].
111 Croft H, Settle E Jr, Houser T, et al. A placebo-controlled comparison of the antidepressant efficacy and effects on sexual functioning of sustained-release bupropion and sertraline. Clin Ther. Apr. 1999;21(4):643-58. [pmid: 10363731].
112 Kavoussi RJ, Segraves RT, Hughes AR, et al. Double-blind comparison of bupropion sustained release and sertraline in depressed outpatients. J Clin Psychiatry. Dec. 1997;58(12):532-7. [pmid: 9448656].
113 Rush AJ, Trivedi MH, Carmody TJ, et al. Response in relation to baseline anxiety levels in major depressive disorder treated with bupropion sustained release or sertraline. Neuropsychopharmacology. Jul. 2001;25(1):131-8. [pmid: 11377926].
114 Feiger A, Kiev A, Shrivastava RK, et al. Nefazodone versus sertraline in outpatients with major depression: focus on efficacy, tolerability, and effects on sexual function and satisfaction. J Clin Psychiatry. Suppl 2. 1996;57:53-62. [pmid: 8626364].
115 Munizza C, Olivieri L, Di Loreto G, et al. A comparative, randomized, double-blind study of trazodone prolonged-release and sertraline in the treatment of major depressive disorder. Curr Med Res Opin. Sep. 2006;22(9):1703-13. [pmid: 16968574].
116 Tourian KA, Padmanabhan SK, Groark J, et al. Desvenlafaxine 50 and 100 mg/d in the treatment of major depressive disorder: an 8-week, phase III, multicenter, randomized, double-blind, placebo-controlled, parallel-group trial and a post hoc pooled analysis of three studies. Clin Ther. Jun. 2009;31(Pt 1):1405-23. [pmid: 19698901].
117 Benkert O, Szegedi A, Philipp M, et al. Mirtazapine orally disintegrating tablets versus venlafaxine extended release: a double-blind, randomized multicenter trial comparing the onset of antidepressant response in patients with major depressive disorder. J Clin Psychopharmacol. Feb. 2006;26(1):75-8. [pmid: 16415711].
118 Guelfi JD, Ansseau M, Timmerman L, et al. Mirtazapine versus venlafaxine in hospitalized severely depressed patients with melancholic features. J Clin Psychopharmacol. Aug. 2001;21(4):425-31. [pmid: 11476127].
119 Halikas JA. Org 3770 (mirtazapine) versus trazodone: A placebo controlled trial in depressed elderly patients. Hum Psychopharmacol. 1995;10(Suppl 2):S125-S33.
120 van Moffaert M, de Wilde J, Vereecken A, et al. Mirtazapine is more effective than trazodone: a double-blind controlled study in hospitalized patients with major depression. Int Clin Psychopharmacol. Mar. 1995;10(1):3-9. [pmid: 7622801].
121 Hewett K, Chrzanowski W, Schmitz M, et al. Eight-week, placebo-controlled, double-blind comparison of the antidepressant efficacy and tolerability of bupropion XR and venlafaxine XR. J Psychopharmacol. Jul. 2009;23(5):531-8. [pmid: 18635695].
122 Hewett K, Gee MD, Krishen A, et al. Double-blind, placebo-controlled comparison of the antidepressant efficacy and tolerability of bupropion XR and venlafaxine XR. J Psychopharmacol. Aug. 2010;24(8):1209-16. [pmid: 19939870].
123 Cunningham LA, Borison RL, Carman JS, et al. A comparison of venlafaxine, trazodone, and placebo in major depression. J Clin Psychopharmacol. Apr. 1994;14(2):99-106. [pmid: 8195464].
124 Weisler RH, Johnston JA, Lineberry CG, et al. Comparison of bupropion and trazodone for the treatment of major depression. J Clin Psychopharmacol. Jun. 1994;14(3):170-9. [pmid: 8027413].
125 Ravindran AV, Guelfi JD, Lane RM, et al. Treatment of dysthymia with sertraline: a double-blind, placebo-controlled trial in dysthymic patients without major depression. J Clin Psychiatry. Nov. 2000;61(11):821-7. [pmid: 11105734].
126 Vanelle JM, Attar-Levy D, Poirier MF, et al. Controlled efficacy study of fluoxetine in dysthymia. Br J Psychiatry. Apr. 1997;170:345-50. [pmid: 9246253].
127 Fava M, Judge R, Hoog SL, et al. Fluoxetine versus sertraline and paroxetine in major depressive disorder: changes in weight with long-term treatment. J Clin Psychiatry. Nov. 2000;61(11):863-7. [pmid: 11105740].
128 Kroenke K, West SL, Swindle R, et al. Similar effectiveness of paroxetine, fluoxetine, and sertraline in primary care: a randomized trial. JAMA. Dec. 19. 2001;286(23):2947-55. [pmid: 11743835].
129 Smith D, Dempster C, Glanville J, et al. Efficacy and tolerability of venlafaxine compared with selective serotonin reuptake inhibitors and other antidepressants: a meta-analysis. Br J Psychiatry. May. 2002;180:396-404. [pmid: 11983635].
130 Rush AJ, Armitage R, Gillin JC, et al. Comparative effects of nefazodone and fluoxetine on sleep in outpatients with major depressive disorder. Biol Psychiatry. Jul. 1. 1998;44(1):3-14. [pmid: 9646878].
131 Perahia DG, Pritchett YL, Kajdasz DK, et al. A randomized, double-blind comparison of duloxetine and venlafaxine in the treatment of patients with major depressive disorder. J Psychiatr Res. Jan. 2008;42(1):22-34. [pmid: 17445831].
132 Kocsis JH, Zisook S, Davidson J, et al. Double-blind comparison of sertraline, imipramine, and placebo in the treatment of dysthymia: psychosocial outcomes. Am J Psychiatry. Mar. 1997;154(3):390-5. [pmid: 9054788].
133 Thase ME, Fava M, Halbreich U, et al. A placebo-controlled, randomized clinical trial comparing sertraline and imipramine for the treatment of dysthymia. Arch Gen Psychiatry. Sep. 1996;53(9):777-84. [pmid: 8792754].
134 Williams JW Jr, Barrett J, Oxman T, et al. Treatment of dysthymia and minor depression in primary care: A randomized controlled trial in older adults. JAMA. Sep. 27. 2000;284(12):1519-26. [pmid: 11000645].
135 Barrett JE, Williams JW Jr, Oxman TE, et al. Treatment of dysthymia and minor depression in primary care: a randomized trial in patients aged 18 to 59 years. J Fam Pract. May. 2001;50(5):405-12. [pmid: 11350703].
136 Devanand DP, Nobler MS, Cheng J, et al. Randomized, double-blind, placebo-controlled trial of fluoxetine treatment for elderly patients with dysthymic disorder. Am J Geriatr Psychiatry. Jan. 2005;13(1):59-68. [pmid: 15653941].
137 Rocca P, Calvarese P, Faggiano F, et al. Citalopram versus sertraline in late-life nonmajor clinically significant depression: a 1-year follow-up clinical trial. J Clin Psychiatry. Mar. 2005;66(3):360-9. [pmid: 15766303].
138 Judd LL, Rapaport MH, Yonkers KA, et al. Randomized, placebo-controlled trial of fluoxetine for acute treatment of minor depressive disorder. Am J Psychiatry. Oct. 2004;161(10):1864-71. [pmid: 15465984].
139 Burke WJ, McArthur-Miller DA. Exploring treatment alternatives: weekly dosing of fluoxetine for the continuation phase of major depressive disorder. J Clin Psychiatry. Suppl 22. 2001;62:38-42. [pmid: 11599647].
140 Schmidt ME, Fava M, Robinson JM, et al. The efficacy and safety of a new enteric-coated formulation of fluoxetine given once weekly during the continuation treatment of major depressive disorder. J Clin Psychiatry. Nov. 2000;61(11):851-7. [pmid: 11105738].
141 Golden RN, Nemeroff CB, McSorley P, et al. Efficacy and tolerability of controlled-release and immediate-release paroxetine in the treatment of depression. J Clin Psychiatry. Jul. 2002;63(7):577-84. [pmid: 12143913].
142 Rapaport MH, Schneider LS, Dunner DL, et al. Efficacy of controlled-release paroxetine in the treatment of late-life depression. J Clin Psychiatry. Sep. 2003;64(9):1065-74. [pmid: 14628982].
143 Cunningham LA. Once-daily venlafaxine extended release (XR) and venlafaxine immediate release (IR) in outpatients with major depression. Venlafaxine XR 208 Study Group. Ann Clin Psychiatry. Sep. 1997;9(3):157-64. [pmid: 9339881].
144 Hansen R, Gaynes B, Thieda P, et al. Meta-analysis of major depressive disorder relapse and recurrence with second-generation antidepressants. Psychiatr Serv. Oct. 2008;59(10):1121-30. [pmid: 18832497].
145 Bauer M, Tharmanathan P, Volz HP, et al. The effect of venlafaxine compared with other antidepressants and placebo in the treatment of major depression: a meta-analysis. Eur Arch Psychiatry Clin Neurosci. Apr. 2009;259(3):172-85. [pmid: 19165525].
146 Franchini L, Gasperini M, Perez J, et al. A double-blind study of long-term treatment with sertraline or fluvoxamine for prevention of highly recurrent unipolar depression. J Clin Psychiatry. Mar. 1997;58(3):104-7. [pmid: 9108811].
147 Franchini L, Gasperini M, Zanardi R, et al. Four-year follow-up study of sertraline and fluvoxamine in long-term treatment of unipolar subjects with high recurrence rate. J Affect Disord. Jun. 2000;58(3):233-6. [pmid: 10802132].
148 Soares CN, Thase ME, Clayton A, et al. Desvenlafaxine and escitalopram for the treatment of postmenopausal women with major depressive disorder. Menopause. Jul. 2010;17(4):700-11. [pmid: 20539246].
149 Keller MB, Trivedi MH, Thase ME, et al. The Prevention of Recurrent Episodes of Depression with Venlafaxine for Two Years (PREVENT) study: outcomes from the acute and continuation phases. Biol Psychiatry. Dec. 15. 2007;62(12):1371-9. [pmid: 17825800].
150 Lin CH, Lin KS, Lin CY, et al. Time to rehospitalization in patients with major depressive disorder taking venlafaxine or fluoxetine. J Clin Psychiatry. Jan. 2008;69(1):54-9. [pmid: 18312038].
151 Weihs KL, Houser TL, Batey SR, et al. Continuation phase treatment with bupropion SR effectively decreases the risk for relapse of depression. Biol Psychiatry. May. 1. 2002;51(9):753-61. [pmid: 11983189].
152 Montgomery SA, Dunbar G. Paroxetine is better than placebo in relapse prevention and the prophylaxis of recurrent depression. Int Clin Psychopharmacol. Fall. 1993;8(3):189-95. [pmid: 8263317].
153 Robert P, Montgomery SA. Citalopram in doses of 20-60 mg is effective in depression relapse prevention: a placebo-controlled 6 month study. Int Clin Psychopharmacol. Mar. Suppl 1. 1995;10:29-35. [pmid: 7622809].
154 Rapaport MH, Bose A, Zheng H. Escitalopram continuation treatment prevents relapse of depressive episodes. J Clin Psychiatry. Jan. 2004;65(1):44-9. [pmid: 14744167].
155 Reimherr FW, Amsterdam JD, Quitkin FM, et al. Optimal length of continuation therapy in depression: a prospective assessment during long-term fluoxetine treatment. Am J Psychiatry. Sep. 1998;155(9):1247-53. [pmid: 9734550].
156 Dinan TG. Efficacy and safety of weekly treatment with enteric-coated fluoxetine in patients with major depressive disorder. J Clin Psychiatry. Suppl 22. 2001;62:48-52. [pmid: 11599649].
157 Thase ME, Nierenberg AA, Keller MB, et al. Efficacy of mirtazapine for prevention of depressive relapse: a placebo-controlled double-blind trial of recently remitted high-risk patients. J Clin Psychiatry. Oct. 2001;62(10):782-8. [pmid: 11816867].
158 Feiger AD, Bielski RJ, Bremner J, et al. Double-blind, placebo-substitution study of nefazodone in the prevention of relapse during continuation treatment of outpatients with major depression. Int Clin Psychopharmacol. Jan. 1999;14(1):19-28. [pmid: 10221638].
159 Doogan DP, Caillard V. Sertraline in the prevention of depression. Br J Psychiatry. Feb. 1992;160:217-22. [pmid: 1540762].
160 Simon JS, Aguiar LM, Kunz NR, et al. Extended-release venlafaxine in relapse prevention for patients with major depressive disorder. J Psychiatr Res. May-Jun. 2004;38(3):249-57. [pmid: 15003430].
161 Perahia DG, Gilaberte I, Wang F, et al. Duloxetine in the prevention of relapse of major depressive disorder: double-blind placebo-controlled study. Br J Psychiatry. Apr. 2006;188:346-53. [pmid: 16582061].
162 Fava M, Detke MJ, Balestrieri M, et al. Management of depression relapse: reinitiation of duloxetine treatment or dose increase. J Psychiatr Res. Jun. 2006;40(4):328-36. [pmid: 16678205].
163 Gorwood P, Weiller E, Lemming O, et al. Escitalopram prevents relapse in older patients with major depressive disorder. Am J Geriatr Psychiatry. Jul. 2007;15(7):581-93. [pmid: 17586783].
164 Kamijima K, Burt T, Cohen G, et al. A placebo-controlled, randomized withdrawal study of sertraline for major depressive disorder in Japan. Int Clin Psychopharmacol. Jan. 2006;21(1):1-9. [pmid: 16317311].
165 Hochstrasser B, Isaksen PM, Koponen H, et al. Prophylactic effect of citalopram in unipolar, recurrent depression: placebo-controlled study of maintenance therapy. Br J Psychiatry. Apr. 2001;178:304-10. [pmid: 11282808].
166 Klysner R, Bent-Hansen J, Hansen HL, et al. Efficacy of citalopram in the prevention of recurrent depression in elderly patients: placebo-controlled study of maintenance therapy. Br J Psychiatry. Jul. 2002;181:29-35. [pmid: 12091260].
167 Gilaberte I, Montejo AL, de la Gandara J, et al. Fluoxetine in the prevention of depressive recurrences: a double-blind study. J Clin Psychopharmacol. Aug. 2001;21(4):417-24. [pmid: 11476126].
168 Terra JL, Montgomery SA. Fluvoxamine prevents recurrence of depression: results of a long-term, double-blind, placebo-controlled study. Int Clin Psychopharmacol. Mar. 1998;13(2):55-62. [pmid: 9669185].
169 Gelenberg AJ, Trivedi MH, Rush AJ, et al. Randomized, placebo-controlled trial of nefazodone maintenance treatment in preventing recurrence in chronic depression. Biol Psychiatry. Oct. 15. 2003;54(8):806-17. [pmid: 14550680].
170 Claghorn JL, Feighner JP. A double-blind comparison of paroxetine with imipramine in the long-term treatment of depression. J Clin Psychopharmacol. Dec. 1993;13(6 Suppl 2):23S-7S. [pmid: 8106652].
171 Keller MB, Kocsis JH, Thase ME, et al. Maintenance phase efficacy of sertraline for chronic depression: a randomized controlled trial. JAMA. Nov. 18. 1998;280(19):1665-72. [pmid: 9831997].
172 Kocsis JH, Schatzberg A, Rush AJ, et al. Psychosocial outcomes following long-term, double-blind treatment of chronic depression with sertraline vs placebo. Arch Gen Psychiatry. Aug. 2002;59(8):723-8. [pmid: 12150648].
173 Lepine JP, Caillard V, Bisserbe JC, et al. A randomized, placebo-controlled trial of sertraline for prophylactic treatment of highly recurrent major depressive disorder. Am J Psychiatry. May. 2004;161(5):836-42. [pmid: 15121648].
174 Wilson KC, Mottram PG, Ashworth L, et al. Older community residents with depression: long-term treatment with sertraline. Randomised, double-blind, placebo-controlled study. Br J Psychiatry. Jun. 2003;182:492-7. [pmid: 12777339].
175 Montgomery SA, Entsuah R, Hackett D, et al. Venlafaxine versus placebo in the preventive treatment of recurrent major depression. J Clin Psychiatry. Mar. 2004;65(3):328-36. [pmid: 15096071].
176 Rickels K, Montgomery SA, Tourian KA, et al. Desvenlafaxine for the prevention of relapse in major depressive disorder: results of a randomized trial. J Clin Psychopharmacol. Feb. 2010;30(1):18-24. [pmid: 20075643].
177 Perahia DG, Maina G, Thase ME, et al. Duloxetine in the prevention of depressive recurrences: a randomized, double-blind, placebo-controlled trial. J Clin Psychiatry. May. 2009;70(5):706-16. [pmid: 19552867].
178 Kornstein SG, Bose A, Li D, et al. Escitalopram maintenance treatment for prevention of recurrent depression: a randomized, placebo-controlled trial. J Clin Psychiatry. Nov. 2006;67(11):1767-75. [pmid: 17196058].
179 McGrath PJ, Stewart JW, Quitkin FM, et al. Predictors of relapse in a prospective study of fluoxetine treatment of major depression. Am J Psychiatry. Sep. 2006;163(9):1542-8. [pmid: 16946178].
180 Reynolds CF 3rd, Dew MA, Pollock BG, et al. Maintenance treatment of major depression in old age. N Engl J Med. Mar. 16. 2006;354(11):1130-8. [pmid: 16540613].
181 Lustman PJ, Clouse RE, Nix BD, et al. Sertraline for prevention of depression recurrence in diabetes mellitus: a randomized, double-blind, placebo-controlled trial. Arch Gen Psychiatry. May. 2006;63(5):521-9. [pmid: 16651509].
182 Kocsis JH, Thase ME, Trivedi MH, et al. Prevention of recurrent episodes of depression with venlafaxine ER in a 1-year maintenance phase from the PREVENT Study. J Clin Psychiatry. Jul. 2007;68(7):1014-23. [pmid: 17685736].
183 Keller MB, Trivedi MH, Thase ME, et al. The Prevention of Recurrent Episodes of Depression with Venlafaxine for Two Years (PREVENT) Study: Outcomes from the 2-year and combined maintenance phases. J Clin Psychiatry. Aug. 2007;68(8):1246-56. [pmid: 17854250].
184 Kornstein SG. Maintenance therapy to prevent recurrence of depression: summary and implications of the PREVENT study. Expert Rev Neurother. May. 2008;8(5):737-42. [pmid: 18457530].
185 Kornstein SG, Kocsis JH, Ahmed S, et al. Assessing the efficacy of 2 years of maintenance treatment with venlafaxine extended release 75-225 mg/day in patients with recurrent major depression: a secondary analysis of data from the PREVENT study. Int Clin Psychopharmacol. Nov. 2008;23(6):357-63. [pmid: 18854724].
186 Fava M, Wiltse C, Walker D, et al. Predictors of relapse in a study of duloxetine treatment in patients with major depressive disorder. J Affect Disord. Mar. 2009;113(3):263-71. [pmid: 18625521].
187 Thase ME, Gelenberg A, Kornstein SG, et al. Comparing venlafaxine extended release and fluoxetine for preventing the recurrence of major depression: Results from the PREVENT study. J Psychiatr Res. 2010. Aug. 28. [pmid: 20801464].
188 Montgomery SA, Rasmussen JG. Citalopram 20 mg, citalopram 40 mg and placebo in the prevention of relapse of major depression. Int Clin Psychopharmacol. Jun. 1992;8:181-8. [pmid: 1431025].
189 Montgomery SA, Rasmussen JG, Lyby K, et al. Dose response relationship of citalopram 20 mg, citalopram 40 mg and placebo in the treatment of moderate and severe depression. Int Clin Psychopharmacol. Jun. Suppl 5. 1992;6:65-70. [pmid: 1431024].
190 Michelson D, Amsterdam JD, Quitkin FM, et al. Changes in weight during a 1-year trial of fluoxetine. Am J Psychiatry. Aug. 1999;156(8):1170-6. [pmid: 10450256].
191 Baldomero EB, Ubago JG, Cercos CL, et al. Venlafaxine extended release versus conventional antidepressants in the remission of depressive disorders after previous antidepressant failure: ARGOS study. Depress Anxiety. Aug. 10. 2005;22(2):68-76. [pmid: 16094658].
192 Poirier MF, Boyer P. Venlafaxine and paroxetine in treatment-resistant depression. Double-blind, randomised comparison. Br J Psychiatry. Jul. 1999;175:12-6. [pmid: 10621762].
193 Fang Y, Yuan C, Xu Y, et al. Comparisons of the efficacy and tolerability of extended-release venlafaxine, mirtazapine, and paroxetine in treatment-resistant depression: a double-blind, randomized pilot study in a Chinese population. J Clin Psychopharmacol. Aug. 2010;30(4):357-64. [pmid: 20571433].
194 Rush AJ, Trivedi MH, Wisniewski SR, et al. Bupropion-SR, sertraline, or venlafaxine-XR after failure of SSRIs for depression. N Engl J Med. Mar. 23. 2006;354(12):1231-42. [pmid: 16554525].
195 Rush AJ, Trivedi MH, Wisniewski SR, et al. Acute and Longer-Term Outcomes in Depressed Outpatients Requiring One or Several Treatment Steps: A STAR*D Report. Am J Psychiatry. Nov. 2006;163(11):1905-17. [pmid: 17074942].
196 Lenox-Smith AJ, Jiang Q. Venlafaxine extended release versus citalopram in patients with depression unresponsive to a selective serotonin reuptake inhibitor. Int Clin Psychopharmacol. 2008;23(3):113-9. [pmid: 18408525].
197 Corya SA, Williamson D, Sanger TM, et al. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, fluoxetine, and venlafaxine in treatment-resistant depression. Depress Anxiety. 2006;23(6):364-72. [pmid: 16710853].
198 Trivedi MH, Fava M, Wisniewski SR, et al. Medication augmentation after the failure of SSRIs for depression. N Engl J Med. Mar. 23. 2006;354(12):1243-52. [pmid: 16554526].
199 Gaynes BN, Rush AJ, Trivedi M, et al. A direct comparison of presenting characteristics of depressed outpatients from primary vs. specialty care settings: preliminary findings from the STAR*D clinical trial. Gen Hosp Psychiatry. Mar-Apr. 2005;27(2):87-96. [pmid: 15763119].
200 Gaynes BN, Rush AJ, Trivedi MH, et al. Major depression symptoms in primary care and psychiatric care settings: a cross-sectional analysis. Ann Fam Med. Mar-Apr. 2007;5(2):126-34. [pmid: 17389536].
201 Fava M, Rosenbaum JF, Hoog SL, et al. Fluoxetine versus sertraline and paroxetine in major depression: tolerability and efficacy in anxious depression. J Affect Disord. Aug. 2000;59(2):119-26. [pmid: 10837880].
202 Flament MF, Lane RM, Zhu R, et al. Predictors of an acute antidepressant response to fluoxetine and sertraline. Int Clin Psychopharmacol. Sep. 1999;14(5):259-75. [pmid: 10529069].
203 Boulenger JP, Hermes A, Huusom AK, et al. Baseline anxiety effect on outcome of SSRI treatment in patients with severe depression: escitalopram vs paroxetine. Curr Med Res Opin. Mar. 2010;26(3):605-14. [pmid: 20067433].
204 Brannan SK, Mallinckrodt CH, Brown EB, et al. Duloxetine 60 mg once-daily in the treatment of painful physical symptoms in patients with major depressive disorder. J Psychiatr Res. Jan. 2005;39(1):43-53. [pmid: 15504423].
205 Detke MJ, Lu Y, Goldstein DJ, et al. Duloxetine, 60 mg once daily, for major depressive disorder: a randomized double-blind placebo-controlled trial. J Clin Psychiatry. Apr. 2002;63(4):308-15. [pmid: 12000204].
206 Detke MJ, Lu Y, Goldstein DJ, et al. Duloxetine 60 mg once daily dosing versus placebo in the acute treatment of major depression. J Psychiatr Res. Nov-Dec. 2002;36(6):383-90. [pmid: 12393307].
207 Brecht S, Courtecuisse C, Debieuvre C, et al. Efficacy and safety of duloxetine 60 mg once daily in the treatment of pain in patients with major depressive disorder and at least moderate pain of unknown etiology: a randomized controlled trial. J Clin Psychiatry. Nov. 2007;68(11):1707-16. [pmid: 18052564].
208 Raskin J, Xu JY, Kajdasz DK. Time to response for duloxetine 60 mg once daily versus placebo in elderly patients with major depressive disorder. Int Psychogeriatr. Apr. 2008;20(2):309-27. [pmid: 17588276].
209 Khan A, Upton GV, Rudolph RL, et al. The use of venlafaxine in the treatment of major depression and major depression associated with anxiety: a dose-response study. Venlafaxine Investigator Study Group. J Clin Psychopharmacol. Feb. 1998;18(1):19-25. [pmid: 9472838].
210 Jefferson JW, Rush AJ, Nelson JC, et al. Extended-release bupropion for patients with major depressive disorder presenting with symptoms of reduced energy, pleasure, and interest: findings from a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Jun. 2006;67(6):865-73. [pmid: 16848645].
211 McCall WV, Blocker JN, D'Agostino R Jr, et al. Treatment of insomnia in depressed insomniacs: Effects on health-related quality of life, objective and self-reported sleep, and depression. Journal of Clinical Sleep Medicine. 2010;6(4):322-9. [pmid: 20726279].
212 Fava M, McCall WV, Krystal A, et al. Eszopiclone co-administered with fluoxetine in patients with insomnia coexisting with major depressive disorder. Biol Psychiatry. Jun. 1. 2006;59(11):1052-60. [pmid: 16581036].
213 Clerc GE, Ruimy P, Verdeau-Palles J. A double-blind comparison of venlafaxine and fluoxetine in patients hospitalized for major depression and melancholia. The Venlafaxine French Inpatient Study Group. Int Clin Psychopharmacol. Sep. 1994;9(3):139-43. [pmid: 7814822].
214 Ashman TA, Cantor JB, Gordon WA, et al. A randomized controlled trial of sertraline for the treatment of depression in persons with traumatic brain injury. Arch Phys Med Rehabil. May. 2009;90(5):733-40. [pmid: 19406291].
215 Garakani A, Martinez JM, Marcus S, et al. A randomized, double-blind, and placebo-controlled trial of quetiapine augmentation of fluoxetine in major depressive disorder. Int Clin Psychopharmacol. Sep. 2008;23(5):269-75. [pmid: 18703936].
216 Goldstein DJ, Lu Y, Detke MJ, et al. Duloxetine in the treatment of depression: a double-blind placebo-controlled comparison with paroxetine. J Clin Psychopharmacol. Aug. 2004;24(4):389-99. [pmid: 15232330].
217 Spielmans GI. Duloxetine does not relieve painful physical symptoms in depression: a meta-analysis. Psychother Psychosom. 2008;77(1):12-6. [pmid: 18087203].
218 Krebs EE, Gaynes BN, Gartlehner G, et al. Treating the physical symptoms of depression with second-generation antidepressants: a systematic review and metaanalysis. Psychosomatics. May-Jun. 2008;49(3):191-8. [pmid: 18448772].
219 Raskin J, Wiltse CG, Siegal A, et al. Efficacy of duloxetine on cognition, depression, and pain in elderly patients with major depressive disorder: an 8-week, double-blind, placebo-controlled trial. Am J Psychiatry. Jun. 2007;164(6):900-9. [pmid: 17541049].
220 U.S. Food and Drug Administration. Guidance for Industry and Investigators. Safety Reporting Requirements for INDs and BA/BE Studies. Draft Guidance. Rockville, MD. U. S. Food and Drug Administration. September. 29. 2010. www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/UCM227351.pdf.
221 Cipriani A, La Ferla T, Furukawa TA, et al. Sertraline versus other antidepressive agents for depression. Cochrane Database Syst Rev. 2010;(4):CD006117. [pmid: 20393946].
222 Brambilla P, Cipriani A, Hotopf M, et al. Side-effect profile of fluoxetine in comparison with other SSRIs, tricyclic and newer antidepressants: a meta-analysis of clinical trial data. Pharmacopsychiatry. Mar. 2005;38(2):69-77. [pmid: 15744630].
223 Mackay FR, Dunn NR, Martin RM, et al. Newer antidepressants: a comparison of tolerability in general practice. Br J Gen Pract. Nov. 1999;49(448):892-6. [pmid: 10818655].
224 Mackay FJ, Dunn NR, Mann RD. Antidepressants and the serotonin syndrome in general practice. Br J Gen Pract. Nov. 1999;49(448):871-4. [pmid: 10818650].
225 Meijer WE, Heerdink ER, van Eijk JT, et al. Adverse events in users of sertraline: results from an observational study in psychiatric practice in The Netherlands. Pharmacoepidemiol Drug Saf. Dec. 2002;11(8):655-62. [pmid: 12512241].
226 Greist J, McNamara RK, Mallinckrodt CH, et al. Incidence and duration of antidepressant-induced nausea: duloxetine compared with paroxetine and fluoxetine. Clin Ther. Sep. 2004;26(9):1446-55. [pmid: 15531007].
227 Kasper S, Baldwin DS, Larsson Lonn S, et al. Superiority of escitalopram to paroxetine in the treatment of depression. Eur Neuropsychopharmacol. 2009;19(4):229-37. [pmid: 19185467].
228 Wise TN, Perahia DGS, Pangallo BA, et al. Effects of the antidepressant duloxetine on body weight: Analyses of 10 clinical studies. Primary Care Companion to the Journal of Clinical Psychiatry. 2006;8(5):269-78.
229 Goldstein DJ, Hamilton SH, Masica DN, et al. Fluoxetine in medically stable, depressed geriatric patients: effects on weight. J Clin Psychopharmacol. Oct. 1997;17(5):365-9. [pmid: 9315987].
230 Croft H, Houser TL, Jamerson BD, et al. Effect on body weight of bupropion sustained-release in patients with major depression treated for 52 weeks. Clin Ther. Apr. 2002;24(4):662-72. [pmid: 12017410].
231 Judge R, Parry MG, Quail D, et al. Discontinuation symptoms: comparison of brief interruption in fluoxetine and paroxetine treatment. Int Clin Psychopharmacol. Sep. 2002;17(5):217-25. [pmid: 12177584].
232 Montgomery SA, Andersen HF. Escitalopram versus venlafaxine XR in the treatment of depression. Int Clin Psychopharmacol. Sep. 2006;21(5):297-309. [pmid: 16877901].
233 Expert Working Group of the Committee on Safety of Medicines (CSM). Report of the CSM expert working group on the safety of selective serotonin reuptake inhibitor antidepressants. United Kingdom. Author. 2004.
234 Zajecka J, Fawcett J, Amsterdam J, et al. Safety of abrupt discontinuation of fluoxetine: a randomized, placebo-controlled study. J Clin Psychopharmacol. Jun. 1998;18(3):193-7. [pmid: 9617977].
235 Perahia DG, Kajdasz DK, Desaiah D, et al. Symptoms following abrupt discontinuation of duloxetine treatment in patients with major depressive disorder. J Affect Disord. Dec. 2005;89(1-3):207-12. [pmid: 16266753].
236 Mackay FJ, Dunn NR, Wilton LV, et al. A comparison of fluvoxamine, fluoxetine, sertraline and paroxetine examined by observational cohort studies. Pharmacoepidemiol Drug Saf. Jul. 1997;6(4):235-46. [pmid: 15073774].
237 Clayton AH, Croft HA, Horrigan JP, et al. Bupropion extended release compared with escitalopram: effects on sexual functioning and antidepressant efficacy in 2 randomized, double-blind, placebo-controlled studies. J Clin Psychiatry. May. 2006;67(5):736-46. [pmid: 16841623].
238 Fergusson D, Doucette S, Glass KC, et al. Association between suicide attempts and selective serotonin reuptake inhibitors: systematic review of randomised controlled trials. BMJ. Feb. 19. 2005;330(7488):396. [pmid: 15718539].
239 Martinez C, Rietbrock S, Wise L, et al. Antidepressant treatment and the risk of fatal and non-fatal self harm in first episode depression: nested case-control study. BMJ. Feb. 19. 2005;330(7488):389. [pmid: 15718538].
240 Gunnell D, Saperia J, Ashby D. Selective serotonin reuptake inhibitors (SSRIs) and suicide in adults: meta-analysis of drug company data from placebo controlled, randomised controlled trials submitted to the MHRA's safety review. BMJ. Feb. 19. 2005;330(7488):385. [pmid: 15718537].
241 Didham RC, McConnell DW, Blair HJ, et al. Suicide and self-harm following prescription of SSRIs and other antidepressants: confounding by indication. Br J Clin Pharmacol. Nov. 2005;60(5):519-25. [pmid: 16236042].
242 Jick H, Kaye JA, Jick SS. Antidepressants and the risk of suicidal behaviors. JAMA. Jul. 21. 2004;292(3):338-43. [pmid: 15265848].
243 Jick SS, Dean AD, Jick H. Antidepressants and suicide. BMJ. Jan. 28. 1995;310(6974):215-8. [pmid: 7677826].
244 Jick H, Ulcickas M, Dean A. Comparison of frequencies of suicidal tendencies among patients receiving fluoxetine, lofepramine, mianserin, or trazodone. Pharmacotherapy. 1992;12(6):451-4. [pmid: 1492009].
245 Aursnes I, Tvete IF, Gaasemyr J, et al. Suicide attempts in clinical trials with paroxetine randomised against placebo. BMC Med. Aug. 22. 2005;3:14. [pmid: 16115311].
246 Khan A, Khan S, Kolts R, et al. Suicide rates in clinical trials of SSRIs, other antidepressants, and placebo: analysis of FDA reports. Am J Psychiatry. Apr. 2003;160(4):790-2. [pmid: 12668373].
247 Lopez-Iibor JJ. Reduced suicidality with paroxetine. European Psychiatry. 1993;8(Suppl 1):17S-9S.
248 Olfson M, Marcus SC. A case-control study of antidepressants and attempted suicide during early phase treatment of major depressive episodes. J Clin Psychiatry. 2008;69(3):425-32. [pmid: 18294025].
249 Barbui C, Esposito E, Cipriani A. Selective serotonin reuptake inhibitors and risk of suicide: A systematic review of observational studies. Can Med Assoc J. 2009;180(3):291-7. [pmid: 19188627].
250 Schneeweiss S, Patrick AR, Solomon DH, et al. Variation in the risk of suicide attempts and completed suicides by antidepressant agent in adults: a propensity score-adjusted analysis of 9 years' data. Arch Gen Psychiatry. May. 2010;67(5):497-506. [pmid: 20439831].
251 Rahme E, Dasgupta K, Turecki G, et al. Risks of suicide and poisoning among elderly patients prescribed selective serotonin reuptake inhibitors: a retrospective cohort study. J Clin Psychiatry. Mar. 2008;69(3):349-57. [pmid: 18278986].
252 Friedman RA, Leon AC. Expanding the black box - depression, antidepressants, and the risk of suicide. N Engl J Med. 2007;356(23):2343-6. [pmid: 17485726].
253 Pedersen AG. Escitalopram and suicidality in adult depression and anxiety. Int Clin Psychopharmacol. May. 2005;20(3):139-43. [pmid: 15812263].
254 Montejo AL, Llorca G, Izquierdo JA, et al. Incidence of sexual dysfunction associated with antidepressant agents: a prospective multicenter study of 1022 outpatients. Spanish Working Group for the Study of Psychotropic-Related Sexual Dysfunction. J Clin Psychiatry. Suppl 3. 2001;62:10-21. [pmid: 11229449].
255 Philipp M, Tiller JW, Baier D, et al. Comparison of moclobemide with selective serotonin reuptake inhibitors (SSRIs) on sexual function in depressed adults. The Australian and German Study Groups. Eur Neuropsychopharmacol. Sep. 2000;10(5):305-14. [pmid: 10974600].
256 Kennedy SH, Eisfeld BS, Dickens SE, et al. Antidepressant-induced sexual dysfunction during treatment with moclobemide, paroxetine, sertraline, and venlafaxine. J Clin Psychiatry. Apr. 2000;61(4):276-81. [pmid: 10830148].
257 Ferguson JM, Shrivastava RK, Stahl SM, et al. Reemergence of sexual dysfunction in patients with major depressive disorder: double-blind comparison of nefazodone and sertraline. J Clin Psychiatry. Jan. 2001;62(1):24-9. [pmid: 11235924].
258 Clayton A, Kornstein S, Prakash A, et al. Changes in sexual functioning associated with duloxetine, escitalopram, and placebo in the treatment of patients with major depressive disorder. J Sex Med. Jul. 2007;4(4 Pt 1):917-29. [pmid: 17627739].
259 Delgado PL, Brannan SK, Mallinckrodt CH, et al. Sexual functioning assessed in 4 double-blind placebo- and paroxetine-controlled trials of duloxetine for major depressive disorder. J Clin Psychiatry. Jun. 2005;66(6):686-92. [pmid: 15960560].
260 Segraves RT, Kavoussi R, Hughes AR, et al. Evaluation of sexual functioning in depressed outpatients: a double-blind comparison of sustained-release bupropion and sertraline treatment. J Clin Psychopharmacol. Apr. 2000;20(2):122-8. [pmid: 10770448].
261 Nieuwstraten CE, Dolovich LR. Bupropion versus selective serotonin-reuptake inhibitors for treatment of depression. Ann Pharmacother. Dec. 2001;35(12):1608-13. [pmid: 11793630].
262 Clayton AH, Pradko JF, Croft HA, et al. Prevalence of sexual dysfunction among newer antidepressants. J Clin Psychiatry. Apr. 2002;63(4):357-66. [pmid: 12000211].
263 Whyte IM, Dawson AH, Buckley NA. Relative toxicity of venlafaxine and selective serotonin reuptake inhibitors in overdose compared to tricyclic antidepressants. QJM. May. 2003;96(5):369-74. [pmid: 12702786].
264 Dunner DL, Zisook S, Billow AA, et al. A prospective safety surveillance study for bupropion sustained-release in the treatment of depression. J Clin Psychiatry. Jul. 1998;59(7):366-73. [pmid: 9714265].
265 Johnston JA, Lineberry CG, Ascher JA, et al. A 102-center prospective study of seizure in association with bupropion. J Clin Psychiatry. Nov. 1991;52(11):450-6. [pmid: 1744061].
266 Martinez C, Assimes TL, Mines D, et al. Use of venlafaxine compared with other antidepressants and the risk of sudden cardiac death or near death: a nested case-control study. BMJ. 340:c249. [pmid: 20139216].
267 Vestergaard P, Rejnmark L, Mosekilde L. Selective serotonin reuptake inhibitors and other antidepressants and risk of fracture. Calcif Tissue Int. 2008;82(2):92-101. [pmid: 18219438].
268 Buckley NA, McManus PR. Fatal toxicity of serotoninergic and other antidepressant drugs: analysis of United Kingdom mortality data. BMJ. Dec. 7. 2002;325(7376):1332-3. [pmid: 12468481].
269 Thapa PB, Gideon P, Cost TW, et al. Antidepressants and the risk of falls among nursing home residents. N Engl J Med. Sep. 24. 1998;339(13):875-82. [pmid: 9744971].
270 Andersohn F, Schade R, Suissa S, et al. Long-term use of antidepressants for depressive disorders and the risk of diabetes mellitus. Am J Psychiatry. May. 2009;166(5):591-8. [pmid: 19339356].
271 Aursnes I, Gjertsen MK. Common adverse events associated with an SSRI: meta-analysis of early paroxetine data. Pharmacoepidemiol Drug Saf. Jul. 2008;17(7):707-13. [pmid: 18383561].
272 Ekselius L, von Knorring L. Effect on sexual function of long-term treatment with selective serotonin reuptake inhibitors in depressed patients treated in primary care. J Clin Psychopharmacol. Apr. 2001;21(2):154-60. [pmid: 11270911].
273 Chen Y, Guo JJ, Li H, et al. Risk of cerebrovascular events associated with antidepressant use in patients with depression: A population-based, nested case-control study. Ann Pharmacother. 2008;42(2):177-84. [pmid: 18212255].
274 Trifirò G, Dieleman J, Sen EF, et al. Risk of ischemic stroke associated with antidepressant drug use in elderly persons. J Clin Psychopharmacol. 2010;30(3):252-8. [pmid: 20473059].
275 Jick SS, Li L. Antidepressant drug use and risk of venous thromboembolism. Pharmacotherapy. 2008;28(2):144-50. [pmid: 18225961].
276 Ziere G, Dieleman JP, Van Der Cammen TJM, et al. Selective serotonin reuptake inhibiting antidepressants are associated with an increased risk of nonvertebral fractures. J Clin Psychopharmacol. 2008;28(4):411-7. [pmid: 18626268].
277 Barbui C, Andretta M, De Vitis G, et al. Antidepressant drug prescription and risk of abnormal bleeding: A case-control study. J Clin Psychopharmacol. 2009;29(1):33-8. [pmid: 19142104].
278 Targownik LE, Bolton JM, Metge CJ, et al. Selective serotonin reuptake inhibitors are associated with a modest increase in the risk of upper gastrointestinal bleeding. Am J Gastroenterol. Jun. 2009;104(6):1475-82. [pmid: 19491861].
279 de Abajo FJ, Garcia-Rodriguez LA. Risk of upper gastrointestinal tract bleeding associated with selective serotonin reuptake inhibitors and venlafaxine therapy: interaction with nonsteroidal anti-inflammatory drugs and effect of acid-suppressing agents. Arch Gen Psychiatry. Jul. 2008;65(7):795-803. [pmid: 18606952].
280 Stewart DE. Hepatic adverse reactions associated with nefazodone. Can J Psychiatry. 2002. May. 2002;47(4):375-7. [pmid: 12025437].
281 Strombom I, Wernicke JF, Seeger J, et al. Hepatic effects of duloxetine-III: analysis of hepatic events using external data sources. Curr Drug Saf. May. 2008;3(2):154-62. [pmid: 18690993].
282 Kirby D, Harrigan S, Ames D. Hyponatraemia in elderly psychiatric patients treated with Selective Serotonin Reuptake Inhibitors and venlafaxine: a retrospective controlled study in an inpatient unit. Int J Geriatr Psychiatry. Mar. 2002;17(3):231-7. [pmid: 11921151].
283 Liu BA, Mittmann N, Knowles SR, et al. Hyponatremia and the syndrome of innappropriate secretion of antidiuretic hormone associated with the use of selective serotonin reuptake inhibitors: a review of spontaneous reports. CMAJ. 1996. Sep. 1996;155(5):519-27. [pmid: 8804257].
284 Mason PJ, Morris VA, Balcezak TJ. Serotonin syndrome Presentation of 2 cases and review of the literature. Medicine (Baltimore). Jul. 2000;79(4):201-9. [pmid: 10941349].
285 Cramer JA, Roy A, Burrell A, et al. Medication compliance and persistence: terminology and definitions. Value Health. Jan-Feb. 2008;11(1):44-7. [pmid: 18237359].
286 Petrakis I, Carroll KM, Nich C, et al. Fluoxetine treatment of depressive disorders in methadone-maintained opioid addicts. Drug Alcohol Depend. May. 1. 1998;50(3):221-6. [pmid: 9649975].
287 Claxton A, de Klerk E, Parry M, et al. Patient compliance to a new enteric-coated weekly formulation of fluoxetine during continuation treatment of major depressive disorder. J Clin Psychiatry. Dec. 2000;61(12):928-32. [pmid: 11206598].
288 Stang P, Young S, Hogue S. Better patient persistence with once-daily bupropion compared with twice-daily bupropion. Am J Ther. Jan-Feb. 2007;14(1):20-4. [pmid: 17303971].
289 Doraiswamy PM, Khan ZM, Donahue RM, et al. Quality of life in geriatric depression: a comparison of remitters, partial responders, and nonresponders. Am J Geriatr Psychiatry. Fall. 2001;9(4):423-8. [pmid: 11739069].
290 Geretsegger C, Bohmer F, Ludwig M. Paroxetine in the elderly depressed patient: randomized comparison with fluoxetine of efficacy, cognitive and behavioural effects. Int Clin Psychopharmacol. Spring. 1994;9(1):25-9. [pmid: 8195578].
291 Schatzberg A, Roose S. A double-blind, placebo-controlled study of venlafaxine and fluoxetine in geriatric outpatients with major depression. Am J Geriatr Psychiatry. Apr. 2006;14(4):361-70. [pmid: 16582045].
292 Echeverry D, Duran P, Bonds C, et al. Effect of pharmacological treatment of depression on A1C and quality of life in low-income hispanics and African Americans with diabetes: A randomized, double-blind, placebo-controlled trial. Diabetes Care. 2009;32(12):2156-60. [pmid: 19729522].
293 Rabkin JG, Wagner GJ, McElhiney MC, et al. Testosterone versus fluoxetine for depression and fatigue in HIV/AIDS: a placebo-controlled trial. J Clin Psychopharmacol. Aug. 2004;24(4):379-85. [pmid: 15232328].
294 Rabkin JG, Wagner GJ, Rabkin R. Fluoxetine treatment for depression in patients with HIV and AIDS: a randomized, placebo-controlled trial. Am J Psychiatry. Jan. 1999;156(1):101-7. [pmid: 9892304].
295 Gual A, Balcells M, Torres M, et al. Sertraline for the prevention of relapse in detoxicated alcohol dependent patients with a comorbid depressive disorder: a randomized controlled trial. Alcohol Alcohol. Nov-Dec. 2003;38(6):619-25. [pmid: 14633652].
296 Hernandez-Avila CA, Modesto-Lowe V, Feinn R, et al. Nefazodone treatment of comorbid alcohol dependence and major depression. Alcohol Clin Exp Res. Mar. 2004;28(3):433-40. [pmid: 15084901].
297 Moak DH, Anton RF, Latham PK, et al. Sertraline and cognitive behavioral therapy for depressed alcoholics: results of a placebo-controlled trial. J Clin Psychopharmacol. Dec. 2003;23(6):553-62. [pmid: 14624185].
298 Lyketsos CG, DelCampo L, Steinberg M, et al. Treating depression in Alzheimer disease: efficacy and safety of sertraline therapy, and the benefits of depression reduction: the DIADS. Arch Gen Psychiatry. Jul. 2003;60(7):737-46. [pmid: 12860778].
299 Glassman AH, O'Connor CM, Califf RM, et al. Sertraline treatment of major depression in patients with acute MI or unstable angina. JAMA. Aug. 14. 2002;288(6):701-9. [pmid: 12169073].
300 Strik JJ, Honig A, Lousberg R, et al. Efficacy and safety of fluoxetine in the treatment of patients with major depression after first myocardial infarction: findings from a double-blind, placebo-controlled trial. Psychosom Med. Nov-Dec. 2000;62(6):783-9. [pmid: 11138997].
301 Andersen G, Vestergaard K, Lauritzen L. Effective treatment of poststroke depression with the selective serotonin reuptake inhibitor citalopram. Stroke. Jun. 1994;25(6):1099-104. [pmid: 8202964].
302 Murray V, Von Arbin M, Bartfai A, et al. Double-blind comparison of sertraline and placebo in stroke patients with minor depression and less severe major depression. J Clin Psychiatry. 2005;66(6):708-16. [pmid: 15960563].
303 Li LT, Wang SH, Ge HY, et al. The beneficial effects of the herbal medicine Free and Easy Wanderer Plus (FEWP) and fluoxetine on post-stroke depression. J Altern Complement Med. Sep. 2008;14(7):841-6. [pmid: 18721085].
304 Kranzler HR, Mueller T, Cornelius J, et al. Sertraline treatment of co-occurring alcohol dependence and major depression. J Clin Psychopharmacol. Feb. 2006;26(1):13-20. [pmid: 16415699].
305 Wohlreich MM, Sullivan MD, Mallinckrodt CH, et al. Duloxetine for the treatment of recurrent major depressive disorder in elderly patients: treatment outcomes in patients with comorbid arthritis. Psychosomatics. Jul-Aug. 2009;50(4):402-12. [pmid: 19687181].
306 Silverstone PH, Salinas E. Efficacy of venlafaxine extended release in patients with major depressive disorder and comorbid generalized anxiety disorder. J Clin Psychiatry. Jul. 2001;62(7):523-9. [pmid: 11488362].
307 Ehde DM, Kraft GH, Chwastiak L, et al. Efficacy of paroxetine in treating major depressive disorder in persons with multiple sclerosis. Gen Hosp Psychiatry. Jan-Feb. 2008;30(1):40-8. [pmid: 18164939].
308 Lesperance F, Frasure-Smith N, Koszycki D, et al. Effects of citalopram and interpersonal psychotherapy on depression in patients with coronary artery disease: the Canadian Cardiac Randomized Evaluation of Antidepressant and Psychotherapy Efficacy (CREATE) trial. JAMA. Jan. 24. 2007;297(4):367-79. [pmid: 17244833].
309 Honig A, Kuyper AM, Schene AH, et al. Treatment of post-myocardial infarction depressive disorder: a randomized, placebo-controlled trial with mirtazapine. Psychosom Med. Sep-Oct. 2007;69(7):606-13. [pmid: 17846258].
310 Rosenberg PB, Drye LT, Martin BK, et al. Sertraline for the treatment of depression in alzheimer disease. Am J Geriatr Psychiatry. 2010;18(2):136-45. [pmid: 20087081].
311 O'Connor CM, Jiang W, Kuchibhatla M, et al. Safety and efficacy of sertraline for depression in patients with heart failure: Results of the SADHART-CHF (Sertraline against depression and heart disease in chronic heart failure) trial. J Am Coll Cardiol. 2010;56(9):692-9. [pmid: 20723799].
312 Fisch MJ, Loehrer PJ, Kristeller J, et al. Fluoxetine versus placebo in advanced cancer outpatients: a double-blinded trial of the Hoosier Oncology Group. J Clin Oncol. May. 15. 2003;21(10):1937-43. [pmid: 12743146].
313 Bush DE, Ziegelstein RC, Patel UV, et al. Post-myocardial infarction depression. Evid Rep Technol Assess (Summ). May. 2005;(123):1-8. [pmid: 15989376].
314 Oslin DW, Ten Have TR, Streim JE, et al. Probing the safety of medications in the frail elderly: evidence from a randomized clinical trial of sertraline and venlafaxine in depressed nursing home residents. J Clin Psychiatry. Aug. 2003;64(8):875-82. [pmid: 12927001].
315 Thase ME, Entsuah R, Cantillon M, et al. Relative Antidepressant Efficacy of Venlafaxine and SSRIs: Sex-Age Interactions. J Womens Health (Larchmt). Sep. 2005;14(7):609-16. [pmid: 16181017].
316 Entsuah AR, Huang H, Thase ME. Response and remission rates in different subpopulations with major depressive disorder administered venlafaxine, selective serotonin reuptake inhibitors, or placebo. J Clin Psychiatry. Nov. 2001;62(11):869-77. [pmid: 11775046].
317 Wagner GJ, Maguen S, Rabkin JG. Ethnic differences in response to fluoxetine in a controlled trial with depressed HIV-positive patients. Psychiatr Serv. Feb. 1998;49(2):239-40. [pmid: 9575014].
318 Lewis-Fernández R, Blanco C, Mallinckrodt CH, et al. Duloxetine in the treatment of major depressive disorder: Comparisons of safety and efficacy in U.S. Hispanic and majority Caucasian patients. J Clin Psychiatry. Sep. 2006. 2006;67(9):1379-90. [pmid: 17017824].
319 Bailey RK, Mallinckrodt CH, Wohlreich MM, et al. Duloxetine in the treatment of major depressive disorder: comparisons of safety and efficacy. J Natl Med Assoc. Mar. 2006;98(3):437-47. [pmid: 16573311].
320 Stewart DE, Wohlreich MM, Mallinckrodt CH, et al. Duloxetine in the treatment of major depressive disorder: comparisons of safety and tolerability in male and female patients. J Affect Disord. Aug. 2006;94(1-3):183-9. [pmid: 16780958].
321 Norman GR, Sloan JA, Wyrwich KW. Interpretation of changes in health-related quality of life: the remarkable universality of half a standard deviation. Med Care. May. 2003;41(5):582-92. [pmid: 12719681].
322 Cipriani A, Furukawa TA, Geddes JR, et al. Does randomized evidence support sertraline as first-line antidepressant for adults with acute major depression? A systematic review and meta-analysis. J Clin Psychiatry. Nov. 2008;69(11):1732-42. [pmid: 19026250].
323 Omori IM, Watanabe N, Nakagawa A, et al. Efficacy, tolerability and side-effect profile of fluvoxamine for major depression: Meta-analysis. J Psychopharmacol (Oxf). Jul. 2009. 2009;23(5):539-50. [pmid: 18562407].
324 Watanabe N, Omori IM, Nakagawa A, et al. Mirtazapine versus other antidepressants in the acute-phase treatment of adults with major depression: Systematic review and meta-analysis. J Clin Psychiatry. Sep. 2008. 2008;69(9):1404-15. [pmid: 19193341].
325 Weinmann S, Becker T, Koesters M. Re-evaluation of the efficacy and tolerability of venlafaxine vs SSRI: meta-analysis (Structured abstract). Psychopharmacology (Berl). 2008;4:511-20. [pmid: 17955213].
326 Girardi P, Pompili M, Innamorati M, et al. Duloxetine in acute major depression: review of comparisons to placebo and standard antidepressants using dissimilar methods. Hum Psychopharmacol. Apr. 2009;24(3):177-90. [pmid: 19229839].
327 Eckert L, Falissard B. Using meta-regression in performing indirect-comparisons: comparing escitalopram with venlafaxine XR. Curr Med Res Opin. Nov. 2006;22(11):2313-21. [pmid: 17076991].
328 Eckert L, Lançon C. Duloxetine compared with fluoxetine and venlafaxine: Use of meta-regression analysis for indirect comparisons. BMC Psychiatry. Jul. 24. 2006;6:30. [pmid: 16867188].
329 Cipriani A, Furukawa TA, Salanti G, et al. Comparative efficacy and acceptability of 12 new-generation antidepressants: a multiple-treatments meta-analysis. Lancet. Feb. 28. 2009;373(9665):746-58. [pmid: 19185342].
330 Gartlehner G, Gaynes BN, Hansen RA, et al. Ranking antidepressants. Lancet. May. 23. 2009;373(9677):1761. author reply -2. [pmid: 19465225].
331 Ioannidis JP. Ranking antidepressants. Lancet. May. 23. 2009;373(9677):1759-60. author reply 61-2. [pmid: 19465221].
332 Turner E, Moreno SG, Sutton AJ. Ranking antidepressants. Lancet. May. 23. 2009;373(9677):1760. author reply 1-2. [pmid: 19465223].
333 Seyringer ME, Kasper S. Ranking antidepressants. Lancet. May. 23. 2009;373(9677):1760-1. author reply 1-2. [pmid: 19465224].
334 Schwan S, Hallberg P. Ranking antidepressants. Lancet. May. 23. 2009;373(9677):1761. author reply -2. [pmid: 19465226].
335 Bagby RM, Ryder AG, Schuller DR, et al. The Hamilton Depression Rating Scale: has the gold standard become a lead weight?. Am J Psychiatry. Dec. 2004;161(12):2163-77. [pmid: 15569884].
336 Bair MJ, Robinson RL, Katon W, et al. Depression and pain comorbidity: a literature review. Arch Intern Med. Nov. 10. 2003;163(20):2433-45. [pmid: 14609780].
337 Gaynes B, Lux L, Lloyd S, et al. Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults. Comparative Effectiveness Review No 33. AHRQ Publication No 11-EHC056-EF. Rockville (MD). Agency for Healthcare Research and Quality. 2011.