# Peer Reviewers

Glenda MacQueen, M.D., Ph.D., FRCPC

Head of the Department of Psychiatry for the Faculty of Medicine

Department of Psychiatry and Behavioral Neurosciences

University of Calgary

Calgary, Alberta, Canada

Marian McDonagh, Pharm.D.

Associate Professor

Department of Medical Informatics and Clinical Epidemiology

Oregon Health Sciences University

Portland, OR

Anand Pandya, M.D.

President

National Alliance on Mental Illness

Arlington, VA

Peter Roy-Byrne, M.D.

Professor and Vice Chair

Department of Psychiatry

University of Washington

Seattle, WA

Richard Shelton, M.D.

Professor of Psychiatry

Vanderbilt University

Nashville, TN