# Methods

This chapter documents all the methods used to conduct and produce this updated comparative effectiveness review (CER) on second-generation antidepressants for the Agency for Healthcare Research and Quality (AHRQ) through its Effective Health Care Program (www.effectivehealthcare.ahrq.gov). Because it is an update, we begin with an overview of the main changes to or differences in methods since we produced the initial report in 2007.^12^

## Summary of Methodological Changes Since the 2007 Report

We have made only a few changes to the methods used for the CER published in 2007. They involve drugs, approaches to the literature searches, articles included or excluded, techniques for quantitative synthesis, and grading strength of evidence for the overall body of evidence. Specific changes are noted here; longer documentation will be found in later parts of this methods chapter.

We added one drug—desvenlafaxine—to the literature searches and analyses (we used the same search strategy in electronic databases as for the original report). For manual literature searches, we changed the process to semi-automatic searches using the Scopus™ abstraction and citation database (www.scopus.com/home.url). The method is described below in the section on Literature Searches. We did not make any changes to the eligibility criteria (Table 4 in the Introduction). We used the same approach as in the 2007 report to select literature, assess the quality of individual studies (i.e., appraise their risk for bias), and extract relevant data.

Despite using identical methods to select relevant evidence, however, we removed some studies in the 2007 report from the current update. These studies had not met eligibility criteria in the 2007 report to begin with, but because they represented the only available evidence to answer a particular question at the time we had retained them. In the 2007 report we also had briefly summarized findings of such studies to provide a synopsis of the best available evidence (best-evidence approach). When, for this update, we have identified newer evidence that meets our eligibility criteria, we excluded the other “ineligible” studies from the current update.

For indirect comparisons we changed our statistical methods. Specifically, we now use a Bayesian mixed-treatment comparisons approach rather than meta-regressions and network meta-analyses. A detailed description of this approach appears in the section below on Data Synthesis.

We changed our method for rating the strength of evidence. In 2007 we used the GRADE (Grading of Recommendations, Assessment, Development and Evaluation) approach. For this update, we follow the principles outlined for use by the AHRQ Evidence-based Practice Centers in AHRQ's Methods Guide for Effectiveness and Comparative Effectiveness Reviews20 (www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318). Details are summarized below in Grading Strength of a Body of Evidence.

## Topic Development

The topic of the first comparative effectiveness review report and preliminary Key Questions arose through an internal process within the AHRQ Evidence-based Practice Center Program in early 2005. Investigators from the RTI International–University of North Carolina Evidence-based Practice Center (RTI–UNC EPC) then refined the questions in consultation with AHRQ and a Technical Expert Panel (TEP). We addressed the refined questions in the 2007 published report. For this report we added three new Key Questions (1c, 2a, 4b) to address input from the current TEP for the update review.

## Literature Search

To identify articles relevant to each Key Question, we searched PubMed, Embase, the Cochrane Library, PsycInfo, and International Pharmaceutical Abstracts. We used either Medical Subject Headings (MeSH or MH) as search terms when available or keywords when appropriate. We combined terms for selected indications (major depressive disorder, dysthymia, minor depression, subsyndromal depressive disorder), drug interactions, and adverse events with a list of 13 specific second-generation antidepressants (bupropion, citalopram, desvenlafaxine, duloxetine, escitalopram, fluoxetine, fluvoxamine, mirtazapine, nefazodone, paroxetine, sertraline, trazodone, and venlafaxine). We limited the electronic searches to “human” and “English language.” We searched sources from 1980 to January 2011 to capture literature relevant to the scope of our topic. We used the National Library of Medicine (NLM) publication type tags to identify reviews, randomized controlled trials (RCTs), and meta-analyses. The search strategy is outlined in Appendix A.

We also used semi-automatic manual searches of reference lists of pertinent review articles and letters to the editor employing Scopus.21 We imported all citations into an electronic database (EndNote X.04).

The Scientific Resource Center (SRC) contacted pharmaceutical manufacturers and invited them to submit dossiers, including citations. We received dossiers from five pharmaceutical companies (AstraZeneca, Eli Lilly, GlaxoSmithKline, Warner Chilcott Pharmaceuticals, and Wyeth). The SRC also searched the following sources for grey literature: the U.S. Food and Drug Administration (FDA) Web site, Health Canada, Authorized Medicines for the European Union, ClinicalTrial.gov, Current Controlled Trials, Clinical Study Results, WHO (World Health Organization) Clinical Trials, Conference Papers Index, NIH RePORTER, HSRProj (a service of the NLM), Hayes, Inc. Health Technology Assessment, and the New York Academy of Medicine's Grey Literature Index. One person reviewed the grey literature found through these searches to detect potentially relevant unpublished data and studies and ongoing trials.

## Study Selection

We developed eligibility criteria with respect to study design or duration, patient population, interventions, outcomes, and comparisons to antidepressant medications within our scope of interest, as described in Table 4 (in the Introduction). Two people independently reviewed abstracts. If both reviewers agreed that the trial did not meet eligibility criteria, we excluded it. We obtained the full text of all remaining articles and used the same eligibility criteria to determine which, if any, to exclude at this stage.

For this review, results from well-conducted, valid head-to-head trials provide the strongest evidence to compare drugs with respect to efficacy, effectiveness, and harms. We defined head-to-head trials as those comparing one second-generation antidepressant with another. RCTs of at least 6 weeks' duration and in adult study population were eligible for inclusion. For quantitative analyses we included all eligible studies without sample size limitations. In addition to head-to-head studies we included placebo-controlled trials for mixed treatment comparisons or if no head-to-head trials were available for a particular Key Question. If we concluded that we could not conduct any quantitative analyses, then we included studies only if they had sample sizes of 40 or larger.

For harms (i.e., evidence pertaining to safety, tolerability, and adverse events), we examined data from both experimental and observational studies. (Throughout this report we use “harms” as a summary term for adverse events and unwanted effects, as suggested by the CONSORT [Consolidated Standards of Reporting Trials] statement).22 We included observational studies that had large sample sizes (1,000 patients or more), lasted at least 3 months, and reported an outcome of interest.

Initially, we reviewed studies with health outcomes as primary outcomes. Such outcomes, for example, were quality of life, relapse, functional capacity, and hospitalization. We reviewed response and remission when based on changes in depression scores as proxies for health outcomes (e.g., for response, a 50 percent improvement of depression scores). For harms, we looked for both overall and specific outcomes ranging in severity (e.g., suicide, sexual side effects, hyponatremia, weight change, seizures, gastrointestinal symptoms, discontinuation syndrome) and for withdrawals attributed by the investigators to adverse events.

We included meta-analyses in this CER if we found them to be relevant for a Key Question and of good or fair methodological quality.23 We did not review individual studies if they had already been included in a high-quality meta-analysis. We excluded meta-analyses that were not based on a comprehensive systematic literature search or did not maintain the units of the studies in their statistical analyses. We checked our database to guarantee that our literature search had detected trials included in any meta-analyses that we discarded, and we then obtained any missing articles.

## Data Extraction

We designed and used a structured data abstraction form to ensure consistency of appraisal for each study. Trained reviewers initially abstracted data from each study and assigned an initial quality rating. A senior reviewer then read each abstracted article, evaluated the completeness and accuracy of the data abstraction, and confirmed the quality rating. We resolved discrepancies by consensus or by the involvement of a third, senior reviewer.

We abstracted the following data from included trials: study design, eligibility criteria, intervention (drugs, dose, duration), additional medications allowed, methods of outcome assessment, population characteristics (such as age, sex, race or ethnicity, or comorbid anxiety), sample size, loss to followup, withdrawals because of adverse events, results, and adverse events reported. We recorded intention-to-treat results (ITT; i.e., all patients are analyzed as randomized with missing values imputed) if available. For studies eligible for quantitative analyses, we contacted authors if reported data were incomplete or missing. All data abstraction employed SRS 4.0, Möbius Analytics.

## Quality Assessment

To assess the quality (internal validity) of studies, we used predefined criteria based on those developed by the U.S. Preventive Services Task Force (ratings: good, fair, poor)24 and the National Health Service Centre for Reviews and Dissemination.25 Elements of quality assessment included, among others, randomization and allocation concealment, similarity of compared groups at baseline, use of ITT analysis, and overall and differential loss to followup. To assess the quality of observational studies, we used criteria outlined by Deeks et al.26 Items assessed included selection of cases or cohorts and controls, adjustment for confounders, methods of outcomes assessment, length of followup, and statistical analysis.

In general terms, a “good” study has the least risk of bias and results are considered to be valid. A “fair” study is susceptible to some bias, but probably not sufficient to invalidate its results. The fair quality category is likely to be broad, so studies with this rating will vary in their strengths and weaknesses. A “poor” rating indicates significant risk of bias (stemming from, e.g., serious errors in design, analysis reporting large amounts of missing information, or discrepancies in reporting) that may invalidate the study's results. We generally excluded studies with a poor rating from our analyses. If no other evidence on an outcome of interest was available, however, we may comment on findings from poor studies.

Ratings of the internal validity of studies are not comparable across study designs. That is, a good observational study does not necessarily equal a good RCT. We take limitations of certain study designs into consideration when we grade the strength of the evidence.

Two independent reviewers assigned quality ratings. They resolved any disagreements by discussion and consensus or by consulting a third, independent party. Time constraints precluded our contacting study authors for clarification of methodological questions.

In addition to internal validity, we assessed the comparability of dosages. To evaluate comparative evidence, we considered a large range of doses within and across studies. Because a reference standard does not exist for making dose comparisons across drugs, we had previously created and then used in this CER a comparative dose classification system to identify gross inequities in drug-dose comparisons.19

This classification provides a rough mechanism to determine whether doses are relatively similar when making head-to-head comparisons. The dose classification is rooted primarily in the dosing range suggested in FDA-approved labeling for these medications. We also made some adjustments to this range to reflect clinical practice patterns that might not have been considered in the FDA-reviewed studies. As shown in Table 5, the usual dosing range (middle column) is divided by the upper and lower quartile to create three levels (right-hand columns).

## Applicability Assessment

Throughout this report, we highlight effectiveness studies conducted in primary care or office-based settings that use less stringent eligibility criteria, assess health outcomes, and have longer followup periods than most efficacy studies. The results of effectiveness studies are more applicable to the spectrum of patients who will use a drug, have a test, or undergo a procedure than results from highly selected populations in efficacy studies. We used criteria proposed by Gartlehner et al. to distinguish effectiveness from efficacy trials.18 These criteria assess seven categories: primary care population, eligibility criteria, outcome measures, study duration and intervention modalities, adverse events assessment, sample size, and ITT analysis.

## Grading Strength of a Body of Evidence

We evaluated the strength of evidence based on methods guidance for the EPC program.20 Strength of evidence is graded only for major comparisons and major outcomes for the topic at hand. The strength of evidence for each outcome or comparison that we graded incorporates scores on four domains: risk of bias, consistency, directness, and precision; it can also reflect ratings for other domains that can be factored in when relevant (e.g., dose-response relationships).

As described in Owens et al., evaluating risk of bias includes assessment of study design and aggregate quality of studies.20 We judged good quality studies to yield evidence with low risk of bias. We graded evidence as consistent when effect sizes across studies were in the same direction. When the evidence linked the interventions directly to health outcomes, we graded the evidence as being direct. We graded evidence as being precise when results had a low degree of uncertainty. A precise estimate is one that would allow a clinically useful conclusion; an imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions.20

As shown in Table 6, we used four grades to designate strength of evidence: high, moderate, low, and insufficient. Grades reflect the strength of the body of evidence to answer Key Questions on the comparative efficacy, effectiveness, and harms of second-generation antidepressants. They do not refer to the general efficacy or effectiveness.

Table 6 Definitions of the grades of the overall strength of evidence

High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit a conclusion.

This approach does not incorporate other factors that might be relevant to assess reliably the comparative efficacy, effectiveness, and harms; such considerations can include funding sources and comparable dosing. For this CER, we reported these additional factors and highlighted any problems that could potentially bias our assessments (e.g., all studies funded by the same manufacturer).

We dually evaluated the overall strength of evidence for each major outcome based on a qualitative assessment of strength of evidence for each domain. We reconciled all disagreements in grades through consensus discussion.

## Data Synthesis

### Overall Approaches and Meta-analyses for Direct Comparisons

Throughout this CER we synthesized the literature qualitatively. These are the results presented first (by Key Question) in Results.

When data were sufficient, we augmented findings with quantitative analyses. We conducted meta-analyses of data for head-to-head comparisons for trials that were fairly homogenous in study populations and outcome assessments. For efficacy, we used two outcome measures:

1. The odds ratio (OR) of being a responder (more than 50 percent improvement from baseline) on the Hamilton Rating Scale for Depression (HAM-D) or the Montgomery-Asberg Depression Rating Scale (MADRS) at study endpoint.
2. The weighted mean difference of changes on a specific depression rating scale (HAM-D or MADRS). We chose this outcome measure to have an estimate of the actual difference in effect sizes between treatments.

For each meta-analysis, we conducted a test of heterogeneity (I^2^ index) and applied both a random and a fixed effects model. We report the results from random effects models because, in all our meta-analyses, the results from random and fixed effects models were very similar. If the OR was statistically significant, we then conducted a meta-analysis of the risk differences to calculate the number needed to treat (NNT). All meta-analyses were conducted using StatsDirect Ltd. version 2.4.5.

We assessed publication bias using funnel plots and Kendell's tests. However, given the small number of component studies in our meta-analyses, these tests have low sensitivity to detect publication bias.

### Indirect Comparisons With Mixed Treatment Comparisons Techniques

If fewer than three head-to-head trials were available for any drug comparison, we computed indirect comparisons employing mixed treatment comparisons (MTC) using Bayesian methods.27, 28 Evidence suggests that indirect comparisons agree with head-to-head trials if component studies are similar and treatment effects are expected to be consistent in patients in different trials.29 Nevertheless, results have to be interpreted cautiously.

To conduct MTC analyses, we included all placebo- and active-controlled double-blinded RCTs of good or fair quality that were fairly homogenous in study populations and outcome assessments. For this analysis, we excluded studies conducted exclusively in subjects who were older than 65 years of age or who had depressive disorders other than MDD or treatment-resistant depression.

Our outcome measure of choice was the rate of response on the HAM-D (defined as a 50 percent improvement of scores from baseline). We recalculated response rates for each study using the number of all randomized patients as the denominator to reflect a true ITT analysis. With this approach we attempted to correct variations in results of modified ITT analyses encountered in individual studies.

We used a random effects logistic regression model that adjusted for correlations between arms within each study, developed by the Multi-Parameter Evidence Synthesis (MPES) Research Group.28

The analysis was performed using WinBUGS Version 1.4, a Bayesian software package that uses Markov chain Monte Carlo (MCMC) techniques.30 For our analysis, study effect and treatment effect parameters were modeled by flat prior distributions that were Normal (0, 10000). For the heterogeneity of the random-effects model, a vague uniform prior distribution with large range was used. The first 20,000 simulations were discarded to allow for model convergence and then a further 80,000 simulations were used in estimating the posterior probabilities. Satisfactory convergence was verified by trace plots and calculation of the Monte Carlo error for each parameter.

We calculated odds ratios and 95 percent credible intervals for all possible comparisons among our drugs of interest.

## Peer Review

Individuals who were experts in psychiatry and individuals representing various stakeholder and user communities were invited to provide an external peer review of this CER. The Task Order Officer and the SRC oversaw the peer review process. Peer reviewers were charged with commenting on the content, structure, and format of the evidence report, providing additional relevant citations, and pointing out issues related to how we had conceptualized and defined the topic and Key Questions. Our peer reviewers (listed in the front matter of the report) gave us permission to acknowledge their review of the draft. In addition to AHRQ staff, an Associate Editor reviewed the report, and the Eisenberg Center placed the draft report on the AHRQ Web site (http://effectivehealthcare.ahrq.gov) for 4 weeks to elicit public comment.

We compiled comments from all these sources and addressed each one individually, revising the text as appropriate. We documented all of this in a peer review disposition report delivered to AHRQ. For purposes of transparency of the entire EPC process, AHRQ makes this report available to the public at about 3 months after the Agency posts the final CER on the AHRQ Web site.