# Discussion

## Organization of This Chapter

We first draw general conclusions about the findings of this comparative effectiveness review and present the strength of the evidence supporting these conclusions. We then discuss findings of each Key Question in more detail and, if relevant, put results into context with other studies. Finally, we outline topics for future research based on areas for which we have identified gaps in the current evidence.

### General Conclusions

We provide a comprehensive summary of the comparative efficacy, effectiveness, and harms of 13 second-generation antidepressants for the treatment of major depressive disorder (MDD), dysthymia, and subsyndromal depression. They include bupropion, citalopram, desvenlafaxine, duloxetine, escitalopram, fluoxetine, fluvoxamine, mirtazapine, nefazodone, paroxetine, sertraline, trazodone, and venlafaxine in three classes: selective serotonin reuptake inhibitors (SSRIs), serotonin and norepinephrine reuptake inhibitors (SNRIs and SSNRIs), and other second-generation antidepressants.

Therefore, our findings indicate that the existing evidence does not warrant the choice of one second-generation antidepressant over another based on either greater efficacy or greater effectiveness. Tables 56 through Table 64 briefly summarize our findings from evidence for five Key Questions and their subquestions and notes the strength of evidence in each case (high, moderate, low, or insufficient). For outcomes for which we had no studies whatsoever, we specify “no evidence” for strength of evidence.

Table 56 Summary of findings with strength of evidence, Key Question 1a: Comparative efficacy and effectiveness of second-generation antidepressants

Disorder, and Outcome of Interest | Strength of Evidence^a^ | Findings^b^
Major depressive disorder Comparative efficacy | Moderate | Results from direct and indirect comparisons based on 61 head-to head trials and 31 placebo-controlled trials indicate that no substantial differences in efficacy exist among second-generation antidepressants.
Comparative effectiveness | Moderate | Direct evidence from three effectiveness trials (one good) and indirect evidence from efficacy trials indicate that no substantial differences in effectiveness exist among second-generation antidepressants.
Quality of life | Moderate | Consistent results from 18 trials indicate that the efficacy of second-generation antidepressants with respect to quality of life does not differ among drugs.
Onset of action | Moderate | Consistent results from seven trials suggest that mirtazapine has a significantly faster onset of action than citalopram, fluoxetine, paroxetine, and sertraline. Whether this difference can be extrapolated to other second-generation antidepressants is unclear. Most other trials do not indicate a faster onset of action of one second-generation antidepressant compared with another.
Dysthymia Comparative efficacy | Insufficient | No head-to-head evidence exists. Results from five placebo-controlled trials were insufficient to draw conclusions about comparative efficacy.
Comparative effectiveness | Insufficient | No head-to-head evidence exists. One effectiveness trial provides mixed evidence about paroxetine versus placebo; patients older than 60 showed greater improvement on paroxetine; those younger than 50 did not show any difference.
Quality of life | Insufficient | No evidence
Onset of action | Insufficient | No evidence
Subsyndromal depression Comparative efficacy | Low | One nonrandomized, open-label trial did not detect any difference between citalopram and sertraline. Results from two placebo-controlled trials were insufficient to draw conclusions.
Comparative effectiveness | Insufficient | No evidence
Quality of life | Insufficient | No evidence
Onset of action | Insufficient | No evidence

a Strength of evidence grades (high, moderate, low, or insufficient) are based on methods guidance for the EPC program; outcomes for which we have no studies are designated no evidence.

b Good, fair, or poor designations relate to quality grades given to each study; see Methods chapter. We provide the designations only for good (or poor) studies; the remaining studies are all of fair quality.

Table 57 Summary of findings with strength of evidence, Key Question 1b: Greater efficacy and effectiveness with previously effective medications

Disorder, and Outcome of Interest | Strength of Evidence^a^ | Findings^b^
Major depressive disorder | Insufficient | No evidence
Dysthymia | Insufficient | No evidence
Subsyndromal depression | Insufficient | No evidence

a Strength of evidence grades (high, moderate, low, or insufficient) are based on methods guidance for the EPC program; outcomes for which we have no studies are designated no evidence.

b Good, fair, or poor designations relate to quality grades given to each study; see Methods chapter. We provide the designations only for good (or poor) studies; the remaining studies are all of fair quality.

Table 58 Summary of findings with strength of evidence, Key Question 1c: Differences in efficacy and effectiveness between immediate- and extended-release formulations

Disorder, and Outcome of Interest | Strength of Evidence^a^ | Findings^b^
Major depressive disorder | Moderate | Results from two trials indicate that no differences in response to treatment exist between paroxetine IR and paroxetine CR. Two trials did not detect significant differences in maintenance of response and remission between fluoxetine daily and fluoxetine weekly.
Major depressive disorder | Low | One trial reported higher response rates for venlafaxine XR than venlafaxine IR.
Dysthymia | Insufficient | No evidence
Subsyndromal depression | Insufficient | No evidence

CR = controlled release; IR = immediate release; XR = extended release

a Strength of evidence grades (high, moderate, low, or insufficient) are based on methods guidance for the EPC program; outcomes for which we have no studies are designated no evidence.

b Good, fair, or poor designations relate to quality grades given to each study; see Methods chapter. We provide the designations only for good (or poor) studies; the remaining studies are all of fair quality.

Table 59 Summary of findings with strength of evidence, Key Question 2a: Efficacy and effectiveness of second-generation antidepressants for maintaining response or remission (i.e., preventing relapse or recurrence)

Outcome of Interest | Strength of Evidence^a^ | Findings^b^
Continuing initial medications Comparative efficacy | Moderate | Based on results from six efficacy trials and one naturalistic study, no significant differences exist between escitalopram and desvenlafaxine, escitalopram and paroxetine, fluoxetine and sertraline, fluoxetine and venlafaxine, fluvoxamine and sertraline, and trazodone and venlafaxine for preventing relapse or recurrence.
Comparative effectiveness | Insufficient | No evidence
Switching medications Comparative efficacy | Insufficient | No evidence
Comparative effectiveness | Insufficient | No evidence

a Strength of evidence grades (high, moderate, low, or insufficient) are based on methods guidance for the EPC program; outcomes for which we have no studies are designated no evidence.

b Good, fair, or poor designations relate to quality grades given to each study; see Methods chapter. We provide the designations only for good (or poor) studies; the remaining studies are all of fair quality.

Table 60 Summary of findings with strength of evidence, Key Question 2b: Efficacy and effectiveness of second-generation antidepressants in managing treatment-resistant depression syndrome or treating recurrent depression

Outcome of Interest | Strength of Evidence^a^ | Findings^b^
Comparative efficacy | Low | Results from four trials suggest no differences, or only modest differences, between SSRIs and venlafaxine. Numerical trends favored venlafaxine over comparator drugs in three of these trials, but differences were statistically significant in only one trial, which compared venlafaxine with paroxetine.
Comparative effectiveness | Low | Results from two effectiveness studies are conflicting. Based on one trial rated good, no significant differences in effectiveness exist among bupropion SR, sertraline, and venlafaxine XR. One effectiveness trial found venlafaxine to be modestly superior to citalopram, fluoxetine, mirtazapine, paroxetine, and sertraline.

SR = slow release; SSRI = selective serotonin reuptake inhibitor; XR = extended release

a Strength of evidence grades (high, moderate, low, or insufficient) are based on methods guidance for the EPC program; outcomes for which we have no studies are designated no evidence.

b Good, fair, or poor designations relate to quality grades given to each study; see Methods chapter. We provide the designations only for good (or poor) studies; the remaining studies are all of fair quality.

Table 61 Summary of findings with strength of evidence, Key Question 3: Comparative efficacy and effectiveness of second-generation antidepressants for treatment of depression in patients with accompanying symptom clusters

Accompanying Symptoms, and Outcome of Interest | Strength of Evidence^a^ | Findings^b^
Anxiety Comparative efficacy for depression | Moderate | Results from five head-to-head trials suggest that efficacy does not differ substantially for treatment of depression in patients with accompanying anxiety.
Comparative effectiveness for depression | Insufficient | No evidence
Comparative efficacy for anxiety | Moderate | Results from eight head-to-head trials and three placebo-controlled trials suggest that no substantial differences in efficacy exist among second-generation antidepressants for treatment of accompanying anxiety symptoms
Comparative effectiveness for anxiety | Insufficient | No evidence
Insomnia Comparative efficacy for depression | Insufficient | Results from one head-to-head study are insufficient to draw conclusions about the comparative efficacy for treating depression in patients with coexisting insomnia.
Comparative effectiveness for depression | Insufficient | No evidence
Comparative efficacy for insomnia | Low | Results from five head-to-head trials suggest that no substantial differences in efficacy exist among second-generation antidepressants for treatment of accompanying insomnia. Results are limited by study design; differences in outcomes are of unknown clinical significance.
Comparative effectiveness for insomnia | Insufficient | No evidence
Low energy Comparative efficacy for depression | Insufficient | Results from one placebo-controlled trial of bupropion XL are insufficient to draw conclusions about treating depression in patients with coexisting low energy. Results from head-to-head trials are not available.
Comparative effectiveness for depression | Insufficient | No evidence
Comparative efficacy for low energy | Insufficient | Results from one placebo-controlled trial of bupropion XL are insufficient to draw conclusions about treating low energy in depressed patients. Results from head-to-head trials are not available.
Comparative effectiveness for low energy | Insufficient | No evidence
Melancholia Comparative efficacy for depression | Insufficient | Results from two head-to-head trials are insufficient to draw conclusions about treating depression in patients with coexisting melancholia. Results are inconsistent across studies.
Comparative effectiveness for depression | Insufficient | No evidence
Comparative efficacy for melancholia | Insufficient | No evidence
Comparative effectiveness for melancholia | Insufficient | No evidence
Pain Comparative efficacy for depression | Insufficient | Results from two placebo-controlled trials are conflicting regarding the superiority of duloxetine over placebo. Results from head-to-head trials are not available.
Comparative effectiveness for depression | Insufficient | No evidence
Comparative efficacy for pain | Moderate | Evidence from one systematic review, two head-to-head trials (one poor) and five placebo-controlled trials indicate no difference in efficacy between paroxetine and duloxetine.
Comparative effectiveness for pain | Insufficient | No evidence
Psychomotor change Comparative efficacy for depression | Insufficient | Results from one head-to-head trial are insufficient to draw conclusions about the comparative efficacy for treating depression in patients with coexisting psychomotor change.
Comparative effectiveness for depression | Insufficient | No evidence
Comparative efficacy for psychomotor change | Insufficient | No evidence
Comparative effectiveness for psychomotor change | Insufficient | No evidence
Somatization Comparative efficacy for depression | Insufficient | No evidence
Comparative effectiveness for depression | Insufficient | No evidence
Comparative efficacy for somatization | Insufficient | Results from one head-to-head trial are insufficient to draw conclusions about the comparative efficacy for treating somatization in depressed patients. Results indicate similar improvement in somatization.
Comparative effectiveness for somatization | Insufficient | Evidence from one open-label head-to-head trial is insufficient to draw conclusions about the comparative efficacy for treating coexisting somatization in depressed patients. Results indicate no difference in effectiveness.

CR = controlled release; IR = immediate release; RCT = randomized controlled trials; SR = slow release; XR = extended release

a Strength of evidence grades (high, moderate, low, or insufficient) are based on methods guidance for the EPC program; outcomes for which we have no studies are designated no evidence.

b Good, fair, or poor designations relate to quality grades given to each study; see Methods chapter. We provide the designations only for good (or poor) studies; the remaining studies are all of fair quality.

Table 62 Summary of findings with strength of evidence, Key Question 4a: Comparative risk of harms (safety, adverse events), adherence, and persistence

Outcome of Interest | Strength of Evidence^a^ | Findings^b^
General tolerability Adverse events profiles | High | Adverse events profiles, based on 92 efficacy trials and 48 studies of experimental or observational design, are similar among second-generation antidepressants. The incidence of specific adverse events differs across antidepressants
Comparative risk of nausea and vomiting | High | Meta-analysis of 15 studies indicates that venlafaxine has a higher rate of nausea and vomiting than SSRIs as a class.
Comparative risk of weight change | High | Results from seven trials indicate that mirtazapine leads to higher weight gains than citalopram, fluoxetine, paroxetine, and sertraline.
Comparative risk of gastrointestinal adverse events | Moderate | Results from 15 studies indicate that sertraline has a higher incidence of diarrhea than bupropion, citalopram, fluoxetine, fluvoxamine, mirtazapine, nefazodone, paroxetine, and venlafaxine. Results from one systematic review confirm some of these findings.
Comparative risk of somnolence | Moderate | Results from six trials indicate that trazodone has a higher rate of somnolence than bupropion, fluoxetine, mirtazapine, paroxetine, and venlafaxine.
Comparative risk of discontinuation syndrome | Moderate | A good systematic review indicates that paroxetine and venlafaxine have the highest rates of discontinuation syndrome; fluoxetine has the lowest.
Comparative risk of discontinuation of treatment | High | Meta-analyses of numerous efficacy trials indicate that overall discontinuation rates are similar. Duloxetine and venlafaxine have a higher rate of discontinuations because of adverse events than SSRIs as a class. Venlafaxine has a lower rate of discontinuations because of lack of efficacy than SSRIs as a class.
Severe adverse events Comparative risk of suicidality (suicidal thoughts and behavior) | Insufficient | Results from 11 observational studies (two good quality), five meta-analyses or systematic reviews (four good), and one systematic review yield conflicting information about the comparative risk of suicidality.
Comparative risk of sexual dysfunction | High | Results from six trials indicate that bupropion causes significantly less sexual dysfunction than escitalopram, fluoxetine, paroxetine, and sertraline.
Comparative risk of sexual dysfunction | Low | Among SSRIs, paroxetine has the highest rates of sexual dysfunction.
Comparative risk of seizures | Insufficient | Results from three studies (one good observational design) yield conflicting information about the comparative risk of seizures.
Cardiovascular events | Insufficient | Results from one good observational study and one pooled analysis yield noncomparative or conflicting information about the comparative risk of cardiovascular events.
Comparative risk of hyponatremia | Insufficient | No trials or observational studies assessing hyponatremia met criteria for inclusion in this review. One cohort study not meeting inclusion criteria suggested that hyponatremia was more common in elderly patients treated with various antidepressants than in placebo-treated patients.
Comparative risk of hepatotoxicity | Insufficient | Evidence from existing studies is insufficient to draw conclusions about the comparative risk of hepatotoxicity. Weak evidence indicates that nefazodone might have an increased risk of hepatotoxicity.
Comparative risk of serotonin syndrome | Insufficient | No trials or observational studies assessing serotonin syndrome were included in this review. Numerous case reports of this syndrome exist but were not included in this review.
Adherence Comparative adherence in efficacy studies | Moderate | Efficacy studies indicate no differences in adherence.
Comparative adherence in effectiveness studies | Insufficient | Evidence from existing studies is insufficient to draw conclusions about adherence in real-world settings.
Comparative persistence | Insufficient | No evidence

SSRI = selective serotonin reuptake inhibitor

a Strength of evidence grades (high, moderate, low, or insufficient) are based on methods guidance for the EPC program; outcomes for which we have no studies are designated no evidence.

b Good, fair, or poor designations relate to quality grades given to each study; see Methods chapter. We provide the designations only for good (or poor) studies; the remaining studies are all of fair quality.

Table 63 Summary of findings with strength of evidence, Key Question 4b: Differences in harms, adherence, and persistence between immediate- and extended-release formulations

Disorder, and Outcome of Interest | Strength of Evidence^a^ | Findings^b^
Major depressive disorder Comparative risk of harms | Moderate | Findings from one trial each indicate that no differences in harms exist between fluoxetine daily and fluoxetine weekly or between venlafaxine IR and venlafaxine XR.
Major depressive disorder Comparative risk of harms | Low | One trial provides evidence that paroxetine IR leads to higher rates of nausea than paroxetine CR.
Comparative adherence | Low | One trial provides evidence that fluoxetine weekly has better adherence rates than fluoxetine daily.
Comparative persistence | Low | Evidence from one observational study indicates that prescription refills are more common with the extended-release than the immediate-release formulation of bupropion.
Dysthymia | Insufficient | No evidence
Subsyndromal depression | Insufficient | No evidence

IR = immediate release; XR = extended release

a Strength of evidence grades (high, moderate, low, or insufficient) are based on methods guidance for the EPC program; outcomes for which we have no studies are designated no evidence.

b Good, fair, or poor designations relate to quality grades given to each study; see Methods chapter. We provide the designations only for good (or poor) studies; the remaining studies are all of fair quality.

Table 64 Summary of findings with strength of evidence, Key Question 5: Subgroups

Subgroup, and Outcome of Interest | Strength of Evidence^a^ | Findings^b^
Age Comparative efficacy | Moderate | Evidence from 11 trials indicates that efficacy does not differ substantially among second-generation antidepressants for treating MDD in patients age 60 years or older.
Age Comparative efficacy | Insufficient | No head-to-head evidence found for dysthymia or subsyndromal depression. Results from one good placebo-controlled trial showed no difference between fluoxetine and placebo.
Comparative effectiveness | Insufficient | No evidence in older patients with MDD.
Comparative effectiveness | Insufficient | One effectiveness study showed greater improvement with paroxetine versus placebo in dysthymia patients older than 60 years; insufficient evidence to draw conclusions on comparative effectiveness.
Comparative harms | Low | Results from six studies indicate that adverse events may differ somewhat across second-generation antidepressants in older adults.
Comparative harms | Insufficient | No head-to-head studies were found for dysthymia or subsyndromal depression.
Sex Comparative efficacy | Insufficient | No evidence
Comparative effectiveness | Insufficient | No evidence
Comparative harms | Low | Two trials suggest differences between men and women in sexual side effects.
Comorbidities Comparative efficacy | Low | Results from a subgroup analysis of one trial indicate significantly greater response with venlafaxine XR than fluoxetine in patients with MDD and comorbid generalized anxiety disorder.
Comorbidities Comparative efficacy | Insufficient | Placebo-controlled trials assessed efficacy in patients with the following comorbidities: alcohol/substance abuse, Alzheimer's disease/dementia, arthritis, diabetes, HIV/AIDS, multiple sclerosis, stroke, and vascular disease. No head-to-head evidence exists on comparative efficacy.
Comparative effectiveness | Insufficient | No evidence
Comparative harms | Insufficient | No evidence

MDD = major depressive disorder; RCT = randomized controlled trials; vs. = versus; XR = extended release

a Strength of evidence grades (high, moderate, low, or insufficient) are based on methods guidance for the EPC program; outcomes for which we have no studies are designated no evidence.

b Good, fair, or poor designations relate to quality grades given to each study; see Methods chapter. We provide the designations only for good (or poor) studies; the remaining studies are all of fair quality.

#### Principal Findings for Treatment of MDD

Overall, the new evidence (78 new studies, 87 articles) we found during the update of our 2007 report12 did not lead to changes in our main conclusion from that review—namely, that no substantial differences in efficacy exist among second-generation antidepressants for the treatment of MDD. Some results are now supported by better evidence than in 2007, which is reflected in a higher grade for the strength of the evidence for some outcomes. In addition, the more advanced statistical analysis that we were able to do for indirect comparisons of second-generation antidepressants when no or only insufficient head-to-head evidence was available also confirmed that conclusion.

Therefore, our findings indicate that the existing evidence does not warrant the choice of one second-generation antidepressant over another based on either greater efficacy or greater effectiveness. Some of the comparisons rendered statistically significant results, the magnitudes of the differences, however, are small and likely not clinically significant. Furthermore, because we had 78 pairwise comparisons, some are expected to be statistically significant by chance alone.

Although second-generation antidepressants are similar in efficacy, they cannot be considered identical drugs. Evidence of high and moderate strength supports some differences among individual drugs with respect to onset of action, adverse events, and some measures of health-related quality of life; these differences are of modest magnitude but statistically significant. Specifically, consistent evidence from multiple trials demonstrates that mirtazapine has a faster onset of action than citalopram, fluoxetine, paroxetine, and sertraline76, 77, 90, 92, 96 and that bupropion has fewer sexual side effects than escitalopram, fluoxetine, paroxetine, and sertraline.100, 101, 110-112, 237 It remains unclear whether the faster response of mirtazapine on depression rating scales might simply be caused by a better sleep profile of mirtazapine.

Some of these differences are small and might be offset by adverse events. For example, a faster onset of mirtazapine must be weighed against possible decreased adherence because of long-term weight gain. Nonetheless, some of these differences may be clinically significant and influence the choice of a medication for specific patients. For example, patients who have a history of nausea or who dread sexual dysfunction might be more adherent to a choice of treatment that takes these factors into consideration. Past treatment experiences may also frame decisions regarding medications to either select or avoid, but no evidence exists to verify these inferences.

### Principal Findings for Less Severe Depression, Symptom Clusters, and Subpopulations

For many other Key Questions, particularly those about dysthymia and minor depression, the underlying evidence remains insufficient to draw inferences about the comparative efficacy, effectiveness, and harms of second-generation antidepressants.

Evidence was completely unavailable (or at best insufficient) for several other topics. These included questions about switching medications and about medications to which a patient had previously responded for treating a new depressive episode.

Clinically, numerous physical and psychological symptoms accompany depressive disorders. Clinicians sometimes recommend using individual second-generation antidepressants for these problems, assuming differences in efficacy to treat these accompanying symptom clusters. The current evidence does not support the selection of one second-generation antidepressant over another for specific accompanying symptoms. The best comparative evidence suggests no difference in efficacy for anxiety and pain. For other symptom clusters such as melancholia, psychomotor change, pain, and somatization, the evidence is limited to few comparisons. For other common symptoms, such as appetite change, evidence is completely absent.

For important population subgroups, the evidence is sparse at best. No differences in comparative efficacy are apparent in elderly subgroups with MDD. The paucity of head-to-head trials addressing differences in other demographic subgroups or groups with co-occurring illnesses means that evidence is insufficient to draw conclusions about the comparative efficacy and effectiveness of second-generation antidepressants in such patients.

### Specific Results for Efficacy and Effectiveness in Major Depressive Disorder

For MDD, direct evidence from head-to-head trials and indirect comparisons using head-to-head and placebo-controlled trials indicate that, overall, the efficacy and effectiveness of second-generation antidepressants do not differ substantially for the treatment of adults. We graded the strength of this evidence as moderate.

In some of our meta-analyses, results of pooled response rates indicate statistically significant differences in efficacy between some drugs. Specifically, for response, escitalopram is more efficacious than citalopram, sertraline more than fluoxetine, and venlafaxine more than fluoxetine. The magnitudes of these statistically significant differences, however, are small and likely not clinically relevant. In addition, accompanying meta-analyses of effect sizes and mixed treatment comparisons suggest that the actual differences in the mean treatment effects are most likely also not clinically significant.

For example, an odds ratio (OR) meta-analysis of response rates indicates that significantly more patients receiving escitalopram than receiving citalopram achieved treatment response (OR, 1.47; 95% CI, 1.07 to 2.01). An effect-size meta-analysis yielded a mean difference of 1.5 points on the Montgomery-Asberg Depression Rating Scale (MADRS), which represents about one-fifth to one-quarter of a standard deviation. Therefore, this difference most likely does not represent a minimal clinically significant difference. A recent methods study concluded that a change of about one-half of a standard deviation reflects a minimal important difference for a patient.321 Furthermore, mixed treatment comparisons taking relative treatment effects of citalopram and escitalopram compared with other second-generation antidepressants into consideration, do not indicate a statistically significant difference in treatment effects between the two drugs (OR, 0.5; 95% credible interval [CrI], 0.13 to 4.14). These findings might indicate underlying publication bias within the body of evidence of head-to-head trials comparing citalopram with escitalopram. Both drugs are produced by the same manufacturer. Citalopram is already available as a generic drug, while escitalopram is still patent protected.

Similarly, sertraline and venlafaxine had statistically significantly greater response rates than fluoxetine. Effect size meta-analyses, however, yielded no clinically significant mean differences on Hamilton Depression Rating Scale (HAM-D) scales.

Findings from mixed treatment comparisons also yielded some statistically significant differences in response rates for some comparisons. Again, the magnitudes of each of these differences were small and indicate no clinically relevant differences in efficacy among second-generation antidepressants.

Although response and remission rates are similar among second-generation antidepressants, 53 percent of patients in these trials did not achieve remission and 37 percent did not respond. Many of these patients will require a second-line treatment. Results from the Sequenced Treatment Alternatives to Relieve Depression (STAR*D) trial—and effectiveness study that randomized patients to bupropion SR (sustained release), sertraline, or venlafaxine XR (extended release) after they had failed treatment with citalopram194—indicate that, even with second-line treatments, a substantial proportion of patients do not achieve remission.

Effectiveness trials have greater applicability of findings than efficacy studies; for acute-phase MDD we found only three such trials. Two of these effectiveness trials were conducted in French primary care settings and one was performed in the United States. Findings were generally consistent with efficacy trials—they did not detect any substantial differences in effectiveness. However, differences between French and U.S. health systems may limit the applicability of results from French effectiveness trials to U.S. patients.

No evidence exists on adherence in effectiveness studies. Although adherence was similar in efficacy trials, the applicability of such findings may be limited. Most likely, dosing regimens, adverse events, and costs substantially influence adherence of patients in everyday practice. Given similar efficacy and effectiveness, such factors need to be considered when choosing a medication.

Our findings are consistent with results of most other systematic reviews assessing the comparative efficacy and safety of second-generation antidepressants.322-328 Our conclusions, however, contradict findings of a comparative effectiveness review conducted by the MANGA (Meta-analysis of New Generation Antidepressants) study group.329 This 2009 review assessed all second-generation antidepressants included in our report except trazodone. Researchers employed Bayesian-based mixed treatment comparisons to determine the relative efficacy and acceptability of all possible comparisons. Results of the MANGA group indicate that escitalopram and sertraline have the best efficacy–acceptability ratio compared with that for other second-generation antidepressants.

The MANGA group's study has been criticized for methodological shortcomings.330-334 Specifically, several letters to the editor criticized the following points: that the authors included studies with high risk of bias; they assumed that a response on the HAM-D scale equals a response on MADRS or CGI (Clinical Global Inventory); and they overstated the importance of statistically significant findings without considering the clinical relevance. In particular, the assumption that responses on HAM-D, MADRS, and CGI are identical is not grounded in evidence;335 thus, making such an assumption might introduce substantial bias in a mixed treatment comparisons model.

For our current update, we employed the same statistical methods as the MANGA authors. We retained, however, our more rigid systematic review methods; these specifically included omitting studies with high risk of bias or open-label designs and limiting pooled outcome measures to relative risks of a response on a single diagnostic scale (HAM-D or MADRS). Furthermore, whenever possible, we used meta-analyses of head-to-head trials as a method of determining the relative efficacy. We employed indirect comparisons as an additional analytic tool only when no sufficient head-to-head evidence was available.

### Specific Results for Maintaining Response or Remission

The majority of studies included in our update involved treating patients with major depression in its acute phase; for this phase, the goal is reducing signs and symptoms of depression to achieve remission. Patients who achieve remission with acute-phase treatment should be followed to maintain that response and remission. That is, they should be managed in a continuation phase to prevent relapse and, if necessary, in a longer-term maintenance phase to prevent recurrence. (See Figure 1 in Introduction for clarification of these treatment cycles.)

Although evidence was sparse on the comparative efficacy and effectiveness for maintaining response or remission, treating recurrent depression, or treating depression that does not respond to first-line treatment, our findings are consistent with results from acute-phase trials. Overall, no substantial differences among second-generation antidepressants were apparent, but comparisons are limited to a few drugs.

Moderate strength evidence from six efficacy trials44, 61, 123, 146-149 suggests that no substantial differences in efficacy exist between escitalopram and desvenlafaxine, escitalopram and paroxetine, fluoxetine and sertraline, fluoxetine and venlafaxine, fluvoxamine and sertraline, and trazodone and venlafaxine for these longer-term treatment goals. One naturalistic study also provides fair-quality evidence that rehospitalization rates do not differ between patients continuing fluoxetine versus venlafaxine.150 Although results are consistent across these studies, evidence for other drug comparisons is not available; hence, these results are not generalizable to other second-generation antidepressants.

Additionally, trials differed in their design and conduct, further limiting the applicability (generalizability) of this evidence. For example, criteria used to define relapse and recurrence differed considerably across trials. As cases in point with respect to relapse: In the six head-to-head studies, one study defined relapse as an increase in the lowest HAM-D or MADRS score of at least 50 percent for 2 weeks, a HAM-D greater than 18 for 2 weeks, and a Clinical Global Impressions – Severity (CGI-S) score greater than 4;^61^ a second study defined relapse as a HAM-D score greater than 15 with functional impairment;146, 147 a third study defined relapse as a HAM-D score of 12 or greater for 2 consecutive visits;149 two trials did not define relapse but rather examined continued response (≥50 percent improvement in MADRS or HAM-D_17_ from baseline) or remission (MADRS≤12 or HAM-D_17_≤7);44, 148 and a fifth simply assessed discontinuation rates.123 Eligibility for continuation- or maintenance-phase treatment also varied considerably.

No evidence addressed how second-generation antidepressants compare when a patient responds to one agent and then is required to switch to a different agent (e.g., because of changes in insurance benefit). Because these circumstances may be relevant for many patients, future studies should consider this question.

We advise that, in future studies, investigators try to build on past and current work by employing definitions of relapse that are similar to those commonly found in the published literature to date. In our view, convergence on standard, accepted definitions of recurrence would be useful as well.

A related question may be how long to continue treatment intended to prevent relapse and recurrence. Although we did not set out to answer this question, we believe that some evidence suggests that the risk of relapse decreases over time. For example, one placebo-controlled study compared 14 weeks, 38 weeks, and 50 weeks of continuation treatment with fluoxetine or placebo.155 Relapse rates were significantly lower for patients on fluoxetine than for those on placebo at 14 and 38 weeks, but not at 50 weeks. This finding implies some degree of diminishing returns for longer treatment, although more work is needed to address this question.

### Specific Results for Managing Treatment-Resistant or Recurrent Depression

Overall, approximately 40 percent of patients do not achieve clinical response with initial treatment. Moreover, approximately 10 percent to 15 percent of patients discontinue treatment because of adverse events. Five studies addressed the comparative efficacy or effectiveness among second-generation antidepressants in patients with treatment-resistant depression. These studies came to inconsistent conclusions, although some of these inconsistencies may be partially explained by variations in the quality and applicability (i.e., internal and external validity) of these investigations. We rated the strength of evidence as low.

The best evidence comes from the Sequenced Treatment Alternatives to Relieve Depression (STAR*D) trial.194, 198 Among patients who did not have a remission or could not tolerate citalopram, the investigators reported that bupropion SR, sertraline, and venlafaxine XR had similar effectiveness and tolerability as second-line treatment. Although the ARGOS study, another effectiveness study, found venlafaxine to be superior to citalopram, fluoxetine, mirtazapine, paroxetine, and sertraline as a second-step treatment,191 differences were relatively small. Further, we could not determine whether raters were blinded to treatment allocation, potentially limiting the ARGOS conclusions. In four other efficacy studies, venlafaxine was numerically favored over SSRIs in three studies, although only the comparison with paroxetine was statistically significant. Additional research is needed to determine whether trends favoring venlafaxine are meaningful, and whether differences might exist among drugs not included in these studies.

No study specifically compared one antidepressant with another in patients experiencing a depressive relapse (i.e., loss of response during continuation-phase treatment) or recurrence (i.e., loss of response during maintenance-phase treatment). Although STAR*D included patients with a history of recurrent depressive episodes at study entry, the analyses involved patients whose acute-phase treatment of the current episode had been unsuccessful; the analyses did not involve patients who initially responded and then lost response.

### Specific Results for Treating Patients With Depression and Accompanying Symptoms

The range of physical and psychological symptoms that accompany depressive disorders is wide. Research involving depressed populations that may be more generalizable suggests that common presenting symptom clusters in both primary care and psychiatric clinics are anxiety, insomnia, and pain and other somatic symptoms.199

We found limited information for many accompanying symptom clusters; however, various symptoms may not have the same importance for clinical care. Our analyses concerned the efficacy and effectiveness of second-generation antidepressants for treating the depressive episode in patients with such symptoms and treating the accompanying symptoms in patients with depression.

In general, antidepressants were equally effective in treating the depressive episodes and the accompanying symptoms. The strength of evidence, however, was moderate only for few comparisons of second-generation antidepressants in patients with accompanying anxiety or pain. For all other symptom clusters, the strength of evidence was either low or insufficient or we found no evidence at all.

Seven head-to-head trials indicated that compared antidepressants have similar antidepressive efficacy in patients with accompanying anxiety symptoms.80, 84, 99, 113, 201-203 Likewise, results from eleven head-to-head trials suggested that antidepressant medications do not differ in efficacy for treating anxiety associated with MDD.43, 49, 52, 67, 84, 99, 107, 113, 201, 203 These studies involved comparisons of some SSRIs (fluoxetine, paroxetine, and sertraline), bupropion, and venlafaxine.

Patients with depression commonly experience physical symptoms; the majority are pain symptoms. In addition, depression is prevalent among patients with chronic pain disorders.336 A well conducted meta-analysis of three fair head-to-head trials87, 88, 218 and one poor trial216 found no substantial difference between duloxetine and paroxetine in the relief of accompanying pain.

For all other symptom clusters or drug-to-drug comparisons, either the strength of evidence was low, insufficient, or no evidence was found. We identified no evidence at all addressing treatment of melancholic symptoms, psychomotor change, or low energy and anhedonia.

### Specific Results for Harms (Adverse Events) and Adherence

#### Common Adverse Events

On average, 63 percent of patients experienced at least one adverse event during the course of the studies we reviewed. Nausea, headache, diarrhea, fatigue, dizziness, sweating, tremor, dry mouth, and weight gain were commonly reported adverse events.

Although the spectrum of adverse events is similar among second-generation antidepressants, the frequencies of specific adverse events differ among individual drugs. For example, venlafaxine had a higher rate of nausea and vomiting than the SSRIs as a class. Also, compared with other second-generation antidepressants, paroxetine frequently led to higher sexual side effects, mirtazapine and paroxetine to higher weight gains, and sertraline to a higher rate of diarrhea. Such differences did not lead to substantial differences in discontinuation rates.

For some patients, these differences might well be clinically important. For example, the choice of an agent with a low rate of sexual side effects might increase adherence in patients who consider sexual dysfunction an intolerable adverse event.

#### Severe Adverse Events

The evidence on the comparative risk for rare but severe adverse events such as suicidality, hyponatremia, seizures, or serotonin syndrome was insufficient to draw firm conclusions. The risk of such harms should be kept in mind during any course of treatment with a second-generation antidepressant.

#### Adherence and Persistence

Efficacy studies did not indicate any differences in adherence across agents. Observational studies indicated that extended-release formulations might have a better a persistence rate than immediate-release medications. This finding, however, could not be confirmed in the only double-blinded RCT that compared paroxetine IR (immediate release) with paroxetine CR (controlled release). An open-label RCT found better adherence in patients treated with fluoxetine weekly than fluoxetine daily during the maintenance phase of depression treatment. The evidence is insufficient to draw any conclusions about differences in adherence in effectiveness studies.

### Specific Results for Population Subgroups

In efficacy studies, treatment effects were similar between different age groups. Despite the importance of the harms of second-generation antidepressants, especially in the elderly, little evidence is available on this topic. Evidence suggests that adverse events may differ across second-generation antidepressants in the elderly. We found little or no head-to-head evidence assessing potential differences in efficacy in different racial groups or in patients with common comorbidities. Specifically for different racial groups and for patients with common comorbidities, the evidence is sparse and limited mainly to placebo-controlled trials assessing the general efficacy of second-generation antidepressants in such subgroups. Some of these studies indicated that the general efficacy of second-generation antidepressants in patients with serious comorbidities (e.g., cancer, substance abuse) is limited.

Many of these studies had serious methodological flaws or were too small to detect clinically meaningful differences, although they may not have been powered to detect statistically significant differences. Differences in study populations, cutoff points on scales, and drug dosages do not allow analysts to compare initial treatment effects across individual placebo-controlled trials to assess differences in subgroups other than those defined by age and sex.

### Specific Results for Dysthymia and Subsyndromal Depression

The evidence is sparse (strength of evidence for comparative efficacy is insufficient for dysthymia and subsyndromal depression). No conclusions can be drawn about comparative efficacy or effectiveness.

For dysthymia, the evidence on general efficacy is limited to fluoxetine, paroxetine, and sertraline; for subsyndromal depression, the evidence covers only citalopram, fluoxetine, and paroxetine. Results are mixed. For dysthymia, the two largest placebo-controlled studies did not detect any differences between fluoxetine or paroxetine and placebo for treating patients younger than 60 years.135, 136 Similarly, the evidence on the general efficacy in subsyndromal depression is limited to few studies with mixed results.

## Applicability of Results

A considerable limitation of our conclusions is that they have been derived primarily from efficacy trials. For example, for acute-phase MDD we found only 3 effectiveness studies out of 92 head-to-head RCTs. Two of these effectiveness studies were conducted in Europe, and the applicability to the U.S. health care system might be limited. Although findings from effectiveness studies are generally consistent with those from efficacy trials, the evidence is limited to a few comparisons. Whether, for acute-phase MDD, such findings can be further extrapolated to other second-generation antidepressants remains unclear.

Similar lack of applicability of findings pertains to treatment-resistant depression. For example, the STAR*D trial and the ARGOS study, which were both large effectiveness studies, provide evidence for only 8 of 13 antidepressants examined in this review.

Finally, the pharmaceutical industry funded a large percentage of the efficacy studies. Selective reporting is conceivable. Despite considerable effort to detect unpublished studies, we had no way to account for missing information.

## Limitations of Report

Several limitations of our review should be considered. As mentioned above, a large majority of studies were efficacy trials conducted in highly selected populations. The applicability of results to the average patient suffering from acute MDD might be limited. Furthermore, most studies were not powered to detect superiority of one treatment over another. Because of the small sample sizes, many studies led to indeterminate findings with confidence intervals encompassing clinically relevant differences. Meta-analyses can help to overcome such limitations and establish equivalence or superiority among treatments. For most subquestions, however, meta-analyses were not feasible. Claims of equivalence, therefore, must be viewed cautiously, and the 95 percent confidence intervals of potential differences need to be taken into consideration.

Indirect comparisons have methodological limitations, most prominently the assumption that prognostic factors for a specific outcome (e.g., response to treatment) are similar across study populations in the network meta-analyses. Nevertheless, they are a valuable additional analytic tool when available head-to-head evidence is insufficient.

Publication bias is a concern for all systematic reviews and has been empirically proven for placebo-controlled trials of second-generation antidepressants. Selective availability of studies with positive results can seriously bias conclusions, particularly when a pharmaceutical company compares two of its own drugs (as in the case of citalopram and escitalopram). The validity of statistical methods to explore publication bias, such as funnel plots, is limited because of the small number of studies for individual comparisons.

## Future Research

We identified multiple areas that require additional research to enable clinicians and researchers to draw firm conclusions about the comparative efficacy, effectiveness, and harms of second-generation antidepressants.

### Efficacy and Effectiveness

Future research has to establish reliably the general efficacy of second-generation antidepressants for the treatment of dysthymia and subsyndromal depression. Ideally, multiple-arm, head-to-head trials, including placebo groups, should evaluate the general and comparative efficacy of second-generation antidepressants in patients with these conditions. Effectiveness trials with less stringent eligibility criteria, health outcomes, long study durations, and a primary care population would be valuable to determine whether existing differences of second-generation antidepressants are clinically meaningful in “real world” settings. These trials should be powered to be able to assess minimal clinically significant differences. Furthermore, they could provide valuable information on differences in adherence among second-generation antidepressants.

Future research should also focus on differences in efficacy and effectiveness in subgroups such as the very elderly or patients with various common comorbidities.

### Prevention of Relapse and Recurrence

More evidence is needed regarding the most appropriate duration of antidepressant treatment for maintaining remission. Such studies should also evaluate whether different formulations (i.e., controlled release vs. immediate release) lead to differences in adherence and subsequently to differences in relapse or recurrence.

Additionally, although most trials maintained the dose used in acute-phase treatment throughout continuation and maintenance treatment, little is known about the effect of drug dose on the risk of relapse or recurrence. The effect of switching to a new drug after successful completion of acute or continuation phase treatment is poorly understood.

### Management of Treatment-Resistant or Recurrent Depression

Given the fact that approximately 40 percent of patients do not respond to initial treatment, additional head-to-head evidence is needed to resolve whether one second-generation antidepressant is better than another in patients who either did not respond or could not tolerate a first-line treatment. These studies also should assess how combinations of antidepressants compare with monotherapy in treatment resistant depression.

Likewise, evidence is lacking to determine whether one antidepressant is better than another in patients who cannot maintain remission during continuation- or maintenance-phase therapy. The role of other depression treatments, such as electroconvulsive therapy, psychotherapy, vagal nerve stimulation, repetitive transcranial magnetic stimulation, and others are used for treatment-resistant patients who do not respond to pharmacological treatment have to be explored.337

### Accompanying Symptoms

More research is needed to evaluate whether outcomes of second-generation antidepressants differ in populations with accompanying symptoms such as anxiety, insomnia, pain, and fatigue. Given that outcomes for depression treatment do not differ substantially between specific antidepressants, a higher priority for research might be to generate information about treatment of accompanying symptoms with antidepressants. Such evidence is key for clinicians who must select among many antidepressant drugs for patients with widely varying co-existing symptoms.

Study questions must be based on a clinically meaningful metric that gives preference to symptoms of high frequency or those that cause a high level of distress. Each subgroup must be clearly and consistently defined. For example, different investigator teams should identify their own patient groups using a consistent definition accepted in the field. Furthermore, they should then conduct their analyses in such subgroups using similarly defined, widely accepted outcomes. In this way, results can be compared across studies and across subgroups. Investigators should report the proportions of patients who reach a predefined threshold for clinically meaningful improvement.

The absence of any trials conducted in a population with change in appetite presents a clinically important void in the literature. In addition, future studies of depression with accompanying pain and other somatic symptoms should identify clinically relevant subgroups of patients with moderate to severe pain or other symptoms.

### Adverse Events

Large, well-conducted observational studies are needed to assess reliably the comparative risks of second-generation antidepressants with respect to rare but serious adverse events such as suicidality, hyponatremia, hepatotoxicity, seizures, cardiovascular adverse events, and serotonin syndrome. Furthermore, these studies need to evaluate whether very elderly patients such as patients older than 85 years old have an excess risk of severe adverse events with any second-generation antidepressant.