# Strength of Evidence Tables

Table 1 Strength of evidence for the comparative efficacy and effectiveness for second-generation antidepressants for the treatment of major depressive disorder in adults

Outcome; Number of Studies | Risk of Bias Design/ Quality | Consistency | Directness | Precision | Other considerations | Results | Strength of Evidence
Comparative efficacy 91 RCTs | Medium^1^ 88 RCTs/fair 3 RCTs/good | Consistent | Some indirectness^2^ | Precise | Publication bias is likely | Results from direct and indirect comparisons indicate that no substantial differences in efficacy exist among second-generation antidepressants. | Moderate
Comparative effectiveness 3 pragmatic RCTs | Medium^1^ 2 RCTs/fair 1 RCT/good | Consistent | Some indirectness^3^ | Precise | None | Direct evidence from three pragmatic trials and indirect evidence from efficacy trials indicate that no substantial differences in effectiveness exist among second-generation antidepressants. | Moderate
Quality of life 18 RCTs | Medium^1^ 18 RCTs/fair | Consistent | Some indirectness^4^ | Precise | None | Consistent results indicate that the efficacy of second-generation antidepressants with respect to quality of life does not differ among drugs | Moderate
Onset of action 7 RCTs | Medium^1^ 7 RCTs/fair | Consistent | Some indirectness^4^ | Precise | Publication bias is likely | Consistent results suggest that mirtazapine has a significantly faster onset of action than citalopram, fluoxetine, paroxetine, and sertraline (NNT for response after 1-2 weeks: 7; 95% CI 4-12) Whether this difference can be extrapolated to other second-generation antidepressants is unclear. Most other trials do not indicate a faster onset of action of one second-generation antidepressant compared with another. | Moderate

NNT: number needed to treat; RCT: randomized controlled trial

1 Considerable attrition in most studies; lack of reporting of allocation concealment

2 Most estimates of treatment effects are based on network meta-analyses

3 Indirect evidence from efficacy trials

4 Data are not available for all possible comparisons

Table 2 Strength of evidence for the comparative efficacy and effectiveness of second-generation antidepressants for the treatment of dysthymia

Outcome; Number of Studies | Risk of Bias Design/ Quality | Consistency | Directness | Precision | Other considerations | Results | Strength of Evidence
Comparative efficacy; none | NA | NA | NA | NA | NA | No evidence | Insufficient
Comparative effectiveness; none | NA | NA | NA | NA | NA | No evidence | Insufficient
Quality of life; none | NA | NA | NA | NA | NA | No evidence | Insufficient
Onset of action; none | NA | NA | NA | NA | NA | No evidence | Insufficient

Table 3 Strength of evidence for the comparative efficacy and effectiveness of second-generation antidepressants for the treatment of subsyndromal depression

Outcome; Number of Studies | Risk of Bias Design/ Quality | Consistency | Directness | Precision | Other considerations | Results | Strength of Evidence
Comparative efficacy; 1 RCT | High 1,2 1 non-randomized RCT/ fair | N/A | Direct | Imprecise^3^ | None | No difference between citalopram and sertraline. | Low
Comparative effectiveness; none | NA | NA | NA | NA | NA | No evidence | Insufficient
Quality of life; none | NA | NA | NA | NA | NA | No evidence | Insufficient
Onset of action; none | NA | NA | NA | NA | NA | No evidence | Insufficient

1 lack of randomization

2 lack of blinding

3 confidence intervals encompass clinically relevant differences

Table 4 Strength of evidence regarding efficacy and effectiveness of previously effective versus new second-generation antidepressants for the treatment of depressive disorders

Outcome; Number of Studies | Risk of Bias Design/ Quality | Consistency | Directness | Precision | Other considerations | Results | Strength of Evidence
Major depressive disorder; none | NA | NA | NA | NA | NA | No evidence | Insufficient
Dysthymia; none | NA | NA | NA | NA | NA | No evidence | Insufficient
Subsyndromal depression; none | NA | NA | NA | NA | NA | No evidence | Insufficient

Table 5 Strength of evidence for the differences in efficacy and effectiveness for second-generation antidepressants between immediate- and extended-release formulations

Outcome; Number of Studies | Risk of Bias Design/ Quality | Consistency | Directness | Precision | Other considerations | Results | Strength of Evidence
Major depressive disorder; 2 RCTs | Low 2 RCTs/Good | Consistent | Direct | Imprecise^2^ | None | Results indicate no differences in response to treatment between paroxetine IR and paroxetine CR. No differences in maintenance of response and remission between fluoxetine daily and fluoxetine weekly. | Moderate
Major depressive disorder; 2 RCTs | Medium^1^ 1 RCT/fair | N/A | Direct | Imprecise^2^ | None | One trial reported higher response rates for venlafaxine XR than venlafaxine IR. | Low
Dysthymia; none | NA | NA | NA | NA | NA | No evidence | Insufficient
Subsyndromal depression; none | NA | NA | NA | NA | NA | No evidence | Insufficient

1 Considerable attrition; lack of reporting of allocation concealment

2 Confidence intervals encompass differences that would be clinically irrelevant

Table 6 Strength of evidence for the comparative efficacy and effectiveness of second-generation antidepressants for maintaining response or remission (i.e., preventing relapse or recurrence) of continuing initial medications

Outcome; Number of Studies | Risk of Bias Design/ Quality | Consistency | Directness | Precision | Other considerations | Results | Strength of Evidence
Comparative efficacy 7 RCTs | Medium 7 RCTs/ fair | Consistent | Direct | Precise | Duration of relapse and recurrence prevention is variable and could influence results; not all comparisons are represented | Based on results from six efficacy trials and one naturalistic study, no significant differences exist between escitalopram and desvenlafaxine, escitalopram and paroxetine, fluoxetine and sertraline, fluoxetine and venlafaxine, fluvoxamine and sertraline, and trazodone and venlafaxine for preventing relapse or recurrence. | Moderate
Comparative effectiveness; none | NA | NA | NA | NA | NA | No evidence | Insufficient

Table 7 Strength of evidence for the comparative efficacy and effectiveness of second-generation antidepressants for maintaining response or remission (i.e., preventing relapse or recurrence) of switching medications

Outcome; Number of Studies | Risk of Bias Design/ Quality | Consistency | Directness | Precision | Other considerations | Results | Strength of Evidence
Comparative efficacy; none | NA | NA | NA | NA | NA | No evidence | Insufficient
Comparative effectiveness; none | NA | NA | NA | NA | NA | No evidence | Insufficient

Table 8 Strength of evidence for the comparative efficacy and effectiveness of second-generation antidepressants in managing treatment-resistant depression syndrome or treating recurrent depression

Outcome; Number of Studies | Risk of Bias Design/ Quality | Consistency | Directness | Precision | Other considerations | Results | Strength of Evidence
Comparative efficacy; 4 RCTs | Medium 4 RCTs/fair | Inconsistent | Direct | Imprecise | Not all comparisons are represented | Results from four trials suggest no differences, or only modest differences, between SSRIs and venlafaxine. Numerical trends favored venlafaxine over comparator drugs in three of these trials, but differences were statistically significant in only one trial, which compared venlafaxine with paroxetine. | Low
Comparative effectiveness; 2 RCTs | Medium 1 RCT/good 1 open trial/fair | Inconsistent | Direct | Imprecise^1^ | Good-rated trial assigned greater weight in conclusions due to risk of bias in fair-rated open trial; not all comparisons are represented | Results from two effectiveness studies are conflicting. Based on one trial rated good, no significant differences in effectiveness exist among bupropion SR, sertraline, and venlafaxine XR. One effectiveness trial found venlafaxine to be modestly superior to citalopram, fluoxetine, mirtazapine, paroxetine, and sertraline. | Low

1 data limited to two RCTs which showed differing results: one indicated a significant difference between agents and one showed no difference.

Table 9 Summary of findings with strength of evidence: Key Question 3: Comparative efficacy and effectiveness of second-generation antidepressants for treatment of depression in patients with accompanying symptom clusters

Outcome; Number of Studies | Risk of Bias Design/ Quality | Consistency | Directness | Precision | Other considerations | Results | Strength of Evidence
Anxiety: Comparative efficacy for depression; 7 RCTs | Medium 7 RCTs/ fair | Consistent | Some indirectness^1^ | Precise | None | Results from five head-to-head trials suggest that efficacy does not differ substantially for treatment of depression in patients with accompanying anxiety. | Moderate
Anxiety: Comparative effectiveness for depression; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Anxiety: Comparative efficacy for anxiety; 13 RCTs | Medium 13 RCTs/ fair | Consistent | Direct | Imprecise^2^ | None | Results from eight head-to-head trials and three placebo-controlled trials suggest that no substantial differences in efficacy exist among second-generation antidepressants for treatment of accompanying anxiety symptoms | Moderate
Anxiety: Comparative effectiveness for anxiety; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Insomnia: Comparative efficacy for depression; 2 RCTs | Medium 2 RCTs/ fair | Consistent | Some indirectness^1^ | Precise | None | Results from one head-to-head study are insufficient to draw conclusions about the comparative efficacy for treating depression in patients with coexisting insomnia. | Insufficient
Insomnia: Comparative effectiveness for depression; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Insomnia: Comparative efficacy for insomnia; 7 RCTs | Medium 7 RCTs/ fair | Inconsistent | Some indirectness^1^ | Imprecise^2^ | None | Results from five head-to-head trials suggest that no substantial differences in efficacy exist among second-generation antidepressants for treatment of accompanying insomnia. Results are limited by study design; differences in outcomes are of unknown clinical significance. | Low
Insomnia: Comparative effectiveness for insomnia; None | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Low Energy: Comparative efficacy for depression; 1 RCT | Medium 1 RCT/ fair | Consistency unknown (single study) | Indirect^3^ | Imprecise^3^ | None | Results from one placebo-controlled trial of bupropion XL is insufficient draw conclusions about treating depression in patients with coexisting low energy. Results from head-to-head trials are not available. | Insufficient
Low Energy: Comparative effectiveness for depression; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Low Energy: Comparative efficacy for low energy; 1 RCT | Medium 1 RCT/ fair | Consistency unknown (single study) | Indirect^3^ | Imprecise^3^ | None | Results from one placebo-controlled trial of bupropion XL are insufficient draw conclusions about treating low energy in depressed patients. Results from head-to-head trials are not available. | Insufficient
Low Energy: Comparative effectiveness for low energy; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Melancholia: Comparative efficacy for depression; none | Medium 2 RCTs/ fair | Inconsistent^4^ | Some indirectness^1^ | Imprecise^4^ | None | Results from two head-to-head trials are insufficient to draw conclusions about treating depression in patients with coexisting melancholia. Results are inconsistent across studies. | Insufficient
Melancholia: Comparative effectiveness for depression (zero studies) | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Melancholia: Comparative efficacy for melancholia; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Melancholia: Comparative effectiveness for melancholia; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Pain: Comparative efficacy for depression; 2 RCTs | Medium 2 RCTs/ fair | Inconsistent^5^ | Indirect^5^ | Imprecise^5^ | None | Results from two placebo-controlled trials are conflicting regarding the superiority of duloxetine over placebo. Results from head-to-head trials are not available. | Insufficient
Pain: Comparative effectiveness for depression; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Pain: Comparative efficacy for pain; 6 RCTs, 1 SR | Medium 1 SR, 6 RCTs/ fair | Consistent | Some indirectness^1^ | Precise | None | Evidence from one systematic review, two head-to-head trials (one poor) and five placebo-controlled trials indicate no difference in efficacy between paroxetine and duloxetine. | Moderate
Pain: Comparative effectiveness for pain; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Psychomotor change: Comparative efficacy for depression; None | Medium 1 RCT/ fair | Consistency unknown (single study) | Indirect^6^ | Imprecise^6^ | None | Results from one head-to-head trial is insufficient to draw conclusions about the comparative efficacy for treating depression in patients with coexisting psychomotor change. | Insufficient
Psychomotor change: Comparative effectiveness for depression; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Psychomotor change: Comparative efficacy for psychomotor change; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Psychomotor change: Comparative effectiveness for psychomotor change; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Somatization: Comparative efficacy for depression; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Somatization: Comparative effectiveness for depression; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Somatization: Comparative efficacy for somatization; 1 RCT | Medium 1 RCT/ fair | Consistency unknown (single study) | Indirect^7^ | Imprecise^7^ | None | Results from one head-to-head trial are insufficient to draw conclusions about the comparative efficacy for treating somatization in depressed patients. Results indicate similar improvement in somatization. | Insufficient
Somatization: Comparative effectiveness for somatization; 1 RCT | Medium 1 RCT/ fair | Consistency unknown (single study) | Indirect^7^ | Imprecise^7^ | None | Evidence from one open-label head-to-head trial is insufficient to draw conclusions about the comparative efficacy for treating coexisting somatization in depressed patients. Results indicate no difference in effectiveness. | Insufficient

N/A: not applicable; RCT: randomized controlled trial; SR: systematic review

1 data are not available for all possible comparisons.

2 some comparisons showed a statistically significant difference, but the majority did not. Therefore is precision of this result is low.

3 data limited to the results of one placebo-controlled trial.

4 data limited to two RCTs which showed differing results: one indicated a significant difference between agents and one showed no difference.

5 data limited to two placebo-controlled RCTs which showed conflicting results.

6 data limited to one RCT

7 data limited to one trial and not all possible comparisons

Table 10 Summary of findings with strength of evidence: Key Question 4a: Comparative risk of harms (safety, adverse events), adherence, and persistence

Outcome; Number of Studies | Risk of Bias Design/ Quality | Consistency | Directness | Precision | Other considerations | Results | Strength of Evidence
General tolerability: Adverse events profiles; 140 Studies | Low 92 RCTs 48 studies of other designs/good or fair | Consistent | Direct | Precise | None | Adverse events profiles of experimental or observational studies are similar among second-generation antidepressants. The incidence of specific adverse events differs across antidepressants | High
General tolerability: Comparative risk of nausea and vomiting; 15 RCTs | Low 15 RCTs/fair | Consistent | Direct | Precise | None | Meta-analysis of 15 studies indicates that venlafaxine has a higher rate of nausea and vomiting than SSRIs as a class (RR 1.52; 1.25 to 1.84). | High
General tolerability: Comparative risk of weight change; 7 RCTs | Medium^1^ 7 RCTs/fair | Consistent | Direct | Precise | None | Results indicate that mirtazapine leads to higher weight gains than citalopram, fluoxetine, paroxetine, and sertraline (range 0.8 to 3.0 kg after 6 to 8 weeks). | High
General tolerability: Comparative risk of gastrointestinal adverse events; 7 RCTs | Medium^1^ 7 RCTs/fair | Consistent | Direct | Precise | None | Results indicate that sertraline has on average an 8% (3 to 11%) higher incidence of diarrhea than bupropion, citalopram, fluoxetine, fluvoxamine, mirtazapine, nefazodone, paroxetine, and venlafaxine. Results from one systematic review confirm some of these findings. | Moderate
General tolerability: Comparative risk of somnolence; 6 RCTs | Medium^1^ 6 RCTs/fair | Consistent | Direct | Precise | None | Results indicate that trazodone has a higher rate of somnolence than bupropion, fluoxetine, mirtazapine, paroxetine, and venlafaxine. | Moderate
General tolerability: Comparative risk of discontinuation syndrome; 1 RCT | Low Low 1 systematic review/good | Consistent | Some indirectness^2^ | Precise | None | A good systematic review indicates that paroxetine and venlafaxine have the highest rates of discontinuation syndrome; fluoxetine has the lowest. | Moderate
General tolerability: Comparative risk of discontinuation of treatment; 3 MAs | Low 3 meta-analyses/good | Consistent | Direct | Precise | None | Meta-analyses of numerous efficacy trials indicate that overall discontinuation rates are similar. Duloxetine and venlafaxine have a higher rate of discontinuations because of adverse events than SSRIs as a class. Venlafaxine has a lower rate of discontinuations because of lack of efficacy than SSRIs as a class. | High
Severe adverse events: Comparative risk of suicidality (suicidal thoughts and behavior); 16 Studies | High 9 observational studies/fair 2observational studies/good 4 meta-analyses/good 1 systematic review/fair | Inconsistent | Indirect^3^ | Imprecise^4^ | Reporting and classification bias likely | Results yield conflicting information about the comparative risk of suicidality. | Insufficient
Severe adverse events: Comparative risk of sexual dysfunction; 7 RCTs | Low 7 RCTs/fair | Consistent | Direct | Precise | None | Results indicate that bupropion causes significantly less sexual dysfunction than escitalopram, fluoxetine, paroxetine, and sertraline. | High
Severe adverse events: Comparative risk of seizures; 3 Studies | Medium^5^ 2 open-label trials/fair 1 prospective cohort study/good | Inconsistent | Direct | Imprecise^4^ | None | Results yield conflicting information about the comparative risk of seizures. | Insufficient
Severe adverse events: Cardiovascular events; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Severe adverse events: Comparative risk of hyponatremia; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Severe adverse events: Comparative risk of hepatotoxicity; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Severe adverse events: Comparative risk of serotonin syndrome; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Adherence: Comparative adherence in efficacy studies; 8 RCTs | Medium^1^ 6 RCTs/fair 2 RCTs/good | Consistent | Direct | Precise | None | Efficacy studies indicate no differences in adherence. | Moderate
Adherence: Comparative adherence in effectiveness studies; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Comparative persistence; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient

1 Considerable attrition in most studies; lack of reporting of allocation concealment

2 Only few drugs have been assessed

3 Few direct head-to-head comparisons

4 Event rates too low to draw conclusions about the comparative risk

5 Lack of blinding; lack of reporting of allocation concealment

Table 11 Summary of findings with strength of evidence: Key Question 4b: Differences in harms, adherence, and persistence between immediate- and extended-release formulations

Outcome; Number of Studies | Risk of Bias Design/ Quality | Consistency | Directness | Precision | Other considerations | Results | Strength of Evidence
Major depressive disorder: Comparative risk of harms; 4RCTs | Medium^1^ 3 RCTs/fair | Consistent | Direct | Imprecise^2^ | None | Findings from one trial each indicate that no differences in harms exist between fluoxetine daily and fluoxetine weekly or between venlafaxine IR and venlafaxine XR. | Moderate
Major depressive disorder: Comparative risk of harms; 4RCTs | 1 RCT/fair | Consistent | Direct | Imprecise^2^ | None | One trial provides evidence that paroxetine IR leads to higher rates of nausea than paroxetine CR. | Low
Major depressive disorder: Comparative adherence; 2 RCTs | Medium^1^ 1 RCT/ fair 1 open-label RCT/fair | Consistent | Direct | Imprecise^2^ | None | One trial provides evidence that fluoxetine weekly has better adherence rates than fluoxetine daily. No differences in adherence could be detected for paroxetine IR and paroxetine CR. | Moderate
Major depressive disorder: Comparative persistence; 1 cohort study | High^3^ Retrospective cohort study/high | Consistent | Direct | Precise | None | Evidence from one observational study indicates that prescription refills are more common with the extended- than the immediate-release formulation of bupropion. | Low
Dysthymia; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Subsyndromal depression; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient

1 Considerable attrition; lack of reporting of allocation concealment

2 Confidence intervals encompass differences that would be clinically irrelevant

3 Selection bias likely

Table 12 Summary of findings with strength of evidence: Key Question 5: Subgroups

Outcome; Number of Studies | Risk of Bias Design/ Quality | Consistency | Directness | Precision | Other considerations | Results | Strength of Evidence
Age: Comparative efficacy in MDD; 11 RCTs | Medium 10 RCTs/fair 1 RCT/good | Consistent | Direct | Some imprecision | None | Efficacy does not differ substantially among second-generation antidepressants for treating MDD in patients age 60 years or older. | Moderate
Age: Comparative efficacy in dysthymia or subsyndromal depression; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Age: Comparative effectiveness in MDD, dysthymia or sybsyndromal depression; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Age: Comparative harms in MDD 7 RCTs | Medium 6 RCTs/fair 1 RCT/good | Some inconsistency | Direct | Imprecise | None | Adverse events may differ somewhat across second-generation antidepressants in older adults. | Low
Age: Comparative harms in dysthymia or sybsyndromal depression; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Sex: Comparative efficacy; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Sex: Comparative effectiveness; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Sex: Comparative harms ; | Medium 2 RCTs/fair | Consistent | Direct | Precise | None | Two trials suggest differences between men and women in sexual side effects | Low
Race or Ethnicity: Comparative efficacy; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Race or Ethnicity: Comparative effectiveness; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Race or Ethnicity: Comparative harms; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Comorbidities: Comparative efficacy: 1 RCT | Low 1 RCT/fair | Unknown, 1 trial | Direct | Precise | Subgroup analysis of one RCT | Results from a subgroup analysis of one trial indicate significantly greater response with venlafaxine XR than fluoxetine in patients with MDD and comorbid generalized anxiety disorder. | Low
Comorbidities: Comparative effectiveness; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient
Comorbidities: Comparative harms; none | N/A | N/A | N/A | N/A | N/A | No evidence | Insufficient