# Bibliography of References by Database Searched

1 Depression guideline panel. Depression in primary care: Volume 2, Treatment of major depression. Vol AHCPR publication No 93-0550. Rockville, MD. US DHHS, Public Health Service, Agency for Health Care Policy and Research. 1993. Source: Handsearch.
2 Citalopram: clinical effect profile in comparison with clomipramine. A controlled multicenter study. Danish University Antidepressant Group. Psychopharmacology (Berl). 1986;90(1):131-8. Source: PubMed. [pmid: 2876451].
3 A double-blind multi-centre trial of fluoxetine and dothiepin in major depressive illness. South Wales Antidepressant Drug Trial Group. Int Clin Psychopharmacol. Jan. 1988;3(1):75-81. Source: PubMed. [pmid: 3282004].
4 Paroxetine: a selective serotonin reuptake inhibitor showing better tolerance, but weaker antidepressant effect than clomipramine in a controlled multicenter study. Danish University Antidepressant Group. J Affect Disord. Apr. 1990;18(4):289-99. Source: PubMed. [pmid: 2140382].
5 Additional cases of suicidal ideation associated with fluoxetine. Am J Psychiatry. Nov. 1990;147(11):1570-1. Source: PubMed. [pmid: 2135165].
6 Novel selective serotonin reuptake inhibitors, Part II. J Clin Psychiatry. Jun. 1992;53(6):216-21. Source: PubMed. [pmid: 1535073].
7 Safety and efficacy of paroxetine in elderly patients. Geriatrics. Nov. Suppl 2. 1993;48:13-5. Source: PubMed.
8 SSRIs: Prozac and company - part II. Harv Ment Health Lett. Nov. 2000;17(5):1-3. Source: PubMed.
9 Practice guideline for the treatment of patients with major depressive disorder (revision). American Psychiatric Association. Am J Psychiatry. Apr. 2000;157(4 Suppl):1-45. Source: PubMed.
10 Fluoxetine (Sarafem) for premenstrual dysphoric disorder. Med Lett Drugs Ther. Jan. 22. 2001;43(1096):5-6. Source: PubMed. [pmid: 11177220].
11 An open, baseline controlled evaluation of sertraline safety and efficacy in the treatment of depression in Thai patients. J Med Assoc Thai. Jan. 2001;84(1):54-62. Source: PubMed. [pmid: 11281500].
12 The brain tells: early signs of depression recovery. Harv Ment Health Lett. Nov. 2002;19(5):6. Source: PubMed.
13 Paroxetine Adult Suicidality Analysis: Major Depressive Disorder and Non-Major Depressive Disorder. http://wwwgskcom/media/paroxetine/briefing_docpdf. 2006. Source: Handsearch.
14 Summaries for patients. Use of drugs to treat depression: guidelines from the American College of Physicians. Ann Intern Med. Nov. 18. 2008;149(10):I56. Source: PubMed.
15 Persistence is the key to treating nonpsychotic major depressive disorder in elderly patients. Drugs and Therapy Perspectives. 2008;24(5):17-20. Source: EMBASE.
16 Agomelatine: new drug. Adverse effects and no proven efficacy. Prescrire Int. Dec. 2009;18(104):241-5. Source: PubMed. [pmid: 20020562].
17 A double-blind, placebo-controlled treatment trial of citalopram for major depressive disorder in older patients with heart failure: the relevance of the placebo effect and psychological symptoms. Contemp Clin Trials. 2009;(3):205-11. Source: PubMed. [pmid: 19470312].
18 Centre for Reviews and Dissemination. Systematic reviews: CRD's guidance for undertaking reviews in health care. 2009. Source: Handsearch.
19 Davidson RJ, Irwin W, Anderle MJ, et al. The neural substrates of affective processing in depressed patients treated with venlafaxine. Am J Psychiatry. Jan. 2003;160(1):64-75. Source: PubMed. [pmid: 12505803].
20 Aberg-Wistedt A, Agren H, Ekselius L, et al. Sertraline versus paroxetine in major depression: clinical outcome after six months of continuous therapy. J Clin Psychopharmacol. Dec. 2000;20(6):645-52. Source: PubMed. [pmid: 11106136].
21 Aberg-Wistedt A, Hasselmark L, Stain-Malmgren R, et al. Serotonergic ‘vulnerability’ in affective disorder: a study of the tryptophan depletion test and relationships between peripheral and central serotonin indexes in citalopram-responders. Acta Psychiatr Scand. May. 1998;97(5):374-80. Source: PubMed. [pmid: 9611088].
22 Abraham G. Massive weight gain and hostility force mirtazapine stoppage. Can J Psychiatry. Aug. 2002;47(6):582. Source: PubMed. [pmid: 12211888].
23 Abraham G, Milev R, Stuart Lawson J. T3 augmentation of SSRI resistant depression. J Affect Disord. Apr. 2006;91(2-3):211-5. Source: PubMed. [pmid: 16483669].
24 Acharya N, Rosen AS, Polzer JP, et al. Duloxetine: meta-analyses of suicidal behaviors and ideation in clinical trials for major depressive disorder. J Clin Psychopharmacol. 2006;26(6):587-94. Source: PubMed. [pmid: 17110815].
25 Ackerman DL, Greenland S, Bystritsky A. Clinical characteristics of response to fluoxetine treatment of obsessive-compulsive disorder. Journal Of Clinical Psychopharmacology. 1998;18(3):185-92. Source: EMBASE.
26 Ackerman DL, Greenland S, Bystritsky A, et al. Characteristics of fluoxetine versus placebo responders in a randomized trial of geriatric depression. Psychopharmacol Bull. 1997;33(4):707-14. Source: PubMed. [pmid: 9493483].
27 Adams-Fryatt A. Acknowledging, recognizing, and treating depression in elderly long-term care residents. Annals of Long-Term Care. 2010;18(11):30-2. Source: EMBASE.
28 Adan-Manes J, Novalbos J, Lopez-Rodriguez R, et al. Lithium and venlafaxine interaction: a case of serotonin syndrome. J Clin Pharm Ther. Aug. 2006;31(4):397-400. Source: PubMed. [pmid: 16882112].
29 Addington D, Addington J, Patten S, et al. Double-blind, placebo-controlled comparison of the efficacy of sertraline as treatment for a major depressive episode in patients with remitted schizophrenia. J Clin Psychopharmacol. Feb. 2002;22(1):20-5. Source: PubMed. [pmid: 11799338].
30 Adeoye OM, Ferrell RE, Kirshner MA, et al. alpha1-acid glycoprotein in late-life depression: relationship to medical burden and genetics. J Geriatr Psychiatry Neurol. Dec. 2003;16(4):235-9. Source: PubMed. [pmid: 14653433].
31 Aga VM, Barklage NE, Jefferson JW. Linezolid, a monoamine oxidase inhibiting antibiotic, and antidepressants. J Clin Psychiatry. May. 2003;64(5):609-11. Source: PubMed. [pmid: 12755668].
32 Agelink MW, Majewski T, Wurthmann C, et al. Autonomic neurocardiac function in patients with major depression and effects of antidepressive treatment with nefazodone. J Affect Disord. Feb. 2001;62(3):187-98. Source: PubMed. [pmid: 11223106].
33 Agius M, Gardner J, Liu K, et al. An audit to compare discharge rates and suicidality between antidepressant monotherapies prescribed for unipolar depression. Psychiatr Danub. Jun. 2010;22(2):350-3. Source: PubMed. [pmid: 20562780].
34 Agius M, Gardner J, Liu K, et al. An audit to compare discharge rates between antidepressant monotherapies prescribed for pure unipolar depression versus depression in the presence of other indications. Psychiatr Danub. Jun. 2010;22(2):346-9. Source: PubMed. [pmid: 20562779].
35 Agosti V. One year clinical and psychosocial outcomes of early-onset chronic depression. J Affect Disord. Jul. 1999;54(1-2):171-5. Source: PubMed. [pmid: 10403160].
36 Agosti V, McGrath PJ. Comparison of the effects of fluoxetine, imipramine and placebo on personality in atypical depression. J Affect Disord. Sep. 2002;71(1-3):113-20. Source: PubMed. [pmid: 12167507].
37 Agosti V, Stewart JW. Six month follow-up of early-onset chronic depression. Depression. 1996;4(2):63-7. Source: PubMed. [pmid: 9160642].
38 Aguglia E, Casacchia M, Cassano GB, et al. Double-blind study of the efficacy and safety of sertraline versus fluoxetine in major depression. Int Clin Psychopharmacol. Fall. 1993;8(3):197-202. Source: PubMed. [pmid: 8263318].
39 Ahlfors UG, Elovaara S, Harma P, et al. Clinical multicentre study of citalopram compared double-blindly with mianserin in depressed patients in Finland. Nordisk Psykiatrisk Tidsskrift. 1988;42(3):201-10. Source: EMBASE.
40 Ahmed I, Dagincourt PG, Miller LG, et al. Possible interaction between fluoxetine and pimozide causing sinus bradycardia. Can J Psychiatry. Feb. 1993;38(1):62-3. Source: PubMed. [pmid: 8448725].
41 Ahmed R, Eagleton C. Toxic epidermal necrolysis after paroxetine treatment. N Z Med J. May. 23. 2008;121(1274):86-9. Source: PubMed. [pmid: 18535650].
42 Ahrold TK, Meston CM. Effects of SNS activation on SSRI-induced sexual side effects differ by SSRI. J Sex Marital Ther. 2009;35(4):311-9. Source: PubMed. [pmid: 19466669].
43 Aikens JE, Nease DE Jr, Klinkman MS. Explaining patients' beliefs about the necessity and harmfulness of antidepressants. Annals of Family Medicine. 2008;6(1):23-9. Source: EMBASE. [pmid: 18195311].
44 Akerblad AC, Bengtsson F, Ekselius L, et al. Effects of an educational compliance enhancement programme and therapeutic drug monitoring on treatment adherence in depressed patients managed by general practitioners. Int Clin Psychopharmacol. Nov. 2003;18(6):347-54. Source: PubMed. [pmid: 14571155].
45 Akerblad AC, Bengtsson F, von Knorring L, et al. Response, remission and relapse in relation to adherence in primary care treatment of depression: a 2-year outcome study. Int Clin Psychopharmacol. Mar. 2006;21(2):117-24. Source: PubMed. [pmid: 16421464].
46 Akhondzadeh S, Faraji H, Sadeghi M, et al. Double-blind comparison of fluoxetine and nortriptyline in the treatment of moderate to severe major depression. J Clin Pharm Ther. Oct. 2003;28(5):379-84. Source: PubMed. [pmid: 14632962].
47 Akiskal HS. Dysthymic and cyclothymic depressions: therapeutic considerations. J Clin Psychiatry. Apr. 1994;55(Suppl):46-52. Source: PubMed. [pmid: 8077176].
48 Akiskal HS, Benazzi F. Does the FDA proposed list of possible correlates of suicidality associated with antidepressants apply to an adult private practice population?. Journal of Affective Disorders. 2006;94(1-3):105-10. Source: EMBASE. [pmid: 16766043].
49 Akkaya C, Sivrioglu EY, Akgoz S, et al. Comparison of efficacy and tolerability of reboxetine and venlafaxine XR in major depression and major depression with anxiety features: an open label study. Hum Psychopharmacol. Jul. 2006;21(5):337-45. Source: PubMed. [pmid: 16856215].
50 Álamo C, López-Munoz F, Rubio G, et al. Combined treatment with reboxetine in depressed patients with no response to venlafaxine: A 6-week follow-up study. Acta Neuropsychiatrica. Oct. 2007. 2007;19(5):291-6. Source: PsycINFO.
51 Albers LJ, Reist C, Helmeste D, et al. Paroxetine shifts imipramine metabolism. Psychiatry Res. Jan. 31. 1996;59(3):189-96. Source: PubMed. [pmid: 8930024].
52 Albert R, Ebert D. Full efficacy of SSRI treatment in refractory dysthymia is achieved only after 16 weeks. J Clin Psychiatry. Apr. 1996;57(4):176. Source: PubMed. [pmid: 8601556].
53 Alby JM, Cabane J, Ferreri M, et al. Efficacy and acceptability of tianeptine in major depressive disorder and in dysthymia (DSM-IIIR) with somatic complaints: Double blind study versus fluoxetine. European Neuropsychopharmacology. 1993;3(3):333. Source: EMBASE.
54 Alby JM, Ferreri M, Cabane J, et al. Efficacy of tianeptine (Stablon(TM)) for the treatment of major depression and dysthymia with somatic complaints. A comparative study versus fluoxetine (Prozac(TM)). Annales de Psychiatrie. 1993;8(2):136-44. Source: EMBASE.
55 Alderman CP, Frith PA. Fluvoxamine-methadone interaction. Aust N Z J Psychiatry. Feb. 1999;33(1):99-101. Source: PubMed. [pmid: 10197892].
56 Alderman CP, Gebauer MG, Gilbert AL, et al. Possible interaction of zopiclone and nefazodone. Ann Pharmacother. Nov. 2001;35(11):1378-80. Source: PubMed. [pmid: 11724087].
57 Alderman CP, Hundertmark JD, Soetratma TW. Interaction of serotonin re-uptake inhibitors with perhexiline. Aust N Z J Psychiatry. Aug. 1997;31(4):601-3. Source: PubMed. [pmid: 9272272].
58 Alderman CP, Lee PC. Comment: Serotonin syndrome associated with combined sertraline-amitriptyline treatment. Ann Pharmacother. Dec. 1996;30(12):1499-500. Source: PubMed. [pmid: 8968471].
59 Alevizos B, Vaidakis N, Alevizos E. Increased libido with the combined use of venlafaxine and mirtazapine. J Clin Psychopharmacol. Apr. 2005;25(2):194-6. Source: PubMed. [pmid: 15738758].
60 Alexopoulos GS, Canuso CM, Gharabawi GM, et al. Placebo-controlled study of relapse prevention with risperidone augmentation in older patients with resistant depression. Am J Geriatr Psychiatry. Jan. 2008;16(1):21-30. Source: PubMed. [pmid: 17928573].
61 Alexopoulos GS, Glatt CE, Hoptman MJ, et al. BDNF val66met polymorphism, white matter abnormalities and remission of geriatric depression. J Affect Disord. Sep. 2010;125(1-3):262-8. Source: PubMed. [pmid: 20346518].
62 Alexopoulos GS, Katz IR, Reynolds CF 3rd, et al. The expert consensus guideline series. Pharmacotherapy of depressive disorders in older patients. Postgrad Med. Oct. Spec No Pharmacotherapy. 2001:1-86. Source: PubMed.
63 Alexopoulos GS, Kiosses DN, Choi SJ, et al. Frontal white matter microstructure and treatment response of late-life depression: a preliminary study. Am J Psychiatry. Nov. 2002;159(11):1929-32. Source: PubMed. [pmid: 12411231].
64 Alexopoulos GS, Kiosses DN, Murphy C, et al. Executive dysfunction, heart disease burden, and remission of geriatric depression. Neuropsychopharmacology. Dec. 2004;29(12):2278-84. Source: PubMed. [pmid: 15340393].
65 Alexopoulos GS, Murphy CF, Gunning-Dixon FM, et al. Event-related potentials in an emotional go/no-go task and remission of geriatric depression. Neuroreport. Feb. 12. 2007;18(3):217-21. Source: PubMed. [pmid: 17314660].
66 Alexopoulos GS, Murphy CF, Gunning-Dixon FM, et al. Microstructural white matter abnormalities and remission of geriatric depression. Am J Psychiatry. Feb. 2008;165(2):238-44. Source: PubMed. [pmid: 18172016].
67 Allard P, Gram L, Timdahl K, et al. Efficacy and tolerability of venlafaxine in geriatric outpatients with major depression: a double-blind, randomised 6-month comparative trial with citalopram. Int J Geriatr Psychiatry. Dec. 2004;19(12):1123-30. Source: PubMed. [pmid: 15526307].
68 Almeida AGD, Quarantini LC, Batista-Neves S, et al. Is the interferon-(alpha)-triggered depressive episode a self-limited kind of depression? Four cases of persistent affective symptoms after antiviral treatment in HCV-infected individuals. World Journal of Biological Psychiatry. 2010;11(7):914-8. Source: EMBASE. [pmid: 20642400].
69 Almeida OP, Alfonso H, Hankey GJ, et al. Depression, antidepressant use and mortality in later life: The health in men study. PLoS One. 2010;5(6). Source: EMBASE.
70 Almeida OP, Waterreus A, Hankey GJ. Preventing depression after stroke: Results from a randomized placebo-controlled trial. J Clin Psychiatry. Jul. 2006;67(7):1104-9. Source: PubMed. [pmid: 16889454].
71 Alonso M, Val E, Rapaport MH. An open-label study of SSRI treatment in depressed hispanic and non-Hispanic women. J Clin Psychiatry. Jan. 1997;58(1):31. Source: PubMed. [pmid: 9055837].
72 Alpert JE, Biggs MM, Davis L, et al. Enrolling research subjects from clinical practice: ethical and procedural issues in the Sequenced Treatment Alternatives to Relieve Depression (STAR*D) trial. Psychiatry Res. Feb. 28. 2006;141(2):193-200. Source: PubMed. [pmid: 16457894].
73 Alpert JE, Maddocks A, Rosenbaum JF, et al. Childhood psychopathology retrospectively assessed among adults with early onset major depression. J Affect Disord. Jul. 1994;31(3):165-71. Source: PubMed. [pmid: 7963068].
74 Alpert JE, Papakostas G, Mischoulon D, et al. S-adenosyl-L-methionine (SAMe) as an adjunct for resistant major depressive disorder: an open trial following partial or nonresponse to selective serotonin reuptake inhibitors or venlafaxine. J Clin Psychopharmacol. Dec. 2004;24(6):661-4. Source: PubMed. [pmid: 15538131].
75 Alpert JE, Uebelacker LA, McLean NE, et al. The Mini-Mental State Examination among adult outpatients with major depressive disorder. Psychother Psychosom. 1995;63(3-4):207-11. Source: PubMed. [pmid: 7624468].
76 Alpert M, Pouget ER, Silva RR. Reflections of depression in acoustic measures of the patient's speech. J Affect Disord. Sep. 2001;66(1):59-69. Source: PubMed. [pmid: 11532533].
77 Altamura AC, De Novellis F, Guercetti G, et al. Fluoxetine compared with amitriptyline in elderly depression: a controlled clinical trial. Int J Clin Pharmacol Res. 1989;9(6):391-6. Source: PubMed. [pmid: 2699465].
78 Altamura AC, Dell'Osso B, Buoli M, et al. Short-term intravenous citalopram augmentation in partial/nonresponders with major depression: a randomized placebo-controlled study. Int Clin Psychopharmacol. Jul. 2008;23(4):198-202. Source: PubMed. [pmid: 18545057].
79 Altamura AC, Dell'Osso B, Mundo E, et al. Duration of untreated illness in major depressive disorder: A naturalistic study. International Journal of Clinical Practice. 2007;61(10):1697-700. Source: EMBASE. [pmid: 17877655].
80 Altamura AC, Mauri MC, Colacurcio F, et al. Trazodone in late life depressive states: a double-blind multicenter study versus amitriptyline and mianserin. Psychopharmacology (Berl). 1988;95(Suppl):S34-6. Source: PubMed. [pmid: 3133712].
81 Altamura AC, Mauri MC, Rudas N, et al. Clinical activity and tolerability of trazodone, mianserin, and amitriptyline in elderly subjects with major depression: a controlled multicenter trial. Clin Neuropharmacol. Suppl 1. 1989;12:S25-33. S4. 7. Source: PubMed. [pmid: 2663151].
82 Altamura AC, Montgomery SA, Wernicke JF. The evidence for 20mg a day of fluoxetine as the optimal dose in the treatment of depression. Br J Psychiatry Suppl. 1988;(3):109-12. Source: PubMed. [pmid: 3074862].
83 Altamura AC, Percudani M, Guercetti G, et al. Efficacy and tolerability of fluoxetine in the elderly: a double-blind study versus amitryptiline. Int Clin Psychopharmacol. Jan. Suppl 1. 1989;4:103-6. Source: PubMed. [pmid: 2783697].
84 Altintoprak AE, Zorlu N, Coskunol H, et al. Effectiveness and tolerability of mirtazapine and amitriptyline in alcoholic patients with co-morbid depressive disorder: a randomized, double-blind study. Hum Psychopharmacol. 2008;23(4):313-9. Source: PubMed. [pmid: 18327889].
85 Altman EM, Manos GH. Serotonin syndrome associated with citalopram and meperidine. Psychosomatics. Jul-Aug. 2007;48(4):361-3. Source: PubMed. [pmid: 17600178].
86 Altshuler LL. Fluoxetine-associated panic attacks. J Clin Psychopharmacol. Dec. 1994;14(6):433-4. Source: PubMed. [pmid: 7884030].
87 Altshuler LL, Pierre JM, Wirshing WC, et al. Sertraline and akathisia. J Clin Psychopharmacol. Aug. 1994;14(4):278-9. Source: PubMed. [pmid: 7962686].
88 Alvarez JC, Gluck N, Arnulf I, et al. Decreased platelet serotonin transporter sites and increased platelet inositol triphosphate levels in patients with unipolar depression: effects of clomipramine and fluoxetine. Clin Pharmacol Ther. Dec. 1999;66(6):617-24. Source: PubMed. [pmid: 10613618].
89 Alves C, Cachola I, Brandao J. Efficacy and tolerability of venlafaxine and fluoxetine in outpatients with major depression. Primary Care Psychiatry. 1999;5(2):57-63. Source: EMBASE.
90 Alves TCTF, Rays J, Telles RMS, et al. Effects of antidepressant treatment on cognitive performance in elderly subjects with heart failure and comorbid major depression: An exploratory study. Psychosomatics. 2007;48(1):22-30. Source: EMBASE. [pmid: 17209146].
91 Al-Yassiri MM, Ankier SI, Bridges PK. A double blind comparison of the efficacy and safety of trazodone and imipramine in endogenous depression. J Affect Disord. Nov. 1983;5(4):333-40. Source: PubMed. [pmid: 6229564].
92 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. Fourth edition, Text Revision. Washington, DC. 2000. Source: Handsearch.
93 Ames D, Wirshing WC, Szuba MP. Organic mental disorders associated with bupropion in three patients. J Clin Psychiatry. Feb. 1992;53(2):53-5. Source: PubMed. [pmid: 1541606].
94 Amini H, Aghayan S, Jalili SA, et al. Comparison of mirtazapine and fluoxetine in the treatment of major depressive disorder: a double-blind, randomized trial. J Clin Pharm Ther. Apr. 2005;30(2):133-8. Source: PubMed. [pmid: 15811165].
95 Amore M, Jori MC. Faster response on amisulpride 50 mg versus sertraline 50-100 mg in patients with dysthymia or double depression: a randomized, double-blind, parallel group study. Int Clin Psychopharmacol. Nov. 2001;16(6):317-24. Source: PubMed. [pmid: 11712619].
96 Amore M, Ricci M, Zanardi R, et al. Long-term treatment of geropsychiatric depressed patients with venlafaxine. J Affect Disord. Dec. 1997;46(3):293-6. Source: PubMed. [pmid: 9547127].
97 Amsterdam J. Efficacy and safety of venlafaxine in the treatment of bipolar II major depressive episode. J Clin Psychopharmacol. Oct. 1998;18(5):414-7. Source: PubMed. [pmid: 9790160].
98 Amsterdam J, Garcia-Espana F, Fawcett J, et al. Fluoxetine efficacy in menopausal women with and without estrogen replacement. J Affect Disord. Sep. 1999;55(1):11-7. Source: PubMed. [pmid: 10512601].
99 Amsterdam JD, Brunswick DJ. Site variability in treatment outcome in antidepressant trials. Prog Neuropsychopharmacol Biol Psychiatry. Jun. 2002;26(5):989-93. Source: PubMed. [pmid: 12369275].
100 Amsterdam JD, Fava M, Maislin G, et al. TRH stimulation test as a predictor of acute and long-term antidepressant response in major depression. J Affect Disord. Jun. 5. 1996;38(2-3):165-72. Source: PubMed. [pmid: 8791185].
101 Amsterdam JD, Fawcett J, Quitkin FM, et al. Fluoxetine and norfluoxetine plasma concentrations in major depression: a multicenter study. Am J Psychiatry. Jul. 1997;154(7):963-9. Source: PubMed. [pmid: 9210747].
102 Amsterdam JD, Garcia-Espana F. Venlafaxine monotherapy in women with bipolar II and unipolar major depression. J Affect Disord. Sep. 2000;59(3):225-9. Source: PubMed. [pmid: 10854639].
103 Amsterdam JD, Hooper MB, Amchin J. Once-versus twice-daily venlafaxine therapy in major depression: a randomized, double-blind study. J Clin Psychiatry. May. 1998;59(5):236-40. Source: PubMed. [pmid: 9632034].
104 Amsterdam JD, Hornig-Rohan M, Maislin G. Efficacy of alprazolam in reducing fluoxetine-induced jitteriness in patients with major depression. J Clin Psychiatry. Sep. 1994;55(9):394-400. Source: PubMed. [pmid: 7929020].
105 Amsterdam JD, Shults J. Fluoxetine monotherapy of bipolar type II and bipolar NOS major depression: a double-blind, placebo-substitution, continuation study. Int Clin Psychopharmacol. Sep. 2005;20(5):257-64. Source: PubMed. [pmid: 16096516].
106 Amsterdam JD, Shults J. Comparison of short-term venlafaxine versus lithium monotherapy for bipolar II major depressive episode: a randomized open-label study. J Clin Psychopharmacol. Apr. 2008;28(2):171-81. Source: PubMed. [pmid: 18344727].
107 Amsterdam JD, Shults J. Does tachyphylaxis occur after repeated antidepressant exposure in patients with Bipolar II major depressive episode. J Affect Disord. May. 2009;115(1-2):234-40. Source: PubMed. [pmid: 18694599].
108 Amsterdam JD, Shults J. Efficacy and mood conversion rate of short-term fluoxetine monotherapy of bipolar ii major depressive episode. Journal of Clinical Psychopharmacology. 2010;30(3):306-11. Source: EMBASE. [pmid: 20473068].
109 Amsterdam JD, Shults J. Efficacy and safety of long-term fluoxetine versus lithium monotherapy of bipolar II disorder: A randomized, double-blind, placebo-substitution study. American Journal of Psychiatry. 2010;167(7):792-800. Source: EMBASE. [pmid: 20360317].
110 Amsterdam JD, Shults J, Rutherford N. Open-label study of s-citalopram therapy of chronic fatigue syndrome and co-morbid major depressive disorder. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1. 2008;32(1):100-6. Source: PubMed. [pmid: 17804135].
111 Amsterdam JD, Shults J, Rutherford N, et al. Safety and efficacy of s-citalopram in patients with co-morbid major depression and diabetes mellitus. Neuropsychobiology. Apr. 2006. 2006;54(4):208-14. Source: PsycINFO. [pmid: 17337914].
112 Amsterdam JD, Wang CH, Shwarz M, et al. Venlafaxine versus lithium monotherapy of rapid and non-rapid cycling patients with bipolar II major depressive episode: a randomized, parallel group, open-label trial. J Affect Disord. Jan. 2009;112(1-3):219-30. Source: PubMed. [pmid: 18486235].
113 Amsterdam JD, Wang G, Shults J. Venlafaxine monotherapy in bipolar type II depressed patients unresponsive to prior lithium monotherapy. Acta psychiatrica Scandinavica. 2010;121(3):201-8. Source: EMBASE. [pmid: 19694630].
114 Amsterdam JD, Williams D, Michelson D, et al. Tachyphylaxis after repeated antidepressant drug exposure in patients with recurrent major depressive disorder. Neuropsychobiology. 2009;59(4):227-33. Source: PubMed. [pmid: 19571597].
115 Ancoli-Israel S, Krystal AD, McCall WV, et al. A 12-week, randomized, double-blind, placebo-controlled study evaluating the effect of eszopiclone 2 mg on sleep/wake function in older adults with primary and comorbid insomnia. Sleep. 2010;33(2):225-34. Source: EMBASE. [pmid: 20175406].
116 Andersen G, Vestergaard K, Lauritzen L. Effective treatment of poststroke depression with the selective serotonin reuptake inhibitor citalopram. Stroke. Jun. 1994;25(6):1099-104. Source: PubMed. [pmid: 8202964].
117 Andersen SW, Clemow DB, Corya SA. Long-term weight gain in patients treated with open-label olanzapine in combination with fluoxetine for major depressive disorder. J Clin Psychiatry. Nov. 2005;66(11):1468-76. Source: PubMed. [pmid: 16420086].
118 Andersohn F, Konzen C, Bronder E, et al. Citalopram-induced bleeding due to severe thrombocytopenia. Psychosomatics. May-Jun. 2009;50(3):297-8. Source: PubMed. [pmid: 19567773].
119 Andersohn F, Schade R, Suissa S, et al. Long-term use of antidepressants for depressive disorders and the risk of diabetes mellitus. Am J Psychiatry. May. 2009;166(5):591-8. Source: PubMed. [pmid: 19339356].
120 Andersohn F, Willich SN. Interaction of serotonin reuptake inhibitors with tamoxifen. Bmj. 2010;340:c783. Source: PubMed. [pmid: 20142323].
121 Anderson IM. Meta-analytical studies on new antidepressants. Br Med Bull. 2001;57:161-78. Source: PubMed. [pmid: 11719915].
122 Anderson IM, Ferrier IN, Baldwin RC, et al. Evidence-based guidelines for treating depressive disorders with antidepressants: A revision of the 2000 British Association for Psychopharmacology guidelines. Journal of Psychopharmacology. 2008;22(4):343-96. Source: Scopus. [pmid: 18413657].
123 Anderson RJ, Gott BM, Sayuk GS, et al. Antidepressant pharmacotherapy in adults with type 2 diabetes: rates and predictors of initial response. Diabetes Care. Mar. 2010;33(3):485-9. Source: PubMed. [pmid: 20032276].
124 Andreescu C, Lenze EJ, Mulsant BH, et al. High worry severity is associated with poorer acute and maintenance efficacy of antidepressants in late-life depression. Depress Anxiety. 2009;26(3):266-72. Source: PubMed. [pmid: 19212971].
125 Andreescu C, Mulsant BH, Peasley-Miklus C, et al. Persisting low use of antipsychotics in the treatment of major depressive disorder with psychotic features. Journal of Clinical Psychiatry. 2007;68(2):194-200. Source: EMBASE. [pmid: 17335316].
126 Andreoli V, Caillard V, Deo RS, et al. Reboxetine, a new noradrenaline selective antidepressant, is at least as effective as fluoxetine in the treatment of depression. J Clin Psychopharmacol. Aug. 2002;22(4):393-9. Source: PubMed. [pmid: 12172339].
127 Andruskevicius S. Parameters of the spectral analysis of the heart rate variability in treating depression. Medicina (Kaunas). 2009;45(3):214-20. Source: PubMed. [pmid: 19357451].
128 Anghelescu I, Klawe C, Dahmen N. Venlafaxine in a patient with idiopathic leukopenia and mirtazapine-induced severe neutropenia. J Clin Psychiatry. Sep. 2002;63(9):838. Source: PubMed. [pmid: 12363126].
129 Angst J, Gamma A, Gerber-Werder R, et al. Does long-term medication with lithium, clozapine or antidepressants prevent or attenuate dementia in bipolar and depressed patients?. International Journal of Psychiatry in Clinical Practice. 2007;11(1):2-8. Source: EMBASE.
130 Anisman H, Ravindran AV, Griffiths J, et al. Interleukin-1 beta production in dysthymia before and after pharmacotherapy. Biol Psychiatry. Dec. 15. 1999;46(12):1649-55. Source: PubMed. [pmid: 10624546].
131 Anne Sirey J, Bruce ML, Kales HC. Improving antidepressant adherence and depression outcomes in primary care: The treatment initiation and participation (TIP) program. American Journal of Geriatric Psychiatry. 2010;18(6):554-62. Source: EMBASE. [pmid: 20220604].
132 Anonymous. Undertaking systematic reviews of research on effectiveness: CRD's guidance for those carrying out or commissioning reviews. CRD Report Number 4. 2nd edition. 2001. 2001. Source: Handsearch.
133 Anonymous. Report of the CSM expert working group on the safety of selective serotonin reuptake inhibitor antidepressants. 2004. Source: Handsearch.
134 Ansseau M, Darimont P, Lecoq A, et al. Controlled comparison of nefazodone and amitriptyline in major depressive inpatients. Psychopharmacology (Berl). Jun. 1994;115(1-2):254-60. Source: PubMed. [pmid: 7862904].
135 Ansseau M, Gabriels A, Loyens J, et al. A double-blind comparison of paroxetine and fluvoxamine in major depression. Eur Neuropsychopharmacol. 1993;3(3):323-4. Source: EMBASE.
136 Ansseau M, Papart P, Troisfontaines B, et al. Controlled comparison of milnacipran and fluoxetine in major depression. Psychopharmacology (Berl). Feb. 1994;114(1):131-7. Source: PubMed. [pmid: 7846195].
137 Ansseau M, von Frenckell R, Gerard MA, et al. Interest of a loading dose of milnacipran in endogenous depressive inpatients. Comparison with the standard regimen and with fluvoxamine. Eur Neuropsychopharmacol. May. 1991;1(2):113-21. Source: PubMed. [pmid: 1821700].
138 Antonuccio D. Treating depressed children with antidepressants: More harm than benefit?. Journal of Clinical Psychology in Medical Settings. Jun. 2008. 2008;15(2):92-7. Source: PsycINFO. [pmid: 19104973].
139 Antonuccio D. ‘Treating depressed children with antidepressants: More harm than benefit?’: Erratum. Journal of Clinical Psychology in Medical Settings. 2008;15(3):260. Source: PsycINFO.
140 Anttila AK, Rasanen L, Leinonen EV. Fluvoxamine augmentation increases serum mirtazapine concentrations three- to fourfold. Ann Pharmacother. Oct. 2001;35(10):1221-3. Source: PubMed. [pmid: 11675851].
141 Appelberg BG, Syvalahti EK, Koskinen TE, et al. Patients with severe depression may benefit from buspirone augmentation of selective serotonin reuptake inhibitors: results from a placebo-controlled, randomized, double-blind, placebo wash-in study. J Clin Psychiatry. Jun. 2001;62(6):448-52. Source: PubMed. [pmid: 11465522].
142 Appelhof BC, Brouwer JP, van Dyck R, et al. Triiodothyronine addition to paroxetine in the treatment of major depressive disorder. J Clin Endocrinol Metab. Dec. 2004;89(12):6271-6. Source: PubMed. [pmid: 15579788].
143 Appelhof BC, Huyser J, Verweij M, et al. Glucocorticoids and relapse of major depression (dexamethasone/corticotropin-releasing hormone test in relation to relapse of major depression). Biol Psychiatry. Apr. 15. 2006;59(8):696-701. Source: PubMed. [pmid: 16368077].
144 Applebee GA, Attarian HP, Schenck CH. An angry bed partner. J Clin Sleep Med. 2009;5(5):477-9. Source: PubMed. [pmid: 19961035].
145 Appleby L, Warner R, Whitton A, et al. A controlled study of fluoxetine and cognitive-behavioural counselling in the treatment of postnatal depression. Bmj. Mar. 29. 1997;314(7085):932-6. Source: PubMed. [pmid: 9099116].
146 Aragona M, Bancheri L, Perinelli D, et al. Randomized double-blind comparison of serotonergic (Citalopram) versus noradrenergic (Reboxetine) reuptake inhibitors in outpatients with somatoform, DSM-IV-TR pain disorder. Eur J Pain. Feb. 2005;9(1):33-8. Source: PubMed. [pmid: 15629872].
147 Araya R, Flynn T, Rojas G, et al. Cost-effectiveness of a primary care treatment program for depression in low-income women in Santiago, Chile. American Journal of Psychiatry. 2006;163(8):1379-87. Source: EMBASE. [pmid: 16877650].
148 Argyropoulos SV, Hicks JA, Nash JR, et al. Correlation of subjective and objective sleep measurements at different stages of the treatment of depression. Psychiatry Res. Sep. 30. 2003;120(2):179-90. Source: PubMed. [pmid: 14527649].
149 Arias B, Catalan R, Gasto C, et al. 5-HTTLPR polymorphism of the serotonin transporter gene predicts non-remission in major depression patients treated with citalopram in a 12-weeks follow up study. J Clin Psychopharmacol. Dec. 2003;23(6):563-7. Source: PubMed. [pmid: 14624186].
150 Arias B, Catalan R, Gasto C, et al. Evidence for a combined genetic effect of the 5-HT(1A) receptor and serotonin transporter genes in the clinical outcome of major depressive patients treated with citalopram. J Psychopharmacol. Mar. 2005;19(2):166-72. Source: PubMed. [pmid: 15728438].
151 Arias B, Serretti A, Lorenzi C, et al. Analysis of COMT gene (Val 158 Met polymorphism) in the clinical response to SSRIs in depressive patients of European origin. Journal of Affective Disorders. Feb. 2006. 2006;90(2):251-6. Source: PsycINFO. [pmid: 16356553].
152 Arias B, Serretti A, Mandelli L, et al. Dysbindin gene (DTNBP1) in major depression: association with clinical response to selective serotonin reuptake inhibitors. Pharmacogenet Genomics. Feb. 2009;19(2):121-8. Source: PubMed. [pmid: 19065121].
153 Arminen SL, Ikonen U, Pulkkinen M, et al. Paroxetine and imipramine: A 12-week, double-blind multicentre study in hospitalized depressed patients. Nordic Journal of Psychiatry, Supplement. 1992;46(27):27-31. Source: EMBASE.
154 Arminen SL, Ikonen U, Pulkkinen P, et al. A 12-week double-blind multi-centre study of paroxetine and imipramine in hospitalized depressed patients. Acta Psychiatr Scand. Jun. 1994;89(6):382-9. Source: PubMed. [pmid: 8085467].
155 Armitage R, Yonkers K, Cole D, et al. A multicenter, double-blind comparison of the effects of nefazodone and fluoxetine on sleep architecture and quality of sleep in depressed outpatients. J Clin Psychopharmacol. Jun. 1997;17(3):161-8. Source: PubMed. [pmid: 9169959].
156 Armstrong EP, Skrepnek GH, Haim Erder M. Cost-utility comparison of escitalopram and sertraline in the treatment of major depressive disorder. Curr Med Res Opin. Feb. 2007;23(2):251-8. Source: PubMed. [pmid: 17288678].
157 Arnold KK, Yager J. A case of unexpected and selective remission of a 20-year history of ephedrine dependence following treatment with low-dose aripiprazole. J Clin Psychiatry. Oct. 2007;68(10):1620-1. Source: PubMed. [pmid: 17960985].
158 Arnold LM, Hudson JI, Wang F, et al. Comparisons of the efficacy and safety of duloxetine for the treatment of fibromyalgia in patients with versus without major depressive disorder. Clin J Pain. 2009;25(6):461-8. Source: PubMed. [pmid: 19542792].
159 Arnold LM, Lu Y, Crofford LJ, et al. A double-blind, multicenter trial comparing duloxetine with placebo in the treatment of fibromyalgia patients with or without major depressive disorder. Arthritis Rheum. Sep. 2004;50(9):2974-84. Source: PubMed. [pmid: 15457467].
160 Arnold LM, McElroy SL, Mutasim DF, et al. Characteristics of 34 adults with psychogenic excoriation. J Clin Psychiatry. Oct. 1998;59(10):509-14. Source: PubMed. [pmid: 9818631].
161 Arnold LM, Meyers AL, Sunderajan P, et al. The effect of pain on outcomes in a trial of duloxetine treatment of major depressive disorder. Ann Clin Psychiatry. Oct-Dec. 2008;20(4):187-93. Source: PubMed. [pmid: 19034749].
162 Arnold LM, Rosen A, Pritchett YL, et al. A randomized, double-blind, placebo-controlled trial of duloxetine in the treatment of women with fibromyalgia with or without major depressive disorder. Pain. Dec. 15. 2005;119(1-3):5-15. Source: PubMed. [pmid: 16298061].
163 Arnott S, Nutt D. Successful treatment of fluvoxamine-induced anorgasmia by cyproheptadine. Br J Psychiatry. Jun. 1994;164(6):838-9. Source: PubMed. [pmid: 7952994].
164 Arnow BA, Blasey C, Manber R, et al. Dropouts versus completers among chronically depressed outpatients. J Affect Disord. Jan. 2007;97(1-3):197-202. Source: PubMed. [pmid: 16857266].
165 Arnow BA, Manber R, Blasey C, et al. Therapeutic reactance as a predictor of outcome in the treatment of chronic depression. J Consult Clin Psychol. Dec. 2003;71(6):1025-35. Source: PubMed. [pmid: 14622078].
166 Arranz FJ, Ros S. Effects of comorbidity and polypharmacy on the clinical usefulness of sertraline in elderly depressed patients: an open multicentre study. J Affect Disord. Dec. 1997;46(3):285-91. Source: PubMed. [pmid: 9547126].
167 Arroll B, Macgillivray S, Ogston S, et al. Efficacy and tolerability of tricyclic antidepressants and SSRIs compared with placebo for treatment of depression in primary care: a meta-analysis. Ann Fam Med. Sep-Oct. 2005;3(5):449-56. Source: PubMed. [pmid: 16189062].
168 Artigas F, Perez V, Alvarez E. Pindolol induces a rapid improvement of depressed patients treated with serotonin reuptake inhibitors. Arch Gen Psychiatry. Mar. 1994;51(3):248-51. Source: PubMed. [pmid: 8122960].
169 Ashleigh EA, Fesler FA. Fluoxetine and suicidal preoccupation. Am J Psychiatry. Dec. 1992;149(12):1750. Source: PubMed. [pmid: 1443254].
170 Ashman TA, Cantor JB, Gordon WA, et al. A randomized controlled trial of sertraline for the treatment of depression in persons with traumatic brain injury. Arch Phys Med Rehabil. 2009;90(5):733-40. Source: PubMed. [pmid: 19406291].
171 Ashton AK. Lack of desipramine toxicity with citalopram. J Clin Psychiatry. Feb. 2000;61(2):144. Source: PubMed. [pmid: 10732663].
172 Association AP. Practice guideline for the treatment of patients with major depressive disorder. Am J Psychiatry. 2010. October. in press at PsychiatryOnline. Source: Handsearch.
173 Atkins D, Eccles M, Flottorp S, et al. Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. Dec. 22. 2004;4(1):38. Source: PubMed. [pmid: 15615589].
174 Atlantis E, Browning C, Sims J, et al. Diabetes incidence associated with depression and antidepressants in the Melbourne Longitudinal Studies on Healthy Ageing (MELSHA). International journal of geriatric psychiatry. 2010;25(7):688-96. Source: EMBASE. [pmid: 19806604].
175 Attia E, Haiman C, Walsh BT, et al. Does fluoxetine augment the inpatient treatment of anorexia nervosa. Am J Psychiatry. Apr. 1998;155(4):548-51. Source: PubMed. [pmid: 9546003].
176 Aursnes I, Gjertsen MK. Common adverse events associated with an SSRI: meta-analysis of early paroxetine data. Pharmacoepidemiol Drug Saf. Jul. 2008;17(7):707-13. Source: PubMed. [pmid: 18383561].
177 Aursnes I, Tvete IF, Gaasemyr J, et al. Suicide attempts in clinical trials with paroxetine randomised against placebo. BMC Med. Aug. 22. 2005;3:14. Source: PubMed. [pmid: 16115311].
178 Austin LS, Arana GW, Melvin JA. Toxicity resulting from lithium augmentation of antidepressant treatment in elderly patients. J Clin Psychiatry. Aug. 1990;51(8):344-5. Source: PubMed. [pmid: 2380160].
179 Averill PM, Wassef AA. Who receives antidepressants and what impact do they have? An acute-care study. Psychiatric Quarterly. 2006;77(2):139-50. Source: EMBASE. [pmid: 16763769].
180 Avissar S, Matuzany-Ruban A, Tzukert K, et al. Beta-arrestin-1 levels: reduced in leukocytes of patients with depression and elevated by antidepressants in rat brain. Am J Psychiatry. Nov. 2004;161(11):2066-72. Source: PubMed. [pmid: 15514408].
181 Avorn J. Depression in the elderly--falls and pitfalls. N Engl J Med. Sep. 24. 1998;339(13):918-20. Source: PubMed. [pmid: 9744979].
182 Aydemir O, Deveci A, Taneli F. The effect of chronic antidepressant treatment on serum brain-derived neurotrophic factor levels in depressed patients: a preliminary study. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 2005;29(2):261-5. Source: PubMed. [pmid: 15694233].
183 Aymard N, Viala A, Baldacci C, et al. Pharmacoclinical strategy in neuroleptic resistant schizophrenic patients treated by clozapine: clinical evolution, concentration of plasma and red blood cell clozapine and desmethylclozapine, whole blood serotonin and tryptophan. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1999;23(1):25-41. Source: PubMed. [pmid: 10368854].
184 Azorin JM, Bovier P, Widmer J, et al. L-tyrosine and L-tryptophan membrane transport in erythrocytes and antidepressant drug choice. Biol Psychiatry. Apr. 1. 1990;27(7):723-34. Source: PubMed. [pmid: 2158354].
185 Baab SW, Peindl KS, Piontek CM, et al. Serum bupropion levels in 2 breastfeeding mother-infant pairs. J Clin Psychiatry. Oct. 2002;63(10):910-1. Source: PubMed. [pmid: 12416600].
186 Babyak M, Blumenthal JA, Herman S, et al. Exercise treatment for major depression: maintenance of therapeutic benefit at 10 months. Psychosom Med. Sep-Oct. 2000;62(5):633-8. Source: PubMed. [pmid: 11020092].
187 Baca E, de Chavez M, Garcia-Toro M, et al. Sertraline is more effective than imipramine in the treatment of non-melancholic depression: results from a multicentre, randomized study. Prog Neuropsychopharmacol Biol Psychiatry. May. 2003;27(3):493-500. Source: PubMed. [pmid: 12691786].
188 Baca E, Roca M, Garcia-Calvo C, et al. Venlafaxine extended-release in patients older than 80 years with depressive syndrome. Int J Geriatr Psychiatry. Apr. 2006;21(4):337-43. Source: PubMed. [pmid: 16570327].
189 Baca-Garcia E, Sher L, Perez-Rodriguez MM, et al. Treatment of depressed bipolar patients with alcohol use disorders: Plenty of room for improvement. Journal of Affective Disorders. 2009;115(1-2):262-8. Source: EMBASE. [pmid: 18973953].
190 Baettig D, Bondolfi G, Montaldi S, et al. Tricyclic antidepressant plasma levels after augmentation with citalopram: a case study. Eur J Clin Pharmacol. 1993;44(4):403-5. Source: PubMed. [pmid: 8513856].
191 Bagby RM, Kennedy SH, Schuller DR, et al. Differential pharmacological treatment response in high angry hostile and low angry hostile depressed patients: a retrospective analysis. J Affect Disord. Sep. 1997;45(3):161-6. Source: PubMed. [pmid: 9298429].
192 Bagby RM, Levitan RD, Kennedy SH, et al. Selective alteration of personality in response to noradrenergic and serotonergic antidepressant medication in depressed sample: evidence of non-specificity. Psychiatry Res. Jun. 30. 1999;86(3):211-6. Source: PubMed. [pmid: 10482340].
193 Bagby RM, Ryder AG, Schuller DR, et al. The Hamilton Depression Rating Scale: has the gold standard become a lead weight. Am J Psychiatry. Dec. 2004;161(12):2163-77. Source: PubMed. [pmid: 15569884].
194 Bailey RK, Mallinckrodt CH, Wohlreich MM, et al. Duloxetine in the treatment of major depressive disorder: comparisons of safety and efficacy. J Natl Med Assoc. 2006;98(3):437-47. Source: PubMed. [pmid: 16573311].
195 Bair MJ, Robinson RL, Eckert GJ, et al. Impact of pain on depression treatment response in primary care. Psychosom Med. Jan-Feb. 2004;66(1):17-22. Source: PubMed. [pmid: 14747633].
196 Bair MJ, Robinson RL, Katon W, et al. Depression and pain comorbidity: a literature review. Arch Intern Med. Nov. 10. 2003;163(20):2433-45. Source: PubMed. [pmid: 14609780].
197 Bajbouj M, Danker-Hopfe H. Maintenance treatment of depression in old age. N Engl J Med. Jun. 8. 2006;354(23):2505-6. author reply -6. Source: PubMed. [pmid: 16764055].
198 Baker B, Dorian P, Sandor P, et al. Electrocardiographic effects of fluoxetine and doxepin in patients with major depressive disorder. J Clin Psychopharmacol. Feb. 1997;17(1):15-21. Source: PubMed. [pmid: 9004052].
199 Bakish D. Fluoxetine potentiation by buspirone: three case histories. Can J Psychiatry. Dec. 1991;36(10):749-50. Source: PubMed. [pmid: 1790522].
200 Bakish D. The patient with comorbid depression and anxiety: the unmet need. J Clin Psychiatry. Suppl 6. 1999;60:20-4. Source: PubMed. [pmid: 10235121].
201 Bakish D, Cavazzoni P, Chudzik J, et al. Effects of selective serotonin reuptake inhibitors on platelet serotonin parameters in major depressive disorder. Biol Psychiatry. Jan. 15. 1997;41(2):184-90. Source: PubMed. [pmid: 9018388].
202 Bakish D, Hooper CL, Thornton MD, et al. Fast onset: an open study of the treatment of major depressive disorder with nefazodone and pindolol combination therapy. Int Clin Psychopharmacol. Mar. 1997;12(2):91-7. Source: PubMed. [pmid: 9219044].
203 Balant-Gorgia AE, Ries C, Balant LP. Metabolic interaction between fluoxetine and clomipramine: a case report. Pharmacopsychiatry. Jan. 1996;29(1):38-41. Source: PubMed. [pmid: 8852534].
204 Baldessarini RJ, Pompili M, Tondo L. Suicidal risk in antidepressant drug trials. Archives of General Psychiatry. 2006;63(3):246-8. Source: Scopus. [pmid: 16520428].
205 Baldessarini RJ, Tarazi FI. Pharmacotherapy of psychosis and mania. Goodman and Gilman's The Pharmacological Basis of Therapeutics. 2005:461-500. Source: Scopus.
206 Baldessarini RJ, Tondo L, Ghiani C, et al. Illness risk following rapid versus gradual discontinuation of antidepressants. The American journal of psychiatry. 2010;167(8):934-41. Source: PsycINFO. [pmid: 20478876].
207 Baldomero EB, Ubago JG, Cercos CL, et al. Venlafaxine extended release versus conventional antidepressants in the remission of depressive disorders after previous antidepressant failure: ARGOS study. Depress Anxiety. Aug. 10. 2005;22(2):68-76. Source: PubMed. [pmid: 16094658].
208 Baldwin D, Bridgman K, Buis C. Resolution of sexual dysfunction during double-blind treatment of major depression with reboxetine or paroxetine. J Psychopharmacol. Jan. 2006;20(1):91-6. Source: PubMed. [pmid: 16204325].
209 Baldwin D, Moreno RA, Briley M. Resolution of sexual dysfunction during acute treatment of major depression with milnacipran. Hum Psychopharmacol. Aug. 2008;23(6):527-32. Source: PubMed. [pmid: 18536065].
210 Baldwin DS, Cooper JA, Huusom AK, et al. A double-blind, randomized, parallel-group, flexible-dose study to evaluate the tolerability, efficacy and effects of treatment discontinuation with escitalopram and paroxetine in patients with major depressive disorder. Int Clin Psychopharmacol. 2006;21(3):159-69. Source: PubMed. [pmid: 16528138].
211 Baldwin DS, Hawley CJ, Abed RT, et al. A multicenter double-blind comparison of nefazodone and paroxetine in the treatment of outpatients with moderate-to-severe depression. J Clin Psychiatry. Suppl 2. 1996;57:46-52. Source: PubMed. [pmid: 8626363].
212 Baldwin DS, Hawley CJ, Mellors K. A randomized, double-blind controlled comparison of nefazodone and paroxetine in the treatment of depression: safety, tolerability and efficacy in continuation phase treatment. J Psychopharmacol. Sep. 2001;15(3):161-5. Source: PubMed. [pmid: 11565622].
213 Baldwin DS, Montgomery SA, Nil R, et al. Discontinuation symptoms in depression and anxiety disorders. International Journal of Neuropsychopharmacology. 2007;10(1):73-84. Source: EMBASE. [pmid: 16359583].
214 Baldwin DS, Reines EH, Guiton C, et al. Escitalopram therapy for major depression and anxiety disorders. Ann Pharmacother. 2007;41(10):1583-92. Source: PubMed. [pmid: 17848424].
215 Baldwin DS, Stein DJ, Dolberg OT, et al. How long should a trial of escitalopram treatment be in patients wit major depressive disorder, generalised anxiety disorder, or social anxiety disorder? An exploration of the randomised controlled trial database. Human Psychopharmacology: Clinical and Experimental. Jun. 2009. 2009;24(4):269-75. Source: PsycINFO. [pmid: 19334042].
216 Balhara Y, Sagar R, Varghese ST. Bleeding gums: duloxetine may be the cause. J Postgrad Med. Jan-Mar. 2007;53(1):44-5. Source: PubMed. [pmid: 17244971].
217 Balk EM, Lau J, Bonis PA. Reading and critically appraising systematic reviews and meta-analyses: a short primer with a focus on hepatology. J Hepatol. Oct. 2005;43(4):729-36. Source: PubMed. [pmid: 16120472].
218 Ballard C, Corbett A, Chitramohan R, et al. Management of agitation and aggression associated with Alzheimer's disease: controversies and possible solutions. Curr Opin Psychiatry. Nov. 2009;22(6):532-40. Source: PubMed. [pmid: 19696673].
219 Ballenger JC. Clinical evaluation of venlafaxine. J Clin Psychopharmacol. Jun. 1996;16(3 Suppl 2):29S-35S. discussion S-6S. Source: PubMed. [pmid: 8784646].
220 Ballesteros J, Callado LF, Gutiérrez M. An independent meta-analysis using summary data for clinical response, remission, and discontinuation for any reason from the 6 pivotal phase III randomized clinical trials of duloxetine in major depressive disorder. Journal of Clinical Psychopharmacology. Apr. 2007. 2007;27(2):219-21. Source: PsycINFO. [pmid: 17414254].
221 Ballus C, Quiros G, De Flores T, et al. The efficacy and tolerability of venlafaxine and paroxetine in outpatients with depressive disorder or dysthymia. Int Clin Psychopharmacol. Jan. 2000;15(1):43-8. Source: PubMed. [pmid: 10836286].
222 Balon R. Sexual obsessions associated with fluoxetine. J Clin Psychiatry. Nov. 1994;55(11):496. Source: PubMed. [pmid: 7989284].
223 Balon R, Yeragani VK, Pohl R, et al. Sexual dysfunction during antidepressant treatment. J Clin Psychiatry. Jun. 1993;54(6):209-12. Source: PubMed. [pmid: 8331089].
224 Bandelow B, Andersen HF, Dolberg OT. Escitalopram in the treatment of anxiety symptoms associated with depression. Depress Anxiety. 2007;24(1):53-61. Source: PubMed. [pmid: 16937393].
225 Bandelow B, Chouinard G, Bobes J, et al. Extended-release quetiapine fumarate (quetiapine XR): A once-daily monotherapy effective in generalized anxiety disorder. Data from a randomized, double-blind, placebo-and active-controlled study. International Journal of Neuropsychopharmacology. 2010;13(3):305-20. Source: EMBASE. [pmid: 19691907].
226 Bang LM, Keating GM. Paroxetine controlled release. CNS Drugs. 2004;18(6):355-64. discussion 65-6. Source: PubMed. [pmid: 15089103].
227 Bangs ME, Emslie GJ, Spencer TJ, et al. Efficacy and safety of atomoxetine in adolescents with attention-deficit/hyperactivity disorder and major depression. Journal of Child and Adolescent Psychopharmacology. Aug. 2007. 2007;17(4):407-19. Source: PsycINFO. [pmid: 17822337].
228 Banos JH, Novack TA, Brunner R, et al. Impact of early administration of sertraline on cognitive and behavioral recovery in the first year after moderate to severe traumatic brain injury. Journal of Head Trauma Rehabilitation. 2010;25(5):357-61. Source: EMBASE. [pmid: 20220529].
229 Barak Y, Kimhi R, Weizman R. Is selectivity for serotonin uptake associated with a reduced emergence of manic episodes in depressed patients. Int Clin Psychopharmacol. Jan. 2000;15(1):53-6. Source: PubMed. [pmid: 10836288].
230 Barbosa L, Berk M, Vorster M. A double-blind, randomized, placebo-controlled trial of augmentation with lamotrigine or placebo in patients concomitantly treated with fluoxetine for resistant major depressive episodes. J Clin Psychiatry. Apr. 2003;64(4):403-7. Source: PubMed. [pmid: 12716240].
231 Barbui C, Andretta M, De Vitis G, et al. Antidepressant drug prescription and risk of abnormal bleeding: A case-control study. Journal of clinical psychopharmacology. 2009;29(1):33-8. Source: PubMed. [pmid: 19142104].
232 Barbui C, Esposito E, Cipriani A. Selective serotonin reuptake inhibitors and risk of suicide: A systematic review of observational studies. Canadian Medical Association Journal. 2009;180(3):291-7. Source: PubMed. [pmid: 19188627].
233 Barbui C, Furukawa TA, Cipriani A. Effectiveness of paroxetine in the treatment of acute major depression in adults: A systematic re-examination of published and unpublished data from randomized trials. Canadian Medical Association Journal. 2008;178(3):296-305. Source: Scopus. [pmid: 18227449].
234 Barbui C, Percudani M. Epidemiological impact of antidepressant and antipsychotic drugs on the general population. Curr Opin Psychiatry. Jul. 2006;19(4):405-10. Source: PubMed. [pmid: 16721172].
235 Bares M, Novak T, Kopecek M, et al. Antidepressant monotherapy and combination of antidepressants in the treatment of resistant depression in current clinical practice: A retrospective study. International Journal of Psychiatry in Clinical Practice. 2010;14(4):303-8. Source: EMBASE.
236 Barge-Schaapveld DQ, Nicolson NA, van der Hoop RG, et al. Changes in daily life experience associated with clinical improvement in depression. J Affect Disord. May. 17. 1995;34(2):139-54. Source: PubMed. [pmid: 7665806].
237 Barim AO, Aydin S, Colak R, et al. Ghrelin, paraoxonase and arylesterase levels in depressive patients before and after citalopram treatment. Clin Biochem. 2009;42(10-11):1076-81. Source: PubMed. [pmid: 19272368].
238 Barone P, Scarzella L, Marconi R, et al. Pramipexole versus sertraline in the treatment of depression in Parkinson's disease: a national multicenter parallel-group randomized study. J Neurol. May. 2006;253(5):601-7. Source: PubMed. [pmid: 16607468].
239 Barr LC, Heninger GR, Goodman W, et al. Effects of fluoxetine administration on mood response to tryptophan depletion in healthy subjects. Biol Psychiatry. May. 1. 1997;41(9):949-54. Source: PubMed. [pmid: 9110100].
240 Barrelet L, Blajev B, Bolzani L, et al. Multicenter study comparing efficacy and tolerance of moclobenide and fluvoxamine in in- and outpatients with a severe depressive episode. Schweizerische Rundschau Fur Medizin Praxis. 1991;80(19):524-8. Source: EMBASE. [pmid: 1904620].
241 Barrett JE, Williams JW Jr., Oxman TE, et al. Treatment of dysthymia and minor depression in primary care: a randomized trial in patients aged 18 to 59 years. J Fam Pract. May. 2001;50(5):405-12. Source: PubMed. [pmid: 11350703].
242 Barrnett J, Frances A, Kocsis J, et al. Peripheral edema associated with trazodone: a report of ten cases. J Clin Psychopharmacol. Jun. 1985;5(3):161-4. Source: PubMed. [pmid: 3998206].
243 Barros J, Asnis G. An interaction of sertraline and desipramine. Am J Psychiatry. Nov. 1993;150(11):1751. Source: PubMed. [pmid: 8214190].
244 Bascara L. A double-blind study to compare the effectiveness and tolerability of paroxetine and amitriptyline in depressed patients. Acta Psychiatr Scand Suppl. 1989;350:141-2. Source: PubMed. [pmid: 2530771].
245 Basoglu C, Ates MA, Alguel A, et al. Adjuvant Folate with Escitalopram Treatment and Homocystein, Folate, Vitamin B-12 Levels in Patients with Major Depressive Disorder. Bulletin of Clinical Psychopharmacology. 2009;19135. Source: Handsearch.
246 Basterzi AD, Yazici K, Aslan E, et al. Effects of fluoxetine and venlafaxine on serum brain derived neurotrophic factor levels in depressed patients. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 17. 2009;33(2):281-5. Source: PubMed. [pmid: 19110026].
247 Basterzi AD, Yazici K, Buturak V, et al. Effects of venlafaxine and fluoxetine on lymphocyte subsets in patients with major depressive disorder: a flow cytometric analysis. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 1. 2010;34(1):70-5. Source: PubMed. [pmid: 19804808].
248 Battegay R, Hager M, Rauchfleisch U. Double-blind comparative study of paroxetine and amitriptyline in depressed patients of a university psychiatric outpatient clinic (pilot study). Neuropsychobiology. 1985;13(1-2):31-7. Source: PubMed. [pmid: 3162108].
249 Battle CL, Uebelacker L, Friedman MA, et al. Treatment goals of depressed outpatients: A qualitative investigation of goals identified by participants in a depression treatment trial. Journal of Psychiatric Practice. 2010;16(6):425-30. Source: PsycINFO. [pmid: 21107149].
250 Baty P. Does nefazadone alone, the cognitive behavioral-analysis system of psychotherapy, or the combination of both work best for patients with chronic depression. J Fam Pract. Aug. 2000;49(8):687. Source: PubMed. [pmid: 10947130].
251 Bauer M, Berman SM, Schlagenhauf F, et al. Regional cerebral glucose metabolism and anxiety symptoms in bipolar depression: Effects of levothyroxine. Psychiatry Research - Neuroimaging. 2010;181(1):71-6. Source: EMBASE.
252 Bauer M, El-Khalili N, Datto C, et al. A pooled analysis of two randomised, placebo-controlled studies of extended release quetiapine fumarate adjunctive to antidepressant therapy in patients with major depressive disorder. Journal of affective disorders. 2010;127(1-3):19-30. Source: EMBASE. [pmid: 20884063].
253 Bauer M, Hellweg R, Baumgartner A. Fluoxetine-induced akathisia does not reappear after switch to paroxetine. J Clin Psychiatry. Dec. 1996;57(12):593-4. Source: PubMed. [pmid: 9010125].
254 Bauer M, Linden M, Schaaf B, et al. Adverse events and tolerability of the combination of fluoxetine/lithium compared with fluoxetine. J Clin Psychopharmacol. Apr. 1996;16(2):130-4. Source: PubMed. [pmid: 8690828].
255 Bauer M, Pretorius HW, Constant EL, et al. Extended release quetiapine as adjunct to an antidepressant in patients with major depressive disorder: Results of a randomized, placebo-controlled, double-blind study. Journal of Clinical Psychiatry. Apr. 2009. 2009;70(4):540-9. Source: PsycINFO. [pmid: 19358791].
256 Bauer M, Tharmanathan P, Volz HP, et al. The effect of venlafaxine compared with other antidepressants and placebo in the treatment of major depression: a meta-analysis. Eur Arch Psychiatry Clin Neurosci. 2009;259(3):172-85. Source: PubMed. [pmid: 19165525].
257 Bauer M, Zaninelli R, Muller-Oerlinghausen B, et al. Paroxetine and amitriptyline augmentation of lithium in the treatment of major depression: a double-blind study. J Clin Psychopharmacol. Apr. 1999;19(2):164-71. Source: PubMed. [pmid: 10211918].
258 Baumann P, Nil R, Bertschy G, et al. A double-blind double-dummy study of citalopram comparing infusion versus oral administration. J Affect Disord. Jun. 1998;49(3):203-10. Source: PubMed. [pmid: 9629950].
259 Baumann P, Nil R, Souche A, et al. A double-blind, placebo-controlled study of citalopram with and without lithium in the treatment of therapy-resistant depressive patients: a clinical, pharmacokinetic, and pharmacogenetic investigation. J Clin Psychopharmacol. Aug. 1996;16(4):307-14. Source: PubMed. [pmid: 8835706].
260 Baumann U, Eckmann F, Stieglitz RD. Self-rating data as a selecting factor in clinical trials of psychotropic drugs. Eur Arch Psychiatry Neurol Sci. 1985;235(2):65-70. Source: PubMed. [pmid: 3905411].
261 Baune BT, Caliskan S, Todder D. Effects of adjunctive antidepressant therapy with quetiapine on clinical outcome, quality of sleep and daytime motor activity in patients with treatment-resistant depression. Hum Psychopharmacol. Jan. 2007;22(1):1-9. Source: PubMed. [pmid: 17191266].
262 Baune BT, Dannlowski U, Domschke K, et al. The Interleukin 1 Beta (IL1B) Gene Is Associated with Failure to Achieve Remission and Impaired Emotion Processing in Major Depression. Biological psychiatry. 2010;67(6):543-9. Source: EMBASE. [pmid: 20044070].
263 Baune BT, Hohoff C, Berger K, et al. Association of the COMT val158met variant with antidepressant treatment response in major depression. Neuropsychopharmacology. 2008;33(4):924-32. Source: EMBASE. [pmid: 17522626].
264 Baxter LR Jr., Phelps ME, Mazziotta JC, et al. Local cerebral glucose metabolic rates in obsessive-compulsive disorder. A comparison with rates in unipolar depression and in normal controls. Arch Gen Psychiatry. Mar. 1987;44(3):211-8. Source: PubMed. [pmid: 3493749].
265 Bayer AJ, Pathy MS, Cameron A, et al. A comparative study of conventional and controlled-release formulations of trazodone in elderly depressed patients. Clin Neuropharmacol. Suppl 1. 1989;12:S50-5. Discussion S6-7. Source: PubMed. [pmid: 2663153].
266 Beasley CM Jr., Dornseif BE, Bosomworth JC, et al. Fluoxetine and suicide: a meta-analysis of controlled trials of treatment for depression. Bmj. Sep. 21. 1991;303(6804):685-92. Source: PubMed. [pmid: 1833012].
267 Beasley CM Jr., Dornseif BE, Pultz JA, et al. Fluoxetine versus trazodone: efficacy and activating-sedating effects. J Clin Psychiatry. Jul. 1991;52(7):294-9. Source: PubMed. [pmid: 2071559].
268 Beasley CM Jr., Holman SL, Potvin JH. Fluoxetine compared with imipramine in the treatment of inpatient depression. A multicenter trial. Ann Clin Psychiatry. Sep. 1993;5(3):199-207. Source: PubMed. [pmid: 8281243].
269 Beasley CM Jr., Koke SC, Nilsson ME, et al. Adverse events and treatment discontinuations in clinical trials of fluoxetine in major depressive disorder: an updated meta-analysis. Clin Ther. Nov. 2000;22(11):1319-30. Source: PubMed. [pmid: 11117656].
270 Beasley CM Jr., Masica DN, Heiligenstein JH, et al. Possible monoamine oxidase inhibitor-serotonin uptake inhibitor interaction: fluoxetine clinical data and preclinical findings. J Clin Psychopharmacol. Oct. 1993;13(5):312-20. Source: PubMed. [pmid: 8227489].
271 Beasley CM Jr., Nilsson ME, Koke SC, et al. Efficacy, adverse events, and treatment discontinuations in fluoxetine clinical studies of major depression: a meta-analysis of the 20-mg/day dose. J Clin Psychiatry. Oct. 2000;61(10):722-8. Source: PubMed. [pmid: 11078032].
272 Beasley CM Jr., Potvin JH. Fluoxetine: activating and sedating effects. Int Clin Psychopharmacol. Winter. 1993;8(4):271-5. Source: PubMed. [pmid: 8277147].
273 Beasley CM Jr., Sayler ME, Cunningham GE, et al. Fluoxetine in tricyclic refractory major depressive disorder. J Affect Disord. Nov. 1990;20(3):193-200. Source: PubMed. [pmid: 2148340].
274 Beasley CM Jr., Sayler ME, Potvin JH. Fluoxetine versus amitriptyline in the treatment of major depression: a multicenter trial. Int Clin Psychopharmacol. Fall. 1993;8(3):143-9. Source: PubMed. [pmid: 8263311].
275 Beasley CM Jr., Sayler ME, Weiss AM, et al. Fluoxetine: activating and sedating effects at multiple fixed doses. J Clin Psychopharmacol. Oct. 1992;12(5):328-33. Source: PubMed. [pmid: 1479050].
276 Beasley CM Jr, Ball SG, Nilsson ME, et al. Fluoxetine and adult suicidality revisited: An updated meta-analysis using expanded data sources from placebo-controlled trials. Journal of Clinical Psychopharmacology. 2007;27(6):682-6. Source: Scopus. [pmid: 18004137].
277 Beaumont G, Gringras M, Ankier SI. Trazodone and mianserin in general practice. Psychopathology. Suppl 2. 1984;17:24-9. Source: PubMed. [pmid: 6371875].
278 Bech P. Meta-analysis of placebo-controlled trials with mirtazapine using the core items of the Hamilton Depression Scale as evidence of a pure antidepressive effect in the short-term treatment of major depression. Int J Neuropsychopharmacol. Dec. 2001;4(4):337-45. Source: PubMed. [pmid: 11806859].
279 Bech P, Allerup P, Gram LF, et al. The Diagnostic Melancholia Scale (DMS): dimensions of endogenous and reactive depression with relationship to the Newcastle Scales. J Affect Disord. Mar-Apr. 1988;14(2):161-70. Source: PubMed. [pmid: 2966830].
280 Bech P, Boyer P, Germain JM, et al. HAM-D17 and HAM-D6 sensitivity to change in relation to desvenlafaxine dose and baseline depression severity in major depressive disorder. Pharmacopsychiatry. 2010;43(7):271-6. Source: EMBASE. [pmid: 20830664].
281 Bech P, Haaber A, Joyce CR. Experiments on clinical observation and judgement in the assessment of depression: profiled videotapes and Judgement Analysis. Psychol Med. Nov. 1986;16(4):873-83. Source: PubMed. [pmid: 3547448].
282 Bech P, Kajdasz DK, Porsdal V. Dose-response relationship of duloxetine in placebo-controlled clinical trials in patients with major depressive disorder. Psychopharmacology. Oct. 2006. 2006;188(3):273-80. Source: PsycINFO. [pmid: 16960699].
283 Bech P, Lonn SL, Overo KF. Relapse prevention and residual symptoms: A closer analysis of placebo-controlled continuation studies with escitalopram in major depressive disorder, generalized anxiety disorder, social anxiety disorder, and obsessive-compulsive disorder. Journal of Clinical Psychiatry. 2010;71(2):121-9. Source: EMBASE. [pmid: 19961809].
284 Beck CA, Patten SB, Williams JVA, et al. Antidepressant utilization in Canada. Social Psychiatry and Psychiatric Epidemiology. 2005;40(10):799-807. Source: EMBASE. [pmid: 16179967].
285 Beck J, Hemmeter U, Brand S, et al. Modafinil reduces microsleep during partial sleep deprivation in depressed patients. Journal of psychiatric research. 2010;44(13):853-64. Source: PsycINFO. [pmid: 20171656].
286 Begre S, Traber M, Gerber M, et al. Change in pain severity with open label venlafaxine use in patients with a depressive symptomatology: an observational study in primary care. Eur Psychiatry. Apr. 2008;23(3):178-86. Source: PubMed. [pmid: 18328675].
287 Begre S, Traber M, Gerber M, et al. Physician speciality and pain reduction in patients with depressive symptoms under treatment with venlafaxine. European Psychiatry. 2010;25(8):455-60. Source: EMBASE. [pmid: 20427156].
288 Begre S, von Bardeleben U, Ladewig D, et al. Paroxetine increases steady-state concentrations of (R)-methadone in CYP2D6 extensive but not poor metabolizers. J Clin Psychopharmacol. Apr. 2002;22(2):211-5. Source: PubMed. [pmid: 11910269].
289 Behnke K, Sogaard J, Martin S, et al. Mirtazapine orally disintegrating tablet versus sertraline: a prospective onset of action study. J Clin Psychopharmacol. Aug. 2003;23(4):358-64. Source: PubMed. [pmid: 12920411].
290 Bell S, Shipman M, Bystritsky A, et al. Fluoxetine treatment and testosterone levels. Ann Clin Psychiatry. Jan-Mar. 2006;18(1):19-22. Source: PubMed. [pmid: 16517449].
291 Bella R, Pennisi G, Cantone M, et al. Clinical presentation and outcome of geriatric depression in subcortical ischemic vascular disease. Gerontology. 2010;56(3):298-302. Source: PubMed. [pmid: 20051663].
292 Bellino S, Barzega G, Bogetto F, et al. An open-label, randomized, prospective comparison of sertraline and amisulpride in the treatment of dysthymia in the elderly. Current Therapeutic Research - Clinical and Experimental. 1997;58(10):798-808. Source: EMBASE.
293 Bellino S, Zizza M, Rinaldi C, et al. Combined treatment of major depression in patients with borderline personality disorder: a comparison with pharmacotherapy. Can J Psychiatry. Jun. 2006;51(7):453-60. Source: PubMed. [pmid: 16838827].
294 Bellodi L, Erzegovesi S, Bianchi L, et al. Plasma tryptophan levels and tryptophan/neutral amino acid ratios in obsessive-compulsive patients with and without depression. Psychiatry Res. Mar. 3. 1997;69(1):9-15. Source: PubMed. [pmid: 9080540].
295 Benazzi F. Involuntary sperm emission with fluoxetine. Can J Psychiatry. Sep. 1995;40(7):431. Source: PubMed. [pmid: 8548730].
296 Benazzi F. Urinary retention with fluoxetine-haloperidol combination in a young patient. Can J Psychiatry. Nov. 1996;41(9):606-7. Source: PubMed. [pmid: 8946091].
297 Benazzi F. Severe anticholinergic side effects with venlafaxine-fluoxetine combination. Can J Psychiatry. Nov. 1997;42(9):980-1. Source: PubMed. [pmid: 9429070].
298 Benazzi F. Venlafaxine-fluoxetine-nortriptyline interaction. J Psychiatry Neurosci. Jul. 1997;22(4):278-9. Source: PubMed. [pmid: 9262050].
299 Benazzi F. Venlafaxine drug-drug interactions in clinical practice. J Psychiatry Neurosci. May. 1998;23(3):181-2. Source: PubMed. [pmid: 9595894].
300 Benazzi F. Venlafaxine-fluoxetine interaction. J Clin Psychopharmacol. Feb. 1999;19(1):96-8. Source: PubMed. [pmid: 9934950].
301 Benazzi F. Organic hypomania secondary to sibutramine-citalopram interaction. J Clin Psychiatry. Feb. 2002;63(2):165. Source: PubMed. [pmid: 11874219].
302 Benazzi F. Fluoxetine and olanzapine for resistant depression. American Journal of Psychiatry. 2002;159(1):155-6. Source: EMBASE. [pmid: 11772722].
303 Benazzi F. Hemorrhages during escitalopram-venlafaxine-mirtazapine combination treatment of depression. Can J Psychiatry. Mar. 2005;50(3):184. Source: PubMed. [pmid: 15830829].
304 Benazzi F, Berk M, Frye MA, et al. Olanzapine/fluoxetine combination for the treatment of mixed depression in bipolar I disorder: a post hoc analysis. J Clin Psychiatry. Oct. 2009;70(10):1424-31. Source: PubMed. [pmid: 19906346].
305 Benedetti F, Barbini B, Bernasconi A, et al. Serotonin 5-HT2A receptor gene variants influence antidepressant response to repeated total sleep deprivation in bipolar depression. Progress in Neuro Psychopharmacology and Biological Psychiatry. 2008;32(8):1863-6. Source: EMBASE. [pmid: 18801406].
306 Benedetti F, Barbini B, Campori E, et al. Patterns of mood variation during antidepressant treatment. J Affect Disord. May. 1998;49(2):133-9. Source: PubMed. [pmid: 9609677].
307 Benedetti F, Campori E, Colombo C, et al. Fluvoxamine treatment of major depression associated with multiple sclerosis. J Neuropsychiatry Clin Neurosci. Summer. 2004;16(3):364-6. Source: PubMed. [pmid: 15377746].
308 Benedetti F, Colombo C, Pontiggia A, et al. Morning light treatment hastens the antidepressant effect of citalopram: a placebo-controlled trial. J Clin Psychiatry. Jun. 2003;64(6):648-53. Source: PubMed. [pmid: 12823078].
309 Benedictis E. Double-blind comparison of venlafaxine and amitriptyline in outpatients with major depression with or without melancholia. J Psychopharmacol. Mar. 2000;14(1):61-6. Source: PubMed. [pmid: 10757255].
310 Bengtsson BO, Lundmark J, Walinder J. No crossover reactions to citalopram or paroxetine among patients hypersensitive to zimeldine. Br J Psychiatry. Jun. 1991;158:853-5. Source: PubMed. [pmid: 1831396].
311 Benkelfat C, Poirier MF, Leouffre P, et al. Dexamethasone suppression test and the response to antidepressant depending on their central monoaminergic action in major depression. Can J Psychiatry. Apr. 1987;32(3):175-8. Source: PubMed. [pmid: 3471304].
312 Benkert O, Grunder G, Wetzel H, et al. A randomized, double-blind comparison of a rapidly escalating dose of venlafaxine and imipramine in inpatients with major depression and melancholia. J Psychiatr Res. Nov-Dec. 1996;30(6):441-51. Source: PubMed. [pmid: 9023787].
313 Benkert O, Szegedi A, Kohnen R. Mirtazapine compared with paroxetine in major depression. J Clin Psychiatry. Sep. 2000;61(9):656-63. Source: PubMed. [pmid: 11030486].
314 Benkert O, Szegedi A, Philipp M, et al. Mirtazapine orally disintegrating tablets versus venlafaxine extended release: a double-blind, randomized multicenter trial comparing the onset of antidepressant response in patients with major depressive disorder. J Clin Psychopharmacol. 2006;26(1):75-8. Source: PubMed. [pmid: 16415711].
315 Benkert O, Szegedi A, Wetzel H, et al. Dose escalation vs. continued doses of paroxetine and maprotiline: a prospective study in depressed out-patients with inadequate treatment response. Acta Psychiatr Scand. Apr. 1997;95(4):288-96. Source: PubMed. [pmid: 9150822].
316 Bennie EH, Khan MC, Tyrer SP, et al. Comparison of trazodone and mianserin in depressive illness. Curr Med Res Opin. 1984;9(4):253-8. Source: PubMed. [pmid: 6391830].
317 Bennie EH, Mullin JM, Martindale JJ. A double-blind multicenter trial comparing sertraline and fluoxetine in outpatients with major depression. J Clin Psychiatry. Jun. 1995;56(6):229-37. Source: PubMed. [pmid: 7775364].
318 Bent-Hansen J, Lunde M, Klysner R, et al. The validity of the depression rating scales in discriminating between citalopram and placebo in depression recurrence in the maintenance therapy of elderly unipolar patients with major depression. Pharmacopsychiatry. Nov. 2003;36(6):313-6. Source: PubMed. [pmid: 14663657].
319 Benvenuti A, Rucci P, Calugi S, et al. Relationship of residual mood and panic-agoraphobic spectrum phenomenology to quality of life and functional impairment in patients with major depression. Int Clin Psychopharmacol. Mar. 2010;25(2):68-74. Source: PubMed. [pmid: 20061961].
320 Bergstrom RF, Beasley CM Jr., Levy NB, et al. The effects of renal and hepatic disease on the pharmacokinetics, renal tolerance, and risk-benefit profile of fluoxetine. Int Clin Psychopharmacol. Winter. 1993;8(4):261-6. Source: PubMed. [pmid: 8277145].
321 Berk M, Acton M. Citalopram-associated clitoral priapism: a case series. Int Clin Psychopharmacol. Mar. 1997;12(2):121-2. Source: PubMed. [pmid: 9219048].
322 Berk M, du Plessis AD, Birkett M, et al. An open-label study of duloxetine hydrochloride, a mixed serotonin and noradrenaline reuptake inhibitor, in patients with DSM-III-R major depressive disorder. Lilly Duloxetine Depression Study Group Int Clin Psychopharmacol. May. 1997;12(3):137-40. Source: PubMed.
323 Berkrot B. US prescription drug sales hit $300 bln in 2009. 2010. Source: Handsearch.
324 Berlanga C, Arechavaleta B, Heinze G, et al. A double-blind comparison of nefazodone and fluoxetine in the treatment of depressed outpatients. Salud Mental. 1997;20(3):1-8. Source: EMBASE.
325 Berlanga C, Flores-Ramos M. Different gender response to serotonergic and noradrenergic antidepressants. A comparative study of the efficacy of citalopram and reboxetine. J Affect Disord. Oct. 2006;95(1-3):119-23. Source: PubMed. [pmid: 16782204].
326 Berlanga C, Mendieta D, Alva G, et al. Failure of tibolone to potentiate the pharmacological effect of fluoxetine in postmenopausal major depression. J Womens Health (Larchmt). Jan-Feb. 2003;12(1):33-9. Source: PubMed. [pmid: 12639367].
327 Berle JO, Steen VM, Aamo TO, et al. Breastfeeding during maternal antidepressant treatment with serotonin reuptake inhibitors: infant exposure, clinical symptoms, and cytochrome p450 genotypes. J Clin Psychiatry. Sep. 2004;65(9):1228-34. Source: PubMed. [pmid: 15367050].
328 Berlim MT, Pavanello DP, Caldieraro MAK, et al. Reliability and validity of the WHOQOL BREF in a sample of Brazilian outpatients with major depression. Quality of Life Research. 2005;14(2):561-4. Source: EMBASE. [pmid: 15892446].
329 Berlin I, Lavergne F. Early predictors of two month response with mianserin and selective serotonin reuptake inhibitors and influence of definition of outcome on prediction. European Psychiatry. 1998;13(3):138-42. Source: EMBASE. [pmid: 19698616].
330 Berman RM, Anand A, Cappiello A, et al. The use of pindolol with fluoxetine in the treatment of major depression: final results from a double-blind, placebo-controlled trial. Biol Psychiatry. May. 1. 1999;45(9):1170-7. Source: PubMed. [pmid: 10331109].
331 Berman RM, Darnell AM, Miller HL, et al. Effect of pindolol in hastening response to fluoxetine in the treatment of major depression: a double-blind, placebo-controlled trial. Am J Psychiatry. Jan. 1997;154(1):37-43. Source: PubMed. [pmid: 8988956].
332 Berman RM, Fava M, Thase ME, et al. Aripiprazole augmentation in major depressive disorder: a double-blind, placebo-controlled study in patients with inadequate response to antidepressants. CNS Spectr. Apr. 2009;14(4):197-206. Source: PubMed. [pmid: 19407731].
333 Berman RM, Marcus RN, Swanink R, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder: a multicenter, randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Jun. 2007;68(6):843-53. Source: PubMed. [pmid: 17592907].
334 Bernardi S, Pallanti S. Successful duloxetine treatment of a binge eating disorder: A case report. Journal of Psychopharmacology. 2010;24(8):1269-72. Source: EMBASE. [pmid: 19010975].
335 Bernardo M, Navarro V, Salva J, et al. Seizure activity and safety in combined treatment with venlafaxine and ECT: a pilot study. J Ect. Mar. 2000;16(1):38-42. Source: PubMed. [pmid: 10735330].
336 Berndt ER, Koran LM, Finkelstein SN, et al. Lost human capital from early-onset chronic depression. Am J Psychiatry. Jun. 2000;157(6):940-7. Source: PubMed. [pmid: 10831474].
337 Berney A, Nishikawa M, Benkelfat C, et al. An index of 5-HT synthesis changes during early antidepressant treatment: alpha-[11C]methyl-L-tryptophan PET study. Neurochem Int. Mar-Apr. 2008;52(4-5):701-8. Source: PubMed. [pmid: 17928105].
338 Bersani G, Rapisarda V, Cian iN, et al. A double-blind comparative study of sertraline and amitriptyline in outpatients with major depressive episodes. Hum Psychopharmacol. 1994;9(1):63-8. Source: EMBASE.
339 Bertolin-Guillen JM, Climent-Diaz B, Navarre-Gimeno A. Serotonin syndrome due to association of venlafaxine, maprotiline and reboxetine. Eur Psychiatry. Nov. 2004;19(7):456-7. Source: PubMed. [pmid: 15504661].
340 Bertschy G, Baumann P, Eap CB, et al. Probable metabolic interaction between methadone and fluvoxamine in addict patients. Ther Drug Monit. Feb. 1994;16(1):42-5. Source: PubMed. [pmid: 8160253].
341 Bertschy G, Ragama-Pardos E, Muscionico M, et al. Trazodone addition for insomnia in venlafaxine-treated, depressed inpatients: a semi-naturalistic study. Pharmacol Res. Jan. 2005;51(1):79-84. Source: PubMed. [pmid: 15519538].
342 Besancon G, Cousin R, Guitton B, et al. Mianserin versus fluoxetine in a double blind trial depressed out-patients. <ORIGINAL>. ETUDE EN DOUBLE AVEUGLE DE LA MIANSERINE ET DE LA FLUOXETINE CHEZ DES PATIENTS DEPRIMES TRAITES EN AMBULATOIRE. Encephale. 1993;19(4):341-5. Source: EMBASE. [pmid: 8275922].
343 Beusterien KM, Buesching DP, Robison RN, et al. Evaluation of an information exchange program for primary care patients with depression. Disease Management. 2000;3(1):1-9. Source: EMBASE.
344 Beusterien KM, Steinwald B, Ware JE Jr. Usefulness of the SF-36 Health Survey in measuring health outcomes in the depressed elderly. J Geriatr Psychiatry Neurol. Jan. 1996;9(1):13-21. Source: PubMed. [pmid: 8679058].
345 Beuzen JN, Ravily VF, Souetre EJ, et al. Impact of fluoxetine on work loss in depression. Int Clin Psychopharmacol. Winter. 1993;8(4):319-21. Source: PubMed. [pmid: 8277155].
346 Bezchlibnyk-Butler K, Aleksic I, Kennedy SH. Citalopram--a review of pharmacological and clinical effects. J Psychiatry Neurosci. May. 2000;25(3):241-54. Source: PubMed. [pmid: 10863884].
347 Bhagwagar Z, Cowen PJ, Goodwin GM, et al. Normalization of enhanced fear recognition by acute SSRI treatment in subjects with a previous history of depression. Am J Psychiatry. Jan. 2004;161(1):166-8. Source: PubMed. [pmid: 14702268].
348 Bhagwagar Z, Whale R, Cowen PJ. State and trait abnormalities in serotonin function in major depression. Br J Psychiatry. Jan. 2002;180:24-8. Source: PubMed. [pmid: 11772847].
349 Bhanji NH. Serotonin syndrome following low-dose sertraline. Can J Psychiatry. Dec. 2000;45(10):936-7. Source: PubMed. [pmid: 11190366].
350 Bhar SS, Gelfand LA, Schmid SP, et al. Sequence of improvement in depressive symptoms across cognitive therapy and pharmacotherapy. J Affect Disord. Sep. 2008;110(1-2):161-6. Source: PubMed. [pmid: 18276017].
351 Bharucha KJ, Sethi KD. Complex movement disorders induced by fluoxetine. Mov Disord. May. 1996;11(3):324-6. Source: PubMed. [pmid: 8723152].
352 Bhatara VS, Magnus RD, Paul KL, et al. Serotonin syndrome induced by venlafaxine and fluoxetine: a case study in polypharmacy and potential pharmacodynamic and pharmacokinetic mechanisms. Ann Pharmacother. Apr. 1998;32(4):432-6. Source: PubMed. [pmid: 9562139].
353 Bielski RJ, Ventura D, Chang CC. A double-blind comparison of escitalopram and venlafaxine extended release in the treatment of major depressive disorder. J Clin Psychiatry. Sep. 2004;65(9):1190-6. Source: PubMed. [pmid: 15367045].
354 Bignamini A, Rapisarda V. A double-blind multicentre study of paroxetine and amitriptyline in depressed outpatients. Italian Paroxetine Study Group. Int Clin Psychopharmacol. Jun. Suppl 4. 1992;6:37-41. Source: PubMed. [pmid: 1431009].
355 Bigos KL, Pollock BG, Aizenstein HJ, et al. Acute 5-HT reuptake blockade potentiates human amygdala reactivity. Neuropsychopharmacology. Dec. 2008;33(13):3221-5. Source: PubMed. [pmid: 18463627].
356 Bijl D, Van Marwijk HWJ, Beekman ATF, et al. A randomized controlled trial to improve the recognition, diagnosis and treatment of major depression in elderly people in general practice: Design, first results and feasibility of the West Friesland Study. Primary Care Psychiatry. 2003;8(4):135-40. Source: EMBASE.
357 Binder EB, Jeffrey Newport D, Zach EB, et al. A serotonin transporter gene polymorphism predicts peripartum depressive symptoms in an at-risk psychiatric cohort. Journal of psychiatric research. 2010;44(10):640-6. Source: EMBASE. [pmid: 20045118].
358 Binder EB, Owens MJ, Liu W, et al. Association of polymorphisms in genes regulating the corticotropin- releasing factor system with antidepressant treatment response. Archives of general psychiatry. 2010;67(4):369-79. Source: EMBASE. [pmid: 20368512].
359 Binneman B, Feltner D, Kolluri S, et al. A 6-week randomized, placebo-controlled trial of CP-316,311 (a selective CRH1 antagonist) in the treatment of major depression. Am J Psychiatry. May. 2008;165(5):617-20. Source: PubMed. [pmid: 18413705].
360 Birkenhager TK, van den Broek WW, Fekkes D, et al. Lithium addition in antidepressant-resistant depression: Effects on platelet 5-HT, plasma 5-HT and plasma 5-HIAA concentration. Progress in Neuro Psychopharmacology and Biological Psychiatry. 2007;31(5):1084-8. Source: EMBASE. [pmid: 17467132].
361 Birkenhager TK, van den Broek WW, Moleman P, et al. Imipramine dose in relation to therapeutic plasma level: are clinical trials using imipramine as a positive control flawed?. Psychopharmacology (Berl). Sep. 2005;181(3):595-9. Source: PubMed. [pmid: 16133127].
362 Birkenhager TK, van den Broek WW, Mulder PG, et al. Comparison of two-phase treatment with imipramine or fluvoxamine, both followed by lithium addition, in inpatients with major depressive disorder. Am J Psychiatry. Nov. 2004;161(11):2060-5. Source: PubMed. [pmid: 15514407].
363 Birnbaum HG, Ben-Hamadi R, Greenberg PE, et al. Determinants of direct cost differences among US employees with major depressive disorders using antidepressants. PharmacoEconomics. 2009;27(6):507-17. Source: EMBASE. [pmid: 19640013].
364 Bisol LW, Lara DR. Low-dose quetiapine for patients with dysregulation of hyperthymic and cyclothymic temperaments. Journal of Psychopharmacology. 2010;24(3):421-4. Source: EMBASE. [pmid: 18838499].
365 Biswas PN, Wilton LV, Shakir SA. The pharmacovigilance of mirtazapine: results of a prescription event monitoring study on 13554 patients in England. J Psychopharmacol. Mar. 2003;17(1):121-6. Source: PubMed. [pmid: 12680749].
366 Bitanihirwe BKY, Lim MP, Woo TUW. N-methyl-D-aspartate receptor expression in parvalbumin-containing inhibitory neurons in the prefrontal cortex in bipolar disorder. Bipolar Disorders. 2010;12(1):95-101. Source: EMBASE. [pmid: 20148871].
367 Bjerkenstedt L, Edman G, Flyckt L, et al. Clinical and biochemical effects of citalopram, a selective 5-HT reuptake inhibitor--a dose-response study in depressed patients. Psychopharmacology (Berl). 1985;87(3):253-9. Source: PubMed. [pmid: 3936081].
368 Bjerkenstedt L, Flyckt L, Overo KF, et al. Relationship between clinical effects, serum drug concentration and serotonin uptake inhibition in depressed patients treated with citalopram. A double-blind comparison of three dose levels. Eur J Clin Pharmacol. 1985;28(5):553-7. Source: PubMed. [pmid: 3899675].
369 Black DW, Wesner R, Bowers W, et al. Acute treatment response in outpatients with panic disorder: high versus low depressive symptoms. Ann Clin Psychiatry. Dec. 1995;7(4):181-8. Source: PubMed. [pmid: 8721892].
370 Black DW, Wesner R, Gabel J. The abrupt discontinuation of fluvoxamine in patients with panic disorder. J Clin Psychiatry. Apr. 1993;54(4):146-9. Source: PubMed. [pmid: 8486592].
371 Blardi P, De Lalla A, Leo A, et al. Serotonin and fluoxetine levels in plasma and platelets after fluoxetine treatment in depressive patients. J Clin Psychopharmacol. Apr. 2002;22(2):131-6. Source: PubMed. [pmid: 11910257].
372 Blardi P, de Lalla A, Urso R, et al. Activity of citalopram on adenosine and serotonin circulating levels in depressed patients. J Clin Psychopharmacol. Jun. 2005;25(3):262-6. Source: PubMed. [pmid: 15876907].
373 Blier P, Bergeron R, de Montigny C. Selective activation of postsynaptic 5-HT1A receptors induces rapid antidepressant response. Neuropsychopharmacology. May. 1997;16(5):333-8. Source: PubMed. [pmid: 9109104].
374 Blier P, Gobbi G, Turcotte JE, et al. Mirtazapine and paroxetine in major depression: a comparison of monotherapy versus their combination from treatment initiation. Eur Neuropsychopharmacol. 2009;19(7):457-65. Source: PubMed. [pmid: 19345072].
375 Blier P, Ward HE, Tremblay P. Combination of antidepressant from treatment initiation for depression. American Psychiatric Association annual meeting. 2006. Source: Scopus.
376 Blier P, Ward HE, Tremblay P, et al. Combination of antidepressant medications from treatment initiation for major depressive disorder: a double-blind randomized study. Am J Psychiatry. Mar. 2010;167(3):281-8. Source: PubMed. [pmid: 20008946].
377 Bligh-Glover W, Kolli TN, Shapiro-Kulnane L, et al. The serotonin transporter in the midbrain of suicide victims with major depression. Biol Psychiatry. Jun. 15. 2000;47(12):1015-24. Source: PubMed. [pmid: 10862800].
378 Block J. Serious Adverse Events and the Modafinil Augmentation Study. CNS Spectrums. May. 2006. 2006;11(5):340. Source: PsycINFO. [pmid: 16791971].
379 Blom MB, Jonker K, Dusseldorp E, et al. Combination treatment for acute depression is superior only when psychotherapy is added to medication. Psychother Psychosom. 2007;76(5):289-97. Source: PubMed. [pmid: 17700049].
380 Blom MBJ, Hoek HW, Spinhoven P, et al. Treatment of depression in patients from ethnic minority groups in the Netherlands. Transcultural Psychiatry. 2010;47(3):473-90. Source: EMBASE. [pmid: 20688800].
381 Blumenfield M, Levy NB, Spinowitz B, et al. Fluoxetine in depressed patients on dialysis. Int J Psychiatry Med. 1997;27(1):71-80. Source: PubMed. [pmid: 9565715].
382 Blumenthal JA, Babyak MA, Doraiswamy PM, et al. Exercise and pharmacotherapy in the treatment of major depressive disorder. Psychosom Med. 2007;69(7):587-96. Source: PubMed. [pmid: 17846259].
383 Bobo WV, Shelton RC. Fluoxetine and olanzapine combination therapy in treatment-resistant major depression: review of efficacy and safety data. Expert Opin Pharmacother. Sep. 2009;10(13):2145-59. Source: PubMed. [pmid: 19640209].
384 Bobon DP, Lapierre YD, Lottin T. Validity and sensitivity of the French version of the Zerssen BfS/BfS' self-rating mood scale during treatment with trazodone and amitriptyline. Progress in Neuro-Psychopharmacology. 1981;5(5-6):519-22. Source: EMBASE. [pmid: 7339644].
385 Bodkin JA, Lasser RA, Wines JD Jr., et al. Combining serotonin reuptake inhibitors and bupropion in partial responders to antidepressant monotherapy. J Clin Psychiatry. Apr. 1997;58(4):137-45. Source: PubMed. [pmid: 9164423].
386 Bodnar LM, Sunder KR, Wisner KL. Treatment with selective serotonin reuptake inhibitors during pregnancy: deceleration of weight gain because of depression or drug. Am J Psychiatry. Jun. 2006;163(6):986-91. Source: PubMed. [pmid: 16741197].
387 Bogetto F, Barzega G, Bellino S, et al. Drug treatment of dysthymia: A clinical study. <ORIGINAL>. IL TRATTAMENTO FARMACOLOGICO DELLA DISTIMIA: UNO STUDIO CLINICO. Rivista Di Psichiatria. 1997;32(1):1-5. Source: EMBASE.
388 Bogetto F, Bellino S, Revello RB, et al. Discontinuation syndrome in dysthymic patients treated with selective serotonin reuptake inhibitors: a clinical investigation. CNS Drugs. 2002;16(4):273-83. Source: PubMed. [pmid: 11945110].
389 Bogetto F, Revello RB, Ferro G, et al. Psychopharmacological treatment of burning mouth syndrome (BMS). A study on a sample of 121 patients. Minerva Psichiatrica. 1999;40(1):1-10. Source: EMBASE.
390 Boggio PS, Fregni F, Bermpohl F, et al. Effect of repetitive TMS and fluoxetine on cognitive function in patients with Parkinson's disease and concurrent depression. Mov Disord. Sep. 2005;20(9):1178-84. Source: PubMed. [pmid: 15895421].
391 Bogner HR, Lin JY, Morales KH. Patterns of early adherence to the antidepressant citalopram among older primary care patients: the prospect study. Int J Psychiatry Med. 2006;36(1):103-19. Source: PubMed. [pmid: 16927582].
392 Bolukbasi O, Akyol A. Spontaneous erections and libido increase associated with venlafaxine. Eur J Neurol. Jul. 1999;6(4):527-8. Source: PubMed. [pmid: 10362913].
393 Bombardier CH, Fann JR, Temkin NR, et al. Rates of major depressive disorder and clinical outcomes following traumatic brain injury. JAMA - Journal of the American Medical Association. 2010;303(19):1938-45. Source: EMBASE.
394 Bonaccorso S, Lin AH, Verkerk R, et al. Immune markers in fibromyalgia: comparison with major depressed patients and normal volunteers. J Affect Disord. Feb. 1998;48(1):75-82. Source: PubMed. [pmid: 9495605].
395 Bondareff W, Alpert M, Friedhoff AJ, et al. Comparison of sertraline and nortriptyline in the treatment of major depressive disorder in late life. Am J Psychiatry. May. 2000;157(5):729-36. Source: PubMed. [pmid: 10784465].
396 Bondolfi G, Chautems C, Rochat B, et al. Non-response to citalopram in depressive patients: pharmacokinetic and clinical consequences of a fluvoxamine augmentation. Psychopharmacology (Berl). Dec. 1996;128(4):421-5. Source: PubMed. [pmid: 8986013].
397 Bonne O, Krausz Y. Pathophysiological significance of cerebral perfusion abnormalities in major depression-trait or state marker. Eur Neuropsychopharmacol. Aug. 1997;7(3):225-33. Source: PubMed. [pmid: 9213083].
398 Book SW, Thomas SE, Randall PK, et al. Paroxetine reduces social anxiety in individuals with a co-occurring alcohol use disorder. J Anxiety Disord. 2008;22(2):310-8. Source: PubMed. [pmid: 17448631].
399 Bordet R, Thomas P, Dupuis B. Effect of pindolol on onset of action of paroxetine in the treatment of major depression: intermediate analysis of a double-blind, placebo-controlled trial. Reseau de Recherche et d'Experimentation Psychopharmacologique. Am J Psychiatry. Oct. 1998;155(10):1346-51. Source: PubMed. [pmid: 9766765].
400 Borkowska A, Drozdz W, Ziolkowska-Kochan M, et al. Enhancing effect of mirtazapine on cognitive functions associated with prefrontal cortex in patients with recurrent depression. Neuropsychopharmacol Hung. Oct. 2007;9(3):131-6. Source: PubMed. [pmid: 18399031].
401 Borrelli B, Niaura R, Keuthen NJ, et al. Development of major depressive disorder during smoking-cessation treatment. J Clin Psychiatry. Nov. 1996;57(11):534-8. Source: PubMed. [pmid: 8968303].
402 Bortolotti B, Menchetti M, Bellini F, et al. Psychological interventions for major depression in primary care: a meta-analytic review of randomized controlled trials. Gen Hosp Psychiatry. Jul-Aug. 2008;30(4):293-302. Source: PubMed. [pmid: 18585531].
403 Bosc M, Dubini A, Polin V. Development and validation of a social functioning scale, the Social Adaptation Self-evaluation Scale. Eur Neuropsychopharmacol. Apr. Suppl 1. 1997;7:S57-70. discussion S1-3. Source: PubMed. [pmid: 9169311].
404 Bose A, Li D, Gandhi C. Escitalopram in the acute treatment of depressed patients aged 60 years or older. Am J Geriatr Psychiatry. 2008;16(1):14-20. Source: PubMed. [pmid: 18165459].
405 Bosmans JE, Hermens MLM, de Bruijne MC, et al. Cost-effectiveness of usual general practitioner care with or without antidepressant medication for patients with minor or mild-major depression. Journal of Affective Disorders. 2008;111(1):106-12. Source: EMBASE. [pmid: 18342952].
406 Bossini L, Fagiolini A, Valdagno M, et al. Sexual disorders in subjects treated for mood and anxiety diseases [8]. Journal of Clinical Psychopharmacology. 2007;27(3):310-2. Source: EMBASE. [pmid: 17502785].
407 Bostwick JM, Brown TM. A toxic reaction from combining fluoxetine and phentermine. J Clin Psychopharmacol. Apr. 1996;16(2):189-90. Source: PubMed. [pmid: 8690835].
408 Bosworth HB, Voils CI, Potter GG, et al. The effects of antidepressant medication adherence as well as psychosocial and clinical factors on depression outcomeamong older adults. International Journal of Geriatric Psychiatry. 2008;23(2):129-34. Source: EMBASE. [pmid: 17563920].
409 Bot M, Pouwer F, Assies J, et al. Eicosapentaenoic acid as an add-on to antidepressant medication for co-morbid major depression in patients with diabetes mellitus: A randomized, double-blind placebo-controlled study. Journal of affective disorders. 2010;126(1-2):282-6. Source: PsycINFO. [pmid: 20466431].
410 Botros WA, Ankier SI, Priest RG, et al. Clinical assessment and performance tasks in depression: a comparison of amitriptyline and trazodone. Br J Psychiatry. Oct. 1989;155:479-82. Source: PubMed. [pmid: 2692763].
411 Bouchard JM, Delaunay J, Delisle JP, et al. Citalopram versus maprotiline: a controlled, clinical multicentre trial in depressed patients. Acta Psychiatr Scand. Nov. 1987;76(5):583-92. Source: PubMed. [pmid: 3324648].
412 Bouchard JM, Strub N, Nil R. Citalopram and viloxazine in the treatment of depression by means of slow drop infusion. A double-blind comparative trial. J Affect Disord. Oct. 1997;46(1):51-8. Source: PubMed. [pmid: 9387086].
413 Boucher N, Bairam A, Beaulac-Baillargeon L. A new look at the neonate's clinical presentation after in utero exposure to antidepressants in late pregnancy. J Clin Psychopharmacol. Jun. 2008;28(3):334-9. Source: PubMed. [pmid: 18480693].
414 Bougerol T, Uchida C, Gachoud JP, et al. Efficacy and tolerability of moclobemide compared with fluvoxamine in depressive disorder (DSM III). A French/Swiss double-blind trial. Psychopharmacology (Berl). 1992;106(Suppl):S102-8. Source: PubMed. [pmid: 1546121].
415 Boulenger JP, Hermes A, Huusom AK, et al. Baseline anxiety effect on outcome of SSRI treatment in patients with severe depression: escitalopram vs paroxetine. Curr Med Res Opin. 2010;26(3):605-14. Source: PubMed. [pmid: 20067433].
416 Boulenger JP, Huusom AK, Florea I, et al. A comparative study of the efficacy of long-term treatment with escitalopram and paroxetine in severely depressed patients. Curr Med Res Opin. 2006;22(7):1331-41. Source: PubMed. [pmid: 16834832].
417 Boulton DW, Balch AH, Royzman K, et al. The pharmacokinetics of standard antidepressants with aripiprazole as adjunctive therapy: studies in healthy subjects and in patients with major depressive disorder. J Psychopharmacol. Apr. 2010;24(4):537-46. Source: PubMed. [pmid: 18832427].
418 Bouman WP, Johnson H, Trescoli-Serrano C, et al. Recurrent hyponatremia associated with sertraline and lofepramine. Am J Psychiatry. Apr. 1997;154(4):580. Source: PubMed. [pmid: 9090354].
419 Bourgeois JA. Reversible hyponatremia and venlafaxine. Psychosomatics. Sep-Oct. 2005;46(5):495-6. Source: PubMed. [pmid: 16145194].
420 Bourin M. Use of paroxetine for the treatment of depression and anxiety disorders in the elderly: a review. Hum Psychopharmacol. Apr. 2003;18(3):185-90. Source: PubMed. [pmid: 12672169].
421 Bourin M, Prica C. Melatonin receptor agonist agomelatine: A new drug for treating unipolar depression. Current Pharmaceutical Design. 2009;15(14):1675-82. Source: Scopus. [pmid: 19442180].
422 Bowdan ND. Seizure possibly caused by trazodone HCl. Am J Psychiatry. May. 1983;140(5):642. Source: PubMed. [pmid: 6846599].
423 Bowden CL, Schatzberg AF, Rosenbaum A, et al. Fluoxetine and desipramine in major depressive disorder. J Clin Psychopharmacol. Oct. 1993;13(5):305-11. Source: PubMed. [pmid: 8227488].
424 Boyer P, Danion JM, Bisserbe JC, et al. Clinical and economic comparison of sertraline and fluoxetine in the treatment of depression. A 6-month double-blind study in a primary-care setting in France. Pharmacoeconomics. Jan. 1998;13(1 Pt 2):157-69. Source: PubMed. [pmid: 10184835].
425 Boyer P, Montgomery S, Lepola U, et al. Efficacy, safety, and tolerability of fixed-dose desvenlafaxine 50 and 100 mg/day for major depressive disorder in a placebo-controlled trial. Int Clin Psychopharmacol. 2008;23(5):243-53. Source: PubMed. [pmid: 18703933].
426 Boyer WF, Blumhardt CL. The safety profile of paroxetine. J Clin Psychiatry. Feb. 1992;53(Suppl):61-6. Source: PubMed. [pmid: 1531828].
427 Boyle MP, Brewer JA, Funatsu M, et al. Acquired deficit of forebrain glucocorticoid receptor produces depression-like changes in adrenal axis regulation and behavior. Proceedings of the National Academy of Sciences of the United States of America. 2005;102(2):473-8. Source: Scopus. [pmid: 15623560].
428 Braconnier A, Le Coent R, Cohen D. Paroxetine versus clomipramine in adolescents with severe major depression: a double-blind, randomized, multicenter trial. J Am Acad Child Adolesc Psychiatry. Jan. 2003;42(1):22-9. Source: PubMed. [pmid: 12500073].
429 Bradford JM, Gratzer TG. A treatment for impulse control disorders and paraphilia: a case report. Can J Psychiatry. Feb. 1995;40(1):4-5. Source: PubMed. [pmid: 7874674].
430 Bradley RH, Barkin RL, Jerome J, et al. Efficacy of venlafaxine for the long term treatment of chronic pain with associated major depressive disorder. Am J Ther. Sep-Oct. 2003;10(5):318-23. Source: PubMed. [pmid: 12975715].
431 Brady K, Zarzar M, Lydiard RB. Fluoxetine in panic disorder patients with imipramine-associated weight gain. J Clin Psychopharmacol. Feb. 1989;9(1):66-7. Source: PubMed. [pmid: 2785123].
432 Brady KT, Clary CM. Affective and anxiety comorbidity in post-traumatic stress disorder treatment trials of sertraline. Compr Psychiatry. Sep-Oct. 2003;44(5):360-9. Source: PubMed. [pmid: 14505296].
433 Brady KT, Lydiard RB, Kellner CH, et al. A comparison of the effects of imipramine and fluvoxamine on the thyroid axis. Biol Psychiatry. Dec. 1. 1994;36(11):778-9. Source: PubMed. [pmid: 7858077].
434 Brambilla P, Cipriani A, Hotopf M, et al. Side-effect profile of fluoxetine in comparison with other SSRIs, tricyclic and newer antidepressants: a meta-analysis of clinical trial data. Pharmacopsychiatry. Mar. 2005;38(2):69-77. Source: PubMed. [pmid: 15744630].
435 Branconnier RJ, Cole JO, Ghazvinian S, et al. Clinical pharmacology of bupropion and imipramine in elderly depressives. J Clin Psychiatry. May. 1983;44(5 Pt 2):130-3. Source: PubMed. [pmid: 6406441].
436 Brand S, Lehtinen A, Hatzinger M, et al. Comparison of sleep EEG profiles of patients suffering from restless legs syndrome, restless legs syndrome and depressive symptoms, and major depressive disorders. Neuropsychobiology. 2010;61(1):41-8. Source: EMBASE. [pmid: 19940519].
437 Brannan SK, Mallinckrodt CH, Brown EB, et al. Duloxetine 60 mg once-daily in the treatment of painful physical symptoms in patients with major depressive disorder. J Psychiatr Res. Jan. 2005;39(1):43-53. Source: PubMed. [pmid: 15504423].
438 Brannan SK, Mallinckrodt CH, Detke MJ, et al. Onset of action for duloxetine 60 mg once daily: double-blind, placebo-controlled studies. J Psychiatr Res. Mar. 2005;39(2):161-72. Source: PubMed. [pmid: 15589564].
439 Brecht S, Courtecuisse C, Debieuvre C, et al. Efficacy and safety of duloxetine 60 mg once daily in the treatment of pain in patients with major depressive disorder and at least moderate pain of unknown etiology: a randomized controlled trial. J Clin Psychiatry. 2007;68(11):1707-16. Source: PubMed. [pmid: 18052564].
440 Brecht S, Kajdasz D, Ball S, et al. Clinical impact of duloxetine treatment on sleep in patients with major depressive disorder. Int Clin Psychopharmacol. 2008;23(6):317-24. Source: PubMed. [pmid: 18854719].
441 Breitbart W, Rosenfeld B, Gibson C, et al. Impact of treatment for depression on desire for hastened death in patients with advanced AIDS. Psychosomatics: Journal of Consultation Liaison Psychiatry. 2010;51(2):98-105. Source: PsycINFO.
442 Bremner JD. Fluoxetine in depressed patients: a comparison with imipramine. J Clin Psychiatry. Oct. 1984;45(10):414-9. Source: PubMed. [pmid: 6384203].
443 Bremner JD. Double-blind comparison of mirtazapine, amitriptyline and placebo in major depression. <ORIGINAL>. DOPPELBLINDVERGLEICH VON MIRTAZAPIN, AMITRIPTYLIN UND PLAZEBO BEI ‘MAJOR DEPRESSION”. Nervenheilkunde. 1996;15(8):533-40. Source: EMBASE.
444 Bremner JD, Smith WT. Org 3770 VS amitriptyline in the continuation treatment of depression: A placebo controlled trial. European Journal of Psychiatry. 1996;10(1):5-15. Source: EMBASE.
445 Bremner JD, Vythilingam M, Vermetten E, et al. Effects of antidepressant treatment on neural correlates of emotional and neutral declarative verbal memory in depression. Journal of Affective Disorders. 2007;101(1-3):99-111. Source: EMBASE. [pmid: 17182108].
446 Brent D. Antidepressants and suicidal behavior: Cause or cure?. American Journal of Psychiatry. 2007;164(7):989-91. Source: Scopus. [pmid: 17606644].
447 Brent D, Emslie G, Clarke G, et al. Switching to another SSRI or to venlafaxine with or without cognitive behavioral therapy for adolescents with SSRI-resistant depression - The TORDIA randomized controlled trial. Journal of the American Medical Association (USA). 08. 01. 2008;299(Aug):901-13. Source: PsycINFO.
448 Brent DA. Antidepressants and pediatric depression--the risk of doing nothing. N Engl J Med. Oct. 14. 2004;351(16):1598-601. Source: PubMed. [pmid: 15483276].
449 Bressi C, Porcellana M, Marinaccio PM, et al. Short-term psychodynamic psychotherapy versus treatment as usual for depressive and anxiety disorders: A randomized clinical trial of efficacy. Journal of Nervous and Mental Disease. 2010;198(9):647-52. Source: EMBASE. [pmid: 20823726].
450 Bretlau LG, Lunde M, Lindberg L, et al. Repetitive transcranial magnetic stimulation (rTMS) in combination with escitalopram in patients with treatment-resistant major depression: a double-blind, randomised, sham-controlled trial. Pharmacopsychiatry. Mar. 2008;41(2):41-7. Source: PubMed. [pmid: 18311683].
451 Brewerton TD. Fluoxetine-induced suicidality, serotonin, and seasonality. Biol Psychiatry. Jul. 15. 1991;30(2):190-6. Source: PubMed. [pmid: 1912109].
452 Bridge JA, Iyengar S, Salary CB, et al. Clinical response and risk for reported suicidal ideation and suicide attempts in pediatric antidepressant treatment: A meta-analysis of randomized controlled trials. Journal of the American Medical Association. 2007;297(15). Source: Scopus.
453 Brody AL, Saxena S, Stoessel P, et al. Regional brain metabolic changes in patients with major depression treated with either paroxetine or interpersonal therapy: preliminary findings. Arch Gen Psychiatry. Jul. 2001;58(7):631-40. Source: PubMed. [pmid: 11448368].
454 Brogden RN, Heel RC, Speight TM, et al. Trazodone: a review of its pharmacological properties and therapeutic use in depression and anxiety. Drugs. Jun. 1981;21(6):401-29. Source: PubMed. [pmid: 7018873].
455 Brooks D, Prothero W, Bouras N, et al. Trazodone--a comparison of single night-time and divided daily dosage regimens. Psychopharmacology (Berl). 1984;84(1):1-4. Source: PubMed. [pmid: 6436874].
456 Brouwer JP, Appelhof BC, Peeters RP, et al. Thyrotropin, but not a polymorphism in type II deiodinase, predicts response to paroxetine in major depression. Eur J Endocrinol. Jun. 2006;154(6):819-25. Source: PubMed. [pmid: 16728541].
457 Brouwer JP, Appelhof BC, van Rossum EF, et al. Prediction of treatment response by HPA-axis and glucocorticoid receptor polymorphisms in major depression. Psychoneuroendocrinology. Nov. 2006;31(10):1154-63. Source: PubMed. [pmid: 17034955].
458 Brown C, Battista DR, Sereika SM, et al. How can you improve antidepressant adherence?. Journal of Family Practice. 2007;56(5):356-63. Source: EMBASE. [pmid: 17475165].
459 Brown EB, McElroy SL, Keck PE Jr., et al. A 7-week, randomized, double-blind trial of olanzapine/fluoxetine combination versus lamotrigine in the treatment of bipolar I depression. J Clin Psychiatry. Jul. 2006;67(7):1025-33. Source: PubMed. [pmid: 16889444].
460 Brown ES, Gan V, Jeffress J, et al. Antidepressant treatment of caregivers of children with asthma. Psychosomatics. 2008;49(5):420-5. Source: EMBASE. [pmid: 18794511].
461 Brown ES, Murray M, Carmody TJ, et al. The Quick Inventory of Depressive Symptomatology-Self-report: a psychometric evaluation in patients with asthma and major depressive disorder. Ann Allergy Asthma Immunol. May. 2008;100(5):433-8. Source: PubMed. [pmid: 18517074].
462 Brown ES, Vigil L, Khan DA, et al. A randomized trial of citalopram versus placebo in outpatients with asthma and major depressive disorder: a proof of concept study. Biol Psychiatry. Dec. 1. 2005;58(11):865-70. Source: PubMed. [pmid: 15993860].
463 Brown ES, Vornik LA, Khan DA, et al. Bupropion in the treatment of outpatients with asthma and major depressive disorder. Int J Psychiatry Med. 2007;37(1):23-8. Source: PubMed. [pmid: 17645195].
464 Brown GW, Harris TO, Kendrick T, et al. Antidepressants, social adversity and outcome of depression in general practice. Journal of affective disorders. 2010;121(3):239-46. Source: EMBASE. [pmid: 19589602].
465 Brown WA, Arato M, Shrivastava R. Pituitary-adrenocortical hyperfunction and intolerance to fluvoxamine, a selective serotonin uptake inhibitor. Am J Psychiatry. Jan. 1986;143(1):88-90. Source: PubMed. [pmid: 3079969].
466 Brown WA, Dornseif BE, Wernicke JF. Placebo response in depression: a search for predictors. Psychiatry Res. Dec. 1988;26(3):259-64. Source: PubMed. [pmid: 3065807].
467 Brown WA, Harrison W. Are patients who are intolerant to one SSRI intolerant to another?. Psychopharmacol Bull. 1992;28(3):253-6. Source: PubMed. [pmid: 1480728].
468 Brown WA, Harrison W. Are patients who are intolerant to one serotonin selective reuptake inhibitor intolerant to another. J Clin Psychiatry. Jan. 1995;56(1):30-4. Source: PubMed. [pmid: 7836337].
469 Browne G, Steiner M, Roberts J, et al. Sertraline and/or interpersonal psychotherapy for patients with dysthymic disorder in primary care: 6-month comparison with longitudinal 2-year follow-up of effectiveness and costs. J Affect Disord. Apr. 2002;68(2-3):317-30. Source: PubMed. [pmid: 12063159].
470 Browne JL, Rice JL, Evans DL, et al. Triiodothyronine augmentation of the antidepressant effect of the nontricyclic antidepressant trazodone. J Nerv Ment Dis. Sep. 1990;178(9):598-9. Source: PubMed. [pmid: 2394983].
471 Browne M, Horn E, Jones TT. The benefits of clomipramine-fluoxetine combination in obsessive compulsive disorder. Can J Psychiatry. May. 1993;38(4):242-3. Source: PubMed. [pmid: 8518974].
472 Bruce ML, Ten Have TR, Reynolds CF 3rd, et al. Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. Jama. Mar. 3. 2004;291(9):1081-91. Source: PubMed. [pmid: 14996777].
473 Bruder GE, Sedoruk JP, Stewart JW, et al. Electroencephalographic alpha measures predict therapeutic response to a selective serotonin reuptake inhibitor antidepressant: pre- and post-treatment findings. Biol Psychiatry. Jun. 15. 2008;63(12):1171-7. Source: PubMed. [pmid: 18061147].
474 Bruijn JA, Moleman P, Mulder PG, et al. Comparison of 2 treatment strategies for depressed inpatients: imipramine and lithium addition or mirtazapine and lithium addition. J Clin Psychiatry. Dec. 1998;59(12):657-63. Source: PubMed. [pmid: 9921699].
475 Bruijn JA, Moleman P, Mulder PG, et al. Depressed in-patients respond differently to imipramine and mirtazapine. Pharmacopsychiatry. May. 1999;32(3):87-92. Source: PubMed. [pmid: 10463374].
476 Bruijn JA, Moleman P, Mulder PG, et al. Treatment of mood-congruent psychotic depression with imipramine. J Affect Disord. Oct. 2001;66(2-3):165-74. Source: PubMed. [pmid: 11578669].
477 Bruijn JA, Moleman P, Mulder PG, et al. A double-blind, fixed blood-level study comparing mirtazapine with imipramine in depressed in-patients. Psychopharmacology (Berl). Oct. 1996;127(3):231-7. Source: PubMed. [pmid: 8912401].
478 Brunnauer A, Laux G, David I, et al. The impact of reboxetine and mirtazapine on driving simulator performance and psychomotor function in depressed patients. J Clin Psychiatry. Dec. 2008;69(12):1880-6. Source: PubMed. [pmid: 19203476].
479 Brunswick DJ, Amsterdam JD, Fawcett J, et al. Fluoxetine and norfluoxetine plasma concentrations during relapse-prevention treatment. J Affect Disord. Apr. 2002;68(2-3):243-9. Source: PubMed. [pmid: 12063152].
480 Brunton S, Wang F, Edwards SB, et al. Profile of adverse events with duloxetine treatment: A pooled analysis of placebo-controlled studies. Drug Safety. 2010;33(5):393-407. Source: EMBASE. [pmid: 20397739].
481 Bryan C, Songer T, Brooks MM, et al. The impact of diabetes on depression treatment outcomes. General Hospital Psychiatry. 2010;32(1):33-41. Source: EMBASE. [pmid: 20114126].
482 Bryan C, Songer T, Brooks MM, et al. Do Depressed Patients With Diabetes Experience More Side Effects When Treated With CitalopramThan Their Counterparts Without Diabetes? A STAR*D Study. Prim Care Companion J Clin Psychiatry. 2009;11(5):186-96. Source: PubMed. [pmid: 19956455].
483 Bryan CJ, Songer TJ, Brooks MM, et al. A comparison of baseline sociodemographic and clinical characteristics between major depressive disorder patients with and without diabetes: a STAR*D report. J Affect Disord. May. 2008;108(1-2):113-20. Source: PubMed. [pmid: 18037497].
484 Bryant SG, Hokanson JA, Brown CS. A drug utilization review of prescribing patterns for trazodone versus amitriptyline. J Clin Psychiatry. Sep. 1990;51(Suppl):27-9. Source: PubMed. [pmid: 2211562].
485 Brymer C, Winograd CH. Fluoxetine in elderly patients: is there cause for concern. J Am Geriatr Soc. Sep. 1992;40(9):902-5. Source: PubMed. [pmid: 1512386].
486 Buchholtz-Hansen PE, Wang AG, Kragh-Sorensen P. Mortality in major affective disorder: relationship to subtype of depression. The Danish University Antidepressant Group. Acta Psychiatr Scand. May. 1993;87(5):329-35. Source: PubMed. [pmid: 8517172].
487 Buchsbaum MS, Wu J, Siegel BV, et al. Effect of sertraline on regional metabolic rate in patients with affective disorder. Biol Psychiatry. Jan. 1. 1997;41(1):15-22. Source: PubMed. [pmid: 8988791].
488 Buckley NA, McManus PR. Fatal toxicity of serotoninergic and other antidepressant drugs: analysis of United Kingdom mortality data. Bmj. Dec. 7. 2002;325(7376):1332-3. Source: PubMed. [pmid: 12468481].
489 Bukh JD, Jørgensen MB, Dam H, et al. Comparison of the antidepressant effects of venlafaxine and dosulepin in a naturalistic setting. Nordic Journal of Psychiatry. Sep. 2009. 2009;63(4):347-51. Source: PsycINFO. [pmid: 19347769].
490 Bump GM, Mulsant BH, Pollock BG, et al. Paroxetine versus nortriptyline in the continuation and maintenance treatment of depression in the elderly. Depress Anxiety. 2001;13(1):38-44. Source: PubMed. [pmid: 11233459].
491 Bump GM, Reynolds CF 3rd, Smith G, et al. Accelerating response in geriatric depression: a pilot study combining sleep deprivation and paroxetine. Depress Anxiety. 1997;6(3):113-8. Source: PubMed. [pmid: 9442985].
492 Buni TM. Treatment of dysthymia. J Fam Pract. Jun. 1997;44(6):528-9. Source: PubMed. [pmid: 9191617].
493 Burke D, Fanker S. Fluoxetine and the syndrome of inappropriate secretion of antidiuretic hormone (SIADH). Aust N Z J Psychiatry. Apr. 1996;30(2):295-8. Source: PubMed. [pmid: 8811276].
494 Burke D, Franker S. Fluoxetine-induced SIADH: most likely in the elderly?. Aust N Z J Psychiatry. Apr. 1996;30(2):299-301. Source: PubMed. [pmid: 8811278].
495 Burke WJ, Dewan V, Wengel SP, et al. The use of selective serotonin reuptake inhibitors for depression and psychosis complicating dementia. Int J Geriatr Psychiatry. May. 1997;12(5):519-25. Source: PubMed. [pmid: 9193959].
496 Burke WJ, Gergel I, Bose A. Fixed-dose trial of the single isomer SSRI escitalopram in depressed outpatients. J Clin Psychiatry. Apr. 2002;63(4):331-6. Source: PubMed. [pmid: 12000207].
497 Burke WJ, Hendricks SE, McArthur-Campbell D, et al. Fluoxetine and norfluoxetine serum concentrations and clinical response in weekly versus daily dosing. Psychopharmacol Bull. 1996;32(1):27-32. Source: PubMed. [pmid: 8927671].
498 Burke WJ, Hendricks SE, McArthur-Miller D, et al. Weekly dosing of fluoxetine for the continuation phase of treatment of major depression: results of a placebo-controlled, randomized clinical trial. J Clin Psychopharmacol. Aug. 2000;20(4):423-7. Source: PubMed. [pmid: 10917403].
499 Burke WJ, McArthur-Miller DA. Exploring treatment alternatives: weekly dosing of fluoxetine for the continuation phase of major depressive disorder. J Clin Psychiatry. Suppl 22. 2001;62:38-42. Source: PubMed. [pmid: 11599647].
500 Burns RA, Lock T, Edwards DR, et al. Predictors of response to amine-specific antidepressants. J Affect Disord. Dec. 13. 1995;35(3):97-106. Source: PubMed. [pmid: 8749837].
501 Burns RB, Hartman EE. Update: A 75-year-old man with depression. Jama. Mar. 10. 2004;291(10):1260. Source: PubMed. [pmid: 15010449].
502 Burrai C, Bocchetta A, del Zompo M. Mania and fluvoxamine. Am J Psychiatry. Sep. 1991;148(9):1263-4. Source: PubMed. [pmid: 1909099].
503 Burrows AB, Salzman C, Satlin A, et al. A randomized, placebo-controlled trial of paroxetine in nursing home residents with non-major depression. Depress Anxiety. 2002;15(3):102-10. Source: PubMed. [pmid: 12001178].
504 Burrows GD, Kremer CM. Mirtazapine: clinical advantages in the treatment of depression. J Clin Psychopharmacol. Apr. Suppl 1. 1997;17:34S-9S. Source: PubMed. [pmid: 9090576].
505 Burt VK, Wohlreich MM, Mallinckrodt CH, et al. Duloxetine for the treatment of major depressive disorder in women ages 40 to 55 years. Psychosomatics. Jul-Aug. 2005;46(4):345-54. Source: PubMed. [pmid: 16000678].
506 Bush DE, Ziegelstein RC, Patel UV, et al. Post-myocardial infarction depression. Evid Rep Technol Assess (Summ). May. 2005;(123):1-8. Source: PubMed. [pmid: 15989376].
507 Bushell I, Newton W. SSRI or tricyclics for depression. J Fam Pract. Oct. 1996;43(4):345-6. Source: PubMed. [pmid: 8874367].
508 Butters MA, Becker JT, Nebes RD, et al. Changes in cognitive functioning following treatment of late-life depression. Am J Psychiatry. Dec. 2000;157(12):1949-54. Source: PubMed. [pmid: 11097959].
509 Butters MA, Bhalla RK, Mulsant BH, et al. Executive functioning, illness course, and relapse/recurrence in continuation and maintenance treatment of late-life depression: is there a relationship. Am J Geriatr Psychiatry. Jul-Aug. 2004;12(4):387-94. Source: PubMed. [pmid: 15249276].
510 Buysse DJ, Kupfer DJ, Cherry C, et al. Effects of prior fluoxetine treatment on EEG sleep in women with recurrent depression. Neuropsychopharmacology. Aug. 1999;21(2):258-67. Source: PubMed. [pmid: 10432474].
511 Byerley WF, Reimherr FW, Wood DR, et al. Fluoxetine, a selective serotonin uptake inhibitor, for the treatment of outpatients with major depression. J Clin Psychopharmacol. Apr. 1988;8(2):112-5. Source: PubMed. [pmid: 3286684].
512 Byerly MJ, Christensen RC, Evans OL. Delirium associated with a combination of sertraline, haloperidol, and benztropine. Am J Psychiatry. Jul. 1996;153(7):965-6. Source: PubMed. [pmid: 8659626].
513 Byrne MM. Meta-analysis of early phase II studies with paroxetine in hospitalized depressed patients. Acta Psychiatr Scand Suppl. 1989;350:138-9. Source: PubMed. [pmid: 2530768].
514 Byrne S, Rothschild AJ. Psychiatrists' responses to failure of maintenance therapy with antidepressants. Psychiatr Serv. Jun. 1997;48(6):835-7. Source: PubMed. [pmid: 9175196].
515 Caballero J, Nahata MC. Use of selective serotonin-reuptake inhibitors in the treatment of depression in adults with HIV. Ann Pharmacother. Jan. 2005;39(1):141-5. Source: PubMed. [pmid: 15562140].
516 Caetano D, Caetano SC. Olanzapine in the treatment of resistant depression. Aust N Z J Psychiatry. Jan-Feb. 2005;39(1-2):108-9. Source: PubMed. [pmid: 15660713].
517 Cahill K, Stead Lindsay F, Lancaster T. Nicotine receptor partial agonists for smoking cessation. Cochrane Database of Systematic Reviews. 2008;(3). Source: The Cochrane Library.
518 Cain JW. Poor response to fluoxetine: underlying depression, serotonergic overstimulation, or a “therapeutic window”. J Clin Psychiatry. Aug. 1992;53(8):272-7. Source: PubMed. [pmid: 1500403].
519 Calabrese JR, Guelfi JD, Perdrizet-Chevallier C. Agomelatine adjunctive therapy for acute bipolar depression: Preliminary open data. Bipolar Disorders. Sep. 2007. 2007;9(6):628-35. Source: PsycINFO. [pmid: 17845278].
520 Calabrese JR, Londborg PD, Shelton MD, et al. Citalopram treatment of fluoxetine-intolerant depressed patients. J Clin Psychiatry. May. 2003;64(5):562-7. Source: PubMed. [pmid: 12755660].
521 Caley CF, Friedman JH. Does fluoxetine exacerbate Parkinson's disease. J Clin Psychiatry. Aug. 1992;53(8):278-82. Source: PubMed. [pmid: 1500404].
522 Caley CF, Weber SS. Paroxetine: a selective serotonin reuptake inhibiting antidepressant. Ann Pharmacother. Oct. 1993;27(10):1212-22. Source: PubMed. [pmid: 8251692].
523 Caliyurt O, Guducu F. Partial sleep deprivation therapy combined with sertraline induces more rapid improvements in quality of life items in major depressive disorder. J Affect Disord. Sep. 2005;88(1):75-8. Source: PubMed. [pmid: 15967511].
524 Caliyurt O, Guducu F. Partial sleep deprivation therapy combined with sertraline affects subjective sleep quality in major depressive disorder. Sleep Med. Nov. 2005;6(6):555-9. Source: PubMed. [pmid: 15994121].
525 Camacho F, Kong MC, Sheehan DV, et al. Expenditures associated with dose titration at initiation of therapy in patients with major depressive disorder: A retrospective analysis of a large managed care claims database. P and T. 2010;35(8):452-60+68. Source: EMBASE. [pmid: 20844695].
526 Camarasa X, Lopez-Martinez E, Duboc A, et al. Escitalopram/reboxetine combination in depressed patients with substance use disorder. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Jan. 2005. 2005;29(1):165-8. Source: PsycINFO. [pmid: 15610962].
527 Camprubi ME, Puri BK. The treatment of refractory depression using paroxetine with lithium augmentation. Prog Neuropsychopharmacol Biol Psychiatry. May. 1995;19(3):515-7. Source: PubMed. [pmid: 7624502].
528 Candrian M, Farabaugh A, Pizzagalli DA, et al. Perceived stress and cognitive vulnerability mediate the effects of personality disorder comorbidity on treatment outcome in major depressive disorder: a path analysis study. J Nerv Ment Dis. Sep. 2007;195(9):729-37. Source: PubMed. [pmid: 17984772].
529 Candrian M, Schwartz F, Farabaugh A, et al. Personality disorders and perceived stress in major depressive disorder. Psychiatry Res. Aug. 15. 2008;160(2):184-91. Source: PubMed. [pmid: 18573540].
530 Cankurtaran ES, Ozalp E, Soygur H, et al. Mirtazapine improves sleep and lowers anxiety and depression in cancer patients: superiority over imipramine. Support Care Cancer. Nov. 2008;16(11):1291-8. Source: PubMed. [pmid: 18299900].
531 Cantrell CR, Eaddy MT, Shah MB, et al. Methods for evaluating patient adherence to antidepressant therapy: a real-world comparison of adherence and economic outcomes. Med Care. Apr. 2006;44(4):300-3. Source: PubMed. [pmid: 16565629].
532 Cardoso EF, Fregni F, Martins Maia F, et al. rTMS treatment for depression in Parkinson's disease increases BOLD responses in the left prefrontal cortex. Int J Neuropsychopharmacol. Mar. 2008;11(2):173-83. Source: PubMed. [pmid: 17708780].
533 Carey PD, Warwick J, Niehaus DJ, et al. Single photon emission computed tomography (SPECT) of anxiety disorders before and after treatment with citalopram. BMC Psychiatry. Oct. 14. 2004;4(1):30. Source: PubMed. [pmid: 15482603].
534 Carney CE, Segal ZV, Edinger JD, et al. A comparison of rates of residual insomnia symptoms following pharmacotherapy or cognitive-behavioral therapy for major depressive disorder. Journal of Clinical Psychiatry. 2007;68(2):254-60. Source: EMBASE. [pmid: 17335324].
535 Carney PA, Healy D, Leonard BE. A double-blind study to compare trazodone with amitriptyline in depressed patients. Psychopathology. Suppl 2. 1984;17:37-8. Source: PubMed. [pmid: 6371877].
536 Carney RM, Blumenthal JA, Freedland KE, et al. Depression and late mortality after myocardial infarction in the Enhancing Recovery in Coronary Heart Disease (ENRICHD) study. Psychosom Med. Jul-Aug. 2004;66(4):466-74. Source: PubMed. [pmid: 15272090].
537 Carney RM, Freedland KE, Rubin EH, et al. Omega-3 augmentation of sertraline in treatment of depression in patients with coronary heart disease: a randomized controlled trial. Jama. 2009;302(15):1651-7. Source: PubMed. [pmid: 19843899].
538 Carney RM, Freedland KE, Stein PK, et al. Effect of omega-3 fatty acids on heart rate variability in depressed patients with coronary heart disease. Psychosom Med. Oct. 2010;72(8):748-54. Source: PubMed. [pmid: 20716712].
539 Carpenter LL, Jocic Z, Hall JM, et al. Mirtazapine augmentation in the treatment of refractory depression. J Clin Psychiatry. Jan. 1999;60(1):45-9. Source: PubMed. [pmid: 10074878].
540 Carpenter LL, Yasmin S, Price LH. A double-blind, placebo-controlled study of antidepressant augmentation with mirtazapine. Biol Psychiatry. Jan. 15. 2002;51(2):183-8. Source: PubMed. [pmid: 11822997].
541 Carreira K, Miller MD, Frank E, et al. A controlled evaluation of monthly maintenance interpersonal psychotherapy in late-life depression with varying levels of cognitive function. Int J Geriatr Psychiatry. Nov. 2008;23(11):1110-3. Source: PubMed. [pmid: 18457338].
542 Carroll BJ. Sertraline and the Cheshire cat in geriatric depression. Am J Psychiatry. Jun. 2004;161(6):1145-6. Source: PubMed. [pmid: 15169734].
543 Carroll BJ. Sertraline and the Cheshire cat in geriatric depression (letter and reply). Am J Psychiatry. Apr. 2004;161(4):759. author reply -61. Source: PubMed. [pmid: 15056533].
544 Carroll BJ. Citalopram and the Curate's egg in geriatric depression. Am J Psychiatry. Sep. 2005;162(9):1762. author reply -3. Source: PubMed. [pmid: 16135653].
545 Carvalho LA, Gorenstein C, Moreno R, et al. Effect of antidepressants on melatonin metabolite in depressed patients. J Psychopharmacol. May. 2009;23(3):315-21. Source: PubMed. [pmid: 18562432].
546 Casamassima F, Huang J, Fava M, et al. Phenotypic effects of a bipolar liability gene among individuals with major depressive disorder. American Journal of Medical Genetics, Part B: Neuropsychiatric Genetics. 2010;153(1):303-9. Source: EMBASE.
547 Casciano J, Doyle J, Arikian S, et al. The health economic impact of antidepressant usage from a payer's perspective: a multinational study. Int J Clin Pract. Jun. 2001;55(5):292-9. Source: PubMed. [pmid: 11452675].
548 Case K, Hurwitz TD, Kim SW, et al. A case of extreme paradoxical insomnia responding selectively to electroconvulsive therapy. J Clin Sleep Med. Feb. 15. 2008;4(1):62-3. Source: PubMed. [pmid: 18350965].
549 Casey DE. Striking a balance between safety and efficacy: experience with the SSRI sertraline. Int Clin Psychopharmacol. Jun. Suppl 3. 1994;9:5-12. Source: PubMed. [pmid: 7963450].
550 Cassano GB, Conti L, Massimetti G, et al. Use of a standardized documentation system (BLIPS/BDP) in the conduct of a multicenter international trial comparing fluvoxamine, imipramine, and placebo. Psychopharmacol Bull. 1986;22(1):52-8. Source: PubMed. [pmid: 3088668].
551 Cassano GB, Jori MC. Efficacy and safety of amisulpride 50 mg versus paroxetine 20 mg in major depression: a randomized, double-blind, parallel group study. Int Clin Psychopharmacol. Jan. 2002;17(1):27-32. Source: PubMed. [pmid: 11800503].
552 Cassano GB, Puca F, Scapicchio PL, et al. Paroxetine and fluoxetine effects on mood and cognitive functions in depressed nondemented elderly patients. J Clin Psychiatry. May. 2002;63(5):396-402. Source: PubMed. [pmid: 12019663].
553 Cassano P, Soares CN, Cohen LS, et al. Sex- and age-related differences in major depressive disorder with comorbid anxiety treated with fluoxetine. Arch Women Ment Health. Jul. 2004;7(3):167-71. Source: PubMed.
554 Cassano P, Soares CN, Cusin C, et al. Antidepressant response and well-being in pre-, peri- and postmenopausal women with major depressive disorder treated with fluoxetine. Psychother Psychosom. 2005;74(6):362-5. Source: PubMed. [pmid: 16244512].
555 Castells X, Casas M, Pérez-Mañá C, et al. Efficacy of Psychostimulant Drugs for Cocaine Dependence. Cochrane Database of Systematic Reviews. 2010;(2). Source: The Cochrane Library.
556 Catalano G, Kanfer SN, Catalano MC, et al. The role of sertraline in a patient with recurrent hyponatremia. Gen Hosp Psychiatry. Jul. 1996;18(4):278-83. Source: PubMed. [pmid: 8832263].
557 Catalano MC, Catalano G, Kanfer SN, et al. The effect of sertraline on routine blood chemistry values. Clin Neuropharmacol. Sep-Oct. 2000;23(5):267-70. Source: PubMed. [pmid: 11154094].
558 Centorrino F, Cincotta SL, Talamo A, et al. Hospital use of antipsychotic drugs: polytherapy. Comprehensive Psychiatry. 2008;49(1):65-9. Source: EMBASE. [pmid: 18063043].
559 Cervera-Enguix S, Baca-Baldomero E, Garcia-Calvo C, et al. Depression in primary care: effectiveness of venlafaxine extended-release in elderly patients; Observational study. Arch Gerontol Geriatr. May-Jun. 2004;38(3):271-80. Source: PubMed. [pmid: 15066313].
560 Ceschin L, Giannunzio V, Favaro A, et al. Pica in an eating disordered woman with multiple sclerosis: Impulse dyscontrol, compulsive symptom or self-medication attempt?. Eating and Weight Disorders. 2010;15(1-2):e116-e8. Source: EMBASE. [pmid: 20571315].
561 Chan AN, Gunja N, Ryan CJ. A Comparison of Venlafaxine and SSRIs in Deliberate Self-poisoning. Journal of Medical Toxicology. 2010;6(2):116-21. Source: EMBASE. [pmid: 20237971].
562 Chandler GM, Iosifescu DV, Pollack MH, et al. Validation of the massachusetts general hospital Antidepressant Treatment History Questionnaire (ATRQ). CNS Neuroscience and Therapeutics. 2010;16(5):322-5. Source: EMBASE. [pmid: 19769599].
563 Chang CC, Shiah IS, Chang HA, et al. Does domperidone potentiate mirtazapine-associated restless legs syndrome. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 2006;30(2):316-8. Source: PubMed. [pmid: 16309808].
564 Chang TT, Leng CH, Wu JY, et al. Lower side effects of milnacipran than paroxetine in the treatment of major depression disorder among Han Chinese in Taiwan. Chin J Physiol. 2008;51(6):387-93. Source: PubMed. [pmid: 19280883].
565 Chapman A, Morgan LC, Gartlehner G. Semi-automating the manual literature search for systematic reviews increases efficiency. Health Information & Libraries Journal. 2009;27(1):22-7. Source: Handsearch. [pmid: 20402801].
566 Chaudhari K, Khanzode S, Dakhale G, et al. Clinical correlation of alteration of endogenous antioxidant-uric acid level in major depressive disorder. Indian Journal of Clinical Biochemistry. 2010;25(1):77-81. Source: EMBASE.
567 Chaudron LH, Schoenecker CJ. Bupropion and breastfeeding: a case of a possible infant seizure. J Clin Psychiatry. Jun. 2004;65(6):881-2. Source: PubMed. [pmid: 15291673].
568 Chelben J, Strous RD, Lustig M, et al. Remission of SSRI-induced akathisia after switch to nefazodone. J Clin Psychiatry. Jul. 2001;62(7):570-1. Source: PubMed. [pmid: 11488371].
569 Chen CY, Tzeng NS, Chen YC. Maintenance therapy of celecoxib for major depression with mimicking neuropsychological dysfunction. General Hospital Psychiatry. 2010;32(6):647.e7-.e9. Source: EMBASE. [pmid: 21112464].
570 Chen F, Larsen MB, Sánchez C, et al. The S-enantiomer of R,S-citalopram, increases inhibitor binding to the human serotonin transporter by an allosteric mechanism. Comparison with other serotonin transporter inhibitors. European Neuropsychopharmacology. 2005;15(2):193-8. Source: Scopus. [pmid: 15695064].
571 Chen PY, Lin PY, Tien SC, et al. Duloxetine-related tardive dystonia and tardive dyskinesia: A case report. General Hospital Psychiatry. 2010;32(6):646.e9-.e11. Source: EMBASE. [pmid: 21112461].
572 Chen R, Lopes J. Hyperglycaemia secondary to mirtazapine therapy in a 37-year-old man. Australian and New Zealand Journal of Psychiatry. Nov. 2008. 2008;42(11):990-1. Source: PsycINFO. [pmid: 18946939].
573 Chen SY, Hansen RA, Farley JF, et al. Follow-up visits by provider specialty for patients with major depressive disorder initiating antidepressant treatment. Psychiatric Services. 2010;61(1):81-5. Source: EMBASE. [pmid: 20044424].
574 Chen Y, Guo JJ, Li H, et al. Risk of cerebrovascular events associated with antidepressant use in patients with depression: A population-based, nested case-control study. Annals of Pharmacotherapy. 2008;42(2):177-84. Source: Handsearch. [pmid: 18212255].
575 Chen YC, Lin WW, Chen YJ, et al. Antidepressant effects on insulin sensitivity and proinflammatory cytokines in the depressed males. Mediators of Inflammation. 2010:2010. Source: EMBASE.
576 Chen YC, Shen YC, Hung YJ, et al. Comparisons of glucose-insulin homeostasis following maprotiline and fluoxetine treatment in depressed males. J Affect Disord. Nov. 2007;103(1-3):257-61. Source: PubMed. [pmid: 17320192].
577 Chengappa KN, Kambhampati RK, Perkins K, et al. Bupropion sustained release as a smoking cessation treatment in remitted depressed patients maintained on treatment with selective serotonin reuptake inhibitor antidepressants. J Clin Psychiatry. Jul. 2001;62(7):503-8. Source: PubMed. [pmid: 11488359].
578 Chengappa KNR, Turkin SR, Schlicht PJ, et al. A Pilot, 15-month, randomised effectiveness trial of Risperidone long-acting injection (RLAI) versus oral atypical antipsychotic agents (AAP) in persons with bipolar disorder. Acta Neuropsychiatrica. 2010;22(2):68-80. Source: EMBASE.
579 Cheung A, Kusumakar V, Kutcher S, et al. Maintenance study for adolescent depression. J Child Adolesc Psychopharmacol. Aug. 2008;18(4):389-94. Source: PubMed. [pmid: 18759650].
580 Chi MH, Chang HH, Lee SY, et al. Brain derived neurotrophic factor gene polymorphism (Val66Met) and short-term antidepressant response in major depressive disorder. Journal of affective disorders. 2010;126(3):430-5. Source: EMBASE. [pmid: 20674983].
581 Chien AJ, Dunner DL. The Tridimensional Personality Questionnaire in depression: state versus trait issues. J Psychiatr Res. Jan-Feb. 1996;30(1):21-7. Source: PubMed. [pmid: 8736463].
582 Chiesa A, di Nasso E, Mencacci C, et al. Impact of axis I comorbidity interaction on duloxetine outcome in major depression. Clinical Neuropsychiatry. 2010;7(4):156-63. Source: EMBASE.
583 Childs PA, Rodin I, Martin NJ, et al. Effect of fluoxetine on melatonin in patients with seasonal affective disorder and matched controls. Br J Psychiatry. Feb. 1995;166(2):196-8. Source: PubMed. [pmid: 7728363].
584 Chisolm MS, Brigham EP, Tuten M, et al. The relationship between antidepressant use and smoking cessation in pregnant women in treatment for substance abuse. American Journal of Drug and Alcohol Abuse. 2010;36(1):46-51. Source: EMBASE. [pmid: 20141396].
585 Choi KH, Kyong YY, Lee KU. Two cases of severe bupropion overdose. Clinical Psychopharmacology and Neuroscience. 2010;8(1):49-52. Source: PsycINFO.
586 Chokka P, Legault M. Escitalopram in the treatment of major depressive disorder in primary-care settings: an open-label trial. Depress Anxiety. 2008;25(12):E173-81. Source: PubMed. [pmid: 19006260].
587 Chollet CA, Andreatini R. Effect of bupropion on sexual dysfunction induced by fluoxetine: a case report of hypersexuality. J Clin Psychiatry. Oct. 2003;64(10):1268-9. Source: PubMed. [pmid: 14658981].
588 Chouinard G. Bupropion and amitriptyline in the treatment of depressed patients. J Clin Psychiatry. May. 1983;44(5 Pt 2):121-9. Source: PubMed. [pmid: 6406440].
589 Chouinard G. A double-blind controlled clinical trial of fluoxetine and amitriptyline in the treatment of outpatients with major depressive disorder. J Clin Psychiatry. Mar. 1985;46(3 Pt 2):32-7. Source: PubMed. [pmid: 3882679].
590 Chouinard G, Saxena B, Belanger MC, et al. A Canadian multicenter, double-blind study of paroxetine and fluoxetine in major depressive disorder. J Affect Disord. Jul. 1999;54(1-2):39-48. Source: PubMed. [pmid: 10403145].
591 Chrapko W, Jurasz P, Radomski MW, et al. Alteration of decreased plasma NO metabolites and platelet NO synthase activity by paroxetine in depressed patients. Neuropsychopharmacology. Jun. 2006;31(6):1286-93. Source: PubMed. [pmid: 16319917].
592 Christensen P, Thomsen HY, Pedersen OL, et al. Orthostatic side effects of clomipramine and citalopram during treatment for depression. Psychopharmacology (Berl). 1985;86(4):383-5. Source: PubMed. [pmid: 3929308].
593 Christensen RC. Adverse interaction of paroxetine and cyproheptadine. J Clin Psychiatry. Sep. 1995;56(9):433-4. Source: PubMed. [pmid: 7665546].
594 Christensen RC, Byerly MJ. Mandibular dystonia associated with the combination of sertraline and metoclopramide. J Clin Psychiatry. Dec. 1996;57(12):596. Source: PubMed. [pmid: 9010129].
595 Christenson GA, MacKenzie TB, Mitchell JE. Adult men and women with trichotillomania. A comparison of male and female characteristics. Psychosomatics. Mar-Apr. 1994;35(2):142-9. Source: PubMed. [pmid: 8171173].
596 Christiansen PE, Behnke K, Black CH, et al. Paroxetine and amitriptyline in the treatment of depression in general practice. Acta Psychiatr Scand. Mar. 1996;93(3):158-63. Source: PubMed. [pmid: 8739658].
597 Christodoulou C, Papadopoulou A, Rizos E, et al. Extrapyramidal side effects and suicidal ideation under fluoxetine treatment: A case report. Annals of General Psychiatry. 2010;9. Source: PsycINFO.
598 Chuang YF, Chiu YL, Hwang TJ, et al. Delirium and multiple electrolyte abnormalities associated with high dose paroxetine exposure. Psychiatry Clin Neurosci. Oct. 2006;60(5):642-3. Source: PubMed. [pmid: 16958954].
599 Cía AH, Brizuela JA, Cascardo E, et al. Clonazepam and milnacipran in the treatment of patients with panic disorder and comorbid major depression. Primary Care & Community Psychiatry. 2006. 2006;11(2):51-6. Source: PsycINFO.
600 Cipriani A, Barbui C, Brambilla P, et al. Are all antidepressants really the same? The case of fluoxetine: a systematic review. J Clin Psychiatry. 2006;67(6):850-64. Source: Handsearch. [pmid: 16848644].
601 Cipriani A, Barbui C, Geddes JR. Suicide, depression, and antidepressants. British Medical Journal. 2005;330(7488):373-4. Source: Scopus. [pmid: 15718515].
602 Cipriani A, Boso M, Barbui C. Clozapine combined with different antipsychotic drugs for treatment resistant schizophrenia. Cochrane Database of Systematic Reviews. 2009;(3). Source: The Cochrane Library.
603 Cipriani A, Brambilla P, Furukawa Toshi A, et al. Fluoxetine versus other types of pharmacotherapy for depression. Cochrane Database of Systematic Reviews. 2005;(4). Source: The Cochrane Library.
604 Cipriani A, Furukawa TA, Geddes JR, et al. Does randomized evidence support sertraline as first-line antidepressant for adults with acute major depression? A systematic review and meta-analysis. J Clin Psychiatry. 2008;69(11):1732-42. Source: PubMed. [pmid: 19026250].
605 Cipriani A, Furukawa TA, Salanti G, et al. Comparative efficacy and acceptability of 12 new-generation antidepressants: a multiple-treatments meta-analysis. Lancet. 2009;373(9665):746-58. Source: PubMed. [pmid: 19185342].
606 Cipriani A, La Ferla T, Furukawa TA, et al. Sertraline versus other antidepressive agents for depression. Cochrane Database Syst Rev. 2010;(4):CD006117. Source: PubMed.
607 Cipriani A, Pontarollo F, Signoretti A, et al. Escitalopram versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2007;(2). Source: Scopus.
608 Cipriani A, Rendell Jennifer M, Geddes J. Haloperidol alone or in combination for acute mania. Cochrane Database of Systematic Reviews. 2006;(3). Source: The Cochrane Library.
609 Cipriani A, Santilli C, Furukawa Toshi A, et al. Escitalopram versus other antidepressive agents for depression. Cochrane Database of Systematic Reviews. 2009;(2). Source: The Cochrane Library.
610 Ciraulo DA, Knapp C, Rotrosen J, et al. Nefazodone treatment of cocaine dependence with comorbid depressive symptoms. Addiction. Mar. Suppl 1. 2005;100:23-31. Source: PubMed. [pmid: 15730347].
611 Claassen CA, Trivedi MH, Rush AJ, et al. Clinical differences among depressed patients with and without a history of suicide attempts: findings from the STAR*D trial. J Affect Disord. Jan. 2007;97(1-3):77-84. Source: PubMed. [pmid: 16824617].
612 Claghorn J. A double-blind comparison of paroxetine and placebo in the treatment of depressed outpatients. Int Clin Psychopharmacol. Jun. Suppl 4. 1992;6:25-30. Source: PubMed. [pmid: 1431007].
613 Claghorn JL. The safety and efficacy of paroxetine compared with placebo in a double-blind trial of depressed outpatients. J Clin Psychiatry. Feb. 1992;53(Suppl):33-5. Source: PubMed. [pmid: 1531821].
614 Claghorn JL, Earl CQ, Walczak DD, et al. Fluvoxamine maleate in the treatment of depression: a single-center, double-blind, placebo-controlled comparison with imipramine in outpatients. J Clin Psychopharmacol. Apr. 1996;16(2):113-20. Source: PubMed. [pmid: 8690826].
615 Claghorn JL, Feighner JP. A double-blind comparison of paroxetine with imipramine in the long-term treatment of depression. J Clin Psychopharmacol. Dec. 1993;13(6 Suppl 2):23S-7S. Source: PubMed. [pmid: 8106652].
616 Claghorn JL, Johnstone EE, Studebaker SL, et al. The effectiveness of 6-azamianserin (Org 3770) in depressed outpatients. Psychopharmacol Bull. 1987;23(1):160-1. Source: PubMed. [pmid: 3602313].
617 Claghorn JL, Kiev A, Rickels K, et al. Paroxetine versus placebo: a double-blind comparison in depressed patients. J Clin Psychiatry. Dec. 1992;53(12):434-8. Source: PubMed. [pmid: 1487471].
618 Claghorn JL, Lesem MD. A double-blind placebo-controlled study of Org 3770 in depressed outpatients. J Affect Disord. Jun. 8. 1995;34(3):165-71. Source: PubMed. [pmid: 7560544].
619 Clark DB, Andrus MR, Byrd DC. Drug interactions between linezolid and selective serotonin reuptake inhibitors: case report involving sertraline and review of the literature. Pharmacotherapy. Feb. 2006;26(2):269-76. Source: PubMed. [pmid: 16466332].
620 Claxton A, de Klerk E, Parry M, et al. Patient compliance to a new enteric-coated weekly formulation of fluoxetine during continuation treatment of major depressive disorder. J Clin Psychiatry. Dec. 2000;61(12):928-32. Source: PubMed. [pmid: 11206598].
621 Clayton A, Kornstein S, Prakash A, et al. Changes in sexual functioning associated with duloxetine, escitalopram, and placebo in the treatment of patients with major depressive disorder. J Sex Med. Jul. 2007;4(4 Pt 1):917-29. Source: PubMed. [pmid: 17627739].
622 Clayton AH, Croft HA, Horrigan JP, et al. Bupropion extended release compared with escitalopram: effects on sexual functioning and antidepressant efficacy in 2 randomized, double-blind, placebo-controlled studies. J Clin Psychiatry. May. 2006;67(5):736-46. Source: PubMed. [pmid: 16841623].
623 Clayton AH, Kornstein SG, Rosas G, et al. An integrated analysis of the safety and tolerability of desvenlafaxine compared with placebo in the treatment of major depressive disorder. CNS Spectr. 2009;14(4):183-95. Source: PubMed. [pmid: 19407730].
624 Clayton AH, McGarvey EL, Abouesh AI, et al. Substitution of an SSRI with bupropion sustained release following SSRI-induced sexual dysfunction. J Clin Psychiatry. Mar. 2001;62(3):185-90. Source: PubMed. [pmid: 11305705].
625 Clayton AH, Pradko JF, Croft HA, et al. Prevalence of sexual dysfunction among newer antidepressants. J Clin Psychiatry. Apr. 2002;63(4):357-66. Source: PubMed. [pmid: 12000211].
626 Clayton AH, Stewart RS, Fayyad R, et al. Sex differences in clinical presentation and response in panic disorder: pooled data from sertraline treatment studies. Arch Women Ment Health. 2005. Nov. 15. Source: PubMed.
627 Clayton AH, Warnock JK, Kornstein SG, et al. A placebo-controlled trial of bupropion SR as an antidote for selective serotonin reuptake inhibitor-induced sexual dysfunction. J Clin Psychiatry. Jan. 2004;65(1):62-7. Source: PubMed. [pmid: 14744170].
628 Clayton AH, Zajecka J, Ferguson JM, et al. Lack of sexual dysfunction with the selective noradrenaline reuptake inhibitor reboxetine during treatment for major depressive disorder. Int Clin Psychopharmacol. May. 2003;18(3):151-6. Source: PubMed. [pmid: 12702894].
629 Clerc G. Antidepressant efficacy and tolerability of milnacipran, a dual serotonin and noradrenaline reuptake inhibitor: a comparison with fluvoxamine. Int Clin Psychopharmacol. May. 2001;16(3):145-51. Source: PubMed. [pmid: 11354236].
630 Clerc GE, Ruimy P, Verdeau-Palles J. A double-blind comparison of venlafaxine and fluoxetine in patients hospitalized for major depression and melancholia. The Venlafaxine French Inpatient Study Group. Int Clin Psychopharmacol. Sep. 1994;9(3):139-43. Source: PubMed. [pmid: 7814822].
631 Coccaro EF, Siever LJ. Second generation antidepressants: a comparative review. J Clin Pharmacol. May-Jun. 1985;25(4):241-60. Source: PubMed. [pmid: 3891797].
632 Cohen BJ, Mahelsky M, Adler L. More cases of SIADH with fluoxetine. Am J Psychiatry. Jul. 1990;147(7):948-9. Source: PubMed. [pmid: 2356883].
633 Cohen LS, Altshuler LL, Harlow BL, et al. Relapse of major depression during pregnancy in women who maintain or discontinue antidepressant treatment: Commentary. Obstetrical and Gynecological Survey. 2006;61(6):368-70. Source: EMBASE.
634 Cohen LS, Viguera AC, Bouffard SM, et al. Venlafaxine in the treatment of postpartum depression. J Clin Psychiatry. Aug. 2001;62(8):592-6. Source: PubMed. [pmid: 11561929].
635 Cohen RB, Brunoni AR, Boggio PS, et al. Clinical predictors associated with duration of repetitive transcranial magnetic stimulation treatment for remission in bipolar depression: A naturalistic study. Journal of Nervous and Mental Disease. 2010;198(9):679-81. Source: EMBASE. [pmid: 20823731].
636 Cohn CK, Robinson DS, Roberts DL, et al. Responders to antidepressant drug treatment: a study comparing nefazodone, imipramine, and placebo in patients with major depression. J Clin Psychiatry. Suppl 2. 1996;57:15-8. Source: PubMed. [pmid: 8626358].
637 Cohn CK, Shrivastava R, Mendels J, et al. Double-blind, multicenter comparison of sertraline and amitriptyline in elderly depressed patients. J Clin Psychiatry. Dec. Suppl B. 1990;51:28-33. Source: PubMed. [pmid: 2258379].
638 Cohn JB, Crowder JE, Wilcox CS, et al. A placebo- and imipramine-controlled study of paroxetine. Psychopharmacol Bull. 1990;26(2):185-9. Source: PubMed. [pmid: 2146697].
639 Cohn JB, Wilcox C. A comparison of fluoxetine, imipramine, and placebo in patients with major depressive disorder. J Clin Psychiatry. Mar. 1985;46(3 Pt 2):26-31. Source: PubMed. [pmid: 3882677].
640 Cohn JB, Wilcox CS. Paroxetine in major depression: a double-blind trial with imipramine and placebo. J Clin Psychiatry. Feb. 1992;53(Suppl):52-6. Source: PubMed. [pmid: 1531826].
641 Coleman CC, Cunningham LA, Foster VJ, et al. Sexual dysfunction associated with the treatment of depression: a placebo-controlled comparison of bupropion sustained release and sertraline treatment. Ann Clin Psychiatry. Dec. 1999;11(4):205-15. Source: PubMed. [pmid: 10596735].
642 Coleman CC, King BR, Bolden-Watson C, et al. A placebo-controlled comparison of the effects on sexual functioning of bupropion sustained release and fluoxetine. Clin Ther. Jul. 2001;23(7):1040-58. Source: PubMed. [pmid: 11519769].
643 Colla M, Kronenberg G, Deuschle M, et al. Hippocampal volume reduction and HPA-system activity in major depression. J Psychiatr Res. Oct. 2007;41(7):553-60. Source: PubMed. [pmid: 17023001].
644 Colonna L, Andersen HF, Reines EH. A randomized, double-blind, 24-week study of escitalopram (10 mg/day) versus citalopram (20 mg/day) in primary care patients with major depressive disorder. Curr Med Res Opin. Oct. 2005;21(10):1659-68. Source: PubMed. [pmid: 16238906].
645 Como PG, Rubin AJ, O'Brien CF, et al. A controlled trial of fluoxetine in nondepressed patients with Huntington's disease. Mov Disord. May. 1997;12(3):397-401. Source: PubMed. [pmid: 9159735].
646 Conca A, al-Dubai Z, Konig P, et al. Combining nefazodone and midazolam during ECT. Eur Psychiatry. Oct. 1999;14(6):360-2. Source: PubMed. [pmid: 10572373].
647 Conus P, Bondolfi G, Eap CB, et al. Pharmacokinetic fluvoxamine-clomipramine interaction with favorable therapeutic consequences in therapy-resistant depressive patient. Pharmacopsychiatry. May. 1996;29(3):108-10. Source: PubMed. [pmid: 8738315].
648 Coogan PF, Palmer JR, Strom BL, et al. Use of selective serotonin reuptake inhibitors and the risk of breast cancer. Am J Epidemiol. 2005;162(9):835-8. Source: PubMed. [pmid: 16177141].
649 Cook IA, Balasubramani GK, Eng H, et al. Electronic source materials in clinical research: acceptability and validity of symptom self-rating in major depressive disorder. J Psychiatr Res. Nov. 2007;41(9):737-43. Source: PubMed. [pmid: 17275840].
650 Cook IA, Leuchter AF. Prefrontal changes and treatment response prediction in depression. Semin Clin Neuropsychiatry. Apr. 2001;6(2):113-20. Source: PubMed. [pmid: 11296311].
651 Cook IA, Leuchter AF, Morgan M, et al. Early changes in prefrontal activity characterize clinical responders to antidepressants. Neuropsychopharmacology. Jul. 2002;27(1):120-31. Source: PubMed. [pmid: 12062912].
652 Cook IA, Leuchter AF, Witte E, et al. Neurophysiologic predictors of treatment response to fluoxetine in major depression. Psychiatry Res. Mar. 22. 1999;85(3):263-73. Source: PubMed. [pmid: 10333379].
653 Cookson J, Gilaberte I, Desaiah D, et al. Treatment benefits of duloxetine in major depressive disorder as assessed by number needed to treat. Int Clin Psychopharmacol. Sep. 2006;21(5):267-73. Source: PubMed. [pmid: 16877897].
654 Cooper GL. The safety of fluoxetine--an update. Br J Psychiatry Suppl. Sep. 1988;(3):77-86. Source: PubMed. [pmid: 3074869].
655 Cooper-Kazaz R, Apter JT, Cohen R, et al. Combined treatment with sertraline and liothyronine in major depression: a randomized, double-blind, placebo-controlled trial. Arch Gen Psychiatry. Jun. 2007;64(6):679-88. Source: PubMed. [pmid: 17548749].
656 Coplan JD, Gorman JM. Detectable levels of fluoxetine metabolites after discontinuation: an unexpected serotonin syndrome. Am J Psychiatry. May. 1993;150(5):837. Source: PubMed. [pmid: 8480837].
657 Copp JE, Schwiderski UE, Robinson DS. Symptom comorbidity in anxiety and depressive disorders. J Clin Psychopharmacol. Jun. 1990;10(3 Suppl):52S-60S. Source: PubMed. [pmid: 1973940].
658 Coppen A, Bailey J. Enhancement of the antidepressant action of fluoxetine by folic acid: a randomised, placebo controlled trial. J Affect Disord. Nov. 2000;60(2):121-30. Source: PubMed. [pmid: 10967371].
659 Corcoran C, Wong ML, O'Keane V. Bupropion in the management of apathy. J Psychopharmacol. Mar. 2004;18(1):133-5. Source: PubMed. [pmid: 15107198].
660 Cornelius JR, Bukstein OG, Douaihy AB, et al. Double-blind fluoxetine trial in comorbid MDD-CUD youth and young adults. Drug and alcohol dependence. 2010;112(1-2):39-45. Source: EMBASE. [pmid: 20576364].
661 Cornelius JR, Bukstein OG, Salloum IM, et al. Fluoxetine in depressed AUD adolescents: a 1-year follow-up evaluation. J Child Adolesc Psychopharmacol. Spring. 2004;14(1):33-8. Source: PubMed. [pmid: 15142389].
662 Cornelius JR, Bukstein OG, Wood DS, et al. Double-blind placebo-controlled trial of fluoxetine in adolescents with comorbid major depression and an alcohol use disorder. Addictive Behaviors. 2009;34(10):905-9. Source: Handsearch. [pmid: 19321268].
663 Cornelius JR, Chung T, Martin C, et al. Cannabis withdrawal is common among treatment-seeking adolescents with cannabis dependence and major depression, and is associated with rapid relapse to dependence. Addict Behav. Nov. 2008;33(11):1500-5. Source: PubMed. [pmid: 18313860].
664 Cornelius JR, Perkins KA, Salloum IM, et al. Fluoxetine versus placebo to decrease the smoking of depressed alcoholic patients. J Clin Psychopharmacol. Apr. 1999;19(2):183-4. Source: PubMed. [pmid: 10211921].
665 Cornelius JR, Salloum IM, Cornelius MD, et al. Fluoxetine trial in suicidal depressed alcoholics. Psychopharmacol Bull. 1993;29(2):195-9. Source: PubMed. [pmid: 8290665].
666 Cornelius JR, Salloum IM, Ehler JG, et al. Double-blind fluoxetine in depressed alcoholic smokers. Psychopharmacol Bull. 1997;33(1):165-70. Source: PubMed. [pmid: 9133770].
667 Cornelius JR, Salloum IM, Ehler JG, et al. Fluoxetine in depressed alcoholics. A double-blind, placebo-controlled trial. Arch Gen Psychiatry. Aug. 1997;54(8):700-5. Source: PubMed. [pmid: 9283504].
668 Cornelius JR, Salloum IM, Haskett RF, et al. Fluoxetine versus placebo in depressed alcoholics: a 1-year follow-up study. Addict Behav. Mar-Apr. 2000;25(2):307-10. Source: PubMed. [pmid: 10795957].
669 Cornelius JR, Salloum IM, Haskett RF, et al. Fluoxetine versus placebo for the marijuana use of depressed alcoholics. Addict Behav. Jan-Feb. 1999;24(1):111-4. Source: PubMed. [pmid: 10189977].
670 Cornelius JR, Salloum IM, Lynch K, et al. Treating the substance-abusing suicidal patient. Ann N Y Acad Sci. Apr. 2001;932:78-90. discussion 1-3. Source: PubMed. [pmid: 11411192].
671 Cornelius JR, Salloum IM, Thase ME, et al. Fluoxetine versus placebo in depressed alcoholic cocaine abusers. Psychopharmacol Bull. 1998;34(1):117-21. Source: PubMed. [pmid: 9564208].
672 Cornelius JR, Soloff PH, Perel JM, et al. A preliminary trial of fluoxetine in refractory borderline patients. J Clin Psychopharmacol. Apr. 1991;11(2):116-20. Source: PubMed. [pmid: 2056138].
673 Corrigan MH, Denahan AQ, Wright CE, et al. Comparison of pramipexole, fluoxetine, and placebo in patients with major depression. Depress Anxiety. 2000;11(2):58-65. Source: PubMed. [pmid: 10812530].
674 Corruble E, Goldberger C, Spann M. Relationship between TSH levels in the normal range and short-term duloxetine efficacy. J Affect Disord. Jun. 2010;123(1-3):312-6. Source: PubMed. [pmid: 19825504].
675 Corya SA, Andersen SW, Detke HC, et al. Long-term antidepressant efficacy and safety of olanzapine/fluoxetine combination: a 76-week open-label study. J Clin Psychiatry. Nov. 2003;64(11):1349-56. Source: PubMed. [pmid: 14658950].
676 Corya SA, Perlis RH, Keck PE Jr., et al. A 24-week open-label extension study of olanzapine-fluoxetine combination and olanzapine monotherapy in the treatment of bipolar depression. J Clin Psychiatry. May. 2006;67(5):798-806. Source: PubMed. [pmid: 16841630].
677 Corya SA, Williamson D, Sanger TM, et al. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, fluoxetine, and venlafaxine in treatment-resistant depression. Depress Anxiety. 2006;23(6):364-72. Source: PubMed. [pmid: 16710853].
678 Costa e Silva J. Randomized, double-blind comparison of venlafaxine and fluoxetine in outpatients with major depression. J Clin Psychiatry. Jul. 1998;59(7):352-7. Source: PubMed. [pmid: 9714263].
679 Cottraux J, Mollard E, Bouvard M, et al. Exposure therapy, fluvoxamine, or combination treatment in obsessive-compulsive disorder: one-year followup. Psychiatry Res. Oct. 1993;49(1):63-75. Source: PubMed. [pmid: 8140182].
680 Court A, Mulder C, Kerr M, et al. Investigating the effectiveness, safety and tolerability of quetiapine in the treatment of anorexia nervosa in young people: A pilot study. Journal of psychiatric research. 2010;44(15):1027-34. Source: EMBASE. [pmid: 20447652].
681 Covey LS, Glassman AH, Stetner F, et al. A randomized trial of sertraline as a cessation aid for smokers with a history of major depression. Am J Psychiatry. Oct. 2002;159(10):1731-7. Source: PubMed. [pmid: 12359680].
682 Cowan MJ, Freedland KE, Burg MM, et al. Predictors of treatment response for depression and inadequate social support--the ENRICHD randomized clinical trial. Psychother Psychosom. 2008;77(1):27-37. Source: PubMed. [pmid: 18087205].
683 Cowen PJ, Ogilvie AD, Gama J. Efficacy, safety and tolerability of duloxetine 60 mg once daily in major depression. Current Medical Research and Opinion. 2005;21(3):345-55. Source: Scopus. [pmid: 15811202].
684 Cowen PJ, Williamson DJ, McTavish SF. Effect of valine on 5-HT neurotransmission and mood. Adv Exp Med Biol. 1996;398:67-71. Source: PubMed. [pmid: 8906242].
685 Cox LS, Patten CA, Niaura RS, et al. Efficacy of bupropion for relapse prevention in smokers with and without a past history of major depression. J Gen Intern Med. Aug. 2004;19(8):828-34. Source: PubMed. [pmid: 15242467].
686 Cramer JA, Roy A, Burrell A, et al. Medication compliance and persistence: terminology and definitions. Value Health. Jan-Feb. 2008;11(1):44-7. Source: PubMed. [pmid: 18237359].
687 Cravello L, Caltagirone C, Spalletta G. The SNRI venlafaxine improves emotional unawareness in patients with post-stroke depression. Hum Psychopharmacol. Jun. 2009;24(4):331-6. Source: PubMed. [pmid: 19330795].
688 Creed F, Guthrie E, Ratcliffe J, et al. Does psychological treatment help only those patients with severe irritable bowel syndrome who also have a concurrent psychiatric disorder. Aust N Z J Psychiatry. Sep. 2005;39(9):807-15. Source: PubMed. [pmid: 16168039].
689 Crews JR, Potts NL, Schreiber J, et al. Hyponatremia in a patient treated with sertraline. Am J Psychiatry. Oct. 1993;150(10):1564. Source: PubMed. [pmid: 8379571].
690 Crockford DN, White WD. Mirtazapine for Alcohol Dependence: A Case Report. Journal of Clinical Psychiatry. Apr. 2005. 2005;66(4):540. Source: PsycINFO. [pmid: 15816801].
691 Croft H, Houser TL, Jamerson BD, et al. Effect on body weight of bupropion sustained-release in patients with major depression treated for 52 weeks. Clin Ther. Apr. 2002;24(4):662-72. Source: PubMed. [pmid: 12017410].
692 Croft H, Settle E Jr., Houser T, et al. A placebo-controlled comparison of the antidepressant efficacy and effects on sexual functioning of sustained-release bupropion and sertraline. Clin Ther. Apr. 1999;21(4):643-58. Source: PubMed. [pmid: 10363731].
693 Croghan TW, Lair TJ, Engelhart L, et al. Effect of antidepressant therapy on health care utilization and costs in primary care. Psychiatr Serv. Nov. 1997;48(11):1420-6. Source: PubMed. [pmid: 9355169].
694 Croom KF, Perry CM, Plosker GL. Mirtazapine: A review of its use in major depression and other psychiatric disorders. CNS Drugs. 2009;23(5):427-52. Source: Scopus. [pmid: 19453203].
695 Croom KF, Plosker GL. Escitalopram: a pharmacoeconomic review of its use in depression. Pharmacoeconomics. 2003;21(16):1185-209. Source: PubMed. [pmid: 14594439].
696 Crossley NA, Bauer M. Acceleration and augmentation of antidepressants with lithium for depressive disorders: Two meta-analyses of randomized, placebo-controlled trials. Journal of Clinical Psychiatry. Jun. 2007. 2007;68(6):935-40. Source: PsycINFO. [pmid: 17592920].
697 Crowe D, Collins JP, Rosse RB. Thyroid hormone supplementation of fluoxetine treatment. J Clin Psychopharmacol. Apr. 1990;10(2):150-1. Source: PubMed. [pmid: 2341594].
698 Crown WH, Treglia M, Meneades L, et al. Long-term costs of treatment for depression: impact of drug selection and guideline adherence. Value Health. Jul-Aug. 2001;4(4):295-307. Source: PubMed. [pmid: 11705297].
699 Croxtall JD, Scott LJ. Olanzapine/fluoxetine: A review of its use in patients with treatment-resistant major depressive disorder. CNS Drugs. 2010;24(3):245-62. Source: EMBASE. [pmid: 20155998].
700 Culang ME, Sneed JR, Keilp JG, et al. Change in cognitive functioning following acute antidepressant treatment in late-life depression. Am J Geriatr Psychiatry. Oct. 2009;17(10):881-8. Source: PubMed. [pmid: 19916207].
701 Cullum JL, Wojciechowski AE, Pelletier G, et al. Bupropion sustained release treatment reduces fatigue in cancer patients. Can J Psychiatry. Feb. 2004;49(2):139-44. Source: PubMed. [pmid: 15065748].
702 Culpepper L. Generalized anxiety disorder in primary care: emerging issues in management and treatment. J Clin Psychiatry. Suppl 8. 2002;63:35-42. Source: PubMed. [pmid: 12044106].
703 Cunningham LA. Once-daily venlafaxine extended release (XR) and venlafaxine immediate release (IR) in outpatients with major depression. Venlafaxine XR 208 Study Group. Ann Clin Psychiatry. Sep. 1997;9(3):157-64. Source: PubMed. [pmid: 9339881].
704 Cunningham LA, Borison RL, Carman JS, et al. A comparison of venlafaxine, trazodone, and placebo in major depression. J Clin Psychopharmacol. Apr. 1994;14(2):99-106. Source: PubMed. [pmid: 8195464].
705 Curran S. Effect of paroxetine on seizure length during electroconvulsive therapy. Acta Psychiatr Scand. Sep. 1995;92(3):239-40. Source: PubMed. [pmid: 7484206].
706 Currier MB, Molina G, Kato M. A prospective trial of sustained-release bupropion for depression in HIV-seropositive and AIDS patients. Psychosomatics. Mar-Apr. 2003;44(2):120-5. Source: PubMed. [pmid: 12618534].
707 Currier MB, Molina G, Kato M. Citalopram treatment of major depressive disorder in Hispanic HIV and AIDS patients: a prospective study. Psychosomatics. May-Jun. 2004;45(3):210-6. Source: PubMed. [pmid: 15123845].
708 Cusin C, Fava M, Amsterdam JD, et al. Early symptomatic worsening during treatment with fluoxetine in major depressive disorder: prevalence and implications. J Clin Psychiatry. Jan. 2007;68(1):52-7. Source: PubMed. [pmid: 17284130].
709 Cusin C, Serretti A, Zanardi R, et al. Influence of monoamine oxidase A and serotonin receptor 2A polymorphisms in SSRI antidepressant activity. Int J Neuropsychopharmacol. Mar. 2002;5(1):27-35. Source: PubMed. [pmid: 12057029].
710 Cutler AJ, Montgomery SA, Feifel D, et al. Extended release quetiapine fumarate monotherapy in major depressive disorder: a placebo- and duloxetine-controlled study. J Clin Psychiatry. 2009;70(4):526-39. Source: PubMed. [pmid: 19358790].
711 Dahlberg M, Lundin K. Antidepressants and the Suicide Rate: Is There Really a Connection?. Upsulla University (Sweden) Economics Department. 2005:4. Source: Scopus.
712 Dalack GW, Glassman AH, Rivelli S, et al. Mood, major depression, and fluoxetine response in cigarette smokers. Am J Psychiatry. Mar. 1995;152(3):398-403. Source: PubMed. [pmid: 7864266].
713 Dalery J, Aubin V. Comparative study of paroxetine and mianserine in depression of the elderly: Efficacy, tolerance, serotonine dependence. Encephale. 2001;27(1):71-81. Source: EMBASE. [pmid: 11294041].
714 Dalery J, Honig A. Fluvoxamine versus fluoxetine in major depressive episode: a double-blind randomised comparison. Hum Psychopharmacol. Jul. 2003;18(5):379-84. Source: PubMed. [pmid: 12858325].
715 Dalery J, Rochat C, Peyron E, et al. Comparative study of the efficacy and the acceptability of amineptine versus fluoxetine in major depressive episodes. <ORIGINAL>. ETUDE COMPARATIVE DE L'EFFICACITE ET DE L'ACCEPTABILITE DE L'AMINEPTINE ET DE LA FLUOXETINE CHEZ DES PATIENTS DEPRESSIFS MAJEURS. Encephale. 1992;18(3):257-62. Source: EMBASE. [pmid: 1299597].
716 Dalery J, Rochat C, Peyron E, et al. The efficacy and acceptability of amineptine versus fluoxetine in major depression. Int Clin Psychopharmacol. Jul. Suppl 3. 1997;12:S35-8. Source: PubMed. [pmid: 9347391].
717 Dam J, Ryde L, Svejso J, et al. Morning fluoxetine plus evening mianserin versus morning fluoxetine plus evening placebo in the acute treatment of major depression. Pharmacopsychiatry. Mar. 1998;31(2):48-54. Source: PubMed. [pmid: 9562208].
718 Davidson J, Miller R, Van Wyck Fleet J, et al. A double-blind comparison of bupropion and amitriptyline in depressed inpatients. J Clin Psychiatry. May. 1983;44(5 Pt 2):115-7. Source: PubMed. [pmid: 6406438].
719 Davidson J, Pelton S. Forms of atypical depression and their response to antidepressant drugs. Psychiatry Res. Feb. 1986;17(2):87-95. Source: PubMed. [pmid: 3083445].
720 Davidson J, Watkins L, Owens M, et al. Effects of paroxetine and venlafaxine XR on heart rate variability in depression. J Clin Psychopharmacol. Oct. 2005;25(5):480-4. Source: PubMed. [pmid: 16160626].
721 Davidson JR, Connor KM. Bupropion sustained release: a therapeutic overview. J Clin Psychiatry. Suppl 4. 1998;59:25-31. Source: PubMed. [pmid: 9554318].
722 Davidson JR, Meoni P, Haudiquet V, et al. Achieving remission with venlafaxine and fluoxetine in major depression: its relationship to anxiety symptoms. Depress Anxiety. 2002;16(1):4-13. Source: PubMed. [pmid: 12203668].
723 Davidson KW, Rieckmann N, Clemow L, et al. Enhanced depression care for patients with acute coronary syndrome and persistent depressive symptoms: Coronary psychosocial evaluation studies randomized controlled trial. Archives of Internal Medicine. 2010;170(7):600-8. Source: EMBASE. [pmid: 20386003].
724 Davis A, Gilhooley M, Agius M, et al. Suicide risk and choice of antidepressant. Psychiatr Danub. Jun. 2010;22(2):358-9. Source: PubMed. [pmid: 20562782].
725 Davis BA, Boulton AA, Yu PH, et al. Longitudinal effect of amitriptyline and fluoxetine treatment on plasma phenylacetic acid concentrations in depression. Biol Psychiatry. Sep. 15. 1991;30(6):600-8. Source: PubMed. [pmid: 1932407].
726 Davis L, Uezato A, Newell JM, et al. Major depression and comorbid substance use disorders. Curr Opin Psychiatry. Jan. 2008;21(1):14-8. Source: PubMed. [pmid: 18281835].
727 Davis LL, Frazier E, Husain MM, et al. Substance use disorder comorbidity in major depressive disorder: a confirmatory analysis of the STAR*D cohort. Am J Addict. Jul-Aug. 2006;15(4):278-85. Source: PubMed. [pmid: 16867922].
728 Davis LL, Frazier EC, Gaynes BN, et al. Are depressed outpatients with and without a family history of substance use disorder different? A baseline analysis of the STAR*D cohort. J Clin Psychiatry. Dec. 2007;68(12):1931-8. Source: PubMed. [pmid: 18162025].
729 Davis LL, Rush JA, Wisniewski SR, et al. Substance use disorder comorbidity in major depressive disorder: an exploratory analysis of the Sequenced Treatment Alternatives to Relieve Depression cohort. Compr Psychiatry. Mar-Apr. 2005;46(2):81-9. Source: PubMed. [pmid: 15723023].
730 Davis LL, Wisniewski SR, Howland RH, et al. Does comorbid substance use disorder impair recovery from major depression with SSRI treatment? An analysis of the STAR*D level one treatment outcomes. Drug Alcohol Depend. Mar. 1. 2010;107(2-3):161-70. Source: PubMed. [pmid: 19945804].
731 Daviss WB, Perel JM, Brent DA, et al. Acute antidepressant response and plasma levels of bupropion and metabolites in a pediatric-aged sample: an exploratory study. Ther Drug Monit. Apr. 2006;28(2):190-8. Source: PubMed. [pmid: 16628130].
732 Davydov DM, Shapiro D, Cook IA, et al. Baroreflex mechanisms in major depression. Progressin Neuro Psychopharmacology and Biological Psychiatry. 2007;31(1):164-77. Source: EMBASE.
733 de Abajo FJ, Garcia-Rodriguez LA. Risk of upper gastrointestinal tract bleeding associated with selective serotonin reuptake inhibitors and venlafaxine therapy: interaction with nonsteroidal anti-inflammatory drugs and effect of acid-suppressing agents. Arch Gen Psychiatry. Jul. 2008;65(7):795-803. Source: PubMed. [pmid: 18606952].
734 de Carvalho GA, Bahls SC, Boeving A, et al. Effects of selective serotonin reuptake inhibitors on thyroid function in depressed patients with primary hypothyroidism or normal thyroid function. Thyroid. Jul. 2009;19(7):691-7. Source: PubMed. [pmid: 19583486].
735 de Diego-Adelino J, Portella MJ, Puigdemont D, et al. A short duration of untreated illness (DUI) improves response outcomes in first-depressive episodes. J Affect Disord. Jan. 2010;120(1-3):221-5. Source: PubMed. [pmid: 19349077].
736 de Dios C, Ezquiaga E. Manic switching in patients receiving duloxetine. The American Journal of Psychiatry. Jul. 2007. 2007;164(7):1121. Source: PsycINFO. [pmid: 17606669].
737 De Fruyt J, Demyttenaere K. Quality of life measurement in antidepressant trials. Is there an added value?. Psychother Psychosom. 2009;78(4):212-9. Source: PubMed. [pmid: 19401621].
738 de Jong J, Hoogenboom B, van Troostwijk LD, et al. Interaction of olanzapine with fluvoxamine. Psychopharmacology (Berl). May. 2001;155(2):219-20. Source: PubMed. [pmid: 11401013].
739 de Jonge P, Honig A, van Melle JP, et al. Nonresponse to treatment for depression following myocardial infarction: association with subsequent cardiac events. Am J Psychiatry. Sep. 2007;164(9):1371-8. Source: PubMed. [pmid: 17728422].
740 De Jonghe F, Dekker J, Kool S, et al. Psychotherapy and/or antidepressants with depression: A randomised study. Tijdschrift Voor Psychiatrie. 2002;44(4):237-48. Source: EMBASE.
741 de Jonghe F, Ravelli DP, Tuynman-Qua H. A randomized, double-blind study of fluoxetine and maprotiline in the treatment of major depression. Pharmacopsychiatry. Mar. 1991;24(2):62-7. Source: PubMed. [pmid: 1852793].
742 de Klerk E. Patient compliance with enteric-coated weekly fluoxetine during continuation treatment of major depressive disorder. J Clin Psychiatry. Suppl 22. 2001;62:43-7. Source: PubMed. [pmid: 11599648].
743 De Las Cuevas C, de la Rosa MA, Troyano JM, et al. Are psychotropics drugs used in pregnancy. Pharmacoepidemiol Drug Saf. Sep. 2007;16(9):1018-23. Source: PubMed. [pmid: 17455181].
744 De Maat S, Dekker J, Schoevers R, et al. Short psychodynamic supportive psychotherapy, antidepressants, and their combination in the treatment of major depression: A mega-analysis based on three randomized clinical trials. Depression and Anxiety. 2008;25(7):565-74. Source: EMBASE. [pmid: 17557313].
745 de Montigny C, Silverstone PH, Debonnel G, et al. Venlafaxine in treatment-resistant major depression: a Canadian multicenter, open-label trial. J Clin Psychopharmacol. Oct. 1999;19(5):401-6. Source: PubMed. [pmid: 10505581].
746 De Nayer A, Geerts S, Ruelens L, et al. Venlafaxine compared with fluoxetine in outpatients with depression and concomitant anxiety. Int J Neuropsychopharmacol. Jun. 2002;5(2):115-20. Source: PubMed. [pmid: 12135535].
747 de Vasconcelos Cunha UG, Lopes Rocha F, Avila de Melo R, et al. A placebo-controlled double-blind randomized study of venlafaxine in the treatment of depression in dementia. Dement Geriatr Cogn Disord. 2007;24(1):36-41. Source: PubMed. [pmid: 17495474].
748 de Wilde J, Mertens C, Overo KF, et al. Citalopram versus mianserin. A controlled, double-blind trial in depressed patients. Acta Psychiatr Scand. Jul. 1985;72(1):89-96. Source: PubMed. [pmid: 3898725].
749 De Wilde J, Peetermans C. Trazodone versus amitriptyline: A multicentre, double-blind trial in patients hospitalized for depression. Acta Therapeutica. 1987;13(5):439-53. Source: EMBASE.
750 De Wilde J, Spiers R, Mertens C, et al. A double-blind, comparative, multicentre study comparing paroxetine with fluoxetine in depressed patients. Acta Psychiatr Scand. Feb. 1993;87(2):141-5. Source: PubMed. [pmid: 8447241].
751 De Wilde JE, Doogan DP. Fluvoxamine and chlorimipramine in endogenous depression. J Affect Disord. Sep. 1982;4(3):249-59. Source: PubMed. [pmid: 6215443].
752 De Wilde JE, Mertens C, Wakelin JS. Clinical trials of fluvoxamine vs chlorimipramine with single and three times daily dosing. Br J Clin Pharmacol. Suppl 3. 1983;15:427S-31S. Source: PubMed. [pmid: 6407503].
753 Deahl M. Pharmacological treatment of depression: the role of paroxetine. Hosp Med. Jan. 2001;62(1):38-42. Source: PubMed. [pmid: 11211460].
754 DeBattista C, Schatzberg AF. Psychotropic dosing and monitoring guidelines. Primary Psychiatry. 2006;13(6):61-81. Source: EMBASE.
755 DeBattista C, Solvason HB, Poirier J, et al. A prospective trial of bupropion SR augmentation of partial and non-responders to serotonergic antidepressants. J Clin Psychopharmacol. Feb. 2003;23(1):27-30. Source: PubMed. [pmid: 12544372].
756 Debonnel G, Saint-Andre E, Hebert C, et al. Differential physiological effects of a low dose and high doses of venlafaxine in major depression. Int J Neuropsychopharmacol. Feb. 2007;10(1):51-61. Source: PubMed. [pmid: 16690006].
757 Debus JR, Rush AJ, Himmel C, et al. Fluoxetine versus trazodone in the treatment of outpatients with major depression. J Clin Psychiatry. Nov. 1988;49(11):422-6. Source: PubMed. [pmid: 3053668].
758 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173. Source: PubMed. [pmid: 14499048].
759 Dekker J, Molenaar PJ, Kool S, et al. Dose-effect relations in time-limited combined psycho-pharmacological treatment for depression. Psychol Med. Jan. 2005;35(1):47-58. Source: PubMed. [pmid: 15842028].
760 Delaney SD. Acute dysphoria or treatment emergent mixed state. Psychiatry. Feb. 2008. 2008;5(2):22. Source: PsycINFO. [pmid: 19727298].
761 Delbressine LP, Vos RM. The clinical relevance of preclinical data: mirtazapine, a model compound. J Clin Psychopharmacol. Apr. Suppl 1. 1997;17:29S-33S. Source: PubMed. [pmid: 9090575].
762 Delgado PL, Brannan SK, Mallinckrodt CH, et al. Sexual functioning assessed in 4 double-blind placebo- and paroxetine-controlled trials of duloxetine for major depressive disorder. J Clin Psychiatry. Jun. 2005;66(6):686-92. Source: PubMed. [pmid: 15960560].
763 Delgado PL, Miller HL, Salomon RM, et al. Tryptophan-depletion challenge in depressed patients treated with desipramine or fluoxetine: implications for the role of serotonin in the mechanism of antidepressant action. Biol Psychiatry. Jul. 15. 1999;46(2):212-20. Source: PubMed. [pmid: 10418696].
764 Delgado PL, Moreno FA, Onate L, et al. Sequential catecholamine and serotonin depletion in mirtazapine-treated depressed patients. Int J Neuropsychopharmacol. Mar. 2002;5(1):63-6. Source: PubMed. [pmid: 12057033].
765 Delini-Stula A, Bischof R. The results of the Swiss observational study of the new, fast-dissolving mirtazapine formulation in depressed patients. International Journal of Psychiatry in Clinical Practice. Jun. 2006. 2006;10(2):124-30. Source: PsycINFO.
766 Delini-Stula A, Van Oers H, Van Willigenburg A, et al. Treating depression with different galenical drug formulations: Does it make a difference? The comparison of mirtazapine fast dissolving formulation (FDT) with conventional mirtazapine tablets (CT). International Journal of Psychiatry in Clinical Practice. 2009;13(2):109-16. Source: PsycINFO.
767 Dell'Osso B, Hadley S, Allen A, et al. Escitalopram in the treatment of impulsive-compulsive internet usage disorder: an open-label trial followed by a double-blind discontinuation phase. J Clin Psychiatry. Mar. 2008;69(3):452-6. Source: PubMed. [pmid: 18312057].
768 Demal U, Zitterl W, Lenz G, et al. Obsessive compulsive disorder and depression--first results of a prospective study on 74 patients. Prog Neuropsychopharmacol Biol Psychiatry. Jul. 1996;20(5):801-13. Source: PubMed. [pmid: 8870065].
769 DeMartinis NA, Yeung PP, Entsuah R, et al. A double-blind, placebo-controlled study of the efficacy and safety of desvenlafaxine succinate in the treatment of major depressive disorder. J Clin Psychiatry. 2007;68(5):677-88. Source: PubMed. [pmid: 17503976].
770 Demyttenaere K, Albert A, Mesters P, et al. What happens with adverse events during 6 months of treatment with selective serotonin reuptake inhibitors?. J Clin Psychiatry. 2005;66(7):859-63. Source: PubMed. [pmid: 16013901].
771 Demyttenaere K, Andersen HF, Reines EH. Impact of escitalopram treatment on Quality of Life Enjoyment and Satisfaction Questionnaire scores in major depressive disorder and generalized anxiety disorder. Int Clin Psychopharmacol. Sep. 2008;23(5):276-86. Source: PubMed. [pmid: 18703937].
772 Demyttenaere K, De Fruyt J, Stahl SM. The many faces of fatigue in major depressive disorder. International Journal of Neuropsychopharmacology. 2005;8(1):93-105. Source: Scopus. [pmid: 15482632].
773 Demyttenaere K, Van Ganse E, Gregoire J, et al. Compliance in depressed patients treated with fluoxetine or amitriptyline. Int Clin Psychopharmacol. 1998;13(1):11-7. Source: EMBASE. [pmid: 9988362].
774 den Boer JA, Bosker FJ, Meesters Y. Clinical efficacy of agomelatine in depression: the evidence. Int Clin Psychopharmacol. Feb. Suppl 1. 2006;21:S21-4. Source: PubMed. [pmid: 16436936].
775 Den Boer JA, Westenberg HG. Effect of a serotonin and noradrenaline uptake inhibitor in panic disorder; a double-blind comparative study with fluvoxamine and maprotiline. Int Clin Psychopharmacol. Jan. 1988;3(1):59-74. Source: PubMed. [pmid: 2833543].
776 Denko TC, Friedman ES. Augmentation strategies in STAR*D : A review. 2007;14(1):5. Source: Handsearch.
777 Denninger JW, Papakostas GI, Mahal Y, et al. Somatic symptoms in outpatients with major depressive disorder treated with fluoxetine. Psychosomatics. Jul-Aug. 2006;47(4):348-52. Source: PubMed. [pmid: 16844895].
778 Denton WH, Carmody TJ, Rush AJ, et al. Dyadic discord at baseline is associated with lack of remission in the acute treatment of chronic depression. Psychol Med. Mar. 2010;40(3):415-24. Source: PubMed. [pmid: 19607755].
779 DeRubeis RJ, Hollon SD, Amsterdam JD, et al. Cognitive therapy vs medications in the treatment of moderate to severe depression. Arch Gen Psychiatry. Apr. 2005;62(4):409-16. Source: PubMed. [pmid: 15809408].
780 Deshauer D, Moher D, Fergusson D, et al. Selective serotonin reuptake inhibitors for unipolar depression: A systematic review of classic long-term randomized controlled trials. Canadian Medical Association Journal. 2008;178(10):1293-301. Source: Handsearch. [pmid: 18458261].
781 Deslandes AC, Moraes H, Alves H, et al. Effect of aerobic training on EEG alpha asymmetry and depressive symptoms in the elderly: A 1-year follow-up study. Brazilian Journal of Medical and Biological Research. 2010;43(6):585-92. Source: EMBASE. [pmid: 20464340].
782 Desmarais JE, Looper KJ. Interactions between tamoxifen and antidepressants via cytochrome P450 2D6. J Clin Psychiatry. Dec. 2009;70(12):1688-97. Source: PubMed. [pmid: 20141708].
783 Dessaulles A, Johnson SM, Denton WH. Emotion-focused therapy for couples in the treatment of depression: a pilot study. American Journal of Family Therapy. 2003;31(5):345-53. Source: EMBASE.
784 Detke MJ, Lu Y, Goldstein DJ, et al. Duloxetine, 60 mg once daily, for major depressive disorder: a randomized double-blind placebo-controlled trial. J Clin Psychiatry. Apr. 2002;63(4):308-15. Source: PubMed. [pmid: 12000204].
785 Detke MJ, Lu Y, Goldstein DJ, et al. Duloxetine 60 mg once daily dosing versus placebo in the acute treatment of major depression. J Psychiatr Res. Nov-Dec. 2002;36(6):383-90. Source: PubMed. [pmid: 12393307].
786 Detke MJ, Wiltse CG, Mallinckrodt CH, et al. Duloxetine in the acute and long-term treatment of major depressive disorder: a placebo- and paroxetine-controlled trial. Eur Neuropsychopharmacol. Dec. 2004;14(6):457-70. Source: PubMed. [pmid: 15589385].
787 Deuschle M, Angermeier T, Westphal S, et al. Venlafaxine, but not mirtazapine lowers retinol-binding protein 4 serum concentrations in nondiabetic depressed patients. Psychotherapy and psychosomatics. 2010;(2):123-5. Source: The Cochrane Library. [pmid: 20090399].
788 Deuschle M, Hamann B, Meichel C, et al. Antidepressive treatment with amitriptyline and paroxetine: effects on saliva cortisol concentrations. J Clin Psychopharmacol. Apr. 2003;23(2):201-5. Source: PubMed. [pmid: 12640223].
789 Deuschle M, Kniest A, Niemann H, et al. Impaired declarative memory in depressed patients is slow to recover: clinical experience. Pharmacopsychiatry. Jul. 2004;37(4):147-51. Source: PubMed. [pmid: 15467969].
790 Deuschle M, Krumm B, Bindeballe N, et al. Open-label non-randomized versus double-blind randomized antidepressive treatment: what are the advantages of clinical decision over randomization. Pharmacopsychiatry. Nov. 2004;37(6):299-302. Source: PubMed. [pmid: 15551197].
791 Devanand DP, Juszczak N, Nobler MS, et al. An open treatment trial of venlafaxine for elderly patients with dysthymic disorder. J Geriatr Psychiatry Neurol. Dec. 2004;17(4):219-24. Source: PubMed. [pmid: 15533993].
792 Devanand DP, Kim MK, Nobler MS. Fluoxetine discontinuation in elderly dysthymic patients. Am J Geriatr Psychiatry. Winter. 1997;5(1):83-7. Source: PubMed. [pmid: 9169249].
793 Devanand DP, Nobler MS, Cheng J, et al. Randomized, double-blind, placebo-controlled trial of fluoxetine treatment for elderly patients with dysthymic disorder. Am J Geriatr Psychiatry. Jan. 2005;13(1):59-68. Source: PubMed. [pmid: 15653941].
794 Devanand DP, Pelton GH, Marston K, et al. Sertraline treatment of elderly patients with depression and cognitive impairment. Int J Geriatr Psychiatry. Feb. 2003;18(2):123-30. Source: PubMed. [pmid: 12571820].
795 DeVane CL, Gill HS. Clinical pharmacokinetics of fluvoxamine: applications to dosage regimen design. J Clin Psychiatry. Suppl 5. 1997;58:7-14. Source: PubMed. [pmid: 9184622].
796 DeVane CL, Liston HL, Markowitz JS. Clinical pharmacokinetics of sertraline. Clin Pharmacokinet. 2002;41(15):1247-66. Source: PubMed. [pmid: 12452737].
797 DeVane CL, Markowitz JS, Hardesty SJ, et al. Fluvoxamine-induced theophylline toxicity. Am J Psychiatry. Sep. 1997;154(9):1317-8. Source: PubMed. [pmid: 9286199].
798 DeVane CL, Pollock BG. Pharmacokinetic considerations of antidepressant use in the elderly. J Clin Psychiatry. Suppl 20. 1999;60:38-44. Source: PubMed. [pmid: 10513858].
799 Devarajan S. Interaction of fluoxetine and chloral hydrate. Can J Psychiatry. Oct. 1992;37(8):590-1. Source: PubMed. [pmid: 1423165].
800 DeVeaugh-Geiss AM, West SL, Miller WC, et al. Depression and comorbid panic in primary care patients. J Affect Disord. Jun. 2010;123(1-3):283-90. Source: PubMed. [pmid: 19828203].
801 Dew MA, Whyte EM, Lenze EJ, et al. Recovery from major depression in older adults receiving augmentation of antidepressant pharmacotherapy. Am J Psychiatry. Jun. 2007;164(6):892-9. Source: PubMed. [pmid: 17541048].
802 Dhillon S, Yang LP, Curran MP. Spotlight on bupropion in major depressive disorder. CNS Drugs. 2008;22(7):613-7. Source: PubMed. [pmid: 18547129].
803 D'Hondt P, Maes M, Leysen JE, et al. Binding of [3H]paroxetine to platelets of depressed patients: seasonal differences and effects of diagnostic classification. J Affect Disord. Sep. 1994;32(1):27-35. Source: PubMed. [pmid: 7798464].
804 Diaz A, Fouilloux C, Ortiz S. Open trial study of a combined antidepressant (amitryptiline, perphenazine, diazepam) versus fluoxetine or imipramine in ambulatory depressed patients. Proc West Pharmacol Soc. 2002;45:154-5. Source: PubMed. [pmid: 12434564].
805 Diazgranados N, Ibrahim L, Brutsche NE, et al. A randomized add-on trial of an N-methyl-D-aspartate antagonist in treatment-resistant bipolar depression. Archives of general psychiatry. 2010;67(8):793-802. Source: EMBASE. [pmid: 20679587].
806 Diaz-Martinez A, Benassinni O, Ontiveros A, et al. A randomized, open-label comparison of venlafaxine and fluoxetine in depressed outpatients. Clin Ther. May-Jun. 1998;20(3):467-76. Source: PubMed. [pmid: 9663362].
807 Dichter GS, Felder JN, Smoski MJ. The effects of Brief Behavioral Activation Therapy for Depression on cognitive control in affective contexts: An fMRI investigation. Journal of affective disorders. 2010;126(1-2):236-44. Source: EMBASE. [pmid: 20421135].
808 Dichter GS, Tomarken AJ, Freid CM, et al. Do venlafaxine XR and paroxetine equally influence negative and positive affect. J Affect Disord. Apr. 2005;85(3):333-9. Source: PubMed. [pmid: 15780704].
809 Dichter GS, Tomarken AJ, Shelton RC, et al. Early- and late-onset startle modulation in unipolar depression. Psychophysiology. May. 2004;41(3):433-40. Source: PubMed. [pmid: 15102129].
810 Dick P, Ferrero E. A double-blind comparative study of the clinical efficacy of fluvoxamine and chlorimipramine. Br J Clin Pharmacol. Suppl 3. 1983;15:419S-25S. Source: PubMed. [pmid: 6407502].
811 Dickens C, Jayson M, Sutton C, et al. The relationship between pain and depression in a trial using paroxetine in sufferers of chronic low back pain. Psychosomatics. Nov-Dec. 2000;41(6):490-9. Source: PubMed. [pmid: 11110112].
812 Didham RC, McConnell DW, Blair HJ, et al. Suicide and self-harm following prescription of SSRIs and other antidepressants: confounding by indication. Br J Clin Pharmacol. Nov. 2005;60(5):519-25. Source: PubMed. [pmid: 16236042].
813 Dieperink E, Ho SB, Tetrick L, et al. Suicidal ideation during interferon-alpha2b and ribavirin treatment of patients with chronic hepatitis C. Gen Hosp Psychiatry. May-Jun. 2004;26(3):237-40. Source: PubMed. [pmid: 15121353].
814 Dierick M, Ravizza L, Realini R, et al. A double-blind comparison of venlafaxine and fluoxetine for treatment of major depression in outpatients. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1996;20(1):57-71. Source: PubMed. [pmid: 8861177].
815 Dimidjian S, Hollon SD, Dobson KS, et al. Randomized trial of behavioral activation, cognitive therapy, and antidepressant medication in the acute treatment of adults with major depression. Journal of Consulting and Clinical Psychology. 2006;74(4):658-70. Source: EMBASE. [pmid: 16881773].
816 Dinan TG. Efficacy and safety of weekly treatment with enteric-coated fluoxetine in patients with major depressive disorder. J Clin Psychiatry. Suppl 22. 2001;62:48-52. Source: PubMed. [pmid: 11599649].
817 Dittmann RW, Czekalla J, Hundemer HP, et al. Efficacy and safety findings from naturalistic fluoxetine drug treatment in adolescent and young adult patients. J Child Adolesc Psychopharmacol. Summer. 2000;10(2):91-102. Source: PubMed. [pmid: 10933119].
818 Dittmann RW, Linden M, Osterheider M, et al. Antidepressant drug use: differences between psychiatrists and general practitioners. Results from a drug utilization observation study with fluoxetine. Pharmacopsychiatry. Jan. 1997;30(1 Suppl):28-34. Source: PubMed. [pmid: 9035225].
819 Divinsky M. A clinical dilemma. Can Fam Physician. Mar. 1996;42:406. Source: PubMed. [pmid: 8616279].
820 Djulus J, Koren G, Einarson TR, et al. Exposure to mirtazapine during pregnancy: a prospective, comparative study of birth outcomes. J Clin Psychiatry. Aug. 2006;67(8):1280-4. Source: PubMed. [pmid: 16965209].
821 D'Mello DA, Meland R, Ransom S. Nefazodone and hypotension: complication or coincidence. J Clin Psychopharmacol. Apr. 1997;17(2):136. Source: PubMed. [pmid: 10950489].
822 Dobkin RD, Menza M, Bienfait KL, et al. The impact of antidepressant treatment on cognitive functioning in depressed patients with Parkinson's disease. J Neuropsychiatry Clin Neurosci. Spring. 2010;22(2):188-95. Source: PubMed. [pmid: 20463113].
823 Doggrell SA. After the failure of citalopram for depression, what next. Expert Opin Pharmacother. Aug. 2006;7(11):1515-8. Source: PubMed. [pmid: 16859434].
824 Dolberg OT, Hirschmann S, Grunhaus L. Melatonin for the treatment of sleep disturbances in major depressive disorder. Am J Psychiatry. Aug. 1998;155(8):1119-21. Source: PubMed. [pmid: 9699707].
825 Dolder C, Nelson M, Stump A. Pharmacological and clinical profile of newer antidepressants: implications for the treatment of elderly patients. Drugs Aging. Aug. 1. 2010;27(8):625-40. Source: PubMed. [pmid: 20658791].
826 Dombrovski AY, Cyranowski JM, Mulsant BH, et al. Which symptoms predict recurrence of depression in women treated with maintenance interpersonal psychotherapy?. Depress Anxiety. 2008;25(12):1060-6. Source: PubMed. [pmid: 18781665].
827 Dombrovski AY, Mulsant BH, Houck PR, et al. Residual symptoms and recurrence during maintenance treatment of late-life depression. J Affect Disord. Nov. 2007;103(1-3):77-82. Source: PubMed. [pmid: 17321595].
828 Dominguez RA, Goldstein BJ. Suicidal and homicidal ideations emerging during a placebo period. J Clin Psychiatry. May. 1992;53(5):171. Source: PubMed. [pmid: 1592845].
829 Dominguez RA, Goldstein BJ, Jacobson AF, et al. A double-blind placebo-controlled study of fluvoxamine and imipramine in depression. J Clin Psychiatry. Mar. 1985;46(3):84-7. Source: PubMed. [pmid: 3918993].
830 Dominguez RA, Goodnick PJ. Adverse events after the abrupt discontinuation of paroxetine. Pharmacotherapy. Nov-Dec. 1995;15(6):778-80. Source: PubMed. [pmid: 8602387].
831 Dominguez RA, Kumar AM, Cua W. Lack of change in fluoxetine and norfluoxetine kinetics when switching from fluoxetine to paroxetine. J Clin Psychopharmacol. Aug. 1996;16(4):320-3. Source: PubMed. [pmid: 8835708].
832 Dominguez RA, Puig A. Olfactory reference syndrome responds to clomipramine but not fluoxetine: a case report. J Clin Psychiatry. Nov. 1997;58(11):497-8. Source: PubMed. [pmid: 9413419].
833 Donovan S. The efficacy and tolerability of dothiepin versus serotonin specific reuptake inhibitors in the treatment of depression. European Neuropsychopharmacology. 1993;3(3):331-2. Source: EMBASE.
834 Doogan DP, Caillard V. Sertraline in the prevention of depression. Br J Psychiatry. Feb. 1992;160:217-22. Source: PubMed. [pmid: 1540762].
835 Doogan DP, Langdon CJ. A double-blind, placebo-controlled comparison of sertraline and dothiepin in the treatment of major depression in general practice. Int Clin Psychopharmacol. Summer. 1994;9(2):95-100. Source: PubMed. [pmid: 8057000].
836 Doraiswamy PM, Khan ZM, Donahue RM, et al. Quality of life in geriatric depression: a comparison of remitters, partial responders, and nonresponders. Am J Geriatr Psychiatry. Fall. 2001;9(4):423-8. Source: PubMed. [pmid: 11739069].
837 Doraiswamy PM, Krishnan KR, Oxman T, et al. Does antidepressant therapy improve cognition in elderly depressed patients. J Gerontol A Biol Sci Med Sci. Dec. 2003;58(12):M1137-44. Source: PubMed. [pmid: 14684712].
838 Dording CM, Fisher L, Papakostas G, et al. A double-blind, randomized, pilot dose-finding study of maca root (L. meyenii) for the management of SSRI-induced sexual dysfunction. CNS Neurosci Ther. Fall. 2008;14(3):182-91. Source: PubMed. [pmid: 18801111].
839 Dorman T. Sleep and paroxetine: a comparison with mianserin in elderly depressed patients. Int Clin Psychopharmacol. Jun. Suppl 4. 1992;6:53-8. Source: PubMed. [pmid: 1431012].
840 Dornseif BE, Dunlop SR, Potvin JH, et al. Effect of dose escalation after low-dose fluoxetine therapy. Psychopharmacol Bull. 1989;25(1):71-9. Source: PubMed. [pmid: 2672072].
841 Dotoli D, Spagnolo C, Bongiorno F, et al. Relapse during a 6-month continuation treatment with fluvoxamine in an Italian population: the role of clinical, psychosocial and genetic variables. Prog Neuropsychopharmacol Biol Psychiatry. May. 2006;30(3):442-8. Source: PubMed. [pmid: 16431008].
842 Doyle JJ, Casciano J, Arikian S, et al. A multinational pharmacoeconomic evaluation of acute major depressive disorder (MDD): a comparison of cost-effectiveness between venlafaxine, SSRIs and TCAs. Value Health. Jan-Feb. 2001;4(1):16-31. Source: PubMed. [pmid: 11704969].
843 Drago A, Serretti A, Smith R, et al. No association between genetic markers in BDNF gene and lithium prophylaxis in a Greek sample. International Journal of Psychiatry in Clinical Practice. 2010;14(2):154-7. Source: EMBASE.
844 Dremencov E, El Mansari M, Blier P. Noradrenergic Augmentation of Escitalopram Response by Risperidone: Electrophysiologic Studies in the Rat Brain. Biological Psychiatry. 2007;61(5):671-8. Source: Scopus. [pmid: 16934772].
845 Dresler M, Kluge M, Genzel L, et al. Impaired off-line memory consolidation in depression. European Neuropsychopharmacology. 2010;20(8):553-61. Source: EMBASE. [pmid: 20199853].
846 Drevets WC, Furey ML. Replication of scopolamine's antidepressant efficacy in major depressive disorder: A randomized, placebo-controlled clinical trial. Biological psychiatry. 2010;67(5):432-8. Source: PsycINFO. [pmid: 20074703].
847 Driscoll HC, Basinski J, Mulsant BH, et al. Late-onset major depression: clinical and treatment-response variability. Int J Geriatr Psychiatry. Jul. 2005;20(7):661-7. Source: PubMed. [pmid: 16021664].
848 Droulers A, Bodak N, Oudjhani M, et al. Decrease of valproic acid concentration in the blood when coprescribed with fluoxetine. J Clin Psychopharmacol. Apr. 1997;17(2):139-40. Source: PubMed. [pmid: 10950492].
849 Duarte A, Mikkelsen H, Delini-Stula A. Moclobemide versus fluoxetine for double depression: a randomized double-blind study. J Psychiatr Res. Nov-Dec. 1996;30(6):453-8. Source: PubMed. [pmid: 9023788].
850 Dube S, Dellva MA, Jones M, et al. A study of the effects of LY2216684, a selective norepinephrine reuptake inhibitor, in the treatment of major depression. J Psychiatr Res. 2010;44(6):356-63. Source: PubMed. [pmid: 19909980].
851 Dubini A, Bosc M, Polin V. Noradrenaline-selective versus serotonin-selective antidepressant therapy: differential effects on social functioning. J Psychopharmacol. 1997;11(4 Suppl):S17-23. Source: PubMed. [pmid: 9438229].
852 Dubini A, Bosc M, Polin V. Do noradrenaline and serotonin differentially affect social motivation and behaviour. Eur Neuropsychopharmacol. Apr. Suppl 1. 1997;7:S49-55. discussion S71-3. Source: PubMed. [pmid: 9169310].
853 Duboff EA. Long-term treatment of major depressive disorder with paroxetine. J Clin Psychopharmacol. Dec. 1993;13(6 Suppl 2):28S-33S. Source: PubMed. [pmid: 8106653].
854 Dudley M, Goldney R, Hadzi-Pavlovic D. Are adolescents dying by suicide taking SSRI antidepressants? A review of observational studies. Australasian Psychiatry. 2010;18(3):242-5. Source: EMBASE. [pmid: 20482427].
855 Duenas HJ, Dwight T, McBride ME, et al. Effectiveness of antidepressants in the treatment of major depressive disorder in Latin America. International Journal of Psychiatry in Clinical Practice. Jun. 2007. 2007;11(2):129-39. Source: PsycINFO.
856 Duggal HS, Fetchko J. Serotonin syndrome and atypical antipsychotics. Am J Psychiatry. Apr. 2002;159(4):672-3. Source: PubMed. [pmid: 11925312].
857 Duinkerke SJ. A double-blind parallel group study of dothiepin and mianserin in depressed psychiatric in/out-patients. Round Table Series - Royal Society of Medicine. 1990;15:55-63. Source: EMBASE.
858 Dunbar GC. Paroxetine in the elderly: a comparative meta-analysis against standard antidepressant pharmacotherapy. Pharmacology. Sep. 1995;51(3):137-44. Source: PubMed. [pmid: 7501698].
859 Dunbar GC, Claghorn JL, Kiev A, et al. A comparison of paroxetine and placebo in depressed outpatients. Acta Psychiatr Scand. May. 1993;87(5):302-5. Source: PubMed. [pmid: 8517168].
860 Dunbar GC, Cohn JB, Fabre LF, et al. A comparison of paroxetine, imipramine and placebo in depressed out-patients. Br J Psychiatry. Sep. 1991;159:394-8. Source: PubMed. [pmid: 1835664].
861 Duncan E, Dunlop BW, Boshoven W, et al. Relative risk of glucose elevation during antipsychotic exposure in a Veterans Administration population. International Clinical Psychopharmacology. 2007;22(1):1-11. Source: Scopus. [pmid: 17159454].
862 Dunkin JJ, Leuchter AF, Cook IA, et al. Executive dysfunction predicts nonresponse to fluoxetine in major depression. J Affect Disord. Oct. 2000;60(1):13-23. Source: PubMed. [pmid: 10940443].
863 Dunlop BW, Li T, Kornstein SG, et al. Correlation between patient and clinician assessments of depression severity in the PREVENT study. Psychiatry Research. 2010;177(1-2):177-83. Source: PsycINFO. [pmid: 20304503].
864 Dunlop SR, Dornseif BE, Wernicke JF, et al. Pattern analysis shows beneficial effect of fluoxetine treatment in mild depression. Psychopharmacol Bull. 1990;26(2):173-80. Source: PubMed. [pmid: 2236453].
865 Dunner DL. Acute and maintenance treatment of chronic depression. J Clin Psychiatry. Suppl 6. 2001;62:10-6. Source: PubMed. [pmid: 11310814].
866 Dunner DL, Amsterdam JD, Shelton RC, et al. Efficacy and tolerability of adjunctive ziprasidone in treatment-resistant depression: a randomized, open-label, pilot study. J Clin Psychiatry. Jul. 2007;68(7):1071-7. Source: PubMed. [pmid: 17685744].
867 Dunner DL, Cohn JB, Walshe T 3rd, et al. Two combined, multicenter double-blind studies of paroxetine and doxepin in geriatric patients with major depression. J Clin Psychiatry. Feb. 1992;53(Suppl):57-60. Source: PubMed. [pmid: 1531827].
868 Dunner DL, D'Souza DN, Kajdasz DK, et al. Is treatment-associated hypomania rare with duloxetine: secondary analysis of controlled trials in non-bipolar depression. J Affect Disord. Jul. 2005;87(1):115-9. Source: PubMed. [pmid: 15967235].
869 Dunner DL, Goldstein DJ, Mallinckrodt C, et al. Duloxetine in treatment of anxiety symptoms associated with depression. Depress Anxiety. 2003;18(2):53-61. Source: PubMed. [pmid: 12964171].
870 Dunner DL, Hendricksen HE, Bea C, et al. Dysthymic disorder: treatment with citalopram. Depress Anxiety. 2002;15(1):18-22. Source: PubMed. [pmid: 11816048].
871 Dunner DL, Schmaling KB, Hendrickson H, et al. Cognitive therapy versus fluoxetine in the treatment of dysthymic disorder. Depression. 1996;4(1):34-41. Source: PubMed. [pmid: 9160652].
872 Dunner DL, Wilson M, Fava M, et al. Long-term tolerability and effectiveness of duloxetine in the treatment of major depressive disorder. Depress Anxiety. 2008;25(5):E1-8. Source: PubMed. [pmid: 17621644].
873 Dunner DL, Wohlreich MM, Mallinckrodt CH, et al. Clinical consequences of initial duloxetine dosing strategies: comparison of 30 and 60 mg QD starting doses. Current Therapeutic Research. 2005;66(6):522-40. Source: Handsearch.
874 Dunner DL, Zisook S, Billow AA, et al. A prospective safety surveillance study for bupropion sustained-release in the treatment of depression. J Clin Psychiatry. Jul. 1998;59(7):366-73. Source: PubMed. [pmid: 9714265].
875 Durham LK, Webb SM, Milos PM, et al. The serotonin transporter polymorphism, 5HTTLPR, is associated with a faster response time to sertraline in an elderly population with major depressive disorder. Psychopharmacology (Berl). Aug. 2004;174(4):525-9. Source: PubMed. [pmid: 12955294].
876 Dursun SM, Bird D, Ronson KE. Nefazodone treatment of dysthymic disorder an open, long-term, prospective pilot study. Prog Neuropsychopharmacol Biol Psychiatry. May. 2002;26(4):671-6. Source: PubMed. [pmid: 12188098].
877 Dursun SM, Devarajan S, Kutcher S. The ‘dalhousie serotonin cocktail’ for treatment-resistant major depressive disorder. J Psychopharmacol. Jun. 2001;15(2):136-8. Source: PubMed. [pmid: 11448087].
878 Duru G, Fantino B. The clinical relevance of changes in the Montgomery-Asberg Depression Rating Scale using the minimum clinically important difference approach. Curr Med Res Opin. May. 2008;24(5):1329-35. Source: PubMed. [pmid: 18377706].
879 Dutta R, Boydell J, Kennedy N, et al. Suicide and other causes of mortality in bipolar disorder: A longitudinal study. Psychological Medicine. 2007;37(6):839-47. Source: Scopus. [pmid: 17349107].
880 Dvir Y, Smallwood P. Serotonin syndrome: a complex but easily avoidable condition. Gen Hosp Psychiatry. May-Jun. 2008;30(3):284-7. Source: PubMed. [pmid: 18433663].
881 Geerts E TvO, Gerlsma C. Nonverbal communication sets the conditions for the relationship between parental bonding and the short-term treatment response in depression. Psychiatry Res. Jan. 30. 2009;165(1-2):120-7. Source: PubMed. [pmid: 19042029].
882 Tamer E GG, Polat M, Alli N. Flare-up of pustular psoriasis with fluoxetine: possibility of a serotoninergic influence?. J Dermatolog Treat. 2009;20(3):1-3. Source: PubMed. [pmid: 18850415].
883 Eaddy M, Bramley T, Regan T. Time to antidepressant discontinuation: a comparison of controlled-release paroxetine and immediate-release selective serotonin-reuptake inhibitors. Manag Care Interface. Dec. 2003;16(12):22-7. Source: PubMed. [pmid: 14750459].
884 Ebbert J, Montori Victor M, Vickers-Douglas Kristin S, et al. Interventions for smokeless tobacco use cessation. Cochrane Database of Systematic Reviews. 2007;(4). Source: The Cochrane Library.
885 Echeverry D, Duran P, Bonds C, et al. Effect of pharmacological treatment of depression on A1C and quality of life in low-income hispanics and African Americans with diabetes: A randomized, double-blind, placebo-controlled trial. Diabetes Care. 2009;32(12):2156-60. Source: PubMed. [pmid: 19729522].
886 Eckert L, Falissard B. Using meta-regression in performing indirect-comparisons: comparing escitalopram with venlafaxine XR. Curr Med Res Opin. 2006;22(11):2313-21. Source: PubMed. [pmid: 17076991].
887 Eckert L, Lançon C. Duloxetine compared with fluoxetine and venlafaxine: Use of meta-regression analysis for indirect comparisons. BMC Psychiatry. 2006;6. Source: Scopus.
888 Egberts AC, Lenderink AW, de Koning FH, et al. Channeling of three newly introduced antidepressants to patients not responding satisfactorily to previous treatment. J Clin Psychopharmacol. Jun. 1997;17(3):149-55. Source: PubMed. [pmid: 9169957].
889 Egberts AC, Veenstra M, de Jong-van den Berg LT. Antidepressant drug choice for first users in two regions in The Netherlands. Pharm World Sci. Jun. 1999;21(3):132-6. Source: PubMed. [pmid: 10427583].
890 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. 2nd edition. 2001. 2001. Source: Handsearch.
891 Ehde DM, Kraft GH, Chwastiak L, et al. Efficacy of paroxetine in treating major depressive disorder in persons with multiple sclerosis. Gen Hosp Psychiatry. 2008;30(1):40-8. Source: PubMed. [pmid: 18164939].
892 Ehrt U, Broich K, Larsen JP, et al. Use of drugs with anticholinergic effect and impact on cognition in Parkinson's disease: A cohort study. Journal of Neurology, Neurosurgery and Psychiatry. 2010;81(2):160-5. Source: EMBASE.
893 Eick TJ, Kofoed L. An unusual indication for a single-subject clinical trial. J Nerv Ment Dis. Oct. 1994;182(10):587-90. Source: PubMed. [pmid: 7931209].
894 Einarson A. Influence of the media on women taking antidepressants during pregnancy. J Clin Psychiatry. Sep. 2009;70(9):1313-4. Source: PubMed. [pmid: 19818247].
895 Einarson A, Choi J, Einarson TR, et al. Incidence of major malformations in infants following antidepressant exposure in pregnancy: Results of a large prospective cohort study. Canadian Journal of Psychiatry. 2009;54(4):242-6. Source: Handsearch.
896 Einarson TR. Evidence based review of escitalopram in treating major depressive disorder in primary care. Int Clin Psychopharmacol. Sep. 2004;19(5):305-10. Source: PubMed. [pmid: 15289704].
897 Einarson TR, Arikian SR, Casciano J, et al. Comparison of extended-release venlafaxine, selective serotonin reuptake inhibitors, and tricyclic antidepressants in the treatment of depression: a meta-analysis of randomized controlled trials. Clin Ther. 1999;21(2):296-308. Source: PubMed. [pmid: 10211533].
898 Eker SS, Akkaya C, Akgöz S, et al. Comparison of reboxetine and sertraline in terms of efficacy and safety in major depressive disorder. Majör Depresif Bozuklukta Sertralin ve Reboksetin'in Etkinlik ve Güvenilirliginin Karşilaştirilmasi. 2005;16(3):153-63. Source: Scopus.
899 Eker SS, Akkaya C, Sarandol A, et al. Effects of various antidepressants on serum thyroid hormone levels in patients with major depressive disorder. Prog Neuropsychopharmacol Biol Psychiatry. May. 15. 2008;32(4):955-61. Source: PubMed. [pmid: 18262705].
900 Eker SS, Kirli S, Akkaya C, et al. Are there differences between serotonergic, noradrenergic and dual acting antidepressants in the treatment of depressed women?. World J Biol Psychiatry. 2009;10(4 Pt 2):400-8. Source: PubMed. [pmid: 19670086].
901 Ekselius L, Bengtsson F, von Knorring L. Non-compliance with pharmacotherapy of depression is associated with a sensation seeking personality. Int Clin Psychopharmacol. Sep. 2000;15(5):273-8. Source: PubMed. [pmid: 10993129].
902 Ekselius L, von Knorring L. Personality disorder comorbidity with major depression and response to treatment with sertraline or citalopram. Int Clin Psychopharmacol. Sep. 1998;13(5):205-11. Source: PubMed. [pmid: 9817625].
903 Ekselius L, von Knorring L. Effect on sexual function of long-term treatment with selective serotonin reuptake inhibitors in depressed patients treated in primary care. J Clin Psychopharmacol. Apr. 2001;21(2):154-60. Source: PubMed. [pmid: 11270911].
904 Ekselius L, von Knorring L, Eberhard G. A double-blind multicenter trial comparing sertraline and citalopram in patients with major depression treated in general practice. Int Clin Psychopharmacol. Nov. 1997;12(6):323-31. Source: PubMed. [pmid: 9547134].
905 Elgamal S, MacQueen G. Galantamine as an adjunctive treatment in major depression. Journal of Clinical Psychopharmacology (USA). 03. 01. 2008;28(Mar):357-9. Source: PsycINFO.
906 El-Khalili N, Joyce M, Atkinson S, et al. Extended-release quetiapine fumarate (quetiapine XR) as adjunctive therapy in major depressive disorder (MDD) in patients with an inadequate response to ongoing antidepressant treatment: A multicentre, randomized, double-blind, placebo-controlled study. International Journal of Neuropsychopharmacology. 2010;13(7):917-32. Source: EMBASE. [pmid: 20175941].
907 Eller T, Vasar V, Shlik J, et al. Pro-inflammatory cytokines and treatment response to escitalopram in major depressive disorder. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 15. 2008;32(2):445-50. Source: PubMed. [pmid: 17976882].
908 Elliott AJ, Russo J, Bergam K, et al. Antidepressant efficacy in HIV-seropositive outpatients with major depressive disorder: an open trial of nefazodone. J Clin Psychiatry. Apr. 1999;60(4):226-31. Source: PubMed. [pmid: 10221282].
909 Elliott AJ, Russo J, Roy-Byrne PP. The effect of changes in depression on health related quality of life (HRQoL) in HIV infection. Gen Hosp Psychiatry. Jan-Feb. 2002;24(1):43-7. Source: PubMed. [pmid: 11814533].
910 Elliott AJ, Uldall KK, Bergam K, et al. Randomized, placebo-controlled trial of paroxetine versus imipramine in depressed HIV-positive outpatients. Am J Psychiatry. Mar. 1998;155(3):367-72. Source: PubMed. [pmid: 9501747].
911 el-Yazigi A, Chaleby K, Gad A, et al. Steady-state kinetics of fluoxetine and amitriptyline in patients treated with a combination of these drugs as compared with those treated with amitriptyline alone. J Clin Pharmacol. Jan. 1995;35(1):17-21. Source: PubMed. [pmid: 7751409].
912 Emrich HM, Berger M, Riemann D, et al. Serotonin reuptake inhibition vs. norepinephrine reuptake inhibition: a double-blind differential-therapeutic study with fluvoxamine and oxaprotiline in endogenous and neurotic depressives. Pharmacopsychiatry. Mar. 1987;20(2):60-3. Source: PubMed. [pmid: 3108909].
913 Emslie GJ, Mayes T, Porta G, et al. Treatment of Resistant Depression in Adolescents (TORDIA): week 24 outcomes. The American journal of psychiatry. 2010;(7):782-91. Source: The Cochrane Library. [pmid: 20478877].
914 Endicott J, McLaughlin TP, Grudzinski AN. Comparison of managed care charges among patients treated with selective serotonin reuptake inhibitors for premenstrual dysphoric disorder. J Clin Psychiatry. Dec. 2003;64(12):1511-6. Source: PubMed. [pmid: 14728114].
915 Engel CC Jr., Walker EA, Engel AL, et al. A randomized, double-blind crossover trial of sertraline in women with chronic pelvic pain. J Psychosom Res. Feb. 1998;44(2):203-7. Source: PubMed. [pmid: 9532549].
916 Englisch S, Fritzinger M, Zink M. Urinary retention during combined treatment of postpsychotic depression with duloxetine and olanzapine. Clin Neuropharmacol. Sep-Oct. 2008;31(5):307-9. Source: PubMed. [pmid: 18836353].
917 Englisch S, Inta D, Eßer A, et al. Bupropion for depression in schizophrenia. Clinical Neuropharmacology. 2010;33(5):257-9. Source: PsycINFO. [pmid: 20852411].
918 Enns MW. Seizure during combination of trimipramine and bupropion. J Clin Psychiatry. Jun. 2001;62(6):476-7. Source: PubMed. [pmid: 11465529].
919 Enns MW, Cox BJ, Levitt AJ, et al. Personality and seasonal affective disorder: results from the CAN-SAD study. J Affect Disord. Jul. 2006;93(1-3):35-42. Source: PubMed. [pmid: 16647139].
920 Entsuah AR, Bradley MM, Littman GS. Cumulative mean change procedure: application to a comparative trial of venlafaxine, imipramine, and placebo in the treatment of major depression. Prog Neuropsychopharmacol Biol Psychiatry. Jul. 1994;18(4):695-706. Source: PubMed. [pmid: 7938560].
921 Entsuah AR, Huang H, Thase ME. Response and remission rates in different subpopulations with major depressive disorder administered venlafaxine, selective serotonin reuptake inhibitors, or placebo. J Clin Psychiatry. Nov. 2001;62(11):869-77. Source: PubMed. [pmid: 11775046].
922 Entsuah AR, Rudolph RL, Chitra R. Effectiveness of venlafaxine treatment in a broad spectrum of depressed patients: a meta-analysis. Psychopharmacol Bull. 1995;31(4):759-66. Source: PubMed. [pmid: 8851650].
923 Entsuah AR, Rudolph RL, Hackett D, et al. Efficacy of venlafaxine and placebo during long-term treatment of depression: a pooled analysis of relapse rates. Int Clin Psychopharmacol. Jun. 1996;11(2):137-45. Source: PubMed. [pmid: 8803651].
924 Entsuah R, Chitra R. A benefit-risk analysis of once-daily venlafaxine extended release (XR) and venlafaxine immediate release (IR) in outpatients with major depression. Psychopharmacol Bull. 1997;33(4):671-6. Source: PubMed. [pmid: 9493478].
925 Entsuah R, Derivan A, Kikta D. Early onset of antidepressant action of venlafaxine: pattern analysis in intent-to-treat patients. Clin Ther. May-Jun. 1998;20(3):517-26. Source: PubMed. [pmid: 9663367].
926 Entsuah R, Gorman JM. Global benefit-risk assessment of antidepressants: venlafaxine XR and fluoxetine. J Psychiatr Res. May-Jun. 2002;36(3):111-8. Source: PubMed. [pmid: 11886688].
927 Eppel AB. Letter to the editor: Agomelatine adjunctive therapy for acute bipolar depression: Preliminary open data. Bipolar Disorders. Sep. 2008. 2008;10(6):749-50. Source: PsycINFO. [pmid: 18837872].
928 Epperson CN, Amin Z, Naftolin F, et al. The resistance to depressive relapse in menopausal women undergoing tryptophan depletion: preliminary findings. J Psychopharmacol. Jun. 2007;21(4):414-20. Source: PubMed. [pmid: 16891341].
929 Ereshefsky L, Dugan D. Review of the pharmacokinetics, pharmacogenetics, and drug interaction potential of antidepressants: focus on venlafaxine. Depress Anxiety. Suppl 1. 2000;12:30-44. Source: PubMed. [pmid: 11098412].
930 Ernst CL, Bird SA, Goldberg JF, et al. The prescription of psychotropic medications for patients discharged from a psychiatric emergency service. Journal of Clinical Psychiatry. 2006;67(5):720-6. Source: EMBASE. [pmid: 16841621].
931 Ersoy MA, Noyan AM, Elbi H. An open-label long-term naturalistic study of mirtazapine treatment for depression in cancer patients. Clin Drug Investig. 2008;28(2):113-20. Source: PubMed.
932 F ES, T ME, W SR, et al. Cognitive Therapy Augmentation versus CT Swith Treatment: A STAR*D Report. International Journal of Cognitive Therapy. 2009;2(1):66-87. Source: Handsearch.
933 Esel E, Ozsoy S, Tutus A, et al. Effects of antidepressant treatment and of gender on serum leptin levels in patients with major depression. Progress in Neuro Psychopharmacology and Biological Psychiatry. 2005;29(4):565-70. Source: EMBASE. [pmid: 15866359].
934 Evans DL, Lynch KG, Benton T, et al. Selective serotonin reuptake inhibitor and substance P antagonist enhancement of natural killer cell innate immunity in human immunodeficiency virus/acquired immunodeficiency syndrome. Biol Psychiatry. May. 1. 2008;63(9):899-905. Source: PubMed. [pmid: 17945197].
935 Evans L, Golshan S, Kelsoe J, et al. Effects of rapid tryptophan depletion on sleep electroencephalogram and mood in subjects with partially remitted depression on bupropion. Neuropsychopharmacology. Dec. 2002;27(6):1016-26. Source: PubMed. [pmid: 12464458].
936 Evans M, Hammond M, Wilson K, et al. Placebo-controlled treatment trial of depression in elderly physically ill patients. Int J Geriatr Psychiatry. Aug. 1997;12(8):817-24. Source: PubMed. [pmid: 9283926].
937 Evans ME. Depression in elderly physically ill in-patients: a 12-month prospective study. Int Clin Psychopharmacol. Winter. 1993;8(4):333-6. Source: PubMed. [pmid: 8277159].
938 Evins AE, Culhane MA, Alpert JE, et al. A controlled trial of bupropion added to nicotine patch and behavioral therapy for smoking cessation in adults with unipolar depressive disorders. J Clin Psychopharmacol. Dec. 2008;28(6):660-6. Source: PubMed. [pmid: 19011435].
939 Extein IL. Recent fluoxetine treatment and complications of tricyclic therapy. Am J Psychiatry. Nov. 1991;148(11):1601-2. Source: PubMed. [pmid: 1928480].
940 Eyding D, Lelgemann M, Grouven U, et al. Reboxetine for acute treatment of major depression: Systematic review and meta-analysis of published and unpublished placebo and selective serotonin reuptake inhibitor controlled trials. Bmj. 2010;341(7777):816. Source: EMBASE.
941 Fabian TJ, Amico JA, Kroboth PD, et al. Paroxetine-induced hyponatremia in the elderly due to the syndrome of inappropriate secretion of antidiuretic hormone (SIADH). J Geriatr Psychiatry Neurol. Sep. 2003;16(3):160-4. Source: PubMed. [pmid: 12967059].
942 Fabian TJ, Dew MA, Pollock BG, et al. Endogenous concentrations of DHEA and DHEA-S decrease with remission of depression in older adults. Biol Psychiatry. Nov. 15. 2001;50(10):767-74. Source: PubMed. [pmid: 11720695].
943 Fabre L, Birkhimer LJ, Zaborny BA, et al. Fluvoxamine versus imipramine and placebo: a double-blind comparison in depressed patients. Int Clin Psychopharmacol. Jun. 1996;11(2):119-27. Source: PubMed. [pmid: 8803649].
944 Fabre LF. Trazodone dosing regimen: experience with single daily administration. J Clin Psychiatry. Sep. 1990;51(Suppl):23-6. Source: PubMed. [pmid: 2211561].
945 Fabre LF. A 6-week, double-blind trial of paroxetine, imipramine, and placebo in depressed outpatients. J Clin Psychiatry. Feb. 1992;53(Suppl):40-3. Source: PubMed. [pmid: 1531823].
946 Fabre LF, Abuzzahab FS, Amin M, et al. Sertraline safety and efficacy in major depression: a double-blind fixed-dose comparison with placebo. Biol Psychiatry. Nov. 1. 1995;38(9):592-602. Source: PubMed. [pmid: 8573661].
947 Fabre LF, Brodie HK, Garver D, et al. A multicenter evaluation of bupropion versus placebo in hospitalized depressed patients. J Clin Psychiatry. May. 1983;44(5 Pt 2):88-94. Source: PubMed. [pmid: 6406472].
948 Fabre LF, Putman HP 3rd. A fixed-dose clinical trial of fluoxetine in outpatients with major depression. J Clin Psychiatry. Oct. 1987;48(10):406-8. Source: PubMed. [pmid: 3312176].
949 Fabre LF, Scharf MB, Itil TM. Comparative efficacy and safety of nortriptyline and fluoxetine in the treatment of major depression: a clinical study. J Clin Psychiatry. Jun. 1991;52(Suppl):62-7. Source: PubMed. [pmid: 2050651].
950 Fagiolini A, Buysse DJ, Frank E, et al. Tolerability of combined treatment with lithium and paroxetine in patients with bipolar disorder and depression. J Clin Psychopharmacol. Oct. 2001;21(5):474-8. Source: PubMed. [pmid: 11593071].
951 Fairweather DB, Kerr JS, Harrison DA, et al. A double blind comparison of the effects of fluoxetine and amitriptyline on cognitive function in elderly depressed patients. Hum Psychopharmacol. 1993;8(1):41-7. Source: EMBASE.
952 Fairweather DB, Stanley N, Yoon JS, et al. The effects of fluoxetine and dothiepin on cognitive function in depressed patients in general practice. Hum Psychopharmacol. 1999;14(5):325-32. Source: EMBASE.
953 Faison WE. Recognizing the needs of elderly patients with psychotic symptoms. Consultant Pharmacist. 2006;21(SUPPL. B):6-10. Source: EMBASE.
954 Falcone NP, Nappo A, Neuteboom B. Interferon beta-1a overdose in a multiple sclerosis patient. Ann Pharmacother. Nov. 2005;39(11):1950-2. Source: PubMed. [pmid: 16204396].
955 Falk WE, Rosenbaum JF, Otto MW, et al. Fluoxetine versus trazodone in depressed geriatric patients. J Geriatr Psychiatry Neurol. Oct-Dec. 1989;2(4):208-14. Source: PubMed. [pmid: 2699556].
956 Falkai P. Mirtazapine: other indications. J Clin Psychiatry. Suppl 17. 1999;60:36-40. discussion 6-8. Source: PubMed. [pmid: 10446741].
957 Fang Y, Yuan C, Xu Y, et al. Comparisons of the efficacy and tolerability of extended-release venlafaxine, mirtazapine, and paroxetine in treatment-resistant depression: a double-blind, randomized pilot study in a Chinese population. J Clin Psychopharmacol. 2010;30(4):357-64. Source: PubMed. [pmid: 20571433].
958 Fann JR, Uomoto JM, Katon WJ. Sertraline in the treatment of major depression following mild traumatic brain injury. J Neuropsychiatry Clin Neurosci. Spring. 2000;12(2):226-32. Source: PubMed. [pmid: 11001601].
959 Fantino B, Moore N, Verdoux H, et al. Cost-effectiveness of escitalopram vs. citalopram in major depressive disorder. Int Clin Psychopharmacol. Mar. 2007;22(2):107-15. Source: PubMed. [pmid: 17293711].
960 Farabaugh A, Mischoulon D, Fava M, et al. The relationship between early changes in the HAMD-17 anxiety/somatization factor items and treatment outcome among depressed outpatients. Int Clin Psychopharmacol. Mar. 2005;20(2):87-91. Source: PubMed. [pmid: 15729083].
961 Farabaugh A, Mischoulon D, Schwartz F, et al. Dysfunctional attitudes and personality disorder comorbidity during long-term treatment of MDD. Depress Anxiety. 2007;24(6):433-9. Source: PubMed. [pmid: 17086540].
962 Farabaugh AH, Bitran S, Witte J, et al. Anxious depression and early changes in the HAMD-17 anxiety-somatization factor items and antidepressant treatment outcome. International Clinical Psychopharmacology. 2010;25(4):214-7. Source: EMBASE. [pmid: 20400905].
963 Farah A. The role of L-methylfolate in depressive disorders. Primary Psychiatry. Jan. 2009. 2009;16(1):1-7. Source: PsycINFO.
964 Farah A. ‘The role of L-methylfolate in depressive disorders’: Erratum. Primary Psychiatry. 2009;16(2):18. Source: PsycINFO.
965 Faramarzi M, Alipor A, Esmaelzadeh S, et al. Treatment of depression and anxiety in infertile women: cognitive behavioral therapy versus fluoxetine. J Affect Disord. 2008;108(1-2):159-64. Source: PubMed. [pmid: 17936366].
966 Farid FF, Wenger TL, Tsai SY, et al. Use of bupropion in patients who exhibit orthostatic hypotension on tricyclic antidepressants. J Clin Psychiatry. May. 1983;44(5 Pt 2):170-3. Source: PubMed. [pmid: 6406451].
967 Fatemi SH, Emamian ES, Kist DA. Venlafaxine and bupropion combination therapy in a case of treatment-resistant depression. Ann Pharmacother. Jun. 1999;33(6):701-3. Source: PubMed. [pmid: 10410184].
968 Fava GA, Ruini C, Sonino N. Management of recurrent depression in primary care. Psychother Psychosom. Jan-Feb. 2003;72(1):3-9. Source: PubMed. [pmid: 12466632].
969 Fava M, Alpert J, Nierenberg A, et al. Double-blind study of high-dose fluoxetine versus lithium or desipramine augmentation of fluoxetine in partial responders and nonresponders to fluoxetine. J Clin Psychopharmacol. Aug. 2002;22(4):379-87. Source: PubMed. [pmid: 12172337].
970 Fava M, Alpert J, Nierenberg AA, et al. Fluoxetine treatment of anger attacks: a replication study. Ann Clin Psychiatry. Mar. 1996;8(1):7-10. Source: PubMed. [pmid: 8743642].
971 Fava M, Alpert J, Nierenberg AA, et al. A Double-blind, randomized trial of St John's wort, fluoxetine, and placebo in major depressive disorder. J Clin Psychopharmacol. Oct. 2005;25(5):441-7. Source: PubMed. [pmid: 16160619].
972 Fava M, Alpert JE, Carmin CN, et al. Clinical correlates and symptom patterns of anxious depression among patients with major depressive disorder in STAR*D. Psychol Med. Oct. 2004;34(7):1299-308. Source: PubMed. [pmid: 15697056].
973 Fava M, Amsterdam JD, Deltito JA, et al. A double-blind study of paroxetine, fluoxetine, and placebo in outpatients with major depression. Ann Clin Psychiatry. Dec. 1998;10(4):145-50. Source: PubMed. [pmid: 9988054].
974 Fava M, Bless E, Otto MW, et al. Dysfunctional attitudes in major depression. Changes with pharmacotherapy. J Nerv Ment Dis. Jan. 1994;182(1):45-9. Source: PubMed. [pmid: 8277301].
975 Fava M, Detke MJ, Balestrieri M, et al. Management of depression relapse: reinitiation of duloxetine treatment or dose increase. J Psychiatr Res. 2006;40(4):328-36. Source: PubMed. [pmid: 16678205].
976 Fava M, Dunner DL, Greist JH, et al. Efficacy and safety of mirtazapine in major depressive disorder patients after SSRI treatment failure: an open-label trial. J Clin Psychiatry. Jun. 2001;62(6):413-20. Source: PubMed. [pmid: 11465517].
977 Fava M, Graves LM, Benazzi F, et al. A cross-sectional study of the prevalence of cognitive and physical symptoms during long-term antidepressant treatment. Journal of Clinical Psychiatry. 2006;67(11):1754-9. Source: EMBASE. [pmid: 17196056].
978 Fava M, Hoog SL, Judge RA, et al. Acute efficacy of fluoxetine versus sertraline and paroxetine in major depressive disorder including effects of baseline insomnia. J Clin Psychopharmacol. Apr. 2002;22(2):137-47. Source: PubMed. [pmid: 11910258].
979 Fava M, Judge R, Hoog SL, et al. Fluoxetine versus sertraline and paroxetine in major depressive disorder: changes in weight with long-term treatment. J Clin Psychiatry. Nov. 2000;61(11):863-7. Source: PubMed. [pmid: 11105740].
980 Fava M, Labbate LA, Abraham ME, et al. Hypothyroidism and hyperthyroidism in major depression revisited. J Clin Psychiatry. May. 1995;56(5):186-92. Source: PubMed. [pmid: 7737957].
981 Fava M, Mallinckrodt CH, Detke MJ, et al. The effect of duloxetine on painful physical symptoms in depressed patients: do improvements in these symptoms result in higher remission rates. J Clin Psychiatry. Apr. 2004;65(4):521-30. Source: PubMed. [pmid: 15119915].
982 Fava M, Martinez JM, Greist J, et al. The efficacy and tolerability of duloxetine in the treatment of anxious versus non-anxious depression: a post-hoc analysis of an open-label outpatient study. Ann Clin Psychiatry. Jul-Sep. 2007;19(3):187-95. Source: PubMed. [pmid: 17729021].
983 Fava M, McCall WV, Krystal A, et al. Eszopiclone co-administered with fluoxetine in patients with insomnia coexisting with major depressive disorder. Biol Psychiatry. 2006;59(11):1052-60. Source: PubMed. [pmid: 16581036].
984 Fava M, McGrath PJ, Sheu WP. Switching to reboxetine: an efficacy and safety study in patients with major depressive disorder unresponsive to fluoxetine. J Clin Psychopharmacol. Aug. 2003;23(4):365-9. Source: PubMed. [pmid: 12920412].
985 Fava M, Mulroy R, Alpert J, et al. Emergence of adverse events following discontinuation of treatment with extended-release venlafaxine. Am J Psychiatry. Dec. 1997;154(12):1760-2. Source: PubMed. [pmid: 9396960].
986 Fava M, Nierenberg AA, Quitkin FM, et al. A preliminary study on the efficacy of sertraline and imipramine on anger attacks in atypical depression and dysthymia. Psychopharmacol Bull. 1997;33(1):101-3. Source: PubMed. [pmid: 9133758].
987 Fava M, Nurnberg HG, Seidman SN, et al. Efficacy and safety of sildenafil in men with serotonergic antidepressant-associated erectile dysfunction: Results from a randomized, double-blind, placebo-controlled trial. Journal of Clinical Psychiatry. 2006;67(2):240-6. Source: EMBASE. [pmid: 16566619].
988 Fava M, Papakostas GI, Petersen T, et al. Switching to bupropion in fluoxetine-resistant major depressive disorder. Ann Clin Psychiatry. Mar. 2003;15(1):17-22. Source: PubMed. [pmid: 12839429].
989 Fava M, Rappe SM, Pava JA, et al. Relapse in patients on long-term fluoxetine treatment: response to increased fluoxetine dose. J Clin Psychiatry. Feb. 1995;56(2):52-5. Source: PubMed. [pmid: 7852252].
990 Fava M, Rosenbaum JF, Hoog SL, et al. Fluoxetine versus sertraline and paroxetine in major depression: tolerability and efficacy in anxious depression. J Affect Disord. Aug. 2000;59(2):119-26. Source: PubMed. [pmid: 10837880].
991 Fava M, Rosenbaum JF, McCarthy M, et al. Anger attacks in depressed outpatients and their response to fluoxetine. Psychopharmacol Bull. 1991;27(3):275-9. Source: PubMed. [pmid: 1775598].
992 Fava M, Rosenbaum JF, McGrath PJ, et al. Lithium and tricyclic augmentation of fluoxetine treatment for resistant major depression: a double-blind, controlled study. Am J Psychiatry. Sep. 1994;151(9):1372-4. Source: PubMed. [pmid: 8067495].
993 Fava M, Rush AJ. Current status of augmentation and combination treatments for major depressive disorder: a literature review and a proposal for a novel approach to improve practice. Psychother Psychosom. 2006;75(3):139-53. Source: PubMed. [pmid: 16636629].
994 Fava M, Rush AJ, Alpert JE, et al. Difference in treatment outcome in outpatients with anxious versus nonanxious depression: a STAR*D report. Am J Psychiatry. 2008;165(3):342-51. Source: PubMed. [pmid: 18172020].
995 Fava M, Rush AJ, Alpert JE, et al. What clinical and symptom features and comorbid disorders characterize outpatients with anxious major depressive disorder: a replication and extension. Can J Psychiatry. Nov. 2006;51(13):823-35. Source: PubMed. [pmid: 17195602].
996 Fava M, Rush AJ, Thase ME, et al. 15 Years of clinical experience with bupropion HCl: From bupropion to bupropion SR to bupropion XL. Primary Care Companion to the Journal of Clinical Psychiatry. 2005;7(3):106-13. Source: Scopus.
997 Fava M, Rush AJ, Trivedi MH, et al. Background and rationale for the sequenced treatment alternatives to relieve depression (STAR*D) study. Psychiatr Clin North Am. Jun. 2003;26(2):457-94. x. Source: PubMed. [pmid: 12778843].
998 Fava M, Rush AJ, Wisniewski SR, et al. A comparison of mirtazapine and nortriptyline following two consecutive failed medication treatments for depressed outpatients: a STAR*D report. Am J Psychiatry. 2006;163(7):1161-72. Source: PubMed. [pmid: 16816220].
999 Fava M, Schmidt ME, Zhang S, et al. Treatment approaches to major depressive disorder relapse. Part 2: reinitiation of antidepressant treatment. Psychother Psychosom. Jul-Aug. 2002;71(4):195-9. Source: PubMed. [pmid: 12097784].
1000 Fava M, Uebelacker LA, Alpert JE, et al. Major depressive subtypes and treatment response. Biol Psychiatry. Oct. 1. 1997;42(7):568-76. Source: PubMed. [pmid: 9376453].
1001 Fava M, Wiltse C, Walker D, et al. Predictors of relapse in a study of duloxetine treatment in patients with major depressive disorder. J Affect Disord. 2009;113(3):263-71. Source: PubMed. [pmid: 18625521].
1002 Fawcett J, Barkin RL. A meta-analysis of eight randomized, double-blind, controlled clinical trials of mirtazapine for the treatment of patients with major depression and symptoms of anxiety. J Clin Psychiatry. Mar. 1998;59(3):123-7. Source: PubMed. [pmid: 9541155].
1003 Fawcett J, Barkin RL. Review of the results from clinical studies on the efficacy, safety and tolerability of mirtazapine for the treatment of patients with major depression. J Affect Disord. Dec. 1998;51(3):267-85. Source: PubMed. [pmid: 10333982].
1004 Fawcett J, Marcus RN, Anton SF, et al. Response of anxiety and agitation symptoms during nefazodone treatment of major depression. J Clin Psychiatry. 1995;56(Suppl):637-42. Source: PubMed.
1005 FDA Center for Drug Evaluation and Research. Stastical Review of NDA 21-323 (Escitalopram Oxalate). http://www.fda.gov/cder/foi/nda/2002/21-323.pdf_Lexapro_Statr.pdf. 2001. Source: Handsearch.
1006 Feder R. Reversal of antidepressant activity of fluoxetine by cyproheptadine in three patients. J Clin Psychiatry. Apr. 1991;52(4):163-4. Source: PubMed. [pmid: 2016249].
1007 Feiger A, Kiev A, Shrivastava RK, et al. Nefazodone versus sertraline in outpatients with major depression: focus on efficacy, tolerability, and effects on sexual function and satisfaction. J Clin Psychiatry. Suppl 2. 1996;57:53-62. Source: PubMed. [pmid: 8626364].
1008 Feiger AD, Bielski RJ, Bremner J, et al. Double-blind, placebo-substitution study of nefazodone in the prevention of relapse during continuation treatment of outpatients with major depression. Int Clin Psychopharmacol. Jan. 1999;14(1):19-28. Source: PubMed. [pmid: 10221638].
1009 Feiger AD, Flament MF, Boyer P, et al. Sertraline versus fluoxetine in the treatment of major depression: a combined analysis of five double-blind comparator studies. Int Clin Psychopharmacol. Jul. 2003;18(4):203-10. Source: PubMed. [pmid: 12817154].
1010 Feiger AD, Tourian KA, Rosas GR, et al. A placebo-controlled study evaluating the efficacy and safety of flexible-dose desvenlafaxine treatment in outpatients with major depressive disorder. CNS Spectr. 2009;14(1):41-50. Source: PubMed. [pmid: 19169187].
1011 Feighner J, Hendrickson G, Miller L, et al. Double-blind comparison of doxepin versus bupropion in outpatients with a major depressive disorder. J Clin Psychopharmacol. Feb. 1986;6(1):27-32. Source: PubMed. [pmid: 3081600].
1012 Feighner J, Targum SD, Bennett ME, et al. A double-blind, placebo-controlled trial of nefazodone in the treatment of patients hospitalized for major depression. J Clin Psychiatry. May. 1998;59(5):246-53. Source: PubMed. [pmid: 9632036].
1013 Feighner JP. Trazodone in major affective disorders. Psychopathology. Suppl 2. 1984;17:15-23. Source: PubMed. [pmid: 6425917].
1014 Feighner JP. A comparative trial of fluoxetine and amitriptyline in patients with major depressive disorder. J Clin Psychiatry. Sep. 1985;46(9):369-72. Source: PubMed. [pmid: 3897204].
1015 Feighner JP. A double-blind comparison of paroxetine, imipramine and placebo in depressed outpatients. Int Clin Psychopharmacol. Jun. Suppl 4. 1992;6:31-5. Source: PubMed. [pmid: 1431008].
1016 Feighner JP. The role of venlafaxine in rational antidepressant therapy. J Clin Psychiatry. Sep. Suppl A. 1994;55:62-8. discussion 9-70, 98-100. Source: PubMed. [pmid: 7961545].
1017 Feighner JP. Overview of antidepressants currently used to treat anxiety disorders. J Clin Psychiatry. Suppl 22. 1999;60:18-22. Source: PubMed. [pmid: 10634351].
1018 Feighner JP, Boyer WF. Paroxetine in the treatment of depression: a comparison with imipramine and placebo. J Clin Psychiatry. Feb. 1992;53(Suppl):44-7. Source: PubMed. [pmid: 1531824].
1019 Feighner JP, Boyer WF, Meredith CH, et al. An overview of fluoxetine in geriatric depression. Br J Psychiatry Suppl. Sep. 1988;(3):105-8. Source: PubMed. [pmid: 3074861].
1020 Feighner JP, Boyer WF, Merideth CH, et al. A double-blind comparison of fluoxetine, imipramine and placebo in outpatients with major depression. Int Clin Psychopharmacol. Apr. 1989;4(2):127-34. Source: PubMed. [pmid: 2663975].
1021 Feighner JP, Boyer WF, Tyler DL, et al. Adverse consequences of fluoxetine-MAOI combination therapy. J Clin Psychiatry. Jun. 1990;51(6):222-5. Source: PubMed. [pmid: 2347858].
1022 Feighner JP, Cohn JB. Double-blind comparative trials of fluoxetine and doxepin in geriatric patients with major depressive disorder. J Clin Psychiatry. Mar. 1985;46(3 Pt 2):20-5. Source: PubMed. [pmid: 3882676].
1023 Feighner JP, Cohn JB, Fabre LF Jr, et al. A study comparing paroxetine placebo and imipramine in depressed patients. J Affect Disord. Jun. 1993;28(2):71-9. Source: PubMed. [pmid: 8354771].
1024 Feighner JP, Entsuah AR, McPherson MK. Efficacy of once-daily venlafaxine extended release (XR) for symptoms of anxiety in depressed outpatients. J Affect Disord. Jan. 1998;47(1-3):55-62. Source: PubMed. [pmid: 9476744].
1025 Feighner JP, Gardner EA, Johnston JA, et al. Double-blind comparison of bupropion and fluoxetine in depressed outpatients. J Clin Psychiatry. Aug. 1991;52(8):329-35. Source: PubMed. [pmid: 1907963].
1026 Feighner JP, Meredith CH, Stern WC, et al. A double-blind study of bupropion and placebo in depression. Am J Psychiatry. Apr. 1984;141(4):525-9. Source: PubMed. [pmid: 6422779].
1027 Feighner JP, Merideth CH, Hendrickson G. Maintenance antidepressant therapy: A double-blind comparison of trazodone and imipramine. Journal Of Clinical Psychopharmacology. 1981;1(Suppl 6):45S-8S. Source: EMBASE.
1028 Feighner JP, Overo K. Multicenter, placebo-controlled, fixed-dose study of citalopram in moderate-to-severe depression. J Clin Psychiatry. Dec. 1999;60(12):824-30. Source: PubMed. [pmid: 10665628].
1029 Feighner JP, Pambakian R, Fowler RC, et al. A comparison of nefazodone, imipramine, and placebo in patients with moderate to severe depression. Psychopharmacol Bull. 1989;25(2):219-21. Source: PubMed. [pmid: 2690165].
1030 Feinstein RE, Blumenfield M, Orlowski B, et al. A national survey of cardiovascular physicians' beliefs and clinical care practices when diagnosing and treating depression in patients with cardiovascular disease. Cardiology in Review. 2006;14(4):164-9. Source: Scopus. [pmid: 16788327].
1031 Feldmann HS, Denber HC. Long-term study of fluvoxamine: a new rapid-acting antidepressant. Int Pharmacopsychiatry. 1982;17(2):114-22. Source: PubMed. [pmid: 6809683].
1032 Feng Y, Pollock BG, Ferrell RE, et al. Paroxetine: population pharmacokinetic analysis in late-life depression using sparse concentration sampling. Br J Clin Pharmacol. May. 2006;61(5):558-69. Source: PubMed. [pmid: 16669849].
1033 Ferentinos P, Rizos E, Christodoulou C, et al. Multiple pulmonary thromboembolism and severe depression. General Hospital Psychiatry. 2010;32(5):560.e5-.e7. Source: EMBASE. [pmid: 20851284].
1034 Ferguson J, Cunningham L, Merideth C, et al. Bupropion in tricyclic antidepressant nonresponders with unipolar major depressive disorder. Ann Clin Psychiatry. Sep. 1994;6(3):153-60. Source: PubMed. [pmid: 7881495].
1035 Ferguson JM. The effects of antidepressants on sexual functioning in depressed patients: a review. J Clin Psychiatry. Suppl 3. 2001;62:22-34. Source: PubMed. [pmid: 11229450].
1036 Ferguson JM, Shrivastava RK, Stahl SM, et al. Reemergence of sexual dysfunction in patients with major depressive disorder: double-blind comparison of nefazodone and sertraline. J Clin Psychiatry. Jan. 2001;62(1):24-9. Source: PubMed. [pmid: 11235924].
1037 Ferguson JM, Wesnes KA, Schwartz GE. Reboxetine versus paroxetine versus placebo: effects on cognitive functioning in depressed patients. Int Clin Psychopharmacol. Jan. 2003;18(1):9-14. Source: PubMed. [pmid: 12490769].
1038 Fergusson D, Doucette S, Glass KC, et al. Association between suicide attempts and selective serotonin reuptake inhibitors: systematic review of randomised controlled trials. Bmj. Feb. 19. 2005;330(7488):396. Source: PubMed. [pmid: 15718539].
1039 Fernandez JL, Montgomery S, Francois C. Evaluation of the cost effectiveness of escitalopram versus venlafaxine XR in major depressive disorder. Pharmacoeconomics. 2005;23(2):155-67. Source: PubMed. [pmid: 15748090].
1040 Ferrando SJ, Goldman JD, Charness WE. Selective serotonin reuptake inhibitor treatment of depression in symptomatic HIV infection and AIDS. Improvements in affective and somatic symptoms. Gen Hosp Psychiatry. Mar. 1997;19(2):89-97. Source: PubMed. [pmid: 9097063].
1041 Ferreira ADA, Neves FS, Pimenta GJGS, et al. The role of genetic variation of BDNF gene in antidepressant-induced mania in bipolar disorder. Psychiatry Research. 2010;180(1):54-6. Source: EMBASE. [pmid: 20483468].
1042 Ferreri M. Fluoxetine versus amineptine in the treatment of outpatients with major depressive disorders. Int Clin Psychopharmacol. Jan. Suppl 1. 1989;4:97-101. Source: PubMed. [pmid: 2644344].
1043 Ferreri M, Lavergne F, Berlin I, et al. Benefits from mianserin augmentation of fluoxetine in patients with major depression non-responders to fluoxetine alone. Acta Psychiatr Scand. Jan. 2001;103(1):66-72. Source: PubMed. [pmid: 11202131].
1044 Feth N, Cattapan-Ludewig K, Sirot EJ. Electric Sensations: Neglected Symptom of Escitalopram Discontinuation. The American Journal of Psychiatry. Jan. 2006. 2006;163(1):160. Source: PsycINFO. [pmid: 16390910].
1045 Fichtner CG, Jobe TH, Braun BG. Does fluoxetine have a therapeutic window?. Lancet. Aug. 24. 1991;338(8765):520-1. Source: PubMed. [pmid: 1678484].
1046 Fichtner CG, O'Connor FL, Yeoh HC, et al. Hypodensity of platelet serotonin uptake sites in posttraumatic stress disorder: associated clinical features. Life Sci. 1995;57(2):PL37-44. Source: PubMed. [pmid: 7603291].
1047 Fiedorowicz JG, Hale N, Spector AA, et al. Neuroticism but not omega-3 fatty acid levels correlate with early responsiveness to escitalopram. Ann Clin Psychiatry. Aug. 2010;22(3):157-63. Source: PubMed. [pmid: 20680188].
1048 Fiedorowicz JG, Takezawa K, Robinson RG. Risk factors for and correlates of poststroke depression following discontinuation of antidepressants. J Neuropsychiatry Clin Neurosci. Fall. 2007;19(4):399-405. Source: PubMed. [pmid: 18070842].
1049 Fieve RR, Goodnick PJ, Peselow E, et al. Fluoxetine response: endpoint vs pattern analysis. Int Clin Psychopharmacol. Oct. 1986;1(4):320-3. Source: PubMed. [pmid: 3549877].
1050 Fieve RR, Goodnick PJ, Peselow ED, et al. Pattern analysis of antidepressant response to fluoxetine. J Clin Psychiatry. Nov. 1986;47(11):560-2. Source: PubMed. [pmid: 3533909].
1051 Figueras G, Perez V, San Martino O, et al. Pretreatment platelet 5-HT concentration predicts the short-term response to paroxetine in major depression. Grupo de Trastornos Afectivos. Biol Psychiatry. Aug. 15. 1999;46(4):518-24. Source: PubMed. [pmid: 10459402].
1052 Filipcic I, Margetic B, Simunovic I, et al. Depression treatment and its impact upon the quality of life in patients with diabetes type 2 - the Croatian study. Psychiatr Danub. Jun. 2010;22(2):231-5. Source: PubMed. [pmid: 20562752].
1053 Filipčić I, Margetić B, Šimunović I, et al. Depression treatment and its impact upon the quality of life in patients with diabetes type 2—The Croatian study. Psychiatria Danubina. 2010;22(2):231-5. Source: PsycINFO. [pmid: 20562752].
1054 Finch SJ, van Zyl LT. Cardioversion of persistent atrial arrhythmia after treatment with venlafaxine in successful management of major depression and posttraumatic stress disorder. Psychosomatics. Nov-Dec. 2006;47(6):533-6. Source: PubMed. [pmid: 17116959].
1055 Findling RL, Johnson JL, McClellan J, et al. Double-Blind Maintenance Safety and Effectiveness Findings From the Treatment of Early-Onset Schizophrenia Spectrum (TEOSS) Study. Journal of the American Academy of Child and Adolescent Psychiatry. 2010;49(6):583-94. Source: EMBASE. [pmid: 20494268].
1056 Findling RL, Pagano ME, McNamara NK, et al. The short-term safety and efficacy of fluoxetine in depressed adolescents with alcohol and cannabis use disorders: A pilot randomized placebo-controlled trial. Child and Adolescent Psychiatry and Mental Health. 2009;3. Source: Handsearch.
1057 Findling RL, Preskorn SH, Marcus RN, et al. Nefazodone pharmacokinetics in depressed children and adolescents. J Am Acad Child Adolesc Psychiatry. Aug. 2000;39(8):1008-16. Source: PubMed. [pmid: 10939229].
1058 Finfgeld DL. SSRI-related hyponatremia among aging adults. J Psychosoc Nurs Ment Health Serv. Apr. 2003;41(4):12-6. Source: PubMed. [pmid: 12698818].
1059 Finfgeld DL. Serotonin syndrome and the use of SSRIs. J Psychosoc Nurs Ment Health Serv. Feb. 2004;42(2):16-20. Source: PubMed. [pmid: 14982105].
1060 Finkel SI, Richter EM, Clary CM. Comparative efficacy and safety of sertraline versus nortriptyline in major depression in patients 70 and older. Int Psychogeriatr. Mar. 1999;11(1):85-99. Source: PubMed. [pmid: 10189602].
1061 Finkel SI, Richter EM, Clary CM, et al. Comparative efficacy of sertraline vs. fluoxetine in patients age 70 or over with major depression. Am J Geriatr Psychiatry. Summer. 1999;7(3):221-7. Source: PubMed. [pmid: 10438693].
1062 Finkelstein SN, Berndt ER, Greenberg PE, et al. Improvement in subjective work performance after treatment of chronic depression: Some preliminary results. Psychopharmacology Bulletin (Berl). 1996;32(1):33-40. Source: EMBASE.
1063 Finnegan KT, Gabiola JM. Fluoxetine overdose. Am J Psychiatry. Dec. 1988;145(12):1604. Source: PubMed. [pmid: 3264119].
1064 Fisar Z, Kalisova L, Paclt I, et al. Platelet serotonin uptake in drug-naive depressive patients before and after treatment with citalopram. Psychiatry Res. Nov. 30. 2008;161(2):185-94. Source: PubMed. [pmid: 18817980].
1065 Fisch C, Knoebel SB. Electrocardiographic findings in sertraline depression trials. Drug Invest. 1992;4(4):305-12. Source: EMBASE.
1066 Fisch MJ, Loehrer PJ, Kristeller J, et al. Fluoxetine versus placebo in advanced cancer outpatients: a double-blinded trial of the Hoosier Oncology Group. J Clin Oncol. 2003;21(10):1937-43. Source: PubMed. [pmid: 12743146].
1067 Fisfalen ME, Hsiung RC. Glucose dysregulation and mirtazapine-induced weight gain. Am J Psychiatry. Apr. 2003;160(4):797. Source: PubMed. [pmid: 12668379].
1068 Fisher AA, Davis MW. Serotonin syndrome caused by selective serotonin reuptake-inhibitors-metoclopramide interaction. Ann Pharmacother. Jan. 2002;36(1):67-71. Source: PubMed. [pmid: 11816261].
1069 Fiss T, Dreier A, Meinke C, et al. Frequency of inappropriate drugs in primary care: Analysis of a sample of immobile patients who received periodic home visits. Age and Ageing. 2011;40(1):66-73. Source: EMBASE. [pmid: 20823125].
1070 Flament MF, Lane R. Acute antidepressant response to fluoxetine and sertraline in psychiatric outpatients with psychomotor agitation. International Journal of Psychiatry in Clinical Practice. 2001;5(2):103-9. Source: EMBASE.
1071 Flament MF, Lane RM, Zhu R, et al. Predictors of an acute antidepressant response to fluoxetine and sertraline. Int Clin Psychopharmacol. Sep. 1999;14(5):259-75. Source: PubMed. [pmid: 10529069].
1072 Flint AJ. Treatment of late-onset agoraphobia secondary to depression. Can J Psychiatry. Nov. 1995;40(9):568. Source: PubMed. [pmid: 8574994].
1073 Flint AJ, Crosby J, Genik JL. Recurrent hyponatremia associated with fluoxetine and paroxetine. Am J Psychiatry. Jan. 1996;153(1):134. Source: PubMed. [pmid: 8540575].
1074 Flint AJ, Rifat SL. A prospective study of lithium augmentation in antidepressant-resistant geriatric depression. J Clin Psychopharmacol. Oct. 1994;14(5):353-6. Source: PubMed. [pmid: 7806693].
1075 Flint AJ, Rifat SL. The effect of sequential antidepressant treatment on geriatric depression. J Affect Disord. Jan. 22. 1996;36(3-4):95-105. Source: PubMed. [pmid: 8821312].
1076 Flint AJ, Rifat SL. Anxious depression in elderly patients. Response to antidepressant treatment. Am J Geriatr Psychiatry. Spring. 1997;5(2):107-15. Source: PubMed. [pmid: 9106374].
1077 Flint AJ, Rifat SL. Two-year outcome of elderly patients with anxious depression. Psychiatry Res. Jan. 15. 1997;66(1):23-31. Source: PubMed. [pmid: 9061801].
1078 Flint AJ, Rifat SL. Maintenance treatment for recurrent depression in late life. A four-year outcome study. Am J Geriatr Psychiatry. Spring. 2000;8(2):112-6. Source: PubMed. [pmid: 10804071].
1079 Flock A, Zobel A, Bauriedel G, et al. Antiplatelet effects of antidepressant treatment: A randomized comparison between escitalopram and nortriptyline. Thrombosis Research. 2010;126(2):e83-e7. Source: EMBASE. [pmid: 20553948].
1080 Folkerts H. Spontaneous seizure after concurrent use of methohexital anesthesia for electroconvulsive therapy and paroxetine: a case report. J Nerv Ment Dis. Feb. 1995;183(2):115-6. Source: PubMed. [pmid: 7844577].
1081 Folkerts HW, Michael N, Tolle R, et al. Electroconvulsive therapy vs. paroxetine in treatment-resistant depression -- a randomized study. Acta Psychiatr Scand. Nov. 1997;96(5):334-42. Source: PubMed. [pmid: 9395150].
1082 Fontaine R, Ontiveros A, Elie R, et al. A double-blind comparison of nefazodone, imipramine, and placebo in major depression. J Clin Psychiatry. Jun. 1994;55(6):234-41. Source: PubMed. [pmid: 8071277].
1083 Fontaine R, Ontiveros A, Elie R, et al. Lithium carbonate augmentation of desipramine and fluoxetine in refractory depression. Biol Psychiatry. May. 1. 1991;29(9):946-8. Source: PubMed. [pmid: 1904782].
1084 Ford AH, Flicker L, McCaul K, et al. The B-VITAGE trial: A randomized trial of homocysteine lowering treatment of depression in later life. Trials. 2010;11. Source: EMBASE.
1085 Ford HE, Jenike MA. Erythema multiforme associated with trazodone therapy: case report. J Clin Psychiatry. Jul. 1985;46(7):294-5. Source: PubMed. [pmid: 4008456].
1086 Forder J, Kavanagh S, Fenyo A. A comparison of the cost-effectiveness of sertraline versus tricyclic antidepressants in primary care. J Affect Disord. Jun. 5. 1996;38(2-3):97-111. Source: PubMed. [pmid: 8791179].
1087 Forlenza OV, Almeida OP, Stoppe A Jr, et al. Antidepressant efficacy and safety of low-dose sertraline and standard-dose imipramine for the treatment of depression in older adults: results from a double-blind, randomized, controlled clinical trial. Int Psychogeriatr. Mar. 2001;13(1):75-84. Source: PubMed. [pmid: 11352337].
1088 Fountoulakis KN, Iacovides A, Karamouzis M, et al. Is it possible to predict the long-term response to venlafaxine with the use of biological markers and psychophysiological methods?. J Affect Disord. Apr. 2007;99(1-3):155-63. Source: PubMed. [pmid: 17049998].
1089 Fountoulakis KN, Samolis S, Iacovides A, et al. Ecchymoses as an adverse effect of fluoxetine treatment. Psychiatry Res. Jul. 30. 2007;152(1):91-2. Source: PubMed. [pmid: 17445912].
1090 Fournier JP, Lane RM, Chouinard G, et al. A double-blind comparison of sertraline and imipramine in outpatients with major depression: Acute (8 weeks) and continuation (16 weeks) treatment. Hum Psychopharmacol. 1997;12(3):203-15. Source: EMBASE.
1091 Fragoso YD, Frota ERC, Lopes JS, et al. Severe depression, suicide attempts, and ideation during the use of interferon beta by patients with multiple sclerosis. Clinical Neuropharmacology. 2010;33(6):312-6. Source: EMBASE. [pmid: 21079457].
1092 Fraguas R Jr, Iosifescu DV, Alpert J, et al. Major depressive disorder and comorbid cardiac disease: is there a depressive subtype with greater cardiovascular morbidity? Results from the STAR*D study. Psychosomatics. Sep-Oct. 2007;48(5):418-25. Source: PubMed. [pmid: 17878501].
1093 Fraile P, Garcia-Cosmes P, Garcia T, et al. Hypotension, as consequence of the interaction between tacrolimus and mirtazapine, in a patient with renal transplant. Nephrol Dial Transplant. 2009;24(6):1999-2001. Source: PubMed. [pmid: 19332869].
1094 Frampton JE, Plosker GL. Duloxetine: a review of its use in the treatment of major depressive disorder. CNS Drugs. 2007;21(7):581-609. Source: PubMed. [pmid: 17579500].
1095 Franchini L, Bongiorno F, Spagnolo C, et al. Psychoeducational Group Intervention in Addition to Antidepressant Therapy As Relapse Preventive Strategy in Unipolar Patients. Clinical Neuropsychiatry: Journal of Treatment Evaluation. Aug. 2006. 2006;3(4):282-5. Source: PsycINFO.
1096 Franchini L, Gasperini M, Perez J, et al. A double-blind study of long-term treatment with sertraline or fluvoxamine for prevention of highly recurrent unipolar depression. J Clin Psychiatry. Mar. 1997;58(3):104-7. Source: PubMed. [pmid: 9108811].
1097 Franchini L, Gasperini M, Perez J, et al. Dose-response efficacy of paroxetine in preventing depressive recurrences: a randomized, double-blind study. J Clin Psychiatry. May. 1998;59(5):229-32. Source: PubMed. [pmid: 9632032].
1098 Franchini L, Gasperini M, Smeraldi E. A 24-month follow-up study of unipolar subjects: a comparison between lithium and fluvoxamine. J Affect Disord. Dec. 1994;32(4):225-31. Source: PubMed. [pmid: 7897085].
1099 Franchini L, Gasperini M, Zanardi R, et al. Four-year follow-up study of sertraline and fluvoxamine in long-term treatment of unipolar subjects with high recurrence rate. J Affect Disord. Jun. 2000;58(3):233-6. Source: PubMed. [pmid: 10802132].
1100 Franchini L, Rossini D, Bongiorno F, et al. Will a second prophylactic treatment with a higher dosage of the same antidepressant either prevent or delay new depressive episodes?. Psychiatry Res. Sep. 25. 2000;96(1):81-5. Source: PubMed. [pmid: 10980329].
1101 Franchini L, Spagnolo C, Rampoldi R, et al. Long-term treatment with citalopram in patients with highly recurrent forms of unipolar depression. Psychiatry Res. Dec. 15. 2001;105(1-2):129-33. Source: PubMed. [pmid: 11740983].
1102 Franchini L, Zanardi R, Gasperini M, et al. Fluvoxamine and lithium in long-term treatment of unipolar subjects with high recurrence rate. J Affect Disord. Apr. 26. 1996;38(1):67-9. Source: PubMed. [pmid: 8735160].
1103 Franchini L, Zanardi R, Gasperini M, et al. Two-year maintenance treatment with citalopram, 20 mg, in unipolar subjects with high recurrence rate. J Clin Psychiatry. Dec. 1999;60(12):861-5. Source: PubMed. [pmid: 10665634].
1104 Franco K, Malhotra S. Poststroke depression. Am J Psychiatry. Apr. 2001;158(4):658-60. Source: PubMed. [pmid: 11282720].
1105 Frank C. Recognition and treatment of serotonin syndrome. Can Fam Physician. Jul. 2008;54(7):988-92. Source: PubMed. [pmid: 18625822].
1106 Frank E, Shear MK, Rucci P, et al. Influence of panic-agoraphobic spectrum symptoms on treatment response in patients with recurrent major depression. Am J Psychiatry. Jul. 2000;157(7):1101-7. Source: PubMed. [pmid: 10873918].
1107 Frank MG, Hendricks SE, Burke WJ, et al. Clinical response augments NK cell activity independent of treatment modality: a randomized double-blind placebo controlled antidepressant trial. Psychol Med. Apr. 2004;34(3):491-8. Source: PubMed. [pmid: 15259834].
1108 Freed E, Goldney R, Lambert T, et al. A double-blind, multicentre study to assess the tolerability and efficacy of paroxetine compared with amitriptyline in the treatment of depressed patients in Australian general practice. Aust N Z J Psychiatry. Jun. 1999;33(3):416-21. Source: PubMed. [pmid: 10442799].
1109 Freeman EW, Rickels K, Sondheimer SJ, et al. Continuous or intermittent dosing with sertraline for patients with severe premenstrual syndrome or premenstrual dysphoric disorder. Am J Psychiatry. Feb. 2004;161(2):343-51. Source: PubMed. [pmid: 14754784].
1110 Freeman EW, Rickels K, Sondheimer SJ, et al. Sertraline versus desipramine in the treatment of premenstrual syndrome: an open-label trial. J Clin Psychiatry. Jan. 1996;57(1):7-11. Source: PubMed. [pmid: 8543554].
1111 Freeman EW, Sondheimer SJ, Polansky M, et al. Predictors of response to sertraline treatment of severe premenstrual syndromes. J Clin Psychiatry. Aug. 2000;61(8):579-84. Source: PubMed. [pmid: 10982201].
1112 Freeman MP. An imperfect literature and evidence-based medicine. J Clin Psychiatry. Mar. 2009;70(3):412-3. Source: PubMed. [pmid: 19317958].
1113 Freeman MP, Nolan PE Jr, Davis MF, et al. Pharmacokinetics of sertraline across pregnancy and postpartum. J Clin Psychopharmacol. Dec. 2008;28(6):646-53. Source: PubMed. [pmid: 19011433].
1114 Fregni F, Santos CM, Myczkowski ML, et al. Repetitive transcranial magnetic stimulation is as effective as fluoxetine in the treatment of depression in patients with Parkinson's disease. J Neurol Neurosurg Psychiatry. Aug. 2004;75(8):1171-4. Source: PubMed. [pmid: 15258224].
1115 Freudenreich O. Exacerbation of idiopathic priapism with risperidone-citalopram combination. J Clin Psychiatry. Mar. 2002;63(3):249-50. Source: PubMed. [pmid: 11926728].
1116 Fric M, Pfuhlmann B, Laux G, et al. The influence of smoking on the serum level of duloxetine. Pharmacopsychiatry. Jul. 2008. 2008;41(4):151-5. Source: PsycINFO. [pmid: 18651344].
1117 Friede M, Henneicke von Zepelin HH, Freudenstein J. Differential therapy of mild to moderate depressive episodes (ICD-10 F 32.0; F 32.1) with St. John's wort. Pharmacopsychiatry. Jul. Suppl 1. 2001;34:S38-41. Source: PubMed. [pmid: 11518073].
1118 Friedman E, Thase M, Kornblith S, et al. The Implementation of Cognitive Therapy in STAR*D. Cognitive Therapy and Research. 2004;28(6):819-33. Source: Handsearch.
1119 Friedman RA, Leon AC. Expanding the black box - depression, antidepressants, and the risk of suicide. New England Journal of Medicine. 2007;356(23):2343-6. Source: PubMed. [pmid: 17485726].
1120 Frye MA. Bipolar disorder - A focus on depression. New England Journal of Medicine. 2011;364(1):51-9. Source: EMBASE. [pmid: 21208108].
1121 Fu WB, Fan L, Zhu XP, et al. Depressive neurosis treated by acupuncture for regulating the liver--a report of 176 cases. J Tradit Chin Med. Jun. 2009;29(2):83-6. Source: PubMed. [pmid: 19663089].
1122 Fukuchi T, Kanemoto K. Differential effects of milnacipran and fluvoxamine, especially in patients with severe depression and agitated depression: a case-control study. Int Clin Psychopharmacol. Mar. 2002;17(2):53-8. Source: PubMed. [pmid: 11890186].
1123 Furey ML, Drevets WC. Antidepressant efficacy of the antimuscarinic drug scopolamine: A randomized, placebo-controlled clinical trial. Archives of General Psychiatry. 2006;63(10):1121-9. Source: EMBASE. [pmid: 17015814].
1124 Furukawa TA, Cipriani A, Barbui C, et al. Long-term treatment of depression with antidepressants: A systematic narrative review. The Canadian Journal of Psychiatry. La Revue canadienne de psychiatrie. 2007;52(9):545-52. Source: PsycINFO.
1125 Fusar-Poli P, Martinelli V, Politi P, et al. Successful antidepressive treatment with mirtazapine following lung transplantation. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Oct. 2008. 2008;32(7):1745-6. Source: PsycINFO. [pmid: 18572297].
1126 Fux M, Taub M, Zohar J. Emergence of depressive symptoms during treatment for panic disorder with specific 5-hydroxytryptophan reuptake inhibitors. Acta Psychiatr Scand. Oct. 1993;88(4):235-7. Source: PubMed. [pmid: 8256637].
1127 Gabriel A. Lamotrigine adjunctive treatment in resistant unipolar depression: An open, descriptive study. Depression and Anxiety. 2006;23(8):485-8. Source: EMBASE. [pmid: 16845646].
1128 Gabriel A. Changes in plasma cholesterol in mood disorder patients: does treatment make a difference?. J Affect Disord. Apr. 2007;99(1-3):273-8. Source: PubMed. [pmid: 16979243].
1129 Gagiano CA. A double blind comparison of paroxetine and fluoxetine in patients with major depression. Br J Clin Res. 1993;4:145-52. Source: EMBASE.
1130 Gagiano CA, Muller PG, Fourie J, et al. The therapeutic efficacy of paroxetine: (a) an open study in patients with major depression not responding to antidepressants; (b) a double-blind comparison with amitriptyline in depressed outpatients. Acta Psychiatr Scand Suppl. 1989;350:130-1. Source: PubMed. [pmid: 2530765].
1131 Gahimer J, Wernicke J, Yalcin I, et al. A retrospective pooled analysis of duloxetine safety in 23,983 subjects. Curr Med Res Opin. Jan. 2007;23(1):175-84. Source: PubMed. [pmid: 17257478].
1132 Galecki P, Szemraj J, Bienkiewicz M, et al. Lipid peroxidation and antioxidant protection in patients during acute depressive episodes and in remission after fluoxetine treatment. Pharmacol Rep. May-Jun. 2009;61(3):436-47. Source: PubMed. [pmid: 19605942].
1133 Gales BJ, Gales MA. Erythema multiforme and angioedema with indapamide and sertraline. Am J Hosp Pharm. Jan. 1. 1994;51(1):118-9. Source: PubMed. [pmid: 8135249].
1134 Gallassi R, Di Sarro R, Morreale A, et al. Memory impairment in patients with late-onset major depression: the effect of antidepressant therapy. J Affect Disord. Apr. 2006;91(2-3):243-50. Source: PubMed. [pmid: 16499971].
1135 Gallimore C. Pharmacological Management of Treatment-Resistant Depression Alternative therapies often required to alleviate symptoms. Journal of the Pharmacy Society of Wisconsin (USA). 01. 01. 2008;(NOV-DEC):18-22. Source: PsycINFO.
1136 Garakani A, Martinez JM, Marcus S, et al. A randomized, double-blind, and placebo-controlled trial of quetiapine augmentation of fluoxetine in major depressive disorder. Int Clin Psychopharmacol. 2008;23(5):269-75. Source: PubMed. [pmid: 18703936].
1137 Garcia Campayo J. Effectiveness of mirtazapine in the treatment of depression with associated somatic symptoms. Actas Esp Psiquiatr. Jan-Feb. 2008;36(1):25-32. Source: PubMed. [pmid: 18286397].
1138 Garcia-Cebrian A, Bauer M, Montejo AL, et al. Factors influencing depression endpoints research (FINDER): Study design and population characteristics. European Psychiatry. 2008;23(1):57-65. Source: EMBASE. [pmid: 18086518].
1139 Garcia-Cebrian A, Gandhi P, Demyttenaere K, et al. The association of depression and painful physical symptoms-a review of the European literature. European Psychiatry. 2006;21(6):379-88. Source: Scopus. [pmid: 16797937].
1140 Garcia-Sevilla JA, Ventayol P, Perez V, et al. Regulation of platelet alpha 2A-adrenoceptors, Gi proteins and receptor kinases in major depression: effects of mirtazapine treatment. Neuropsychopharmacology. Mar. 2004;29(3):580-8. Source: PubMed. [pmid: 14628003].
1141 Garcia-Toro M, Pascual-Leone A, Romera M, et al. Prefrontal repetitive transcranial magnetic stimulation as add on treatment in depression. J Neurol Neurosurg Psychiatry. Oct. 2001;71(4):546-8. Source: PubMed. [pmid: 11561046].
1142 Gardner EA. Long-term preventive care in depression: the use of bupropion in patients intolerant of other antidepressants. J Clin Psychiatry. May. 1983;44(5 Pt 2):157-62. Source: PubMed. [pmid: 6406449].
1143 Gardner EA, Johnston JA. Bupropion--an antidepressant without sexual pathophysiological action. J Clin Psychopharmacol. Feb. 1985;5(1):24-9. Source: PubMed. [pmid: 3919069].
1144 Garnock-Jones KP, McCormack PL. Escitalopram: a review of its use in the management of major depressive disorder in adults. CNS Drugs. Sep. 1. 2010;24(9):769-96. Source: PubMed. [pmid: 20806989].
1145 Garriock HA, Hamilton SP. Genetic studies of drug response and side effects in the STAR*D study, part 2. J Clin Psychiatry. Sep. 2009;70(9):1323-5. Source: PubMed. [pmid: 19818256].
1146 Garriock HA, Kraft JB, Shyn SI, et al. A genomewide association study of citalopram response in major depressive disorder. Biol Psychiatry. Jan. 15. 2010;67(2):133-8. Source: PubMed. [pmid: 19846067].
1147 Gartlehner G, Gaynes BN, Hansen RA, et al. Ranking antidepressants. Lancet. May. 23. 2009;373(9677):1761. author reply -2. Source: PubMed. [pmid: 19465225].
1148 Gartlehner G, Gaynes BN, Hansen RA, et al. Comparative benefits and harms of second-generation antidepressants: background paper for the American College of Physicians. Ann Intern Med. Nov. 18. 2008;149(10):734-50. Source: PubMed. [pmid: 19017592].
1149 Gartlehner G, Hansen RA, Carey TS, et al. Discontinuation rates for selective serotonin reuptake inhibitors and other second-generation antidepressants in outpatients with major depressive disorder: A systematic review and meta-analysis. International Clinical Psychopharmacology. 2005;20(2):59-69. Source: Scopus. [pmid: 15729080].
1150 Gartlehner G, Hansen RA, Nissman D, et al. A simple and valid tool distinguished efficacy from effectiveness studies. J of Clinical Epidemiology. 2006. Source: Handsearch.
1151 Gartlehner G, Hansen RA, Thieda P, et al. Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression. Rockville, MD. Agency for Healthcare Research and Quality (US). 2007. Report No.: 07-EHC007-EF. Source: PubMed.
1152 Gartlehner G, Thaler K, Hansen RA, et al. The general and comparative efficacy and safety of duloxetine in major depressive disorder: a systematic review and meta-analysis. Drug Saf. 2009;32(12):1159-73. Source: PubMed. [pmid: 19916583].
1153 Gartlehner G, Thieda P, Hansen RA, et al. Comparative risk for harms of second-generation antidepressants : a systematic review and meta-analysis. Drug Saf. 2008;31(10):851-65. Source: PubMed. [pmid: 18759509].
1154 Gartrell N. Increased libido in women receiving trazodone. Am J Psychiatry. Jun. 1986;143(6):781-2. Source: PubMed. [pmid: 3717405].
1155 Gasperini M, Gatti F, Bellini L, et al. Perspectives in clinical psychopharmacology of amitriptyline and fluvoxamine. A double-blind study in depressed inpatients. Neuropsychobiology. 1992;26(4):186-92. Source: PubMed. [pmid: 1299793].
1156 Gasto C, Navarro V, Marcos T, et al. Single-blind comparison of venlafaxine and nortriptyline in elderly major depression. J Clin Psychopharmacol. Feb. 2003;23(1):21-6. Source: PubMed. [pmid: 12544371].
1157 Gastpar M, Singer A, Zeller K. Efficacy and tolerability of hypericum extract STW3 in long-term treatment with a once-daily dosage in comparison with sertraline. Pharmacopsychiatry. Mar. 2005;38(2):78-86. Source: PubMed. [pmid: 15744631].
1158 Gastpar M, Singer A, Zeller K. Comparative efficacy and safety of a once-daily dosage of hypericum extract STW3-VI and citalopram in patients with moderate depression: a double-blind, randomised, multicentre, placebo-controlled study. Pharmacopsychiatry. 2006;39(2):66-75. Source: PubMed. [pmid: 16555167].
1159 Gater R, Waheed W, Husain N, et al. Social intervention for British Pakistani women with depression: Randomised controlled trial. British Journal of Psychiatry. 2010;197(3):227-33. Source: EMBASE. [pmid: 20807969].
1160 Gattaz WF, Vogel P, Kick H, et al. Moclobemide versus fluoxetine in the treatment of inpatients with major depression. J Clin Psychopharmacol. Aug. 1995;15(4 Suppl 2):35S-40S. Source: PubMed. [pmid: 7593728].
1161 Gatti F, Bellini L, Gasperini M, et al. Fluvoxamine alone in the treatment of delusional depression. Am J Psychiatry. Mar. 1996;153(3):414-6. Source: PubMed. [pmid: 8610832].
1162 Gau YT, Liou YJ, Yu YW, et al. Evidence for association between genetic variants of p75 neurotrophin receptor (p75NTR) gene and antidepressant treatment response in Chinese major depressive disorder. Am J Med Genet B Neuropsychiatr Genet. Jul. 5. 2008;147B(5):594-9. Source: PubMed. [pmid: 18081157].
1163 Gaynes B, Lux L, Lloyd S, et al. Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults. Comparative Effectiveness Review No. Rockville, MD. Agency for Healthcare Research and Quality. 2011. Source: Handsearch.
1164 Gaynes BN, Davis L, Rush AJ, et al. The aims and design of the Sequenced Treatment Alternatives to Relieve Depression (STAR*D) study. 2005;12(2):6. Source: Handsearch.
1165 Gaynes BN, Magruder KM, Burns BJ, et al. Does a coexisting anxiety disorder predict persistence of depressive illness in primary care patients with major depression?. Gen Hosp Psychiatry. May-Jun. 1999;21(3):158-67. Source: PubMed. [pmid: 10378109].
1166 Gaynes BN, Rush AJ, Trivedi M, et al. A direct comparison of presenting characteristics of depressed outpatients from primary vs. specialty care settings: preliminary findings from the STAR*D clinical trial. Gen Hosp Psychiatry. Mar-Apr. 2005;27(2):87-96. Source: PubMed. [pmid: 15763119].
1167 Gaynes BN, Rush AJ, Trivedi MH, et al. Primary versus specialty care outcomes for depressed outpatients managed with measurement-based care: results from STAR*D. J Gen Intern Med. May. 2008;23(5):551-60. Source: PubMed. [pmid: 18247097].
1168 Gaynes BN, Rush AJ, Trivedi MH, et al. Major depression symptoms in primary care and psychiatric care settings: a cross-sectional analysis. Ann Fam Med. Mar-Apr. 2007;5(2):126-34. Source: PubMed. [pmid: 17389536].
1169 Gaynes BN, Rush AJ, Trivedi MH, et al. The STAR*D study: treating depression in the real world. Cleve Clin J Med. Jan. 2008;75(1):57-66. Source: PubMed. [pmid: 18236731].
1170 Gecici O, Gokmen Z, Nebioglu M. Fentanyl dependence caused by the non-medical use: A case report. Klinik Psikofarmakoloji Bulteni. 2010;20(3):255-7. Source: EMBASE.
1171 Geddes JR, Carney SM, Davies C, et al. Relapse prevention with antidepressant drug treatment in depressive disorders: a systematic review. Lancet. Feb. 22. 2003;361(9358):653-61. Source: PubMed. [pmid: 12606176].
1172 Geddes JR, Freemantle N, Mason J, et al. Selective serotonin reuptake inhibitors (SSRIs) versus other antidepressants for depression. The Cochrane Library (Cochrane Review). 2006. 2006;(1). Source: Handsearch.
1173 Geerts S, Bruynooghe F, De Cuyper H, et al. Moclobemide versus fluoxetine for major depressive episodes. Clin Neuropharmacol. Suppl 1. 1994;17:S50-7. Source: PubMed. [pmid: 7954484].
1174 Gelenberg AJ, McGahuey C, Laukes C, et al. Mirtazapine substitution in SSRI-induced sexual dysfunction. J Clin Psychiatry. May. 2000;61(5):356-60. Source: PubMed. [pmid: 10847310].
1175 Gelenberg AJ, Trivedi MH, Rush AJ, et al. Randomized, placebo-controlled trial of nefazodone maintenance treatment in preventing recurrence in chronic depression. Biol Psychiatry. Oct. 15. 2003;54(8):806-17. Source: PubMed. [pmid: 14550680].
1176 Gendall KA, Joyce PR, Mulder RT, et al. Thyroid indices and response to fluoxetine and nortriptyline in major depression. J Psychopharmacol. Dec. 2003;17(4):431-7. Source: PubMed. [pmid: 14870956].
1177 Gentile S. Antipsychotic-associated weight gain. Ann Pharmacother. May. 2004;38(5):903-4. Source: PubMed. [pmid: 14996995].
1178 Gentile S. Quetiapine-fluvoxamine combination during pregnancy and while breastfeeding. Arch Womens Ment Health. May. 2006;9(3):158-9. Source: PubMed. [pmid: 16683078].
1179 Gentile S, Bellantuono C. Selective serotonin reuptake inhibitor exposure during early pregnancy and the risk of fetal major malformations: focus on paroxetine. J Clin Psychiatry. 2009;70(3):414-22. Source: PubMed. [pmid: 19254517].
1180 George MS, Lisanby SH, Avery D, et al. Daily left prefrontal transcranial magnetic stimulation therapy for major depressive disorder: A sham-controlled randomized trial. Archives of general psychiatry. 2010;67(5):507-16. Source: EMBASE. [pmid: 20439832].
1181 George MS, Rush AJ, Marangell LB, et al. A one-year comparison of vagus nerve stimulation with treatment as usual for treatment-resistant depression. Biological Psychiatry. 2005;58(5):364-73. Source: EMBASE. [pmid: 16139582].
1182 George T, Theodoros MT, Chiu E, et al. An open study of sertraline in patients with major depression who failed to respond to moclobemide. Aust N Z J Psychiatry. Dec. 1999;33(6):889-95. Source: PubMed. [pmid: 10619217].
1183 Geracioti TD Jr, Loosen PT, Gold PW, et al. Cortisol, thyroid hormone, and mood in atypical depression: a longitudinal case study. Biol Psychiatry. Mar. 1. 1992;31(5):515-9. Source: PubMed. [pmid: 1581426].
1184 Geretsegger C, Bohmer F, Ludwig M. Paroxetine in the elderly depressed patient: randomized comparison with fluoxetine of efficacy, cognitive and behavioural effects. Int Clin Psychopharmacol. Spring. 1994;9(1):25-9. Source: PubMed. [pmid: 8195578].
1185 Geretsegger C, Stuppaeck CH, Mair M, et al. Multicenter double blind study of paroxetine and amitryptyline in elderly depressed inpatients. Psychopharmacology. 1995;119(3):277-81. Source: EMBASE. [pmid: 7675961].
1186 Gershon S. Comparative side effect profiles of trazodone and imipramine: special reference to the geriatric population. Psychopathology. Suppl 2. 1984;17:39-50. Source: PubMed. [pmid: 6371878].
1187 Gershon S, Georgotas A, Newton R, et al. Clinical evaluation of two new antidepressants. Adv Biochem Psychopharmacol. 1982;32:57-68. Source: PubMed. [pmid: 6211943].
1188 Gerstenberg G, Aoshima T, Fukasawa T, et al. Relationship between clinical effects of fluvoxamine and the steady-state plasma concentrations of fluvoxamine and its major metabolite fluvoxamino acid in Japanese depressed patients. Psychopharmacology (Berl). Jun. 2003;167(4):443-8. Source: PubMed. [pmid: 12682708].
1189 Gervasoni N, Legendre-Simon P, Aubry JM, et al. Early telephone intervention for psychiatric outpatients starting antidepressant treatment. Nord J Psychiatry. Aug. 2010;64(4):265-7. Source: PubMed. [pmid: 20166864].
1190 Ghaeli P, Shahsavand E, Mesbahi M, et al. Comparing the effects of 8-week treatment with fluoxetine and imipramine on fasting blood glucose of patients with major depressive disorder. J Clin Psychopharmacol. Aug. 2004;24(4):386-8. Source: PubMed. [pmid: 15232329].
1191 Ghaemi SN, Goodwin FK. Antidepressants for Bipolar Depression. The American Journal of Psychiatry. Aug. 2005. 2005;162(8):1545-6. Source: PsycINFO. [pmid: 16055786].
1192 Ghaemi SN, Ostacher MM, El-Mallakh RS, et al. Antidepressant discontinuation in bipolar depression: A systematic treatment enhancement program for bipolar disorder (STEP-BD) randomized clinical trial of long-term effectiveness and safety. Journal of Clinical Psychiatry. 2010;71(4):372-80. Source: EMBASE. [pmid: 20409444].
1193 Giannelli A, Rabboni M, Zarattini F, et al. A combination of hypothalamic phospholipid liposomes with trazodone for treatment of depression. An open controlled study. Acta Psychiatr Scand. Jan. 1989;79(1):52-8. Source: PubMed. [pmid: 2648767].
1194 Gibbons RD, Brown CH, Hur K, et al. Early evidence on the effects of regulators' suicidality warnings on SSRI prescriptions and suicide in children and adolescents. American Journal of Psychiatry. 2007;164(9):1356-63. Source: Scopus. [pmid: 17728420].
1195 Gibbons RD, Brown CH, Hur K, et al. Relationship between antidepressants and suicide attempts: An analysis of the veterans health administration data sets. American Journal of Psychiatry. 2007;164(7):1044-9. Source: Scopus. [pmid: 17606656].
1196 Gibbons RD, Hur K, Bhaumik DK, et al. The relationship between antidepressant medication use and rate of suicide. Archives of General Psychiatry. 2005;62(2):165-72. Source: Scopus. [pmid: 15699293].
1197 Gibbons RD, Hur K, Bhaumik DK, et al. The relationship between antidepressant prescription rates and rate of early adolescent suicide. American Journal of Psychiatry. 2006;163(11):1898-904. Source: Scopus. [pmid: 17074941].
1198 Gibson TB, Jing Y, Carls GS, et al. Cost burden of treatment resistance in patients with depression. American Journal of Managed Care. 2010;16(5):370-7. Source: EMBASE. [pmid: 20469957].
1199 Gijsman HJ, Geddes JR, Rendell JM, et al. Dr Gijsman and Colleagues Reply: Antidepressants and Bipolar Depression. The American Journal of Psychiatry. Aug. 2005. 2005;162(8):1547-8. Source: PsycINFO.
1200 Gilaberte I, Montejo AL, de la Gandara J, et al. Fluoxetine in the prevention of depressive recurrences: a double-blind study. J Clin Psychopharmacol. Aug. 2001;21(4):417-24. Source: PubMed. [pmid: 11476126].
1201 Gill J, Luckenbaugh D, Charney D, et al. Sustained elevation of serum interleukin-6 and relative insensitivity to hydrocortisone differentiates posttraumatic stress disorder with and without depression. Biological psychiatry. 2010;68(11):999-1006. Source: EMBASE. [pmid: 20951370].
1202 Gillin JC, Rapaport M, Erman MK, et al. A comparison of nefazodone and fluoxetine on mood and on objective, subjective, and clinician-rated measures of sleep in depressed patients: a double-blind, 8-week clinical trial. J Clin Psychiatry. May. 1997;58(5):185-92. Source: PubMed. [pmid: 9184611].
1203 Gillman K. Venlafaxine-lithium toxicity: suitability for use in the elderly. J Clin Pharm Ther. Oct. 2007;32(5):529-31. Source: PubMed. [pmid: 17875121].
1204 Gilmer WS, Gollan JK, Wisniewski SR, et al. Does the duration of index episode affect the treatment outcome of major depressive disorder? A STAR*D report. J Clin Psychiatry. Aug. 2008;69(8):1246-56. Source: PubMed. [pmid: 18681756].
1205 Gilmer WS, Kemp DE. STAR*D: What have we learned thus far?. International Drug Therapy Newsletter (USA). 10. 1. 2006;41(Oct). Source: PsycINFO.
1206 Gilmer WS, Trivedi MH, Rush AJ, et al. Factors associated with chronic depressive episodes: a preliminary report from the STAR-D project. Acta Psychiatr Scand. Dec. 2005;112(6):425-33. Source: PubMed. [pmid: 16279871].
1207 Gilmor ML, Owens MJ, Nemeroff CB. Inhibition of norepinephrine uptake in patients with major depression treated with paroxetine. Am J Psychiatry. Oct. 2002;159(10):1702-10. Source: PubMed. [pmid: 12359676].
1208 Ginestet D. Fluoxetine in endogenous depression and melancholia versus clomipramine. Int Clin Psychopharmacol. Jan. Suppl 1. 1989;4:37-40. Source: PubMed. [pmid: 2644338].
1209 Ginsberg DL. Adjunctive ropinirole for treatment-resistant depression. Primary Psychiatry. 2005;12(8):26-7. Source: EMBASE.
1210 Ginsberg DL. Vardenafil Treatment of Sertraline-Induced Anorgasmia in a Woman. Primary Psychiatry. Jan. 2005. 2005;12(1):17-8. Source: PsycINFO.
1211 Girardi P, Pompili M, Innamorati M, et al. Duloxetine in acute major depression: review of comparisons to placebo and standard antidepressants using dissimilar methods. Hum Psychopharmacol. 2009;24(3):177-90. Source: PubMed. [pmid: 19229839].
1212 Girgis RR, Duggal HS, Douaihy AB. Respiratory depression from Symbyax® overdose and binge drinking. General Hospital Psychiatry. May-Jun. 2006. 2006;28(3):255-6. Source: PsycINFO. [pmid: 16675370].
1213 Gittelman DK, Kirby MG. A seizure following bupropion overdose. J Clin Psychiatry. Apr. 1993;54(4):162. Source: PubMed. [pmid: 8486598].
1214 Glassman AH, Bigger JT Jr, Gaffney M. Psychiatric characteristics associated with long-term mortality among 361 patients having an acute coronary syndrome and major depression: seven-year follow-up of SADHART participants. Arch Gen Psychiatry. Sep. 2009;66(9):1022-9. Source: PubMed. [pmid: 19736359].
1215 Glassman AH, Bigger JT, Gaffney M, et al. Onset of major depression associated with acute coronary syndromes: relationship of onset, major depressive disorder history, and episode severity to sertraline benefit. Arch Gen Psychiatry. 2006;63(3):283-8. Source: PubMed. [pmid: 16520433].
1216 Glassman AH, Bigger JT, Gaffney M, et al. Heart rate variability in acute coronary syndrome patients with major depression: influence of sertraline and mood improvement. Arch Gen Psychiatry. Sep. 2007;64(9):1025-31. Source: PubMed. [pmid: 17768267].
1217 Glassman AH, O'Connor CM, Califf RM, et al. Sertraline treatment of major depression in patients with acute MI or unstable angina. Jama. Aug. 14. 2002;288(6):701-9. Source: PubMed. [pmid: 12169073].
1218 Gleason OC, Yates WR, Isbell MD, et al. An open-label trial of citalopram for major depression in patients with hepatitis C. J Clin Psychiatry. Mar. 2002;63(3):194-8. Source: PubMed. [pmid: 11926717].
1219 Glenny AM, Altman DG, Song F, et al. Indirect comparisons of competing interventions. Health Technol Assess. Jul. 2005;9(26):1-134. iii. iv. Source: PubMed. [pmid: 16014203].
1220 Glod C. Prozac: pros and cons. J Psychosoc Nurs Ment Health Serv. Dec. 1990;28(12):33-4. Source: PubMed. [pmid: 2283599].
1221 Goethe JW, Woolley SB, Cardoni AA, et al. Selective serotonin reuptake inhibitor discontinuation: side effects and other factors that influence medication adherence. J Clin Psychopharmacol. Oct. 2007;27(5):451-8. Source: PubMed. [pmid: 17873676].
1222 Goldapple K, Segal Z, Garson C, et al. Modulation of cortical-limbic pathways in major depression: treatment-specific effects of cognitive behavior therapy. Arch Gen Psychiatry. Jan. 2004;61(1):34-41. Source: PubMed. [pmid: 14706942].
1223 Goldberg HL, Finnerty RJ. Trazodone in the treatment of neurotic depression. J Clin Psychiatry. Dec. 1980;41(12 Pt 1):430-4. Source: PubMed. [pmid: 7440519].
1224 Goldberg JF. The modern pharmacopoeia: a return to depressive realism?. Bipolar Disord. Dec. 2008;10(8):969-72. Source: PubMed. [pmid: 19594511].
1225 Goldberg JF, Sacks MH, Kocsis JH. Attenuation of response to serotonin reuptake inhibitors. Am J Psychiatry. Jun. 1995;152(6):954. Source: PubMed. [pmid: 7755133].
1226 Goldbloom DS, Olmsted MP. Pharmacotherapy of bulimia nervosa with fluoxetine: assessment of clinically significant attitudinal change. Am J Psychiatry. May. 1993;150(5):770-4. Source: PubMed. [pmid: 8480824].
1227 Golden RN. Efficacy and tolerability of controlled-release paroxetine. Psychopharmacol Bull. Spring. Suppl 1. 2003;37:176-86. Source: PubMed. [pmid: 14566210].
1228 Golden RN, De Vane CL, Laizure SC, et al. Bupropion in depression. II. The role of metabolites in clinical outcome. Arch Gen Psychiatry. Feb. 1988;45(2):145-9. Source: PubMed. [pmid: 3122699].
1229 Golden RN, Nemeroff CB, McSorley P, et al. Efficacy and tolerability of controlled-release and immediate-release paroxetine in the treatment of depression. J Clin Psychiatry. Jul. 2002;63(7):577-84. Source: PubMed. [pmid: 12143913].
1230 Golden RN, Rudorfer MV, Sherer MA, et al. Bupropion in depression. I. Biochemical effects and clinical response. Arch Gen Psychiatry. Feb. 1988;45(2):139-43. Source: PubMed. [pmid: 3122698].
1231 Goldman S. Possible antipsychotic effect of fluvoxamine. CNS Spectr. Oct. 2005;10(10):774. author reply -5. Source: PubMed. [pmid: 16404786].
1232 Goldsmith SJ, Anger Friedfeld K, Beren S, et al. Psychiatric illness in patients presenting for obesity treatment. International Journal of Eating Disorders. 1992;12(1):63-71. Source: EMBASE.
1233 Goldstein DJ. Effects of third trimester fluoxetine exposure on the newborn. J Clin Psychopharmacol. Dec. 1995;15(6):417-20. Source: PubMed. [pmid: 8748430].
1234 Goldstein DJ. Duloxetine in the treatment of major depressive disorder. Neuropsychiatric Disease and Treatment. 2007. 2007;3(2):193-209. Source: PsycINFO. [pmid: 19300553].
1235 Goldstein DJ, Hamilton SH, Masica DN, et al. Fluoxetine in medically stable, depressed geriatric patients: effects on weight. J Clin Psychopharmacol. Oct. 1997;17(5):365-9. Source: PubMed. [pmid: 9315987].
1236 Goldstein DJ, Lu Y, Detke MJ, et al. Effects of duloxetine on painful physical symptoms associated with depression. Psychosomatics. Jan-Feb. 2004;45(1):17-28. Source: PubMed. [pmid: 14709757].
1237 Goldstein DJ, Lu Y, Detke MJ, et al. Duloxetine in the treatment of depression: a double-blind placebo-controlled comparison with paroxetine. J Clin Psychopharmacol. Aug. 2004;24(4):389-99. Source: PubMed. [pmid: 15232330].
1238 Goldstein DJ, Mallinckrodt C, Lu Y, et al. Duloxetine in the treatment of major depressive disorder: a double-blind clinical trial. J Clin Psychiatry. Mar. 2002;63(3):225-31. Source: PubMed. [pmid: 11926722].
1239 Goldstein DJ, Rampey AH Jr, Potvin JH, et al. Analyses of suicidality in double-blind, placebo-controlled trials of pharmacotherapy for weight reduction. J Clin Psychiatry. Aug. 1993;54(8):309-16. Source: PubMed. [pmid: 8253699].
1240 Goldstein DJ, Wilson MG, Ascroft RC, et al. Effectiveness of fluoxetine therapy in bulimia nervosa regardless of comorbid depression. Int J Eat Disord. Jan. 1999;25(1):19-27. Source: PubMed. [pmid: 9924649].
1241 Goldstein L, Barker M, Segall F, et al. Seizure and transient SIADH associated with sertraline. Am J Psychiatry. May. 1996;153(5):732. Source: PubMed. [pmid: 8615425].
1242 Gomez Gomez JM, Teixido Perramon C. Combined treatment with venlafaxine and tricyclic antidepressants in depressed patients who had partial response to clomipramine or imipramine: initial findings. J Clin Psychiatry. Apr. 2000;61(4):285-9. Source: PubMed. [pmid: 10830150].
1243 Gómez-Gil E, Navinés R, Martínez De Osaba MJ, et al. Hormonal responses to the 5-HT1A agonist buspirone in remitted endogenous depressive patients after long-term imipramine treatment. Psychoneuroendocrinology. 2010;(4):481-9. Source: The Cochrane Library. [pmid: 19762159].
1244 Gonella G, Baignoli G, Ecari U. Fluvoxamine and imipramine in the treatment of depressive patients: a double-blind controlled study. Curr Med Res Opin. 1990;12(3):177-84. Source: PubMed. [pmid: 2125547].
1245 Gonzalez-Pinto A, Gutierrez M, Gonzalez N, et al. Efficacy and safety of venlafaxine-ECT combination in treatment-resistant depression. J Neuropsychiatry Clin Neurosci. Spring. 2002;14(2):206-9. Source: PubMed. [pmid: 11983797].
1246 Gonzalez-Pinto A, Imaz H, De Heredia JL, et al. Mania and tramadol-fluoxetine combination. Am J Psychiatry. Jun. 2001;158(6):964-5. Source: PubMed. [pmid: 11384912].
1247 Goode DJ, Manning AA. Comparison of bupropion alone and with haloperidol in schizo-affective disorder, depressed type. J Clin Psychiatry. Jul. 1983;44(7):253-5. Source: PubMed. [pmid: 6408068].
1248 Goodman WK, Price LH, Delgado PL, et al. Specificity of serotonin reuptake inhibitors in the treatment of obsessive-compulsive disorder. Comparison of fluvoxamine and desipramine. Arch Gen Psychiatry. Jun. 1990;47(6):577-85. Source: PubMed. [pmid: 2112374].
1249 Goodnick PJ, Dominguez RA, DeVane CL, et al. Bupropion slow-release response in depression: diagnosis and biochemistry. Biol Psychiatry. Oct. 1. 1998;44(7):629-32. Source: PubMed. [pmid: 9787888].
1250 Goodnick PJ, Fieve RR, Peselow ED, et al. Double-blind treatment of major depression with fluoxetine: use of pattern analysis and relation of HAM-D score to CGI change. Psychopharmacol Bull. 1987;23(1):162-3. Source: PubMed. [pmid: 3496624].
1251 Goodnick PJ, Kumar A, Henry JH, et al. Sertraline in coexisting major depression and diabetes mellitus. Psychopharmacol Bull. 1997;33(2):261-4. Source: PubMed. [pmid: 9230640].
1252 Goodnick PJ, Sandoval R, Brickman A, et al. Bupropion treatment of fluoxetine-resistant chronic fatigue syndrome. Biol Psychiatry. Nov. 1. 1992;32(9):834-8. Source: PubMed. [pmid: 1450297].
1253 Goodwin GM. Innovation translates into antidepressant effectiveness. Journal of psychopharmacology (Oxford England). 2008;22(7 Suppl):9-12. Source: Scopus.
1254 Gooneratne NS, Patel NP, Corcoran A. Chronic obstructive pulmonary disease diagnosis and management in older adults. Journal of the American Geriatrics Society. 2010;58(6):1153-62. Source: EMBASE. [pmid: 20936735].
1255 Gorenstein C, Andrade L, Moreno RA, et al. Social adjustment in depressed patients treated with venlafaxine and amitriptyline. Int Clin Psychopharmacol. Jul. 2002;17(4):171-5. Source: PubMed. [pmid: 12131600].
1256 Gorwood P, Weiller E, Lemming O, et al. Escitalopram prevents relapse in older patients with major depressive disorder. Am J Geriatr Psychiatry. 2007;15(7):581-93. Source: PubMed. [pmid: 17586783].
1257 Gossen D, de Suray JM, Vandenhende F, et al. Influence of fluoxetine on olanzapine pharmacokinetics. AAPS PharmSci. 2002;4(2):E11. Source: PubMed. [pmid: 12102620].
1258 Gottfries CG. Scandinavian experience with citalopram in the elderly. Int Clin Psychopharmacol. Mar. Suppl 1. 1996;11:41-4. Source: PubMed. [pmid: 8732444].
1259 Gourion D. Antidepressants and their onset of action: A major clinical, methodological and pronostical issue. Délai d'action des antidépresseurs : une problématique clinique, méthodologique et pronostique fondamentale dans le traitement de la dépression majeure. 2008;34(1):73-81. Source: Scopus.
1260 Gouvea F, Lopes A, Greenberg B, et al. Response to sham and active gamma ventral capsulotomy in otherwise intractable obsessive-compulsive disorder. Stereotactic and Functional Neurosurgery. 2010;88(3):177-82. Source: EMBASE. [pmid: 20431329].
1261 Graber MA, Hoehns TB, Perry PJ. Sertraline-phenelzine drug interaction: a serotonin syndrome reaction. Ann Pharmacother. Jun. 1994;28(6):732-5. Source: PubMed. [pmid: 7919561].
1262 Gracious BL, Hanusa BH, Wisner KL, et al. Weight changes in postpartum women with remitted depression. J Clin Psychiatry. Mar. 2005;66(3):291-3. Source: PubMed. [pmid: 15766293].
1263 Grady TA, Pigott TA, L'Heureux F, et al. Double-blind study of adjuvant buspirone for fluoxetine-treated patients with obsessive-compulsive disorder. Am J Psychiatry. May. 1993;150(5):819-21. Source: PubMed. [pmid: 8480832].
1264 Granger AL, Fehnel SE, Hogue SL, et al. An assessment of patient preference and adherence to treatment with Wellbutrin SR: a web-based survey. J Affect Disord. Feb. 2006;90(2-3):217-21. Source: PubMed. [pmid: 16360216].
1265 Grasmader K, Verwohlt PL, Kuhn KU, et al. Relationship between mirtazapine dose, plasma concentration, response, and side effects in clinical practice. Pharmacopsychiatry. May. 2005;38(3):113-7. Source: PubMed. [pmid: 15902580].
1266 Gravem A, Amthor KF, Astrup C, et al. A double-blind comparison of citalopram (Lu 10-171) and amitriptyline in depressed patients. Acta Psychiatr Scand. May. 1987;75(5):478-86. Source: PubMed. [pmid: 3300171].
1267 Greco T, Eckert G, Kroenke K. The outcome of physical symptoms with treatment of depression. J Gen Intern Med. Aug. 2004;19(8):813-8. Source: PubMed. [pmid: 15242465].
1268 Green TD, Reynolds CF 3rd, Mulsant BH, et al. Accelerating antidepressant response in geriatric depression: a post hoc comparison of combined sleep deprivation and paroxetine versus monotherapy with paroxetine, nortriptyline, or placebo. J Geriatr Psychiatry Neurol. Summer. 1999;12(2):67-71. Source: PubMed. [pmid: 10483927].
1269 Greenberg PE, Kessler RC, Birnbaum HG, et al. The economic burden of depression in the United States: how did it change between 1990 and 2000?. J Clin Psychiatry. 2003. Dec. 2003;64(12):1465-75. Source: Handsearch. [pmid: 14728109].
1270 Greenberg RP, Bornstein RF, Zborowski MJ, et al. A meta-analysis of fluoxetine outcome in the treatment of depression. J Nerv Ment Dis. Oct. 1994;182(10):547-51. Source: PubMed. [pmid: 7931201].
1271 Greene DS, Barbhaiya RH. Clinical pharmacokinetics of nefazodone. Clin Pharmacokinet. Oct. 1997;33(4):260-75. Source: PubMed. [pmid: 9342502].
1272 Greenes D, Fava M, Cioffi J, et al. The relationship of depression to dissociation in patients with bulimia nervosa. J Psychiatr Res. Apr-Jun. 1993;27(2):133-7. Source: PubMed. [pmid: 8366464].
1273 Greenlee A, Karp JF, Dew MA, et al. Anxiety impairs depression remission in partial responders during extended treatment in late-life. Depress Anxiety. May. 2010;27(5):451-6. Source: PubMed. [pmid: 20186975].
1274 Greenway FL, Fujioka K, Plodkowski RA, et al. Effect of naltrexone plus bupropion on weight loss in overweight and obese adults (COR-I): A multicentre, randomised, double-blind, placebo-controlled, phase 3 trial. The Lancet. 2010;376(9741):595-605. Source: EMBASE.
1275 Gregor KJ, Way K, Young CH, et al. Concomitant use of selective serotonin reuptake inhibitors with other cytochrome P450 2D6 or 3A4 metabolized medications: how often does it really happen?. J Affect Disord. Oct. 1997;46(1):59-67. Source: PubMed. [pmid: 9387087].
1276 Greist J, McNamara RK, Mallinckrodt CH, et al. Incidence and duration of antidepressant-induced nausea: duloxetine compared with paroxetine and fluoxetine. Clin Ther. Sep. 2004;26(9):1446-55. Source: PubMed. [pmid: 15531007].
1277 Griffiths RI, Sullivan EM, Frank RG, et al. Medical resource use and cost of venlafaxine or tricyclic antidepressant therapy. Following selective serotonin reuptake inhibitor therapy for depression. Pharmacoeconomics. May. 1999;15(5):495-505. Source: PubMed. [pmid: 10537966].
1278 Grigoriadis S, Kennedy SH, Bagby RM. A comparison of antidepressant response in younger and older women. J Clin Psychopharmacol. Aug. 2003;23(4):405-7. Source: PubMed. [pmid: 12920418].
1279 Grimsley SR, Jann MW. Paroxetine, sertraline, and fluvoxamine: new selective serotonin reuptake inhibitors. Clin Pharm. Nov. 1992;11(11):930-57. Source: PubMed. [pmid: 1464219].
1280 Grinshpoon A, Marom E, Weizman A, et al. Psychotropic drug use in Israel: Results from the national health survey. Primary Care Companion to the Journal of Clinical Psychiatry. 2007;9(5):356-63. Source: EMBASE.
1281 Gronli O, Stensland GO, Wynn R, et al. Neurotrophic factors in serum following ECT: a pilot study. World J Biol Psychiatry. 2009;10(4):295-301. Source: PubMed. [pmid: 19921971].
1282 Grossman R, Reynolds D, Goodman M, et al. Efficacy of open-label venlafaxine in subjects with major depressive disorder: associations with neuroendocrine response to serotonergic and noradrenergic probes. Psychiatry Res. Sep. 30. 2004;128(2):203-6. Source: PubMed. [pmid: 15488964].
1283 Grunder G, Wetzel H, Schlosser R, et al. Subchronic antidepressant treatment with venlafaxine or imipramine and effects on blood pressure and heart rate: assessment by automatic 24-hour monitoring. Pharmacopsychiatry. Mar. 1996;29(2):72-8. Source: PubMed. [pmid: 8741025].
1284 Grunhaus L, Hirschman S, Dolberg OT, et al. Coadministration of melatonin and fluoxetine does not improve the 3-month outcome following ECT. J Ect. Jun. 2001;17(2):124-8. Source: PubMed. [pmid: 11417923].
1285 Grunze H, Marcuse A, Scharer LO, et al. Nefazodone in psychotic unipolar and bipolar depression: a retrospective chart analysis and open prospective study on its efficacy and safety versus combined treatment with amitriptyline and haloperidol. Neuropsychobiology. Suppl 1. 2002;46:31-5. Source: PubMed. [pmid: 12571431].
1286 Guaiana G, Andretta M, Corbari L, et al. Antidepressant drug consumption and public health indicators in Italy, 1955 to 2000. Journal of Clinical Psychiatry. 2005;66(6):750-5. Source: Scopus. [pmid: 15960569].
1287 Guaiana G, Gupta S, Chiodo D, et al. Agomelatine versus other antidepressive agents for major depression. Cochrane Database of Systematic Reviews. 2010;(11). Source: The Cochrane Library.
1288 Gual A, Balcells M, Torres M, et al. Sertraline for the prevention of relapse in detoxicated alcohol dependent patients with a comorbid depressive disorder: a randomized controlled trial. Alcohol Alcohol. Nov-Dec. 2003;38(6):619-25. Source: PubMed. [pmid: 14633652].
1289 Gualtieri CT, Johnson LG. Bupropion normalizes cognitive performance in patients with depression. MedGenMed. 2007;9(1):22. Source: PubMed. [pmid: 17435629].
1290 Guelfi JD, Ansseau M, Corruble E, et al. A double-blind comparison of the efficacy and safety of milnacipran and fluoxetine in depressed inpatients. Int Clin Psychopharmacol. May. 1998;13(3):121-8. Source: PubMed. [pmid: 9690979].
1291 Guelfi JD, Ansseau M, Timmerman L, et al. Mirtazapine versus venlafaxine in hospitalized severely depressed patients with melancholic features. J Clin Psychopharmacol. Aug. 2001;21(4):425-31. Source: PubMed. [pmid: 11476127].
1292 Guelfi JD, Bouhassira M, Bonett Perrin E, et al. Study of the efficacy of fluoxetine versus tianeptine in the treatment of elderly depressed patients, followed in general practice. Encephale. 1999;25(3):265-70. Source: EMBASE. [pmid: 10434153].
1293 Guelfi JD, Dreyfus JF, Pichot P. Fluvoxamine and imipramine: results of a long-term controlled trial. Int Clin Psychopharmacol. Apr. 1987;2(2):103-9. Source: PubMed. [pmid: 3110264].
1294 Guelfi JD, Strub N, Loft H. Efficacy of intravenous citalopram compared with oral citalopram for severe depression. Safety and efficacy data from a double-blind, double-dummy trial. J Affect Disord. Jun. 2000;58(3):201-9. Source: PubMed. [pmid: 10802128].
1295 Guelfi JD, White C, Hackett D, et al. Effectiveness of venlafaxine in patients hospitalized for major depression and melancholia. J Clin Psychiatry. Oct. 1995;56(10):450-8. Source: PubMed. [pmid: 7559370].
1296 Guillibert E, Pelicier Y, Archambault JC, et al. A double-blind, multicentre study of paroxetine versus clomipramine in depressed elderly patients. Acta Psychiatr Scand Suppl. 1989;350:132-4. Source: PubMed. [pmid: 2530766].
1297 Gulseren L, Gulseren S, Hekimsoy Z, et al. Comparison of fluoxetine and paroxetine in type II diabetes mellitus patients. Arch Med Res. Mar-Apr. 2005;36(2):159-65. Source: PubMed. [pmid: 15847950].
1298 Gulsun M, Doruk A. Mirtazapine-induced akathisia. J Clin Psychopharmacol. Aug. 2008;28(4):467. Source: PubMed. [pmid: 18626283].
1299 Gunnell D, Saperia J, Ashby D. Selective serotonin reuptake inhibitors (SSRIs) and suicide in adults: meta-analysis of drug company data from placebo controlled, randomised controlled trials submitted to the MHRA's safety review. Bmj. Feb. 19. 2005;330(7488):385. Source: PubMed. [pmid: 15718537].
1300 Gunning-Dixon FM, Walton M, Cheng J, et al. MRI signal hyperintensities and treatment remission of geriatric depression. Journal of affective disorders. 2010;126(3):395-401. Source: EMBASE. [pmid: 20452031].
1301 Gupta AK, Saravay SM. Venlafaxine-induced hyponatremia. J Clin Psychopharmacol. Jun. 1997;17(3):223-5. Source: PubMed. [pmid: 9169969].
1302 Gupta RK, Parker G, Norman TR, et al. Fluoxetine--delayed half-life and an adverse event. Med J Aust. May. 17. 1993;158(10):722-3. Source: PubMed. [pmid: 8487709].
1303 Gupta S, Ghaly N, Dewan M. Augmenting fluoxetine with dextroamphetamine to treat refractory depression. Hosp Community Psychiatry. Mar. 1992;43(3):281-3. Source: PubMed. [pmid: 1555827].
1304 Gupta S, Major LF. Hair loss associated with fluoxetine. Br J Psychiatry. Nov. 1991;159:737-8. Source: PubMed. [pmid: 1756373].
1305 Gupta S, Nihalani N, Masand P. Duloxetine: review of its pharmacology, and therapeutic use in depression and other psychiatric disorders. Ann Clin Psychiatry. Apr-Jun. 2007;19(2):125-32. Source: PubMed. [pmid: 17612852].
1306 Guthrie E, Barlow J, Fernandes L, et al. Changes in tolerance to rectal distension correlate with changes in psychological state in patients with severe irritable bowel syndrome. Psychosom Med. Jul-Aug. 2004;66(4):578-82. Source: PubMed. [pmid: 15272106].
1307 Gutierrez MA, Stimmel GL, Aiso JY. Venlafaxine: a 2003 update. Clin Ther. Aug. 2003;25(8):2138-54. Source: PubMed. [pmid: 14512125].
1308 Gutierrez RL, McKercher R, Galea J, et al. Lamotrigine augmentation strategy for patients with treatment-resistant depression. CNS Spectrums. 2005;10(10):800-5. Source: Scopus. [pmid: 16400242].
1309 Guy W, Wilson WH, Ban TA, et al. A double-blind clinical trial of fluvoxamine and imipramine in patients with primary depression. Psychopharmacol Bull. Winter. 1984;20(1):73-8. Source: PubMed. [pmid: 6425916].
1310 Guyatt G, Gutterman D, Baumann MH, et al. Grading strength of recommendations and quality of evidence in clinical guidelines: report from an american college of chest physicians task force. Chest. Jan. 2006;129(1):174-81. Source: PubMed. [pmid: 16424429].
1311 Habra ME, Baker B, Frasure-Smith N, et al. First episode of major depressive disorder and vascular factors in coronary artery disease patients: Baseline characteristics and response to antidepressant treatment in the CREATE trial. J Psychosom Res. Aug. 2010;69(2):133-41. Source: PubMed. [pmid: 20624511].
1312 Hackett D. Venlafaxine XR in the treatment of anxiety. Acta Psychiatr Scand Suppl. 2000;(406):30-5. Source: PubMed. [pmid: 11131468].
1313 Haddad PM, Pal BR, Clarke P, et al. Neonatal symptoms following maternal paroxetine treatment: serotonin toxicity or paroxetine discontinuation syndrome?. J Psychopharmacol. Sep. 2005;19(5):554-7. Source: PubMed. [pmid: 16166193].
1314 Hadikusumo B, Ng B. Serotonin syndrome induced by duloxetine. Aust N Z J Psychiatry. Jun. 2009;43(6):581-2. Source: PubMed. [pmid: 19452666].
1315 Haffmans PM, Timmerman L, Hoogduin CA. Efficacy and tolerability of citalopram in comparison with fluvoxamine in depressed outpatients: a double-blind, multicentre study. The LUCIFER Group. Int Clin Psychopharmacol. Sep. 1996;11(3):157-64. Source: PubMed. [pmid: 8923094].
1316 Hahn SM, Griffin JH. Comment: fluoxetine adverse effects and drug interactions. Dicp. Nov. 1991;25(11):1273-4. Source: PubMed. [pmid: 1763551].
1317 Haider SI, Haider I. Comparative trial of selective serotonin reuptake inhibitors in depression. Pakistan Journal of Medical Sciences. 2001;17(4):237-9. Source: EMBASE.
1318 Halaris A. Antidepressant drug therapy in the elderly: enhancing safety and compliance. Int J Psychiatry Med. 1986;16(1):1-19. Source: PubMed. [pmid: 2873110].
1319 Halaris AE, Stern W, Harto-Truax N. Clinical efficacy of the new antidepressant bupropion (Wellbutrin) [proceedings]. Psychopharmacol Bull. Jan. 1981;17(1):140-2. Source: PubMed. [pmid: 6785817].
1320 Halaris AE, Stern WC, Van Wyck Fleet J, et al. Evaluation of the safety and efficacy of bupropion in depression. J Clin Psychiatry. May. 1983;44(5 Pt 2):101-3. Source: PubMed. [pmid: 6406435].
1321 Hale A, Corral RM, Mencacci C, et al. Superior antidepressant efficacy results of agomelatine versus fluoxetine in severe MDD patients: A randomized, double-blind study. International Clinical Psychopharmacology. 2010;25(6):305-14. Source: EMBASE. [pmid: 20856123].
1322 Halikas JA. Org 3770 (mirtazapine) versus trazodone: A placebo controlled trial in depressed elderly patients. Hum Psychopharmacol. 1995;10(Suppl 2):S125-S33. Source: EMBASE.
1323 Hall WD, Lucke J. How have the selective serotonin reuptake inhibitor antidepressants affected suicide mortality?. Aust N Z J Psychiatry. Nov-Dec. 2006;40(11-12):941-50. Source: PubMed. [pmid: 17054562].
1324 Halman M, Goldbloom DS. Fluoxetine and neuroleptic malignant syndrome. Biol Psychiatry. Sep. 15. 1990;28(6):518-21. Source: PubMed. [pmid: 2223920].
1325 Ham BJ, Lee BC, Paik JW, et al. Association between the tryptophan hydroxylase-1 gene A218C polymorphism and citalopram antidepressant response in a Korean population. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 30. 2007;31(1):104-7. Source: PubMed. [pmid: 16979275].
1326 Hamed A, Lee A, Ren XS, et al. Use of antidepressant medications: are there differences in psychiatric visits among patient treatments in the Veterans Administration?. Med Care. Jun. 2004;42(6):551-9. Source: PubMed. [pmid: 15167323].
1327 Hameed U, Schwartz TL, Malhotra K, et al. Antidepressant Treatment in the Primary Care Office: Outcomes for Adjustment Disorder Versus Major Depression. Annals of Clinical Psychiatry. Apr-Jun. 2005. 2005;17(2):77-81. Source: PsycINFO. [pmid: 16075660].
1328 Hamilton BA, Jones PG, Hoda AN, et al. Flupenthixol and fluvoxamine in mild to moderate depression: a comparison in general practice. Pharmatherapeutica. 1989;5(5):292-7. Source: PubMed. [pmid: 2501801].
1329 Hamilton SP, Nunes EV, Janal M, et al. The effect of sertraline on methadone plasma levels in methadone-maintenance patients. Am J Addict. Winter. 2000;9(1):63-9. Source: PubMed. [pmid: 10914294].
1330 Hammad TA, Laughren T, Racoosin J. Suicidality in pediatric patients treated with antidepressant drugs. Archives of General Psychiatry. 2006;63(3):332-9. Source: Scopus. [pmid: 16520440].
1331 Hammad TA, Laughren TP, Racoosin JA. Suicide rates in short-term randomized controlled trials of newer antidepressants. Journal of Clinical Psychopharmacology. 2006;26(2):203-7. Source: Scopus. [pmid: 16633153].
1332 Hannan N, Hamzah Z, Akinpeloye HO, et al. Venlafaxine-mirtazapine combination in the treatment of persistent depressive illness. J Psychopharmacol. Mar. 2007;21(2):161-4. Source: PubMed. [pmid: 17329295].
1333 Hanretta AT, Malek-Ahmadi P. Combined Use of ECT with Duloxetine and Olanzapine: A Case Report. The Journal of ECT. Jun. 2006. 2006;22(2):139-41. Source: PsycINFO. [pmid: 16801831].
1334 Hansen L. Fluoxetine dose-increment related akathisia in depression: implications for clinical care, recognition and management of selective serotonin reuptake inhibitor-induced akathisia. J Psychopharmacol. Dec. 2003;17(4):451-2. Source: PubMed. [pmid: 14870959].
1335 Hansen R, Gaynes B, Thieda P, et al. Meta-analysis of major depressive disorder relapse and recurrence with second-generation antidepressants. Psychiatr Serv. 2008;59(10):1121-30. Source: PubMed. [pmid: 18832497].
1336 Hansen RA, Gartlehner G, Lohr KN, et al. Efficacy and safety of second-generation antidepressants in the treatment of major depressive disorder. Ann Intern Med. Sep. 20. 2005;143(6):415-26. Source: PubMed. [pmid: 16172440].
1337 Hansen RA, Moore CG, Dusetzina SB, et al. Controlling for drug dose in systematic review and meta-analysis: a case study of the effect of antidepressant dose. Med Decis Making. Jan-Feb. 2009;29(1):91-103. Source: PubMed. [pmid: 19141788].
1338 Hargrave R, Martinez D, Bernstein AJ. Fluoxetine-induced seizures. Psychosomatics. Spring. 1992;33(2):236-9. Source: PubMed. [pmid: 1557494].
1339 Harley J, Roberts R, Joyce P, et al. Orosomucoid influences the response to antidepressants in major depressive disorder. J Psychopharmacol. Apr. 2010;24(4):531-5. Source: PubMed. [pmid: 19395425].
1340 Harley R, Petersen T, Scalia M, et al. Problem-solving ability and comorbid personality disorders in depressed outpatients. Depress Anxiety. 2006;23(8):496-501. Source: PubMed. [pmid: 16845662].
1341 Harlow MC, Davidson CM, Bourgeois JA. Psychogenic tremor in a patient with a major depressive episode. S D Med. 2009;62(6):233-5. Source: PubMed. [pmid: 19650275].
1342 Harman JS, Veazie PJ, Lyness JM. Primary care physician office visits for depression by older Americans. Journal of General Internal Medicine. 2006;21(9):926-30. Source: EMBASE. [pmid: 16918736].
1343 Harmer CJ, Shelley NC, Cowen PJ, et al. Increased positive versus negative affective perception and memory in healthy volunteers following selective serotonin and norepinephrine reuptake inhibition. Am J Psychiatry. Jul. 2004;161(7):1256-63. Source: PubMed. [pmid: 15229059].
1344 Haro R, Drucker-Colin R. Effects of long-term administration of nicotine and fluoxetine on sleep in depressed patients. Arch Med Res. Nov-Dec. 2004;35(6):499-506. Source: PubMed. [pmid: 15631874].
1345 Harrer G, Schmidt U, Kuhn U, et al. Comparison of equivalence between the St. John's wort extract LoHyp-57 and fluoxetine. Arzneimittelforschung. Apr. 1999;49(4):289-96. Source: PubMed. [pmid: 10337446].
1346 Harris MG, Benfield P. Fluoxetine. A review of its pharmacodynamic and pharmacokinetic properties, and therapeutic use in older patients with depressive illness. Drugs Aging. Jan. 1995;6(1):64-84. Source: PubMed. [pmid: 7696780].
1347 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001. Apr. 2001;20(3 Suppl):21-35. Source: Handsearch. [pmid: 11306229].
1348 Harrison CL, Ferrier N, Young AH. Tolerability of high-dose venlafaxine in depressed patients. J Psychopharmacol. Jun. 2004;18(2):200-4. Source: PubMed. [pmid: 15260908].
1349 Harrison G, Dilley JW, Loeb L, et al. Priapism and quetiapine: a case report. Psychopharmacol Bull. 2006;39(1):117-9. Source: PubMed. [pmid: 17065976].
1350 Hart S, Fonareva I, Merluzzi N, et al. Treatment for depression and its relationship to improvement in quality of life and psychological well-being in multiple sclerosis patients. Qual Life Res. Apr. 2005;14(3):695-703. Source: PubMed. [pmid: 16022063].
1351 Harto NE, Spera KF, Branconnier RJ. Fluoxetine-induced reduction of body mass in patients with major depressive disorder. Psychopharmacol Bull. 1988;24(2):220-3. Source: PubMed. [pmid: 3264922].
1352 Hartter S, Wetzel H, Hammes E, et al. Serum concentrations of fluvoxamine and clinical effects. A prospective open clinical trial. Pharmacopsychiatry. Sep. 1998;31(5):199-200. Source: PubMed. [pmid: 9832352].
1353 Hartter S, Wetzel H, Hammes E, et al. Nonlinear pharmacokinetics of fluvoxamine and gender differences. Ther Drug Monit. Aug. 1998;20(4):446-9. Source: PubMed. [pmid: 9712472].
1354 Harvey AT, Silkey BS, Kornstein SG, et al. Acute worsening of chronic depression during a double-blind, randomized clinical trial of antidepressant efficacy: differences by sex and menopausal status. J Clin Psychiatry. Jun. 2007;68(6):951-8. Source: PubMed. [pmid: 17592923].
1355 Hashimoto K. Comments on “An innovative design to establish proof of concept of the antidepressant effects of the NR2B subunit selective N-methyl-D-aspartate antagonist, CP-101,606 in patients with treatment-refractory major depressive disorder”. J Clin Psychopharmacol. Aug. 2009;29(4):411-2. author reply 2. Source: PubMed. [pmid: 19593196].
1356 Hassan R, Pollard CA. Late-life-onset panic disorder: clinical and demographic characteristics of a patient sample. J Geriatr Psychiatry Neurol. Apr-Jun. 1994;7(2):84-8. Source: PubMed. [pmid: 8204193].
1357 Haukka J, Arffman M, Partonen T, et al. Antidepressant use and mortality in Finland: A register-linkage study from a nationwide cohort. European Journal of Clinical Pharmacology. 2009;65(7):715-20. Source: Handsearch. [pmid: 19259654].
1358 Hauser P, Khosla J, Aurora H, et al. A prospective study of the incidence and open-label treatment of interferon-induced major depressive disorder in patients with hepatitis C. Mol Psychiatry. 2002;7(9):942-7. Source: PubMed. [pmid: 12399946].
1359 Hawley CJ, Fineberg NA. Commentary on ‘STAR*D: A summary and UK perspective’. Journal of Psychopharmacology. Aug. 2009. 2009;23(6):620-1. Source: PsycINFO. [pmid: 19351796].
1360 Hawley CJ, Pattinson HA, Quick SJ, et al. A protocol for the pharmacologic treatment of major depression. A field test of a potential prototype. J Affect Disord. Jan. 1998;47(1-3):87-96. Source: PubMed. [pmid: 9476748].
1361 Hawley CJ, Quick SJ, Ratnam S, et al. Safety and tolerability of combined treatment with moclobemide and SSRIs: a systematic study of 50 patients. Int Clin Psychopharmacol. Sep. 1996;11(3):187-91. Source: PubMed. [pmid: 8923097].
1362 Hawthorne ME, Lacey JH. Severe disturbance occurring during treatment for depression of a bulimic patient with fluoxetine. J Affect Disord. Nov. 1992;26(3):205-7. Source: PubMed. [pmid: 1460171].
1363 Hayes RL, Gerner RH, Fairbanks L, et al. ECG findings in geriatric depressives given trazodone, placebo, or imipramine. J Clin Psychiatry. May. 1983;44(5):180-3. Source: PubMed. [pmid: 6343360].
1364 Hayford KE, Patten CA, Rummans TA, et al. Efficacy of bupropion for smoking cessation in smokers with a former history of major depression or alcoholism. Br J Psychiatry. Feb. 1999;174:173-8. Source: PubMed. [pmid: 10211174].
1365 Haykal RF, Akiskal HS. The long-term outcome of dysthymia in private practice: clinical features, temperament, and the art of management. J Clin Psychiatry. Aug. 1999;60(8):508-18. Source: PubMed. [pmid: 10485632].
1366 Hayward R, Jordan KP, Croft P. Healthcare use in adults with insomnia: A longitudinal study. British Journal of General Practice. 2010;60(574):334-40. Source: EMBASE. [pmid: 20423585].
1367 Health USDo, Human Services F, Administration D. Guidance for Industry and Investigators. Safety Reporting Requirements for INDs and BA/BE Studies. Draft Guidance. Rockville, MD. United States Department of Health and Human Services, Food and Drug Administration. 2010. Source: Handsearch.
1368 Healy D. Reboxetine: its effects as measured by the Social Adaptation Self-evaluation Scale. Acta Psychiatr Scand Suppl. 2000;402:45-51. Source: PubMed. [pmid: 10901159].
1369 Healy D, Carney PA, O'Halloran A, et al. Peripheral adrenoceptors and serotonin receptors in depression. Changes associated with response to treatment with trazodone or amitriptyline. J Affect Disord. Nov. 1985;9(3):285-96. Source: PubMed. [pmid: 2934461].
1370 Healy D, O'Halloran A, Carney PA, et al. Variations in platelet 5-hydroxytryptamine in control and depressed populations. J Psychiatr Res. 1986;20(4):345-53. Source: PubMed. [pmid: 3806429].
1371 Healy E, McKeon P. Dopaminergic sensitivity and prediction of antidepressant response. J Psychopharmacol. Jun. 2000;14(2):152-6. Source: PubMed. [pmid: 10890309].
1372 Hebenstreit GF, Fellerer K, Zochling R, et al. A pharmacokinetic dose titration study in adult and elderly depressed patients. Acta Psychiatr Scand Suppl. 1989;350:81-4. Source: PubMed. [pmid: 2530795].
1373 Hecht Orzack M, Cole JO, Friedman L, et al. Weight changes in antidepressants: a comparison of amitriptyline and trazodone. Neuropsychobiology. Suppl 1. 1986;15:28-30. Source: PubMed. [pmid: 3725001].
1374 Hegerl U, Hautzinger M, Mergl R, et al. Effects of pharmacotherapy and psychotherapy in depressed primary-care patients: A randomized, controlled trial including a patients' choice arm. International Journal of Neuropsychopharmacology. 2010;13(1):31-44. Source: PsycINFO. [pmid: 19341510].
1375 Hegerl U, Mergl R, Henkel V, et al. Differential effects of reboxetine and citalopram on hand-motor function in patients suffering from major depression. Psychopharmacology (Berl). Feb. 2005;178(1):58-66. Source: PubMed. [pmid: 15316714].
1376 Heijnen WT, van den Broek WW, Mulder PG, et al. Prevalence of trait anxiety in a sample of depressed inpatients and its influence on response to antidepressants. J Psychopharmacol. Apr. 2010;24(4):559-63. Source: PubMed. [pmid: 19028834].
1377 Heiligenstein JH, Faries DE, Rush AJ, et al. Latency to rapid eye movement sleep as a predictor of treatment response to fluoxetine and placebo in nonpsychotic depressed outpatients. Psychiatry Res. Jun. 1994;52(3):327-39. Source: PubMed. [pmid: 7991725].
1378 Heiligenstein JH, Tollefson GD, Faries DE. A double-blind trial of fluoxetine, 20 mg, and placebo in out-patients with DSM-III-R major depression and melancholia. Int Clin Psychopharmacol. Winter. 1993;8(4):247-51. Source: PubMed. [pmid: 8277143].
1379 Heiligenstein JH, Tollefson GD, Faries DE. Response patterns of depressed outpatients with and without melancholia: a double-blind, placebo-controlled trial of fluoxetine versus placebo. J Affect Disord. Mar. 1994;30(3):163-73. Source: PubMed. [pmid: 8006243].
1380 Heiligenstein JH, Ware JE Jr, Beusterien KM, et al. Acute effects of fluoxetine versus placebo on functional health and well-being in late-life depression. Int Psychogeriatr. 1995;7(Suppl):125-37. Source: PubMed. [pmid: 8580388].
1381 Hellerstein DJ, Batchelder S, Kreditor D, et al. Bupropion sustained-release for the treatment of dysthymic disorder: an open-label study. J Clin Psychopharmacol. Jun. 2001;21(3):325-9. Source: PubMed. [pmid: 11386496].
1382 Hellerstein DJ, Batchelder ST, Hyler S, et al. Escitalopram versus placebo in the treatment of dysthymic disorder. International Clinical Psychopharmacology. 2010;25(3):143-8. Source: EMBASE. [pmid: 21811192].
1383 Hellerstein DJ, Batchelder ST, Little SA, et al. Venlafaxine in the treatment of dysthymia: an open-label study. J Clin Psychiatry. Dec. 1999;60(12):845-9. Source: PubMed. [pmid: 10665631].
1384 Hellerstein DJ, Kocsis JH, Chapman D, et al. Double-blind comparison of sertraline, imipramine, and placebo in the treatment of dysthymia: effects on personality. Am J Psychiatry. Sep. 2000;157(9):1436-44. Source: PubMed. [pmid: 10964860].
1385 Hellerstein DJ, Little SA, Samstag LW, et al. Adding group psychotherapy to medication treatment in dysthymia: a randomized prospective pilot study. J Psychother Pract Res. Spring. 2001;10(2):93-103. Source: PubMed. [pmid: 11264333].
1386 Hellerstein DJ, Samstag LW, Cantillon M, et al. Follow-up assessment of medication-treated dysthymia. Prog Neuropsychopharmacol Biol Psychiatry. Apr. 1996;20(3):427-42. Source: PubMed. [pmid: 8771599].
1387 Hellerstein DJ, Yanowitch P, Rosenthal J, et al. Long-term treatment of double depression: a preliminary study with serotonergic antidepressants. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1994;18(1):139-47. Source: PubMed. [pmid: 8115668].
1388 Hellerstein DJ, Yanowitch P, Rosenthal J, et al. A randomized double-blind study of fluoxetine versus placebo in the treatment of dysthymia. Am J Psychiatry. Aug. 1993;150(8):1169-75. Source: PubMed. [pmid: 8328559].
1389 Hellweg R, Ziegenhorn A, Heuser I, et al. Serum concentrations of nerve growth factor and brain-derived neurotrophic factor in depressed patients before and after antidepressant treatment. Pharmacopsychiatry. Mar. 2008;41(2):66-71. Source: PubMed. [pmid: 18311687].
1390 Hendrick V, Altshuler L. Management of major depression during pregnancy. Am J Psychiatry. Oct. 2002;159(10):1667-73. Source: PubMed. [pmid: 12359670].
1391 Hendrickx B, Van MM, Spiers R, et al. The treatment of psychocutaneous disorders: A new approach. Curr Ther Res Clin Exp. 1991;49(1):111-9. Source: EMBASE.
1392 Henkel V, Mergl R, Allgaier AK, et al. Treatment of atypical depression: Post-hoc analysis of a randomized controlled study testing the efficacy of sertraline and cognitive behavioural therapy in mildly depressed outpatients. European Psychiatry. 2010;25(8):491-8. Source: EMBASE. [pmid: 20965118].
1393 Henning O, Niedermaier N, Kniest A, et al. Amitriptyline and paroxetine: effects upon peripheral nervous system (PNS). Journal of Clinical Psychopharmacology. 2002;22(2):229-30. Source: EMBASE. [pmid: 11910274].
1394 Henningsen P, Löwe B. Depression, pain, and somatoform disorders. Current Opinion in Psychiatry. 2006;19(1):19-24. Source: Scopus. [pmid: 16612174].
1395 Henry ME, Kaufman MJ, Hennen J, et al. Cerebral blood volume and clinical changes on the third day of placebo substitution for SSRI treatment. Biol Psychiatry. Jan. 1. 2003;53(1):100-5. Source: PubMed. [pmid: 12513950].
1396 Henry ME, Moore CM, Kaufman MJ, et al. Brain kinetics of paroxetine and fluoxetine on the third day of placebo substitution: a fluorine MRS study. Am J Psychiatry. Sep. 2000;157(9):1506-8. Source: PubMed. [pmid: 10964871].
1397 Henry NL, Stearns V, Flockhart DA, et al. Drug interactions and pharmacogenomics in the treatment of breast cancer and depression. Am J Psychiatry. Oct. 2008;165(10):1251-5. Source: PubMed. [pmid: 18829880].
1398 Hensley PL. Treatment of bereavement-related depression and traumatic grief. J Affect Disord. May. 2006;92(1):117-24. Source: PubMed. [pmid: 16458978].
1399 Hensley PL, Slonimski CK, Uhlenhuth EH, et al. Escitalopram: an open-label study of bereavement-related depression and grief. J Affect Disord. Feb. 2009;113(1-2):142-9. Source: PubMed. [pmid: 18597854].
1400 Herberg KW. Antidepressants and traffic safety. Fortschr Neurol Psychiatr. 1994;62(Suppl 1):24-8. Source: EMBASE. [pmid: 7959523].
1401 Herken H, Gurel A, Selek S, et al. Adenosine Deaminase, Nitric Oxide, Superoxide Dismutase, and Xanthine Oxidase in Patients with Major Depression: Impact of Antidepressant Treatment. Archives of Medical Research. 2007;38(2):247-52. Source: EMBASE. [pmid: 17227736].
1402 Herman JB, Brotman AW, Pollack MH, et al. Fluoxetine-induced sexual dysfunction. J Clin Psychiatry. Jan. 1990;51(1):25-7. Source: PubMed. [pmid: 2295587].
1403 Hernandez CR, Smith GS, Houck PR, et al. The clinical response to total sleep deprivation and recovery sleep in geriatric depression: potential indicators of antidepressant treatment outcome. Psychiatry Res. Dec. 4. 2000;97(1):41-9. Source: PubMed. [pmid: 11104856].
1404 Hernandez-Avila CA, Modesto-Lowe V, Feinn R, et al. Nefazodone treatment of comorbid alcohol dependence and major depression. Alcohol Clin Exp Res. Mar. 2004;28(3):433-40. Source: PubMed. [pmid: 15084901].
1405 Herold N, Uebelhack K, Franke L, et al. Imaging of serotonin transporters and its blockade by citalopram in patients with major depression using a novel SPECT ligand [123I]-ADAM. J Neural Transm. May. 2006;113(5):659-70. Source: PubMed. [pmid: 16465456].
1406 Herrera-Guzman I, Gudayol-Ferre E, Herrera-Abarca JE, et al. Major Depressive Disorder in recovery and neuropsychological functioning: effects of selective serotonin reuptake inhibitor and dual inhibitor depression treatments on residual cognitive deficits in patients with Major Depressive Disorder in recovery. J Affect Disord. Jun. 2010;123(1-3):341-50. Source: PubMed. [pmid: 19896719].
1407 Herrera-Guzman I, Gudayol-Ferre E, Herrera-Guzman D, et al. Effects of selective serotonin reuptake and dual serotonergic-noradrenergic reuptake treatments on memory and mental processing speed in patients with major depressive disorder. J Psychiatr Res. Jun. 2009;43(9):855-63. Source: PubMed. [pmid: 19128810].
1408 Herrera-Guzman I, Gudayol-Ferre E, Lira-Mandujano J, et al. Cognitive predictors of treatment response to bupropion and cognitive effects of bupropion in patients with major depressive disorder. Psychiatry Res. Jul. 15. 2008;160(1):72-82. Source: PubMed. [pmid: 18501971].
1409 Herrera-Guzman I, Herrera-Abarca JE, Gudayol-Ferre E, et al. Effects of selective serotonin reuptake and dual serotonergic-noradrenergic reuptake treatments on attention and executive functions in patients with major depressive disorder. Psychiatry Res. 2010;177(3):323-9. Source: PubMed. [pmid: 20385412].
1410 Hertzberg MA, Feldman ME, Beckham JC, et al. Open trial of nefazodone for combat-related posttraumatic stress disorder. J Clin Psychiatry. Sep. 1998;59(9):460-4. Source: PubMed. [pmid: 9771816].
1411 Hertzberg MA, Feldman ME, Beckham JC, et al. Three- to four-year follow-up to an open trial of nefazodone for combat-related posttraumatic stress disorder. Ann Clin Psychiatry. Dec. 2002;14(4):215-21. Source: PubMed. [pmid: 12630657].
1412 Hetrick Sarah E, Merry Sally N, McKenzie J, et al. Selective serotonin reuptake inhibitors (SSRIs) for depressive disorders in children and adolescents. Cochrane Database of Systematic Reviews. 2007;(3). Source: The Cochrane Library.
1413 Hetrick Sarah E, Purcell R, Garner B, et al. Combined pharmacotherapy and psychological therapies for post traumatic stress disorder (PTSD). Cochrane Database of Systematic Reviews. 2010;(7). Source: The Cochrane Library.
1414 Hetzel G, Moeller O, Erfurth A, et al. The impact of the selective monoamine reuptake inhibitors reboxetine and citalopram on visually-evoked event-related potentials in depressed patients. Pharmacopsychiatry. Sep. 2004;37(5):200-5. Source: PubMed. [pmid: 15470798].
1415 Hetzel G, Moeller O, Evers S, et al. The astroglial protein S100B and visually evoked event-related potentials before and after antidepressant treatment. Psychopharmacology. 2005;178(2-3):161-6. Source: EMBASE. [pmid: 15316717].
1416 Hewer W, Rost W, Gattaz WF. Cardiovascular effects of fluvoxamine and maprotiline in depressed patients. Eur Arch Psychiatry Clin Neurosci. 1995;246(1):1-6. Source: PubMed. [pmid: 8773212].
1417 Hewett K, Chrzanowski W, Jokinen R, et al. Double-blind, placebo-controlled evaluation of extended-release bupropion in elderly patients with major depressive disorder. J Psychopharmacol. Apr. 2010;24(4):521-9. Source: PubMed. [pmid: 19164492].
1418 Hewett K, Chrzanowski W, Schmitz M, et al. Eight-week, placebo-controlled, double-blind comparison of the antidepressant efficacy and tolerability of bupropion XR and venlafaxine XR. J Psychopharmacol. 2009;23(5):531-8. Source: PubMed. [pmid: 18635695].
1419 Hewett K, Gee MD, Krishen A, et al. Double-blind, placebo-controlled comparison of the antidepressant efficacy and tolerability of bupropion XR and venlafaxine XR. J Psychopharmacol. 2010;24(8):1209-16. Source: PubMed. [pmid: 19939870].
1420 Hickie I, Wilson A. A catecholamine model of fatigue. Br J Psychiatry. Aug. 1994;165(2):275-6. Source: PubMed. [pmid: 7953052].
1421 Hicks JA, Argyropoulos SV, Rich AS, et al. Randomised controlled study of sleep after nefazodone or paroxetine treatment in out-patients with depression. Br J Psychiatry. Jun. 2002;180:528-35. Source: PubMed. [pmid: 12042232].
1422 Higgins JPT, Green S. Cochrane Handbook for Systematic Reviews of Interventions 4.2.5. Cochrane Handbook for Systematic Reviews of Interventions 425. 2005. Source: Scopus.
1423 Hilleret H, Voirol P, Bovier P, et al. Very long half-life of paroxetine following intoxication in an extensive cytochrome P4502D6 metabolizer. Ther Drug Monit. Aug. 2002;24(4):567-9. Source: PubMed. [pmid: 12142644].
1424 Himmelhoch JM, Schechtman K, Auchenbach R. The role of trazodone in the treatment of depressed cardiac patients. Psychopathology. Suppl 2. 1984;17:51-63. Source: PubMed. [pmid: 6201941].
1425 Himmerich H, Fulda S, Schaaf L, et al. Changes in weight and glucose tolerance during treatment with mirtazapine. Diabetes Care. Jan. 2006;29(1):170. Source: PubMed. [pmid: 16373922].
1426 Hindmarch I. A review of the psychomotor effects of paroxetine. Int Clin Psychopharmacol. Jun. Suppl 4. 1992;6:65-7. Source: PubMed. [pmid: 1431014].
1427 Hindmarch I, Kimber S, Cockle SM. Abrupt and brief discontinuation of antidepressant treatment: effects on cognitive function and psychomotor performance. Int Clin Psychopharmacol. Nov. 2000;15(6):305-18. Source: PubMed. [pmid: 11110006].
1428 Hintz S, Kuck J, Peterkin JJ, et al. Depression in the context of human immunodeficiency virus infection: implications for treatment. J Clin Psychiatry. Dec. 1990;51(12):497-501. Source: PubMed. [pmid: 2258363].
1429 Hirose S. Restlessness related to SSRI withdrawal. Psychiatry Clin Neurosci. Feb. 2001;55(1):79-80. Source: PubMed. [pmid: 11235863].
1430 Hirose S, Ashby CR Jr. An open pilot study combining risperidone and a selective serotonin reuptake inhibitor as initial antidepressant therapy. J Clin Psychiatry. Aug. 2002;63(8):733-6. Source: PubMed. [pmid: 12197455].
1431 Hirschfeld RM. Guidelines for the long-term treatment of depression. J Clin Psychiatry. Dec. 1994;55(Suppl):61-9. discussion 70-1. Source: PubMed. [pmid: 7814359].
1432 Hirschfeld RM. Efficacy of SSRIs and newer antidepressants in severe depression: comparison with TCAs. J Clin Psychiatry. May. 1999;60(5):326-35. Source: PubMed. [pmid: 10362442].
1433 Hirschfeld RM, Dunner DL, Keitner G, et al. Does psychosocial functioning improve independent of depressive symptoms? A comparison of nefazodone, psychotherapy, and their combination. Biol Psychiatry. Jan. 15. 2002;51(2):123-33. Source: PubMed. [pmid: 11822991].
1434 Hirschfeld RM, Mallinckrodt C, Lee TC, et al. Time course of depression-symptom improvement during treatment with duloxetine. Depress Anxiety. 2005;21(4):170-7. Source: PubMed. [pmid: 16035056].
1435 Hirschfeld RM, Russell JM, Delgado PL, et al. Predictors of response to acute treatment of chronic and double depression with sertraline or imipramine. J Clin Psychiatry. Dec. 1998;59(12):669-75. Source: PubMed. [pmid: 9921701].
1436 Hirschfeld RMA, Fochtmann LJ, McIntyre JS. To The Editor: Antidepressants for Bipolar Depression. The American Journal of Psychiatry. Aug. 2005. 2005;162(8):1546-7. Source: PsycINFO. [pmid: 16055788].
1437 Hoagwood K, Hibbs E, Brent D, et al. Introduction to the special section: efficacy and effectiveness in studies of child and adolescent psychotherapy. J Consult Clin Psychol. 1995. Oct. 1995;63(5):683-7. Source: Handsearch. [pmid: 7593860].
1438 Hobara T, Uchida S, Otsuki K, et al. Altered gene expression of histone deacetylases in mood disorder patients. Journal of psychiatric research. 2010;44(5):263-70. Source: EMBASE. [pmid: 19767015].
1439 Hochberg HM, Kanter D, Houser VP. Electrocardiographic findings during extended clinical trials of fluvoxamine in depression: one years experience. Pharmacopsychiatry. Nov. 1995;28(6):253-6. Source: PubMed. [pmid: 8773292].
1440 Hochstrasser B, Isaksen PM, Koponen H, et al. Prophylactic effect of citalopram in unipolar, recurrent depression: placebo-controlled study of maintenance therapy. Br J Psychiatry. Apr. 2001;178:304-10. Source: PubMed. [pmid: 11282808].
1441 Hocqueloux L, Gallien S, Bornstain C, et al. Quadricyclic antidepressant overdosage in a patient with AIDS under mega-highly active antiretroviral therapy. Arch Intern Med. Oct. 8. 2001;161(18):2260-1. Source: PubMed. [pmid: 11575985].
1442 Hoehn-Saric R, Ninan P, Black DW, et al. Multicenter double-blind comparison of sertraline and desipramine for concurrent obsessive-compulsive and major depressive disorders. Arch Gen Psychiatry. Jan. 2000;57(1):76-82. Source: PubMed. [pmid: 10632236].
1443 Hoehn-Saric R, Schlaepfer TE, Greenberg BD, et al. Cerebral blood flow in obsessive-compulsive patients with major depression: effect of treatment with sertraline or desipramine on treatment responders and non-responders. Psychiatry Res. Nov. 30. 2001;108(2):89-100. Source: PubMed. [pmid: 11738543].
1444 Hoencamp E, Haffmans J, Dijken WA, et al. Lithium augmentation of venlafaxine: an open-label trial. J Clin Psychopharmacol. Oct. 2000;20(5):538-43. Source: PubMed. [pmid: 11001238].
1445 Hoeppner J, Padberg F, Domes G, et al. Influence of repetitive transcranial magnetic stimulation on psychomotor symptoms in major depression. European Archives of Psychiatry and Clinical Neuroscience. 2010;260(3):197-202. Source: EMBASE. [pmid: 19680706].
1446 Hoes MJ, Zeijpveld JH. First report of mirtazapine overdose. Int Clin Psychopharmacol. Jun. 1996;11(2):147. Source: PubMed. [pmid: 8803652].
1447 Hoflich G, Kasper S, Danos P, et al. Thyroid hormones, body temperature, and antidepressant treatment. Biol Psychiatry. Apr. 15. 1992;31(8):859-62. Source: PubMed. [pmid: 1643199].
1448 Holl AK, Wilkinson L, Painold A, et al. Combating depression in Huntington's disease: effective antidepressive treatment with venlafaxine XR. Int Clin Psychopharmacol. Jan. 2010;25(1):46-50. Source: PubMed. [pmid: 19996754].
1449 Holland JC, Romano SJ, Heiligenstein JH, et al. A controlled trial of fluoxetine and desipramine in depressed women with advanced cancer. Psychooncology. Jul-Aug. 1998;7(4):291-300. Source: PubMed. [pmid: 9741068].
1450 Hollister LE, Krajewski K, Rustin T, et al. Drugs for cocaine dependence: not easy. Arch Gen Psychiatry. Nov. 1992;49(11):905-6. Source: PubMed. [pmid: 1444730].
1451 Hollon SD, DeRubeis RJ, Shelton RC, et al. Prevention of relapse following cognitive therapy vs medications in moderate to severe depression. Arch Gen Psychiatry. Apr. 2005;62(4):417-22. Source: PubMed. [pmid: 15809409].
1452 Hollon SD, Jarrett RB, Nierenberg AA, et al. Psychotherapy and Medication in the Treatment of Adult and Geriatric Depression: Which Monotherapy or Combined Treatment?. Journal of Clinical Psychiatr. Apr. 2005. 2005;66(4):455-68. Source: PsycINFO.
1453 Hollon SD, Shelton RC, Wisniewski S, et al. Presenting characteristics of depressed outpatients as a function of recurrence: preliminary findings from the STAR*D clinical trial. J Psychiatr Res. Feb. 2006;40(1):59-69. Source: PubMed. [pmid: 16243357].
1454 Holma IAK, Holma KM, Melartin TK, et al. Maintenance pharmacotherapy for recurrent major depressive disorder: 5-Year follow-up study. British Journal of Psychiatry. 2008;193(2):163-4. Source: EMBASE. [pmid: 18670005].
1455 Holma KM, Holma IAK, Melartin TK, et al. Long-term outcome of major depressive disorder in psychiatric patients is variable. Journal of Clinical Psychiatry. 2008;69(2):196-205. Source: Scopus. [pmid: 18251627].
1456 Holshoe JM. Antidepressants and sleep: a review. Perspect Psychiatr Care. Jul. 2009;45(3):191-7. Source: PubMed. [pmid: 19566691].
1457 Holtzheimer PE 3rd, Meeks TW, Kelley ME, et al. A double blind, placebo-controlled pilot study of galantamine augmentation of antidepressant treatment in older adults with major depression. Int J Geriatr Psychiatry. Jun. 2008;23(6):625-31. Source: PubMed. [pmid: 18058832].
1458 Holtzheimer PE, Veitengruber J, Wang CC, et al. Utility of the Beck Depression Inventory to screen for and track depression in injection drug users seeking hepatitis C treatment. General Hospital Psychiatry. 2010;32(4):426-32. Source: EMBASE. [pmid: 20633748].
1459 Holzbach R, Jahn H, Pajonk FG, et al. Suicide attempts with mirtazapine overdose without complications. Biol Psychiatry. Nov. 1. 1998;44(9):925-6. Source: PubMed. [pmid: 9807651].
1460 Hon D, Preskorn SH. Mania during fluoxetine treatment for recurrent depression. Am J Psychiatry. Dec. 1989;146(12):1638-9. Source: PubMed. [pmid: 2589562].
1461 Hong CJ, Hu WH, Chen CC, et al. A double-blind, randomized, group-comparative study of the tolerability and efficacy of 6 weeks' treatment with mirtazapine or fluoxetine in depressed Chinese patients. J Clin Psychiatry. Aug. 2003;64(8):921-6. Source: PubMed. [pmid: 12927007].
1462 Hong Ng C, Norman TR, Naing KO, et al. A comparative study of sertraline dosages, plasma concentrations, efficacy and adverse reactions in Chinese versus Caucasian patients. Int Clin Psychopharmacol. Mar. 2006;21(2):87-92. Source: PubMed. [pmid: 16421459].
1463 Honig A, Kuyper AM, Schene AH, et al. Treatment of post-myocardial infarction depressive disorder: a randomized, placebo-controlled trial with mirtazapine. Psychosom Med. 2007;69(7):606-13. Source: PubMed. [pmid: 17846258].
1464 Hood SD, Hince DA, Davies SJC, et al. Effects of acute tryptophan depletion in serotonin reuptake inhibitor-remitted patients with generalized anxiety disorder. Psychopharmacology. 2010;208(2):223-32. Source: EMBASE. [pmid: 19936713].
1465 Hooshyar D, Goulet J, Chwastiak L, et al. Time to depression treatment in primary care among HIV-infected and uninfected veterans. Journal of general internal medicine. 2010;25(7):656-62. Source: EMBASE. [pmid: 20405335].
1466 Hornig-Rohan M, Amsterdam JD. Venlafaxine versus stimulant therapy in patients with dual diagnosis ADD and depression. Prog Neuropsychopharmacol Biol Psychiatry. Apr. 2002;26(3):585-9. Source: PubMed. [pmid: 11999912].
1467 Horstmann S, Dose T, Lucae S, et al. Suppressive effect of mirtazapine on the hpa system in acutely depressed women seems to be transient and not related to antidepressant action. Psychoneuroendocrinology. 2009;34(2):238-48. Source: PsycINFO. [pmid: 18926641].
1468 Horstmann S, Lucae S, Menke A, et al. Polymorphisms in GRIK4, HTR2A, and FKBP5 show interactive effects in predicting remission to antidepressant treatment. Neuropsychopharmacology. 2010;35(3):727-40. Source: EMBASE. [pmid: 19924111].
1469 Höschl C, Švestka J. Escitalopram for the treatment of major depression and anxiety disorders. Expert Review of Neurotherapeutics. 2008;8(4):537-52. Source: Scopus. [pmid: 18416657].
1470 Houck C. An open-label pilot study of fluvoxamine for mixed anxiety-depression. Psychopharmacol Bull. 1998;34(2):225-7. Source: PubMed. [pmid: 9641005].
1471 Houck PR, Mazumdar S, Koru-Sengul T, et al. Estimating treatment effects from longitudinal clinical trial data with missing values: comparative analyses using different methods. Psychiatry Res. Dec. 15. 2004;129(2):209-15. Source: PubMed. [pmid: 15590048].
1472 Hougardy DM, Egberts TC, van der Graaf F, et al. Serotonin transporter polymorphism and bleeding time during SSRI therapy. Br J Clin Pharmacol. May. 2008;65(5):761-6. Source: PubMed. [pmid: 18279474].
1473 Houlihan DJ. Serotonin syndrome resulting from coadministration of tramadol, venlafaxine, and mirtazapine. Ann Pharmacother. Mar. 2004;38(3):411-3. Source: PubMed. [pmid: 14970364].
1474 Howland RH. Electroencephalography technology for predicting response to antidepressant medications. Journal of Psychosocial Nursing & Mental Health Services. Oct. 2006. 2006;44(10):11-4. Source: PsycINFO.
1475 Howland RH, Rush AJ, Wisniewski SR, et al. Concurrent anxiety and substance use disorders among outpatients with major depression: clinical features and effect on treatment outcome. Drug Alcohol Depend. Jan. 1. 2009;99(1-3):248-60. Source: PubMed. [pmid: 18986774].
1476 Howland RH, Wilson MG, Kornstein SG, et al. Factors predicting reduced antidepressant response: experience with the SNRI duloxetine in patients with major depression. Ann Clin Psychiatry. Oct-Dec. 2008;20(4):209-18. Source: PubMed. [pmid: 19034753].
1477 Hoyberg OJ, Maragakis B, Mullin J, et al. A double-blind multicentre comparison of mirtazapine and amitriptyline in elderly depressed patients. Acta Psychiatr Scand. Mar. 1996;93(3):184-90. Source: PubMed. [pmid: 8739664].
1478 Hrdina PD, Bakish D, Ravindran A, et al. Platelet serotonergic indices in major depression: up-regulation of 5-HT2A receptors unchanged by antidepressant treatment. Psychiatry Res. Feb. 7. 1997;66(2-3):73-85. Source: PubMed. [pmid: 9075272].
1479 Hrdina PD, Demeter E, Vu TB, et al. 5-HT uptake sites and 5-HT2 receptors in brain of antidepressant-free suicide victims/depressives: increase in 5-HT2 sites in cortex and amygdala. Brain Res. Jun. 18. 1993;614(1-2):37-44. Source: PubMed. [pmid: 8348328].
1480 Hruby R, Nosalova G, Hruba S. Predictive significance of TCI-R for antidepressant treatment. Case Reports and Clinical Practice Review. 2010;16(8):CR383-8. Source: EMBASE.
1481 Hruby R, Nosalova G, Ondrejka I, et al. Personality changes during antidepressant treatment. Psychiatr Danub. 2009;21(1):25-32. Source: PubMed. [pmid: 19270618].
1482 Hsiao CC. Difference in pre- and post-treatment plasma DHEA levels were significantly and positively correlated with difference in pre- and post-treatment Hamilton depression scores following successful therapy for major depression. Psychoneuroendocrinology. Aug. 2006;31(7):839-46. Source: PubMed. [pmid: 16716529].
1483 Hsueh KL, Lin PY. Treatment-resistant depression prior to the diagnosis of cryptococcal meningitis: A case report. General Hospital Psychiatry. 2010;32(5):560.e9-.e10. Source: EMBASE. [pmid: 20851285].
1484 Hu XZ, Rush AJ, Charney D, et al. Association between a functional serotonin transporter promoter polymorphism and citalopram treatment in adult outpatients with major depression. Arch Gen Psychiatry. Jul. 2007;64(7):783-92. Source: PubMed. [pmid: 17606812].
1485 Huang CC, Shiah IS, Chen HK, et al. Adjunctive use of methylphenidate in the treatment of psychotic unipolar depression. Clin Neuropharmacol. Jul-Aug. 2008;31(4):245-7. Source: PubMed. [pmid: 18670250].
1486 Huang CC, Wei IH. Unexpected interaction between quetiapine and valproate in patients with bipolar disorder. General Hospital Psychiatry. 2010;32(4):446.e1-.e2. Source: EMBASE. [pmid: 20633751].
1487 Huang TL, Lee CT, Liu YL. Serum brain-derived neurotrophic factor levels in patients with major depression: Effects of antidepressants. Journal of Psychiatric Research. 2008;42(7):521-5. Source: EMBASE. [pmid: 17585940].
1488 Hudson JI, Wohlreich MM, Kajdasz DK, et al. Safety and tolerability of duloxetine in the treatment of major depressive disorder: analysis of pooled data from eight placebo-controlled clinical trials. Human Psychopharmacology: Clinical and Experimental. 2005;20(5):327-41. Source: Handsearch. [pmid: 15912562].
1489 Hung CI, Wang SJ, Liu CY. Validation of the Depression and Somatic Symptoms Scale by comparison with the Short Form 36 scale among psychiatric outpatients with major depressive disorder. Depress Anxiety. 2009;26(6):583-91. Source: PubMed. [pmid: 19242983].
1490 Hunter AM, Leuchter AF, Morgan ML, et al. Changes in brain function (quantitative EEG cordance) during placebo lead-in and treatment outcomes in clinical trials for major depression. Am J Psychiatry. Aug. 2006;163(8):1426-32. Source: PubMed. [pmid: 16877657].
1491 Hunter AM, Muthén BO, Cook IA, et al. Antidepressant response trajectories and quantitative electroencephalography (QEEG) biomarkers in major depressive disorder. Journal of psychiatric research. 2010;(2):90-8. Source: The Cochrane Library. [pmid: 19631948].
1492 Hunziker ME, Suehs BT, Bettinger TL, et al. Duloxetine hydrochloride: a new dual-acting medication for the treatment of major depressive disorder. Clin Ther. 2005;27(8):1126-43. Source: PubMed. [pmid: 16199241].
1493 Husain MM, Rush AJ, Sackeim HA, et al. Age-related characteristics of depression: a preliminary STAR*D report. Am J Geriatr Psychiatry. Oct. 2005;13(10):852-60. Source: PubMed. [pmid: 16223963].
1494 Husain MM, Rush AJ, Trivedi MH, et al. Pain in depression: STAR*D study findings. J Psychosom Res. Aug. 2007;63(2):113-22. Source: PubMed. [pmid: 17662746].
1495 Husain MM, Rush JA, Wisniewski SR, et al. Family history of depression and therapeutic outcome: findings from STAR*D. J Clin Psychiatry. Feb. 2009;70(2):185-95. Source: PubMed. [pmid: 19192454].
1496 Huskamp HA, Busch AB, Domino ME, et al. Antidepressant reformulations: Who uses them, and what are the benefits?. Health Affairs. 2009;28(3):734-45. Source: EMBASE. [pmid: 19414882].
1497 Hutchinson DR, Tong S, Moon CA, et al. Paroxetine in the treatment of elderly depressed patients in general practice: a double-blind comparison with amitriptyline. Int Clin Psychopharmacol. Jun. Suppl 4. 1992;6:43-51. Source: PubMed. [pmid: 1431010].
1498 Huyse FJ, Zwaan WA, Kupka R. The applicability of antidepressants in the depressed medically ill: an open clinical trial with fluoxetine. J Psychosom Res. Oct. 1994;38(7):695-703. Source: PubMed. [pmid: 7877124].
1499 Hwang JP, Yang CH, Tsai SJ. Comparison study of venlafaxine and paroxetine for the treatment of depression in elderly Chinese inpatients. Int J Geriatr Psychiatry. Feb. 2004;19(2):189-90. Source: PubMed. [pmid: 14758586].
1500 Hybels CF, Steffens DC, McQuoid DR, et al. Residual symptoms in older patients treated for major depression. International Journal of Geriatric Psychiatry. 2005;20(12):1196-202. Source: Scopus. [pmid: 16315146].
1501 Hylan TR, Crown WH, Meneades L, et al. SSRI antidepressant drug use patterns in the naturalistic setting: a multivariate analysis. Med Care. Apr. 1999;37(4 Suppl Lilly):AS36-44. Source: PubMed. [pmid: 10217392].
1502 Hypericum Depression Trial Study Group. Effect of Hypericum perforatum (St John's wort) in major depressive disorder: a randomized controlled trial. Jama. Apr. 10. 2002;287(14):1807-14. Source: PubMed. [pmid: 11939866].
1503 Iacoviello BM, McCarthy KS, Barrett MS, et al. Treatment preferences affect the therapeutic alliance: implications for randomized controlled trials. J Consult Clin Psychol. Feb. 2007;75(1):194-8. Source: PubMed. [pmid: 17295580].
1504 Ibor JJ, Carrasco JL, Prieto R, et al. Effectiveness and safety of venlafaxine extended release in elderly depressed patients. Arch Gerontol Geriatr. May-Jun. 2008;46(3):317-26. Source: PubMed. [pmid: 17617478].
1505 Iga J, Ueno S, Yamauchi K, et al. Altered HDAC5 and CREB mRNA expressions in the peripheral leukocytes of major depression. Prog Neuropsychopharmacol Biol Psychiatry. Apr. 13. 2007;31(3):628-32. Source: PubMed. [pmid: 17258370].
1506 Iga J, Ueno S, Yamauchi K, et al. Gene expression and association analysis of vascular endothelial growth factor in major depressive disorder. Prog Neuropsychopharmacol Biol Psychiatry. Apr. 13. 2007;31(3):658-63. Source: PubMed. [pmid: 17257729].
1507 Ikenouchi-Sugita A, Yoshimura R, Hori H, et al. Effects of antidepressants on plasma metabolites of nitric oxide in major depressive disorder: comparison between milnacipran and paroxetine. Prog Neuropsychopharmacol Biol Psychiatry. Nov. 13. 2009;33(8):1451-3. Source: PubMed. [pmid: 19664676].
1508 Imperadore G, Cipriani A, Signoretti A, et al. Citalopram versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2007;(2). Source: Scopus.
1509 IMS Health. Press Release: Growth is sustained by new products despite a difficult year. http://www.imshealth.com/ims/portal/front/articleC/0,2777,6599_3665_44771558,00.html. IMS Reports. 2004. February. 17. 2004. Source: Handsearch.
1510 indicated Na. Antidepressant efficacy may be enhanced with dual reuptake inhibition. South African Psychiatry Review. Feb. 2006. 2006;9(1):65. Source: PsycINFO.
1511 Ioannidis JP. Ranking antidepressants. Lancet. May. 23. 2009;373(9677):1759-60. author reply 61-2. Source: PubMed. [pmid: 19465221].
1512 Ioannidis JPA, Evans SJW, GÃ¸tzsche PC, et al. Better Reporting of Harms in Randomized Trials: An Extension of the CONSORT Statement. Annals of Internal Medicine. November. 16. 2004. 2004;141(10):781-8. Source: Handsearch. [pmid: 15545678].
1513 Ioannou C. Media coverage versus fluoxetine as the cause of suicidal ideation. Am J Psychiatry. Apr. 1992;149(4):572. Source: PubMed. [pmid: 1554048].
1514 Iodice AJ, McCall WV. ECT resistance and early relapse: two cases of subsequent response to venlafaxine. J Ect. Dec. 2003;19(4):238-41. Source: PubMed. [pmid: 14657779].
1515 Iosifescu DV, Clementi-Craven N, Fraguas R, et al. Cardiovascular risk factors may moderate pharmacological treatment effects in major depressive disorder. Psychosom Med. Sep-Oct. 2005;67(5):703-6. Source: PubMed. [pmid: 16204427].
1516 Iosifescu DV, Nierenberg AA, Alpert JE, et al. Comorbid medical illness and relapse of major depressive disorder in the continuation phase of treatment. Psychosomatics. Sep-Oct. 2004;45(5):419-25. Source: PubMed. [pmid: 15345787].
1517 Iosifescu DV, Nierenberg AA, Alpert JE, et al. The impact of medical comorbidity on acute treatment in major depressive disorder. Am J Psychiatry. Dec. 2003;160(12):2122-7. Source: PubMed. [pmid: 14638581].
1518 Iosifescu DV, Renshaw PF, Lyoo IK, et al. Brain white-matter hyperintensities and treatment outcome in major depressive disorder. British Journal of Psychiatry. 2006;188(FEB):180-5. Source: EMBASE. [pmid: 16449707].
1519 Ipser Jonathan V, Sander C, Stein Dan J. Pharmacotherapy and psychotherapy for body dysmorphic disorder. Cochrane Database of Systematic Reviews. 2009;(1). Source: The Cochrane Library.
1520 Iraqi A, Baickle E. A case report of hyponatremia with citalopram use. J Am Med Dir Assoc. Jan-Feb. 2004;5(1):64-5. Source: PubMed. [pmid: 14726801].
1521 Isaac MT, Tome MB. Pindolol-paroxetine combination. Am J Psychiatry. Dec. 1997;154(12):1790-1. Source: PubMed. [pmid: 9396965].
1522 Isaac MT, Tome MB. Selective serotonin reuptake inhibitors plus pindolol. Lancet. Jul. 26. 1997;350(9073):288-9. Source: PubMed. [pmid: 9242815].
1523 Isacsson G, Reutfors J, Papadopoulos FC, et al. Antidepressant medication prevents suicide in depression. Acta psychiatrica Scandinavica. 2010;122(6):454-60. Source: PsycINFO. [pmid: 20384599].
1524 IsHak WW, Davis M, Jeffrey J, et al. The role of dopaminergic agents in improving quality of life in major depressive disorder. Curr Psychiatry Rep. Dec. 2009;11(6):503-8. Source: PubMed. [pmid: 19909674].
1525 Ishii M, Tatsuzawa Y, Yoshino A, et al. Serotonin syndrome induced by augmentation of SSRI with methylphenidate. Psychiatry Clin Neurosci. Apr. 2008;62(2):246. Source: PubMed. [pmid: 18412855].
1526 Itil TM, Shrivastava RK, Mukherjee S, et al. A double-blind placebo-controlled study of fluvoxamine and imipramine in out-patients with primary depression. Br J Clin Pharmacol. Suppl 3. 1983;15:433S-8S. Source: PubMed. [pmid: 6407504].
1527 Ivanova JI, Birnbaum HG, Kidolezi Y, et al. Direct and indirect costs of employees with treatment-resistant and non-treatment-resistant major depressive disorder. Current Medical Research and Opinion. 2010;26(10):2475-84. Source: EMBASE. [pmid: 20825269].
1528 Jacob S, Spinler SA. Hyponatremia associated with selective serotonin-reuptake inhibitors in older adults. Ann Pharmacother. Sep. 2006;40(9):1618-22. Source: PubMed. [pmid: 16896026].
1529 Jacobi C, Dahme B, Dittmann R. Cognitive-behavioural, fluoxetine and combined treatment for bulimia nervosa: Short- and long-term results. European Eating Disorders Review. 2002;10(3):179-98. Source: EMBASE.
1530 Jacobsen FM. Fluoxetine-induced sexual dysfunction and an open trial of yohimbine. J Clin Psychiatry. Apr. 1992;53(4):119-22. Source: PubMed. [pmid: 1564046].
1531 Jaffe PD, Batziris HP, van der Hoeven P, et al. A study involving venlafaxine overdoses: comparison of fatal and therapeutic concentrations in postmortem specimens. J Forensic Sci. Jan. 1999;44(1):193-6. Source: PubMed. [pmid: 9987886].
1532 Jagsch C, Marksteiner J, Seiringer E, et al. Successful mirtazapine treatment of an 81-year-old patient with syndrome of inappropriate antidiuretic hormone secretion. Pharmacopsychiatry. May. 2007;40(3):129-31. Source: PubMed. [pmid: 17541890].
1533 Jahn H, Schick M, Kiefer F, et al. Metyrapone as additive treatment in major depression: a double-blind and placebo-controlled trial. Arch Gen Psychiatry. Dec. 2004;61(12):1235-44. Source: PubMed. [pmid: 15583115].
1534 Jakob F, Wolf J. EPMS under antidepressive therapy with fluvoxamine and concomitant antibiotic therapy with clindamycin. Pharmacopsychiatry. May. 2007;40(3):129. Source: PubMed. [pmid: 17541891].
1535 Jamerson BD, Krishnan KR, Roberts J, et al. Effect of bupropion SR on specific symptom clusters of depression: analysis of the 31-item Hamilton Rating Scale for depression. Psychopharmacol Bull. Spring. 2003;37(2):67-78. Source: PubMed. [pmid: 14566216].
1536 Jang BS, Kim H, Lim SW, et al. Serum S100B levels and major depressive disorder: Its characteristics and role in antidepressant response. Psychiatry Investigation. 2008;5(3):193-8. Source: EMBASE. [pmid: 20046365].
1537 Janicak PG, Nahas Z, Lisanby SH, et al. Durability of clinical benefit with transcranial magnetic stimulation (TMS) in the treatment of pharmacoresistant major depression: Assessment of relapse during a 6-month, multisite, open-label study. Brain Stimulation. 2010;3(4):187-99. Source: PsycINFO. [pmid: 20965447].
1538 Jansen JP, Crawford B, Bergman G, et al. Bayesian meta-analysis of multiple treatment comparisons: an introduction to mixed treatment comparisons. Value Health. Sep-Oct. 2008;11(5):956-64. Source: PubMed. [pmid: 18489499].
1539 Janssen J, Hulshoff Pol HE, Schnack HG, et al. Cerebral volume measurements and subcortical white matter lesions and short-term treatment response in late life depression. Int J Geriatr Psychiatry. May. 2007;22(5):468-74. Source: PubMed. [pmid: 17357181].
1540 Jarrett RB, Thase ME. Comparative efficacy and durability of continuation phase cognitive therapy for preventing recurrent depression: Design of a double-blinded, fluoxetine- and pill placebo-controlled, randomized trial with 2-year follow-up. Contemporary clinical trials. 2010;31(4):355-77. Source: EMBASE. [pmid: 20451668].
1541 Jarvik LF. Trazodone for treatment of older depressed patients: comment. J Clin Psychopharmacol. Dec. 1988;8(6):449-50. Source: PubMed. [pmid: 3069883].
1542 Javed MA. Priapism associated with fluoxetine therapy: a case report. J Pak Med Assoc. Feb. 1996;46(2):45-6. Source: PubMed. [pmid: 8683851].
1543 Jazayeri S, Tehrani-Doost M, Keshavarz SA, et al. Comparison of therapeutic effects of omega-3 fatty acid eicosapentaenoic acid and fluoxetine, separately and in combination, in major depressive disorder. Aust N Z J Psychiatry. Mar. 2008;42(3):192-8. Source: PubMed. [pmid: 18247193].
1544 Jefferson JW. Bupropion extended-release for depressive disorders. Expert Rev Neurother. May. 2008;8(5):715-22. Source: PubMed. [pmid: 18457528].
1545 Jefferson JW, Pradko JF, Muir KT. Bupropion for major depressive disorder: Pharmacokinetic and formulation considerations. Clin Ther. Nov. 2005;27(11):1685-95. Source: PubMed. [pmid: 16368442].
1546 Jefferson JW, Rush AJ, Nelson JC, et al. Extended-release bupropion for patients with major depressive disorder presenting with symptoms of reduced energy, pleasure, and interest: findings from a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. 2006;67(6):865-73. Source: PubMed. [pmid: 16848645].
1547 Jenner PN. Paroxetine: an overview of dosage, tolerability, and safety. Int Clin Psychopharmacol. Jun. Suppl 4. 1992;6:69-80. Source: PubMed. [pmid: 1431015].
1548 Jerome L. Bupropion and drug-induced parkinsonism. Can J Psychiatry. Aug. 2001;46(6):560-1. Source: PubMed. [pmid: 11526815].
1549 Jiang W, O'Connor C, Silva SG, et al. Safety and Efficacy of Sertraline for Depression in Patients with CHF (SADHART-CHF): A randomized, double-blind, placebo-controlled trial of sertraline for major depression with congestive heart failure. American Heart Journal. 2008;156(3):437-44. Source: Handsearch. [pmid: 18760123].
1550 Jick H, Kaye JA, Jick SS. Antidepressants and the risk of suicidal behaviors. Jama. Jul. 21. 2004;292(3):338-43. Source: PubMed. [pmid: 15265848].
1551 Jick H, Ulcickas M, Dean A. Comparison of frequencies of suicidal tendencies among patients receiving fluoxetine, lofepramine, mianserin, or trazodone. Pharmacotherapy. 1992;12(6):451-4. Source: PubMed. [pmid: 1492009].
1552 Jick SS, Dean AD, Jick H. Antidepressants and suicide. Bmj. Jan. 28. 1995;310(6974):215-8. Source: PubMed. [pmid: 7677826].
1553 Jick SS, Li L. Antidepressant drug use and risk of venous thromboembolism. Pharmacotherapy. 2008;28(2):144-50. Source: PubMed. [pmid: 18225961].
1554 Jimenez F, Velasco F, Salin-Pascual R, et al. A patient with a resistant major depression disorder treated with deep brain stimulation in the inferior thalamic peduncle. Neurosurgery. 2005;57(3):585-92. Source: EMBASE. [pmid: 16145540].
1555 Jimenez-Genchi A. Immediate switching from moclobemide to duloxetine may induce serotonin syndrome. J Clin Psychiatry. Nov. 2006;67(11):1821-2. Source: PubMed. [pmid: 17196070].
1556 Jin Y, Pollock BG, Frank E, et al. Effect of age, weight, and CYP2C19 genotype on escitalopram exposure. J Clin Pharmacol. Jan. 2010;50(1):62-72. Source: PubMed. [pmid: 19841156].
1557 Jindal RD, Friedman ES, Berman SR, et al. Effects of sertraline on sleep architecture in patients with depression. J Clin Psychopharmacol. Dec. 2003;23(6):540-8. Source: PubMed. [pmid: 14624183].
1558 Joffe G, Appelberg B, Rimon R. Adjunctive nefazodone in neuroleptic-treated schizophrenic patients with predominantly negative symptoms: an open prospective pilot study. Int Clin Psychopharmacol. Jul. 1999;14(4):233-8. Source: PubMed. [pmid: 10468316].
1559 Joffe H, Soares CN, Petrillo LF, et al. Treatment of depression and menopause-related symptoms with the serotonin-norepinephrine reuptake inhibitor duloxetine. J Clin Psychiatry. Jun. 2007;68(6):943-50. Source: PubMed. [pmid: 17592922].
1560 Joffe RT. Triiodothyronine potentiation of fluoxetine in depressed patients. Can J Psychiatry. Feb. 1992;37(1):48-50. Source: PubMed. [pmid: 1551045].
1561 Joffe RT, Levitt AJ, Sokolov ST, et al. Response to an open trial of a second SSRI in major depression. J Clin Psychiatry. Mar. 1996;57(3):114-5. Source: PubMed. [pmid: 8617695].
1562 Joffe RT, Marshall AM, Lee DK. A large open-label study of venlafaxine in depressed outpatients by community-based physicians. J Clin Psychiatry. Oct. 1998;59(10):515-20. Source: PubMed. [pmid: 9818632].
1563 John AP, Koloth R. Severe serotonin toxicity and manic switch induced by combined use of tramadol and paroxetine. Aust N Z J Psychiatry. Feb. 2007;41(2):192-3. Source: PubMed. [pmid: 17484083].
1564 Johnson EM, Whyte E, Mulsant BH, et al. Cardiovascular changes associated with venlafaxine in the treatment of late-life depression. Am J Geriatr Psychiatry. Sep. 2006;14(9):796-802. Source: PubMed. [pmid: 16943176].
1565 Johnson MR, Lydiard RB, Morton WA, et al. Effect of fluvoxamine, imipramine and placebo on catecholamine function in depressed outpatients. J Psychiatr Res. Apr-Jun. 1993;27(2):161-72. Source: PubMed. [pmid: 8396179].
1566 Johnston JA, Lineberry CG, Ascher JA, et al. A 102-center prospective study of seizure in association with bupropion. J Clin Psychiatry. Nov. 1991;52(11):450-6. Source: PubMed. [pmid: 1744061].
1567 Joliat MJ, Schmidt ME, Fava M, et al. Long-term treatment outcomes of depression with associated anxiety: efficacy of continuation treatment with fluoxetine. J Clin Psychiatry. 2004;65(3):373-8. Source: PubMed. [pmid: 15096077].
1568 Jones JE, Hermann BP, Barry JJ, et al. Clinical assessment of axis I psychiatric morbidity in chronic epilepsy: A multicenter investigation. Journal of Neuropsychiatry and Clinical Neurosciences. 2005;17(2):172-9. Source: EMBASE. [pmid: 15939970].
1569 Jones LE, Turvey C, Carney-Doebbeling C. Inadequate follow-up care for depression and its impact on antidepressant treatment duration among veterans with and without diabetes mellitus in the Veterans Health Administration. General Hospital Psychiatry. 2006;28(6):465-74. Source: EMBASE. [pmid: 17088161].
1570 Jonsson GW, Moosa MY, Jeenah FY. Toxic epidermal necrolysis and fluoxetine: a case report. J Clin Psychopharmacol. Feb. 2008;28(1):93-5. Source: PubMed. [pmid: 18204349].
1571 Joo JH, Lenze EJ, Mulsant BH, et al. Risk factors for falls during treatment of late-life depression. J Clin Psychiatry. Oct. 2002;63(10):936-41. Source: PubMed. [pmid: 12416604].
1572 Joos AA, Konig F, Frank UG, et al. Dose-dependent pharmacokinetic interaction of clozapine and paroxetine in an extensive metabolizer. Pharmacopsychiatry. Nov. 1997;30(6):266-70. Source: PubMed. [pmid: 9442550].
1573 Joseph AP, Farmer A. An unusual case of central pontine myelinolysis. Alcohol Alcohol. Jul. 1995;30(4):423-5. Source: PubMed. [pmid: 8540908].
1574 Joyce PR, Luty SE, McKenzie JM, et al. Bipolar II disorder: personality and outcome in two clinical samples. Aust N Z J Psychiatry. Jun. 2004;38(6):433-8. Source: PubMed. [pmid: 15209835].
1575 Joyce PR, McKenzie JM, Luty SE, et al. Temperament, childhood environment and psychopathology as risk factors for avoidant and borderline personality disorders. Aust N Z J Psychiatry. Dec. 2003;37(6):756-64. Source: PubMed. [pmid: 14636393].
1576 Joyce PR, McKenzie JM, Mulder RT, et al. Genetic, developmental and personality correlates of self-mutilation in depressed patients. Aust N Z J Psychiatry. Mar. 2006;40(3):225-9. Source: PubMed. [pmid: 16476149].
1577 Joyce PR, Mulder RT, Luty SE, et al. Age-dependent antidepressant pharmacogenomics: polymorphisms of the serotonin transporter and G protein beta3 subunit as predictors of response to fluoxetine and nortriptyline. Int J Neuropsychopharmacol. Dec. 2003;6(4):339-46. Source: PubMed. [pmid: 14604448].
1578 Joyce PR, Mulder RT, Luty SE, et al. A differential response to nortriptyline and fluoxetine in melancholic depression: the importance of age and gender. Acta Psychiatr Scand. Jul. 2003;108(1):20-3. Source: PubMed. [pmid: 12807373].
1579 Joyce PR, Mulder RT, Luty SE, et al. Borderline personality disorder in major depression: symptomatology, temperament, character, differential drug response, and 6-month outcome. Compr Psychiatry. Jan-Feb. 2003;44(1):35-43. Source: PubMed. [pmid: 12524634].
1580 Joyce PR, Mulder RT, Luty SE, et al. Patterns and predictors of remission, response and recovery in major depression treated with fluoxetine or nortriptyline. Aust N Z J Psychiatry. Jun. 2002;36(3):384-91. Source: PubMed. [pmid: 12060188].
1581 Joyce PR, Porter RJ, Mulder RT, et al. Reversed diurnal variation in depression: associations with a differential antidepressant response, tryptophan: large neutral amino acid ratio and serotonin transporter polymorphisms. Psychol Med. Apr. 2005;35(4):511-7. Source: PubMed. [pmid: 15856721].
1582 Juckel G, Pogarell O, Augustin H, et al. Differential prediction of first clinical response to serotonergic and noradrenergic antidepressants using the loudness dependence of auditory evoked potentials in patients with major depressive disorder. J Clin Psychiatry. Aug. 2007;68(8):1206-12. Source: PubMed. [pmid: 17854244].
1583 Judd FK, Moore K, Norman TR, et al. A multicentre double blind trial of fluoxetine versus amitriptyline in the treatment of depressive illness. Aust N Z J Psychiatry. Mar. 1993;27(1):49-55. Source: PubMed. [pmid: 8481170].
1584 Judd LL, Rapaport MH, Yonkers KA, et al. Randomized, placebo-controlled trial of fluoxetine for acute treatment of minor depressive disorder. Am J Psychiatry. Oct. 2004;161(10):1864-71. Source: PubMed. [pmid: 15465984].
1585 Judge R. Patient perspectives on once-weekly fluoxetine. J Clin Psychiatry. Suppl 22. 2001;62:53-7. Source: PubMed. [pmid: 11599651].
1586 Judge R, Parry MG, Quail D, et al. Discontinuation symptoms: comparison of brief interruption in fluoxetine and paroxetine treatment. Int Clin Psychopharmacol. Sep. 2002;17(5):217-25. Source: PubMed. [pmid: 12177584].
1587 Judge R, Plewes JM, Kumar V, et al. Changes in energy during treatment of depression: an analysis of fluoxetine in double-blind, placebo-controlled trials. J Clin Psychopharmacol. Dec. 2000;20(6):666-72. Source: PubMed. [pmid: 11106139].
1588 Jureidini JN, Tonkin AL. Clinical practice guidelines for depression in young people. Med J Aust. Mar. 17. 2003;178(6):300. author reply -2. Source: PubMed. [pmid: 12633493].
1589 Juurlink DN, Mamdani MM, Kopp A, et al. The risk of suicide with selective serotonin reuptake inhibitors in the elderly. American Journal of Psychiatry. 2006;163(5):813-21. Source: Scopus. [pmid: 16648321].
1590 Kadusevicius E, Mikucionyte L, Maciulaitis R, et al. Trends in the consumption of antidepressant drugs in Lithuania in 2002-2004. Medicina (Kaunas, Lithuania). 2006;42(12):1020-9. Source: Scopus.
1591 Kafka MP, Prentky R. Fluoxetine treatment of nonparaphilic sexual addictions and paraphilias in men. J Clin Psychiatry. Oct. 1992;53(10):351-8. Source: PubMed. [pmid: 1429474].
1592 Kahn DG. Increased plasma nortriptyline concentration in a patient cotreated with fluoxetine. J Clin Psychiatry. Jan. 1990;51(1):36. Source: PubMed. [pmid: 2295592].
1593 Kalayam B, Alexopoulos GS. A preliminary study of left frontal region error negativity and symptom improvement in geriatric depression. Am J Psychiatry. Nov. 2003;160(11):2054-6. Source: PubMed. [pmid: 14594757].
1594 Kalia R, Magsalin RM, Khan AY, et al. Mania possibly induced by desvenlafaxine. Journal of Psychiatric Practice. 2010;16(1):58-62. Source: PsycINFO. [pmid: 20098233].
1595 Kalman J, Palotas A, Juhasz A, et al. Impact of venlafaxine on gene expression profile in lymphocytes of the elderly with major depression - Evolution of antidepressants and the role of the “neuro-immune” system. Neurochemical Research. 2005;30(11):1429-38. Source: EMBASE. [pmid: 16341940].
1596 Kamath J, Handratta V. Desvenlafaxine succinate for major depressive disorder: a critical review of the evidence. Expert Rev Neurother. Dec. 2008;8(12):1787-97. Source: PubMed. [pmid: 19086875].
1597 Kamath V, Kamath S, Ramkisson R. Maintenance ect over nine years in schizoaffective disorder. German Journal of Psychiatry. 2010;13(2):100-3. Source: EMBASE.
1598 Kamijima K, Burt T, Cohen G, et al. A placebo-controlled, randomized withdrawal study of sertraline for major depressive disorder in Japan. Int Clin Psychopharmacol. 2006;21(1):1-9. Source: PubMed. [pmid: 16317311].
1599 Kamijima K, Koyama T, Mita T, et al. Clinical evaluation of sertraline hydrochloride, a selective serotonin reuptake inhibitor in the treatment of depression and depressive state: A double-blind, group comparison study of sertraline by hydrochloride vs amitriptyline hydrochloride. Japanese Journal of Neuropsychopharmacology. 1997;19(6):529-48. Source: EMBASE.
1600 Kamo T, Horikawa N, Tsuruta Y, et al. Efficacy and pharmacokinetics of fluvoxamine maleate in patients with mild depression undergoing hemodialysis. Psychiatry Clin Neurosci. Apr. 2004;58(2):133-7. Source: PubMed. [pmid: 15009816].
1601 Kane JM, Cole K, Sarantakos S, et al. Safety and efficacy of bupropion in elderly patients: preliminary observations. J Clin Psychiatry. May. 1983;44(5 Pt 2):134-6. Source: PubMed. [pmid: 6406442].
1602 Kaneda Y, Kawamura I, Fujii A, et al. Serotonin syndrome - ‘potential’ role of the CYP2D6 genetic polymorphism in Asians. Int J Neuropsychopharmacol. Mar. 2002;5(1):105-6. Source: PubMed. [pmid: 12057035].
1603 Kaneda Y, Ohmori T, Okabe H. Possible mild serotonin syndrome related to co-prescription of tandospirone and trazodone. Gen Hosp Psychiatry. Mar-Apr. 2001;23(2):98-101. Source: PubMed. [pmid: 11354048].
1604 Kang EH, Lee IS, Chung SK, et al. Mirtazapine versus venlafaxine for the treatment of somatic symptoms associated with major depressive disorder: a randomized, open-labeled trial. Psychiatry Res. 2009;169(2):118-23. Source: PubMed. [pmid: 19695711].
1605 Kang RH, Choi MJ, Paik JW, et al. Effect of serotonin receptor 2A gene polymorphism on mirtazapine response in major depression. Int J Psychiatry Med. 2007;37(3):315-29. Source: PubMed. [pmid: 18314859].
1606 Kang RH, Hahn SW, Choi MJ, et al. Relationship between G-protein beta-3 subunit C825T polymorphism and mirtazapine responses in Korean patients with major depression. Neuropsychobiology. 2007. 2007;56(1):1-5. Source: PsycINFO. [pmid: 17943025].
1607 Kang RH, Wong ML, Choi MJ, et al. Association study of the serotonin transporter promotor polymorphism and mirtazapine antidepressant response in major depressive disorder. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Aug. 2007. 2007;31(6):1317-21. Source: PsycINFO. [pmid: 17618721].
1608 Kao YC, Shiah IS, Lee WK, et al. Deanxit-associated tardive dyskinesia and tardive akathisia in a depressed patient. Acta Neuropsychiatrica. 2010;22(1):47-8. Source: PsycINFO.
1609 Kapitany T, Schindl M, Schindler SD, et al. The citalopram challenge test in patients with major depression and in healthy controls. Psychiatry Res. Nov. 8. 1999;88(2):75-88. Source: PubMed. [pmid: 10622344].
1610 Kaplan EM. Efficacy of venlafaxine in patients with major depressive disorder who have unsustained or no response to selective serotonin reuptake inhibitors: an open-label, uncontrolled study. Clin Ther. Jul. 2002;24(7):1194-200. Source: PubMed. [pmid: 12182262].
1611 Karlsson H, Hirvonen J, Kajander J, et al. Research letter: Psychotherapy increases brain serotonin 5-HT1A receptors in patients with major depressive disorder. Psychological medicine. 2010;(3):523-8. Source: The Cochrane Library. [pmid: 19903365].
1612 Karlsson I, Godderis J, Augusto De Mendonca Lima C, et al. A randomised, double-blind comparison of the efficacy and safety of citalopram compared to mianserin in elderly, depressed patients with or without mild to moderate dementia. Int J Geriatr Psychiatry. Apr. 2000;15(4):295-305. Source: PubMed. [pmid: 10767728].
1613 Karnik NS, Maldonado JR. Antidepressant and statin interactions: a review and case report of simvastatin and nefazodone-induced rhabdomyolysis and transaminitis. Psychosomatics. Nov-Dec. 2005;46(6):565-8. Source: PubMed. [pmid: 16288136].
1614 Karp JF, Skidmore E, Lotz M, et al. Use of the late-life function and disability instrument to assess disability in major depression. J Am Geriatr Soc. Sep. 2009;57(9):1612-9. Source: PubMed. [pmid: 19682111].
1615 Karp JF, Weiner D, Seligman K, et al. Body pain and treatment response in late-life depression. Am J Geriatr Psychiatry. Mar. 2005;13(3):188-94. Source: PubMed. [pmid: 15728749].
1616 Karp JF, Weiner DK, Dew MA, et al. Duloxetine and care management treatment of older adults with comorbid major depressive disorder and chronic low back pain: Results of an open-label pilot study. International journal of geriatric psychiatry. 2010;25(6):633-42. Source: PsycINFO. [pmid: 19750557].
1617 Karson CN, Newton JE, Livingston R, et al. Human brain fluoxetine concentrations. J Neuropsychiatry Clin Neurosci. Summer. 1993;5(3):322-9. Source: PubMed. [pmid: 8369643].
1618 Kasckow J, Fellows I, Golshan S, et al. Treatment of subsyndromal depressive symptoms in middle-age and older patients with schizophrenia: Effect of age on response. American Journal of Geriatric Psychiatry. 2010;18(9):853-7. Source: EMBASE. [pmid: 20808103].
1619 Kasckow J, Lanouette N, Patterson T, et al. Treatment of subsyndromal depressive symptoms in middle-aged and older adults with schizophrenia: Effect on functioning. International journal of geriatric psychiatry. 2010;25(2):183-90. Source: EMBASE. [pmid: 19711335].
1620 Kashner TM, Trivedi MH, Wicker A, et al. Voice response system to measure healthcare costs: a STAR*D report. Am J Manag Care. Mar. 2009;15(3):153-62. Source: PubMed. [pmid: 19298096].
1621 Kashner TM, Trivedi MH, Wicker A, et al. The impact of nonclinical factors on care use for patients with depression: a STAR*D report. CNS Neurosci Ther. Winter. 2009;15(4):320-32. Source: PubMed. [pmid: 19712127].
1622 Kasper S, Baldwin DS, Larsson Lonn S, et al. Superiority of escitalopram to paroxetine in the treatment of depression. European Neuropsychopharmacology. 2009;19(4):229-37. Source: PubMed. [pmid: 19185467].
1623 Kasper S, de Swart H, Friis Andersen H. Escitalopram in the treatment of depressed elderly patients. Am J Geriatr Psychiatry. Oct. 2005;13(10):884-91. Source: PubMed. [pmid: 16223967].
1624 Kasper S, Dotsch M, Kick H, et al. Plasma concentrations of fluvoxamine and maprotiline in major depression: implications on therapeutic efficacy and side effects. Eur Neuropsychopharmacol. Mar. 1993;3(1):13-21. Source: PubMed. [pmid: 8471827].
1625 Kasper S, el Giamal N, Hilger E. Reboxetine: the first selective noradrenaline re-uptake inhibitor. Expert Opin Pharmacother. May. 2000;1(4):771-82. Source: PubMed. [pmid: 11249515].
1626 Kasper S, Hajak G, Wulff K, et al. Efficacy of the novel antidepressant agomelatine on the circadian rest-activity cycle and depressive and anxiety symptoms in patients with major depressive disorder: a randomized, double-blind comparison with sertraline. J Clin Psychiatry. Feb. 2010;71(2):109-20. Source: PubMed. [pmid: 20193645].
1627 Kasper S, Lemming OM, de Swart H. Escitalopram in the long-term treatment of major depressive disorder in elderly patients. Neuropsychobiology. 2006;54(3):152-9. Source: PubMed. [pmid: 17230032].
1628 Kasper S, Moller HJ, Montgomery SA, et al. Antidepressant efficacy in relation to item analysis and severity of depression: a placebo-controlled trial of fluvoxamine versus imipramine. Int Clin Psychopharmacol. Jan. Suppl 4. 1995;9:3-12. Source: PubMed. [pmid: 7622821].
1629 Kasper S, Montgomery SA, Moller HJ, et al. Longitudinal analysis of the suicidal behaviour risk in short-term placebo-controlled studies of mirtazapine in major depressive disorder. World J Biol Psychiatry. 2010;11(1):36-44. Source: PubMed. [pmid: 20146649].
1630 Kasper S, Olivieri L, Di Loreto G, et al. A comparative, randomised, double-blind study of trazodone prolonged-release and paroxetine in the treatment of patients with major depressive disorder. Curr Med Res Opin. Aug. 2005;21(8):1139-46. Source: PubMed. [pmid: 16083521].
1631 Kasper S, Spadone C, Verpillat P, et al. Onset of action of escitalopram compared with other antidepressants: Results of a pooled analysis. International Clinical Psychopharmacology. Mar. 2006. 2006;21(2):105-10. Source: PsycINFO. [pmid: 16421462].
1632 Kasper S, Voll G, Vieira A, et al. Response to total sleep deprivation before and during treatment with fluvoxamine or maprotiline in patients with major depression--results of a double-blind study. Pharmacopsychiatry. May. 1990;23(3):135-42. Source: PubMed. [pmid: 2115680].
1633 Kasper S, Volz HP, Moller HJ, et al. Continuation and long-term maintenance treatment with Hypericum extract WS 5570 after recovery from an acute episode of moderate depression--a double-blind, randomized, placebo controlled long-term trial. Eur Neuropsychopharmacol. Nov. 2008;18(11):803-13. Source: PubMed. [pmid: 18694635].
1634 Kasper S, Zivkov M, Roes KC, et al. Pharmacological treatment of severely depressed patients: a meta-analysis comparing efficacy of mirtazapine and amitriptyline. Eur Neuropsychopharmacol. May. 1997;7(2):115-24. Source: PubMed. [pmid: 9169299].
1635 Kato M, Fukuda T, Serretti A, et al. ABCB1 (MDR1) gene polymorphisms are associated with the clinical response to paroxetine in patients with major depressive disorder. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 15. 2008;32(2):398-404. Source: PubMed. [pmid: 17913323].
1636 Kato M, Ikenaga Y, Wakeno M, et al. Controlled clinical comparison of paroxetine and fluvoxamine considering the serotonin transporter promoter polymorphism. Int Clin Psychopharmacol. May. 2005;20(3):151-6. Source: PubMed. [pmid: 15812265].
1637 Kato M, Zanardi R, Rossini D, et al. 5-HT2A gene variants influence specific and different aspects of antidepressant response in Japanese and Italian mood disorder patients. Psychiatry Res. May. 15. 2009;167(1-2):97-105. Source: PubMed. [pmid: 19361869].
1638 Katon W, Russo J, Frank E, et al. Predictors of nonresponse to treatment in primary care patients with dysthymia. Gen Hosp Psychiatry. Jan-Feb. 2002;24(1):20-7. Source: PubMed. [pmid: 11814530].
1639 Katona CL, Abou-Saleh MT, Harrison DA, et al. Placebo-controlled trial of lithium augmentation of fluoxetine and lofepramine. Br J Psychiatry. Jan. 1995;166(1):80-6. Source: PubMed. [pmid: 7894881].
1640 Katona CL, Hunter BN, Bray J. A double-blind comparison of the efficacy and safely of paroxetine and imipramine in the treatment of depression with dementia. Int J Geriatr Psychiatry. Feb. 1998;13(2):100-8. Source: PubMed. [pmid: 9526179].
1641 Katz LY, Kozyrskyj AL, Prior HJ, et al. Effect of regulatory warnings on antidepressant prescription rates, use of health services and outcomes among children, adolescents and young adults. Canadian Medical Association Journal. 2008;178(8):1005-11. Source: EMBASE. [pmid: 18390943].
1642 Katz MM, Tekell JL, Bowden CL, et al. Onset and early behavioral effects of pharmacologically different antidepressants and placebo in depression. Neuropsychopharmacology. Mar. 2004;29(3):566-79. Source: PubMed. [pmid: 14627997].
1643 Katz RJ, Rosenthal M. Adverse interaction of cyproheptadine with serotonergic antidepressants. J Clin Psychiatry. Jul. 1994;55(7):314-5. Source: PubMed. [pmid: 8071295].
1644 Katz T, Fisher P, Katz A, et al. The feasibility of a randomised, placebo-controlled clinical trial of homeopathic treatment of depression in general practice. Homeopathy. Jul. 2005;94(3):145-52. Source: PubMed. [pmid: 16060200].
1645 Katzelnick DJ, Simon GE, Pearson SD, et al. Randomized trial of a depression management program in high utilizers of medical care. Arch Fam Med. Apr. 2000;9(4):345-51. Source: PubMed. [pmid: 10776363].
1646 Katzman MA, Tricco AC, McIntosh D, et al. Paroxetine versus placebo and other agents for depressive disorders: a systematic review and meta-analysis. J Clin Psychiatry. 2007;68(12):1845-59. Source: PubMed. [pmid: 18162015].
1647 Kaufeler R, Meier B, Brattstrom A. Efficacy and tolerability of Ze 117 St. John's wort extract in comparison with placebo, imipramine and fluoxetine for the treatment of mild to moderate depression according to ICD-10. An overview. Pharmacopsychiatry. Jul. Suppl 1. 2001;34:S49-50. Source: PubMed. [pmid: 11518076].
1648 Kauffman RP, Castracane VD, White DL, et al. Impact of the selective serotonin reuptake inhibitor citalopram on insulin sensitivity, leptin and basal cortisol secretion in depressed and non-depressed euglycemic women of reproductive age. Gynecol Endocrinol. Sep. 2005;21(3):129-37. Source: PubMed. [pmid: 16335904].
1649 Kaufman KR, Mohebati A, Sotolongo A. Pseudoseizures and hysterical stridor. Epilepsy Behav. Apr. 2004;5(2):269-72. Source: PubMed. [pmid: 15123032].
1650 Kaufman MJ, Henry ME, Frederick B, et al. Selective serotonin reuptake inhibitor discontinuation syndrome is associated with a rostral anterior cingulate choline metabolite decrease: a proton magnetic resonance spectroscopic imaging study. Biol Psychiatry. Sep. 1. 2003;54(5):534-9. Source: PubMed. [pmid: 12946882].
1651 Kavoussi RJ, Hauger RL, Coccaro EF. Prolactin response to d-fenfluramine in major depression before and after treatment with serotonin reuptake inhibitors. Biol Psychiatry. Feb. 1. 1999;45(3):295-9. Source: PubMed. [pmid: 10023505].
1652 Kavoussi RJ, Segraves RT, Hughes AR, et al. Double-blind comparison of bupropion sustained release and sertraline in depressed outpatients. J Clin Psychiatry. Dec. 1997;58(12):532-7. Source: PubMed. [pmid: 9448656].
1653 Kaye CM, Haddock RE, Langley PF, et al. A review of the metabolism and pharmacokinetics of paroxetine in man. Acta Psychiatr Scand Suppl. 1989;350:60-75. Source: PubMed. [pmid: 2530793].
1654 Kaynak H, Kaynak D, Gozukirmizi E, et al. The effects of trazodone on sleep in patients treated with stimulant antidepressants. Sleep Med. Jan. 2004;5(1):15-20. Source: PubMed. [pmid: 14725822].
1655 Keck PE Jr, McElroy SL. Ratio of plasma fluoxetine to norfluoxetine concentrations and associated sedation. J Clin Psychiatry. Apr. 1992;53(4):127-9. Source: PubMed. [pmid: 1564047].
1656 Keedwell P, Drapier D, Surguladze S, et al. Neural markers of symptomatic improvement during antidepressant therapy in severe depression: Subgenual cingulate and visual cortical responses to sad, but not happy, facial stimuli are correlated with changes in symptom score. Journal of Psychopharmacology. 2009;23(7):775-88. Source: EMBASE. [pmid: 18635699].
1657 Keegan D, Bowen RC, Blackshaw S, et al. A comparison of fluoxetine and amitriptyline in the treatment of major depression. Int Clin Psychopharmacol. Summer. 1991;6(2):117-24. Source: PubMed. [pmid: 1960381].
1658 Keene MS, Eaddy MT, Mauch RP, et al. Differences in compliance patterns across the selective serotonin reuptake inhibitors (SSRIs). Curr Med Res Opin. Oct. 2005;21(10):1651-8. Source: PubMed. [pmid: 16238905].
1659 Keene MS, Eaddy MT, Nelson WW, et al. Adherence to paroxetine CR compared with paroxetine IR in a Medicare-eligible population with anxiety disorders. Am J Manag Care. Oct. 2005;11(12 Suppl):S362-9. Source: PubMed. [pmid: 16236018].
1660 Kelin K, Berk M, Spann M, et al. Duloxetine 60 mg/day for the prevention of depressive recurrences: Post hoc analyses from a recurrence prevention study. International journal of clinical practice. 2010;64(6):719-26. Source: EMBASE. [pmid: 20345508].
1661 Keller MB. Citalopram therapy for depression: a review of 10 years of European experience and data from U.S. clinical trials. J Clin Psychiatry. Dec. 2000;61(12):896-908. Source: PubMed. [pmid: 11206593].
1662 Keller MB. Paroxetine treatment of major depressive disorder. Psychopharmacol Bull. Spring. Suppl 1. 2003;37:42-52. Source: PubMed. [pmid: 14566200].
1663 Keller MB, Gelenberg AJ, Hirschfeld RM, et al. The treatment of chronic depression, part 2: a double-blind, randomized trial of sertraline and imipramine. J Clin Psychiatry. Nov. 1998;59(11):598-607. Source: PubMed. [pmid: 9862606].
1664 Keller MB, Kocsis JH, Thase ME, et al. Maintenance phase efficacy of sertraline for chronic depression: a randomized controlled trial. Jama. Nov. 18. 1998;280(19):1665-72. Source: PubMed. [pmid: 9831997].
1665 Keller MB, McCullough JP, Klein DN, et al. A comparison of nefazodone, the cognitive behavioral-analysis system of psychotherapy, and their combination for the treatment of chronic depression. N Engl J Med. May. 18. 2000;342(20):1462-70. Source: PubMed. [pmid: 10816183].
1666 Keller MB, Trivedi MH, Thase ME, et al. The Prevention of Recurrent Episodes of Depression with Venlafaxine for Two Years (PREVENT) study: outcomes from the acute and continuation phases. Biol Psychiatry. 2007;62(12):1371-9. Source: PubMed. [pmid: 17825800].
1667 Keller MB, Trivedi MH, Thase ME, et al. The Prevention of Recurrent Episodes of Depression with Venlafaxine for Two Years (PREVENT) Study: Outcomes from the 2-year and combined maintenance phases. J Clin Psychiatry. 2007;68(8):1246-56. Source: PubMed. [pmid: 17854250].
1668 Kellett JM. Fluvoxamine: an antidepressant for the elderly?. J Psychiatry Neurosci. Jul. 1991;16(2 Suppl 1):26-9. Source: PubMed. [pmid: 1931933].
1669 Kelly AM. Does the clinically significant difference in visual analog scale pain scores vary with gender, age, or cause of pain?. Acad Emerg Med. Nov. 1998;5(11):1086-90. Source: PubMed. [pmid: 9835471].
1670 Kelly AM. The minimum clinically significant difference in visual analogue scale pain score does not differ with severity of pain. Emerg Med J. May. 2001;18(3):205-7. Source: PubMed. [pmid: 11354213].
1671 Kelly CM, Juurlink DN, Gomes T, et al. Selective serotonin reuptake inhibitors and breast cancer mortality in women receiving tamoxifen: a population based cohort study. Bmj. 2010;340:c693. Source: PubMed. [pmid: 20142325].
1672 Kelly MW, Perry PJ, Holstad SG, et al. Serum fluoxetine and norfluoxetine concentrations and antidepressant response. Ther Drug Monit. 1989;11(2):165-70. Source: PubMed. [pmid: 2785723].
1673 Kelly O, Matheson K, Ravindran A, et al. Ruminative coping among patients with dysthymia before and after pharmacotherapy. Depress Anxiety. 2007;24(4):233-43. Source: PubMed. [pmid: 17004237].
1674 Kennedy GJ. Advances in the treatment of late-life psychotic depression. Primary Psychiatry. 2008;15(7):27-9. Source: EMBASE.
1675 Kennedy S. Flibanserin: Initial evidence of efficacy on sexual dysfunction, in patients with major depressive disorder. Journal of Sexual Medicine. 2010;7(10):3449-59. Source: EMBASE. [pmid: 20646181].
1676 Kennedy SE, Koeppe RA, Young EA, et al. Dysregulation of endogenous opioid emotion regulation circuitry in major depression in women. Arch Gen Psychiatry. Nov. 2006;63(11):1199-208. Source: PubMed. [pmid: 17088500].
1677 Kennedy SH, Andersen HF, Lam RW. Efficacy of escitalopram in the treatment of major depressive disorder compared with conventional selective serotonin reuptake inhibitors and venlafaxine XR: a meta-analysis. J Psychiatry Neurosci. 2006;31(2):122-31. Source: PubMed. [pmid: 16575428].
1678 Kennedy SH, Andersen HF, Thase ME. Escitalopram in the treatment of major depressive disorder: a meta-analysis. Curr Med Res Opin. 2009;25(1):161-75. Source: PubMed. [pmid: 19210149].
1679 Kennedy SH, Eisfeld BS, Dickens SE, et al. Antidepressant-induced sexual dysfunction during treatment with moclobemide, paroxetine, sertraline, and venlafaxine. J Clin Psychiatry. Apr. 2000;61(4):276-81. Source: PubMed. [pmid: 10830148].
1680 Kennedy SH, Evans KR, Kruger S, et al. Changes in regional brain glucose metabolism measured with positron emission tomography after paroxetine treatment of major depression. Am J Psychiatry. Jun. 2001;158(6):899-905. Source: PubMed. [pmid: 11384897].
1681 Kennedy SH, Fulton KA, Bagby RM, et al. Sexual function during bupropion or paroxetine treatment of major depressive disorder. Can J Psychiatry. Mar. 2006;51(4):234-42. Source: PubMed. [pmid: 16629348].
1682 Kennedy SH, Konarski JZ, Segal ZV, et al. Differences in brain glucose metabolism between responders to CBT and venlafaxine in a 16-week randomized controlled trial. Am J Psychiatry. May. 2007;164(5):778-88. Source: PubMed. [pmid: 17475737].
1683 Kennedy SH, Rizvi S, Fulton K, et al. A double-blind comparison of sexual functioning, antidepressant efficacy, and tolerability between agomelatine and venlafaxine XR. J Clin Psychopharmacol. Jun. 2008;28(3):329-33. Source: PubMed. [pmid: 18480691].
1684 Kenny ER, O'Brien JT, Cousins DA, et al. Functional connectivity in late-life depression using resting-state functional magnetic resonance imaging. American Journal of Geriatric Psychiatry. 2010;18(7):643-51. Source: EMBASE. [pmid: 20220591].
1685 Kerr JS, Fairweather DB, Hindmarch I. Effects of fluoxetine on psychomotor performance, cognitive function and sleep in depressed patients. Int Clin Psychopharmacol. Winter. 1993;8(4):341-3. Source: PubMed. [pmid: 8277161].
1686 Kerr TA, McClelland HA, Stephens DA, et al. Trazodone. A comparative clinical and predictive study. Acta Psychiatr Scand. Dec. 1984;70(6):573-7. Source: PubMed. [pmid: 6395636].
1687 Kessler RC, Berglund P, Demler O, et al. The epidemiology of major depressive disorder: results from the National Comorbidity Survey Replication (NCS-R). JAMA. 2003. Jun. 18. 2003;289(23):3095-105. Source: Handsearch. [pmid: 12813115].
1688 Kessler RC, Berglund P, Demler O, et al. Lifetime prevalence and age-of-onset distributions of DSM-IV disorders in the national comorbidity survey replication. Archives of General Psychiatry. 2005;62(6):593-602. Source: Scopus. [pmid: 15939837].
1689 Kessler RC, Demler O, Frank RG, et al. Prevalence and treatment of mental disorders, 1990 to 2003. New England Journal of Medicine. 2005;352(24):2515-23. Source: Scopus. [pmid: 15958807].
1690 Kessler RC, McGonagle KA, Zhao S, et al. Lifetime and 12-month prevalence of DSM-III-R psychiatric disorders in the United States. Results from the National Comorbidity Survey. Arch Gen Psychiatry. 1994. Jan. 1994;51(1):8-19. Source: Handsearch. [pmid: 8279933].
1691 Ketter TA, Jenkins JB, Schroeder DH, et al. Carbamazepine but not valproate induces bupropion metabolism. J Clin Psychopharmacol. Oct. 1995;15(5):327-33. Source: PubMed. [pmid: 8830063].
1692 Khan A, Bose A, Alexopoulos GS, et al. Double-blind comparison of escitalopram and duloxetine in the acute treatment of major depressive disorder. Clin Drug Investig. 2007;27(7):481-92. Source: PubMed.
1693 Khan A, Brodhead AE, Kolts RL, et al. Severity of depressive symptoms and response to antidepressants and placebo in antidepressant trials. Journal of Psychiatric Research. 2005;39(2):145-50. Source: Scopus. [pmid: 15589562].
1694 Khan A, Brodhead AE, Schwartz KA, et al. Sex differences in antidepressant response in recent antidepressant clinical trials. J Clin Psychopharmacol. Aug. 2005;25(4):318-24. Source: PubMed. [pmid: 16012273].
1695 Khan A, Cohen S, Dager S, et al. Onset of response in relation to outcome in depressed outpatients with placebo and imipramine. J Affect Disord. Jul-Aug. 1989;17(1):33-8. Source: PubMed. [pmid: 2525576].
1696 Khan A, Fabre LF, Rudolph R. Venlafaxine in depressed outpatients. Psychopharmacol Bull. 1991;27(2):141-4. Source: PubMed. [pmid: 1924660].
1697 Khan A, Khan S, Kolts R, et al. Suicide rates in clinical trials of SSRIs, other antidepressants, and placebo: analysis of FDA reports. Am J Psychiatry. Apr. 2003;160(4):790-2. Source: PubMed. [pmid: 12668373].
1698 Khan A, Schwartz KA, Kolts RL, et al. BMI, sex, and antidepressant response. J Affect Disord. 2007;99(1-3):101-6. Source: PubMed. [pmid: 17010444].
1699 Khan A, Shad MU, Preskorn SH. Lack of sertraline efficacy probably due to an interaction with carbamazepine. J Clin Psychiatry. Jul. 2000;61(7):526-7. Source: PubMed. [pmid: 10937612].
1700 Khan A, Upton GV, Rudolph RL, et al. The use of venlafaxine in the treatment of major depression and major depression associated with anxiety: a dose-response study. Venlafaxine Investigator Study Group. J Clin Psychopharmacol. Feb. 1998;18(1):19-25. Source: PubMed. [pmid: 9472838].
1701 Khan AY, Carrithers J, Preskorn SH, et al. Clinical and demographic factors associated with DSM-IV melancholic depression. Ann Clin Psychiatry. Apr-Jun. 2006;18(2):91-8. Source: PubMed. [pmid: 16754414].
1702 Khan MC. A randomised, double-blind, placebo-controlled, 5-weeks' study of Org 3770 (mirtazapine) in major depression. Hum Psychopharmacol. 1995;10(Suppl 2):S119-S24. Source: EMBASE.
1703 Khandker RK, Kruzikas DT, McLaughlin TP. Pharmacy and medical costs associated with switching between venlafaxine and SSRI antidepressant therapy for the treatment of major depressive disorder. J Manag Care Pharm. Jun. 2008;14(5):426-41. Source: PubMed. [pmid: 18597572].
1704 Kho KH, Zwinderman AH, Blansjaar BA. Predictors for the efficacy of electroconvulsive therapy: Chart review of a naturalistic study. Journal of Clinical Psychiatry. 2005;66(7):894-9. Source: EMBASE. [pmid: 16013905].
1705 Khouzam HR, Donnelly NJ. Remission of traumatic brain injury-induced compulsions during venlafaxine treatment. Gen Hosp Psychiatry. Jan. 1998;20(1):62-3. Source: PubMed. [pmid: 9506256].
1706 Khouzam HR, Kissmeyer P. Antidepressant treatment, posttraumatic stress disorder, survivor guilt, and spiritual awakening. J Trauma Stress. Oct. 1997;10(4):691-6. Source: PubMed. [pmid: 9391952].
1707 Khouzam HR, Monteiro AJ, Gerken ME. Remission of cancer chemotherapy-induced emesis during antidepressant therapy with nefazodone. Psychosom Med. Jan-Feb. 1998;60(1):89-91. Source: PubMed. [pmid: 9492245].
1708 Kiev A, Feiger A. A double-blind comparison of fluvoxamine and paroxetine in the treatment of depressed outpatients. J Clin Psychiatry. Apr. 1997;58(4):146-52. Source: PubMed. [pmid: 9164424].
1709 Kiev A, Masco HL, Wenger TL, et al. The cardiovascular effects of bupropion and nortriptyline in depressed outpatients. Ann Clin Psychiatry. Jun. 1994;6(2):107-15. Source: PubMed. [pmid: 7804386].
1710 Killen JD, Fortmann SP, Schatzberg A, et al. Onset of major depression during treatment for nicotine dependence. Addict Behav. Apr. 2003;28(3):461-70. Source: PubMed. [pmid: 12628619].
1711 Kim H, Lim SW, Kim S, et al. Monoamine Transporter Gene Polymorphisms and Antidepressant Response in Koreans With Late-Life Depression. JAMA: Journal of the American Medical Association. Oct. 2006. 2006;296(13):1609-18. Source: PsycINFO.
1712 Kim J, Riggs KW, Misri S, et al. Stereoselective disposition of fluoxetine and norfluoxetine during pregnancy and breast-feeding. Br J Clin Pharmacol. Feb. 2006;61(2):155-63. Source: PubMed. [pmid: 16433870].
1713 Kim SW, Shin IS, Kim JM, et al. Mirtazapine for severe gastroparesis unresponsive to conventional prokinetic treatment. Psychosomatics. Sep-Oct. 2006;47(5):440-2. Source: PubMed. [pmid: 16959934].
1714 Kim SW, Shin IS, Kim JM, et al. Effectiveness of mirtazapine for nausea and insomnia in cancer patients with depression. Psychiatry Clin Neurosci. Feb. 2008;62(1):75-83. Source: PubMed. [pmid: 18289144].
1715 Kimmick GG, Lovato J, McQuellon R, et al. Randomized, double-blind, placebo-controlled, crossover study of sertraline (Zoloft) for the treatment of hot flashes in women with early stage breast cancer taking tamoxifen. Breast J. Mar-Apr. 2006;12(2):114-22. Source: PubMed. [pmid: 16509835].
1716 Kiosses DN, Arean PA, Teri L, et al. Home-delivered problem adaptation therapy (PATH) for depressed, cognitively impaired, disabled elders: A preliminary study. American Journal of Geriatric Psychiatry. 2010;18(11):988-98. Source: EMBASE. [pmid: 20808092].
1717 Kirby D, Harrigan S, Ames D. Hyponatraemia in elderly psychiatric patients treated with Selective Serotonin Reuptake Inhibitors and venlafaxine: a retrospective controlled study in an inpatient unit. Int J Geriatr Psychiatry. Mar. 2002;17(3):231-7. Source: PubMed. [pmid: 11921151].
1718 Kirli S, Caliskan M. A comparative study of sertraline versus imipramine in postpsychotic depressive disorder of schizophrenia. Schizophr Res. Sep. 7. 1998;33(1-2):103-11. Source: PubMed. [pmid: 9783350].
1719 Kirsch MA, Louie AK. Paroxetine and irritable bowel syndrome. Am J Psychiatry. Sep. 2000;157(9):1523-4. Source: PubMed. [pmid: 10964877].
1720 Kirwin JL, Goren JL. Duloxetine: a dual serotonin-norepinephrine reuptake inhibitor for treatment of major depressive disorder. Pharmacotherapy. Mar. 2005;25(3):396-410. Source: PubMed. [pmid: 15843287].
1721 Kishi T, Fukuo Y, Yoshimura R, et al. Pharmacogenetic study of serotonin 6 receptor gene with antidepressant response in major depressive disorder in the Japanese population. Human Psychopharmacology. 2010;25(6):481-6. Source: EMBASE. [pmid: 20737521].
1722 Kishi T, Kitajima T, Ikeda M, et al. Orphan nuclear receptor Rev-erb alpha gene (NR1D1) and fluvoxamine response in major depressive disorder in the Japanese population. Neuropsychobiology. 2009;59(4):234-8. Source: PubMed. [pmid: 19571598].
1723 Kishi T, Yoshimura R, Kitajima T, et al. SIRT1 gene is associated with major depressive disorder in the Japanese population. Journal of affective disorders. 2010;126(1-2):167-73. Source: EMBASE. [pmid: 20451257].
1724 Kishi T, Yoshimura R, Kitajima T, et al. HTR2A is associated with SSRI response in major depressive disorder in a Japanese Cohort. NeuroMolecular Medicine. 2010;12(3):237-42. Source: EMBASE. [pmid: 19937159].
1725 Kishi T, Yoshimura R, Okochi T, et al. Association analysis of SIGMAR1 with major depressive disorder and SSRI response. Neuropharmacology. Jun. 2010;58(7):1168-73. Source: PubMed. [pmid: 20178807].
1726 Kito S, Koga Y. Visual hallucinations and amnesia associated with zolpidem triggered by fluvoxamine: a possible interaction. Int Psychogeriatr. Dec. 2006;18(4):749-51. Source: PubMed. [pmid: 17026779].
1727 Kivimaki M, Tabak AG, Lawlor DA, et al. Antidepressant use before and after the diagnosis of type 2 diabetes: A longitudinal modeling study. Diabetes Care. 2010;33(7):1471-6. Source: EMBASE. [pmid: 20368411].
1728 Klein DF. The flawed basis for FDA post-marketing safety decisions: The example of anti-depressants and children. Neuropsychopharmacology. 2006;31(4):689-99. Source: Scopus. [pmid: 16395296].
1729 Klein DN, Schatzberg AF, McCullough JP, et al. Early- versus late-onset dythymic disorder: comparison in out-patients with superimposed major depressive episodes. J Affect Disord. Jan-Mar. 1999;52(1-3):187-96. Source: PubMed. [pmid: 10357032].
1730 Klein DN, Schwartz JE, Santiago NJ, et al. Therapeutic alliance in depression treatment: controlling for prior change and patient characteristics. J Consult Clin Psychol. Dec. 2003;71(6):997-1006. Source: PubMed. [pmid: 14622075].
1731 Klein HE, Muller N. Trazodone in endogenous depressed patients: a negative report and a critical evaluation of the pertaining literature. Prog Neuropsychopharmacol Biol Psychiatry. 1985;9(2):173-86. Source: PubMed. [pmid: 4001432].
1732 Klieser E, Lehmann E. Experimental comparison between the effect of standardized trazodone-amitriptyline and placebo treatment in vitalized depressive patients. Psychopharmacology (Berl). 1988;95(Suppl):S3-5. Source: PubMed. [pmid: 3133710].
1733 Klieser E, Lehmann E. Experimental examination of trazodone. Clin Neuropharmacol. Suppl 1. 1989;12:S18-24. Source: PubMed. [pmid: 2743348].
1734 Klieser E, Lehmann E, Heinrich K. Fluoxetine in patients with major depressive disorder--a responder analysis. Pharmacopsychiatry. Jan. 1995;28(1):14-9. Source: PubMed. [pmid: 7746839].
1735 Klimek V, Roberson G, Stockmeier CA, et al. Serotonin transporter and MAO-B levels in monoamine nuclei of the human brainstem are normal in major depression. J Psychiatr Res. Sep-Oct. 2003;37(5):387-97. Source: PubMed. [pmid: 12849931].
1736 Klimek V, Stockmeier C, Overholser J, et al. Reduced levels of norepinephrine transporters in the locus coeruleus in major depression. J Neurosci. Nov. 1. 1997;17(21):8451-8. Source: PubMed. [pmid: 9334417].
1737 Klimke A, Larisch R, Janz A, et al. Dopamine D2 receptor binding before and after treatment of major depression measured by [123I]IBZM SPECT. Psychiatry Res. Apr. 26. 1999;90(2):91-101. Source: PubMed. [pmid: 10482381].
1738 Klok CJ, Brouwer GJ, Van Praag HM, et al. Fluvoxamine and clomipramine in depressed patients. A double blind clinical study. Acta Psychiatrica Scandinavica. 1981;64(1):1-11. Source: EMBASE. [pmid: 6172005].
1739 Kluge M, Schussler P, Steiger A. Duloxetine increases stage 3 sleep and suppresses rapid eye movement (REM) sleep in patients with major depression. Eur Neuropsychopharmacol. Jul. 2007;17(8):527-31. Source: PubMed. [pmid: 17337164].
1740 Klysner R, Bent-Hansen J, Hansen HL, et al. Efficacy of citalopram in the prevention of recurrent depression in elderly patients: placebo-controlled study of maintenance therapy. Br J Psychiatry. Jul. 2002;181:29-35. Source: PubMed. [pmid: 12091260].
1741 Knott V, Mahoney C, Kennedy S, et al. Pre-treatment EEG and it's relationship to depression severity and paroxetine treatment outcome. Pharmacopsychiatry. Nov. 2000;33(6):201-5. Source: PubMed. [pmid: 11147926].
1742 Knott VJ, Lapierre YD. Computerized EEG correlates of depression and antidepressant treatment. Prog Neuropsychopharmacol Biol Psychiatry. 1987;11(2-3):213-21. Source: PubMed. [pmid: 3306804].
1743 Knudsen P, Hansen EH, Eskildsen K. Leading ordinary lives: a qualitative study of younger women's perceived functions of antidepressants. Pharm World Sci. Aug. 2003;25(4):162-7. Source: PubMed. [pmid: 12964495].
1744 Ko HC, Lu RB, Shiah IS, et al. Plasma free 3-methoxy-4-hydroxyphenylglycol predicts response to fluoxetine. Biol Psychiatry. Apr. 1. 1997;41(7):774-81. Source: PubMed. [pmid: 9084896].
1745 Kocsis JH, Leon AC, Markowitz JC, et al. Patient preference as a moderator of outcome for chronic forms of major depressive disorder treated with nefazodone, cognitive behavioral analysis system of psychotherapy, or their combination. J Clin Psychiatry. Mar. 2009;70(3):354-61. Source: PubMed. [pmid: 19192474].
1746 Kocsis JH, Rush AJ, Markowitz JC, et al. Continuation treatment of chronic depression: a comparison of nefazodone, cognitive behavioral analysis system of psychotherapy, and their combination. Psychopharmacol Bull. 2003;37(4):73-87. Source: PubMed. [pmid: 15131518].
1747 Kocsis JH, Schatzberg A, Rush AJ, et al. Psychosocial outcomes following long-term, double-blind treatment of chronic depression with sertraline vs placebo. Arch Gen Psychiatry. Aug. 2002;59(8):723-8. Source: PubMed. [pmid: 12150648].
1748 Kocsis JH, Thase ME, Trivedi MH, et al. Prevention of recurrent episodes of depression with venlafaxine ER in a 1-year maintenance phase from the PREVENT Study. J Clin Psychiatry. 2007;68(7):1014-23. Source: PubMed. [pmid: 17685736].
1749 Kocsis JH, Zisook S, Davidson J, et al. Double-blind comparison of sertraline, imipramine, and placebo in the treatment of dysthymia: psychosocial outcomes. Am J Psychiatry. Mar. 1997;154(3):390-5. Source: PubMed. [pmid: 9054788].
1750 Koetsier GC, Volkers AC, Tulen JH, et al. CPT performance in major depressive disorder before and after treatment with imipramine or fluvoxamine. J Psychiatr Res. Nov-Dec. 2002;36(6):391-7. Source: PubMed. [pmid: 12393308].
1751 Koga M, Kodaka F, Miyata H, et al. Symptoms of delusion: the effects of discontinuation of low-dose venlafaxine. Acta Psychiatr Scand. Oct. 2009;120(4):329-31. Source: PubMed. [pmid: 19573048].
1752 Kok R, Nolen W, Heeren T. Cardiovascular changes associated with venlafaxine in the treatment of late-life depression. Am J Geriatr Psychiatry. Aug. 2007;15(8):725. author reply 6. Source: PubMed. [pmid: 17670999].
1753 Kok RM, Nolen WA, Heeren TJ. Venlafaxine versus nortriptyline in the treatment of elderly depressed inpatients: a randomised, double-blind, controlled trial. Int J Geriatr Psychiatry. Dec. 2007;22(12):1247-54. Source: PubMed. [pmid: 17562523].
1754 Kok RM, Nolen WA, Heeren TJ. Outcome of late-life depression after 3 years of sequential treatment. Acta Psychiatr Scand. Apr. 2009;119(4):274-81. Source: PubMed. [pmid: 19053970].
1755 Kok RM, Vink D, Heeren TJ, et al. Lithium augmentation compared with phenelzine in treatment-resistant depression in the elderly: an open, randomized, controlled trial. J Clin Psychiatry. Aug. 2007;68(8):1177-85. Source: PubMed. [pmid: 17854241].
1756 Konarski JZ, Kennedy SH, Segal ZV, et al. Predictors of nonresponse to cognitive behavioural therapy or venlafaxine using glucose metabolism in major depressive disorder. J Psychiatry Neurosci. 2009;34(3):175-80. Source: PubMed. [pmid: 19448846].
1757 Konig F, Hauger B, von Hippel C, et al. Effect of paroxetine on thyroid hormone levels in severely depressed patients. Neuropsychobiology. 2000;42(3):135-8. Source: PubMed. [pmid: 11015031].
1758 Konig F, von Hippel C, Petersdorff T, et al. First experiences in combination therapy using olanzapine with SSRIs (citalopram, paroxetine) in delusional depression. Neuropsychobiology. 2001;43(3):170-4. Source: PubMed. [pmid: 11287796].
1759 Konitsiotis S, Pappa S, Mantas C, et al. Acute reversible dyskinesia induced by mirtazapine. Mov Disord. Jun. 2005;20(6):771. Source: PubMed. [pmid: 15732128].
1760 Kontoangelos K, Vaidakis N, Zervas I, et al. Administration of inositol to a patient with bipolar disorder and psoriasis: A case report. Cases Journal. 2010;3(2). Source: EMBASE.
1761 Konuk N, Atasoy N, Atik L, et al. Open-label study of adjunct modafinil for the treatment of patients with fatigue, sleepiness, and major depression treated with selective serotonin reuptake inhibitors. Advances in Therapy. 2006;23(4):646-54. Source: Scopus. [pmid: 17050507].
1762 Kool S, Dekker J, Duijsens IJ, et al. Efficacy of combined therapy and pharmacotherapy for depressed patients with or without personality disorders. Harv Rev Psychiatry. May-Jun. 2003;11(3):133-41. Source: PubMed. [pmid: 12893503].
1763 Kopecek M, Cerna L, Sulak J, et al. Depressed patients perception of the efficacy of electroconvulsive therapy and venlafaxine therapy. Neuro Endocrinol Lett. Dec. 2007;28(6):889-94. Source: PubMed. [pmid: 18063943].
1764 Kopf D, Westphal S, Luley CW, et al. Lipid metabolism and insulin resistance in depressed patients: significance of weight, hypercortisolism, and antidepressant treatment. J Clin Psychopharmacol. Oct. 2004;24(5):527-31. Source: PubMed. [pmid: 15349009].
1765 Koran LM, Aboujaoude EN, Gamel NN. Duloxetine treatment of dysthymia and double depression: an open-label trial. J Clin Psychiatry. May. 2007;68(5):761-5. Source: PubMed. [pmid: 17503986].
1766 Koran LM, Chuong HW, Bullock KD, et al. Citalopram for compulsive shopping disorder: an open-label study followed by double-blind discontinuation. J Clin Psychiatry. Jul. 2003;64(7):793-8. Source: PubMed. [pmid: 12934980].
1767 Koran LM, Gelenberg AJ, Kornstein SG, et al. Sertraline versus imipramine to prevent relapse in chronic depression. J Affect Disord. Jun. 2001;65(1):27-36. Source: PubMed. [pmid: 11426506].
1768 Koran LM, Hamilton SH, Hertzman M, et al. Predicting response to fluoxetine in geriatric patients with major depression. J Clin Psychopharmacol. Dec. 1995;15(6):421-7. Source: PubMed. [pmid: 8748431].
1769 Korn ML, Kotler M, Molcho A, et al. Suicide and violence associated with panic attacks. Biol Psychiatry. Mar. 15. 1992;31(6):607-12. Source: PubMed. [pmid: 1581440].
1770 Kornstein SG. Beyond remission: rationale and design of the Prevention of Recurrent Episodes of Depression with Venlafaxine for Two Years (PREVENT) Study. CNS Spectr. Dec. 2006;11(12 Suppl 15):28-34. Source: PubMed. [pmid: 17146416].
1771 Kornstein SG. Maintenance therapy to prevent recurrence of depression: summary and implications of the PREVENT study. Expert Rev Neurother. 2008;8(5):737-42. Source: PubMed. [pmid: 18457530].
1772 Kornstein SG, Bose A, Li D, et al. Escitalopram maintenance treatment for prevention of recurrent depression: a randomized, placebo-controlled trial. J Clin Psychiatry. 2006;67(11):1767-75. Source: PubMed. [pmid: 17196058].
1773 Kornstein SG, Clayton AH, Soares CN, et al. Analysis by age and sex of efficacy data from placebo-controlled trials of desvenlafaxine in outpatients with major depressive disorder. Journal of Clinical Psychopharmacology. 2010;30(3):294-9. Source: EMBASE. [pmid: 20473066].
1774 Kornstein SG, Dunner DL, Meyers AL, et al. A randomized, double-blind study of increasing or maintaining duloxetine dose in patients without remission of major depressive disorder after initial duloxetine therapy. J Clin Psychiatry. Sep. 2008;69(9):1383-92. Source: PubMed. [pmid: 19193339].
1775 Kornstein SG, Harvey AT, Rush AJ, et al. Self-reported premenstrual exacerbation of depressive symptoms in patients seeking treatment for major depression. Psychol Med. May. 2005;35(5):683-92. Source: PubMed. [pmid: 15918345].
1776 Kornstein SG, Jiang Q, Reddy S, et al. Short-term efficacy and safety of desvenlafaxine in a randomized, placebo-controlled study of perimenopausal and postmenopausal women with major depressive disorder. J Clin Psychiatry. 2010;71(8):1088-96. Source: PubMed. [pmid: 20797382].
1777 Kornstein SG, Kocsis JH, Ahmed S, et al. Assessing the efficacy of 2 years of maintenance treatment with venlafaxine extended release 75-225 mg/day in patients with recurrent major depression: a secondary analysis of data from the PREVENT study. Int Clin Psychopharmacol. 2008;23(6):357-63. Source: PubMed. [pmid: 18854724].
1778 Kornstein SG, Li D, Mao Y, et al. Escitalopram versus SNRI antidepressants in the acute treatment of major depressive disorder: Integrative analysis of four double-blind, randomized clinical trials. CNS Spectrums. 2009;14(6):326-33. Source: PsycINFO. [pmid: 19668123].
1779 Kornstein SG, Schatzberg AF, Thase ME, et al. Gender differences in treatment response to sertraline versus imipramine in chronic depression. Am J Psychiatry. Sep. 2000;157(9):1445-52. Source: PubMed. [pmid: 10964861].
1780 Kornstein SG, Wohlreich MM, Mallinckrodt CH, et al. Duloxetine efficacy for major depressive disorder in male vs. female patients: data from 7 randomized, double-blind, placebo-controlled trials. J Clin Psychiatry. 2006;67(5):761-70. Source: PubMed. [pmid: 16841626].
1781 Kostiukova EG, Granenov GM, Andreichik LA, et al. Comparative efficacy and tolerance of fluvoxamine and amitriptyline in the treatment of moderate and severe depression in mental hospital. Zhurnal Nevrologii I Psikhiatrii Imeni Ss Korsakova. 2003;103(1):24-9. Source: EMBASE.
1782 Koutouvidis N, Pratikakis M, Fotiadou A. The use of mirtazapine in a group of 11 patients following poor compliance to selective serotonin reuptake inhibitor treatment due to sexual dysfunction. Int Clin Psychopharmacol. Jul. 1999;14(4):253-5. Source: PubMed. [pmid: 10468319].
1783 Kozel FA, Trivedi MH, Wisniewski SR, et al. Treatment outcomes for older depressed patients with earlier versus late onset of first depressive episode: a Sequenced Treatment Alternatives to Relieve Depression (STAR*D) report. Am J Geriatr Psychiatry. Jan. 2008;16(1):58-64. Source: PubMed. [pmid: 18165462].
1784 Kraemer HC, Kupfer DJ. Size of Treatment Effects and Their Importance to Clinical Research and Practice. Biological Psychiatry. 2006;59(11):990-6. Source: Scopus. [pmid: 16368078].
1785 Kraft JB, Peters EJ, Slager SL, et al. Analysis of association between the serotonin transporter and antidepressant response in a large clinical sample. Biol Psychiatry. Mar. 15. 2007;61(6):734-42. Source: PubMed. [pmid: 17123473].
1786 Kraft JB, Slager SL, McGrath PJ, et al. Sequence analysis of the serotonin transporter and associations with antidepressant response. Biological Psychiatry. 2005;58(5):374-81. Source: EMBASE. [pmid: 15993855].
1787 Krahn LE, Hanson CA, Pileggi TS, et al. Electroconvulsive therapy and cardiovascular complications in patients taking trazodone for insomnia. J Clin Psychiatry. Feb. 2001;62(2):108-10. Source: PubMed. [pmid: 11247094].
1788 Kramer MS, Cutler N, Feighner J, et al. Distinct mechanism for antidepressant activity by blockade of central substance P receptors. Science. Sep. 11. 1998;281(5383):1640-5. Source: PubMed. [pmid: 9733503].
1789 Kranzler HR, Burleson JA, Brown J, et al. Fluoxetine treatment seems to reduce the beneficial effects of cognitive-behavioral therapy in type B alcoholics. Alcohol Clin Exp Res. Dec. 1996;20(9):1534-41. Source: PubMed. [pmid: 8986200].
1790 Kranzler HR, Burleson JA, Korner P, et al. Placebo-controlled trial of fluoxetine as an adjunct to relapse prevention in alcoholics. Am J Psychiatry. Mar. 1995;152(3):391-7. Source: PubMed. [pmid: 7864265].
1791 Kranzler HR, Mueller T, Cornelius J, et al. Sertraline treatment of co-occurring alcohol dependence and major depression. J Clin Psychopharmacol. 2006;26(1):13-20. Source: PubMed. [pmid: 16415699].
1792 Kraus JE, Horrigan JP, Carpenter DJ, et al. Clinical features of patients with treatment-emergent suicidal behavior following initiation of paroxetine therapy. J Affect Disord. Jan. 2010;120(1-3):40-7. Source: PubMed. [pmid: 19439363].
1793 Kraus MR, Schafer A, Schottker K, et al. Therapy of interferon-induced depression in chronic hepatitis C with citalopram: a randomised, double-blind, placebo-controlled study. Gut. Apr. 2008;57(4):531-6. Source: PubMed. [pmid: 18079286].
1794 Kraus RP. Rapid cycling triggered by pindolol augmentation of paroxetine, but not with desipramine. Depression. 1996;4(2):92-4. Source: PubMed. [pmid: 9160648].
1795 Kraus RP, Diaz P, McEachran A. Managing rapid metabolizers of antidepressants. Depress Anxiety. 1996;4(6):320-7. Source: PubMed. [pmid: 9166660].
1796 Kraus T, Haack M, Schuld A, et al. Body weight, the tumor necrosis factor system, and leptin production during treatment with mirtazapine or venlafaxine. Pharmacopsychiatry. Nov. 2002;35(6):220-5. Source: PubMed. [pmid: 12518269].
1797 Kravitz RL, Epstein RM, Feldman MD, et al. Influence of patients' requests for direct-to-consumer advertised antidepressants: A randomized controlled trial. Journal of the American Medical Association. 2005;293(16):1995-2002. Source: EMBASE. [pmid: 15855433].
1798 Krebs EE, Gaynes BN, Gartlehner G, et al. Treating the physical symptoms of depression with second-generation antidepressants: a systematic review and metaanalysis. Psychosomatics. 2008;49(3):191-8. Source: PubMed. [pmid: 18448772].
1799 Kreider MS, Bushnell WD, Oakes R, et al. A double-blind, randomized study to provide safety information on switching fluoxetine-treated patients to paroxetine without an intervening washout period. J Clin Psychiatry. Apr. 1995;56(4):142-5. Source: PubMed. [pmid: 7713852].
1800 Krishnan KR, Doraiswamy PM, Clary CM. Clinical and treatment response characteristics of late-life depression associated with vascular disease: a pooled analysis of two multicenter trials with sertraline. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 2001;25(2):347-61. Source: PubMed. [pmid: 11294481].
1801 Kroenke K, Messina N 3rd, Benattia I, et al. Venlafaxine extended release in the short-term treatment of depressed and anxious primary care patients with multisomatoform disorder. J Clin Psychiatry. 2006;67(1):72-80. Source: PubMed. [pmid: 16426091].
1802 Kroenke K, West SL, Swindle R, et al. Similar effectiveness of paroxetine, fluoxetine, and sertraline in primary care: a randomized trial. Jama. Dec. 19. 2001;286(23):2947-55. Source: PubMed. [pmid: 11743835].
1803 Kruger S, Lindstaedt M. Duloxetine and hyponatremia: a report of 5 cases. J Clin Psychopharmacol. Feb. 2007;27(1):101-4. Source: PubMed. [pmid: 17224730].
1804 Krystal A, Fava M, Rubens R, et al. Evaluation of eszopiclone discontinuation after cotherapy with fluoxetine for insomnia with coexisting depression. J Clin Sleep Med. Feb. 15. 2007;3(1):48-55. Source: PubMed. [pmid: 17557453].
1805 Krystal AD. Depression and insomnia in women. Clin Cornerstone. Suppl 1B. 2004;6:S19-28. Source: PubMed. [pmid: 15457812].
1806 Krystal AD, Harsh JR, Yang RR, et al. A double-blind, placebo-controlled study of armodafinil for excessive sleepiness in patients with treated obstructive sleep apnea and comorbid depression. Journal of Clinical Psychiatry. 2010;71(1):32-40. Source: EMBASE. [pmid: 20051221].
1807 Kubera M, Kenis G, Bosmans E, et al. Stimulatory effect of antidepressants on the production of IL-6. Int Immunopharmacol. Feb. 2004;4(2):185-92. Source: PubMed. [pmid: 14996410].
1808 Kubota T, Miyata A. Syndrome of inappropriate secretion of antidiuretic hormone associated with paroxetine. J Anesth. 2006;20(2):126-8. Source: PubMed. [pmid: 16633772].
1809 Kucukalic A, Bravo-Mehmedbasic A, Kulenovic AD, et al. Venlafaxine efficacy and tolerability in the treatment of post-stroke depression. Psychiatr Danub. Jun. 2007;19(1-2):56-60. Source: PubMed. [pmid: 17603417].
1810 Kugaya A, Sanacora G, Staley JK, et al. Brain serotonin transporter availability predicts treatment response to selective serotonin reuptake inhibitors. Biol Psychiatry. Oct. 1. 2004;56(7):497-502. Source: PubMed. [pmid: 15450785].
1811 Kuhn KU, Quednow BB, Thiel M, et al. Antidepressive treatment in patients with temporal lobe epilepsy and major depression: a prospective study with three different antidepressants. Epilepsy Behav. Dec. 2003;4(6):674-9. Source: PubMed. [pmid: 14698701].
1812 Kuhs H, Schlake HP, Rolf LH, et al. Relationship between parameters of serotonin transport and antidepressant plasma levels or therapeutic response in depressive patients treated with paroxetine and amitriptyline. Acta Psychiatr Scand. May. 1992;85(5):364-9. Source: PubMed. [pmid: 1534961].
1813 Kulisevsky J, Pagonabarraga J, Pascual-Sedano B, et al. Motor changes during sertraline treatment in depressed patients with Parkinson's disease*. Eur J Neurol. Sep. 2008;15(9):953-9. Source: PubMed. [pmid: 18637826].
1814 Kuliwaba A. Non-lethal mirtazapine overdose with rhabdomyolysis. Australian and New Zealand Journal of Psychiatry. Apr. 2005. 2005;39(4):312-3. Source: PsycINFO. [pmid: 15777372].
1815 Kulp W, von der Schulenburg JM, Greiner W. Cost-effectiveness of outpatient treatment in depressive patients with escitalopram in Germany. Eur J Health Econ. Dec. 2005;6(4):317-21. Source: PubMed. [pmid: 16267659].
1816 Kumar P, Waiter G, Ahearn T, et al. Abnormal temporal difference reward-learning signals in major depression. Brain. Aug. 2008;131(Pt 8):2084-93. Source: PubMed. [pmid: 18579575].
1817 Kumar S. Prophylaxis of depression in older people. Br J Psychiatry. Oct. 2003;183:365. author reply. Source: PubMed. [pmid: 14519617].
1818 Kumra S, Oberstar JV, Sikich L, et al. Efficacy and tolerability of second-generation antipsychotics in children and adolescents with schizophrenia. Schizophrenia Bulletin. 2008;34(1):60-71. Source: Scopus. [pmid: 17923452].
1819 Kupfer DJ. Long-term treatment of depression. J Clin Psychiatry. May. 1991;52(Suppl):28-34. Source: PubMed. [pmid: 1903134].
1820 Kupfer DJ. Depression and associated sleep disturbances: Patient benefits with agomelatine. European Neuropsychopharmacology. Sep. 2006. 2006;16(5):S639-S43. Source: PsycINFO.
1821 Kupfer DJ, Perel JM, Pollock BG, et al. Fluvoxamine versus desipramine: comparative polysomnographic effects. Biol Psychiatry. 1991;29(1):23-40. Source: PubMed. [pmid: 1900443].
1822 Kushner SC, Quilty LC, McBride C, et al. A comparison of depressed patients in randomized versus nonrandomized trials of antidepressant medication and psychotherapy. Depression and Anxiety. 2009;26(7):666-73. Source: EMBASE. [pmid: 19319994].
1823 Kuyken W, Watkins E, Holden E, et al. How does mindfulness-based cognitive therapy work?. Behaviour Research and Therapy. 2010;48(11):1105-12. Source: EMBASE. [pmid: 20810101].
1824 Kwan BM, Dimidjian S, Rizvi SL. Treatment preference, engagement, and clinical improvement in pharmacotherapy versus psychotherapy for depression. Behaviour Research and Therapy. 2010;48(8):799-804. Source: EMBASE. [pmid: 20462569].
1825 Kwon JS, Youn T, Jung HY. Right hemisphere abnormalities in major depression: quantitative electroencephalographic findings before and after treatment. J Affect Disord. Oct. 14. 1996;40(3):169-73. Source: PubMed. [pmid: 8897116].
1826 Kyle CJ, Petersen HE, Overo KF. Comparison of the tolerability and efficacy of citalopram and amitriptyline in elderly depressed patients treated in general practice. Depress Anxiety. 1998;8(4):147-53. Source: PubMed. [pmid: 9871816].
1827 Kyomen HH, Whitfield TH. Psychosis in the elderly. Am J Psychiatry. Feb. 2009;166(2):146-50. Source: PubMed. [pmid: 19188291].
1828 Labbate LA. Bupropion-SR-induced increased libido and spontaneous orgasm. Can J Psychiatry. Aug. 1998;43(6):644-5. Source: PubMed. [pmid: 9729695].
1829 Labbate LA, Pollack MH. Treatment of fluoxetine-induced sexual dysfunction with bupropion: a case report. Ann Clin Psychiatry. Mar. 1994;6(1):13-5. Source: PubMed. [pmid: 7951639].
1830 Labuschagne I, Croft RJ, Phan KL, et al. Augmenting serotonin neurotransmission with citalopram modulates emotional expression decoding but not structural encoding of moderate intensity sad facial emotional stimuli: an event-related potential (ERP) investigation. J Psychopharmacol. Aug. 2010;24(8):1153-64. Source: PubMed. [pmid: 18832432].
1831 Lachiewicz A, Dawson D, Spiridigliozzi G, et al. Indicators of anxiety and depression in women with the fragile X premutation: Assessment of a clinical sample. Journal of Intellectual Disability Research. 2010;54(7):597-610. Source: EMBASE. [pmid: 20629912].
1832 Ladabaum U, Sharabidze A, Levin TR, et al. Citalopram Provides Little or No Benefit in Nondepressed Patients With Irritable Bowel Syndrome. Clinical Gastroenterology and Hepatology. 2010;8(1):42-8.e1. Source: EMBASE. [pmid: 19765674].
1833 Ladd CO, Newport DJ, Ragan KA, et al. Venlafaxine in the treatment of depressive and vasomotor symptoms in women with perimenopausal depression. Depress Anxiety. 2005;22(2):94-7. Source: PubMed. [pmid: 16094663].
1834 Lader M, Andersen HF, Baekdal T. The effect of escitalopram on sleep problems in depressed patients. Hum Psychopharmacol. Jul. 2005;20(5):349-54. Source: PubMed. [pmid: 15912558].
1835 Lafer B, Fava M, Hammerness P, et al. The influence of DST and TRH test administration on depression assessments: a controlled study. Biol Psychiatry. Nov. 1. 1993;34(9):650-3. Source: PubMed. [pmid: 8292694].
1836 Laghrissi-Thode F, Pollock BG, Miller MC, et al. Double-blind comparison of paroxetine and nortriptyline on the postural stability of late-life depressed patients. Psychopharmacol Bull. 1995;31(4):659-63. Source: PubMed. [pmid: 8851637].
1837 Lai CH. Duloxetine related hypersexuality: A case report. Progress in neuro-psychopharmacology & biological psychiatry. 2010;34(2):414-5. Source: PsycINFO. [pmid: 19945494].
1838 Laidlaw K, Davidson K, Toner H, et al. A randomised controlled trial of cognitive behaviour therapy vs treatment as usual in the treatment of mild to moderate late life depression. International Journal of Geriatric Psychiatry. 2008;23(8):843-50. Source: EMBASE. [pmid: 18311844].
1839 Laika B, Leucht S, Heres S, et al. Pharmacogenetics and olanzapine treatment: CYP1A2*1F and serotonergic polymorphisms influence therapeutic outcome. Pharmacogenomics J. Feb. 2010;10(1):20-9. Source: PubMed. [pmid: 19636338].
1840 Laimer M, Kramer-Reinstadler K, Rauchenzauner M, et al. Effect of mirtazapine treatment on body composition and metabolism. J Clin Psychiatry. Mar. 2006;67(3):421-4. Source: PubMed. [pmid: 16649829].
1841 Laje G, Paddock S, Manji H, et al. Genetic markers of suicidal ideation emerging during citalopram treatment of major depression. Am J Psychiatry. Oct. 2007;164(10):1530-8. Source: PubMed. [pmid: 17898344].
1842 Laje G, Perlis RH, Rush AJ, et al. Pharmacogenetics studies in STAR*D: strengths, limitations, and results. Psychiatr Serv. Nov. 2009;60(11):1446-57. Source: PubMed. [pmid: 19880459].
1843 Lakshmanan MN, Meier SLC, Meier RS, et al. An archetype of the collaborative efforts of psychotherapy and psychopharmacology in successfully treating dissociative identity disorder with comorbid bipolar disorder. Psychiatry (Edgemont). 2010;7(7):33-7. Source: EMBASE.
1844 Lam RW, Andersen HF. The influence of baseline severity on efficacy of escitalopram and citalopram in the treatment of major depressive disorder: an extended analysis. Pharmacopsychiatry. Sep. 2006;39(5):180-4. Source: PubMed. [pmid: 16944409].
1845 Lam RW, Gorman CP, Michalon M, et al. Multicenter, placebo-controlled study of fluoxetine in seasonal affective disorder. Am J Psychiatry. Dec. 1995;152(12):1765-70. Source: PubMed. [pmid: 8526243].
1846 Lam RW, Hossie H, Solomons K, et al. Citalopram and bupropion-SR: combining versus switching in patients with treatment-resistant depression. J Clin Psychiatry. Mar. 2004;65(3):337-40. Source: PubMed. [pmid: 15096072].
1847 Lam RW, Kennedy SH, Grigoriadis S, et al. Canadian Network for Mood and Anxiety Treatments (CANMAT) clinical guidelines for the management of major depressive disorder in adults. III. Pharmacotherapy. J Affect Disord. Oct. Suppl 1. 2009;117:S26-43. Source: PubMed. [pmid: 19674794].
1848 Lam RW, Lee SK, Tam EM, et al. An open trial of light therapy for women with seasonal affective disorder and comorbid bulimia nervosa. J Clin Psychiatry. Mar. 2001;62(3):164-8. Source: PubMed. [pmid: 11305701].
1849 Lam RW, Levitt AJ, Levitan RD, et al. The Can-SAD study: a randomized controlled trial of the effectiveness of light therapy and fluoxetine in patients with winter seasonal affective disorder. Am J Psychiatry. May. 2006;163(5):805-12. Source: PubMed. [pmid: 16648320].
1850 Lam RW, Lonn SL, Despiegel N. Escitalopram versus serotonin noradrenaline reuptake inhibitors as second step treatment for patients with major depressive disorder: A pooled analysis. International Clinical Psychopharmacology. 2010;25(4):199-203. Source: EMBASE. [pmid: 20357664].
1851 Lammers CH, Deuschle M, Weigmann H, et al. Coadministration of clozapine and fluvoxamine in psychotic patients--clinical experience. Pharmacopsychiatry. Mar. 1999;32(2):76-7. Source: PubMed. [pmid: 10333167].
1852 Lanctot KL, Best TS, Mittmann N, et al. Efficacy and safety of neuroleptics in behavioral disorders associated with dementia. J Clin Psychiatry. Oct. 1998;59(10):550-61. quiz 62-3. Source: PubMed. [pmid: 9818639].
1853 Lanctot KL, Rapoport MJ, Chan F, et al. Genetic predictors of response to treatment with citalopram in depression secondary to traumatic brain injury. Brain Inj. 2010;24(7-8):959-69. Source: PubMed. [pmid: 20515362].
1854 Landen M, Bjorling G, Agren H, et al. A randomized, double-blind, placebo-controlled trial of buspirone in combination with an SSRI in patients with treatment-refractory depression. J Clin Psychiatry. Dec. 1998;59(12):664-8. Source: PubMed. [pmid: 9921700].
1855 Landen M, Hogberg P, Thase ME. Incidence of sexual side effects in refractory depression during treatment with citalopram or paroxetine. J Clin Psychiatry. Jan. 2005;66(1):100-6. Source: PubMed. [pmid: 15669895].
1856 Lanes T, Ravaris CL. Prolonged ECT seizure duration in a patient taking trazodone. Am J Psychiatry. Mar. 1993;150(3):525. Source: PubMed. [pmid: 8434678].
1857 Langlois RP, Paquette D. Sustained bradycardia during fluvoxamine and buspirone intoxication. Can J Psychiatry. Mar. 1994;39(2):126-7. Source: PubMed. [pmid: 8149317].
1858 Langworth S, Bodlund O, Agren H. Efficacy and tolerability of reboxetine compared with citalopram: a double-blind study in patients with major depressive disorder. J Clin Psychopharmacol. Apr. 2006;26(2):121-7. Source: PubMed. [pmid: 16633139].
1859 Lanza di Scalea T, Hanusa BH, Wisner KL. Sexual function in postpartum women treated for depression: results from a randomized trial of nortriptyline versus sertraline. J Clin Psychiatry. 2009;70(3):423-8. Source: PubMed. [pmid: 19284932].
1860 Lapierre Y, Bentkover J, Schainbaum S, et al. Direct cost of depression: analysis of treatment costs of paroxetine versus Imipramine in Canada. Can J Psychiatry. Sep. 1995;40(7):370-7. Source: PubMed. [pmid: 8548716].
1861 Lapierre YD. Controlling acute episodes of depression. Int Clin Psychopharmacol. Dec. Suppl 2. 1991;6:23-35. Source: PubMed. [pmid: 1806627].
1862 Lapierre YD, Browne M, Horn E, et al. Treatment of major affective disorder with fluvoxamine. J Clin Psychiatry. Feb. 1987;48(2):65-8. Source: PubMed. [pmid: 3100510].
1863 Lapierre YD, Joffe R, McKenna K, et al. Moclobemide versus fluoxetine in the treatment of major depressive disorder in adults. J Psychiatry Neurosci. Mar. 1997;22(2):118-26. Source: PubMed. [pmid: 9074306].
1864 Lara DR, Busnello ED, Souza DO. Ondansetron rather than metoclopramide for bupropion-induced nausea. Can J Psychiatry. May. 2001;46(4):371. Source: PubMed. [pmid: 11387797].
1865 Lasch K, Joish VN, Zhu YP, et al. Validation of the sleep impact scale in patients with major depressive disorder and insomnia. Current Medical Research and Opinion (England). 2009;25:1699. Source: PsycINFO.
1866 Lash TL, Cronin-Fenton D, Ahern TP, et al. Breast cancer recurrence risk related to concurrent use of SSRI antidepressants and tamoxifen. Acta Oncologica. 2010;49(3):305-12. Source: EMBASE. [pmid: 20156115].
1867 Lauritzen L, Odgaard K, Clemmesen L, et al. Relapse prevention by means of paroxetine in ECT-treated patients with major depression: a comparison with imipramine and placebo in medium-term continuation therapy. Acta Psychiatr Scand. Oct. 1996;94(4):241-51. Source: PubMed. [pmid: 8911559].
1868 Laursen AL, Mikkelsen PL, Rasmussen S, et al. Paroxetine in the treatment of depression--a randomized comparison with amitriptyline. Acta Psychiatr Scand. Mar. 1985;71(3):249-55. Source: PubMed. [pmid: 3157296].
1869 Lavergne F, Berlin I, Gamma A, et al. Onset of improvement and response to mirtazapine in depression: A multicenter naturalistic study of 4771 patients. Neuropsychiatric Disease and Treatment. 2005;1(1):59-68. 2005. Source: PsycINFO. [pmid: 18568129].
1870 Lavori PW, Rush AJ, Wisniewski SR, et al. Strengthening clinical effectiveness trials: equipoise-stratified randomization. Biol Psychiatry. Nov. 15. 2001;50(10):792-801. Source: PubMed. [pmid: 11720698].
1871 Lavretsky H, Kim MD, Kumar A, et al. Combined treatment with methylphenidate and citalopram for accelerated response in the elderly: an open trial. J Clin Psychiatry. Dec. 2003;64(12):1410-4. Source: PubMed. [pmid: 14728100].
1872 Lavretsky H, Kumar A. Methylphenidate augmentation of citalopram in elderly depressed patients. Am J Geriatr Psychiatry. Summer. 2001;9(3):298-303. Source: PubMed. [pmid: 11481139].
1873 Lavretsky H, Park S, Siddarth P, et al. Methylphenidate-enhanced antidepressant response to citalopram in the elderly: a double-blind, placebo-controlled pilot trial. Am J Geriatr Psychiatry. Feb. 2006;14(2):181-5. Source: PubMed. [pmid: 16473984].
1874 Lavretsky H, Roybal DJ, Ballmaier M, et al. Antidepressant exposure may protect against decrement in frontal gray matter volumes in geriatric depression. Journal of Clinical Psychiatry. 2005;66(8):964-7. Source: EMBASE. [pmid: 16086609].
1875 Lavretsky H, Siddarth P, Irwin MR. Improving depression and enhancing resilience in family dementia caregivers: A pilot randomized placebo-controlled trial of escitalopram. The American Journal of Geriatric Psychiatry. 2010;18(2):154-62. Source: PsycINFO. [pmid: 20104071].
1876 Lavretsky H, Siddarth P, Kumar A, et al. The effects of the dopamine and serotonin transporter polymorphisms on clinical features and treatment response in geriatric depression: a pilot study. Int J Geriatr Psychiatry. Jan. 2008;23(1):55-9. Source: PubMed. [pmid: 17621383].
1877 Lawrence KM, De Paermentier F, Cheetham SC, et al. Brain 5-HT uptake sites, labelled with [3H]-paroxetine, in post-mortem samples from depressed suicide victims. Br J Pharmacol. Dec. 1989;98(Suppl):812P. Source: PubMed.
1878 Lawrence KM, De Paermentier F, Cheetham SC, et al. Symmetrical hemispheric distribution of 3H-paroxetine binding sites in postmortem human brain from controls and suicides. Biol Psychiatry. Sep. 15. 1990;28(6):544-6. Source: PubMed. [pmid: 2145984].
1879 Lawrence KM, De Paermentier F, Cheetham SC, et al. Brain 5-HT uptake sites, labelled with [3H]paroxetine, in antidepressant-free depressed suicides. Brain Res. Aug. 27. 1990;526(1):17-22. Source: PubMed. [pmid: 2150340].
1880 Lawrence KM, De Paermentier F, Lowther S, et al. Brain 5-hydroxytryptamine uptake sites labeled with [3H]paroxetine in antidepressant drug-treated depressed suicide victims and controls. J Psychiatry Neurosci. May. 1997;22(3):185-91. Source: PubMed. [pmid: 9183117].
1881 Lawrence KM, Katona CL, Abou-Saleh MT, et al. Platelet 5-HT uptake sites, labelled with [3H] paroxetine, in controls and depressed patients before and after treatment with fluoxetine or lofepramine. Psychopharmacology (Berl). Jun. 1994;115(1-2):261-4. Source: PubMed. [pmid: 7862905].
1882 Laws D, Ashford JJ, Anstee JA. A multicentre double-blind comparative trial of fluvoxamine versus lorazepam in mixed anxiety and depression treated in general practice. Acta Psychiatr Scand. Feb. 1990;81(2):185-9. Source: PubMed. [pmid: 2109498].
1883 Lecrubier Y, Dolberg OT, Andersen HF, et al. Qualitative changes in symptomatology as an effect of treatment with escitalopram in generalized anxiety disorder and major depressive disorder. European Archives of Psychiatry and Clinical Neuroscience. Apr. 2008. 2008;258(3):171-8. Source: PsycINFO. [pmid: 18084791].
1884 Lederbogen F, Horer E, Hellweg R, et al. Platelet counts in depressed patients treated with amitriptyline or paroxetine. Eur Psychiatry. Mar. 2003;18(2):89-91. Source: PubMed. [pmid: 12711406].
1885 Lee H, Kim JH, Min BH, et al. Efficacy of venlafaxine for symptomatic relief in young adult patients with functional chest pain: A randomized, double-blind, placebo-controlled, crossover trial. American Journal of Gastroenterology. 2010;105(7):1504-12. Source: EMBASE. [pmid: 20332772].
1886 Lee HY, Kang RH, Paik JW, et al. Association of the adrenergic alpha 2a receptor--1291C/G polymorphism with weight change and treatment response to mirtazapine in patients with major depressive disorder. Brain Res. 2009:12621-6. Source: PubMed.
1887 Lee HY, Kim YK. Plasma brain-derived neurotrophic factor as a peripheral marker for the action mechanism of antidepressants. Neuropsychobiology. 2008;57(4):194-9. Source: PubMed. [pmid: 18679038].
1888 Lee KM, Kim YK. The role of IL-12 and TGF-beta1 in the pathophysiology of major depressive disorder. Int Immunopharmacol. Aug. 2006;6(8):1298-304. Source: PubMed. [pmid: 16782542].
1889 Lee MS, Ham BJ, Kee BS, et al. Comparison of efficacy and safety of milnacipran and fluoxetine in Korean patients with major depression. Curr Med Res Opin. Sep. 2005;21(9):1369-75. Source: PubMed. [pmid: 16197655].
1890 Lee P, Shu L, Xu X, et al. Once-daily duloxetine 60 mg in the treatment of major depressive disorder: multicenter, double-blind, randomized, paroxetine-controlled, non-inferiority trial in China, Korea, Taiwan and Brazil. Psychiatry Clin Neurosci. 2007;61(3):295-307. Source: PubMed. [pmid: 17472599].
1891 Lee SH, Lee MS, Lee JH, et al. MRP1 polymorphisms associated with citalopram response in patients with major depression. Journal of Clinical Psychopharmacology. 2010;30(2):116-25. Source: EMBASE. [pmid: 20520284].
1892 Lee YP, Lee JYY. Recurrent factitious subcutaneous emphysema: Report of a complex case in a young woman and a literature review. Kaohsiung Journal of Medical Sciences. 2010;26(7):377-83. Source: EMBASE. [pmid: 20638041].
1893 Leentjens AF, Vreeling FW, Luijckx GJ, et al. SSRIs in the treatment of depression in Parkinson's disease. Int J Geriatr Psychiatry. Jun. 2003;18(6):552-4. Source: PubMed. [pmid: 12789682].
1894 Lefkowitz D, Kilgo G, Lee S. Seizures and trazodone therapy. Arch Gen Psychiatry. May. 1985;42(5):523. Source: PubMed. [pmid: 3985762].
1895 Lehert P, Poirier-Littre MF, Pringuey D, et al. New statistical proposals to evaluate the benefit/risk ratio of long-term treatment of depression: application to a one-year double-blind study comparing medifoxamine with fluoxetine. Clin Drug Investig. 1998;15(4):285-95. Source: EMBASE.
1896 Lehto SM, Tolmunen T, Kuikka J, et al. Midbrain serotonin and striatum dopamine transporter binding in double depression: a one-year follow-up study. Neurosci Lett. Aug. 29. 2008;441(3):291-5. Source: PubMed. [pmid: 18588943].
1897 Leibenluft E, Noonan BM, Wehr TA. Diurnal variation: reliability of measurement and relationship to typical and atypical symptoms of depression. J Affect Disord. Nov. 1992;26(3):199-204. Source: PubMed. [pmid: 1460170].
1898 Leiblum SR, Goldmeier D. Persistent genital arousal disorder in women: case reports of association with anti-depressant usage and withdrawal. J Sex Marital Ther. 2008;34(2):150-9. Source: PubMed. [pmid: 18224549].
1899 Leinonen E, Koponen H, Lepola U. Delirium during fluoxetine treatment. A case report. Ann Clin Psychiatry. Dec. 1993;5(4):255-7. Source: PubMed. [pmid: 8312983].
1900 Leinonen E, Lepola U, Koponen H. Substituting carbamazepine with oxcarbazepine increases citalopram levels. A report on two cases. Pharmacopsychiatry. Jul. 1996;29(4):156-8. Source: PubMed. [pmid: 8858715].
1901 Leinonen E, Niemi H. The influence of educational information on depressed outpatients treated with escitalopram: a semi-naturalistic study. Nord J Psychiatry. 2007;61(2):109-14. Source: PubMed. [pmid: 17454725].
1902 Leinonen E, Skarstein J, Behnke K, et al. Efficacy and tolerability of mirtazapine versus citalopram: a double-blind, randomized study in patients with major depressive disorder. Nordic Antidepressant Study Group. Int Clin Psychopharmacol. Nov. 1999;14(6):329-37. Source: PubMed. [pmid: 10565799].
1903 Lemoine P, Guilleminault C, Alvarez E. Improvement in subjective sleep in major depressive disorder with a novel antidepressant, agomelatine: randomized, double-blind comparison with venlafaxine. J Clin Psychiatry. Nov. 2007;68(11):1723-32. Source: PubMed. [pmid: 18052566].
1904 Lemonde S, Du L, Bakish D, et al. Association of the C(-1019)G 5-HT1A functional promoter polymorphism with antidepressant response. Int J Neuropsychopharmacol. Dec. 2004;7(4):501-6. Source: PubMed. [pmid: 15447813].
1905 Lenderking WR, Tennen H, Nackley JF, et al. The effects of venlafaxine on social activity level in depressed outpatients. J Clin Psychiatry. Mar. 1999;60(3):157-63. Source: PubMed. [pmid: 10192590].
1906 Lenox-Smith AJ, Jiang Q. Venlafaxine extended release versus citalopram in patients with depression unresponsive to a selective serotonin reuptake inhibitor. International Clinical Psychopharmacology. 2008;23(3):113-9. Source: PubMed. [pmid: 18408525].
1907 Lenox-Smith AJ, Reynolds A. A double-blind, randomised, placebo controlled study of venlafaxine XL in patients with generalised anxiety disorder in primary care. Br J Gen Pract. Oct. 2003;53(495):772-7. Source: PubMed. [pmid: 14601352].
1908 Lenze EJ, Mulsant BH, Dew MA, et al. Good treatment outcomes in late-life depression with comorbid anxiety. J Affect Disord. Dec. 2003;77(3):247-54. Source: PubMed. [pmid: 14612224].
1909 Leo R, Di Lorenzo G, Tesauro M, et al. Association between enhanced soluble CD40 ligand and proinflammatory and prothrombotic states in major depressive disorder: pilot observations on the effects of selective serotonin reuptake inhibitor therapy. J Clin Psychiatry. Nov. 2006;67(11):1760-6. Source: PubMed. [pmid: 17196057].
1910 Leo RJ. Movement disorders associated with the serotonin selective reuptake inhibitors. J Clin Psychiatry. Oct. 1996;57(10):449-54. Source: PubMed. [pmid: 8909330].
1911 Leon AC. The revised warning for antidepressants and suicidality: Unveiling the black box of statistical analyses. American Journal of Psychiatry. 2007;164(12):1786-9. Source: Scopus. [pmid: 18056231].
1912 Leon AC, Keller MB, Warshaw MG, et al. Prospective study of fluoxetine treatment and suicidal behavior in affectively ill subjects. Am J Psychiatry. Feb. 1999;156(2):195-201. Source: PubMed. [pmid: 9989554].
1913 Leon AC, Marzuk PM, Tardiff K, et al. Antidepressants in adult suicides in New York City: 2001-2004. Journal of Clinical Psychiatry. 2007;68(9):1399-403. Source: Scopus. [pmid: 17915979].
1914 Lepine JP, Altamura C, Ansseau M, et al. Tianeptine and paroxetine in major depressive disorder, with a special focus on the anxious component in depression: An international, 6-week double-blind study. Hum Psychopharmacol. 2001;16(3):219-27. Source: EMBASE. [pmid: 12404574].
1915 Lepine JP, Caillard V, Bisserbe JC, et al. A randomized, placebo-controlled trial of sertraline for prophylactic treatment of highly recurrent major depressive disorder. Am J Psychiatry. May. 2004;161(5):836-42. Source: PubMed. [pmid: 15121648].
1916 Lepine JP, Goger J, Blashko C, et al. A double-blind study of the efficacy and safety of sertraline and clomipramine in outpatients with severe major depression. Int Clin Psychopharmacol. Sep. 2000;15(5):263-71. Source: PubMed. [pmid: 10993128].
1917 Lepola U, Arato M, Zhu Y, et al. Sertraline versus imipramine treatment of comorbid panic disorder and major depressive disorder. J Clin Psychiatry. Jun. 2003;64(6):654-62. Source: PubMed. [pmid: 12823079].
1918 Lepola U, Wade A, Andersen HF. Do equivalent doses of escitalopram and citalopram have similar efficacy? A pooled analysis of two positive placebo-controlled studies in major depressive disorder. Int Clin Psychopharmacol. May. 2004;19(3):149-55. Source: PubMed. [pmid: 15107657].
1919 Lepola UM, Loft H, Reines EH. Escitalopram (10-20 mg/day) is effective and well tolerated in a placebo-controlled study in depression in primary care. Int Clin Psychopharmacol. Jul. 2003;18(4):211-7. Source: PubMed. [pmid: 12817155].
1920 Lepola UM, Wade AG, Leinonen EV, et al. A controlled, prospective, 1-year trial of citalopram in the treatment of panic disorder. J Clin Psychiatry. Oct. 1998;59(10):528-34. Source: PubMed. [pmid: 9818634].
1921 Leppik IE, Birnbaum AK. Epilepsy in the elderly. 2010:1184208-24. Source: Handsearch.
1922 Lerman C, Niaura R, Collins BN, et al. Effect of bupropion on depression symptoms in a smoking cessation clinical trial. Psychol Addict Behav. Dec. 2004;18(4):362-6. Source: PubMed. [pmid: 15631608].
1923 Leroi AM, Lalaude O, Antonietti M, et al. Prolonged stationary colonic motility recording in seven patients with severe constipation secondary to antidepressants. Neurogastroenterol Motil. Apr. 2000;12(2):149-54. Source: PubMed. [pmid: 10771496].
1924 Leroi I, Walentynowicz MA. Fluoxetine-imipramine interaction. Can J Psychiatry. Jun. 1996;41(5):318-9. Source: PubMed. [pmid: 8793156].
1925 Lesperance F, Frasure-Smith N, Koszycki D, et al. Effects of citalopram and interpersonal psychotherapy on depression in patients with coronary artery disease: the Canadian Cardiac Randomized Evaluation of Antidepressant and Psychotherapy Efficacy (CREATE) trial. Jama. 2007;297(4):367-79. Source: PubMed. [pmid: 17244833].
1926 Lesperance F, Frasure-Smith N, Laliberte MA, et al. An open-label study of nefazodone treatment of major depression in patients with congestive heart failure. Can J Psychiatry. Nov. 2003;48(10):695-701. Source: PubMed. [pmid: 14674053].
1927 Lesser I, Rosales A, Zisook S, et al. Depression outcomes of Spanish- and english-speaking Hispanic outpatients in STAR*D. Psychiatr Serv. 2008;59(11):1273-84. Source: PubMed. [pmid: 18971403].
1928 Lesser IM, Castro DB, Gaynes BN, et al. Ethnicity/race and outcome in the treatment of depression: results from STAR*D. Med Care. 2007;45(11):1043-51. Source: PubMed. [pmid: 18049344].
1929 Lesser IM, Leuchter AF, Trivedi MH, et al. Insured and non-insured depressed outpatients: how do they compare?. Ann Clin Psychiatry. Apr-Jun. 2007;19(2):73-82. Source: PubMed. [pmid: 17612846].
1930 Lesser IM, Leuchter AF, Trivedi MH, et al. Characteristics of insured and noninsured outpatients with depression in STAR(*)D. Psychiatr Serv. Aug. 2005;56(8):995-1004. Source: PubMed. [pmid: 16088018].
1931 Lesser IM, Myers HF, Lin KM, et al. Ethnic differences in antidepressant response: a prospective multi-site clinical trial. Depress Anxiety. 2010;27(1):56-62. Source: PubMed. [pmid: 19960492].
1932 Lestra C, d'Amato T, Ghaemmaghami C, et al. Biological parameters in major depression: effects of paroxetine, viloxazine, moclobemide, and electroconvulsive therapy. Relation to early clinical outcome. Biol Psychiatry. Aug. 15. 1998;44(4):274-80. Source: PubMed. [pmid: 9715359].
1933 Letizia C, Kapik B, Flanders WD. Suicidal risk during controlled clinical investigations of fluvoxamine. J Clin Psychiatry. Sep. 1996;57(9):415-21. Source: PubMed. [pmid: 9746450].
1934 Leuchter AF, Cook IA, Gilmer WS, et al. Effectiveness of a quantitative electroencephalographic biomarker for predicting differential response or remission with escitalopram and bupropion in major depressive disorder. Psychiatry Research. Sep. 30. 2009. 2009;169(2):132-8. Source: PsycINFO. [pmid: 19709754].
1935 Leuchter AF, Cook IA, Witte EA, et al. Changes in brain function of depressed subjects during treatment with placebo. Am J Psychiatry. Jan. 2002;159(1):122-9. Source: PubMed. [pmid: 11772700].
1936 Leuchter AF, Husain MM, Cook IA, et al. Painful physical symptoms and treatment outcome in major depressive disorder: A STAR*D (Sequenced Treatment Alternatives to Relieve Depression) report. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2010;40(2):239-51. Source: PsycINFO.
1937 Leuchter AF, Lesser IM, Trivedi MH, et al. An open pilot study of the combination of escitalopram and bupropion-SR for outpatients with major depressive disorder. J Psychiatr Pract. Sep. 2008;14(5):271-80. Source: PubMed. [pmid: 18832958].
1938 Leuchter AF, Morgan M, Cook IA, et al. Pretreatment neurophysiological and clinical characteristics of placebo responders in treatment trials for major depression. Psychopharmacology (Berl). Dec. 2004;177(1-2):15-22. Source: PubMed. [pmid: 15252704].
1939 Leung M, Remick R. Sertraline-associated hyponatremia. Can J Psychiatry. Oct. 1995;40(8):497-8. Source: PubMed. [pmid: 8681276].
1940 Leung VP, Chiu HF, Lam LC. Hyponatremia associated with paroxetine. Pharmacopsychiatry. Jan. 1998;31(1):32-4. Source: PubMed. [pmid: 9524983].
1941 Leverich GS, Altshuler LL, Frye MA, et al. Risk of switch in mood polarity to hypomania or mania in patients with bipolar depression during acute and continuation trials of venlafaxine, sertraline, and bupropion as adjuncts to mood stabilizers. American Journal of Psychiatry. 2006;163(2):232-9. Source: Scopus. [pmid: 16449476].
1942 Levin FR, Bisaga A, Raby W, et al. Effects of major depressive disorder and attention-deficit/hyperactivity disorder on the outcome of treatment for cocaine dependence. J Subst Abuse Treat. Jan. 2008;34(1):80-9. Source: PubMed. [pmid: 17574796].
1943 Levin OS. Coaxil (tianeptine) in the treatment of depression in Parkinson's disease. Neuroscience and Behavioral Physiology. May. 2007. 2007;37(4):419-24. Source: PsycINFO. [pmid: 17457538].
1944 Levin TT, Cortes-Ladino A, Weiss M, et al. Life-threatening serotonin toxicity due to a citalopram-fluconazole drug interaction: case reports and discussion. Gen Hosp Psychiatry. Jul-Aug. 2008;30(4):372-7. Source: PubMed. [pmid: 18585543].
1945 Levine LR, Pope HGJ, Enas GG, et al. Fluoxetine in the treatment of bulimia nervosa: A multicenter, placebo- controlled, double-blind trial. Arch Gen Psychiatry. 1992;49(2):139-47. Source: EMBASE. [pmid: 1550466].
1946 Levine MD, Perkins KA, Kalarchian MA, et al. Bupropion and cognitive behavioral therapy for weight-concerned women smokers. Archives of Internal Medicine. 2010;170(6):543-50. Source: EMBASE. [pmid: 20308641].
1947 Levine S, Anderson D, Bystritsky A, et al. A report of eight HIV-seropositive patients with major depression responding to fluoxetine. J Acquir Immune Defic Syndr. 1990;3(11):1074-7. Source: PubMed. [pmid: 2213507].
1948 Levine S, Deo R, Mahadevan K. A comparative trial of a new antidepressant, fluoxetine. Br J Psychiatry. May. 1987;150:653-5. Source: PubMed. [pmid: 3307982].
1949 Levitan RD, Shen JH, Jindal R, et al. Preliminary randomized double-blind placebo-controlled trial of tryptophan combined with fluoxetine to treat major depressive disorder: antidepressant and hypnotic effects. J Psychiatry Neurosci. Sep. 2000;25(4):337-46. Source: PubMed. [pmid: 11022398].
1950 Levkovitz Y, Caftori R, Avital A, et al. The SSRIs drug Fluoxetine, but not the noradrenergic tricyclic drug Desipramine, improves memory performance during acute major depression. Brain Res Bull. Aug. 15. 2002;58(4):345-50. Source: PubMed. [pmid: 12183009].
1951 Levsky ME, Schwartz JB. Sertraline-induced hyponatremia in an older patient. J Am Geriatr Soc. Dec. 1998;46(12):1582-3. Source: PubMed. [pmid: 9848826].
1952 Levy E, Margolese HC. Migraine headache prophylaxis and treatment with low-dose mirtazapine. Int Clin Psychopharmacol. Sep. 2003;18(5):301-3. Source: PubMed. [pmid: 12920393].
1953 Levy NB, Blumenfield M, Beasley CM Jr, et al. Fluoxetine in depressed patients with renal failure and in depressed patients with normal kidney function. Gen Hosp Psychiatry. Jan. 1996;18(1):8-13. Source: PubMed. [pmid: 8666216].
1954 Lewis Ian S, Joska John A, Siegfried N. Antidepressants for depression in adults with HIV infection. Cochrane Database of Systematic Reviews. 2010;(5). Source: The Cochrane Library.
1955 Lewis-Fernández R, Blanco C, Mallinckrodt CH, et al. Duloxetine in the treatment of major depressive disorder: Comparisons of safety and efficacy in U S Hispanic and majority Caucasian patients. Journal of Clinical Psychiatry. 2006;67(9):1379-90. Source: PsycINFO. [pmid: 17017824].
1956 Lewis-Hall FC, Wilson MG, Tepner RG, et al. Fluoxetine vs. tricyclic antidepressants in women with major depressive disorder. J Womens Health. Jun. 1997;6(3):337-43. Source: PubMed. [pmid: 9201668].
1957 Leykin Y, Amsterdam JD, DeRubeis RJ, et al. Progressive resistance to a selective serotonin reuptake inhibitor but not to cognitive therapy in the treatment of major depression. J Consult Clin Psychol. Apr. 2007;75(2):267-76. Source: PubMed. [pmid: 17469884].
1958 Leznoff A, Binkley KE, Joffee RT, et al. Adverse cutaneous reactions associated with fluoxetine strategy for reintroduction of this drug in selected patients. J Clin Psychopharmacol. Oct. 1992;12(5):355-7. Source: PubMed. [pmid: 1479054].
1959 Li CT, Lin CP, Chou KH, et al. Structural and cognitive deficits in remitting and non-remitting recurrent depression: A voxel-based morphometric study. NeuroImage. 2010;50(1):347-56. Source: EMBASE. [pmid: 19931620].
1960 Li LT, Wang SH, Ge HY, et al. The beneficial effects of the herbal medicine Free and Easy Wanderer Plus (FEWP) and fluoxetine on post-stroke depression. J Altern Complement Med. 2008;14(7):841-6. Source: PubMed. [pmid: 18721085].
1961 Liappas J, Paparrigopoulos T, Tzavellas E, et al. Mirtazapine and venlafaxine in the management of collateral psychopathology during alcohol detoxification. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 2005;29(1):55-60. Source: PubMed. [pmid: 15610945].
1962 Liau CH, Shen WW, Su KP. Venlafaxine-associated serotonin syndrome and manic episode in a geriatric depressive patient. Psychiatry Clin Neurosci. Feb. 2006;60(1):121-2. Source: PubMed. [pmid: 16472373].
1963 Libby AM, Brent DA, Morrato EH, et al. Decline in treatment of pediatric depression after FDA advisory on risk of suicidality with SSRIs. American Journal of Psychiatry. 2007;164(6):884-91. Source: Scopus. [pmid: 17541047].
1964 Liberek C, Aubry JM, Baud P. Manic switch and serotonin syndrome with venlafaxine-lithium-valproate association. Therapie. Nov-Dec. 2006;61(6):531-3. Source: PubMed. [pmid: 17348610].
1965 Licht CMM, De Geus EJC, Van Dyck R, et al. Longitudinal evidence for unfavorable effects of antidepressants on heart rate variability. Biological psychiatry. 2010;68(9):861-8. Source: EMBASE. [pmid: 20843507].
1966 Licht RW, Gijsman H, Nolen WA, et al. Are antidepressants safe in the treatment of bipolar depression? A critical evaluation of their potential risk to induce switch into mania or cycle acceleration. Acta Psychiatrica Scandinavica. 2008;118(5):337-46. Source: Scopus. [pmid: 18754834].
1967 Licht RW, Qvitzau S. Treatment strategies in patients with major depression not responding to first-line sertraline treatment. A randomised study of extended duration of treatment, dose increase or mianserin augmentation. Psychopharmacology (Berl). May. 2002;161(2):143-51. Source: PubMed. [pmid: 11981594].
1968 Licinio J, Dong C, Wong ML. Novel sequence variations in the brain-derived neurotrophic factor gene and association with major depression and antidepressant treatment response. Arch Gen Psychiatry. 2009;66(5):488-97. Source: PubMed. [pmid: 19414708].
1969 Licinio J, O'Kirwan F, Irizarry K, et al. Association of a corticotropin-releasing hormone receptor 1 haplotype and antidepressant treatment response in Mexican-Americans. Mol Psychiatry. Dec. 2004;9(12):1075-82. Source: PubMed. [pmid: 15365580].
1970 Lieb K, Vollm B, Rucker G, et al. Pharmacotherapy for borderline personality disorder: Cochrane systematic review of randomised trials. British Journal of Psychiatry. 2010;196(1):4-12. Source: EMBASE. [pmid: 20044651].
1971 Lieberman DZ, Montgomery SA, Tourian KA, et al. A pooled analysis of two placebo-controlled trials of desvenlafaxine in major depressive disorder. Int Clin Psychopharmacol. Jul. 2008;23(4):188-97. Source: PubMed. [pmid: 18545056].
1972 Lieberman JA, Greenhouse J, Hamer RM, et al. Comparing the effects of antidepressants: Consensus guidelines for evaluating quantitative reviews of antidepressant efficacy. Neuropsychopharmacology. 2005;30(3):445-60. Source: Scopus. [pmid: 15647752].
1973 Liebowitz MR, Manley AL, Padmanabhan SK, et al. Efficacy, safety, and tolerability of desvenlafaxine 50 mg/day and 100 mg/day in outpatients with major depressive disorder. Curr Med Res Opin. 2008;24(7):1877-90. Source: PubMed. [pmid: 18507895].
1974 Liebowitz MR, Yeung PP, Entsuah R. A randomized, double-blind, placebo-controlled trial of desvenlafaxine succinate in adult outpatients with major depressive disorder. J Clin Psychiatry. 2007;68(11):1663-72. Source: PubMed. [pmid: 18052559].
1975 Lin CC. Duloxetine treatment of social anxiety disorder with comorbid major depression. J Clin Psychopharmacol. Oct. 2008;28(5):591-2. author reply 2-3. Source: PubMed. [pmid: 18794669].
1976 Lin CH, Lin KS, Lin CY, et al. Time to rehospitalization in patients with major depressive disorder taking venlafaxine or fluoxetine. J Clin Psychiatry. 2008;69(1):54-9. Source: PubMed. [pmid: 18312038].
1977 Linden M, Gothe H, Dittmann RW, et al. Early termination of antidepressant drug treatment. J Clin Psychopharmacol. Oct. 2000;20(5):523-30. Source: PubMed. [pmid: 11001236].
1978 Linden M, Ludewig K, Munz T, et al. Dosage finding and outcome of venlafaxine treatment in psychiatric outpatients and inpatients: results of a drug utilization observation study. Pharmacopsychiatry. Sep. 2003;36(5):197-205. Source: PubMed. [pmid: 14571355].
1979 Linden M, Westram A. Prescribing a sedative antidepressant for patients at work or on sick leave under conditions of routine care. Pharmacopsychiatry. 2010;43(1):1-6. Source: PsycINFO. [pmid: 20013553].
1980 Linden M, Westram A, Schmidt LG, et al. Impact of the WHO depression guideline on patient care by psychiatrists: a randomized controlled trial. Eur Psychiatry. Sep. 2008;23(6):403-8. Source: PubMed. [pmid: 18583105].
1981 Linden RD, Wilcox CS, Heiser JF, et al. Are selective serotonin reuptake inhibitors well tolerated in somatizing depressives?. Psychopharmacol Bull. 1994;30(2):151-6. Source: PubMed. [pmid: 7831448].
1982 Lindenmayer JP, Iskander A, Park M, et al. Clinical and neurocognitive effects of clozapine and risperidone in treatment-refractory schizophrenic patients: a prospective study. J Clin Psychiatry. Oct. 1998;59(10):521-7. Source: PubMed. [pmid: 9818633].
1983 Lineberry CG, Johnston JA, Raymond RN, et al. A fixed-dose (300 mg) efficacy study of bupropion and placebo in depressed outpatients. J Clin Psychiatry. May. 1990;51(5):194-9. Source: PubMed. [pmid: 2110559].
1984 Linet LS. Treatment of a refractory depression with a combination of fluoxetine and d-amphetamine. Am J Psychiatry. Jun. 1989;146(6):803-4. Source: PubMed. [pmid: 2786343].
1985 Linka T, Muller BW, Bender S, et al. The intensity dependence of the auditory evoked N1 component as a predictor of response to Citalopram treatment in patients with major depression. Neurosci Lett. Sep. 9. 2004;367(3):375-8. Source: PubMed. [pmid: 15337269].
1986 Liskin B, Walsh BT, Roose SP, et al. Imipramine-induced inappropriate ADH secretion. J Clin Psychopharmacol. Jun. 1984;4(3):146-7. Source: PubMed. [pmid: 6429213].
1987 Liston HL, Markowitz JS, Hunt N, et al. Lack of citalopram effect on the pharmacokinetics of cyclosporine. Psychosomatics. Jul-Aug. 2001;42(4):370-2. Source: PubMed. [pmid: 11496034].
1988 Little JT, Ketter TA, Kimbrell TA, et al. Venlafaxine or bupropion responders but not nonresponders show baseline prefrontal and paralimbic hypometabolism compared with controls. Psychopharmacol Bull. 1996;32(4):629-35. Source: PubMed. [pmid: 8993084].
1989 Little JT, Ketter TA, Kimbrell TA, et al. Bupropion and venlafaxine responders differ in pretreatment regional cerebral metabolism in unipolar depression. Biol Psychiatry. Feb. 1. 2005;57(3):220-8. Source: PubMed. [pmid: 15691522].
1990 Little JT, Ketter TA, Mathe AA, et al. Venlafaxine but not bupropion decreases cerebrospinal fluid 5-hydroxyindoleacetic acid in unipolar depression. Biol Psychiatry. Feb. 1. 1999;45(3):285-9. Source: PubMed. [pmid: 10023503].
1991 Liu BA, Mittmann N, Knowles SR, et al. Hyponatremia and the syndrome of innappropriate secretion of antidiuretic hormone associated with the use of selective serotonin reuptake inhibitors: a review of spontaneous reports. CMAJ. 1996. Sep. 1996;155(5):519-27. Source: Handsearch. [pmid: 8804257].
1992 Liu CC, Liang KY, Liao SC. Antidepressant-associated mania: soon after switch from fluoxetine to mirtazapine in an elderly woman with mixed depressive features. J Psychopharmacol. Mar. 2009;23(2):220-2. Source: PubMed. [pmid: 18515466].
1993 Liu CY, Yang YY, Wang SJ, et al. Fluoxetine-related suicidality and muscle aches in a patient with poststroke depression. J Clin Psychopharmacol. Dec. 1996;16(6):466-7. Source: PubMed. [pmid: 8959479].
1994 Liu KS, Snavely DB, Ball WA, et al. Is bigger better for depression trials?. J Psychiatr Res. Jul. 2008;42(8):622-30. Source: PubMed. [pmid: 17825841].
1995 Liu P, He FF, Bai WP, et al. Menopausal depression: comparison of hormone replacement therapy and hormone replacement therapy plus fluoxetine. Chin Med J (Engl). Feb. 2004;117(2):189-94. Source: PubMed. [pmid: 14975200].
1996 Liu X, Gelwicks S, Faries DE, et al. Initial duloxetine prescription dose and treatment adherence and persistence in patients with major depressive disorder. International Clinical Psychopharmacology. 2010;25(6):315-22. Source: EMBASE. [pmid: 20706125].
1997 Llorca PM, Azorin JM, Despiegel N, et al. Efficacy of escitalopram in patients with severe depression: a pooled analysis. Int J Clin Pract. Mar. 2005;59(3):268-75. Source: PubMed. [pmid: 15857321].
1998 Llorca PM, Fernandez JL. Escitalopram in the treatment of major depressive disorder: clinical efficacy, tolerability and cost-effectiveness vs. venlafaxine extended-release formulation. Int J Clin Pract. Apr. 2007;61(4):702-10. Source: PubMed. [pmid: 17394446].
1999 Lobello KW, Preskorn SH, Guico-Pabia CJ, et al. Cytochrome P450 2D6 phenotype predicts antidepressant efficacy of venlafaxine: A secondary analysis of 4 studies in major depressive disorder. Journal of Clinical Psychiatry. 2010;71(11):1482-7. Source: EMBASE. [pmid: 20441720].
2000 Lock JD, Gwirtsman HE, Targ EF. Possible adverse drug interactions between fluoxetine and other psychotropics. J Clin Psychopharmacol. Oct. 1990;10(5):383-4. Source: PubMed. [pmid: 2258459].
2001 Loftis JM, Socherman RE, Howell CD, et al. Association of interferon-alpha-induced depression and improved treatment response in patients with hepatitis C. Neurosci Lett. Jul. 22. 2004;365(2):87-91. Source: PubMed. [pmid: 15245784].
2002 Logsdon MC, Wisner K, Hanusa BH. Does maternal role functioning improve with antidepressant treatment in women with postpartum depression?. J Womens Health (Larchmt). Jan-Feb. 2009;18(1):85-90. Source: PubMed. [pmid: 19132881].
2003 Logsdon MC, Wisner K, Hanusa BH, et al. Role functioning and symptom remission in women with postpartum depression after antidepressant treatment. Arch Psychiatr Nurs. Dec. 2003;17(6):276-83. Source: PubMed. [pmid: 14685952].
2004 Loi S, Bonwick R. Electroconvulsive therapy for treatment of late-onset obsessive compulsive disorder. International Psychogeriatrics. 2010;22(5):830-1. Source: EMBASE. [pmid: 20370958].
2005 Lojko D, Rybakowski JK. L-thyroxine augmentation of serotonergic antidepressants in female patients with refractory depression. J Affect Disord. Nov. 2007;103(1-3):253-6. Source: PubMed. [pmid: 17289154].
2006 Londborg PD, Smith WT, Glaudin V, et al. Short-term cotherapy with clonazepam and fluoxetine: anxiety, sleep disturbance and core symptoms of depression. J Affect Disord. Dec. 2000;61(1-2):73-9. Source: PubMed. [pmid: 11099743].
2007 Lonnqvist J, Sihvo S, Syvalahti E, et al. Moclobemide and fluoxetine in atypical depression: a double-blind trial. J Affect Disord. Nov. 1994;32(3):169-77. Source: PubMed. [pmid: 7852659].
2008 Lonnqvist J, Sihvo S, Syvalahti E, et al. Moclobemide and fluoxetine in the prevention of relapses following acute treatment of depression. Acta Psychiatr Scand. Mar. 1995;91(3):189-94. Source: PubMed. [pmid: 7625194].
2009 Lonnqvist J, Sintonen H, Syvalahti E, et al. Antidepressant efficacy and quality of life in depression: a double-blind study with moclobemide and fluoxetine. Acta Psychiatr Scand. Jun. 1994;89(6):363-9. Source: PubMed. [pmid: 8085464].
2010 Loo H, Hale A, D'Haenen H. Determination of the dose of agomelatine, a melatoninergic agonist and selective 5-HT(2C) antagonist, in the treatment of major depressive disorder: a placebo-controlled dose range study. Int Clin Psychopharmacol. Sep. 2002;17(5):239-47. Source: PubMed. [pmid: 12177586].
2011 Loo H, Saiz-Ruiz J, Costa e Silva J, et al. Efficacy and safety of tianeptine in the treatment of depressive disorders in comparison with fluoxetine. J Affect Disord. Dec. 1999;56(2-3):109-18. Source: PubMed. [pmid: 10701468].
2012 Loonen AJ, Doorschot CH, Oostelbos MC, et al. Lack of drug interactions between mirtazapine and risperidone in psychiatric patients: a pilot study. Eur Neuropsychopharmacol. Dec. 1999;10(1):51-7. Source: PubMed. [pmid: 10647097].
2013 Lopez-Iibor. Reduced suicidality with paroxetine. European Psychiatry. 1993;8(Suppl 1):17S-9S. Source: Handsearch.
2014 Lopez-Munoz F, Rubio G, Alamo C, et al. Reboxetine addition in patients with mirtazapine-resistant depression: a case series. Clin Neuropharmacol. Jul-Aug. 2006;29(4):192-6. Source: PubMed. [pmid: 16855420].
2015 Lorenz RA, Vandenberg AM, Canepa EA. Serotonergic antidepressants and linezolid: a retrospective chart review and presentation of cases. Int J Psychiatry Med. 2008;38(1):81-90. Source: PubMed. [pmid: 18624020].
2016 Lorenzetti V, Allen NB, Whittle S, et al. Amygdala volumes in a sample of current depressed and remitted depressed patients and healthy controls. Journal of affective disorders. 2010;120(1-3):112-9. Source: EMBASE. [pmid: 19464062].
2017 Lotrich FE, Rosen J, Pollock BG. Dextromethorphan-induced delirium and possible methadone interaction. Am J Geriatr Pharmacother. Mar. 2005;3(1):17-20. Source: PubMed. [pmid: 16089243].
2018 Louie AK, Lewis TB, Lannon RA. Use of low-dose fluoxetine in major depression and panic disorder. J Clin Psychiatry. Nov. 1993;54(11):435-8. Source: PubMed. [pmid: 8270588].
2019 Lowe B, Schenkel I, Bair MJ, et al. Efficacy, predictors of therapy response, and safety of sertraline in routine clinical practice: prospective, open-label, non-interventional postmarketing surveillance study in 1878 patients. J Affect Disord. Aug. 2005;87(2-3):271-9. Source: PubMed. [pmid: 15979151].
2020 Lowe B, Schenkel I, Carney-Doebbeling C, et al. Responsiveness of the PHQ-9 to Psychopharmacological Depression Treatment. Psychosomatics. Jan-Feb. 2006;47(1):62-7. Source: PubMed. [pmid: 16384809].
2021 Lowe B, Unutzer J, Callahan CM, et al. Monitoring depression treatment outcomes with the patient health questionnaire-9. Med Care. Dec. 2004;42(12):1194-201. Source: PubMed. [pmid: 15550799].
2022 Lu G, Ades AE. Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med. Oct. 30. 2004;23(20):3105-24. Source: PubMed. [pmid: 15449338].
2023 Lu G, Ades AE. Assessing evidence inconsistency in mixed treatment comparisons. Journal of the American Statistical Association. 447. 101(474):2006-59. Source: Scopus.
2024 Luborzewski A, Regen F, Schindler F, et al. Modafinil-induced reversible hyperkinetic nondystonic movement disorder in a patient with major depressive disorder. J Neuropsychiatry Clin Neurosci. Spring. 2006;18(2):248-9. Source: PubMed. [pmid: 16720809].
2025 Lucae S, Ising M, Horstmann S, et al. HTR2A gene variation is involved in antidepressant treatment response. European Neuropsychopharmacology. 2010;20(1):65-8. Source: EMBASE. [pmid: 19758789].
2026 Lucca A, Gentilini G, Lopez-Silva S, et al. Simultaneous determination of human plasma levels of four selective serotonin reuptake inhibitors by high-performance liquid chromatography. Ther Drug Monit. Jun. 2000;22(3):271-6. Source: PubMed. [pmid: 10850393].
2027 Lucena MI, Blanco E, Corrales MA, et al. Interaction of fluoxetine and valproic acid. Am J Psychiatry. Apr. 1998;155(4):575. Source: PubMed. [pmid: 9546010].
2028 Ludwig J, Marcotte DE. Anti-depressants, suicide, and drug regulation. Journal of Policy Analysis and Management. 2005;24(2):249-72. Source: Scopus. [pmid: 15776534].
2029 Ludwig J, Marcotte DE, Norberg K. Anti-depressants and suicide. Journal of Health Economics. 2009;28(3):659-76. Source: EMBASE. [pmid: 19324439].
2030 Luis Blay S. Depression and psoriasis comorbidity. Treatment with paroxetine: two case reports. Ann Clin Psychiatry. Oct-Dec. 2006;18(4):271-2. Source: PubMed. [pmid: 17162628].
2031 Lumley T. Network meta-analysis for indirect treatment comparisons. Stat Med. Aug. 30. 2002;21(16):2313-24. Source: PubMed. [pmid: 12210616].
2032 Lustman PJ, Clouse RE, Nix BD, et al. Sertraline for prevention of depression recurrence in diabetes mellitus: a randomized, double-blind, placebo-controlled trial. Arch Gen Psychiatry. 2006;63(5):521-9. Source: PubMed. [pmid: 16651509].
2033 Lustman PJ, Williams MM, Sayuk GS, et al. Factors influencing glycemic control in type 2 diabetes during acute- and maintenance-phase treatment of major depressive disorder with bupropion. Diabetes Care. Mar. 2007;30(3):459-66. Source: PubMed. [pmid: 17327305].
2034 Luthringer R, Toussaint M, Schaltenbrand N, et al. A double-blind, placebo-controlled evaluation of the effects of orally administered venlafaxine on sleep in inpatients with major depression. Psychopharmacol Bull. 1996;32(4):637-46. Source: PubMed. [pmid: 8993085].
2035 Luty SE, Joyce PR, Mulder RT. Comparison between noradrenergic and serotonergic medications using the social adjustment scale: is drive enhancement necessary for recovery of social functioning?. J Psychopharmacol. Dec. 2001;15(4):257-64. Source: PubMed. [pmid: 11769819].
2036 Lydiard RB, Anton RF, Cunningham T. Interactions between sertraline and tricyclic antidepressants. Am J Psychiatry. Jul. 1993;150(7):1125-6. Source: PubMed. [pmid: 8317590].
2037 Lydiard RB, Laird LK, Morton WA Jr, et al. Fluvoxamine, imipramine, and placebo in the treatment of depressed outpatients: effects on depression. Psychopharmacol Bull. 1989;25(1):68-70. Source: PubMed. [pmid: 2505304].
2038 Lydiard RB, Stahl SM, Hertzman M, et al. A double-blind, placebo-controlled study comparing the effects of sertraline versus amitriptyline in the treatment of major depression. J Clin Psychiatry. Nov. 1997;58(11):484-91. Source: PubMed. [pmid: 9413414].
2039 Lydiatt WM, Denman D, McNeilly DP, et al. A randomized, placebo-controlled trial of citalopram for the prevention of major depression during treatment for head and neck cancer. Arch Otolaryngol Head Neck Surg. May. 2008;134(5):528-35. Source: PubMed. [pmid: 18490576].
2040 Lyketsos CG, DelCampo L, Steinberg M, et al. Treating depression in Alzheimer disease: efficacy and safety of sertraline therapy, and the benefits of depression reduction: the DIADS. Arch Gen Psychiatry. Jul. 2003;60(7):737-46. Source: PubMed. [pmid: 12860778].
2041 Lyketsos CG, Sheppard JM, Steele CD, et al. Randomized, placebo-controlled, double-blind clinical trial of sertraline in the treatment of depression complicating Alzheimer's disease: initial results from the Depression in Alzheimer's Disease study. Am J Psychiatry. Oct. 2000;157(10):1686-9. Source: PubMed. [pmid: 11007727].
2042 Lyketsos CG, Taragano F, Treisman GJ, et al. Major depression and its response to sertraline in primary care vs. psychiatric office practice patients. Results of an open-label trial in Argentina. Psychosomatics. Jan-Feb. 1999;40(1):70-5. Source: PubMed. [pmid: 9989124].
2043 IJ MA, Huijbregts KML, Van Marwijk HWJ, et al. Cost-effectiveness of collaborative care including PST and an antidepressant treatment algorithm for the treatment of major depressive disorder in primary care; A randomised clinical trial. BMC Health Services Research. 2007;7(34). Source: EMBASE.
2044 Mackay FJ, Dunn NR, Mann RD. Antidepressants and the serotonin syndrome in general practice. Br J Gen Pract. Nov. 1999;49(448):871-4. Source: PubMed. [pmid: 10818650].
2045 Mackay FJ, Dunn NR, Wilton LV, et al. A comparison of fluvoxamine, fluoxetine, sertraline and paroxetine examined by observational cohort studies. Pharmacoepidemiol Drug Saf. Jul. 1997;6(4):235-46. Source: PubMed. [pmid: 15073774].
2046 Mackay FR, Dunn NR, Martin RM, et al. Newer antidepressants: a comparison of tolerability in general practice. Br J Gen Pract. Nov. 1999;49(448):892-6. Source: PubMed. [pmid: 10818655].
2047 Madhusoodanan S, Alexeenko L, Sanders R, et al. Extrapyramidal symptoms associated with antidepressants--a review of the literature and an analysis of spontaneous reports. Ann Clin Psychiatry. Aug. 2010;22(3):148-56. Source: PubMed. [pmid: 20680187].
2048 Madsen IEH, Diderichsen F, Burr H, et al. Person-related work and incident use of antidepressants: Relations and mediating factors from the Danish work environment cohort study. Scandinavian Journal of Work, Environment and Health. 2010;36(6):435-44. Source: EMBASE.
2049 Maes M, Libbrecht I, van Hunsel F, et al. Pindolol and mianserin augment the antidepressant activity of fluoxetine in hospitalized major depressed patients, including those with treatment resistance. J Clin Psychopharmacol. Apr. 1999;19(2):177-82. Source: PubMed. [pmid: 10211920].
2050 Maes M, Meltzer HY, Bosmans E, et al. Increased plasma concentrations of interleukin-6, soluble interleukin-6, soluble interleukin-2 and transferrin receptor in major depression. J Affect Disord. Aug. 18. 1995;34(4):301-9. Source: PubMed. [pmid: 8550956].
2051 Maes M, Mihaylova I, Kubera M, et al. Increased plasma peroxides and serum oxidized low density lipoprotein antibodies in major depression: Markers that further explain the higher incidence of neurodegeneration and coronary artery disease. Journal of affective disorders. 2010;125(1-3):287-94. Source: EMBASE. [pmid: 20083310].
2052 Maes M, Van Gastel A, Delmeire L, et al. Decreased platelet alpha-2 adrenoceptor density in major depression: effects of tricyclic antidepressants and fluoxetine. Biol Psychiatry. Feb. 1. 1999;45(3):278-84. Source: PubMed. [pmid: 10023502].
2053 Maes M, Vandoolaeghe E, Desnyder R. Efficacy of treatment with trazodone in combination with pindolol or fluoxetine in major depression. J Affect Disord. Dec. 16. 1996;41(3):201-10. Source: PubMed. [pmid: 8988452].
2054 Maes M, Verkerk R, Vandoolaeghe E, et al. Serum levels of excitatory amino acids, serine, glycine, histidine, threonine, taurine, alanine and arginine in treatment-resistant depression: modulation by treatment with antidepressants and prediction of clinical responsivity. Acta Psychiatr Scand. Apr. 1998;97(4):302-8. Source: PubMed. [pmid: 9570492].
2055 Maes M, Westenberg H, Vandoolaeghe E, et al. Effects of trazodone and fluoxetine in the treatment of major depression: therapeutic pharmacokinetic and pharmacodynamic interactions through formation of meta-chlorophenylpiperazine. J Clin Psychopharmacol. Oct. 1997;17(5):358-64. Source: PubMed. [pmid: 9315986].
2056 Magai C, Kennedy G, Cohen CI, et al. A controlled clinical trial of sertraline in the treatment of depression in nursing home patients with late-stage Alzheimer's disease. Am J Geriatr Psychiatry. Winter. 2000;8(1):66-74. Source: PubMed. [pmid: 10648297].
2057 Mahapatra SN, Hackett D. A randomised, double-blind, parallel-group comparison of venlafaxine and dothiepin in geriatric patients with major depression. Int J Clin Pract. Jun. 1997;51(4):209-13. Source: PubMed. [pmid: 9287259].
2058 Mahlberg R, Kunz D, Sasse J, et al. Serotonin syndrome with tramadol and citalopram. Am J Psychiatry. Jun. 2004;161(6):1129. Source: PubMed. [pmid: 15169709].
2059 Maina G, Albert U, Salvi V, et al. Weight gain during long-term treatment of obsessive-compulsive disorder: a prospective comparison between serotonin reuptake inhibitors. J Clin Psychiatry. Oct. 2004;65(10):1365-71. Source: PubMed. [pmid: 15491240].
2060 Maina G, Rosso G, Crespi C, et al. Combined brief dynamic therapy and pharmacotherapy in the treatment of major depressive disorder: a pilot study. Psychother Psychosom. 2007;76(5):298-305. Source: PubMed. [pmid: 17700050].
2061 Maina G, Rosso G, Rigardetto S, et al. No effect of adding brief dynamic therapy to pharmacotherapy in the treatment of obsessive-compulsive disorder with concurrent major depression. Psychother Psychosom. 2010;79(5):295-302. Source: PubMed. [pmid: 20616624].
2062 Maj J, Palider W, Rawlow. Trazodone, a central serotonin antagonist and agonist. J Neural Transm. 1979;44(3):237-48. Source: PubMed. [pmid: 438809].
2063 Malek-Ahmadi P. Gabapentin and posttraumatic stress disorder. Ann Pharmacother. May. 2003;37(5):664-6. Source: PubMed. [pmid: 12708942].
2064 Malek-Ahmadi P, Allen SA. Paroxetine-molindone interaction. J Clin Psychiatry. Feb. 1995;56(2):82-3. Source: PubMed. [pmid: 7852260].
2065 Malek-Ahmadi P, Chavez M, Contreras SA. Coadministration of isoniazid and antidepressant drugs. J Clin Psychiatry. Nov. 1996;57(11):550. Source: PubMed. [pmid: 8968310].
2066 Malhi GS, Ng F, Berk M. Dual-dual action? Combining venlafaxine and mirtazapine in the treatment of depression. Aust N Z J Psychiatry. Apr. 2008;42(4):346-9. Source: PubMed. [pmid: 18330778].
2067 Malison RT, Price LH, Berman R, et al. Reduced brain serotonin transporter availability in major depression as measured by [123I]-2 beta-carbomethoxy-3 beta-(4-iodophenyl)tropane and single photon emission computed tomography. Biol Psychiatry. Dec. 1. 1998;44(11):1090-8. Source: PubMed. [pmid: 9836013].
2068 Mallinckrodt C, Chuang-Stein C, McSorley P, et al. A case study comparing a randomized withdrawal trial and a double-blind long-term trial for assessing the long-term efficacy of an antidepressant. Pharmaceutical Statistics. 2007;6(1):9-22. Source: EMBASE. [pmid: 17238129].
2069 Mallinckrodt CH, Goldstein DJ, Detke MJ, et al. Duloxetine: A New Treatment for the Emotional and Physical Symptoms of Depression. Prim Care Companion J Clin Psychiatry. Feb. 2003;5(1):19-28. Source: PubMed. [pmid: 15156243].
2070 Mallinckrodt CH, Prakash A, Andorn AC, et al. Duloxetine for the treatment of major depressive disorder: a closer look at efficacy and safety data across the approved dose range. J Psychiatr Res. 2006;40(4):337-48. Source: PubMed. [pmid: 16271726].
2071 Mallinckrodt CH, Prakash A, Houston JP, et al. Differential antidepressant symptom efficacy: placebo-controlled comparisons of duloxetine and SSRIs (fluoxetine, paroxetine, escitalopram). Neuropsychobiology. 2007;56(2-3):73-85. Source: PubMed. [pmid: 18037817].
2072 Mallinckrodt CH, Watkin JG, Liu C, et al. Duloxetine in the treatment of Major Depressive Disorder: a comparison of efficacy in patients with and without melancholic features. BMC Psychiatry. Jan. 4. 2005;5(1):1. Source: PubMed. [pmid: 15631624].
2073 Malling D, Poulsen MN, Sogaard B. The effect of cimetidine or omeprazole on the pharmacokinetics of escitalopram in healthy subjects. Br J Clin Pharmacol. Sep. 2005;60(3):287-90. Source: PubMed. [pmid: 16120067].
2074 Malone DC. A budget-impact and cost-effectiveness model for second-line treatment of major depression. J Manag Care Pharm. Jul. 2007;13(6 Suppl A):S8-18. Source: PubMed. [pmid: 17874482].
2075 Malt UF, Robak OH, Madsbu HP, et al. The Norwegian naturalistic treatment study of depression in general practice (NORDEP)-I: randomised double blind study. Bmj. May. 1. 1999;318(7192):1180-4. Source: PubMed. [pmid: 10221945].
2076 Malvini L, Cipriani A, Furukawa TA, et al. Sertraline versus other antidepressive agents for depression. (Protocol). Cochrane Database of Systematic Reviews. 2006;(3). Source: Scopus.
2077 Mamo DC, Pollock BG, Mulsant B, et al. Effects of nortriptyline and paroxetine on postural sway in depressed elderly patients. Am J Geriatr Psychiatry. Mar-Apr. 2002;10(2):199-205. Source: PubMed. [pmid: 11925281].
2078 Mamo DC, Sweet RA, Mulsant BH, et al. Effect of nortriptyline and paroxetine on extrapyramidal signs and symptoms: A prospective double-blind study in depressed elderly patients. Am J Geriatr Psychiatry. Summer. 2000;8(3):226-31. Source: PubMed. [pmid: 10910421].
2079 Manber R, Arnow B, Blasey C, et al. Patient's therapeutic skill acquisition and response to psychotherapy, alone or in combination with medication. Psychol Med. May. 2003;33(4):693-702. Source: PubMed. [pmid: 12785471].
2080 Manber R, Edinger JD, Gress JL, et al. Cognitive behavioral therapy for insomnia enhances depression outcome in patients with comorbid major depressive disorder and insomnia. Sleep. Apr. 1. 2008;31(4):489-95. Source: PubMed. [pmid: 18457236].
2081 Manber R, Kraemer HC, Arnow BA, et al. Faster remission of chronic depression with combined psychotherapy and medication than with each therapy alone. J Consult Clin Psychol. Jun. 2008;76(3):459-67. Source: PubMed. [pmid: 18540739].
2082 Manber R, Rush AJ, Thase ME, et al. The effects of psychotherapy, nefazodone, and their combination on subjective assessment of disturbed sleep in chronic depression. Sleep. Mar. 15. 2003;26(2):130-6. Source: PubMed. [pmid: 12683470].
2083 Manberg PJ, Carter RG. Bupropion in the treatment of psychotic depression: two case reports. J Clin Psychiatry. May. 1984;45(5):230-1. Source: PubMed. [pmid: 6427198].
2084 Mandelli L, Serretti A, Zanardi R, et al. Antidepressant response in the elderly. Psychiatry Res. Jul. 30. 2007;152(1):37-44. Source: PubMed. [pmid: 17383015].
2085 Maneeton N, Thongkam A, Maneeton B. Cognitive-behavioral therapy added to fluoxetine in major depressive disorder after 4 weeks of fluoxetine-treatment: 16-week open label study. J Med Assoc Thai. Mar. 2010;93(3):337-42. Source: PubMed. [pmid: 20420109].
2086 Manfredi G, Lazanio S, Kotzalidis GD, et al. Postpartum depression without delivering a child?. Acta Psychiatr Scand. Sep. 2005;112(3):233-6. discussion 6-7. Source: PubMed. [pmid: 16095479].
2087 Mann JJ, Georgotas A, Newton R, et al. A controlled study of trazodone, imipramine, and placebo in outpatients with endogenous depression. J Clin Psychopharmacol. Mar. 1981;1(2):75-80. Source: PubMed. [pmid: 7028798].
2088 Manna V, Martucci N, Agnoli A. Double-blind controlled study on the clinical efficacy and safety of fluoxetine vs clomipramine in the treatment of major depressive disorders. Int Clin Psychopharmacol. Jan. Suppl 1. 1989;4:81-8. Source: PubMed. [pmid: 2644342].
2089 Mannheimer B, Wettermark B, Lundberg M, et al. Nationwide drug-dispensing data reveal important differences in adherence to drug label recommendations on CYP2D6-dependent drug interactions. Br J Clin Pharmacol. Apr. 2010;69(4):411-7. Source: PubMed. [pmid: 20406225].
2090 Manning JS, Haykal RF, Connor PD, et al. Sustained remission with lamotrigine augmentation or monotherapy in female resistant depressives with mixed cyclothymic-dysthymic temperament. Journal of Affective Disorders. 2005;84(2-3):259-66. Source: Scopus. [pmid: 15708424].
2091 Mao PX, Tang YL, Jiang F, et al. Escitalopram in major depressive disorder: a multicenter, randomized, double-blind, fixed-dose, parallel trial in a Chinese population. Depress Anxiety. 2008;25(1):46-54. Source: PubMed. [pmid: 17149753].
2092 Marangell LB, Clauw DJ, Choy E, et al. Comparative pain and mood effects in patients with comorbid fibromyalgia and major depressive disorder: Secondary analyses of four pooled randomized controlled trials of duloxetine. Pain. 2011;152(1):31-7. Source: EMBASE. [pmid: 20598442].
2093 Marazziti D, Dell'Osso L, Rossi A, et al. Decreased platelet [3H]paroxetine binding sites in suicide attempters. Psychiatry Res. Sep. 20. 2001;103(2-3):125-31. Source: PubMed. [pmid: 11549401].
2094 March JS. Review of ‘Let Them Eat Prozac: The Unhealthy Relationship Between the Pharmaceutical Industry and Depression’. Journal of the American Academy of Child & Adolescent Psychiatry. Sep. 2005. 2005;44(9):955-8. Source: PsycINFO.
2095 March JS, Klee BJ, Kremer CME. Treatment benefit and the risk of suicidality in multicenter, randomized, controlled trials of sertraline in children and adolescents. Journal of Child and Adolescent Psychopharmacology. 2006;16(1-2):91-102. Source: Scopus. [pmid: 16553531].
2096 March JS, Kobak KA, Jefferson JW, et al. A double-blind, placebo-controlled trial of fluvoxamine versus imipramine in outpatients with major depression. J Clin Psychiatry. May. 1990;51(5):200-2. Source: PubMed. [pmid: 2110560].
2097 March JS, Team T, Silva S, et al. The Treatment for Adolescents with Depression Study (TADS) - Long-term effectiveness and safety outcomes. Archives of General Psychiatry (USA). 10. 01. 2007;64(Oct):1132-44. Source: PsycINFO.
2098 Marchesi C, Ceccherininelli A, Rossi A, et al. Is anxious-agitated major depression responsive to fluoxetine? A double-blind comparison with amitriptyline. Pharmacopsychiatry. Nov. 1998;31(6):216-21. Source: PubMed. [pmid: 9930635].
2099 Marcinko D. Antidepressants and suicidality: the basis of controversies. Psychiatr Danub. Sep. 2007;19(3):238-40. Source: PubMed. [pmid: 17914327].
2100 Marcus RN, McQuade RD, Carson WH, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder: a second multicenter, randomized, double-blind, placebo-controlled study. J Clin Psychopharmacol. Apr. 2008;28(2):156-65. Source: PubMed. [pmid: 18344725].
2101 Marcus RN, Mendels J. Nefazodone in the treatment of severe, melancholic, and recurrent depression. J Clin Psychiatry. 1996;57(Suppl):219-23. Source: PubMed.
2102 Marcus SC, Olfson M. Psychosocial functioning of medicaid recipients with major depression. [3]. Psychiatric Services. 2006;57(7):1046-7. Source: EMBASE. [pmid: 16816296].
2103 Marcus SM, Kerber KB, Rush AJ, et al. Sex differences in depression symptoms in treatment-seeking adults: confirmatory analyses from the Sequenced Treatment Alternatives to Relieve Depression study. Compr Psychiatry. May-Jun. 2008;49(3):238-46. Source: PubMed. [pmid: 18396182].
2104 Marcus SM, Young EA, Kerber KB, et al. Gender differences in depression: findings from the STAR*D study. J Affect Disord. Aug. 2005;87(2-3):141-50. Source: PubMed. [pmid: 15982748].
2105 Margolese HC, Beauclair L, Szkrumelak N, et al. Hypomania induced by adjunctive lamotrigine. Am J Psychiatry. Jan. 2003;160(1):183-4. Source: PubMed. [pmid: 12505823].
2106 Marie-Mitchell A, Leuchter AF, Chou CP, et al. Predictors of improved mood over time in clinical trials for major depression. Psychiatry Res. Jun. 30. 2004;127(1-2):73-84. Source: PubMed. [pmid: 15261707].
2107 Markoula S, Konitsiotis S, Chatzistefanidis D, et al. Akathisia induced by mirtazapine after 20 years of continuous treatment. Clinical Neuropharmacology. 2010;33(1):50-1. Source: PsycINFO. [pmid: 20124786].
2108 Markovitz JH, Shuster JL, Chitwood WS, et al. Platelet activation in depression and effects of sertraline treatment: An open-label study. Am J Psychiatry. Jun. 2000;157(6):1006-8. Source: PubMed. [pmid: 10831484].
2109 Markowitz JC, Kocsis JH, Bleiberg KL, et al. A comparative trial of psychotherapy and pharmacotherapy for “pure” dysthymic patients. J Affect Disord. Dec. 2005;89(1-3):167-75. Source: PubMed. [pmid: 16263177].
2110 Marsland TW, Newton W. Are there differences by gender in response to pharmacotherapy for depression?. J Fam Pract. Dec. 2000;49(12):1149. Source: PubMed. [pmid: 11132066].
2111 Martenyi F, Dossenbach M, Mraz K, et al. Gender differences in the efficacy of fluoxetine and maprotiline in depressed patients: a double-blind trial of antidepressants with serotonergic or norepinephrinergic reuptake inhibition profile. Eur Neuropsychopharmacol. Jun. 2001;11(3):227-32. Source: PubMed. [pmid: 11418283].
2112 Martin BK, Frangakis CE, Rosenberg PB, et al. Design of Depression in Alzheimer's Disease Study-2. Am J Geriatr Psychiatry. Nov. 2006;14(11):920-30. Source: PubMed. [pmid: 17068314].
2113 Martin SD, Martin E, Rai SS, et al. Brain blood flow changes in depressed patients treated with interpersonal psychotherapy or venlafaxine hydrochloride: preliminary findings. Arch Gen Psychiatry. Jul. 2001;58(7):641-8. Source: PubMed. [pmid: 11448369].
2114 Martinez C, Assimes TL, Mines D, et al. Use of venlafaxine compared with other antidepressants and the risk of sudden cardiac death or near death: a nested case-control study. Bmj. 340:c249. Source: PubMed.
2115 Martinez C, Rietbrock S, Wise L, et al. Antidepressant treatment and the risk of fatal and non-fatal self harm in first episode depression: nested case-control study. Bmj. Feb. 19. 2005;330(7488):389. Source: PubMed. [pmid: 15718538].
2116 Martinez JM, Kent JM, Coplan JD, et al. Respiratory variability in panic disorder. Depression & Anxiety. 2001;14(4):232-7. Source: EMBASE. [pmid: 11754131].
2117 Martin-Merino E, Ruigomez A, Garcia Rodriguez LA, et al. Depression and treatment with antidepressants are associated with the development of gastro-oesophageal reflux disease. Alimentary Pharmacology and Therapeutics. 2010;31(10):1132-40. Source: EMBASE. [pmid: 20199498].
2118 Martiny K. Adjunctive bright light in non-seasonal major depression. Acta Psychiatr Scand Suppl. 2004;(425):7-28. Source: PubMed. [pmid: 15527426].
2119 Martiny K, Lunde M, Simonsen C, et al. Relapse prevention by citalopram in SAD patients responding to 1 week of light therapy. A placebo-controlled study. Acta Psychiatr Scand. Mar. 2004;109(3):230-4. Source: PubMed. [pmid: 14984396].
2120 Martiny K, Lunde M, Unden M, et al. Adjunctive bright light in non-seasonal major depression: results from clinician-rated depression scales. Acta Psychiatr Scand. Aug. 2005;112(2):117-25. Source: PubMed. [pmid: 15992393].
2121 Martiny K, Lunde M, Unden M, et al. Adjunctive bright light in non-seasonal major depression: results from patient-reported symptom and well-being scales. Acta Psychiatr Scand. Jun. 2005;111(6):453-9. Source: PubMed. [pmid: 15877712].
2122 Martiny K, Lunde M, Unden M, et al. The lack of sustained effect of bright light, after discontinuation, in non-seasonal major depression. Psychol Med. Sep. 2006;36(9):1247-52. Source: PubMed. [pmid: 16756691].
2123 Martire LM, Schulz R, Reynolds Iii CF, et al. Treatment of late-life depression alleviates caregiver burden. Journal of the American Geriatrics Society. 2010;58(1):23-9. Source: EMBASE. [pmid: 19943833].
2124 Marttila M, Jaaskelainen J, Jarvi R, et al. A double-blind study comparing the efficacy and tolerability of mirtazapine and doxepin in patients with major depression. Eur Neuropsychopharmacol. Dec. 1995;5(4):441-6. Source: PubMed. [pmid: 8998395].
2125 Masand P, Gupta S, Dewan M. Suicidal ideation related to fluoxetine treatment. N Engl J Med. Feb. 7. 1991;324(6):420. Source: PubMed. [pmid: 1987466].
2126 Masand P, Stern TA. Bupropion and secondary mania. Is there a relationship?. Ann Clin Psychiatry. Dec. 1993;5(4):271-4. Source: PubMed. [pmid: 8312984].
2127 Maschi S, Clavenna A, Campi R, et al. Neonatal outcome following pregnancy exposure to antidepressants: A prospective controlled cohort study. BJOG: An International Journal of Obstetrics and Gynaecology. 2008;115(2):283-9. Source: Handsearch. [pmid: 17903222].
2128 Masdrakis VG, Oulis P, Florakis A, et al. The safety of the electroconvulsive therapy-escitalopram combination. J Ect. Dec. 2008;24(4):289-91. Source: PubMed. [pmid: 18617866].
2129 Mashiko H, Niwa S, Kumashiro H, et al. Effect of trazodone in a single dose before bedtime for sleep disorders accompanied by a depressive state: dose-finding study with no concomitant use of hypnotic agent. Psychiatry Clin Neurosci. Apr. 1999;53(2):193-4. Source: PubMed. [pmid: 10459686].
2130 Masi G, Liboni F, Brovedani P. Pharmacotherapy of major depressive disorder in adolescents. Expert Opin Pharmacother. Feb. 2010;11(3):375-86. Source: PubMed. [pmid: 20102303].
2131 Maskall DD, Lam RW. Increased plasma concentration of imipramine following augmentation with fluvoxamine. Am J Psychiatry. Oct. 1993;150(10):1566. Source: PubMed. [pmid: 8379574].
2132 Mason PJ, Morris VA, Balcezak TJ. Serotonin syndrome Presentation of 2 cases and review of the literature. Medicine (Baltimore). Jul. 2000;79(4):201-9. Source: PubMed. [pmid: 10941349].
2133 Massana J, Moller HJ, Burrows GD, et al. Reboxetine: a double-blind comparison with fluoxetine in major depressive disorder. Int Clin Psychopharmacol. Mar. 1999;14(2):73-80. Source: PubMed. [pmid: 10220121].
2134 Mathew SJ, Murrough JW, Aan Het, Rot M, et al. Riluzole for relapse prevention following intravenous ketamine in treatment-resistant depression: A pilot randomized, placebo-controlled continuation trial. International Journal of Neuropsychopharmacology. 2010;13(1):71-82. Source: EMBASE. [pmid: 19288975].
2135 Mathews J, Garcia KS, Mintun MA, et al. Antidepressant efficacy of olanzapine as monotherapy in major depressive disorder, without psychosis: A pilot study. Psychiatry Research Neuroimaging. 2006;146(2):149-55. Source: EMBASE.
2136 Matreja PS, Badyal DK, Khosla P, et al. Effectiveness and acceptability of sertraline and citalopram in major depressive disorder: pragmatic randomized open-label comparison. Hum Psychopharmacol. 2007;22(7):477-82. Source: PubMed. [pmid: 17647298].
2137 Matrisciano F, Bonaccorso S, Ricciardi A, et al. Changes in BDNF serum levels in patients with major depression disorder (MDD) after 6 months treatment with sertraline, escitalopram, or venlafaxine. J Psychiatr Res. Jan. 2009;43(3):247-54. Source: PubMed. [pmid: 18511076].
2138 Matthews JD, Bottonari KA, Polania LM, et al. An open study of olanzapine and fluoxetine for psychotic major depressive disorder: interim analyses. J Clin Psychiatry. Dec. 2002;63(12):1164-70. Source: PubMed. [pmid: 12523877].
2139 Matthews JD, Siefert C, Dording C, et al. An open study of aripiprazole and escitalopram for psychotic major depressive disorder. J Clin Psychopharmacol. Feb. 2009;29(1):73-6. Source: PubMed. [pmid: 19142112].
2140 Mattila MJ, Saarialho-Kere U, Mattila M. Acute effects of sertraline, amitriptyline, and placebo on the psychomotor performance of healthy subjects over 50 years of age. J Clin Psychiatry. Aug. 1988;49(Suppl):52-8. Source: PubMed. [pmid: 3045113].
2141 Matuzany-Ruban A, Schreiber G, Farkash P, et al. Phosducin-like protein levels in leukocytes of patients with major depression and in rat cortex: The effect of chronic treatment with antidepressants. Psychiatry Research. 2006;141(3):287-94. Source: EMBASE. [pmid: 16510194].
2142 Mauri MC, Fiorentini A, Cerveri G, et al. Long-term efficacy and therapeutic drug monitoring of sertraline in major depression. Hum Psychopharmacol. Jul. 2003;18(5):385-8. Source: PubMed. [pmid: 12858326].
2143 Mayberg HS, Silva JA, Brannan SK, et al. The functional neuroanatomy of the placebo effect. Am J Psychiatry. May. 2002;159(5):728-37. Source: PubMed. [pmid: 11986125].
2144 Mayer LS, Bay RC, Politis A, et al. Comparison of three rating scales as outcome measures for treatment trials of depression in Alzheimer disease: findings from DIADS. Int J Geriatr Psychiatry. Oct. 2006;21(10):930-6. Source: PubMed. [pmid: 16955427].
2145 Mazeh D, Shahal B, Saraf R, et al. Venlafaxine for the treatment of depressive episode during the course of schizophrenia. J Clin Psychopharmacol. Dec. 2004;24(6):653-5. Source: PubMed. [pmid: 15538129].
2146 Mbaya P, Alam F, Ashim S, et al. Cardiovascular effects of high dose venlafaxine XL in patients with major depressive disorder. Hum Psychopharmacol. Apr. 2007;22(3):129-33. Source: PubMed. [pmid: 17397100].
2147 McAlpine DE, O'Kane DJ, Black JL, et al. Cytochrome P450 2D6 genotype variation and venlafaxine dosage. Mayo Clin Proc. Sep. 2007;82(9):1065-8. Source: PubMed. [pmid: 17803873].
2148 McBride C, Segal Z, Kennedy S, et al. Changes in autobiographical memory specificity following cognitive behavior therapy and pharmacotherapy for major depression. Psychopathology. 2007;40(3):147-52. Source: EMBASE. [pmid: 17318006].
2149 McCabe C, Mishor Z, Cowen PJ, et al. Diminished neural processing of aversive and rewarding stimuli during selective serotonin reuptake inhibitor treatment. Biol Psychiatry. Mar. 1. 2010;67(5):439-45. Source: PubMed. [pmid: 20034615].
2150 McCall WV, Blocker JN, D'Agostino R Jr, et al. Treatment of insomnia in depressed insomniacs: Effects on health-related quality of life, objective and self-reported sleep, and depression. Journal of Clinical Sleep Medicine. 2010;6(4):322-9. Source: EMBASE. [pmid: 20726279].
2151 McCall WV, Blocker JN, D'Agostino R Jr, et al. Insomnia severity is an indicator of suicidal ideation during a depression clinical trial. Sleep Med. Oct. 2010;11(9):822-7. Source: PubMed. [pmid: 20478741].
2152 McCombs JS, Shi L, Stimmel GL, et al. A retrospective analysis of the revocation of prior authorization restrictions and the use of antidepressant medications for treating major depressive disorder. Clin Ther. Nov. 2002;24(11):1939-59. discussion 8. Source: PubMed. [pmid: 12501884].
2153 McCue RE, Joseph M. Venlafaxine- and trazodone-induced serotonin syndrome. Am J Psychiatry. Dec. 2001;158(12):2088-9. Source: PubMed. [pmid: 11729039].
2154 McDougle CJ, Goodman WK, Leckman JF, et al. The efficacy of fluvoxamine in obsessive-compulsive disorder: effects of comorbid chronic tic disorder. J Clin Psychopharmacol. Oct. 1993;13(5):354-8. Source: PubMed. [pmid: 8227493].
2155 McDougle CJ, Goodman WK, Leckman JF, et al. Limited therapeutic effect of addition of buspirone in fluvoxamine-refractory obsessive-compulsive disorder. Am J Psychiatry. Apr. 1993;150(4):647-9. Source: PubMed. [pmid: 8465885].
2156 McDowell DM, Levin FR, Seracini AM, et al. Venlafaxine treatment of cocaine abusers with depressive disorders. Am J Drug Alcohol Abuse. Feb. 2000;26(1):25-31. Source: PubMed. [pmid: 10718161].
2157 McElroy SL, Hudson JI, Malhotra S, et al. Citalopram in the treatment of binge-eating disorder: a placebo-controlled trial. J Clin Psychiatry. Jul. 2003;64(7):807-13. Source: PubMed. [pmid: 12934982].
2158 McElroy SL, Martens BE, Creech RS, et al. Randomized, double-blind, placebo-controlled study of divalproex extended release loading monotherapy in ambulatory bipolar spectrum disorder patients with moderate-to-severe hypomania or mild mania. Journal of Clinical Psychiatry. 2010;71(5):557-65. Source: EMBASE. [pmid: 20361901].
2159 McElroy SL, Weisler RH, Chang W, et al. A Double-Blind, Placebo-Controlled Study of Quetiapine and Paroxetine as Monotherapy in Adults with Bipolar Depression (EMBOLDEN II). Journal of Clinical Psychiatry. 2010;71(2):163-74. Source: EMBASE. [pmid: 20122366].
2160 McEwen BS, Olié JP. Neurobiology of mood, anxiety, and emotions as revealed by studies of a unique antidepressant: Tianeptine. Molecular Psychiatry. Jun. 2005. 2005;10(6):525-37. Source: PsycINFO. [pmid: 15753957].
2161 McFall M, Saxon AJ, Malte CA, et al. Integrating tobacco cessation into mental health care for posttraumatic stress disorder a randomized controlled trial. JAMA - Journal of the American Medical Association. 2010;304(22):2485-93. Source: EMBASE.
2162 McFarlane A, Kamath MV, Fallen EL, et al. Effect of sertraline on the recovery rate of cardiac autonomic function in depressed patients after acute myocardial infarction. Am Heart J. Oct. 2001;142(4):617-23. Source: PubMed. [pmid: 11579351].
2163 McGrath PJ, Khan AY, Trivedi MH, et al. Response to a selective serotonin reuptake inhibitor (citalopram) in major depressive disorder with melancholic features: a STAR*D report. J Clin Psychiatry. Dec. 2008;69(12):1847-55. Source: PubMed. [pmid: 19026268].
2164 McGrath PJ, Stewart JW, Fava M, et al. Tranylcypromine versus venlafaxine plus mirtazapine following three failed antidepressant medication trials for depression: a STAR*D report. Am J Psychiatry. 2006;163(9):1531-41. quiz 666. Source: PubMed. [pmid: 16946177].
2165 McGrath PJ, Stewart JW, Janal MN, et al. A placebo-controlled study of fluoxetine versus imipramine in the acute treatment of atypical depression. Am J Psychiatry. Mar. 2000;157(3):344-50. Source: PubMed. [pmid: 10698808].
2166 McGrath PJ, Stewart JW, Petkova E, et al. Predictors of relapse during fluoxetine continuation or maintenance treatment of major depression. J Clin Psychiatry. Jul. 2000;61(7):518-24. Source: PubMed. [pmid: 10937611].
2167 McGrath PJ, Stewart JW, Quitkin FM, et al. Predictors of relapse in a prospective study of fluoxetine treatment of major depression. Am J Psychiatry. 2006;163(9):1542-8. Source: PubMed. [pmid: 16946178].
2168 McIntosh D. A mild case of serotonin syndrome?. Can J Psychiatry. Aug. 2000;45(6):571-2. Source: PubMed. [pmid: 10986578].
2169 McIntyre A, Gendron A. Quetiapine adjunct to selective serotonin reuptake inhibitors or venlafaxine in patients with major depression, comorbid anxiety, and residual depressive symptoms: a randomized, placebo-controlled pilot study. Depress Anxiety. 2007;24(7):487-94. Source: PubMed. [pmid: 17177199].
2170 McIntyre RS, Konarski JZ, Mancini DA, et al. Improving outcomes in depression: A focus on somatic symptoms. Journal of Psychosomatic Research. 2006;60(3):279-82. Source: EMBASE. [pmid: 16516660].
2171 McIntyre RS, Mancini DA, McCann S, et al. Topiramate versus bupropion SR when added to mood stabilizer therapy for the depressive phase of bipolar disorder: a preliminary single-blind study. Bipolar Disord. Jun. 2002;4(3):207-13. Source: PubMed. [pmid: 12180276].
2172 McKay MS, Zakzanis KK. The impact of treatment on HPA axis activity in unipolar major depression. Journal of psychiatric research. 2010;44(3):183-92. Source: EMBASE. [pmid: 19747693].
2173 McKinnon MC, Cusi AM, MacQueen GM. Impaired theory of mind performance in patients with recurrent bipolar disorder: Moderating effect of cognitive load. Psychiatry Research. 2010;177(1-2):261-2. Source: EMBASE. [pmid: 20223523].
2174 McLeod MN, Gaynes BN, Golden RN. Chromium potentiation of antidepressant pharmacotherapy for dysthymic disorder in 5 patients. J Clin Psychiatry. Apr. 1999;60(4):237-40. Source: PubMed. [pmid: 10221284].
2175 McMahon FJ, Buervenich S, Charney D, et al. Variation in the gene encoding the serotonin 2A receptor is associated with outcome of antidepressant treatment. Am J Hum Genet. May. 2006;78(5):804-14. Source: PubMed. [pmid: 16642436].
2176 McPartlin GM, Reynolds A, Anderson C, et al. A comparison of once-daily venlafaxine XR and paroxetine in depressed outpatients treated in general practice. Primary Care Psychiatry. 1998. 1998;4(3):127-32. Source: Handsearch.
2177 Meertens JH, Monteban-Kooistra WE, Ligtenberg JJ, et al. Severe hypoglycemia following venlafaxine intoxication: a case report. J Clin Psychopharmacol. Aug. 2007;27(4):414-5. Source: PubMed. [pmid: 17632237].
2178 Mehtonen OP, Sogaard J, Roponen P, et al. Randomized, double-blind comparison of venlafaxine and sertraline in outpatients with major depressive disorder. Venlafaxine 631 Study Group. J Clin Psychiatry. Feb. 2000;61(2):95-100. Source: PubMed. [pmid: 10732656].
2179 Meijer WE, Heerdink ER, van Eijk JT, et al. Adverse events in users of sertraline: results from an observational study in psychiatric practice in The Netherlands. Pharmacoepidemiol Drug Saf. Dec. 2002;11(8):655-62. Source: PubMed. [pmid: 12512241].
2180 Melartin TK, Rytsälä HJ, Leskelä US, et al. Continuity is the main challenge in treating major depressive disorder in psychiatric care. Journal of Clinical Psychiatry. 2005;66(2):220-7. Source: Scopus. [pmid: 15705008].
2181 Mellerup ET, Bech P, Lauritzen L, et al. Platelet paroxetine binding in alcoholics. Alcohol Alcohol. Nov. 1992;27(6):603-6. Source: PubMed. [pmid: 1292433].
2182 Mellerup ET, Errebo I, Molin J, et al. Platelet paroxetine binding and light therapy in winter depression. J Affect Disord. Sep. 1993;29(1):11-5. Source: PubMed. [pmid: 8254138].
2183 Melton ST, Kirkwood CK, Farrar TW, et al. Economic evaluation of paroxetine and imipramine in depressed outpatients. Psychopharmacol Bull. 1997;33(1):93-100. Source: PubMed. [pmid: 9133757].
2184 Meltzer CC, Price JC, Mathis CA, et al. Serotonin 1A receptor binding and treatment response in late-life depression. Neuropsychopharmacology. Dec. 2004;29(12):2258-65. Source: PubMed. [pmid: 15483563].
2185 Meltzer H, Bastani B, Jayathilake K, et al. Fluoxetine, but not tricyclic antidepressants, potentiates the 5-hydroxytryptophan-mediated increase in plasma cortisol and prolactin secretion in subjects with major depression or with obsessive compulsive disorder. Neuropsychopharmacology. Jul. 1997;17(1):1-11. Source: PubMed. [pmid: 9194044].
2186 Melvin GA, Tonge BJ, King NJ, et al. A Comparison of Cognitive-Behavioral Therapy, Sertraline, and Their Combination for Adolescent Depression. Journal of the American Academy of Child & Adolescent Psychiatry. Oct. 2006. 2006;45(10):1151-61. Source: PsycINFO. [pmid: 17003660].
2187 Mendels J, Amin MM, Chouinard G, et al. A comparative study of bupropion and amitriptyline in depressed outpatients. J Clin Psychiatry. May. 1983;44(5 Pt 2):118-20. Source: PubMed. [pmid: 6406439].
2188 Mendels J, Johnston R, Mattes J, et al. Efficacy and safety of b.i.d. doses of venlafaxine in a dose-response study. Psychopharmacol Bull. 1993;29(2):169-74. Source: PubMed. [pmid: 8290661].
2189 Mendels J, Kiev A, Fabre LF. Double-blind comparison of citalopram and placebo in depressed outpatients with melancholia. Depress Anxiety. 1999;9(2):54-60. Source: PubMed. [pmid: 10207659].
2190 Mendels J, Reimherr F, Marcus RN, et al. A double-blind, placebo-controlled trial of two dose ranges of nefazodone in the treatment of depressed outpatients. J Clin Psychiatry. Suppl 6. 1995;56:30-6. Source: PubMed. [pmid: 7649971].
2191 Mendelson WB. A review of the evidence for the efficacy and safety of trazodone in insomnia. J Clin Psychiatry. Apr. 2005;66(4):469-76. Source: PubMed. [pmid: 15816789].
2192 Mendlewicz J, Kriwin P, Oswald P, et al. Shortened onset of action of antidepressants in major depression using acetylsalicylic acid augmentation: A pilot open-label study. International Clinical Psychopharmacology. 2006;21(4):227-31. Source: EMBASE. [pmid: 16687994].
2193 Menkes DB, Taghavi E, Mason PA, et al. Fluoxetine's spectrum of action in premenstrual syndrome. Int Clin Psychopharmacol. Summer. 1993;8(2):95-102. Source: PubMed. [pmid: 8345163].
2194 Menting JE, Honig A, Verhey FR, et al. Selective serotonin reuptake inhibitors (SSRIs) in the treatment of elderly depressed patients: a qualitative analysis of the literature on their efficacy and side-effects. Int Clin Psychopharmacol. Sep. 1996;11(3):165-75. Source: PubMed. [pmid: 8923095].
2195 Menza M, DeFonzo Dobkin R, Marin H, et al. The impact of treatment of depression on quality of life, disability and relapse in patients with Parkinson's disease. Movement Disorders. 2009;24(9):1325-32. Source: Handsearch. [pmid: 19412944].
2196 Menza M, Dobkin RD, Marin H, et al. A controlled trial of antidepressants in patients with Parkinson disease and depression. Neurology. 2009;72(10):886-92. Source: PubMed. [pmid: 19092112].
2197 Mera MT, Perez BV, Fernandez RO, et al. Hypersensitivity to paroxetine. Allergol Immunopathol (Madr). May-Jun. 2006;34(3):125-6. Source: PubMed. [pmid: 16858890].
2198 Merideth CH, Feighner JP. The use of bupropion in hospitalized depressed patients. J Clin Psychiatry. May. 1983;44(5 Pt 2):85-7. Source: PubMed. [pmid: 6406471].
2199 Merlob P, Stahl B, Sulkes J. Paroxetine during breast-feeding: infant weight gain and maternal adherence to counsel. Eur J Pediatr. Mar. 2004;163(3):135-9. Source: PubMed. [pmid: 14745552].
2200 Mertens C, Pintens H. Paroxetine in the treatment of depression. A double-blind multicenter study versus mianserin. Acta Psychiatr Scand. Jun. 1988;77(6):683-8. Source: PubMed. [pmid: 2970203].
2201 Mertens C, Pintens H. A double-blind, multicentre study of paroxetine and mianserin in depression. Acta Psychiatrica Scandinavica, Supplement. 1989;80(350):140. Source: EMBASE.
2202 Messa C, Colombo C, Moresco RM, et al. 5-HT(2A) receptor binding is reduced in drug-naive and unchanged in SSRI-responder depressed patients compared to healthy controls: a PET study. Psychopharmacology (Berl). Apr. 2003;167(1):72-8. Source: PubMed. [pmid: 12632246].
2203 Mesters P, Cosyns P, Dejaiffe G, et al. Assessment of quality of life in the treatment of major depressive disorder with fluoxetine, 20 mg, in ambulatory patients aged over 60 years. Int Clin Psychopharmacol. Winter. 1993;8(4):337-40. Source: PubMed. [pmid: 8277160].
2204 Meston CM, Rellini AH, Telch MJ. Short- and long-term effects of Ginkgo biloba extract on sexual dysfunction in women. Arch Sex Behav. Aug. 2008;37(4):530-47. Source: PubMed. [pmid: 18274887].
2205 Meyer JH, Wilson AA, Ginovart N, et al. Occupancy of serotonin transporters by paroxetine and citalopram during treatment of depression: a [(11)C]DASB PET imaging study. Am J Psychiatry. Nov. 2001;158(11):1843-9. Source: PubMed. [pmid: 11691690].
2206 Meyers BS, Alpert S, Gabriele M, et al. State specificity of DST abnormalities in geriatric depression. Biol Psychiatry. Jul. 1-15. 1993;34(1-2):108-14. Source: PubMed. [pmid: 8373930].
2207 Meyers BS, English J, Gabriele M, et al. A delusion assessment scale for psychotic major depression: Reliability, validity, and utility. Biol Psychiatry. Dec. 15. 2006;60(12):1336-42. Source: PubMed. [pmid: 17046724].
2208 Meyers BS, Flint AJ, Rothschild AJ, et al. A Double-blind Randomized Controlled Trial of Olanzapine Plus Sertraline vs Olanzapine Plus Placebo for Psychotic Depression. Archives of General Psychiatry (USA). 2009;66:838. Source: Handsearch.
2209 Meyers BS, Flint AJ, Rothschild AJ, et al. A double-blind randomized controlled trial of olanzapine plus sertraline vs olanzapine plus placebo for psychotic depression: the study of pharmacotherapy of psychotic depression (STOP-PD). Arch Gen Psychiatry. 2009;66(8):838-47. Source: PubMed. [pmid: 19652123].
2210 Michael A, Owen A. Venlafaxine-induced increased libido and spontaneous erections. Br J Psychiatry. Feb. 1997;170:193. Source: PubMed. [pmid: 9093519].
2211 Michalak EE, Murray G, Levitt AJ, et al. Quality of life as an outcome indicator in patients with seasonal affective disorder: results from the Can-SAD study. Psychol Med. May. 2007;37(5):727-36. Source: PubMed. [pmid: 17112403].
2212 Michelson D, Adler LA, Amsterdam JD, et al. Addition of atomoxetine for depression incompletely responsive to sertraline: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Apr. 2007;68(4):582-7. Source: PubMed. [pmid: 17474814].
2213 Michelson D, Amsterdam J, Apter J, et al. Hormonal markers of stress response following interruption of selective serotonin reuptake inhibitor treatment. Psychoneuroendocrinology. Feb. 2000;25(2):169-77. Source: PubMed. [pmid: 10674280].
2214 Michelson D, Amsterdam JD, Quitkin FM, et al. Changes in weight during a 1-year trial of fluoxetine. Am J Psychiatry. Aug. 1999;156(8):1170-6. Source: PubMed. [pmid: 10450256].
2215 Michelson D, Bancroft J, Targum S, et al. Female sexual dysfunction associated with antidepressant administration: a randomized, placebo-controlled study of pharmacologic intervention. Am J Psychiatry. Feb. 2000;157(2):239-43. Source: PubMed. [pmid: 10671393].
2216 Michelson D, Schmidt M, Lee J, et al. Changes in sexual function during acute and six-month fluoxetine therapy: a prospective assessment. J Sex Marital Ther. May-Jun. 2001;27(3):289-302. Source: PubMed. [pmid: 11354934].
2217 Miehle K, Paschke R, Koch CA. Citalopram therapy as a risk factor for symptomatic hyponatremia caused by the syndrome of inappropriate secretion of antidiuretic hormone (SIADH): a case report. Pharmacopsychiatry. Jul. 2005;38(4):181-2. Source: PubMed. [pmid: 16025423].
2218 Mihaljevic Peles A, Bozina N, Sagud M, et al. MDR1 gene polymorphism: therapeutic response to paroxetine among patients with major depression. Prog Neuropsychopharmacol Biol Psychiatry. Aug. 1. 2008;32(6):1439-44. Source: PubMed. [pmid: 18550244].
2219 Mihara K, Otani K, Ishida M, et al. Increases in plasma concentration of m-chlorophenylpiperazine, but not trazodone, with low-dose haloperidol. Ther Drug Monit. Feb. 1997;19(1):43-5. Source: PubMed. [pmid: 9029745].
2220 Mihara K, Otani K, Suzuki A, et al. Relationship between the CYP2D6 genotype and the steady-state plasma concentrations of trazodone and its active metabolite m-chlorophenylpiperazine. Psychopharmacology (Berl). Sep. 1997;133(1):95-8. Source: PubMed. [pmid: 9335086].
2221 Mihara K, Otani K, Tybring G, et al. The CYP2D6 genotype and plasma concentrations of mianserin enantiomers in relation to therapeutic response to mianserin in depressed Japanese patients. J Clin Psychopharmacol. Dec. 1997;17(6):467-71. Source: PubMed. [pmid: 9408809].
2222 Milak MS, Parsey RV, Lee L, et al. Pretreatment regional brain glucose uptake in the midbrain on PET may predict remission from a major depressive episode after three months of treatment. Psychiatry Res. 2009;173(1):63-70. Source: PubMed. [pmid: 19446443].
2223 Miljkovic BR, Pokrajac M, Timotijevic I, et al. The influence of lithium on fluvoxamine therapeutic efficacy and pharmacokinetics in depressed patients on combined fluvoxamine-lithium therapy. Int Clin Psychopharmacol. Jul. 1997;12(4):207-12. Source: PubMed. [pmid: 9347381].
2224 Miller FT, Freilicher J. Comparison of TCAs and SSRIs in the treatment of major depression in hospitalized geriatric patients. J Geriatr Psychiatry Neurol. Jul. 1995;8(3):173-6. Source: PubMed. [pmid: 7576042].
2225 Miller IW, Keitner GI, Schatzberg AF, et al. The treatment of chronic depression, part 3: psychosocial functioning before and after treatment with sertraline or imipramine. J Clin Psychiatry. Nov. 1998;59(11):608-19. Source: PubMed. [pmid: 9862607].
2226 Miller LG, Bowman RC, Mann D, et al. A case of fluoxetine-induced serum sickness. Am J Psychiatry. Dec. 1989;146(12):1616-7. Source: PubMed. [pmid: 2589557].
2227 Miller LG, Hays RD. Adherence to combination antiretroviral therapy: synthesis of the literature and clinical implications. AIDS Read. Mar. 2000;10(3):177-85. Source: PubMed. [pmid: 10758022].
2228 Miller SM, Naylor GJ, Murtagh M, et al. A double-blind comparison of paroxetine and placebo in the treatment of depressed patients in a psychiatric outpatient clinic. Acta Psychiatr Scand Suppl. 1989;350:143-4. Source: PubMed. [pmid: 2530772].
2229 Miner CM, Brown EB, Gonzales JS, et al. Switching patients from daily citalopram, paroxetine, or sertraline to once-weekly fluoxetine in the maintenance of response for depression. J Clin Psychiatry. 2002;63(3):232-40. Source: PubMed. [pmid: 11926723].
2230 Miniati M, Rucci P, Benvenuti A, et al. Clinical characteristics and treatment outcome of depression in patients with and without a history of emotional and physical abuse. Journal of psychiatric research. 2010;44(5):302-9. Source: EMBASE. [pmid: 19800634].
2231 Miniati M, Rucci P, Frank E, et al. Sensitivity to change and predictive validity of the MOODS-SR questionnaire, last-month version. Psychother Psychosom. 2009;78(2):116-24. Source: PubMed. [pmid: 19218830].
2232 Miranda J, Green BL, Krupnick JL, et al. One-year outcomes of a randomized clinical trial treating depression in low-income minority women. J Consult Clin Psychol. Feb. 2006;74(1):99-111. Source: PubMed. [pmid: 16551147].
2233 Mirassou MM. Rectal antidepressant medication in the treatment of depression. J Clin Psychiatry. Jan. 1998;59(1):29. Source: PubMed. [pmid: 9491063].
2234 Mischoulon D, Opitz G, Kelly K, et al. A preliminary open study of the tolerability and effectiveness of nefazodone in major depressive disorder: comparing patients who recently discontinued an SSRI with those on no recent antidepressant treatment. Depress Anxiety. 2004;19(1):43-50. Source: PubMed. [pmid: 14978785].
2235 Miser WF. Exercise as an effective treatment option for major depression in older adults. J Fam Pract. Feb. 2000;49(2):109-10. Source: PubMed. [pmid: 10718684].
2236 Miskowiak KW, Favaron E, Hafizi S, et al. Erythropoietin modulates neural and cognitive processing of emotional information in biomarker models of antidepressant drug action in depressed patients. Psychopharmacology. 2010;210(3):419-28. Source: EMBASE. [pmid: 20401747].
2237 Misri S, Kendrick K, Oberlander TF, et al. Antenatal depression and anxiety affect postpartum parenting stress: a longitudinal, prospective study. Can J Psychiatry. Apr. 2010;55(4):222-8. Source: PubMed. [pmid: 20416145].
2238 Misri S, Reebye P, Corral M, et al. The use of paroxetine and cognitive-behavioral therapy in postpartum depression and anxiety: a randomized controlled trial. J Clin Psychiatry. Sep. 2004;65(9):1236-41. Source: PubMed. [pmid: 15367052].
2239 Mitchell AJ, Subramaniam H. Prognosis of depression in old age compared to middle age: a systematic review of comparative studies. Am J Psychiatry. Sep. 2005;162(9):1588-601. Source: PubMed. [pmid: 16135616].
2240 Mitchell PB, Schweitzer I, Burrows G, et al. Efficacy of venlafaxine and predictors of response in a prospective open-label study of patients with treatment-resistant major depression. J Clin Psychopharmacol. Aug. 2000;20(4):483-7. Source: PubMed. [pmid: 10917411].
2241 Mittmann N, Herrmann N, Einarson TR, et al. The efficacy, safety and tolerability of antidepressants in late life depression: a meta-analysis. J Affect Disord. Dec. 1997;46(3):191-217. Source: PubMed. [pmid: 9547117].
2242 Miyashita M, Sasayama D, Sugiyama N, et al. Psychotic symptoms complicate the clinical differentiation of Parkinson's disease with major depressive disorder from dementia with Lewy bodies. Psychogeriatrics. 2010;10(2):107-11. Source: EMBASE. [pmid: 20738816].
2243 Mizoguchi Y, Monji A. Low-dose-trazodone-induced disorganized type psychosis. J Neuropsychiatry Clin Neurosci. Spring. 2005;17(2):253-4. Source: PubMed. [pmid: 15939985].
2244 Moak DH, Anton RF, Latham PK, et al. Sertraline and cognitive behavioral therapy for depressed alcoholics: results of a placebo-controlled trial. J Clin Psychopharmacol. Dec. 2003;23(6):553-62. Source: PubMed. [pmid: 14624185].
2245 Modell JG, Katholi CR, Modell JD, et al. Comparative sexual side effects of bupropion, fluoxetine, paroxetine, and sertraline. Clin Pharmacol Ther. Apr. 1997;61(4):476-87. Source: PubMed. [pmid: 9129565].
2246 Modell JG, Rosenthal NE, Harriett AE, et al. Seasonal affective disorder and its prevention by anticipatory treatment with bupropion XL. Biol Psychiatry. Oct. 15. 2005;58(8):658-67. Source: PubMed. [pmid: 16271314].
2247 Moeller O, Hetzel G, Michael N, et al. Basal prolactin values correlate with response to reboxetine treatment in major depression, but not with response to citalopram. Neuropsychobiology. 2005;51(2):67-71. Source: PubMed. [pmid: 15741746].
2248 Mohamed S, Osatuke K, Aslam M, et al. Escitalopram for comorbid depression and anxiety in elderly patients: A 12-week, open-label, flexible-dose, pilot trial. Am J Geriatr Pharmacother. Sep. 2006;4(3):201-9. Source: PubMed. [pmid: 17062320].
2249 Mohan CG, Moore JJ. Fluoxetine toxicity in a preterm infant. J Perinatol. Oct-Nov. 2000;20(7):445-6. Source: PubMed. [pmid: 11076330].
2250 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999. Nov. 27. 1999;354(9193):1896-900. Source: Handsearch. [pmid: 10584742].
2251 Mohr DC, Epstein L, Luks TL, et al. Brain lesion volume and neuropsychological function predict efficacy of treatment for depression in multiple sclerosis. J Consult Clin Psychol. Dec. 2003;71(6):1017-24. Source: PubMed. [pmid: 14622077].
2252 Mohr DC, Hart SL, Fonareva I, et al. Treatment of depression for patients with multiple sclerosis in neurology clinics. Multiple Sclerosis. 2006;12(2):204-8. Source: EMBASE. [pmid: 16629424].
2253 Mohr DC, Hart SL, Goldberg A. Effects of treatment for depression on fatigue in multiple sclerosis. Psychosom Med. 2003;65(4):542-7. Source: EMBASE. [pmid: 12883103].
2254 Möller HJ. Is there evidence for negative effects of antidepressants on suicidality in depressive patients? A systematic review. European Archives of Psychiatry and Clinical Neuroscience. 2006;256(8):476-96. Source: Scopus. [pmid: 17143567].
2255 Moller HJ, Fuger J, Kasper S. Efficacy of new generation antidepressants: meta-analysis of imipramine-controlled studies. Pharmacopsychiatry. Nov. 1994;27(6):215-23. Source: PubMed. [pmid: 7870742].
2256 Moller HJ, Gallinat J, Hegerl U, et al. Double-blind, multicenter comparative study of sertraline and amitriptyline in hospitalized patients with major depression. Pharmacopsychiatry. Sep. 1998;31(5):170-7. Source: PubMed. [pmid: 9832348].
2257 Moller HJ, Glaser K, Leverkus F, et al. Double-blind, multicenter comparative study of sertraline versus amitriptyline in outpatients with major depression. Pharmacopsychiatry. Nov. 2000;33(6):206-12. Source: PubMed. [pmid: 11147927].
2258 Moller HJ, Kasper S, Muller H, et al. A controlled study of the efficacy and safety of mianserin and amitriptyline in depressive inpatients. Pharmacopsychiatry. Nov. 1995;28(6):249-52. Source: PubMed. [pmid: 8773291].
2259 Moller HJ, Schnitker J, Flurenbrock W. Factors associated with response in depressed elderly outpatients treated with escitalopram in a naturalistic setting in Germany. Pharmacopsychiatry. 2010;43(6):210-5. Source: EMBASE. [pmid: 20589597].
2260 Moller HJ, Steinmeyer EM. Are serotonergic reuptake inhibitors more potent in reducing suicidality? An empirical study on paroxetine. Eur Neuropsychopharmacol. Mar. 1994;4(1):55-9. Source: PubMed. [pmid: 8204997].
2261 Moller SE, Bech P, Bjerrum H, et al. Plasma ratio tryptophan/neutral amino acids in relation to clinical response to paroxetine and clomipramine in patients with major depression. J Affect Disord. Jan. 1990;18(1):59-66. Source: PubMed. [pmid: 2136870].
2262 Moller SE, de Beurs P, Timmerman L, et al. Plasma tryptophan and tyrosine ratios to competing amino acids in relation to antidepressant response to citalopram and maprotiline. A preliminary study. Psychopharmacology (Berl). 1986;88(1):96-100. Source: PubMed. [pmid: 3080781].
2263 Moncrieff J, Kirsch I. Efficacy of antidepressants in adults. British Medical Journal. 2005;331(7509):155-7. Source: Scopus. [pmid: 16020858].
2264 Monte S, Macchia A, Romero M, et al. Antidepressants and cardiovascular outcomes in patients without known cardiovascular risk. Eur J Clin Pharmacol. 2009;65(11):1131-8. Source: PubMed. [pmid: 19597805].
2265 Montejo AL, Llorca G, Izquierdo JA, et al. Incidence of sexual dysfunction associated with antidepressant agents: a prospective multicenter study of 1022 outpatients. Spanish Working Group for the Study of Psychotropic-Related Sexual Dysfunction. J Clin Psychiatry. Suppl 3. 2001;62:10-21. Source: PubMed. [pmid: 11229449].
2266 Montejo AL, Prieto N, Terleira A, et al. Better sexual acceptability of agomelatine (25 and 50 mg) compared with paroxetine (20 mg) in healthy male volunteers. An 8-week, placebo-controlled study using the PRSEXDQ-SALSEX scale. Journal of Psychopharmacology. 2010;24(1):111-20. Source: EMBASE. [pmid: 18801825].
2267 Montejo-Gonzalez AL, Llorca G, Izquierdo JA, et al. SSRI-induced sexual dysfunction: fluoxetine, paroxetine, sertraline, and fluvoxamine in a prospective, multicenter, and descriptive clinical study of 344 patients. J Sex Marital Ther. Fall. 1997;23(3):176-94. Source: PubMed. [pmid: 9292833].
2268 Monteleone P, Gnocchi G. Evidence for a linear relationship between plasma trazodone levels and clinical response in depression in the elderly. Clin Neuropharmacol. Suppl 1. 1990;13:S84-9. Source: PubMed. [pmid: 2379183].
2269 Monteleone P, Maj M, Iovino M, et al. GABA, depression and the mechanism of action of antidepressant drugs: a neuroendocrine approach. J Affect Disord. Sep. 1990;20(1):1-5. Source: PubMed. [pmid: 2174069].
2270 Montgomery SA. Safety of mirtazapine: a review. Int Clin Psychopharmacol. Dec. Suppl 4. 1995;10:37-45. Source: PubMed. [pmid: 8930008].
2271 Montgomery SA. Reboxetine: additional benefits to the depressed patient. J Psychopharmacol. 1997;11(4 Suppl):S9-15. Source: PubMed. [pmid: 9438228].
2272 Montgomery SA. Comparative efficacy and tolerability of escitalopram oxalate versus venlafaxine XR. Data on file--Forest Laboratories. 2004. Source: Handsearch.
2273 Montgomery SA. Major depressive disorders: Clinical efficacy and tolerability of agomelatine, a new melatonergic agonist. European Neuropsychopharmacology. Sep. 2006. 2006;16(6):S633-S8. Source: PsycINFO.
2274 Montgomery SA, Andersen HF. Escitalopram versus venlafaxine XR in the treatment of depression. Int Clin Psychopharmacol. Sep. 2006;21(5):297-309. Source: PubMed. [pmid: 16877901].
2275 Montgomery SA, Baldwin DS, Blier P, et al. Which antidepressants have demonstrated superior efficacy? A review of the evidence. International Clinical Psychopharmacology. 2007;22(6):323-9. Source: PsycINFO. [pmid: 17917550].
2276 Montgomery SA, Baldwin DS, Blier P, et al. Which antidepressants have demonstrated superior efficacy? A review of the evidence: Erratum. International Clinical Psychopharmacology. 2008;23(1):61. Source: PsycINFO.
2277 Montgomery SA, Baldwin DS, Riley A. Antidepressant medications: a review of the evidence for drug-induced sexual dysfunction. J Affect Disord. May. 2002;69(1-3):119-40. Source: PubMed. [pmid: 12103459].
2278 Montgomery SA, Dunbar G. Paroxetine is better than placebo in relapse prevention and the prophylaxis of recurrent depression. Int Clin Psychopharmacol. Fall. 1993;8(3):189-95. Source: PubMed. [pmid: 8263317].
2279 Montgomery SA, Entsuah R, Hackett D, et al. Venlafaxine versus placebo in the preventive treatment of recurrent major depression. J Clin Psychiatry. Mar. 2004;65(3):328-36. Source: PubMed. [pmid: 15096071].
2280 Montgomery SA, Gabriel R, James D, et al. The specificity of the zimelidine reaction. Int Clin Psychopharmacol. Jan. 1989;4(1):19-23. Source: PubMed. [pmid: 2531772].
2281 Montgomery SA, Gabriel R, James D, et al. Hypersensitivity to zimelidine without cross reactivity to fluoxetine. Int Clin Psychopharmacol. Jan. Suppl 1. 1989;4:27-9. Source: PubMed. [pmid: 2521657].
2282 Montgomery SA, Huusom AK, Bothmer J. A randomised study comparing escitalopram with venlafaxine XR in primary care patients with major depressive disorder. Neuropsychobiology. 2004;50(1):57-64. Source: PubMed. [pmid: 15179022].
2283 Montgomery SA, Kennedy SH, Burrows GD, et al. Absence of discontinuation symptoms with agomelatine and occurrence of discontinuation symptoms with paroxetine: a randomized, double-blind, placebo-controlled discontinuation study. Int Clin Psychopharmacol. Sep. 2004;19(5):271-80. Source: PubMed. [pmid: 15289700].
2284 Montgomery SA, Möller HJ. Is the significant superiority of escitalopram compared with other antidepressants clinically relevant?. International Clinical Psychopharmacology. May. 2009. 2009;24(3):111-8. Source: PsycINFO. [pmid: 19357527].
2285 Montgomery SA, Pedersen V, Tanghoj P, et al. The optimal dosing regimen for citalopram--a meta-analysis of nine placebo-controlled studies. Int Clin Psychopharmacol. Mar. Suppl 1. 1994;9:35-40. Source: PubMed. [pmid: 8021436].
2286 Montgomery SA, Rasmussen JG. Citalopram 20 mg, citalopram 40 mg and placebo in the prevention of relapse of major depression. Int Clin Psychopharmacol. Jun. 1992;8:181-8. Source: PubMed. [pmid: 8263316].
2287 Montgomery SA, Rasmussen JG, Lyby K, et al. Dose response relationship of citalopram 20 mg, citalopram 40 mg and placebo in the treatment of moderate and severe depression. Int Clin Psychopharmacol. Jun. Suppl 5. 1992;6:65-70. Source: PubMed. [pmid: 1431024].
2288 Montgomery SA, Reimitz PE, Zivkov M. Mirtazapine versus amitriptyline in the long-term treatment of depression: a double-blind placebo-controlled study. Int Clin Psychopharmacol. Mar. 1998;13(2):63-73. Source: PubMed. [pmid: 9669186].
2289 Moon CAL, Jago LW, Wood K, et al. A double-blind comparison of sertraline and clomipramine in the treatment of major depressive disorder and associated anxiety in general practice. Journal Of Psychopharmacology. 1994;8(3):171-6. Source: EMBASE. [pmid: 22298585].
2290 Moore N, Verdoux H, Fantino B. Prospective, multicentre, randomized, double-blind study of the efficacy of escitalopram versus citalopram in outpatient treatment of major depressive disorder. Int Clin Psychopharmacol. May. 2005;20(3):131-7. Source: PubMed. [pmid: 15812262].
2291 Moosa MY, Panz VR, Jeenah FY, et al. African women with depression: the effect of imipramine and fluoxetine on body mass index and leptin secretion. J Clin Psychopharmacol. Dec. 2003;23(6):549-52. Source: PubMed. [pmid: 14624184].
2292 Morales N, Vermette H. Serotonin syndrome associated with linezolid treatment after discontinuation of fluoxetine. Psychosomatics. May-Jun. 2005;46(3):274-5. Source: PubMed. [pmid: 15883150].
2293 Morasco BJ, Loftis JM, Indest DW, et al. Prophylactic antidepressant treatment in patients with hepatitis C on antiviral therapy: a double-blind, placebo-controlled trial. Psychosomatics. Sep-Oct. 2010;51(5):401-8. Source: PubMed. [pmid: 20833939].
2294 Morasco BJ, Rifai MA, Loftis JM, et al. A randomized trial of paroxetine to prevent interferon-alpha-induced depression in patients with hepatitis C. J Affect Disord. Nov. 2007;103(1-3):83-90. Source: PubMed. [pmid: 17292481].
2295 Moreau X, Azorin JM, Lejeune PJ, et al. Red blood cell triiodothyronine uptake in unipolar major depression: effect of a chronic antidepressant treatment. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 2000;24(1):23-35. Source: PubMed. [pmid: 10659981].
2296 Moreno FA, Parkinson D, Palmer C, et al. CSF neurochemicals during tryptophan depletion in individuals with remitted depression and healthy controls. Eur Neuropsychopharmacol. Jan. 2010;20(1):18-24. Source: PubMed. [pmid: 19896342].
2297 Moreno RA, Teng CT, Almeida KM, et al. Hypericum perforatum versus fluoxetine in the treatment of mild to moderate depression: a randomized double-blind trial in a Brazilian sample. Rev Bras Psiquiatr. 2006;28(1):29-32. Source: PubMed. [pmid: 16612487].
2298 Morgan ML, Rapkin AJ, Biggio G, et al. Neuroactive steroids after estrogen exposure in depressed postmenopausal women treated with sertraline and asymptomatic postmenopausal women. Arch Womens Ment Health. Feb. 2010;13(1):91-8. Source: PubMed. [pmid: 19728035].
2299 Morishita S, Arita S. Differential effects of milnacipran, fluvoxamine and paroxetine for depression, especially in gender. Eur Psychiatry. Dec. 2003;18(8):418-20. Source: PubMed. [pmid: 14680720].
2300 Morishita S, Arita S. Induction of mania in depression by paroxetine. Hum Psychopharmacol. Oct. 2003;18(7):565-8. Source: PubMed. [pmid: 14533140].
2301 Morishita S, Arita S. Differential period of onset of action of fluvoxamine, paroxetine and milnacipran for depression. Hum Psychopharmacol. Aug. 2003;18(6):479-82. Source: PubMed. [pmid: 12923828].
2302 Morishita S, Arita S. Possible predictors of response to fluvoxamine for depression. Hum Psychopharmacol. Apr. 2003;18(3):197-200. Source: PubMed. [pmid: 12672171].
2303 Morishita S, Arita S. Suitable dose and duration of fluvoxamine administration to treat depression. Psychiatry Clin Neurosci. Apr. 2003;57(2):177-81. Source: PubMed. [pmid: 12667164].
2304 Morishita S, Arita S. Response Period of Combined Fluvoxamine and Milnacipran Treatment for Depression. International Medical Journal. Mar. 2005. 2005;12(1):25-6. Source: PsycINFO.
2305 Morishita S, Kinoshita T. Predictors of response to sertraline in patients with major depression. Hum Psychopharmacol. Dec. 2008;23(8):647-51. Source: PubMed. [pmid: 18821727].
2306 Morris DW, Rush AJ, Jain S, et al. Diurnal mood variation in outpatients with major depressive disorder: implications for DSM-V from an analysis of the Sequenced Treatment Alternatives to Relieve Depression Study data. J Clin Psychiatry. Sep. 2007;68(9):1339-47. Source: PubMed. [pmid: 17915971].
2307 Moscovitch A, Blashko CA, Eagles JM, et al. A placebo-controlled study of sertraline in the treatment of outpatients with seasonal affective disorder. Psychopharmacology (Berl). Feb. 2004;171(4):390-7. Source: PubMed. [pmid: 14504682].
2308 Moslinger Gehmayr R, Zanineli R, Contu A, et al. A double-blind study comparing the efficacy and tolerability of paroxetine and amitriptyline in the treatment of breast-cancer patients with depression. Zentralblatt Fur Gynakologie. 2000;122(4):195-202. Source: EMBASE. [pmid: 10795116].
2309 Moss JH. A novel placebo lead-in behavior strategy for sertraline dosing in a depressed patient highly sensitive to medication side effects. J Clin Psychiatry. Sep. 1997;58(9):405-6. Source: PubMed. [pmid: 9378695].
2310 Mottram P, Wilson K, Strobl J. Antidepressants for depressed elderly. Cochrane Database Syst Rev. 2006;(1). Source: Scopus.
2311 Mouret J, Lemoine P, Minuit MP, et al. Effects of trazodone on the sleep of depressed subjects--a polygraphic study. Psychopharmacology (Berl). 1988;95(Suppl):S37-43. Source: PubMed. [pmid: 3133713].
2312 Moustgaard G. Treatment-refractory depression successfully treated with the combination of mirtazapine and lithium. J Clin Psychopharmacol. Apr. 2000;20(2):268. Source: PubMed. [pmid: 10770470].
2313 Mowla A, Ghanizadeh A, Pani A. A comparison of effects of fluoxetine and nortriptyline on the symptoms of major depressive disorder. J Clin Psychopharmacol. Apr. 2006;26(2):209-11. Source: PubMed. [pmid: 16633155].
2314 Mrazek DA, Rush AJ, Biernacka JM, et al. SLC6A4 variation and citalopram response. Am J Med Genet B Neuropsychiatr Genet. Apr. 5. 2009;150B(3):341-51. Source: PubMed. [pmid: 18618621].
2315 Mucci M. Reboxetine: a review of antidepressant tolerability. J Psychopharmacol. 1997;11(4 Suppl):S33-7. Source: PubMed. [pmid: 9438231].
2316 Muck-Seler D, Jakovljevic M, Deanovic Z. Effect of antidepressant treatment on platelet 5-HT content and relation to therapeutic outcome in unipolar depressive patients. J Affect Disord. Nov. 1991;23(3):157-64. Source: PubMed. [pmid: 1774431].
2317 Muck-Weymann M, Rechlin T. Reflexes of the cutaneous microcirculation in amitriptyline and in fluoxetine treated patients. Psychopharmacology (Berl). Apr. 1996;124(3):241-4. Source: PubMed. [pmid: 8740045].
2318 Mühlbacher M, Konstantinidis A, Kasper S, et al. Intravenous Mirtazapine Is Safe and Effective in the Treatment of Depressed Inpatients. Neuropsychobiology. Apr. 2006. 2006;53(2):83-7. Source: PsycINFO. [pmid: 16511339].
2319 Müller N, Schennach R, Riedel M, et al. Duloxetine in the treatment of major psychiatric and neuropathic disorders. Expert Review of Neurotherapeutics. 2008;8(4):527-36. Source: Scopus. [pmid: 18416656].
2320 Münchau A, Langosch JM, Gerschlager W, et al. Mirtazapine increases cortical excitability in healthy controls and epilepsy patients with major depression. Journal of Neurology, Neurosurgery & Psychiatry. Apr. 2005. 2005;76(4):527-33. Source: PsycINFO.
2321 Muhonen LH, Lahti J, Sinclair D, et al. Treatment of alcohol dependence in patients with co-morbid major depressive disorder--predictors for the outcomes with memantine and escitalopram medication. Subst Abuse Treat Prev Policy. 2008;3:20. Source: PubMed. [pmid: 18834506].
2322 Muhonen LH, Lonnqvist J, Juva K, et al. Double-blind, randomized comparison of memantine and escitalopram for the treatment of major depressive disorder comorbid with alcohol dependence. J Clin Psychiatry. Mar. 2008;69(3):392-9. Source: PubMed. [pmid: 18348597].
2323 Muhonen LH, Lonnqvist J, Lahti J, et al. Age at onset of first depressive episode as a predictor for escitalopram treatment of major depression comorbid with alcohol dependence. Psychiatry Res. May. 15. 2009;167(1-2):115-22. Source: PubMed. [pmid: 19346004].
2324 Muijen M, Roy D, Silverstone T, et al. A comparative clinical trial of fluoxetine, mianserin and placebo in depressed outpatients. Acta Psychiatr Scand. Sep. 1988;78(3):384-90. Source: PubMed. [pmid: 3057817].
2325 Muijsers RB, Plosker GL, Noble S. Sertraline: a review of its use in the management of major depressive disorder in elderly patients. Drugs Aging. 2002;19(5):377-92. Source: PubMed. [pmid: 12093324].
2326 Muijsers RB, Plosker GL, Noble S. Spotlight on sertraline in the management of major depressive disorder in elderly patients. CNS Drugs. 2002;16(11):789-94. Source: PubMed. [pmid: 12383038].
2327 Mukai Y, Tampi RR. Treatment of depression in the elderly: A review of the recent literature on the efficacy of single- versus dual-action antidepressants. Clinical Therapeutics. 2009;31(5):945-61. Source: Scopus. [pmid: 19539096].
2328 Mukherjee PK, Davey A. Differential dosing of trazodone in elderly depressed patients: a study to investigate optimal dosing. J Int Med Res. 1986;14(5):279-84. Source: PubMed. [pmid: 3533676].
2329 Mulder RT, Frampton CM, Luty SE, et al. Eighteen months of drug treatment for depression: predicting relapse and recovery. J Affect Disord. Apr. 2009;114(1-3):263-70. Source: PubMed. [pmid: 18805590].
2330 Mulder RT, Joyce PR, Frampton C. Relationships among measures of treatment outcome in depressed patients. J Affect Disord. Sep. 2003;76(1-3):127-35. Source: PubMed. [pmid: 12943942].
2331 Mulder RT, Joyce PR, Frampton CM. Personality disorders improve in patients treated for major depression. Acta Psychiatr Scand. Sep. 2010;122(3):219-25. Source: PubMed. [pmid: 19895619].
2332 Mulder RT, Joyce PR, Frampton CM, et al. Antidepressant treatment is associated with a reduction in suicidal ideation and suicide attempts. Acta Psychiatr Scand. Aug. 2008;118(2):116-22. Source: PubMed. [pmid: 18384467].
2333 Mulder RT, Joyce PR, Luty SE. The relationship of personality disorders to treatment outcome in depressed outpatients. J Clin Psychiatry. Mar. 2003;64(3):259-64. Source: PubMed. [pmid: 12716266].
2334 Mulder RT, Watkins WG, Joyce PR, et al. Age may affect response to antidepressants with serotonergic and noradrenergic actions. J Affect Disord. Sep. 2003;76(1-3):143-9. Source: PubMed. [pmid: 12943944].
2335 Muldoon C. The safety and tolerability of citalopram. Int Clin Psychopharmacol. Mar. Suppl 1. 1996;11:35-40. Source: PubMed. [pmid: 8732443].
2336 Mulert C, Juckel G, Augustin H, et al. Comparison between the analysis of the loudness dependency of the auditory N1/P2 component with LORETA and dipole source analysis in the prediction of treatment response to the selective serotonin reuptake inhibitor citalopram in major depression. Clin Neurophysiol. Oct. 2002;113(10):1566-72. Source: PubMed. [pmid: 12350432].
2337 Mulert C, Juckel G, Brunnmeier M, et al. Prediction of treatment response in major depression: integration of concepts. J Affect Disord. Mar. 2007;98(3):215-25. Source: PubMed. [pmid: 16996140].
2338 Mulert C, Juckel G, Brunnmeier M, et al. Rostral anterior cingulate cortex activity in the theta band predicts response to antidepressive medication. Clinical EEG and Neuroscience. 2007;38(2):78-81. Source: EMBASE. [pmid: 17515172].
2339 Mullin J, Lodge A, Bennie E, et al. A multicentre, double-blind, amitriptyline-controIled study of mirtazapine in patients with major depression. Journal Of Psychopharmacology. 1996;10(3):235-40. Source: EMBASE. [pmid: 22302951].
2340 Mullin JM, Pandita-Gunawardena VR, Whitehead AM. A double-blind comparison of fluvoxamine and dothiepin in the treatment of major affective disorder. Br J Clin Pract. Feb. 1988;42(2):51-5. Source: PubMed. [pmid: 3140864].
2341 Mulrow CD, Williams JW Jr, Trivedi M, et al. Treatment of depression--newer pharmacotherapies. Psychopharmacol Bull. 1998;34(4):409-795. Source: PubMed. [pmid: 10513454].
2342 Mulsant BH. Onset of confusion in the context of late-life depression. J Psychiatry Neurosci. Mar. 2007;32(2):152. Source: PubMed. [pmid: 17353943].
2343 Mulsant BH, Pollock BG, Nebes RD, et al. A double-blind randomized comparison of nortriptyline and paroxetine in the treatment of late-life depression: 6-week outcome. J Clin Psychiatry. Suppl 20. 1999;60:16-20. Source: PubMed. [pmid: 10513853].
2344 Munizza C, Olivieri L, Di Loreto G, et al. A comparative, randomized, double-blind study of trazodone prolonged-release and sertraline in the treatment of major depressive disorder. Curr Med Res Opin. 2006;22(9):1703-13. Source: PubMed. [pmid: 16968574].
2345 Munoz RA, McBride ME, Brnabic AJM, et al. Major depressive disorder in Latin America: The relationship between depression severity, painful somatic symptoms, and quality of life. Journal of Affective Disorders. 2005;86(1):93-8. Source: Scopus. [pmid: 15820276].
2346 Munro CA, Brandt J, Sheppard JM, et al. Cognitive response to pharmacological treatment for depression in Alzheimer disease: secondary outcomes from the depression in Alzheimer's disease study (DIADS). Am J Geriatr Psychiatry. Sep-Oct. 2004;12(5):491-8. Source: PubMed. [pmid: 15353387].
2347 Murasaki M, Kamijima K, Yamashita I, et al. Clinical evaluation of sertraline hydrochloride, a selective serotonin reuptake inhibitor for depression and depressive state-A double-blind study compared with imipramine hydrochloride. Japanese Journal of Neuropsychopharmacology. 1997;19(6):505-27. Source: EMBASE.
2348 Murck H, Nickel T, Kunzel H, et al. State markers of depression in sleep EEG: dependency on drug and gender in patients treated with tianeptine or paroxetine. Neuropsychopharmacology. Feb. 2003;28(2):348-58. Source: PubMed. [pmid: 12589388].
2349 Murdoch D, Keam SJ. Escitalopram: a review of its use in the management of major depressive disorder. Drugs. 2005;65(16):2379-404. Source: PubMed. [pmid: 16266205].
2350 Murdoch D, Keam SJ. Spotlight on escitalopram in the management of major depressive disorder. CNS Drugs. 2006;20(2):167-70. Source: PubMed. [pmid: 16478291].
2351 Murphy GM Jr, Hollander SB, Rodrigues HE, et al. Effects of the serotonin transporter gene promoter polymorphism on mirtazapine and paroxetine efficacy and adverse events in geriatric major depression. Arch Gen Psychiatry. Nov. 2004;61(11):1163-9. Source: PubMed. [pmid: 15520364].
2352 Murray G, Michalak EE, Levitt AJ, et al. Therapeutic mechanism in seasonal affective disorder: do fluoxetine and light operate through advancing circadian phase?. Chronobiol Int. 2005;22(5):937-43. Source: PubMed. [pmid: 16298778].
2353 Murray G, Michalak EE, Levitt AJ, et al. O sweet spot where art thou? Light treatment of Seasonal Affective Disorder and the circadian time of sleep. J Affect Disord. Feb. 2006;90(2-3):227-31. Source: PubMed. [pmid: 16337687].
2354 Murray V, von Arbin M, Bartfai A, et al. Double-blind comparison of sertraline and placebo in stroke patients with minor depression and less severe major depression. J Clin Psychiatry. Jun. 2005;66(6):708-16. Source: PubMed. [pmid: 15960563].
2355 Musselman DL, Lawson DH, Gumnick JF, et al. Paroxetine for the prevention of depression induced by high-dose interferon alfa. N Engl J Med. Mar. 29. 2001;344(13):961-6. Source: PubMed. [pmid: 11274622].
2356 Musselman DL, Somerset WI, Guo Y, et al. A double-blind, multicenter, parallel-group study of paroxetine, desipramine, or placebo in breast cancer patients (stages I, II, III, and IV) with major depression. J Clin Psychiatry. Feb. 2006;67(2):288-96. Source: PubMed. [pmid: 16566626].
2357 Mussig K, Morike K, Haring HU. Severe and symptomatic hyponatremia following duloxetine treatment. J Psychopharmacol. May. 2009;23(3):338-9. Source: PubMed. [pmid: 18562431].
2358 Mustafa FA, Almoshmosh N, Al-Robb H, et al. A case of possible duloxetine-induced mania. German Journal of Psychiatry. 2010;13(1):54-6. Source: EMBASE.
2359 Muzina DJ, Calabrese JR. Reply to Dr Eppel regarding ‘Letter to the editor: Agomelatine adjunctive therapy for acute bipolar depression: Preliminary open data ’. Bipolar Disorders. Sep. 2008. 2008;10(6):750-1. Source: PsycINFO.
2360 Mynors-Wallis LM, Gath DH, Day A, et al. Randomised controlled trial of problem solving treatment, antidepressant medication, and combined treatment for major depression in primary care. Bmj. Jan. 1. 2000;320(7226):26-30. Source: PubMed. [pmid: 10617523].
2361 Nagler J. Absence of asystole during bifrontal stimulation in electroconvulsive therapy. Journal of ECT. 2010;26(2):100-3. Source: EMBASE. [pmid: 19935092].
2362 Nagy LM, Morgan CA 3rd, Southwick SM, et al. Open prospective trial of fluoxetine for posttraumatic stress disorder. J Clin Psychopharmacol. Apr. 1993;13(2):107-13. Source: PubMed. [pmid: 8463442].
2363 Nahshoni E, Weizman A, Shefet D, et al. A case of hyponatremia associated with escitalopram. J Clin Psychiatry. Dec. 2004;65(12):1722. Source: PubMed. [pmid: 15641882].
2364 Nakagawa A, Watanabe N, Omori IM, et al. Milnacipran versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2007;(2). Source: Scopus.
2365 Nakajima S, Ishida T, Akaishi R, et al. Impacts of switching antidepressants after successful electroconvulsive therapy on the maintenance of clinical remission in patients with treatment-resistant depression: a chart review. J Ect. Sep. 2009;25(3):178-81. Source: PubMed. [pmid: 19710625].
2366 Nakano Y, Baba H, Maeshima H, et al. Executive dysfunction in medicated, remitted state of major depression. Journal of Affective Disorders. 2008;111(1):46-51. Source: EMBASE. [pmid: 18304646].
2367 Nakao M, Takeuchi T, Nomura K, et al. Clinical application of paroxetine for tapering benzodiazepine use in non-major-depressive outpatients visiting an internal medicine clinic. Psychiatry Clin Neurosci. Oct. 2006;60(5):605-10. Source: PubMed. [pmid: 16958945].
2368 Nakhai-Pour HR, Broy P, Berard A. Use of antidepressants during pregnancy and the risk of spontaneous abortion. CMAJ. 2010;182(10):1031-7. Source: PubMed. [pmid: 20513781].
2369 Nambudiri DE, Mirchandani IC, Young RC. Two more cases of trazodone-related syncope in the elderly. J Geriatr Psychiatry Neurol. Oct-Dec. 1989;2(4):225. Source: PubMed. [pmid: 2635019].
2370 Nankai M, Yamada S, Yoshimoto S, et al. Platelet 3H-paroxetine binding in control subjects and depressed patients: relationship to serotonin uptake and age. Psychiatry Res. Feb. 1994;51(2):147-55. Source: PubMed. [pmid: 8022949].
2371 Narayan M, Anderson G, Cellar J, et al. Serotonin transporter-blocking properties of nefazodone assessed by measurement of platelet serotonin. J Clin Psychopharmacol. Feb. 1998;18(1):67-71. Source: PubMed. [pmid: 9472845].
2372 Nardi AE, Lopes FL, Valenca AM. Body dysmorphic disorder treated with bupropion: cases report. Aust N Z J Psychiatry. Jan-Feb. 2005;39(1-2):112. Source: PubMed. [pmid: 15660717].
2373 Narushima K, Kosier JT, Robinson RG. Preventing poststroke depression: a 12-week double-blind randomized treatment trial and 21-month follow-up. J Nerv Ment Dis. May. 2002;190(5):296-303. Source: PubMed. [pmid: 12011609].
2374 Narushima K, Robinson RG. The effect of early versus late antidepressant treatment on physical impairment associated with poststroke depression: is there a time-related therapeutic window?. Journal of Nervous & Mental Disease. 2003;191(10):645-52. Source: EMBASE. [pmid: 14555866].
2375 Nathan RS, Perel JM, Pollock BG, et al. The role of neuropharmacologic selectivity in antidepressant action: fluvoxamine versus desipramine. J Clin Psychiatry. Sep. 1990;51(9):367-72. Source: PubMed. [pmid: 2120201].
2376 Navari RM, Brenner MC, Wilson MN. Treatment of depressive symptoms in patients with early stage breast cancer undergoing adjuvant therapy. Breast Cancer Research and Treatment. 2008;112(1):197-201. Source: Handsearch. [pmid: 18064563].
2377 Navarro V, Gasto C, Torres X, et al. Citalopram versus nortriptyline in late-life depression: a 12-week randomized single-blind study. Acta Psychiatr Scand. Jun. 2001;103(6):435-40. Source: PubMed. [pmid: 11401657].
2378 Navines R, Martin-Santos R, Gomez-Gil E, et al. Interaction between serotonin 5-HT1A receptors and beta-endorphins modulates antidepressant response. Prog Neuropsychopharmacol Biol Psychiatry. Dec. 12. 2008;32(8):1804-9. Source: PubMed. [pmid: 18725263].
2379 Nebes RD, Butters MA, Houck PR, et al. Dual-task performance in depressed geriatric patients. Psychiatry Res. Jun. 1. 2001;102(2):139-51. Source: PubMed. [pmid: 11408053].
2380 Nebes RD, Pollock BG, Houck PR, et al. Persistence of cognitive impairment in geriatric patients following antidepressant treatment: a randomized, double-blind clinical trial with nortriptyline and paroxetine. J Psychiatr Res. Mar-Apr. 2003;37(2):99-108. Source: PubMed. [pmid: 12842163].
2381 Nebes RD, Pollock BG, Mulsant BH, et al. Cognitive effects of paroxetine in older depressed patients. J Clin Psychiatry. Suppl 20. 1999;60:26-9. Source: PubMed. [pmid: 10513855].
2382 Nelson C, Those ME, Khan A. Are antidepressants effective? What's a clinician to think?. Journal of Clinical Psychiatry. Jun. 2008. 2008;69(6):1014-5. Source: PsycINFO. [pmid: 18683997].
2383 Nelson E, Cloninger CR. Exploring the TPQ as a possible predictor of antidepressant response to nefazodone in a large multi-site study. J Affect Disord. Jul. 1997;44(2-3):197-200. Source: PubMed. [pmid: 9241580].
2384 Nelson EC. An open-label study of nefazodone in the treatment of depression with and without comorbid obsessive compulsive disorder. Ann Clin Psychiatry. Dec. 1994;6(4):249-53. Source: PubMed. [pmid: 7647834].
2385 Nelson JC. Anxious depression and response to treatment. The American Journal of Psychiatry. Mar. 2008. 2008;165(3):297-9. Source: PsycINFO. [pmid: 18316424].
2386 Nelson JC. Anxiety does not predict response to duloxetine in major depression: results of a pooled analysis of individual patient data from 11 placebo-controlled trials. Depress Anxiety. 2010;27(1):12-8. Source: PubMed. [pmid: 20013987].
2387 Nelson JC, Delucchi K, Schneider L. Suicidal thinking and behavior during treatment with sertraline in late-life depression. Am J Geriatr Psychiatry. 2007;15(7):573-80. Source: PubMed. [pmid: 17586782].
2388 Nelson JC, Delucchi K, Schneider LS. Efficacy of second generation antidepressants in late-life depression: a meta-analysis of the evidence. Am J Geriatr Psychiatry. 2008;16(7):558-67. Source: PubMed. [pmid: 18591576].
2389 Nelson JC, Holden K, Roose S, et al. Are there predictors of outcome in depressed elderly nursing home residents during treatment with mirtazapine orally disintegrating tablets?. Int J Geriatr Psychiatry. Oct. 2007;22(10):999-1003. Source: PubMed. [pmid: 17447229].
2390 Nelson JC, Hollander SB, Betzel J, et al. Mirtazapine orally disintegrating tablets in depressed nursing home residents 85 years of age and older. Int J Geriatr Psychiatry. Sep. 2006;21(9):898-901. Source: PubMed. [pmid: 16955423].
2391 Nelson JC, Kennedy JS, Pollock BG, et al. Treatment of major depression with nortriptyline and paroxetine in patients with ischemic heart disease. Am J Psychiatry. Jul. 1999;156(7):1024-8. Source: PubMed. [pmid: 10401446].
2392 Nelson JC, Mankoski R, Baker RA, et al. Effects of aripiprazole adjunctive to standard antidepressant treatment on the core symptoms of depression: a post-hoc, pooled analysis of two large, placebo-controlled studies. J Affect Disord. Jan. 2010;120(1-3):133-40. Source: PubMed. [pmid: 19656577].
2393 Nelson JC, Mazure CM, Bowers MB Jr, et al. A preliminary, open study of the combination of fluoxetine and desipramine for rapid treatment of major depression. Arch Gen Psychiatry. Apr. 1991;48(4):303-7. Source: PubMed. [pmid: 2009031].
2394 Nelson JC, Mazure CM, Jatlow PI, et al. Combining norepinephrine and serotonin reuptake inhibition mechanisms for treatment of depression: a double-blind, randomized study. Biol Psychiatry. Feb. 1. 2004;55(3):296-300. Source: PubMed. [pmid: 14744472].
2395 Nelson JC, Portera L, Leon AC. Residual symptoms in depressed patients after treatment with fluoxetine or reboxetine. J Clin Psychiatry. Nov. 2005;66(11):1409-14. Source: PubMed. [pmid: 16420078].
2396 Nelson JC, Wohlreich MM, Mallinckrodt CH, et al. Duloxetine for the treatment of major depressive disorder in older patients. Am J Geriatr Psychiatry. Mar. 2005;13(3):227-35. Source: PubMed. [pmid: 15728754].
2397 Nemeroff CB. Paroxetine: an overview of the efficacy and safety of a new selective serotonin reuptake inhibitor in the treatment of depression. J Clin Psychopharmacol. Dec. 1993;13(6 Suppl 2):10S-7S. Source: PubMed. [pmid: 8106649].
2398 Nemeroff CB. Evolutionary trends in the pharmacotherapeutic management of depression. J Clin Psychiatry. Dec. 1994;55(Suppl):3-15. discussion 6-7. Source: PubMed. [pmid: 7814356].
2399 Nemeroff CB. Improving antidepressant adherence. J Clin Psychiatry. Suppl 18. 2003;64:25-30. Source: PubMed. [pmid: 14700452].
2400 Nemeroff CB, Entsuah R, Benattia I, et al. Comprehensive analysis of remission (COMPARE) with venlafaxine versus SSRIs. Biol Psychiatry. Feb. 15. 2008;63(4):424-34. Source: PubMed. [pmid: 17888885].
2401 Nemeroff CB, Heim CM, Thase ME, et al. Differential responses to psychotherapy versus pharmacotherapy in patients with chronic forms of major depression and childhood trauma. Proc Natl Acad Sci U S A. Nov. 25. 2003;100(24):14293-6. Source: PubMed. [pmid: 14615578].
2402 Nemeroff CB, Kalali A, Keller MB, et al. Impact of publicity concerning pediatric suicidality data on physician practice patterns in the United States. Archives of General Psychiatry. 2007;64(4):466-72. Source: Scopus. [pmid: 17404123].
2403 Nemeroff CB, Ninan PT, Ballenger J, et al. Double-blind multicenter comparison of fluvoxamine versus sertraline in the treatment of depressed outpatients. Depression. 1995;3(4):163-9. Source: EMBASE.
2404 Nemeroff CB, Schatzberg AF, Goldstein DJ, et al. Duloxetine for the treatment of major depressive disorder. Psychopharmacol Bull. Autumn. 2002;36(4):106-32. Source: PubMed. [pmid: 12858150].
2405 Nemeroff CB, Thase ME. A double-blind, placebo-controlled comparison of venlafaxine and fluoxetine treatment in depressed outpatients. Journal of Psychiatric Research. 2007;41(3-4):351-9. Source: PubMed. [pmid: 16165158].
2406 Nemets B, Bersudsky Y, Belmaker RH. Controlled double-blind trial of phenytoin vs. fluoxetine in major depressive disorder. J Clin Psychiatry. May. 2005;66(5):586-90. Source: PubMed. [pmid: 15889944].
2407 Neri S, Bertino G, Petralia A, et al. A multidisciplinary therapeutic approach for reducing the risk of psychiatric side effects in patients with chronic hepatitis C treated with pegylated interferon (alpha) and ribavirin. Journal of Clinical Gastroenterology. 2010;44(9):e210-e7. Source: EMBASE. [pmid: 20838237].
2408 Nevin RL. Mefloquine prescriptions in the presence of contraindications: Prevalence among US military personnel deployed to Afghanistan, 2007. Pharmacoepidemiology and Drug Safety. 2010;19(2):206-10. Source: EMBASE. [pmid: 19998269].
2409 New AS, Woo-Ming A, Mitropoulou V, et al. Serotonin and the prediction of response time to fluoxetine in patients with mild depression. Psychiatry Res. Nov. 8. 1999;88(2):89-93. Source: PubMed. [pmid: 10622345].
2410 Newhouse PA, Krishnan KR, Doraiswamy PM, et al. A double-blind comparison of sertraline and fluoxetine in depressed elderly outpatients. J Clin Psychiatry. Aug. 2000;61(8):559-68. Source: PubMed. [pmid: 10982198].
2411 Newman JR, Ewing SE, McColl RD, et al. Tridimensional personality questionnaire and treatment response in major depressive disorder: a negative study. J Affect Disord. Jan-Mar. 2000;57(1-3):241-7. Source: PubMed. [pmid: 10708838].
2412 Ng CH, Easteal S, Tan S, et al. Serotonin transporter polymorphisms and clinical response to sertraline across ethnicities. Prog Neuropsychopharmacol Biol Psychiatry. Jul. 2006;30(5):953-7. Source: PubMed. [pmid: 16580768].
2413 Ng J, Sansone RA, McDonald S. Akathisia and abnormal movements of the upper extremities with venlafaxine and methimazole. Gen Hosp Psychiatry. 2009;(4):388-90. Source: PubMed. [pmid: 19555803].
2414 Nickel T, Sonntag A, Backmund M, et al. Depression during therapy with interferon alpha--how long should an antidepressant treatment last?. Pharmacopsychiatry. Mar. 2005;38(2):102-4. Source: PubMed. [pmid: 15744637].
2415 Nickel T, Sonntag A, Schill J, et al. Clinical and neurobiological effects of tianeptine and paroxetine in major depression. J Clin Psychopharmacol. Apr. 2003;23(2):155-68. Source: PubMed. [pmid: 12640217].
2416 Niederhofer H. Acetylcholinesterase inhibitors may improve efficacy and reduce adverse effects of tricyclic antidepressants for depression. Drugs & Aging. 2008. 2008;25(8):715. Source: PsycINFO. [pmid: 18665663].
2417 Niedermaier N, Bohrer E, Schulte K, et al. Prevention and treatment of poststroke depression with mirtazapine in patients with acute stroke. J Clin Psychiatry. Dec. 2004;65(12):1619-23. Source: PubMed. [pmid: 15641866].
2418 Nielsen BM, Behnke K, Arup P, et al. A comparison of fluoxetine and imipramine in the treatment of outpatients with major depressive disorder. Acta Psychiatr Scand. Apr. 1993;87(4):269-72. Source: PubMed. [pmid: 8488748].
2419 Nierenberg AA, Adler LA, Peselow E, et al. Trazodone for antidepressant-associated insomnia. Am J Psychiatry. Jul. 1994;151(7):1069-72. Source: PubMed. [pmid: 8010365].
2420 Nierenberg AA, Alpert JE, Gaynes BN, et al. Family history of completed suicide and characteristics of major depressive disorder: a STAR*D (sequenced treatment alternatives to relieve depression) study. J Affect Disord. May. 2008;108(1-2):129-34. Source: PubMed. [pmid: 18006073].
2421 Nierenberg AA, Cole JO, Glass L. Possible trazodone potentiation of fluoxetine: a case series. J Clin Psychiatry. Mar. 1992;53(3):83-5. Source: PubMed. [pmid: 1548249].
2422 Nierenberg AA, Fava M, Trivedi MH, et al. A comparison of lithium and T3 augmentation following two failed medication treatments for depression: A STAR*D report. American Journal of Psychiatry. 2006;163(9):1519-30. Source: Scopus. [pmid: 16946176].
2423 Nierenberg AA, Feighner JP, Rudolph R, et al. Venlafaxine for treatment-resistant unipolar depression. J Clin Psychopharmacol. Dec. 1994;14(6):419-23. Source: PubMed. [pmid: 7884023].
2424 Nierenberg AA, Greist JH, Mallinckrodt CH, et al. Duloxetine versus escitalopram and placebo in the treatment of patients with major depressive disorder: onset of antidepressant action, a non-inferiority study. Curr Med Res Opin. 2007;23(2):401-16. Source: PubMed. [pmid: 17288694].
2425 Nierenberg AA, Grossbard SJ, Fava M, et al. Social adjustment does not predict depressive relapse during continuation fluoxetine therapy. J Affect Disord. May. 17. 1995;34(2):73-7. Source: PubMed. [pmid: 7665807].
2426 Nierenberg AA, Husain MM, Trivedi MH, et al. Residual symptoms after remission of major depressive disorder with citalopram and risk of relapse: a STAR*D report. Psychol Med. Jan. 2010;40(1):41-50. Source: PubMed. [pmid: 19460188].
2427 Nierenberg AA, McLean NE, Alpert JE, et al. Early nonresponse to fluoxetine as a predictor of poor 8-week outcome. Am J Psychiatry. Oct. 1995;152(10):1500-3. Source: PubMed. [pmid: 7573590].
2428 Nierenberg AA, Papakostas GI, Petersen T, et al. Nortriptyline for treatment-resistant depression. J Clin Psychiatry. Jan. 2003;64(1):35-9. Source: PubMed. [pmid: 12590621].
2429 Nierenberg AA, Pava JA, Clancy K, et al. Are neurovegetative symptoms stable in relapsing or recurrent atypical depressive episodes?. Biol Psychiatry. Oct. 15. 1996;40(8):691-6. Source: PubMed. [pmid: 8894060].
2430 Nierenberg AA, Quitkin FM, Kremer C, et al. Placebo-controlled continuation treatment with mirtazapine: acute pattern of response predicts relapse. Neuropsychopharmacology. May. 2004;29(5):1012-8. Source: PubMed. [pmid: 14997172].
2431 Nierenberg AA, Trivedi MH, Fava M, et al. Family history of mood disorder and characteristics of major depressive disorder: a STAR*D (sequenced treatment alternatives to relieve depression) study. J Psychiatr Res. Apr-Jun. 2007;41(3-4):214-21. Source: PubMed. [pmid: 16690084].
2432 Nierenberg AA, Trivedi MH, Ritz L, et al. Suicide risk management for the sequenced treatment alternatives to relieve depression study: applied NIMH guidelines. J Psychiatr Res. Nov-Dec. 2004;38(6):583-9. Source: PubMed. [pmid: 15458854].
2433 Nieuwstraten CE, Dolovich LR. Bupropion versus selective serotonin-reuptake inhibitors for treatment of depression. Ann Pharmacother. Dec. 2001;35(12):1608-13. Source: PubMed. [pmid: 11793630].
2434 Nikisch G, Mathe AA, Czernik A, et al. Stereoselective metabolism of citalopram in plasma and cerebrospinal fluid of depressive patients: relationship with 5-HIAA in CSF and clinical response. J Clin Psychopharmacol. Jun. 2004;24(3):283-90. Source: PubMed. [pmid: 15118482].
2435 Nikisch G, Mathé AA, Czernik A, et al. Long-term citalopram administration reduces responsiveness of HPA axis in patients with major depression: relationship with S-citalopram concentrations in plasma and cerebrospinal fluid (CSF) and clinical response. Psychopharmacology. Oct. 2005. 2005;181(4):751-60. Source: PsycINFO. [pmid: 15988572].
2436 Nilsen OG, Dale O, Husebo B. Pharmacokinetics of trazodone during multiple dosing to psychiatric patients. Pharmacol Toxicol. Apr-May. 1993;72(4-5):286-9. Source: PubMed. [pmid: 8372048].
2437 Ninan PT. The functional anatomy, neurochemistry, and pharmacology of anxiety. J Clin Psychiatry. Suppl 22. 1999;60:12-7. Source: PubMed. [pmid: 10634350].
2438 Ninan PT. Use of venlafaxine in other psychiatric disorders. Depress Anxiety. Suppl 1. 2000;12:90-4. Source: PubMed. [pmid: 11098421].
2439 Ninan PT, Hassman HA, Glass SJ, et al. Adjunctive modafinil at initiation of treatment with a selective serotonin reuptake inhibitor enhances the degree and onset of therapeutic effects in patients with major depressive disorder and fatigue. J Clin Psychiatry. 2004;65(3):414-20. Source: PubMed. [pmid: 15096082].
2440 Ninan PT, Rush AJ, Crits-Christoph P, et al. Symptomatic and syndromal anxiety in chronic forms of major depression: effect of nefazodone, cognitive behavioral analysis system of psychotherapy, and their combination. J Clin Psychiatry. May. 2002;63(5):434-41. Source: PubMed. [pmid: 12025827].
2441 Nirmalani A, Stock SL, Catalano G. Syndrome of Inappropriate Antidiuretic Hormone Associated with Escitalopram Therapy. CNS Spectrums. Jun. 2006. 2006;11(6):429-32. Source: PsycINFO. [pmid: 16816780].
2442 Nishida T, Wada M, Ito H, et al. Activation syndrome caused by paroxetine in a cancer patient. Palliat Support Care. Jun. 2008;6(2):183-5. Source: PubMed. [pmid: 18501054].
2443 Nofzinger EA, Berman S, Fasiczka A, et al. Effects of bupropion SR on anterior paralimbic function during waking and REM sleep in depression: preliminary findings using. Psychiatry Res. Apr. 10. 2001;106(2):95-111. Source: PubMed. [pmid: 11306249].
2444 Nofzinger EA, Fasiczka A, Berman S, et al. Bupropion SR reduces periodic limb movements associated with arousals from sleep in depressed patients with periodic limb movement disorder. J Clin Psychiatry. Nov. 2000;61(11):858-62. Source: PubMed. [pmid: 11105739].
2445 Nofzinger EA, Reynolds CF 3rd, Thase ME, et al. REM sleep enhancement by bupropion in depressed men. Am J Psychiatry. Feb. 1995;152(2):274-6. Source: PubMed. [pmid: 7840365].
2446 Noguera R, Altuna R, Alvarez E, et al. Fluoxetine vs. clomipramine in depressed patients: a controlled multicentre trial. J Affect Disord. Jul. 1991;22(3):119-24. Source: PubMed. [pmid: 1918655].
2447 Nolen WA, van de Putte JJ, Dijken WA, et al. L-5HTP in depression resistant to re-uptake inhibitors. An open comparative study with tranylcypromine. Br J Psychiatry. Jul. 1985;147:16-22. Source: PubMed. [pmid: 3933601].
2448 Nolen WA, van de Putte JJ, Dijken WA, et al. Treatment strategy in depression. II. MAO inhibitors in depression resistant to cyclic antidepressants: two controlled crossover studies with tranylcypromine versus L-5-hydroxytryptophan and nomifensine. Acta Psychiatr Scand. Dec. 1988;78(6):676-83. Source: PubMed. [pmid: 3146891].
2449 Nolen WA, van de Putte JJ, Dijken WA, et al. Treatment strategy in depression. I. Non-tricyclic and selective reuptake inhibitors in resistant depression: a double-blind partial crossover study on the effects of oxaprotiline and fluvoxamine. Acta Psychiatr Scand. Dec. 1988;78(6):668-75. Source: PubMed. [pmid: 3146890].
2450 Nonacs RM, Soares CN, Viguera AC, et al. Bupropion SR for the treatment of postpartum depression: a pilot study. Int J Neuropsychopharmacol. Sep. 2005;8(3):445-9. Source: PubMed. [pmid: 15817137].
2451 Noorbala AA, Akhondzadeh S, Tahmacebi-Pour N, et al. Hydro-alcoholic extract of Crocus sativus L. versus fluoxetine in the treatment of mild to moderate depression: a double-blind, randomized pilot trial. J Ethnopharmacol. Feb. 28. 2005;97(2):281-4. Source: PubMed. [pmid: 15707766].
2452 Norman GR, Sloan JA, Wyrwich KW. Interpretation of changes in health-related quality of life: the remarkable universality of half a standard deviation. Med Care. May. 2003;41(5):582-92. Source: PubMed. [pmid: 12719681].
2453 Norman TR, Gupta RK, Burrows GD, et al. Relationship between antidepressant response and plasma concentrations of fluoxetine and norfluoxetine. Int Clin Psychopharmacol. Spring. 1993;8(1):25-9. Source: PubMed. [pmid: 8473717].
2454 Normann C, Hesslinger B, Frauenknecht S, et al. Psychosis during chronic levodopa therapy triggered by the new antidepressive drug mirtazapine. Pharmacopsychiatry. Nov. 1997;30(6):263-5. Source: PubMed. [pmid: 9442549].
2455 Normann C, Horn M, Hummel B, et al. Paroxetine in major depression: correlating plasma concentrations and clinical response. Pharmacopsychiatry. May. 2004;37(3):123-6. Source: PubMed. [pmid: 15138896].
2456 Normann C, Hummel B, Scharer LO, et al. Lamotrigine as adjunct to paroxetine in acute depression: a placebo-controlled, double-blind study. J Clin Psychiatry. Apr. 2002;63(4):337-44. Source: PubMed. [pmid: 12000208].
2457 Norris Susan L, Zhang X, Avenell A, et al. Pharmacotherapy for weight loss in adults with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. 2005;(1). Source: The Cochrane Library.
2458 Norton KR, Sireling LI, Bhat AV, et al. A double-blind comparison of fluvoxamine, imipramine and placebo in depressed patients. J Affect Disord. Dec. 1984;7(3-4):297-308. Source: PubMed. [pmid: 6241211].
2459 Norton PJ, Hope DA. Preliminary evaluation of a broad-spectrum cognitive-behavioral group therapy for anxiety. J Behav Ther Exp Psychiatry. Jun. 2005;36(2):79-97. Source: PubMed. [pmid: 15814078].
2460 Nose M, Cipriani A, Furukawa TA, et al. Duloxetine versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2007;(2). Source: Scopus.
2461 Novaretti JPT, Pompeo ACL, Arap S. Selective serotonin uptake inhibitor in the treatment of premature ejaculation. Brazilian Journal of Urology. 2002;28(2):116-22. Source: EMBASE.
2462 Noveske FG, Hahn KR, Flynn RJ. Possible toxicity of combined fluoxetine and lithium. Am J Psychiatry. Nov. 1989;146(11):1515. Source: PubMed. [pmid: 2510522].
2463 Novick JS, Stewart JW, Wisniewski SR, et al. Clinical and demographic features of atypical depression in outpatients with major depressive disorder: preliminary findings from STAR*D. J Clin Psychiatry. Aug. 2005;66(8):1002-11. Source: PubMed. [pmid: 16086615].
2464 Novotny V, Faltus F. Tianeptine and fluoxetine in major depression: a 6-week randomised double-blind study. Hum Psychopharmacol. Aug. 2002;17(6):299-303. Source: PubMed. [pmid: 12404675].
2465 Nowak G, Siwek M, Dudek D, et al. Effect of zinc supplementation on antidepressant therapy in unipolar depression: a preliminary placebo-controlled study. Pol J Pharmacol. Nov-Dec. 2003;55(6):1143-7. Source: PubMed. [pmid: 14730113].
2466 Nulman I, Rovet J, Stewart DE, et al. Neurodevelopment of children exposed in utero to antidepressant drugs. N Engl J Med. Jan. 23. 1997;336(4):258-62. Source: PubMed. [pmid: 8995088].
2467 Nurnberg HG, Fava M, Gelenberg AJ, et al. Open-label sildenafil treatment of partial and non-responders to double-blind treatment in men with antidepressant-associated sexual dysfunction. International Journal of Impotence Research. 2007;19(2):167-75. Source: EMBASE. [pmid: 16871270].
2468 Nurnberg HG, Hensley PL, Heiman JR, et al. Sildenafil treatment of women with antidepressant-associated sexual dysfunction: A randomized controlled trial. JAMA Journal of the American Medical Association. 2008;300(4):395-404. Source: EMBASE.
2469 Nyhuis PW, Gastpar M, Scherbaum N. Opiate treatment in depression refractory to antidepressants and electroconvulsive therapy. Journal of Clinical Psychopharmacology. 2008;28(5):593-5. Source: EMBASE. [pmid: 18794671].
2470 Nyth AL, Gottfries CG, Lyby K, et al. A controlled multicenter clinical study of citalopram and placebo in elderly depressed patients with and without concomitant dementia. Acta Psychiatr Scand. Aug. 1992;86(2):138-45. Source: PubMed. [pmid: 1529737].
2471 Oakley F, Khin NA, Parks R, et al. Improvement in activities of daily living in elderly following treatment for post-bereavement depression. Acta Psychiatr Scand. Mar. 2002;105(3):231-4. Source: PubMed. [pmid: 11939978].
2472 Obenchain RL, Robinson RL, Swindle RW. Cost-effectiveness inferences from bootstrap quadrant confidence levels: three degrees of dominance. J Biopharm Stat. 2005;15(3):419-36. Source: PubMed. [pmid: 15920889].
2473 O'Brien L, Laporte A, Koren G. Estimating the economic costs of antidepressant discontinuation during pregnancy. Canadian Journal of Psychiatry. 2009;54(6):399-408. Source: EMBASE.
2474 O'Brien SM. A possible role of recurrent major depression in risk of fracture. Arch Intern Med. Nov. 26. 2007;167(21):2370. author reply -1. Source: PubMed. [pmid: 18040002].
2475 O'Connor CM, Glassman AH, Harrison DJ. Pharmacoeconomic analysis of sertraline treatment of depression in patients with unstable angina or a recent myocardial infarction. J Clin Psychiatry. Mar. 2005;66(3):346-52. Source: PubMed. [pmid: 15766301].
2476 O'Connor CM, Jiang W, Kuchibhatla M, et al. Safety and efficacy of sertraline for depression in patients with heart failure: Results of the SADHART-CHF (Sertraline against depression and heart disease in chronic heart failure) trial. Journal of the American College of Cardiology. 2010;56(9):692-9. Source: EMBASE. [pmid: 20723799].
2477 O'Flynn K, O'Keane V, Lucey JV, et al. Effect of fluoxetine on noradrenergic mediated growth hormone release: a double blind, placebo-controlled study. Biol Psychiatry. Aug. 15. 1991;30(4):377-82. Source: PubMed. [pmid: 1912129].
2478 Ohishi M, Kamijima K. A comparison of characteristics of depressed patients and efficacy of sertraline and amitriptyline between Japan and the West. J Affect Disord. Jul. 2002;70(2):165-73. Source: PubMed. [pmid: 12117628].
2479 Ohman R, Hagg S, Carleborg L, et al. Excretion of paroxetine into breast milk. J Clin Psychiatry. Aug. 1999;60(8):519-23. Source: PubMed. [pmid: 10485633].
2480 Ohrberg S, Christiansen PE, Severin B, et al. Paroxetine and imipramine in the treatment of depressive patients in psychiatric practice. Acta Psychiatr Scand. Dec. 1992;86(6):437-44. Source: PubMed. [pmid: 1471536].
2481 Okada F, Okajima K. Increased sexual desire during fluvoxamine treatment. Can J Psychiatry. Oct. 2000;45(8):762-3. Source: PubMed. [pmid: 11086562].
2482 O'Keane V, McLoughlin D, Dinan TG. D-fenfluramine-induced prolactin and cortisol release in major depression: response to treatment. J Affect Disord. Nov. 1992;26(3):143-50. Source: PubMed. [pmid: 1460163].
2483 Oktem M, Eroglu D, Karahan HB, et al. Black cohosh and fluoxetine in the treatment of postmenopausal symptoms: A prospective, randomized trial. Advances in Therapy (USA). 02. 01. 2007;24(Feb):448-61. Source: PsycINFO.
2484 Okuda A, Kishi T, Okochi T, et al. Translin-associated factor X gene (TSNAX) may be associated with female major depressive disorder in the Japanese population. Neuromolecular Med. Mar. 2010;12(1):78-85. Source: PubMed. [pmid: 19760522].
2485 Okuda A, Suzuki T, Kishi T, et al. Duration of untreated illness and antidepressant fluvoxamine response in major depressive disorder. Psychiatry Clin Neurosci. Jun. 2010;64(3):268-73. Source: PubMed. [pmid: 20602727].
2486 Okumura T, Kishi T, Okochi T, et al. Genetic association analysis of functional polymorphisms in neuronal nitric oxide synthase 1 gene (NOS1) and mood disorders and fluvoxamine response in major depressive disorder in the Japanese population. Neuropsychobiology. 2010;61(2):57-63. Source: PubMed. [pmid: 20016223].
2487 Olatunji BO, Feldman G, Smits JA, et al. Examination of the decline in symptoms of anxiety and depression in generalized anxiety disorder: impact of anxiety sensitivity on response to pharmacotherapy. Depress Anxiety. 2008;25(2):167-71. Source: PubMed. [pmid: 17335002].
2488 Olfson M, Das AK, Gameroff MJ, et al. Bipolar depression in a low-income primary care clinic. American Journal of Psychiatry. 2005;162(11):2146-51. Source: EMBASE. [pmid: 16263856].
2489 Olfson M, Marcus SC. A case-control study of antidepressants and attempted suicide during early phase treatment of major depressive episodes. Journal of Clinical Psychiatry. 2008;69(3):425-32. Source: EMBASE. [pmid: 18294025].
2490 Olfson M, Marcus SC. National patterns in antidepressant medication treatment. Arch Gen Psychiatry. Aug. 2009;66(8):848-56. Source: PubMed. [pmid: 19652124].
2491 Olfson M, Shaffer D. SSRI prescriptions and the rate of suicide. American Journal of Psychiatry. 2007;164(12):1907-8. Source: Scopus. [pmid: 18056247].
2492 Olfson M, Wilner MT. A family case history of fluoxetine-induced skin reactions. J Nerv Ment Dis. Aug. 1991;179(8):504-5. Source: PubMed. [pmid: 1830329].
2493 Olie JP, Gourion D, Montagne A, et al. Milnacipran and venlafaxine at flexible doses (up to 200 mg/day) in the outpatient treatment of adults with moderate-to-severe major depressive disorder: A 24-week randomized, double-blind exploratory study. Neuropsychiatric Disease and Treatment. 2010;6(1):71-9. Source: EMBASE. [pmid: 20396639].
2494 Olie JP, Gunn KP, Katz E. A double-blind placebo-controlled multicentre study of sertraline in the acute and continuation treatment of major depression. European Psychiatry. 1997;12(1):34-41. Source: EMBASE. [pmid: 19698503].
2495 Olié JP, Kasper S. Efficacy of agomelatine, a MT_1_/MT_2_ receptor agonist with 5-HT [sub]2C[sub] antagonistic properties, in major depressive disorder. International Journal of Neuropsychopharmacology. Oct. 2007. 2007;10(5):661-73. Source: PsycINFO. [pmid: 17477888].
2496 Olie JP, Tonnoir B, Menard F, et al. A prospective study of escitalopram in the treatment of major depressive episodes in the presence or absence of anxiety. Depress Anxiety. 2007;24(5):318-24. Source: PubMed. [pmid: 17041922].
2497 Olivera AO. Sertraline and akathisia: spontaneous resolution. Biol Psychiatry. Jan. 15. 1997;41(2):241-2. Source: PubMed. [pmid: 9018398].
2498 Olver JS, Burrows GD, Norman TR. The treatment of depression with different formulations of venlafaxine: a comparative analysis. Hum Psychopharmacol. Jan. 2004;19(1):9-16. Source: PubMed. [pmid: 14716706].
2499 Omori I, Watanabe N, Nakagawa A, et al. Fluvoxamine versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2006;(3). Source: Scopus.
2500 Omori Ichiro M, Wang J. Sulpiride versus placebo for schizophrenia. Cochrane Database of Systematic Reviews. 2009;(2). Source: The Cochrane Library.
2501 Omori Ichiro M, Watanabe N, Nakagawa A, et al. Fluvoxamine versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2010;(3). Source: The Cochrane Library.
2502 Omori IM, Watanabe N, Nakagawa A, et al. Efficacy, tolerability and side-effect profile of fluvoxamine for major depression: Meta-analysis. Journal of Psychopharmacology. 2009;23(5):539-50. Source: PsycINFO. [pmid: 18562407].
2503 Onder E, Tural U. Faster response in depressive patients treated with fluoxetine alone than in combination with buspirone. J Affect Disord. Sep. 2003;76(1-3):223-7. Source: PubMed. [pmid: 12943952].
2504 Ong MK, Rubenstein LV. Wishing upon a STAR*D: the promise of ideal depression care by primary care providers. Psychiatr Serv. Nov. 2009;60(11):1460-2. Source: PubMed. [pmid: 19880461].
2505 Ontiveros A, Fontaine R, Elie R. Refractory depression: the addition of lithium to fluoxetine or desipramine. Acta Psychiatr Scand. Mar. 1991;83(3):188-92. Source: PubMed. [pmid: 1903237].
2506 Orengo CA, Kunik ME, Molinari V, et al. The use and tolerability of fluoxetine in geropsychiatric inpatients. J Clin Psychiatry. Jan. 1996;57(1):12-6. Source: PubMed. [pmid: 8543541].
2507 Orsel Donbak S, Turkcapar MH, Ozturk Kilic EZ, et al. Moclobemide and sertraline in the treatment of depressive disorders: a comparative study. Acta Psychiatr Belg. May-Jun. 1995;95(3):139-51. Source: PubMed. [pmid: 8525856].
2508 Ose BL, Pandurangi AK, Gorman JM. Delusional wife: a case of diagnostic ambiguity and treatment challenge. J Psychiatr Pract. May. 2005;11(3):205-11. Source: PubMed. [pmid: 15920395].
2509 Oslin DW. Treatment of late-life depression complicated by alcohol dependence. Am J Geriatr Psychiatry. Jun. 2005;13(6):491-500. Source: PubMed. [pmid: 15956269].
2510 Oslin DW, Streim JE, Katz IR, et al. Heuristic comparison of sertraline with nortriptyline for the treatment of depression in frail elderly patients. Am J Geriatr Psychiatry. Spring. 2000;8(2):141-9. Source: PubMed. [pmid: 10804075].
2511 Oslin DW, Ten Have TR, Streim JE, et al. Probing the safety of medications in the frail elderly: evidence from a randomized clinical trial of sertraline and venlafaxine in depressed nursing home residents. J Clin Psychiatry. Aug. 2003;64(8):875-82. Source: PubMed. [pmid: 12927001].
2512 Otani K, Yasui N, Kaneko S, et al. Trazodone treatment increases plasma prolactin concentrations in depressed patients. Int Clin Psychopharmacol. Jun. 1995;10(2):115-7. Source: PubMed. [pmid: 7673654].
2513 Otero FJ, Hernandez HC, Martinez AMJ, et al. Fluoxetine/bentazepam combination in the treatment of dysthymic disorders. Ther Res Clin Exp. May. 1994;55(5):519-31. Source: EMBASE.
2514 Othmer E, Othmer SC, Stern WC, et al. Long-term efficacy and safety of bupropion. J Clin Psychiatry. May. 1983;44(5 Pt 2):153-6. Source: PubMed. [pmid: 6406448].
2515 Othmer SC, Othmer E, Preskorn SH, et al. Differential effect of amitriptyline and bupropion on primary and secondary depression: a pilot study. J Clin Psychiatry. Aug. 1988;49(8):310-2. Source: PubMed. [pmid: 3137218].
2516 Otsubo T, Akimoto Y, Yamada H, et al. A comparative study of the efficacy and safety profiles between fluvoxamine and nortriptyline in Japanese patients with major depression. Pharmacopsychiatry. Jan. 2005;38(1):30-5. Source: PubMed. [pmid: 15706464].
2517 Ott GE, Rao U, Lin KM, et al. Effect of treatment with bupropion on EEG sleep: relationship to antidepressant response. Int J Neuropsychopharmacol. Sep. 2004;7(3):275-81. Source: PubMed. [pmid: 15122973].
2518 Ott GE, Rao U, Nuccio I, et al. Effect of bupropion-SR on REM sleep: relationship to antidepressant response. Psychopharmacology (Berl). Dec. 2002;165(1):29-36. Source: PubMed. [pmid: 12474115].
2519 Otte C, Hinkelmann K, Moritz S, et al. Modulation of the mineralocorticoid receptor as add-on treatment in depression: a randomized, double-blind, placebo-controlled proof-of-concept study. J Psychiatr Res. Apr. 2010;44(6):339-46. Source: PubMed. [pmid: 19909979].
2520 Ottevanger EA. The efficacy of fluvoxamine in patients with severe depression. Prog Neuropsychopharmacol Biol Psychiatry. Jul. 1994;18(4):731-40. Source: PubMed. [pmid: 7938563].
2521 Ottevanger EA. Fluvoxamine and clomipramine in depressed hospitalised patients: results from a randomised, double-blind study. Encephale. Jul-Aug. 1995;21(4):317-21. Source: PubMed. [pmid: 7588171].
2522 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. Source: PubMed. [pmid: 19595577].
2523 Owens MJ, Krulewicz S, Simon JS, et al. Estimates of serotonin and norepinephrine transporter inhibition in depressed patients treated with paroxetine or venlafaxine. Neuropsychopharmacology. 2008;33(13):3201-12. Source: PubMed. [pmid: 18418363].
2524 Oxman TE, Barrett JE, Sengupta A, et al. Status of minor depression or dysthymia in primary care following a randomized controlled treatment. Gen Hosp Psychiatry. Nov-Dec. 2001;23(6):301-10. Source: PubMed. [pmid: 11738460].
2525 Oxman TE, Hull JG. Social support and treatment response in older depressed primary care patients. J Gerontol B Psychol Sci Soc Sci. Jan. 2001;56(1):P35-45. Source: PubMed. [pmid: 11192336].
2526 Ozcanli T, Unsalver B, Ozdemir S, et al. Sertraline- and Mirtazapine-Induced Severe Neutropenia. The American Journal of Psychiatry. Jul. 2005;162(7):1386. Source: PsycINFO. [pmid: 15994730].
2527 Ozdemir S, Yalug I, Aker AT. Serotonin syndrome associated with sertraline monotherapy at therapeutic doses. Prog Neuropsychopharmacol Biol Psychiatry. Apr. 1. 2008;32(3):897-8. Source: PubMed. [pmid: 18077070].
2528 Ozmenler NK, Karlidere T, Bozkurt A, et al. Mirtazapine augmentation in depressed patients with sexual dysfunction due to selective serotonin reuptake inhibitors. Hum Psychopharmacol. Jun. 2008;23(4):321-6. Source: PubMed. [pmid: 18278806].
2529 Packer S, Berman SA. Serotonin syndrome precipitated by the monoamine oxidase inhibitor linezolid. Am J Psychiatry. Feb. 2007;164(2):346-7. Source: PubMed. [pmid: 17267801].
2530 Paclt I, Slavicek J, Dohnalova A, et al. Electrocardiographic dose-dependent changes in prophylactic doses of dosulepine, lithium and citalopram. Physiol Res. 2003;52(3):311-7. Source: PubMed. [pmid: 12790762].
2531 Padala KP, Padala PR, Malloy T, et al. New onset multimodal hallucinations associated with mirtazapine: A case report. International Psychogeriatrics. 2010;22(5):837-9. Source: PsycINFO. [pmid: 20500925].
2532 Paddock S, Laje G, Charney D, et al. Association of GRIK4 with outcome of antidepressant treatment in the STAR*D cohort. Am J Psychiatry. Aug. 2007;164(8):1181-8. Source: PubMed. [pmid: 17671280].
2533 Pae CU. Comments on ‘Association study of the serotonin transporter promoter polymorphism and mirtazapine antidepressant response in major depressive disorder ’. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Feb. 2008. 2008;32(2):597-8. Source: PsycINFO. [pmid: 17919799].
2534 Pae CU, Bahk WM, Jon DI, et al. Effectiveness and tolerability of paroxetine controlled release (CR) in the treatment of major depressive disorder: an open-label, prospective, multi-center trial in Korea. Hum Psychopharmacol. Aug. 2007;22(6):351-9. Source: PubMed. [pmid: 17487934].
2535 Pae CU, Kim JJ, Lee CU, et al. Injured temporomandibular joint associated with fluoxetine-monotherapy-induced repeated yawning. Gen Hosp Psychiatry. May-Jun. 2003;25(3):217-8. Source: PubMed. [pmid: 12748036].
2536 Pae CU, Kim YJ, Won WY, et al. Paroxetine in the treatment of depressed patients with haematological malignancy: an open-label study. Hum Psychopharmacol. Jan. 2004;19(1):25-9. Source: PubMed. [pmid: 14716708].
2537 Pae CU, Lim HK, Ajwani N, et al. Extended-release formulation of venlafaxine in the treatment of post-traumatic stress disorder. Expert Review of Neurotherapeutics. 2007;7(6):603-15. Source: Scopus. [pmid: 17563244].
2538 Pae CU, Marks DM, Shah M, et al. Milnacipran: beyond a role of antidepressant. Clin Neuropharmacol. Nov-Dec. 2009;32(6):355-63. Source: PubMed. [pmid: 19620845].
2539 Pae CU, Park MH, Marks DM, et al. Desvenlafaxine, a serotonin-norepinephrine uptake inhibitor for major depressive disorder, neuropathic pain and the vasomotor symptoms associated with menopause. Curr Opin Investig Drugs. Jan. 2009;10(1):75-90. Source: PubMed.
2540 Pae CU, Patkar AA, Jun TY, et al. Aripiprazole augmentation for treatment of patients with inadequate antidepressants response. Depression and Anxiety. 2007;24(7):522-6. Source: EMBASE. [pmid: 17111388].
2541 Pae CU, Serretti A, Mandelli L, et al. Dysbindin associated with selective serotonin reuptake inhibitor antidepressant efficacy. Pharmacogenetics and Genomics. 2007;17(1):69-75. Source: EMBASE. [pmid: 17264804].
2542 Pae CU, Drago A, Kim JJ, et al. TAAR6 variations possibly associated with antidepressant response and suicidal behavior. Psychiatry Research. 2010;180(1):20-4. Source: PsycINFO. [pmid: 20493543].
2543 Paige SR, Hendricks SE, Fitzpatrick DF, et al. Amplitude/intensity functions of auditory event-related potentials predict responsiveness to bupropion in major depressive disorder. Psychopharmacol Bull. 1995;31(2):243-8. Source: PubMed. [pmid: 7491375].
2544 Pakesch G, Dossenbach M. Efficacy and safety of fluoxetine versus clomipramine in the treatment of outpatients with depression in a clinical trial in private practice. Wiener Klinische Wochenschrift. 1991;103(6):176-82. Source: EMBASE. [pmid: 2035279].
2545 Pallanti S, Quercioli L, Bruscoli M. Response acceleration with mirtazapine augmentation of citalopram in obsessive-compulsive disorder patients without comorbid depression: a pilot study. J Clin Psychiatry. Oct. 2004;65(10):1394-9. Source: PubMed. [pmid: 15491244].
2546 Palomaki H, Kaste M, Berg A, et al. Prevention of poststroke depression: 1 year randomised placebo controlled double blind trial of mianserin with 6 month follow up after therapy. J Neurol Neurosurg Psychiatry. Apr. 1999;66(4):490-4. Source: PubMed. [pmid: 10201422].
2547 Pan JJ, Shen WW. Serotonin syndrome induced by low-dose venlafaxine. Ann Pharmacother. Feb. 2003;37(2):209-11. Source: PubMed. [pmid: 12549949].
2548 Pande AC, Birkett M, Fechner-Bates S, et al. Fluoxetine versus phenelzine in atypical depression. Biol Psychiatry. Nov. 15. 1996;40(10):1017-20. Source: PubMed. [pmid: 8915561].
2549 Pande AC, Sayler ME. Severity of depression and response to fluoxetine. Int Clin Psychopharmacol. Winter. 1993;8(4):243-5. Source: PubMed. [pmid: 8277142].
2550 Pani Pier P, Vacca R, Trogu E, et al. Pharmacological treatment for depression during opioid agonist treatment for opioid dependence. Cochrane Database of Systematic Reviews. 2010;(9). Source: The Cochrane Library.
2551 Panzarino PJ Jr, Xuan J. Economic evaluation of major selective serotonin-reuptake inhibitors in a managed care population. Manag Care Interface. Apr. 2001;14(4):59-65. Source: PubMed. [pmid: 11339023].
2552 Panzer MJ. Are SSRIs really more effective for anxious depression?. Ann Clin Psychiatry. Jan-Mar. 2005;17(1):23-9. Source: PubMed. [pmid: 15941028].
2553 Panzer PE, Regan TS, Chiao E, et al. Implications of an SSRI generic step therapy pharmacy benefit design: an economic model in anxiety disorders. Am J Manag Care. Oct. 2005;11(12 Suppl):S370-9. Source: PubMed. [pmid: 16236019].
2554 Panzer PG, Fullilove MT. Belinda's puzzle: assembling the pieces of an illness. Am J Psychiatry. May. 1997;154(5):677-80. Source: PubMed. [pmid: 9137125].
2555 Papadimitriou GN, Theleritis CG, Papageorgiou CC, et al. Acute adverse cutaneous reaction after the concomitant use of venlafaxine and orphenadrine citrate plus paracetamol in a depressed patient. J Eur Acad Dermatol Venereol. Sep. 2006;20(8):1019. Source: PubMed. [pmid: 16922966].
2556 Papakostas GI. Dopaminergic-based pharmacotherapies for depression. European Neuropsychopharmacology. 2006;16(6):391-402. Source: Scopus. [pmid: 16413172].
2557 Papakostas GI, Chuzi SE, Sousa JL, et al. 5HT1A-mediated stimulation of cortisol release in major depression: use of non-invasive cortisol measurements to predict clinical response. Eur Arch Psychiatry Clin Neurosci. Mar. 2010;260(2):175-80. Source: PubMed. [pmid: 19641981].
2558 Papakostas GI, Clain A, Ameral VE, et al. Fluoxetine-clonazepam cotherapy for anxious depression: an exploratory, post-hoc analysis of a randomized, double blind study. Int Clin Psychopharmacol. 2010;25(1):17-21. Source: PubMed. [pmid: 19898245].
2559 Papakostas GI, Crawford CM, Scalia MJ, et al. Timing of clinical improvement and symptom resolution in the treatment of major depressive disorder. A replication of findings with the use of a double-blind, placebo-controlled trial of Hypericum perforatum versus fluoxetine. Neuropsychobiology. 2007;56(2-3):132-7. Source: PubMed. [pmid: 18259086].
2560 Papakostas GI, Fava M. Monoamine-based pharmacotherapy. Biology of Depression: From Novel Insights to Therapeutic Strategies. 2005:87-140. Source: Scopus.
2561 Papakostas GI, Homberger CH, Fava M. A meta-analysis of clinical trials comparing mirtazapine with selective serotonin reuptake inhibitors for the treatment of major depressive disorder. J Psychopharmacol. 2008;22(8):843-8. Source: PubMed. [pmid: 18308801].
2562 Papakostas GI, Iosifescu DV, Petersen T, et al. Serum cholesterol in the continuation phase of pharmacotherapy with fluoxetine in remitted major depressive disorder. J Clin Psychopharmacol. Aug. 2004;24(4):467-9. Source: PubMed. [pmid: 15232350].
2563 Papakostas GI, Kornstein SG, Clayton AH, et al. Relative antidepressant efficacy of bupropion and the selective serotonin reuptake inhibitors in major depressive disorder: gender-age interactions. Int Clin Psychopharmacol. 2007;22(4):226-9. Source: PubMed. [pmid: 17519646].
2564 Papakostas GI, McGrath P, Stewart J, et al. Psychic and somatic anxiety symptoms as predictors of response to fluoxetine in major depressive disorder. Psychiatry Res. Oct. 30. 2008;161(1):116-20. Source: PubMed. [pmid: 18755514].
2565 Papakostas GI, Mischoulon D, Shyu I, et al. S-adenosyl methionine (SAMe) augmentation of serotonin reuptake inhibitors for antidepressant nonresponders with major depressive disorder: A double-blind, randomized clinical trial. American Journal of Psychiatry. 2010;167(8):942-8. Source: EMBASE. [pmid: 20595412].
2566 Papakostas GI, Montgomery SA, Thase ME, et al. Comparing the rapidity of response during treatment of major depressive disorder with bupropion and the SSRIs: a pooled survival analysis of 7 double-blind, randomized clinical trials. J Clin Psychiatry. Dec. 2007;68(12):1907-12. Source: PubMed. [pmid: 18162022].
2567 Papakostas GI, Nutt DJ, Hallett LA, et al. Resolution of sleepiness and fatigue in major depressive disorder: A comparison of bupropion and the selective serotonin reuptake inhibitors. Biol Psychiatry. 2006;60(12):1350-5. Source: PubMed. [pmid: 16934768].
2568 Papakostas GI, Petersen T, Denninger JW, et al. Treatment-related adverse events and outcome in a clinical trial of fluoxetine for major depressive disorder. Ann Clin Psychiatry. Sep-Dec. 2003;15(3-4):187-92. Source: PubMed. [pmid: 14971864].
2569 Papakostas GI, Petersen T, Denninger JW, et al. Psychosocial functioning during the treatment of major depressive disorder with fluoxetine. J Clin Psychopharmacol. Oct. 2004;24(5):507-11. Source: PubMed. [pmid: 15349006].
2570 Papakostas GI, Petersen T, Hughes ME, et al. Anxiety and somatic symptoms as predictors of treatment-related adverse events in major depressive disorder. Psychiatry Res. May. 30. 2004;126(3):287-90. Source: PubMed. [pmid: 15157754].
2571 Papakostas GI, Petersen T, Iosifescu DV, et al. Obesity among outpatients with major depressive disorder. Int J Neuropsychopharmacol. Mar. 2005;8(1):59-63. Source: PubMed. [pmid: 15361263].
2572 Papakostas GI, Petersen T, Mischoulon D, et al. Serum folate, vitamin B12, and homocysteine in major depressive disorder, Part 2: predictors of relapse during the continuation phase of pharmacotherapy. J Clin Psychiatry. Aug. 2004;65(8):1096-8. Source: PubMed. [pmid: 15323595].
2573 Papakostas GI, Petersen T, Mischoulon D, et al. Serum folate, vitamin B12, and homocysteine in major depressive disorder, Part 1: predictors of clinical response in fluoxetine-resistant depression. J Clin Psychiatry. Aug. 2004;65(8):1090-5. Source: PubMed. [pmid: 15323594].
2574 Papakostas GI, Petersen T, Worthington JJ, et al. A pilot, open study of sertraline in outpatients with treatment-resistant depression (TRD) or with a history of TRD who responded but later relapsed. Int Clin Psychopharmacol. Sep. 2003;18(5):293-6. Source: PubMed. [pmid: 12920390].
2575 Papakostas GI, Petersen TJ, Iosifescu DV, et al. Somatic symptoms as predictors of time to onset of response to fluoxetine in major depressive disorder. J Clin Psychiatry. Apr. 2004;65(4):543-6. Source: PubMed. [pmid: 15119918].
2576 Papakostas GI, Thase ME, Fava M, et al. Are Antidepressant Drugs That Combine Serotonergic and Noradrenergic Mechanisms of Action More Effective Than the Selective Serotonin Reuptake Inhibitors in Treating Major Depressive Disorder? A Meta-analysis of Studies of Newer Agents. Biological Psychiatry. 2007;62(11):1217-27. Source: Scopus. [pmid: 17588546].
2577 Papakostas GI, Trivedi MH, Alpert JE, et al. Efficacy of bupropion and the selective serotonin reuptake inhibitors in the treatment of anxiety symptoms in major depressive disorder: a meta-analysis of individual patient data from 10 double-blind, randomized clinical trials. J Psychiatr Res. Jan. 2008;42(2):134-40. Source: PubMed. [pmid: 17631898].
2578 Papakostas GI, Worthington JJ 3rd, Iosifescu DV, et al. The combination of duloxetine and bupropion for treatment-resistant major depressive disorder. Depress Anxiety. 2006;23(3):178-81. Source: PubMed. [pmid: 16528701].
2579 Papakostas YG, Markianos M, Zervas IM, et al. Administration of citalopram before ECT: seizure duration and hormone responses. J Ect. Dec. 2000;16(4):356-60. Source: PubMed. [pmid: 11314873].
2580 Papiol S, Arias B, Gasto C, et al. Genetic variability at HPA axis in major depression and clinical response to antidepressant treatment. J Affect Disord. Dec. 2007;104(1-3):83-90. Source: PubMed. [pmid: 17467808].
2581 Parikh AR, Thatcher BT, Tamano EA, et al. Suicidal ideation associated with duloxetine use: a case series. J Clin Psychopharmacol. Feb. 2008;28(1):101-2. Source: PubMed. [pmid: 18204351].
2582 Parish SJ. Challenges in the identification and management of HSDD. J Fam Pract. Jul. 2009;58(7 Suppl Hypoactive):S31-2. Source: PubMed. [pmid: 19825317].
2583 Park YM, Lee HJ, Kang SG, et al. Tardive dyskinesia associated with long-term administration of escitalopram and itopride in major depressive disorder. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 17. 2009;33(2):380-1. Source: PubMed. [pmid: 19121360].
2584 Parker G. Differential effectiveness of newer and older antidepressants appears mediated by an age effect on the phenotypic expression of depression. Acta Psychiatr Scand. Sep. 2002;106(3):168-70. Source: PubMed. [pmid: 12197852].
2585 Parker G, Brotchie H, Parker K. Is combination olanzapine and antidepressant medication associated with a more rapid response trajectory than antidepressant alone?. American Journal of Psychiatry. 2005;162(4):796-8. Source: EMBASE. [pmid: 15800157].
2586 Parker G, Malhi G. Are atypical antipsychotic drugs also atypical antidepressants?. Aust N Z J Psychiatry. Oct. 2001;35(5):631-8. Source: PubMed. [pmid: 11551279].
2587 Parker G, Parker K, Austin MP, et al. Gender differences in response to differing antidepressant drug classes: two negative studies. Psychol Med. Nov. 2003;33(8):1473-7. Source: PubMed. [pmid: 14672256].
2588 Parker G, Tully L, Olley A, et al. SSRIs as mood stabilizers for Bipolar II Disorder? A proof of concept study. J Affect Disord. Jun. 2006;92(2-3):205-14. Source: PubMed. [pmid: 16516304].
2589 Parrino L, Spaggiari MC, Boselli M, et al. Clinical and polysomnographic effects of trazodone CR in chronic insomnia associated with dysthymia. Psychopharmacology (Berl). Dec. 1994;116(4):389-95. Source: PubMed. [pmid: 7701038].
2590 Parry BL. Perimenopausal depression. Am J Psychiatry. Jan. 2008;165(1):23-7. Source: PubMed. [pmid: 18178752].
2591 Partonen T, Lonnqvist J. Moclobemide and fluoxetine in treatment of seasonal affective disorder. J Affect Disord. Nov. 25. 1996;41(2):93-9. Source: PubMed. [pmid: 8961036].
2592 Partonen T, Sihvo S, Lonnqvist JK. Patients excluded from an antidepressant efficacy trial. Journal Of Clinical Psychiatry. 1996;57(12):572-5. Source: EMBASE. [pmid: 9010119].
2593 Pasco J. Emergency medicine. Is this a drug reaction?. Aust Fam Physician. May. 1998;27(5):409. Source: PubMed. [pmid: 9613007].
2594 Paslakis G, Gilles M, Meyer-Lindenberg A, et al. Oral administration of the NMDA receptor antagonist S-ketamine as add-on therapy of depression: A case series. Pharmacopsychiatry. 2010;43(1):33-5. Source: EMBASE. [pmid: 20013614].
2595 Paslakis G, Luppa P, Gilles M, et al. Venlafaxine and mirtazapine treatment lowers serum concentrations of dehydroepiandrosterone-sulfate in depressed patients remitting during the course of treatment. Journal of psychiatric research. 2010;44(8):556-60. Source: EMBASE. [pmid: 20022345].
2596 Pasquini M, Biondi M, Costantini A, et al. Detection and treatment of depressive and anxiety disorders among cancer patients: feasibility and preliminary findings from a liaison service in an oncology division. Depress Anxiety. 2006;23(7):441-8. Source: PubMed. [pmid: 16841345].
2597 Patankar TF, Baldwin R, Mitra D, et al. Virchow-Robin space dilatation may predict resistance to antidepressant monotherapy in elderly patients with depression. Journal of Affective Disorders. 2007;97(1-3):265-70. Source: EMBASE. [pmid: 16919335].
2598 Patel V, Weiss HA, Chowdhary N, et al. Effectiveness of an intervention led by lay health counsellors for depressive and anxiety disorders in primary care in Goa, India (MANAS): a cluster randomised controlled trial. Lancet. Dec. 18. 2010;376(9758):2086-95. Source: PubMed. [pmid: 21159375].
2599 Patkar AA, Masand PS, Pae CU, et al. A randomized, double-blind, placebo-controlled trial of augmentation with an extended release formulation of methylphenidate in outpatients with treatment-resistant depression. Journal of Clinical Psychopharmacology. 2006;26(6):653-6. Source: EMBASE. [pmid: 17110825].
2600 Paton C, Ferrier IN. SSRIs and gastrointestinal bleeding. Bmj. Sep. 10. 2005;331(7516):529-30. Source: PubMed. [pmid: 16150746].
2601 Patris M, Bouchard JM, Bougerol T, et al. Citalopram versus fluoxetine: a double-blind, controlled, multicentre, phase III trial in patients with unipolar major depression treated in general practice. Int Clin Psychopharmacol. Jun. 1996;11(2):129-36. Source: PubMed. [pmid: 8803650].
2602 Patten CA, Rummans TA, Croghan IT, et al. Development of depression during placebo-controlled trials of bupropion for smoking cessation: case reports. J Clin Psychiatry. Jul. 1999;60(7):436-41. Source: PubMed. [pmid: 10453796].
2603 Patten SB, Wang JL, Williams JVA, et al. Frequency of antidepressant use in relation to recent and past major depressive episodes. Canadian Journal of Psychiatry. 2010;55(8):532-5. Source: EMBASE.
2604 Paykel ES, Scott J, Teasdale JD, et al. Prevention of relapse in residual depression by cognitive therapy: a controlled trial. Arch Gen Psychiatry. Sep. 1999;56(9):829-35. Source: PubMed. [pmid: 12884889].
2605 Pearlstein TB, Stone AB. Long-term fluoxetine treatment of late luteal phase dysphoric disorder. J Clin Psychiatry. Aug. 1994;55(8):332-5. Source: PubMed. [pmid: 8071300].
2606 Pearson HJ. Interaction of fluoxetine with carbamazepine. J Clin Psychiatry. Mar. 1990;51(3):126. Source: PubMed. [pmid: 2353956].
2607 Pedersen AG. Escitalopram and suicidality in adult depression and anxiety. Int Clin Psychopharmacol. May. 2005;20(3):139-43. Source: PubMed. [pmid: 15812263].
2608 Pedersen AG. Citalopram and suicidality in adult major depression and anxiety disorders. Nordic Journal of Psychiatry. 2006;60(5):392-9. Source: Scopus. [pmid: 17038305].
2609 Pedersen LH, Henriksen TB, Olsen J. Fetal exposure to antidepressants and normal milestone development at 6 and 19 months of age. Pediatrics. 2010;125(3):e600-e8. Source: EMBASE. [pmid: 20176667].
2610 Pedersen LH, Henriksen TB, Vestergaard M, et al. Selective serotonin reuptake inhibitors in pregnancy and congenital malformations: population based cohort study. Bmj. 2009;339:b3569. Source: PubMed. [pmid: 19776103].
2611 Pedersen OL, Kragh-Sorensen P, Bjerre M, et al. Citalopram, a selective serotonin reuptake inhibitor: clinical antidepressive and long-term effect--a phase II study. Psychopharmacology (Berl). 1982;77(3):199-204. Source: PubMed. [pmid: 6812140].
2612 Peeters F, Berkhof J, Rottenberg J, et al. Ambulatory emotional reactivity to negative daily life events predicts remission from major depressive disorder. Behaviour Research and Therapy. 2010;48(8):754-60. Source: EMBASE. [pmid: 20537317].
2613 Pelicier Y, Schaeffer P. A multi-centre, double-blind study to compare the efficacy and tolerability of paroxetine and clomipramine in elderly patients with reactive depression. <ORIGINAL>. ETUDE MULTICENTRIQUE EN DOUBLE AVEUGLE COMPARENT L'EFFICACITE ET LA TOLERANCE DE LA PAROXETINE ET DE LA CLOMIPRAMINE DANS LA DEPRESSION REACTIONNELLE DU SUJET AGE. Encephale. 1993;19(3):257-61. Source: EMBASE. [pmid: 8275912].
2614 Pelton GH, Harper OL, Tabert MH, et al. Randomized double-blind placebo-controlled donepezil augmentation in antidepressant-treated elderly patients with depression and cognitive impairment: a pilot study. Int J Geriatr Psychiatry. Jul. 2008;23(7):670-6. Source: PubMed. [pmid: 18088076].
2615 Perahia DG, Gilaberte I, Wang F, et al. Duloxetine in the prevention of relapse of major depressive disorder: double-blind placebo-controlled study. Br J Psychiatry. 2006:188346-53. Source: PubMed.
2616 Perahia DG, Kajdasz DK, Desaiah D, et al. Symptoms following abrupt discontinuation of duloxetine treatment in patients with major depressive disorder. J Affect Disord. Dec. 2005;89(1-3):207-12. Source: PubMed. [pmid: 16266753].
2617 Perahia DG, Kajdasz DK, Royer MG, et al. Duloxetine in the treatment of major depressive disorder: an assessment of the relationship between outcomes and episode characteristics. Int Clin Psychopharmacol. 2006;21(5):285-95. Source: PubMed. [pmid: 16877900].
2618 Perahia DG, Kajdasz DK, Walker DJ, et al. Duloxetine 60 mg once daily in the treatment of milder major depressive disorder. Int J Clin Pract. 2006;60(5):613-20. Source: PubMed. [pmid: 16700869].
2619 Perahia DG, Maina G, Thase ME, et al. Duloxetine in the prevention of depressive recurrences: a randomized, double-blind, placebo-controlled trial. J Clin Psychiatry. 2009;70(5):706-16. Source: PubMed. [pmid: 19552867].
2620 Perahia DG, Pritchett YL, Kajdasz DK, et al. A randomized, double-blind comparison of duloxetine and venlafaxine in the treatment of patients with major depressive disorder. J Psychiatr Res. 2008;42(1):22-34. Source: PubMed. [pmid: 17445831].
2621 Perahia DG, Quail D, Desaiah D, et al. Switching to duloxetine from selective serotonin reuptake inhibitor antidepressants: a multicenter trial comparing 2 switching techniques. J Clin Psychiatry. Jan. 2008;69(1):95-105. Source: PubMed. [pmid: 18312043].
2622 Perahia DG, Quail D, Desaiah D, et al. Switching to duloxetine in selective serotonin reuptake inhibitor non- and partial-responders: effects on painful physical symptoms of depression. J Psychiatr Res. Feb. 2009;43(5):512-8. Source: PubMed. [pmid: 18707693].
2623 Perahia DG, Quail D, Gandhi P, et al. A randomized, controlled trial of duloxetine alone vs. duloxetine plus a telephone intervention in the treatment of depression. J Affect Disord. May. 2008;108(1-2):33-41. Source: PubMed. [pmid: 17905442].
2624 Perahia DG, Wang F, Mallinckrodt CH, et al. Duloxetine in the treatment of major depressive disorder: a placebo- and paroxetine-controlled trial. Eur Psychiatry. 2006;21(6):367-78. Source: PubMed. [pmid: 16697153].
2625 Perahia DGS, Pritchett YL, Desaiah D, et al. Efficacy of duloxetine in painful symptoms: An analgesic or antidepressant effect?. International Clinical Psychopharmacology. Nov. 2006. 2006;21(6):311-7. Source: PsycINFO. [pmid: 17012978].
2626 Perez A, Ashford JJ. A double-blind, randomized comparison of fluvoxamine with mianserin in depressive illness. Curr Med Res Opin. 1990;12(4):234-41. Source: PubMed. [pmid: 2127561].
2627 Perez V, Bel N, Celada P, et al. Relationship between blood serotonergic variables, melancholic traits, and response to antidepressant treatments. J Clin Psychopharmacol. Jun. 1998;18(3):222-30. Source: PubMed. [pmid: 9617981].
2628 Perez V, Puiigdemont D, Gilaberte I, et al. Augmentation of fluoxetine's antidepressant action by pindolol: analysis of clinical, pharmacokinetic, and methodologic factors. J Clin Psychopharmacol. Feb. 2001;21(1):36-45. Source: PubMed. [pmid: 11199945].
2629 Perez V, Soler J, Puigdemont D, et al. A double-blind, randomized, placebo-controlled trial of pindolol augmentation in depressive patients resistant to serotonin reuptake inhibitors. Grup de Recerca en Trastorns Afectius. Arch Gen Psychiatry. Apr. 1999;56(4):375-9. Source: PubMed. [pmid: 10197835].
2630 Perlis RH, Adams DH, Fijal B, et al. Genetic association study of treatment response with olanzapine/fluoxetine combination or lamotrigine in bipolar I depression. Journal of Clinical Psychiatry. 2010;71(5):599-605. Source: EMBASE. [pmid: 20021991].
2631 Perlis RH, Alpert J, Nierenberg AA, et al. Clinical and sociodemographic predictors of response to augmentation, or dose increase among depressed outpatients resistant to fluoxetine 20 mg/day. Acta Psychiatr Scand. Dec. 2003;108(6):432-8. Source: PubMed. [pmid: 14616224].
2632 Perlis RH, Beasley CM Jr, Wines JD Jr, et al. Treatment-associated suicidal ideation and adverse effects in an open, multicenter trial of fluoxetine for major depressive episodes. Psychother Psychosom. 2007;76(1):40-6. Source: PubMed. [pmid: 17170562].
2633 Perlis RH, Fava M, Trivedi MH, et al. Irritability is associated with anxiety and greater severity, but not bipolar spectrum features, in major depressive disorder. Acta Psychiatr Scand. Apr. 2009;119(4):282-9. Source: PubMed. [pmid: 19207123].
2634 Perlis RH, Fijal B, Adams DH, et al. Variation in catechol-O-methyltransferase is associated with duloxetine response in a clinical trial for major depressive disorder. Biol Psychiatry. May. 1. 2009;65(9):785-91. Source: PubMed. [pmid: 19095219].
2635 Perlis RH, Fijal B, Dharia S, et al. Failure to replicate genetic associations with antidepressant treatment response in duloxetine-treated patients. Biol Psychiatry. Jun. 1. 2010;67(11):1110-3. Source: PubMed. [pmid: 20110084].
2636 Perlis RH, Fraguas R, Fava M, et al. Prevalence and clinical correlates of irritability in major depressive disorder: a preliminary report from the Sequenced Treatment Alternatives to Relieve Depression study. J Clin Psychiatry. Feb. 2005;66(2):159-66. quiz 47, 273-4. Source: PubMed. [pmid: 15705000].
2637 Perlis RH, Iosifescu DV, Alpert J, et al. Effect of medical comorbidity on response to fluoxetine augmentation or dose increase in outpatients with treatment-resistant depression. Psychosomatics. May-Jun. 2004;45(3):224-9. Source: PubMed. [pmid: 15123848].
2638 Perlis RH, Moorjani P, Fagerness J, et al. Pharmacogenetic analysis of genes implicated in rodent models of antidepressant response: association of TREK1 and treatment resistance in the STAR(*)D study. Neuropsychopharmacology. Nov. 2008;33(12):2810-9. Source: PubMed. [pmid: 18288090].
2639 Perlis RH, Nierenberg AA, Alpert JE, et al. Effects of adding cognitive therapy to fluoxetine dose increase on risk of relapse and residual depressive symptoms in continuation treatment of major depressive disorder. J Clin Psychopharmacol. Oct. 2002;22(5):474-80. Source: PubMed. [pmid: 12352270].
2640 Perlis RH, Perlis CS, Wu Y, et al. Industry sponsorship and financial conflict of interest in the reporting of clinical trials in psychiatry. American Journal of Psychiatry. 2005;162(10):1957-60. Source: Scopus. [pmid: 16199844].
2641 Perlis RH, Purcell S, Fava M, et al. Association between treatment-emergent suicidal ideation with citalopram and polymorphisms near cyclic adenosine monophosphate response element binding protein in the STAR*D study. Arch Gen Psychiatry. Jun. 2007;64(6):689-97. Source: PubMed. [pmid: 17548750].
2642 Perna G, Favaron E, Di Bella D, et al. Antipanic efficacy of paroxetine and polymorphism within the promoter of the serotonin transporter gene. Neuropsychopharmacology. 2005;30(12):2230-5. Source: Scopus. [pmid: 16034444].
2643 Perroud N, Aitchison KJ, Uher R, et al. Genetic predictors of increase in suicidal ideation during antidepressant treatment in the GENDEP project. Neuropsychopharmacology. Nov. 2009;34(12):2517-28. Source: PubMed. [pmid: 19641488].
2644 Perroud N, Uher R, Hauser J, et al. History of suicide attempts among patients with depression in the GENDEP project. J Affect Disord. Jun. 2010;123(1-3):131-7. Source: PubMed. [pmid: 19772940].
2645 Perry EB, Berman RM, Sanacora G, et al. Pindolol augmentation in depressed patients resistant to selective serotonin reuptake inhibitors: a double-blind, randomized, controlled trial. J Clin Psychiatry. Feb. 2004;65(2):238-43. Source: PubMed. [pmid: 15003079].
2646 Perry PJ, Garvey MJ, Kelly MW, et al. A comparative trial of fluoxetine versus trazodone in outpatients with major depression. J Clin Psychiatry. Aug. 1989;50(8):290-4. Source: PubMed. [pmid: 2668259].
2647 Perry R, Cassagnol M. Desvenlafaxine: A new serotonin-norepinephrine reuptake inhibitor for the treatment of adults with major depressive disorder. Clinical Therapeutics. 2009;31(SUPPL. 1):1374-404. Source: Scopus. [pmid: 19698900].
2648 Perse TL, Greist JH, Jefferson JW, et al. Fluvoxamine treatment of obsessive-compulsive disorder. Am J Psychiatry. Dec. 1987;144(12):1543-8. Source: PubMed. [pmid: 3120604].
2649 Persky S, Reinus JF. Sertraline hepatotoxicity: a case report and review of the literature on selective serotonin reuptake inhibitor hepatotoxicity. Dig Dis Sci. May. 2003;48(5):939-44. Source: PubMed. [pmid: 12772794].
2650 Perugi G, Frare F, Toni C, et al. Open-label evaluation of venlafaxine sustained release in outpatients with generalized anxiety disorder with comorbid major depression or dysthymia: effectiveness, tolerability and predictors of response. Neuropsychobiology. 2002;46(3):145-9. Source: PubMed. [pmid: 12422062].
2651 Perugi G, Frare F, Toni C, et al. Adjunctive valproate in panic disorder patients with comorbid bipolar disorder or otherwise resistant to standard antidepressants: A 3-year “open” follow-up study. European Archives of Psychiatry and Clinical Neuroscience. 2010;260(7):553-60. Source: EMBASE. [pmid: 20238120].
2652 Perugi G, Romano A, Tusini G. Short-term and long-term treatment in depressive syndromes: Focus on antidepressants tolerability. Trattamento farmacologico a breve e lungo termine nelle sindromi depressive: Focus sulla tollerabilità degli antidepressivi. 2007;13(3):378-86. Source: Scopus.
2653 Peselow ED, Robins CJ, Sanfilipo MP, et al. Sociotropy and autonomy: relationship to antidepressant drug treatment response and endogenous-nonendogenous dichotomy. J Abnorm Psychol. Aug. 1992;101(3):479-86. Source: PubMed. [pmid: 1386856].
2654 Peselow ED, Stanley M, Filippi AM, et al. The predictive value of the dexamethasone suppression test. A placebo-controlled study. Br J Psychiatry. Nov. 1989;155:667-72. Source: PubMed. [pmid: 2532946].
2655 Peters UH, Lenhard P, Metzm M. Therapy of depression in the psychiatrist's office - A double-blind multicenter study. Nervenheilkunde. 1990;9(1):28-31. Source: EMBASE.
2656 Petersen T, Harley R, Papakostas GI, et al. Continuation cognitive-behavioural therapy maintains attributional style improvement in depressed patients responding acutely to fluoxetine. Psychol Med. Apr. 2004;34(3):555-61. Source: PubMed. [pmid: 15259840].
2657 Petersen T, Hughes M, Papakostas GI, et al. Treatment-resistant depression and Axis II comorbidity. Psychother Psychosom. Sep-Oct. 2002;71(5):269-74. Source: PubMed. [pmid: 12207107].
2658 Petersen T, Papakostas GI, Pasternak MA, et al. Empirical testing of two models for staging antidepressant treatment resistance. Journal of Clinical Psychopharmacology. 2005;25(4):336-41. Source: Scopus. [pmid: 16012276].
2659 Petersen TJ. Enhancing the efficacy of antidepressants with psychotherapy. Journal of Psychopharmacology. May. 2006. 2006;20(3):19-28. Source: PsycINFO. [pmid: 16644768].
2660 Petersen TJ, Pava JA, Buchin J, et al. The role of cognitive-behavioral therapy and fluoxetine in prevention of recurrence of major depressive disorder. Cognitive Therapy and Research. 2010;34(1):13-23. Source: PsycINFO.
2661 Peterson TJ, Feldman G, Harley R, et al. Extreme response style in recurrent and chronically depressed patients: change with antidepressant administration and stability during continuation treatment. J Consult Clin Psychol. Feb. 2007;75(1):145-53. Source: PubMed. [pmid: 17295573].
2662 Petracca GM, Chemerinski E, Starkstein SE. A double-blind, placebo-controlled study of fluoxetine in depressed patients with Alzheimer's disease. Int Psychogeriatr. Jun. 2001;13(2):233-40. Source: PubMed. [pmid: 11495397].
2663 Petrakis I, Carroll KM, Nich C, et al. Fluoxetine treatment of depressive disorders in methadone-maintained opioid addicts. Drug Alcohol Depend. May. 1. 1998;50(3):221-6. Source: PubMed. [pmid: 9649975].
2664 Pettinati HM, Oslin DW, Kampman KM, et al. A double-blind, placebo-controlled trial combining sertraline and naltrexone for treating co-occurring depression and alcohol dependence. Am J Psychiatry. 2010;167(6):668-75. Source: PubMed. [pmid: 20231324].
2665 Pettinati HM, Volpicelli JR, Luck G, et al. Double-blind clinical trial of sertraline treatment for alcohol dependence. J Clin Psychopharmacol. Apr. 2001;21(2):143-53. Source: PubMed. [pmid: 11270910].
2666 Pezard L, Nandrino JL, Renault B, et al. Depression as a dynamical disease. Biol Psychiatry. Jun. 15. 1996;39(12):991-9. Source: PubMed. [pmid: 8780833].
2667 Phanjoo A. The elderly depressed and treatment with fluvoxamine. Int Clin Psychopharmacol. Dec. Suppl 3. 1991;6:33-7. discussion 7-9. Source: PubMed. [pmid: 1806633].
2668 Phanjoo AL, Wonnacott S, Hodgson A. Double-blind comparative multicentre study of fluvoxamine and mianserin in the treatment of major depressive episode in elderly people. Acta Psychiatr Scand. Jun. 1991;83(6):476-9. Source: PubMed. [pmid: 1909083].
2669 Phelps JR. Agitated dysphoria after late-onset loss of response to antidepressants: a case report. J Affect Disord. Jun. 2005;86(2-3):277-80. Source: PubMed. [pmid: 15935247].
2670 Philipp M, Tiller JW, Baier D, et al. Comparison of moclobemide with selective serotonin reuptake inhibitors (SSRIs) on sexual function in depressed adults. The Australian and German Study Groups. Eur Neuropsychopharmacol. Sep. 2000;10(5):305-14. Source: PubMed. [pmid: 10974600].
2671 Phillips KA, Dwight MM, McElroy SL. Efficacy and safety of fluvoxamine in body dysmorphic disorder. J Clin Psychiatry. Apr. 1998;59(4):165-71. Source: PubMed. [pmid: 9590666].
2672 Phillips KA, McElroy SL, Keck PE Jr, et al. Body dysmorphic disorder: 30 cases of imagined ugliness. Am J Psychiatry. Feb. 1993;150(2):302-8. Source: PubMed. [pmid: 8422082].
2673 Piaggio G, Elbourne DR, Altman DG, et al. Reporting of noninferiority and equivalence randomized trials: an extension of the CONSORT statement. Jama. Mar. 8. 2006;295(10):1152-60. Source: PubMed. [pmid: 16522836].
2674 Pierson K, Addington D, Addington J, et al. Serum monitoring of antipsychotic drug levels during concomitant administration of sertraline and antipsychotic medication. Can J Psychiatry. Oct. 2006;51(11):715-8. Source: PubMed. [pmid: 17121171].
2675 Pigott TA, Prakash A, Arnold LM, et al. Duloxetine versus escitalopram and placebo: an 8-month, double-blind trial in patients with major depressive disorder. Curr Med Res Opin. 2007;23(6):1303-18. Source: PubMed. [pmid: 17559729].
2676 Pilhatsch M, Wolf R, Winter C, et al. Comparison of paroxetine and amitriptyline as adjunct to lithium maintenance therapy in bipolar depression: A reanalysis of a randomized, double-blind study. Journal of affective disorders. 2010;126(3):453-7. Source: EMBASE. [pmid: 20547424].
2677 Pillay SS, Renshaw PF, Bonello CM, et al. A quantitative magnetic resonance imaging study of caudate and lenticular nucleus gray matter volume in primary unipolar major depression: relationship to treatment response and clinical severity. Psychiatry Res. Dec. 14. 1998;84(2-3):61-74. Source: PubMed. [pmid: 10710164].
2678 Pillay SS, Yurgelun-Todd DA, Bonello CM, et al. A quantitative magnetic resonance imaging study of cerebral and cerebellar gray matter volume in primary unipolar major depression: relationship to treatment response and clinical severity. Biol Psychiatry. Jul. 15. 1997;42(2):79-84. Source: PubMed. [pmid: 9209723].
2679 Pini S, Amador XF, Dell'Osso L, et al. Treatment of depression with comorbid anxiety disorders: differential efficacy of paroxetine versus moclobemide. Int Clin Psychopharmacol. Jan. 2003;18(1):15-21. Source: PubMed. [pmid: 12490770].
2680 Pinkofsky HB, Stone KD, Reeves RR. Serotonin, cigarettes, and nausea. J Clin Psychopharmacol. Dec. 1997;17(6):492. Source: PubMed. [pmid: 9408816].
2681 Pinquart M, Duberstein PR, Lyness JM. Treatments for later-life depressive conditions: A meta-analytic comparison of pharmacotherapy and psychotherapy. American Journal of Psychiatry. 2006;163(9):1493-501. Source: Scopus. [pmid: 16946172].
2682 Pinto C, Trivedi JK, Vankar GK, et al. An open-label multicentric study of the tolerability and response to escitalopram treatment in Indian patients with major depressive disorder. J Indian Med Assoc. Jul. 2007;105(7):364. 6. 8 passim. Source: PubMed. [pmid: 18178988].
2683 Pinto-Meza A, Fernandez A, Serrano-Blanco A, et al. Adequacy of antidepressant treatment in Spanish primary care: A naturalistic six-month follow-up study. Psychiatric Services. 2008;59(1):78-83. Source: EMBASE. [pmid: 18182543].
2684 Pintor L, Baillés E, Matrai S, et al. Efficiency of venlafaxine in patients with psychogenic nonepileptic seizures and anxiety and/or depressive disorders. The Journal of neuropsychiatry and clinical neurosciences. 2010;22(4):401-8. Source: PsycINFO. [pmid: 21037125].
2685 Pitchot W, Ansseau M. Shock-like sensations associated with duloxetine discontinuation. Ann Clin Psychiatry. Jul-Sep. 2008;20(3):175. Source: PubMed. [pmid: 18633745].
2686 Pittenger C, Naungayan C, Kendell SF, et al. Visual hallucinations from the addition of riluzole to memantine and bupropion. J Clin Psychopharmacol. Apr. 2006;26(2):218-20. Source: PubMed. [pmid: 16633160].
2687 Pitts WM, Fann WE, Halaris AE, et al. Bupropion in depression: a tri-center placebo-controlled study. J Clin Psychiatry. May. 1983;44(5 Pt 2):95-100. Source: PubMed. [pmid: 6406473].
2688 Pivac N, Muck-Seler D, Sagud M, et al. Long-term sertraline treatment and peripheral biochemical markers in female depressed patients. Prog Neuropsychopharmacol Biol Psychiatry. Aug. 2003;27(5):759-65. Source: PubMed. [pmid: 12921906].
2689 Piwowarska J, Dryll K, Szelenberger W, et al. Cortisol level in men with major depressive disorder treated with fluoxetine or imipramine. Acta Pol Pharm. Jan-Feb. 2008;65(1):159-64. Source: PubMed. [pmid: 18536191].
2690 Pjrek E, Willeit M, Praschak-Rieder N, et al. Treatment of seasonal affective disorder with duloxetine: an open-label study. Pharmacopsychiatry. May. 2008;41(3):100-5. Source: PubMed. [pmid: 18484551].
2691 Pjrek E, Winkler D, Stastny J, et al. Escitalopram in seasonal affective disorder: results of an open trial. Pharmacopsychiatry. Jan. 2007;40(1):20-4. Source: PubMed. [pmid: 17327956].
2692 Plesnicar BK. Efficacy and tolerability of venlafaxine extended release in patients with major depressive disorder. Psychiatr Danub. Sep. 2010;22(3):413-7. Source: PubMed. [pmid: 20856184].
2693 Poelinger W, Haber H. Fluoxetine 40 mg vs maprotiline 75 mg in the treatment of out-patients with depressive disorders. Int Clin Psychopharmacol. Jan. Suppl 1. 1989;4:47-50. Source: PubMed. [pmid: 2644340].
2694 Pohl R, Balon R, Jayaraman A, et al. Effect of fluoxetine, pemoline and placebo on heart period and QT variability in normal humans. J Psychosom Res. Sep. 2003;55(3):247-51. Source: PubMed. [pmid: 12932798].
2695 Poirier MF, Boyer P. Venlafaxine and paroxetine in treatment-resistant depression. Double-blind, randomised comparison. Br J Psychiatry. Jul. 1999;175:12-6. Source: PubMed. [pmid: 10621762].
2696 Poldinger W. Experiences with doxepin and trazodone in the therapy with outpatients suffering from depression. Psychopathology. Suppl 2. 1984;17:30-6. Source: PubMed. [pmid: 6371876].
2697 Poldinger W, Calanchini B, Schwarz W. A functional-dimensional approach to depression: serotonin deficiency as a target syndrome in a comparison of 5-hydroxytryptophan and fluvoxamine. Psychopathology. 1991;24(2):53-81. Source: PubMed. [pmid: 1909444].
2698 Poling J, Pruzinsky R, Kosten TR, et al. Clinical efficacy of citalopram alone or augmented with bupropion in methadone-stabilized patients. Am J Addict. May-Jun. 2007;16(3):187-94. Source: PubMed. [pmid: 17612822].
2699 Pollack MH, Rapaport MH, Clary CM, et al. Sertraline treatment of panic disorder: response in patients at risk for poor outcome. Journal Of Clinical Psychiatry. 2000;61(12):922-7. Source: EMBASE. [pmid: 11206597].
2700 Pollock BG, Ferrell RE, Mulsant BH, et al. Allelic variation in the serotonin transporter promoter affects onset of paroxetine treatment response in late-life depression. Neuropsychopharmacology. Nov. 2000;23(5):587-90. Source: PubMed. [pmid: 11027924].
2701 Pollock BG, Laghrissi-Thode F, Wagner WR. Evaluation of platelet activation in depressed patients with ischemic heart disease after paroxetine or nortriptyline treatment. J Clin Psychopharmacol. Apr. 2000;20(2):137-40. Source: PubMed. [pmid: 10770450].
2702 Pollock BG, Mulsant BH, Nebes R, et al. Serum anticholinergicity in elderly depressed patients treated with paroxetine or nortriptyline. Am J Psychiatry. Aug. 1998;155(8):1110-2. Source: PubMed. [pmid: 9699704].
2703 Pollock BG, Sweet RA, Kirshner M, et al. Bupropion plasma levels and CYP2D6 phenotype. Ther Drug Monit. Oct. 1996;18(5):581-5. Source: PubMed. [pmid: 8885123].
2704 Polsky D, Onesirosan P, Bauer MS, et al. Duration of therapy and health care costs of fluoxetine, paroxetine, and sertraline in 6 health plans. J Clin Psychiatry. Feb. 2002;63(2):156-64. Source: PubMed. [pmid: 11874218].
2705 Pompili M, Amador XF, Girardi P, et al. Suicide risk in schizophrenia: Learning from the past to change the future. Annals of General Psychiatry. 2007;6. Source: Scopus.
2706 Pompili M, Baldessarini RJ, Tondo L, et al. Response to intravenous antidepressant treatment by suicidal vs. nonsuicidal depressed patients. J Affect Disord. Apr. 2010;122(1-2):154-8. Source: PubMed. [pmid: 19709752].
2707 Pope HG Jr, Amiaz R, Brennan BP, et al. Parallel-group placebo-controlled trial of testosterone gel in men with major depressive disorder displaying an incomplete response to standard antidepressant treatment. Journal of Clinical Psychopharmacology. 2010;30(2):126-34. Source: PsycINFO. [pmid: 20520285].
2708 Pope HG Jr, Keck PE Jr, McElroy SL, et al. A placebo-controlled study of trazodone in bulimia nervosa. J Clin Psychopharmacol. Aug. 1989;9(4):254-9. Source: PubMed. [pmid: 2671058].
2709 Pope HG Jr, McElroy SL, Nixon RA. Possible synergism between fluoxetine and lithium in refractory depression. Am J Psychiatry. Oct. 1988;145(10):1292-4. Source: PubMed. [pmid: 3262313].
2710 Poret AW, Neslusan C, Ricci JF, et al. Retrospective analysis of the health-care costs of bupropion sustained release in comparison with other antidepressants. Value Health. Sep-Oct. 2001;4(5):362-9. Source: PubMed. [pmid: 11705126].
2711 Portella MJ, Marcos T, Rami L, et al. Residual cognitive impairment in late-life depression after a 12-month period follow-up. Int J Geriatr Psychiatry. Jul. 2003;18(7):571-6. Source: PubMed. [pmid: 12833300].
2712 Porter RJ, Mulder RT, Joyce PR, et al. Tryptophan and tyrosine availability and response to antidepressant treatment in major depression. J Affect Disord. Jun. 2005;86(2-3):129-34. Source: PubMed. [pmid: 15935231].
2713 Posey DJ, Guenin KD, Kohn AE, et al. A naturalistic open-label study of mirtazapine in autistic and other pervasive developmental disorders. J Child Adolesc Psychopharmacol. Fall. 2001;11(3):267-77. Source: PubMed. [pmid: 11642476].
2714 Posner K, Oquendo MA, Gould M, et al. Columbia Classification Algorithm of Suicide Assessment (C-CASA): Classification of suicidal events in the FDA's pediatric suicidal risk analysis of antidepressants. American Journal of Psychiatry. 2007;164(7):1035-43. Source: Scopus. [pmid: 17606655].
2715 Post RM, Altshuler LL, Frye MA, et al. Complexity of pharmacologic treatment required for sustained improvement in outpatients with bipolar disorder. Journal of Clinical Psychiatry. 2010;71(9):1176-86. Source: EMBASE. [pmid: 20923622].
2716 Post RM, Altshuler LL, Leverich GS, et al. Mood switch in bipolar depression: comparison of adjunctive venlafaxine, bupropion and sertraline. Br J Psychiatry. Aug. 2006;189:124-21. Source: PubMed. [pmid: 16880481].
2717 Posternak MA, Zimmerman M. Dual Reuptake Inhibitors Incur Lower Rates of Tachyphylaxis Than Selective Serotonin Reuptake Inhibitors: A Retrospective Study. Journal of Clinical Psychiatry. Jun. 2005. 2005;66(6):705-7. Source: PsycINFO. [pmid: 15960562].
2718 Postolache TT, Rosenthal RN, Hellerstein DJ, et al. Early augmentation of sertraline with methylphenidate. J Clin Psychiatry. Feb. 1999;60(2):123-4. Source: PubMed. [pmid: 10084641].
2719 Potluri K, Hou S. Obesity in Kidney Transplant Recipients and Candidates. American Journal of Kidney Diseases. 2010;56(1):143-56. Source: EMBASE. [pmid: 20452710].
2720 Prasad KP, Tharangani PG, Samaranayake CN. Recurrent relapses of depression in a patient established on sertraline after taking herbal medicinal mixtures--a herb-drug interaction?. J Psychopharmacol. Mar. 2009;23(2):216-9. Source: PubMed. [pmid: 18515463].
2721 Prasher VP. Seizures associated with fluoxetine therapy. Seizure. Dec. 1993;2(4):315-7. Source: PubMed. [pmid: 8162401].
2722 Presecki P, Mihanovic M, Silic A, et al. Venlafaxine - quetiapine combination in the treatment of complicated clinical picture of enduring personality changes following PTSD in comorbidity with psychotic depression. Psychiatr Danub. Jun. 2010;22(2):360-2. Source: PubMed. [pmid: 20562783].
2723 Preskorn S. Targeted pharmacotherapy in depression management: comparative pharmacokinetics of fluoxetine, paroxetine and sertraline. Int Clin Psychopharmacol. Jun. Suppl 3. 1994;9:13-9. Source: PubMed. [pmid: 7963446].
2724 Preskorn SH. Antidepressant response and plasma concentrations of bupropion. J Clin Psychiatry. May. 1983;44(5 Pt 2):137-9. Source: PubMed. [pmid: 6406443].
2725 Preskorn SH. Pharmacokinetics of antidepressants: why and how they are relevant to treatment. J Clin Psychiatry. Sep. 1993;54(Suppl):14-34. discussion 55-6. Source: PubMed. [pmid: 8407856].
2726 Preskorn SH. Comparison of the tolerability of bupropion, fluoxetine, imipramine, nefazodone, paroxetine, sertraline, and venlafaxine. J Clin Psychiatry. Suppl 6. 1995;56:12-21. Source: PubMed. [pmid: 7649968].
2727 Preskorn SH. Reboxetine: a norepinephrine selective reuptake pump inhibitor. J Psychiatr Pract. Jan. 2004;10(1):57-63. Source: PubMed. [pmid: 15334987].
2728 Preskorn SH. Practical application of therapeutic drug monitoring: a tale of two patients. J Psychiatr Pract. Sep. 2008;14(5):301-6. Source: PubMed. [pmid: 18832961].
2729 Preskorn SH. Results of the STAR*D Study: Implications for Clinicians and Drug Developers. Journal of Psychiatric Practice. January. 2009;15(1):45-9. Source: Handsearch. [pmid: 19182564].
2730 Preskorn SH, Baker B, Kolluri S, et al. An innovative design to establish proof of concept of the antidepressant effects of the NR2B subunit selective N-methyl-D-aspartate antagonist, CP-101,606, in patients with treatment-refractory major depressive disorder. J Clin Psychopharmacol. Dec. 2008;28(6):631-7. Source: PubMed. [pmid: 19011431].
2731 Preskorn SH, Nichols AI, Paul J, et al. Effect of desvenlafaxine on the cytochrome P450 2D6 enzyme system. J Psychiatr Pract. Nov. 2008;14(6):368-78. Source: PubMed. [pmid: 19057238].
2732 Preskorn SH, Othmer SC, Lai CW, et al. Tricyclic-induced electroencephalogram abnormalities and plasma drug concentrations. J Clin Psychopharmacol. Oct. 1984;4(5):262-4. Source: PubMed. [pmid: 6436340].
2733 Price LH, Charney DS, Heninger GR. Efficacy of lithium-tranylcypromine treatment in refractory depression. Am J Psychiatry. May. 1985;142(5):619-23. Source: PubMed. [pmid: 3920923].
2734 Pritchett YL, Marciniak MD, Corey-Lisle PK, et al. Use of effect size to determine optimal dose of duloxetine in major depressive disorder. J Psychiatr Res. Apr-Jun. 2007;41(3-4):311-8. Source: PubMed. [pmid: 16934840].
2735 Prospero-Garcia KA, Torres-Ruiz A, Ramirez-Bermudez J, et al. Fluoxetine-mirtazapine interaction may induce restless legs syndrome: report of 3 cases from a clinical trial. J Clin Psychiatry. Nov. 2006;67(11):1820. Source: PubMed. [pmid: 17196069].
2736 Prowler ML, Baldassano CF. Pramipexole in rapid cycling bipolar disorder: A case series. Primary Psychiatry. 2010;17(8):42-5. Source: EMBASE.
2737 Prukkanone B, Vos T, Burgess P, et al. Adherence to antidepressant therapy for major depressive patients in a psychiatric hospital in Thailand. BMC Psychiatry. 2010;10:64. Source: PubMed. [pmid: 20727215].
2738 Pukadan D, Antony J, Mohandas E, et al. Use of escitalopram in psychogenic excoriation. Aust N Z J Psychiatry. May. 2008;42(5):435-6. Source: PubMed. [pmid: 18499934].
2739 Purdon SE, Snaterse M. Selective serotonin reuptake inhibitor modulation of clozapine effects on cognition in schizophrenia. Can J Psychiatry. Feb. 1998;43(1):84-5. Source: PubMed. [pmid: 9494753].
2740 Pyne JM, Bullock D, Kaplan RM, et al. Health-related quality-of-life measure enhances acute treatment response prediction in depressed inpatients. J Clin Psychiatry. Apr. 2001;62(4):261-8. Source: PubMed. [pmid: 11379840].
2741 Qadir A, Haider N. Duloxetine withdrawal seizure. Psychiatry. Sep. 2006;3(9):10. Source: PsycINFO. [pmid: 20975823].
2742 Qaseem A, Snow V, Denberg TD, et al. Using second-generation antidepressants to treat depressive disorders: a clinical practice guideline from the American College of Physicians. Ann Intern Med. Nov. 18. 2008;149(10):725-33. Source: PubMed. [pmid: 19017591].
2743 Quante A, Zeugmann S, Luborzewski A, et al. Aripiprazole as adjunct to a mood stabilizer and citalopram in bipolar depression: A randomized placebo-controlled pilot study. Human Psychopharmacology. 2010;25(2):126-32. Source: EMBASE. [pmid: 20196183].
2744 Quednow BB, Kuhn KU, Stelzenmuelle R, et al. Effects of serotonergic and noradrenergic antidepressants on auditory startle response in patients with major depression. Psychopharmacology (Berl). Oct. 2004;175(4):399-406. Source: PubMed. [pmid: 15042278].
2745 Quilty LC, De Fruyt F, Rolland JP, et al. Dimensional personality traits and treatment outcome in patients with major depressive disorder. J Affect Disord. Jun. 2008;108(3):241-50. Source: PubMed. [pmid: 18067975].
2746 Quilty LC, Godfrey KM, Kennedy SH, et al. Harm avoidance as a mediator of treatment response to antidepressant treatment of patients with major depression. Psychotherapy and Psychosomatics. 2010;79(2):116-22. Source: EMBASE. [pmid: 20090398].
2747 Quitkin FM, McGrath PJ, Stewart JW, et al. Remission rates with 3 consecutive antidepressant trials: effectiveness for depressed outpatients. J Clin Psychiatry. Jun. 2005;66(6):670-6. Source: PubMed. [pmid: 15960558].
2748 Quitkin FM, Petkova E, McGrath PJ, et al. When should a trial of fluoxetine for major depression be declared failed?. Am J Psychiatry. Apr. 2003;160(4):734-40. Source: PubMed. [pmid: 12668363].
2749 Quitkin FM, Stewart JW, McGrath PJ, et al. Are there differences between women's and men's antidepressant responses?. Am J Psychiatry. Nov. 2002;159(11):1848-54. Source: PubMed. [pmid: 12411218].
2750 Rabkin JG, Wagner GJ, McElhiney MC, et al. Testosterone versus fluoxetine for depression and fatigue in HIV/AIDS: a placebo-controlled trial. J Clin Psychopharmacol. Aug. 2004;24(4):379-85. Source: PubMed. [pmid: 15232328].
2751 Rabkin JG, Wagner GJ, Rabkin R. Fluoxetine treatment for depression in patients with HIV and AIDS: a randomized, placebo-controlled trial. Am J Psychiatry. Jan. 1999;156(1):101-7. Source: PubMed. [pmid: 9892304].
2752 Rachid F, Golaz J, Bondolfi G, et al. Induction of a mixed depressive episode during rTMS treatment in a patient with refractory major depression. World J Biol Psychiatry. 2006;7(4):261-4. Source: PubMed. [pmid: 17071547].
2753 Rahimi R, Nikfar S, Abdollahi M. Efficacy and tolerability of Hypericum perforatum in major depressive disorder in comparison with selective serotonin reuptake inhibitors: a meta-analysis. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 1. 2009;33(1):118-27. Source: PubMed. [pmid: 19028540].
2754 Rahme E, Dasgupta K, Turecki G, et al. Risks of suicide and poisoning among elderly patients prescribed selective serotonin reuptake inhibitors: a retrospective cohort study. J Clin Psychiatry. Mar. 2008;69(3):349-57. Source: PubMed. [pmid: 18278986].
2755 Raison CL, Woolwine BJ, Demetrashvili MF, et al. Paroxetine for prevention of depressive symptoms induced by interferon-alpha and ribavirin for hepatitis C. Aliment Pharmacol Ther. May. 15. 2007;25(10):1163-74. Source: PubMed. [pmid: 17451562].
2756 Raja M, Azzoni A. Are antidepressants warranted in the treatment of patients who present suicidal behavior?. Human Psychopharmacology. 2008;23(8):661-8. Source: EMBASE. [pmid: 19016273].
2757 Rajagopalan M. Comparison of venlafaxine and imipramine in depressive illness. Acta Psychiatr Scand. May. 1998;97(5):384-5. Source: PubMed. [pmid: 9611090].
2758 Rajji TK, Mulsant BH, Lotrich FE, et al. Use of antidepressants in late-life depression. Drugs and Aging. 2008;25(10):841-53. Source: Handsearch. [pmid: 18808208].
2759 Ramaekers JG, Ansseau M, Muntjewerff ND, et al. Considering the P450 cytochrome system as determining combined effects of antidepressants and benzodiazepines on actual driving performance of depressed outpatients. Int Clin Psychopharmacol. May. 1997;12(3):159-69. Source: PubMed. [pmid: 9248873].
2760 Ramasubbu R. Minor strokes related to paroxetine discontinuation in an elderly subject: emergent adverse events. Can J Psychiatry. May. 2003;48(4):281-2. Source: PubMed. [pmid: 12776398].
2761 Rampello L, Chiechio S, Nicoletti G, et al. Prediction of the response to citalopram and reboxetine in post-stroke depressed patients. Psychopharmacology (Berl). Apr. 2004;173(1-2):73-8. Source: PubMed. [pmid: 14685645].
2762 Ranieri P, Franzoni S, Rozzini R, et al. Venlafaxine-induced reset osmostat syndrome: case of a 79-year-old depressed woman. J Geriatr Psychiatry Neurol. Apr. 1997;10(2):75-8. Source: PubMed. [pmid: 9188023].
2763 Rao ML, Ruhrmann S, Retey B, et al. Low plasma thyroid indices of depressed patients are attenuated by antidepressant drugs and influence treatment outcome. Pharmacopsychiatry. Sep. 1996;29(5):180-6. Source: PubMed. [pmid: 8895943].
2764 Rao U, Ott GE, Lin KM, et al. Effect of bupropion on nocturnal urinary free cortisol and its association with antidepressant response. J Psychiatr Res. Mar. 2005;39(2):183-90. Source: PubMed. [pmid: 15589567].
2765 Rao V, Spiro JR, Rosenberg PB, et al. An open-label study of escitalopram (Lexapro) for the treatment of ‘Depression of Alzheimer's disease’ (dAD). Int J Geriatr Psychiatry. Mar. 2006;21(3):273-4. Source: PubMed. [pmid: 16477587].
2766 Rapaport M, Coccaro E, Sheline Y, et al. A comparison of fluvoxamine and fluoxetine in the treatment of major depression. J Clin Psychopharmacol. Oct. 1996;16(5):373-8. Source: PubMed. [pmid: 8889909].
2767 Rapaport MH, Bose A, Zheng H. Escitalopram continuation treatment prevents relapse of depressive episodes. J Clin Psychiatry. Jan. 2004;65(1):44-9. Source: PubMed. [pmid: 14744167].
2768 Rapaport MH, Clary C, Fayyad R, et al. Quality-of-life impairment in depressive and anxiety disorders. Am J Psychiatry. Jun. 2005;162(6):1171-8. Source: PubMed. [pmid: 15930066].
2769 Rapaport MH, Judd LL. Minor depressive disorder and subsyndromal depressive symptoms: functional impairment and response to treatment. J Affect Disord. Mar. 1998;48(2-3):227-32. Source: PubMed. [pmid: 9543213].
2770 Rapaport MH, Lydiard RB, Pitts CD, et al. Low doses of controlled-release paroxetine in the treatment of late-life depression: a randomized, placebo-controlled trial. J Clin Psychiatry. 2009;70(1):46-57. Source: PubMed. [pmid: 19026248].
2771 Rapaport MH, Schneider LS, Dunner DL, et al. Efficacy of controlled-release paroxetine in the treatment of late-life depression. J Clin Psychiatry. Sep. 2003;64(9):1065-74. Source: PubMed. [pmid: 14628982].
2772 Raphael K, Tokeshi J. Hyponatremia associated with sertraline and fluoxetine: a case report. Hawaii Med J. Mar. 2002;61(3):46-7. Source: PubMed. [pmid: 11965835].
2773 Rapoport MJ, Chan F, Lanctot K, et al. An open-label study of citalopram for major depression following traumatic brain injury. J Psychopharmacol. Nov. 2008;22(8):860-4. Source: PubMed. [pmid: 18208921].
2774 Rapoport MJ, Mitchell RA, McCullagh S, et al. A randomized controlled trial of antidepressant continuation for major depression following traumatic brain injury. J Clin Psychiatry. 2010;71(9):1125-30. Source: PubMed. [pmid: 20441723].
2775 Rasanen P, Hakko H, Jokelainen J, et al. Outcome of different types of long-term antidepressant treatments: a 3-year follow-up study of 14182 patients. J Affect Disord. Sep. 1999;55(1):67-71. Source: PubMed. [pmid: 10512609].
2776 Rasgon NL, Altshuler LL, Fairbanks LA, et al. Estrogen replacement therapy in the treatment of major depressive disorder in perimenopausal women. J Clin Psychiatry. Suppl 7. 2002;63:45-8. Source: PubMed. [pmid: 11995778].
2777 Rasgon NL, Carter MS, Elman S, et al. Common treatment of polycystic ovarian syndrome and major depressive disorder: case report and review. Curr Drug Targets Immune Endocr Metabol Disord. Apr. 2002;2(1):97-102. Source: PubMed. [pmid: 12477299].
2778 Rasgon NL, Dunkin J, Fairbanks L, et al. Estrogen and response to sertraline in postmenopausal women with major depressive disorder: a pilot study. J Psychiatr Res. Apr-Jun. 2007;41(3-4):338-43. Source: PubMed. [pmid: 16697413].
2779 Raskin J, Goldstein DJ, Mallinckrodt CH, et al. Duloxetine in the long-term treatment of major depressive disorder. J Clin Psychiatry. Oct. 2003;64(10):1237-44. Source: PubMed. [pmid: 14658974].
2780 Raskin J, Wiltse CG, Dinkel JJ, et al. Safety and tolerability of duloxetine at 60 mg once daily in elderly patients with major depressive disorder. J Clin Psychopharmacol. 2008;28(1):32-8. Source: PubMed. [pmid: 18204338].
2781 Raskin J, Wiltse CG, Siegal A, et al. Efficacy of duloxetine on cognition, depression, and pain in elderly patients with major depressive disorder: an 8-week, double-blind, placebo-controlled trial. Am J Psychiatry. 2007;164(6):900-9. Source: PubMed. [pmid: 17541049].
2782 Raskin J, Xu JY, Kajdasz DK. Time to response for duloxetine 60 mg once daily versus placebo in elderly patients with major depressive disorder. Int Psychogeriatr. 2008;20(2):309-27. Source: PubMed. [pmid: 17588276].
2783 Rasmussen A, Lunde M, Poulsen DL, et al. A double-blind, placebo-controlled study of sertraline in the prevention of depression in stroke patients. Psychosomatics. May-Jun. 2003;44(3):216-21. Source: PubMed. [pmid: 12724503].
2784 Ratan DA. Fluoxetine and suicidal ideation. J Clin Psychopharmacol. Feb. 1997;17(1):61-2. Source: PubMed. [pmid: 9004066].
2785 Raue PJ, Schulberg HC, Heo M, et al. Patients' depression treatment preferences and initiation, adherence, and outcome: a randomized primary care study. Psychiatr Serv. 2009;60(3):337-43. Source: PubMed. [pmid: 19252046].
2786 Rausch JLJM, Fei YJ, Jun QL, Shendarkar N, Hobby HM, Ganapathy V, Leibach FH. Initial conditions of serotonin transporter kinetics and genotype: Influence on SSRI treatment trial outcome. Psychiatry;Biological. Source: EMBASE.
2787 Ravindran AV, Anisman H, Merali Z, et al. Treatment of primary dysthymia with group cognitive therapy and pharmacotherapy: clinical symptoms and functional impairments. Am J Psychiatry. Oct. 1999;156(10):1608-17. Source: PubMed. [pmid: 10518174].
2788 Ravindran AV, Charbonneau Y, Zaharia MD, et al. Efficacy and tolerability of venlafaxine in the treatment of primary dysthymia. J Psychiatry Neurosci. Nov. 1998;23(5):288-92. Source: PubMed. [pmid: 9846033].
2789 Ravindran AV, Chudzik J, Bialik RJ, et al. Platelet serotonin measures in primary dysthymia. Am J Psychiatry. Sep. 1994;151(9):1369-71. Source: PubMed. [pmid: 8067494].
2790 Ravindran AV, Griffiths J, Merali Z, et al. Lymphocyte subsets associated with major depression and dysthymia: modification by antidepressant treatment. Psychosom Med. Nov-Dec. 1995;57(6):555-63. Source: PubMed. [pmid: 8600482].
2791 Ravindran AV, Guelfi JD, Lane RM, et al. Treatment of dysthymia with sertraline: a double-blind, placebo-controlled trial in dysthymic patients without major depression. J Clin Psychiatry. Nov. 2000;61(11):821-7. Source: PubMed. [pmid: 11105734].
2792 Ravindran AV, Judge R, Hunter BN, et al. A double-blind, multicenter study in primary care comparing paroxetine and clomipramine in patients with depression and associated anxiety. Paroxetine Study Group J Clin Psychiatry. Mar. 1997;58(3):112-8. Source: PubMed.
2793 Ravindran AV, Kennedy SH, O'Donovan MC, et al. Osmotic-release oral system methylphenidate augmentation of antidepressant monotherapy in major depressive disorder: Results of a double-blind, randomized, placebo-controlled trial. Journal of Clinical Psychiatry. Jan. 2008. 2008;69(1):87-94. Source: PsycINFO. [pmid: 18312042].
2794 Ravindran AV, Teehan MD, Bakish D, et al. The impact of sertraline, desipramine, and placebo on psychomotor functioning in depression. Hum Psychopharmacol. 1995;10(4):273-81. Source: EMBASE.
2795 Ravindran LN, Eisfeld BS, Kennedy SH. Combining mirtazapine and duloxetine in treatment-resistant depression improves outcomes and sexual function. Journal of Clinical Psychopharmacology (USA). 01. 01. 2008;28(Jan):107-8. Source: PsycINFO.
2796 Rawls WN. Trazodone (Desyrel, Mead-Johnson Pharmaceutical Division). Drug Intell Clin Pharm. Jan. 1982;16(1):7-13. Source: PubMed. [pmid: 7032872].
2797 Rayner L, Price A, Evans A, et al. Antidepressants for depression in physically ill people. Cochrane Database of Systematic Reviews. 2010;(3). Source: The Cochrane Library.
2798 Razavi D, Allilaire JF, Smith M, et al. The effect of fluoxetine on anxiety and depression symptoms in cancer patients. Acta Psychiatr Scand. 1996;94(3):205-10. Source: PubMed. [pmid: 8891089].
2799 Razavi M, Barrash J, Paradiso S. A longitudinal study of transient epileptic amnesia. Cognitive and Behavioral Neurology. 2010;23(2):142-5. Source: EMBASE. [pmid: 20535066].
2800 Rechlin T. The effect of amitriptyline, doxepin, fluvoxamine, and paroxetine treatment on heart rate variability. J Clin Psychopharmacol. Dec. 1994;14(6):392-5. Source: PubMed. [pmid: 7884019].
2801 Rechlin T, Weis M, Claus D. Heart rate variability in depressed patients and differential effects of paroxetine and amitriptyline on cardiovascular autonomic functions. Pharmacopsychiatry. May. 1994;27(3):124-8. Source: PubMed. [pmid: 8078953].
2802 Reddy S, Kane C, Pitrosky B, et al. Clinical utility of desvenlafaxine 50 mg/d for treating MDD: a review of two randomized placebo-controlled trials for the practicing physician. Curr Med Res Opin. Jan. 2010;26(1):139-50. Source: PubMed. [pmid: 19919295].
2803 Reed SM, Glick JW. Fluoxetine and reactivation of the herpes simplex virus. Am J Psychiatry. Jul. 1991;148(7):949-50. Source: PubMed. [pmid: 1647143].
2804 Reimherr F, Amsterdam J, Dunner D, et al. Genetic polymorphisms in the treatment of depression: Speculations from an augmentation study using atomoxetine. Psychiatry Research. 2010;175(1-2):67-73. Source: EMBASE. [pmid: 19969374].
2805 Reimherr FW, Amsterdam JD, Quitkin FM, et al. Optimal length of continuation therapy in depression: a prospective assessment during long-term fluoxetine treatment. Am J Psychiatry. Sep. 1998;155(9):1247-53. Source: PubMed. [pmid: 9734550].
2806 Reimherr FW, Byerley WF, Ward MF, et al. Sertraline, a selective inhibitor of serotonin uptake, for the treatment of outpatients with major depressive disorder. Psychopharmacol Bull. 1988;24(1):200-5. Source: PubMed. [pmid: 3290941].
2807 Reimherr FW, Chouinard G, Cohn CK, et al. Antidepressant efficacy of sertraline: a double-blind, placebo- and amitriptyline-controlled, multicenter comparison study in outpatients with major depression. J Clin Psychiatry. Dec. Suppl B. 1990;51:18-27. Source: PubMed. [pmid: 2258378].
2808 Reimherr FW, Cunningham LA, Batey SR, et al. A multicenter evaluation of the efficacy and safety of 150 and 300 mg/d sustained-release bupropion tablets versus placebo in depressed outpatients. Clin Ther. May-Jun. 1998;20(3):505-16. Source: PubMed. [pmid: 9663366].
2809 Reimherr FW, Strong RE, Marchant BK, et al. Factors affecting return of symptoms 1 year after treatment in a 62-week controlled study of fluoxetine in major depression. J Clin Psychiatry. Suppl 22. 2001;62:16-23. Source: PubMed. [pmid: 11599643].
2810 Reimherr FW, Wood DR, Byerley B, et al. Characteristics of responders to fluoxetine. Psychopharmacol Bull. Winter. 1984;20(1):70-2. Source: PubMed. [pmid: 6371874].
2811 Reis M, Aberg-Wistedt A, Agren H, et al. Serum disposition of sertraline, N-desmethylsertraline and paroxetine: a pharmacokinetic evaluation of repeated drug concentration measurements during 6 months of treatment for major depression. Hum Psychopharmacol. Jul. 2004;19(5):283-91. Source: PubMed. [pmid: 15252820].
2812 Reis M, Prochazka J, Sitsen A, et al. Inter- and intraindividual pharmacokinetic variations of mirtazapine and its N-demethyl metabolite in patients treated for major depressive disorder: a 6-month therapeutic drug monitoring study. Ther Drug Monit. Aug. 2005;27(4):469-77. Source: PubMed. [pmid: 16044104].
2813 Remick RA, Campos PE, Misri S, et al. A comparison of the safety and efficacy of bupropion HCL and amitriptyline hcl in depressed outpatients. Prog Neuropsychopharmacol Biol Psychiatry. 1982;6(4-6):523-7. Source: PubMed. [pmid: 6819598].
2814 Remick RA, Claman J, Reesal R, et al. Comparison of fluoxetine and desipramine in depressed outpatients. Curr Ther Res Clin Exp. 1993;53(5):457-65. Source: EMBASE.
2815 Resler G, Lavie R, Campos J, et al. Effect of folic acid combined with fluoxetine in patients with major depression on plasma homocysteine and vitamin B12, and serotonin levels in lymphocytes. Neuroimmunomodulation. 2008;15(3):145-52. Source: PubMed. [pmid: 18716414].
2816 Retz W, Maier S, Maris F, et al. Non-fatal mirtazapine overdose. Int Clin Psychopharmacol. Nov. 1998;13(6):277-9. Source: PubMed. [pmid: 9861579].
2817 Revicki DA, Palmer CS, Phillips SD, et al. Acute medical costs of fluoxetine versus tricyclic antidepressants. A prospective multicentre study of antidepressant drug overdoses. Pharmacoeconomics. Jan. 1997;11(1):48-55. Source: PubMed. [pmid: 10165526].
2818 Reynaert C, Parent M, Mirel J, et al. Moclobemide versus fluoxetine for a major depressive episode. Psychopharmacology (Berl). Mar. 1995;118(2):183-7. Source: PubMed. [pmid: 7617806].
2819 Reynolds CF 3rd. Paroxetine treatment of depression in late life. Psychopharmacol Bull. Spring. Suppl 1. 2003;37:123-34. Source: PubMed. [pmid: 14566207].
2820 Reynolds CF 3rd, Dew MA, Pollock BG, et al. Maintenance treatment of major depression in old age. N Engl J Med. 2006;354(11):1130-8. Source: PubMed. [pmid: 16540613].
2821 Reynolds CF 3rd, Frank E, Perel JM, et al. High relapse rate after discontinuation of adjunctive medication for elderly patients with recurrent major depression. Am J Psychiatry. Nov. 1996;153(11):1418-22. Source: PubMed. [pmid: 8890674].
2822 Reynolds CF 3rd, Smith GS, Dew MA, et al. Accelerating symptom-reduction in late-life depression: a double-blind, randomized, placebo-controlled trial of sleep deprivation. Am J Geriatr Psychiatry. May. 2005;13(5):353-8. Source: PubMed. [pmid: 15879583].
2823 Reynolds CF Iii, Dew MA, Martire LM, et al. Treating depression to remission in older adults: A controlled evaluation of combined escitalopram with interpersonal psychotherapy versus escitalopram with depression care management. International journal of geriatric psychiatry. 2010;25(11):1134-41. Source: EMBASE. [pmid: 20957693].
2824 RH P. Half Full or Half Empty? Lessons from STAR*D. Primary Psychiatry. 2007;14(1):44-5. Source: Handsearch.
2825 Ricca V, Mannucci E, Paionni A, et al. Venlafaxine versus fluoxetine in the treatment of atypical anorectic outpatients: a preliminary study. Eat Weight Disord. Mar. 1999;4(1):10-4. Source: PubMed. [pmid: 10728173].
2826 Richards S, Umbreit JN, Fanucchi MP, et al. Selective serotonin reuptake inhibitor-induced rhabdomyolysis associated with irinotecan. South Med J. Oct. 2003;96(10):1031-3. Source: PubMed. [pmid: 14570350].
2827 Richardson JS, Keegan DL, Bowen RC, et al. Verbal learning by major depressive disorder patients during treatment with fluoxetine or amitriptyline. Int Clin Psychopharmacol. Spring. 1994;9(1):35-40. Source: PubMed. [pmid: 8195581].
2828 Richou H, Ruimy P, Charbaut J, et al. A multicentre, double-blind, clomipramine-controlled efficacy and safety study of Org 3770. Hum Psychopharmacol. 1995;10(4):263-71. Source: EMBASE.
2829 Richter N, Juckel G, Assion HJ. Metabolic syndrome: A follow-up study of acute depressive inpatients. European Archives of Psychiatry and Clinical Neuroscience. 2010;260(1):41-9. Source: EMBASE. [pmid: 19399357].
2830 Rickels K, Amsterdam J, Clary C, et al. A placebo-controlled, double-blind, clinical trial of paroxetine in depressed outpatients. Acta Psychiatr Scand Suppl. 1989;350:117-23. Source: PubMed. [pmid: 2530761].
2831 Rickels K, Amsterdam J, Clary C, et al. The efficacy and safety of paroxetine compared with placebo in outpatients with major depression. J Clin Psychiatry. Feb. 1992;53(Suppl):30-2. Source: PubMed. [pmid: 1531820].
2832 Rickels K, Case WG. Trazodone in depressed outpatients. Am J Psychiatry. Jun. 1982;139(6):803-6. Source: PubMed. [pmid: 7044154].
2833 Rickels K, Derivan A, Entsuah R, et al. Rapid onset of antidepressant activity with venlafaxine treatment. Depression. 1995;3(3):146-53. Source: EMBASE.
2834 Rickels K, Montgomery SA, Tourian KA, et al. Desvenlafaxine for the prevention of relapse in major depressive disorder: results of a randomized trial. J Clin Psychopharmacol. 2010;30(1):18-24. Source: PubMed. [pmid: 20075643].
2835 Rickels K, Pollack MH, Sheehan DV, et al. Efficacy of extended-release venlafaxine in nondepressed outpatients with generalized anxiety disorder. Am J Psychiatry. Jun. 2000;157(6):968-74. Source: PubMed. [pmid: 10831478].
2836 Rickels K, Schweizer E, Case WG, et al. Nefazodone in major depression: adjunctive benzodiazepine therapy and tolerability. J Clin Psychopharmacol. Apr. 1998;18(2):145-53. Source: PubMed. [pmid: 9580369].
2837 Rickels K, Schweizer E, Clary C, et al. Nefazodone and imipramine in major depression: a placebo-controlled trial. Br J Psychiatry. Jun. 1994;164(6):802-5. Source: PubMed. [pmid: 7952987].
2838 Rickels K, Smith WT, Glaudin V, et al. Comparison of two dosage regimens of fluoxetine in major depression. J Clin Psychiatry. Mar. 1985;46(3 Pt 2):38-41. Source: PubMed. [pmid: 3882680].
2839 Ried LD, Jia H, Cameon R, et al. Does prestroke depression impact poststroke depression and treatment?. American Journal of Geriatric Psychiatry. 2010;18(7):624-33. Source: EMBASE. [pmid: 20220578].
2840 Rigonatti SP, Boggio PS, Myczkowski ML, et al. Transcranial direct stimulation and fluoxetine for the treatment of depression. Eur Psychiatry. Jan. 2008;23(1):74-6. Source: PubMed. [pmid: 18023968].
2841 Rihmer Z, Akiskal H. Do antidepressants t(h)reat(en) depressives? Toward a clinically judicious formulation of the antidepressant-suicidality FDA advisory in light of declining national suicide statistics from many countries. J Affect Disord. Aug. 2006;94(1-3):3-13. Source: PubMed. [pmid: 16712945].
2842 Robert P, Montgomery SA. Citalopram in doses of 20-60 mg is effective in depression relapse prevention: a placebo-controlled 6 month study. Int Clin Psychopharmacol. Mar. Suppl 1. 1995;10:29-35. Source: PubMed. [pmid: 7622809].
2843 Roberts RL, Joyce PR, Mulder RT, et al. A common P-glycoprotein polymorphism is associated with nortriptyline-induced postural hypotension in patients treated for major depression. Pharmacogenomics J. 2002;2(3):191-6. Source: PubMed. [pmid: 12082591].
2844 Roberts RL, Mulder RT, Joyce PR, et al. No evidence of increased adverse drug reactions in cytochrome P450 CYP2D6 poor metabolizers treated with fluoxetine or nortriptyline. Hum Psychopharmacol. Jan. 2004;19(1):17-23. Source: PubMed. [pmid: 14716707].
2845 Roberts SH, Bedson E, Hughes D, et al. Folate augmentation of treatment - evaluation for depression (FolATED): protocol of a randomised controlled trial. BMC Psychiatry. 2007;7:65. Source: PubMed. [pmid: 18005429].
2846 Robertson B, Wang L, Diaz MT, et al. Effect of bupropion extended release on negative emotion processing in major depressive disorder: a pilot functional magnetic resonance imaging study. J Clin Psychiatry. Feb. 2007;68(2):261-7. Source: PubMed. [pmid: 17335325].
2847 Robertson MM, Abou SMT, Harrison DA, et al. A double-blind controlled comparison of fluoxetine and lofepramine in major depressive illness. Journal Of Psychopharmacology. 1994;8(2):98-103. Source: EMBASE. [pmid: 22298536].
2848 Robinson DS, Roberts DL, Smith JM, et al. The safety profile of nefazodone. J Clin Psychiatry. Suppl 2. 1996;57:31-8. Source: PubMed. [pmid: 8626361].
2849 Robinson RG, Jorge RE, Moser DJ, et al. Escitalopram and problem-solving therapy for prevention of poststroke depression: a randomized controlled trial. Jama. May. 28. 2008;299(20):2391-400. Source: PubMed. [pmid: 18505948].
2850 Robinson RG, Tenev V, Jorge RE. Citalopram for continuation therapy after repetitive transcranial magnetic stimulation in vascular depression. Am J Geriatr Psychiatry. Aug. 2009;17(8):682-7. Source: PubMed. [pmid: 19625785].
2851 Rocca P, Calvarese P, Faggiano F, et al. Citalopram versus sertraline in late-life nonmajor clinically significant depression: a 1-year follow-up clinical trial. J Clin Psychiatry. Mar. 2005;66(3):360-9. Source: PubMed. [pmid: 15766303].
2852 Rocca P, Fonzo V, Ravizza L, et al. A comparison of paroxetine and amisulpride in the treatment of dysthymic disorder. J Affect Disord. Aug. 2002;70(3):313-7. Source: PubMed. [pmid: 12128243].
2853 Rocca P, Marchiaro L, Rasetti R, et al. A comparison of paroxetine versus paroxetine plus amisulpride in the treatment of dysthymic disorder: efficacy and psychosocial outcomes. Psychiatry Res. Oct. 10. 2002;112(2):145-52. Source: PubMed. [pmid: 12429360].
2854 Rocha FL, Hara C. Lamotrigine augmentation in unipolar depression. Int Clin Psychopharmacol. Mar. 2003;18(2):97-9. Source: PubMed. [pmid: 12598821].
2855 Rojas G, Fritsch R, Solis J, et al. Treatment of postnatal depression in low-income mothers in primary-care clinics in Santiago, Chile: a randomised controlled trial. Lancet. Nov. 10. 2007;370(9599):1629-37. Source: PubMed. [pmid: 17993363].
2856 Rojo JE, Gibert K, Cobo J, et al. Onset of antidepressant action: a pharmacological question?. Hum Psychopharmacol. Aug. 2005;20(6):425-33. Source: PubMed. [pmid: 16106477].
2857 Romeo E, Pompili E, di Michele F, et al. Effects of fluoxetine, indomethacine and placebo on 3 alpha, 5 alpha tetrahydroprogesterone (THP) plasma levels in uncomplicated alcohol withdrawal. World J Biol Psychiatry. Apr. 2000;1(2):101-4. Source: PubMed. [pmid: 12607205].
2858 Romeo E, Strohle A, Spalletta G, et al. Effects of antidepressant treatment on neuroactive steroids in major depression. Am J Psychiatry. Jul. 1998;155(7):910-3. Source: PubMed. [pmid: 9659856].
2859 Romeo R, Patel A, Knapp M, et al. The cost-effectiveness of mirtazapine versus paroxetine in treating people with depression in primary care. Int Clin Psychopharmacol. May. 2004;19(3):125-34. Source: PubMed. [pmid: 15107654].
2860 Rooney A, Grant R. Pharmacological treatment of depression in patients with a primary brain tumour. Cochrane Database of Systematic Reviews. 2010;(3). Source: The Cochrane Library.
2861 Roose SP. Tolerability and patient compliance. J Clin Psychiatry. Suppl 17. 1999;60:14-7. discussion 46-8. Source: PubMed. [pmid: 10446736].
2862 Roose SP, Glassman AH, Attia E, et al. Comparative efficacy of selective serotonin reuptake inhibitors and tricyclics in the treatment of melancholia. Am J Psychiatry. Dec. 1994;151(12):1735-9. Source: PubMed. [pmid: 7977878].
2863 Roose SP, Glassman AH, Attia E, et al. Cardiovascular effects of fluoxetine in depressed patients with heart disease. Am J Psychiatry. May. 1998;155(5):660-5. Source: PubMed. [pmid: 9585718].
2864 Roose SP, Glassman AH, Giardina EG, et al. Cardiovascular effects of imipramine and bupropion in depressed patients with congestive heart failure. J Clin Psychopharmacol. Aug. 1987;7(4):247-51. Source: PubMed. [pmid: 3114333].
2865 Roose SP, Laghrissi-Thode F, Kennedy JS, et al. Comparison of paroxetine and nortriptyline in depressed patients with ischemic heart disease. Jama. Jan. 28. 1998;279(4):287-91. Source: PubMed. [pmid: 9450712].
2866 Roose SP, Nelson JC, Salzman C, et al. Open-label study of mirtazapine orally disintegrating tablets in depressed patients in the nursing home. Curr Med Res Opin. 2003;19(8):737-46. Source: PubMed. [pmid: 14687445].
2867 Roose SP, Sackeim HA, Krishnan KR, et al. Antidepressant pharmacotherapy in the treatment of depression in the very old: a randomized, placebo-controlled trial. Am J Psychiatry. Nov. 2004;161(11):2050-9. Source: PubMed. [pmid: 15514406].
2868 Roose SP, Suthers KM. Antidepressant response in late-life depression. J Clin Psychiatry. Suppl 10. 1998;59:4-8. Source: PubMed. [pmid: 9720475].
2869 Ropert R. Fluoxetine versus clomipramine in major depressive disorders. Int Clin Psychopharmacol. 1989;4(Suppl):189-95. Source: PubMed.
2870 Ros LT. A case of “double” depression under outpatient treatment conditions. World J Biol Psychiatry. Jul. 2004;5(3):161-3. Source: PubMed. [pmid: 15346541].
2871 Rosa AR, Cruz N, Franco C, et al. Why do clinicians maintain antidepressants in some patients with acute mania? Hints from the European Mania in Bipolar longitudinal evaluation of medication (EMBLEM), a large naturalistic study. Journal of Clinical Psychiatry. 2010;71(8):1000-6. Source: EMBASE. [pmid: 20361912].
2872 Roschke J, Wolf C, Muller MJ, et al. The benefit from whole body acupuncture in major depression. J Affect Disord. Jan-Mar. 2000;57(1-3):73-81. Source: PubMed. [pmid: 10708818].
2873 Roscoe JA, Morrow GR, Hickok JT, et al. Effect of paroxetine hydrochloride (Paxil) on fatigue and depression in breast cancer patients receiving chemotherapy. Breast Cancer Res Treat. Feb. 2005;89(3):243-9. Source: PubMed. [pmid: 15754122].
2874 Rosel P, Arranz B, Vallejo J, et al. Altered [3H]imipramine and 5-HT2 but not [3H]paroxetine binding sites in platelets from depressed patients. J Affect Disord. Jan-Mar. 1999;52(1-3):225-33. Source: PubMed. [pmid: 10357037].
2875 Rosel P, Menchon JM, Vallejo J, et al. Platelet [3H]imipramine and [3H]paroxetine binding in depressed patients. J Affect Disord. Jun. 1997;44(1):79-85. Source: PubMed. [pmid: 9186805].
2876 Rosen J, Mulsant BH, Pollock BG. Sertraline in the treatment of minor depression in nursing home residents: a pilot study. Int J Geriatr Psychiatry. Feb. 2000;15(2):177-80. Source: PubMed. [pmid: 10679849].
2877 Rosenbaum JF, Fava M, Hoog SL, et al. Selective serotonin reuptake inhibitor discontinuation syndrome: a randomized clinical trial. Biol Psychiatry. Jul. 15. 1998;44(2):77-87. Source: PubMed. [pmid: 9646889].
2878 Rosenbaum JF, Zajecka J. Clinical management of antidepressant discontinuation. J Clin Psychiatry. Suppl 7. 1997;58:37-40. Source: PubMed. [pmid: 9219493].
2879 Rosenberg C, Damsbo N, Fuglum E, et al. Citalopram and imipramine in the treatment of depressive patients in general practice. A Nordic multicentre clinical study. Int Clin Psychopharmacol. Mar. Suppl 1. 1994;9:41-8. Source: PubMed. [pmid: 8021437].
2880 Rosenberg C, Lauritzen L, Brix J, et al. Citalopram versus amitriptyline in elderly depressed patients with or without mild cognitive dysfunction: a danish multicentre trial in general practice. Psychopharmacol Bull. 2007;40(1):63-73. Source: PubMed. [pmid: 17285097].
2881 Rosenberg PB, Drye LT, Martin BK, et al. Sertraline for the treatment of depression in alzheimer disease. American Journal of Geriatric Psychiatry. 2010;18(2):136-45. Source: EMBASE. [pmid: 20087081].
2882 Rosenberg PB, Mielke MM, Lyketsos CG. Caregiver assessment of patients' depression in Alzheimer disease: longitudinal analysis in a drug treatment study. Am J Geriatr Psychiatry. Sep. 2005;13(9):822-6. Source: PubMed. [pmid: 16166413].
2883 Rosenstein DL, Takeshita J, Nelson JC. Fluoxetine-induced elevation and prolongation of tricyclic levels in overdose. Am J Psychiatry. Jun. 1991;148(6):807. Source: PubMed. [pmid: 2035725].
2884 Rosenthal J, Hemlock C, Hellerstein DJ, et al. A preliminary study of serotonergic antidepressants in treatment of dysthymia. Prog Neuropsychopharmacol Biol Psychiatry. 1992;16(6):933-41. Source: PubMed. [pmid: 1513932].
2885 Rossini D, Magri L, Lucca A, et al. Does rTMS hasten the response to escitalopram, sertraline, or venlafaxine in patients with major depressive disorder? A double-blind, randomized, sham-controlled trial. J Clin Psychiatry. Dec. 2005;66(12):1569-75. Source: PubMed. [pmid: 16401159].
2886 Rossini D, Serretti A, Franchini L, et al. Sertraline versus fluvoxamine in the treatment of elderly patients with major depression: a double-blind, randomized trial. J Clin Psychopharmacol. Oct. 2005;25(5):471-5. Source: PubMed. [pmid: 16160624].
2887 Roth D, Mattes J, Sheehan KH, et al. A double-blind comparison of fluvoxamine, desipramine and placebo in outpatients with depression. Prog Neuropsychopharmacol Biol Psychiatry. 1990;14(6):929-39. Source: PubMed. [pmid: 2126144].
2888 Rothbaum BO, Killeen TK, Davidson JR, et al. Placebo-controlled trial of rispeyidone augmentation for selective seyotonin seyotonin inhibitor-resistant civilian posttraumatic stress disorder. Journal of Clinical Psychiatry. 04. 01. 2008;69(Apr):520-5. Source: PsycINFO. [pmid: 18278987].
2889 Rothschild AJ. Selective serotonin reuptake inhibitor-induced sexual dysfunction: efficacy of a drug holiday. Am J Psychiatry. Oct. 1995;152(10):1514-6. Source: PubMed. [pmid: 7573593].
2890 Rothschild AJ. Sexual side effects of antidepressants. J Clin Psychiatry. Suppl 11. 2000;61:28-36. Source: PubMed. [pmid: 10926052].
2891 Rothschild AJ, Duval SE. How long should patients with psychotic depression stay on the antipsychotic medication?. J Clin Psychiatry. Apr. 2003;64(4):390-6. Source: PubMed. [pmid: 12716238].
2892 Rothschild AJ, Locke CA. Reexposure to fluoxetine after serious suicide attempts by three patients: the role of akathisia. J Clin Psychiatry. Dec. 1991;52(12):491-3. Source: PubMed. [pmid: 1752848].
2893 Rothschild AJ, Williamson DJ, Tohen MF, et al. A double-blind, randomized study of olanzapine and olanzapine/fluoxetine combination for major depression with psychotic features. J Clin Psychopharmacol. Aug. 2004;24(4):365-73. Source: PubMed. [pmid: 15232326].
2894 Rottach KG, Schaner BM, Kirch MH, et al. Restless legs syndrome as side effect of second generation antidepressants. J Psychiatr Res. Nov. 2008;43(1):70-5. Source: PubMed. [pmid: 18468624].
2895 Rottmann CN. SSRIs and the syndrome of inappropriate antidiuretic hormone secretion. Am J Nurs. Jan. 2007;107(1):51-8. quiz 8-9. Source: PubMed. [pmid: 17200634].
2896 Rowbotham MC, Jones RT, Benowitz NL, et al. Trazodone-oral cocaine interactions. Arch Gen Psychiatry. Sep. 1984;41(9):895-9. Source: PubMed. [pmid: 6380447].
2897 Roxanas M, Hibbert E, Field M. Venlafaxine hyponatraemia: incidence, mechanism and management. Aust N Z J Psychiatry. May. 2007;41(5):411-8. Source: PubMed. [pmid: 17464733].
2898 Roy A, Cole K, Goldman Z, et al. Fluoxetine treatment of postpartum depression. Am J Psychiatry. Aug. 1993;150(8):1273. Source: PubMed. [pmid: 8328582].
2899 Royall DR, Cordes JA, Roman G, et al. Sertraline improves executive function in patients with vascular cognitive impairment. J Neuropsychiatry Clin Neurosci. 2009;21(4):445-54. Source: PubMed. [pmid: 19996254].
2900 Roy-Byrne PP, Pages KP, Russo JE, et al. Nefazodone treatment of major depression in alcohol-dependent patients: a double-blind, placebo-controlled trial. J Clin Psychopharmacol. Apr. 2000;20(2):129-36. Source: PubMed. [pmid: 10770449].
2901 Roy-Byrne PP, Perera P, Pitts CD, et al. Paroxetine response and tolerability among ethnic minority patients with mood or anxiety disorders: a pooled analysis. J Clin Psychiatry. Oct. 2005;66(10):1228-33. Source: PubMed. [pmid: 16259535].
2902 Rubey RN, Johnson MR, Emmanuel N, et al. Fluoxetine in the treatment of anger: an open clinical trial. J Clin Psychiatry. Sep. 1996;57(9):398-401. Source: PubMed. [pmid: 9746447].
2903 Rubio G, San L, Lopez-Munoz F, et al. Reboxetine adjunct for partial or nonresponders to antidepressant treatment. J Affect Disord. Jul. 2004;81(1):67-72. Source: PubMed. [pmid: 15183602].
2904 Rucklidge JJ, Harrison R. Successful treatment of bipolar disorder II and ADHD with a micronutrient formula: A case study. CNS spectrums. 2010;15(5):289-95. Source: EMBASE. [pmid: 20448519].
2905 Rudolph RL. Achieving remission from depression with venlafaxine and venlafaxine extended release: a literature review of comparative studies with selective serotonin reuptake inhibitors. Acta Psychiatr Scand Suppl. 2002;(415):24-30. Source: PubMed. [pmid: 12492770].
2906 Rudolph RL, Entsuah R, Chitra R. A meta-analysis of the effects of venlafaxine on anxiety associated with depression. J Clin Psychopharmacol. Apr. 1998;18(2):136-44. Source: PubMed. [pmid: 9555599].
2907 Rudolph RL, Fabre LF, Feighner JP, et al. A randomized, placebo-controlled, dose-response trial of venlafaxine hydrochloride in the treatment of major depression. J Clin Psychiatry. Mar. 1998;59(3):116-22. Source: PubMed. [pmid: 9541154].
2908 Rudolph RL, Feiger AD. A double-blind, randomized, placebo-controlled trial of once-daily venlafaxine extended release (XR) and fluoxetine for the treatment of depression. J Affect Disord. Dec. 1999;56(2-3):171-81. Source: PubMed. [pmid: 10701474].
2909 Rufer M, Hand I, Alsleben H, et al. Long-term course and outcome of obsessive-compulsive patients after cognitive-behavioral therapy in combination with either fluvoxamine or placebo: a 7-year follow-up of a randomized double-blind trial. Eur Arch Psychiatry Clin Neurosci. Apr. 2005;255(2):121-8. Source: PubMed. [pmid: 15812606].
2910 Ruhe HG, Booij J, v Weert HC, et al. Evidence why paroxetine dose escalation is not effective in major depressive disorder: a randomized controlled trial with assessment of serotonin transporter occupancy. Neuropsychopharmacology. Mar. 2009;34(4):999-1010. Source: PubMed. [pmid: 18830236].
2911 Ruhrmann S, Kasper S, Hawellek B, et al. Effects of fluoxetine versus bright light in the treatment of seasonal affective disorder. Psychol Med. Jul. 1998;28(4):923-33. Source: PubMed. [pmid: 9723147].
2912 Rupprecht R, Strohle A, Hermann B, et al. Neuroactive steroid concentrations following metyrapone administration in depressed patients and healthy volunteers. Biol Psychiatry. Nov. 1. 1998;44(9):912-4. Source: PubMed. [pmid: 9807647].
2913 Rush AJ. Limitations in efficacy of antidepressant monotherapy. J Clin Psychiatry. Suppl 10. 2007;68:8-10. Source: PubMed. [pmid: 17900203].
2914 Rush AJ. STAR*D: what have we learned?. Am J Psychiatry. Feb. 2007;164(2):201-4. Source: PubMed. [pmid: 17267779].
2915 Rush AJ, Armitage R, Gillin JC, et al. Comparative effects of nefazodone and fluoxetine on sleep in outpatients with major depressive disorder. Biol Psychiatry. Jul. 1. 1998;44(1):3-14. Source: PubMed. [pmid: 9646878].
2916 Rush AJ, Batey SR, Donahue RM, et al. Does pretreatment anxiety predict response to either bupropion SR or sertraline?. J Affect Disord. 2001;64(1):81-7. Source: PubMed. [pmid: 11292522].
2917 Rush AJ, Bernstein IH, Trivedi MH, et al. An evaluation of the quick inventory of depressive symptomatology and the hamilton rating scale for depression: a sequenced treatment alternatives to relieve depression trial report. Biol Psychiatry. Mar. 15. 2006;59(6):493-501. Source: PubMed. [pmid: 16199008].
2918 Rush AJ, Bose A. Escitalopram in clinical practice: results of an open-label trial in a naturalistic setting. Depress Anxiety. 2005;21(1):26-32. Source: PubMed. [pmid: 15786487].
2919 Rush AJ, Bose A, Heydorn WE. Naturalistic study of the early psychiatric use of citalopram in the United States. Depress Anxiety. 2002;16(3):121-7. Source: PubMed. [pmid: 12415537].
2920 Rush AJ, Carmody TJ, Haight BR, et al. Does pretreatment insomnia or anxiety predict acute response to bupropion SR?. Ann Clin Psychiatry. Jan-Mar. 2005;17(1):1-9. Source: PubMed. [pmid: 15941026].
2921 Rush AJ, Fava M, Wisniewski SR, et al. Sequenced treatment alternatives to relieve depression (STAR*D): rationale and design. Control Clin Trials. Feb. 2004;25(1):119-42. Source: PubMed. [pmid: 15061154].
2922 Rush AJ, Kilner J, Fava M, et al. Clinically Relevant Findings from STAR*D. Psychiatric Annals. 2008;38(3):188-93. Source: Handsearch.
2923 Rush AJ, Kraemer HC, Sackeim HA, et al. Report by the ACNP Task Force on response and remission in major depressive disorder. Neuropsychopharmacology. 2006;31(9):1841-53. Source: Scopus. [pmid: 16794566].
2924 Rush AJ, Trivedi M, Fava M. Depression, IV: STAR*D treatment trial for depression. Am J Psychiatry. Feb. 2003;160(2):237. Source: PubMed. [pmid: 12562566].
2925 Rush AJ, Trivedi MH, Carmody TJ, et al. Response in relation to baseline anxiety levels in major depressive disorder treated with bupropion sustained release or sertraline. Neuropsychopharmacology. Jul. 2001;25(1):131-8. Source: PubMed. [pmid: 11377926].
2926 Rush AJ, Trivedi MH, Carmody TJ, et al. Self-reported depressive symptom measures: sensitivity to detecting change in a randomized, controlled trial of chronically depressed, nonpsychotic outpatients. Neuropsychopharmacology. Feb. 2005;30(2):405-16. Source: PubMed. [pmid: 15578008].
2927 Rush AJ, Trivedi MH, Wisniewski SR, et al. Acute and Longer-Term Outcomes in Depressed Outpatients Requiring One or Several Treatment Steps: A STAR*D Report. Am J Psychiatry. 2006;163(11):1905-17. Source: PubMed. [pmid: 17074942].
2928 Rush AJ, Trivedi MH, Wisniewski SR, et al. Bupropion-SR, sertraline, or venlafaxine-XR after failure of SSRIs for depression. N Engl J Med. Mar. 23. 2006;354(12):1231-42. Source: PubMed. [pmid: 16554525].
2929 Rush AJ, Wisniewski SR, Warden D, et al. Selecting among second-step antidepressant medication monotherapies: predictive value of clinical, demographic, or first-step treatment features. Arch Gen Psychiatry. 2008;65(8):870-80. Source: PubMed. [pmid: 18678792].
2930 Rush AJ, Zimmerman M, Wisniewski SR, et al. Comorbid psychiatric disorders in depressed outpatients: demographic and clinical features. J Affect Disord. Jul. 2005;87(1):43-55. Source: PubMed. [pmid: 15894381].
2931 Russell JM, Berndt ER, Miceli R, et al. Course and cost of treatment for depression with fluoxetine, paroxetine, and sertraline. Am J Manag Care. May. 1999;5(5):597-606. Source: PubMed. [pmid: 10537866].
2932 Russell JM, Koran LM, Rush J, et al. Effect of concurrent anxiety on response to sertraline and imipramine in patients with chronic depression. Depress Anxiety. 2001;13(1):18-27. Source: PubMed. [pmid: 11233456].
2933 Russell JM, Kornstein SG, Shea MT, et al. Chronic depression and comorbid personality disorders: response to sertraline versus imipramine. J Clin Psychiatry. May. 2003;64(5):554-61. Source: PubMed. [pmid: 12755659].
2934 Ruther E, Degner D, Munzel U, et al. Antidepressant action of sulpiride. Results of a placebo-controlled double-blind trial. Pharmacopsychiatry. Jul. 1999;32(4):127-35. Source: PubMed. [pmid: 10505482].
2935 Rutherford B, Sneed J, Devanand D, et al. Antidepressant study design affects patient expectancy: a pilot study. Psychol Med. May. 2010;40(5):781-8. Source: PubMed. [pmid: 19732481].
2936 Rymaszewska J, Ramsey D, Chladzinska-Kiejna S. Whole-body cryotherapy as adjunct treatment of depressive and anxiety disorders. Arch Immunol Ther Exp (Warsz). Jan-Feb. 2008;56(1):63-8. Source: PubMed. [pmid: 18250970].
2937 Sabbe B, Hulstijn W, van Hoof J, et al. Retardation in depression: assessment by means of simple motor tasks. J Affect Disord. Sep. 1999;55(1):39-44. Source: PubMed. [pmid: 10512604].
2938 Sackeim HA, Brannan SK, Rush AJ, et al. Durability of antidepressant response to vagus nerve stimulation (VNS[trademark]). International Journal of Neuropsychopharmacology. 2007;10(6):817-26. Source: EMBASE. [pmid: 17288644].
2939 Sackeim HA, Dillingham EM, Prudic J, et al. Effect of concomitant pharmacotherapy on electroconvulsive therapy outcomes: short-term efficacy and adverse effects. Arch Gen Psychiatry. 2009;66(7):729-37. Source: PubMed. [pmid: 19581564].
2940 Sacristan JA, Gilaberte I, Boto B, et al. Cost-effectiveness of fluoxetine plus pindolol in patients with major depressive disorder: results from a randomized, double-blind clinical trial. Int Clin Psychopharmacol. Mar. 2000;15(2):107-13. Source: PubMed. [pmid: 10759342].
2941 Safarinejad MR. The effects of the adjunctive bupropion on male sexual dysfunction induced by a selective serotonin reuptake inhibitor: a double-blind placebo-controlled and randomized study. BJU Int. 2010;106(6):840-7. Source: PubMed. [pmid: 20067456].
2942 Saghafi R, Brown C, Butters MA, et al. Predicting 6-week treatment response to escitalopram pharmacotherapy in late-life major depressive disorder. Int J Geriatr Psychiatry. Nov. 2007;22(11):1141-6. Source: PubMed. [pmid: 17486678].
2943 Sagud M, Pivac N, Muck-Seler D, et al. Effects of sertraline treatment on plasma cortisol, prolactin and thyroid hormones in female depressed patients. Neuropsychobiology. 2002;45(3):139-43. Source: PubMed. [pmid: 11979064].
2944 Sagud M, Pivac N, Mustapic M, et al. The effect of lamotrigine on platelet serotonin concentration in patients with bipolar depression. Psychopharmacology (Berl). May. 2008;197(4):683-5. Source: PubMed. [pmid: 18246328].
2945 Saito S, Takahashi N, Ishihara R, et al. Association study between vesicle-associated membrane protein 2 gene polymorphisms and fluvoxamine response in Japanese major depressive patients. Neuropsychobiology. 2006;54(4):226-30. Source: PubMed. [pmid: 17356306].
2946 Saiz-Ruiz J, Ibanez A, Diaz-Marsa M, et al. Nefazodone in the treatment of elderly patients with depressive disorders: a prospective, observational study. CNS Drugs. 2002;16(9):635-43. Source: PubMed. [pmid: 12153334].
2947 Saiz-Ruiz J, Ibanez A, Diaz-Marsa M, et al. Efficacy of venlafaxine in major depression resistant to selective serotonin reuptake inhibitors. Prog Neuropsychopharmacol Biol Psychiatry. Oct. 2002;26(6):1129-34. Source: PubMed. [pmid: 12452535].
2948 Saiz-Ruiz J, Montes JM, Ibanez A, et al. Assessment of sexual functioning in depressed patients treated with mirtazapine: a naturalistic 6-month study. Hum Psychopharmacol. Aug. 2005;20(6):435-40. Source: PubMed. [pmid: 16106478].
2949 Sakado K, Sato T, Uehara T, et al. Perceived parenting pattern and response to antidepressants in patients with major depression. J Affect Disord. Jan-Mar. 1999;52(1-3):59-66. Source: PubMed. [pmid: 10357018].
2950 Saletu-Zyhlarz GM, Abu-Bakr MH, Anderer P, et al. Insomnia in depression: differences in objective and subjective sleep and awakening quality to normal controls and acute effects of trazodone. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 2002;26(2):249-60. Source: PubMed. [pmid: 11817501].
2951 Saletu-Zyhlarz GM, Abu-Bakr MH, Anderer P, et al. Insomnia related to dysthymia: polysomnographic and psychometric comparison with normal controls and acute therapeutic trials with trazodone. Neuropsychobiology. 2001;44(3):139-49. Source: PubMed. [pmid: 11586054].
2952 Salih SB, Al Qahtani M, Al Anazi T, et al. Metabolic acidosis and generalized seizures secondary to citalopram overdose: A case report. Journal of Clinical Pharmacy and Therapeutics. 2010;35(4):479-82. Source: PsycINFO. [pmid: 20831549].
2953 Salloway S, Boyle PA, Correia S, et al. The relationship of MRI subcortical hyperintensities to treatment response in a trial of sertraline in geriatric depressed outpatients. Am J Geriatr Psychiatry. Jan-Feb. 2002;10(1):107-11. Source: PubMed. [pmid: 11790641].
2954 Salloway S, Correia S, Boyle P, et al. MRI subcortical hyperintensities in old and very old depressed outpatients: the important role of age in late-life depression. J Neurol Sci. Nov. 15. 2002;203-204:227-33. Source: PubMed. [pmid: 12417389].
2955 Salminen JK, Karlsson H, Hietala J, et al. Short-term psychodynamic psychotherapy and fluoxetine in major depressive disorder: a randomized comparative study. Psychother Psychosom. 2008;77(6):351-7. Source: PubMed. [pmid: 18701831].
2956 Salomon RM, Ripley B, Kennedy JS, et al. Diurnal variation of cerebrospinal fluid hypocretin-1 (Orexin-A) levels in control and depressed subjects. Biol Psychiatry. Jul. 15. 2003;54(2):96-104. Source: PubMed. [pmid: 12873798].
2957 Salzman C, Jimerson D, Vasile R, et al. Response to SSRI antidepressants correlates with reduction in plasma HVA: pilot study. Biol Psychiatry. Oct. 15. 1993;34(8):569-71. Source: PubMed. [pmid: 8274586].
2958 Samuelian JC, Hackett D. A randomized, double-blind, parallel-group comparison of venlafaxine and clomipramine in outpatients with major depression. J Psychopharmacol. 1998;12(3):273-8. Source: PubMed. [pmid: 10958254].
2959 San L, Arranz B. Mirtazapine: Only for depression?. Acta Neuropsychiatrica. Jun-Aug. 2006. 2006;18(3):130-43. Source: PsycINFO.
2960 Sanacora G, Berman RM, Cappiello A, et al. Addition of the alpha2-antagonist yohimbine to fluoxetine: effects on rate of antidepressant response. Neuropsychopharmacology. Jun. 2004;29(6):1166-71. Source: PubMed. [pmid: 15010697].
2961 Sanders J, Whitty P, Murray D, et al. Delusions or obsessions: the same only different? A case report. Psychopathology. 2006;39(1):45-8. Source: PubMed. [pmid: 16282719].
2962 Sandor P, Baker B, Irvine J, et al. Effectiveness of fluoxetine and doxepin in treatment of melancholia in depressed patients. Depress Anxiety. 1998;7(2):69-72. Source: PubMed. [pmid: 9614594].
2963 Sanger TM, Grundy SL, Gibson PJ, et al. Long-term olanzapine therapy in the treatment of bipolar I disorder: an open-label continuation phase study. J Clin Psychiatry. Apr. 2001;62(4):273-81. Source: PubMed. [pmid: 11379842].
2964 Sansone RA, Sansone LA. Duloxetine-related acute dysphoria. Psychiatry. Nov. 2007. 2007;4(11):65-7. Source: PsycINFO.
2965 Sansone RA, Sansone LA. Bupropion-induced neck and shoulder pain. Pharmacopsychiatry. Sep. 2009;42(5):203-4. Source: PubMed. [pmid: 19724984].
2966 Santos MA, Rocha FL, Hara C. Efficacy and safety of antidepressant augmentation with lamotrigine in patients with treatment-resistant depression: A randomized, placebo-controlled, double-blind study. Primary Care Companion to the Journal of Clinical Psychiatry. 2008;10(3):187-90. Source: EMBASE.
2967 Santos PM, Lopez-Garcia P, Navarro JS, et al. False positive phencyclidine results caused by venlafaxine. Am J Psychiatry. Feb. 2007;164(2):349. Source: PubMed. [pmid: 17267806].
2968 Saraf M, Schrader G. Seizure associated with sertraline. Aust N Z J Psychiatry. Dec. 1999;33(6):944-5. Source: PubMed. [pmid: 10619229].
2969 Sarandol A, Sarandol E, Eker SS, et al. Major depressive disorder is accompanied with oxidative stress: Short-term antidepressant treatment does not alter oxidative - Antioxidative systems. Human Psychopharmacology. 2007;22(2):67-73. Source: EMBASE. [pmid: 17299810].
2970 Sarchiapone M, Amore M, De Risio S, et al. Mirtazapine in the treatment of panic disorder: an open-label trial. Int Clin Psychopharmacol. Jan. 2003;18(1):35-8. Source: PubMed. [pmid: 12490773].
2971 Sargent PA, Williamson DJ, Cowen PJ. Brain 5-HT neurotransmission during paroxetine treatment. Br J Psychiatry. Jan. 1998:49-52. Source: PubMed.
2972 Sarginson JE, Lazzeroni LC, Ryan HS, et al. FKBP5 polymorphisms and antidepressant response in geriatric depression. American Journal of Medical Genetics, Part B: Neuropsychiatric Genetics. 2010;153(2):554-60. Source: EMBASE.
2973 Satterlee WG, Faries D. The effects of fluoxetine on symptoms of insomnia in depressed patients. Psychopharmacol Bull. 1995;31(2):227-37. Source: PubMed. [pmid: 7491373].
2974 Sattler HD, Richter P, Fritzsche M, et al. Neurophysiologic tests during antidepressive treatment - an exploratory study. Pharmacopsychiatry. Nov. 2000;33(6):229-33. Source: PubMed. [pmid: 11147931].
2975 Sauer H, Huppertz-Helmhold S, Dierkes W. Efficacy and safety of venlafaxine ER vs. amitriptyline ER in patients with major depression of moderate severity. Pharmacopsychiatry. Sep. 2003;36(5):169-75. Source: PubMed. [pmid: 14571350].
2976 Saules KK, Schuh LM, Arfken CL, et al. Double-blind placebo-controlled trial of fluoxetine in smoking cessation treatment including nicotine patch and cognitive-behavioral group therapy. Am J Addict. Oct-Dec. 2004;13(5):438-46. Source: PubMed. [pmid: 15764422].
2977 Sava FA, Yates BT, Lupu V, et al. Cost-effectiveness and cost-utility of cognitive therapy, rational emotive behavioral therapy, and fluoxetine (Prozac) in treating depression: a randomized clinical trial. J Clin Psychol. Jan. 2009;65(1):36-52. Source: PubMed. [pmid: 19051275].
2978 Savaskan E, Müller SE, Böhringer A, et al. Antidepressive therapy with escitalopram improves mood, cognitive symptoms, and identity memory for angry faces in elderly depressed patients. International Journal of Neuropsychopharmacology. May. 2008. 2008;11(3):381-8. Source: PsycINFO. [pmid: 17697395].
2979 Sawada N, Uchida H, Suzuki T, et al. Persistence and compliance to antidepressant treatment in patients with depression: a chart review. BMC Psychiatry. 2009;9:38. Source: PubMed. [pmid: 19531229].
2980 Saxena S, Brody AL, Ho ML, et al. Differential cerebral metabolic changes with paroxetine treatment of obsessive-compulsive disorder vs major depression. Arch Gen Psychiatry. Mar. 2002;59(3):250-61. Source: PubMed. [pmid: 11879163].
2981 Saxena S, Brody AL, Ho ML, et al. Differential brain metabolic predictors of response to paroxetine in obsessive-compulsive disorder versus major depression. Am J Psychiatry. Mar. 2003;160(3):522-32. Source: PubMed. [pmid: 12611834].
2982 Sayyah M, Feizy F, Boostani H. A preliminary randomized double-blind clinical trial on efficacy of estrogen after hysterectomy in postmenopausal women with major depression disorder. Minerva Psichiatrica. 2010;51(2):73-7. Source: EMBASE.
2983 Scardigli G, Jans G. Comparative double-blind study on efficacy and side-effects of trazodone, nomifensine, mianserin in elderly patients. Adv Biochem Psychopharmacol. 1982;32:229-36. Source: PubMed. [pmid: 7046366].
2984 Schaefer M, Schwaiger M, Garkisch AS, et al. Prevention of interferon-alpha associated depression in psychiatric risk patients with chronic hepatitis C. J Hepatol. Jun. 2005;42(6):793-8. Source: PubMed. [pmid: 15885349].
2985 Schaffer A, Zuker P, Levitt A. Randomized, double-blind pilot trial comparing lamotrigine versus citalopram for the treatment of bipolar depression. Journal of Affective Disorders. Nov. 2006. 2006;96(1):95-9. Source: PsycINFO. [pmid: 16820213].
2986 Scharf MB, Sachais BA. Sleep laboratory evaluation of the effects and efficacy of trazodone in depressed insomniac patients. J Clin Psychiatry. Sep. 1990;51(Suppl):13-7. Source: PubMed. [pmid: 2211559].
2987 Scharnholz B, Lederbogen F, Feuerhack A, et al. Does night-time cortisol excretion normalize in the long-term course of depression?. Pharmacopsychiatry. Jul. 2010;43(5):161-5. Source: PubMed. [pmid: 20191443].
2988 Scharnholz B, Weber-Hamann B, Lederbogen F, et al. Antidepressant treatment with mirtazapine, but not venlafaxine, lowers cortisol concentrations in saliva: a randomised open trial. Psychiatry Res. May. 15. 2010;177(1-2):109-13. Source: PubMed. [pmid: 20381159].
2989 Schatzberg A, Roose S. A double-blind, placebo-controlled study of venlafaxine and fluoxetine in geriatric outpatients with major depression. Am J Geriatr Psychiatry. 2006;14(4):361-70. Source: PubMed. [pmid: 16582045].
2990 Schatzberg AF. Noradrenergic versus serotonergic antidepressants: predictors of treatment response. Journal Of Clinical Psychiatry. 1998;59(Suppl 14):15-8. Source: EMBASE. [pmid: 9818626].
2991 Schatzberg AF. Safety and tolerability of antidepressants: Weighing the impact on treatment decisions. Journal of Clinical Psychiatry. 2007;68(SUPPL. 8):26-34. Source: Scopus. [pmid: 17640155].
2992 Schatzberg AF, Kremer C, Rodrigues HE, et al. Double-blind, randomized comparison of mirtazapine and paroxetine in elderly depressed patients. Am J Geriatr Psychiatry. Sep-Oct. 2002;10(5):541-50. Source: PubMed. [pmid: 12213688].
2993 Schatzberg AF, Rush AJ, Arnow BA, et al. Chronic depression: medication (nefazodone) or psychotherapy (CBASP) is effective when the other is not. Arch Gen Psychiatry. May. 2005;62(5):513-20. Source: PubMed. [pmid: 15867104].
2994 Schenck CH, Mahowald MW, Kim SW, et al. Prominent eye movements during NREM sleep and REM sleep behavior disorder associated with fluoxetine treatment of depression and obsessive-compulsive disorder. Sleep. Jun. 1992;15(3):226-35. Source: PubMed. [pmid: 1621023].
2995 Schenck CH, Mandell M, Lewis GM. A case of monthly unipolar psychotic depression with suicide attempt by self-burning: selective response to bupropion treatment. Compr Psychiatry. Sep-Oct. 1992;33(5):353-6. Source: PubMed. [pmid: 1395556].
2996 Schillerstrom JE, Seaman JS. Modafinil augmentation of mirtazapine in a failure-to-thrive geriatric inpatient. Int J Psychiatry Med. 2002;32(4):405-10. Source: PubMed. [pmid: 12779190].
2997 Schins A, Hamulyak K, Scharpe S, et al. Whole blood serotonin and platelet activation in depressed post-myocardial infarction patients. Life Sci. Dec. 24. 2004;76(6):637-50. Source: PubMed. [pmid: 15567189].
2998 Schirman S, Kronenberg S, Apter A, et al. Effectiveness and tolerability of citalopram for the treatment of depression and anxiety disorders in children and adolescents: An open-label study. Journal of Neural Transmission. 2010;117(1):139-45. Source: PsycINFO. [pmid: 19851705].
2999 Schittecatte M, Dumont F, Machowski R, et al. Effects of mirtazapine on sleep polygraphic variables in major depression. Neuropsychobiology. 2002;46(4):197-201. Source: PubMed. [pmid: 12566938].
3000 Schlake HP, Kuhs H, Rolf LH, et al. Platelet 5-HT transport in depressed patients under double-blind treatment with paroxetine versus amitriptyline. Acta Psychiatr Scand Suppl. 1989;350:149-51. Source: PubMed. [pmid: 2530775].
3001 Schmaling KB, Dimidjian S, Katon W, et al. Response styles among patients with minor depression and dysthymia in primary care. J Abnorm Psychol. May. 2002;111(2):350-6. Source: PubMed. [pmid: 12003456].
3002 Schmid DA, Wichniak A, Uhr M, et al. Changes of sleep architecture, spectral composition of sleep EEG, the nocturnal secretion of cortisol, ACTH, GH, prolactin, melatonin, ghrelin, and leptin, and the DEX-CRH test in depressed patients during treatment with mirtazapine. Neuropsychopharmacology. Apr. 2006. 2006;31(4):832-44. Source: PsycINFO. [pmid: 16237393].
3003 Schmidt ME, Fava M, Robinson JM, et al. The efficacy and safety of a new enteric-coated formulation of fluoxetine given once weekly during the continuation treatment of major depressive disorder. J Clin Psychiatry. Nov. 2000;61(11):851-7. Source: PubMed. [pmid: 11105738].
3004 Schmidt ME, Fava M, Zhang S, et al. Treatment approaches to major depressive disorder relapse. Part 1: dose increase. Psychother Psychosom. Jul-Aug. 2002;71(4):190-4. Source: PubMed. [pmid: 12097783].
3005 Schmitt JA, Ramaekers JG, Kruizinga MJ, et al. Additional dopamine reuptake inhibition attenuates vigilance impairment induced by serotonin reuptake inhibition in man. J Psychopharmacol. Sep. 2002;16(3):207-14. Source: PubMed. [pmid: 12236626].
3006 Schmitt L, Tonnoir B, Arbus C. Safety and efficacy of oral escitalopram as continuation treatment of intravenous citalopram in patients with major depressive disorder. Neuropsychobiology. 2006;54(4):201-7. Source: PubMed. [pmid: 17337913].
3007 Schmitz JM, Averill P, Stotts AL, et al. Fluoxetine treatment of cocaine-dependent patients with major depressive disorder. Drug Alcohol Depend. Aug. 1. 2001;63(3):207-14. Source: PubMed. [pmid: 11418225].
3008 Schneeweiss S, Patrick AR, Solomon DH, et al. Variation in the risk of suicide attempts and completed suicides by antidepressant agent in adults: a propensity score-adjusted analysis of 9 years' data. Arch Gen Psychiatry. May. 2010;67(5):497-506. Source: PubMed. [pmid: 20439831].
3009 Schneider LS, Nelson JC, Clary CM, et al. An 8-week multicenter, parallel-group, double-blind, placebo-controlled study of sertraline in elderly outpatients with major depression. Am J Psychiatry. Jul. 2003;160(7):1277-85. Source: PubMed. [pmid: 12832242].
3010 Schneider LS, Small GW, Clary CM. Estrogen replacement therapy and antidepressant response to sertraline in older depressed women. Am J Geriatr Psychiatry. Fall. 2001;9(4):393-9. Source: PubMed. [pmid: 11739065].
3011 Schneider LS, Small GW, Hamilton SH, et al. Estrogen replacement and response to fluoxetine in a multicenter geriatric depression trial. Fluoxetine Collaborative Study Group. Am J Geriatr Psychiatry. Spring. 1997;5(2):97-106. Source: PubMed. [pmid: 9106373].
3012 Schneier FR, Blanco C, Campeas R, et al. Citalopram treatment of social anxiety disorder with comorbid major depression. Depress Anxiety. 2003;17(4):191-6. Source: PubMed. [pmid: 12820174].
3013 Schnoll RA, Martinez E, Tatum KL, et al. A bupropion smoking cessation clinical trial for cancer patients. Cancer Causes Control. Jun. 2010;21(6):811-20. Source: PubMed. [pmid: 20087643].
3014 Schnyder U, Koller-Leiser A. A double-blind, multicentre study of paroxetine and maprotiline in major depression. Can J Psychiatry. May. 1996;41(4):239-44. Source: PubMed. [pmid: 8726790].
3015 Schone W, Ludwig M. A double-blind study of paroxetine compared with fluoxetine in geriatric patients with major depression. J Clin Psychopharmacol. Dec. 1993;13(6 Suppl 2):34S-9S. Source: PubMed. [pmid: 8106654].
3016 Schone W, Ludwig M. Paratoxetine in the treatment of geriatric depressed patients - A double-blind comparison with fluoxetine. <ORIGINAL>. PAROXETIN IN DER DEPRESSIONSBEHANDLUNG GERIATRISCHER PATIENTEN - EINE DOPPELBLINDE VERGLEICHSSTUDIE MIT FLUOXETIN. Fortschr Neurol Psychiatr. 1994;62(Suppl 1):16-8. Source: EMBASE. [pmid: 7959520].
3017 Schouten WE, Sepers JM. Hyponatraemia associated with the use of a selective serotonin-reuptake inhibitor in an older patient. Age Ageing. Jan. 2001;30(1):94. Source: PubMed. [pmid: 11322690].
3018 Schrader E. Equivalence of St John's wort extract (Ze 117) and fluoxetine: a randomized, controlled study in mild-moderate depression. Int Clin Psychopharmacol. Mar. 2000;15(2):61-8. Source: PubMed. [pmid: 10759336].
3019 Schraml F, Benedetti G, Hoyle K, et al. Fluoxetine and nortriptyline combination therapy. Am J Psychiatry. Dec. 1989;146(12):1636-7. Source: PubMed. [pmid: 2589560].
3020 Schramm E, Schneider D, Zobel I, et al. Efficacy of Interpersonal Psychotherapy plus pharmacotherapy in chronically depressed inpatients. J Affect Disord. Jul. 2008;109(1-2):65-73. Source: PubMed. [pmid: 18067973].
3021 Schramm E, van Calker D, Dykierek P, et al. An intensive treatment program of interpersonal psychotherapy plus pharmacotherapy for depressed inpatients: acute and long-term results. Am J Psychiatry. May. 2007;164(5):768-77. Source: PubMed. [pmid: 17475736].
3022 Schrijvers D, Maas YJ, Sabbe BG. Effects of fluoxetine on fine motor performance in dysthymia: an 8-week, nonrandomized, open-label study. Clin Ther. 2009;31(1):123-9. Source: PubMed. [pmid: 19243713].
3023 Schüle C, Romeo E, Uzunov DP, et al. Influence of mirtazapine on plasma concentrations of neuroactive steroids in major depression and on 3α-hydroxysteroid dehydrogenase activity. Molecular Psychiatry. Mar. 2006. 2006;11(3):261-72. Source: PsycINFO. [pmid: 16344854].
3024 Schüle C, Sighart C, Hennig J, et al. Mirtazapine inhibits salivary cortisol concentrations in anorexia nervosa. Progressi n Neuro-Psychopharmacology & Biological Psychiatry. Jul. 2006. 2006;30(6):1015-9. Source: PsycINFO.
3025 Schule C, Baghai TC, Alajbegovic L, et al. The influence of 4-week treatment with sertraline on the combined T3/TRH test in depressed patients. Eur Arch Psychiatry Clin Neurosci. Oct. 2005;255(5):334-40. Source: PubMed. [pmid: 15747035].
3026 Schule C, Baghai TC, Eser D, et al. Mirtazapine monotherapy versus combination therapy with mirtazapine and aripiprazole in depressed patients without psychotic features: a 4-week open-label parallel-group study. World J Biol Psychiatry. 2007;8(2):112-22. Source: PubMed. [pmid: 17455104].
3027 Schule C, Baghai TC, Eser D, et al. Lithium but not carbamazepine augments antidepressant efficacy of mirtazapine in unipolar depression: an open-label study. World J Biol Psychiatry. 2009;10(4 Pt 2):390-9. Source: PubMed. [pmid: 18609420].
3028 Schule C, Baghai TC, Eser D, et al. Time course of hypothalamic-pituitary-adrenocortical axis activity during treatment with reboxetine and mirtazapine in depressed patients. Psychopharmacology (Berl). Jul. 2006;186(4):601-11. Source: PubMed. [pmid: 16758243].
3029 Schule C, Zwanzger P, Baghai T, et al. Effects of antidepressant pharmacotherapy after repetitive transcranial magnetic stimulation in major depression: an open follow-up study. J Psychiatr Res. Mar-Apr. 2003;37(2):145-53. Source: PubMed. [pmid: 12842168].
3030 Schwan S, Hallberg P. Ranking antidepressants. Lancet. May. 23. 2009;373(9677):1761. author reply -2. Source: PubMed. [pmid: 19465226].
3031 Schwartz JA, McDaniel JS. Double-blind comparison of fluoxetine and desipramine in the treatment of depressed women with advanced HIV disease: a pilot study. Depress Anxiety. 1999;9(2):70-4. Source: PubMed. [pmid: 10207661].
3032 Schwartz T, Jindal S, Virk S, et al. Safety and tolerability of extended-release venlafaxine in severe medical and surgical illness. Psychosomatics. May-Jun. 2004;45(3):217-9. Source: PubMed. [pmid: 15123846].
3033 Schwartz TL, Nasra GS, Ashton AK, et al. An open-label study to evaluate switching from an SSRI or SNRI to tiagabine to alleviate antidepressant-induced sexual dysfunction in generalized anxiety disorder. Ann Clin Psychiatry. Jan-Mar. 2007;19(1):25-30. Source: PubMed. [pmid: 17453658].
3034 Schweitzer I, Burrows G, Tuckwell V, et al. Sustained response to open-label venlafaxine in drug-resistant major depression. J Clin Psychopharmacol. Apr. 2001;21(2):185-9. Source: PubMed. [pmid: 11270915].
3035 Schweitzer I, Maguire K, Ng C. Sexual side-effects of contemporary antidepressants: review. Aust N Z J Psychiatry. Sep. 2009;43(9):795-808. Source: PubMed. [pmid: 19670052].
3036 Schweizer E, Feighner J, Mandos LA, et al. Comparison of venlafaxine and imipramine in the acute treatment of major depression in outpatients. J Clin Psychiatry. Mar. 1994;55(3):104-8. Source: PubMed. [pmid: 8071246].
3037 Schweizer E, Rickels K, Amsterdam JD, et al. What constitutes an adequate antidepressant trial for fluoxetine?. J Clin Psychiatry. Jan. 1990;51(1):8-11. Source: PubMed. [pmid: 2403998].
3038 Schweizer E, Rynn M, Mandos LA, et al. The antidepressant effect of sertraline is not enhanced by dose titration: results from an outpatient clinical trial. Int Clin Psychopharmacol. May. 2001;16(3):137-43. Source: PubMed. [pmid: 11354235].
3039 Schweizer E, Weise C, Clary C, et al. Placebo-controlled trial of venlafaxine for the treatment of major depression. J Clin Psychopharmacol. Aug. 1991;11(4):233-6. Source: PubMed. [pmid: 1918421].
3040 Sclar DA, Robison LM, Skaer TL, et al. Antidepressant pharmacotherapy: economic evaluation of fluoxetine, paroxetine and sertraline in a health maintenance organization. J Int Med Res. Nov-Dec. 1995;23(6):395-412. Source: PubMed. [pmid: 8746607].
3041 Sclar DA, Robison LM, Skaer TL, et al. Antidepressant pharmacotherapy: economic outcomes in a health maintenance organization. Clin Ther. Jul-Aug. 1994;16(4):715-30. discussion 74. Source: PubMed. [pmid: 7982260].
3042 Sclar DA, Skaer TL, Robison LM, et al. Economic appraisal of citalopram in the management of single-episode depression. J Clin Psychopharmacol. Oct. 1999;19(5 Suppl 1):47S-54S. Source: PubMed. [pmid: 10507508].
3043 Scoppetta M, Di Gennaro G, Scoppetta C. Selective serotonine reuptake inhibitors prevents emotional lability in healthy subjects. Eur Rev Med Pharmacol Sci. Nov-Dec. 2005;9(6):343-8. Source: PubMed. [pmid: 16479738].
3044 Scott TF, Nussbaum P, McConnell H, et al. Measurement of treatment response to sertraline in depressed multiple sclerosis patients using the Carroll scale. Neurol Res. Dec. 1995;17(6):421-2. Source: PubMed. [pmid: 8622794].
3045 Sebestyen B, Rihmer Z, Balint L, et al. Gender differences in antidepressant use-related seasonality change in suicide mortality in Hungary, 1998-2006. The World Journal of Biological Psychiatry. 2010;11(3-4):579-85. Source: PsycINFO. [pmid: 20218927].
3046 Sechter D, Troy S, Paternetti S, et al. A double-blind comparison of sertraline and fluoxetine in the treatment of major depressive episode in outpatients. Eur Psychiatry. Mar. 1999;14(1):41-8. Source: PubMed. [pmid: 10572324].
3047 Sechter D, Vandel P, Weiller E, et al. A comparative study of milnacipran and paroxetine in outpatients with major depression. J Affect Disord. Dec. 2004;83(2-3):233-6. Source: PubMed. [pmid: 15555719].
3048 Seedat S, Haskis A, Stein DJ. Benefits of consumer psychoeducation: a pilot program in South Africa. Int J Psychiatry Med. 2008;38(1):31-42. Source: PubMed. [pmid: 18624015].
3049 Seemuller F, Moller HJ, Obermeier M, et al. Do efficacy and effectiveness samples differ in antidepressant treatment outcome? An analysis of eligibility criteria in randomized controlled trials. Journal of Clinical Psychiatry. 2010;71(11):1425-33. Source: EMBASE. [pmid: 20816028].
3050 Seemuller F, Riedel M, Obermeier M, et al. Outcomes of 1014 naturalistically treated inpatients with major depressive episode. European Neuropsychopharmacology. 2010;20(5):346-55. Source: EMBASE. [pmid: 20097046].
3051 Segal ZV, Bieling P, Young T, et al. Antidepressant monotherapy vs sequential pharmacotherapy and mindfulness-based cognitive therapy, or placebo, for relapse prophylaxis in recurrent depression. Archives of general psychiatry. 2010;67(12):1256-64. Source: EMBASE. [pmid: 21135325].
3052 Segraves RT. Psychiatric drugs and inhibited female orgasm. J Sex Marital Ther. Fall. 1988;14(3):202-7. Source: PubMed. [pmid: 2902230].
3053 Segraves RT, Kavoussi R, Hughes AR, et al. Evaluation of sexual functioning in depressed outpatients: a double-blind comparison of sustained-release bupropion and sertraline treatment. J Clin Psychopharmacol. Apr. 2000;20(2):122-8. Source: PubMed. [pmid: 10770448].
3054 Segraves RT, Segraves KB, Bubna CN. Sexual function in patients taking bupropion sustained release. J Clin Psychiatry. 1995;56(8):374. Source: PubMed. [pmid: 7635855].
3055 Segui J, Lopez-Munoz F, Alamo C, et al. Effects of adjunctive reboxetine in patients with duloxetine-resistant depression: a 12-week prospective study. J Psychopharmacol. Aug. 2010;24(8):1201-7. Source: PubMed. [pmid: 19282423].
3056 Seifritz E, Holsboer-Trachsler E, Hemmeter U, et al. Increased trimipramine plasma levels during fluvoxamine comedication. Eur Neuropsychopharmacol. Mar. 1994;4(1):15-20. Source: PubMed. [pmid: 8204992].
3057 Seitz Dallas P, Adunuri N, Gill S, et al. Antidepressants for agitation and psychosis in dementia. Cochrane Database of Systematic Reviews. 2010;(1). Source: The Cochrane Library.
3058 Selzer JA. Fluoxetine, suicidal ideation, and aggressive behavior. Am J Psychiatry. May. 1992;149(5):708-9. Source: PubMed. [pmid: 1575263].
3059 Sene Costa EM, Antonio R, De Macedo Soares MB, et al. Psychodramatic psychotherapy combined with pharmacotherapy in major depressive disorder: An open and naturalistic study. Revista Brasileira de Psiquiatria. 2006;28(1):40-3. Source: EMBASE. [pmid: 16612489].
3060 Seo HJ, Jung YE, Woo YS, et al. Effect of augmented atypical antipsychotics on weight change in patients with major depressive disorder in a naturalistic setting. Hum Psychopharmacol. Mar. 2009;24(2):135-43. Source: PubMed. [pmid: 19156709].
3061 Septien-Velez L, Pitrosky B, Padmanabhan SK, et al. A randomized, double-blind, placebo-controlled trial of desvenlafaxine succinate in the treatment of major depressive disorder. Int Clin Psychopharmacol. 2007;22(6):338-47. Source: PubMed. [pmid: 17917552].
3062 Serafini G, Pompili M, Del Casale A, et al. Duloxetine versus venlafaxine in the treatment of unipolar and bipolar depression. Clinica Terapeutica. 2010;161(4):321-7. Source: EMBASE. [pmid: 20931154].
3063 Serby M. Methylphenidate-induced obsessive-compulsive symptoms in an elderly man. CNS Spectr. Aug. 2003;8(8):612-3. Source: PubMed. [pmid: 12907924].
3064 Serfaty MA, Osborne D, Buszewicz MJ, et al. A randomized double-blind placebo-controlled trial of treatment as usual plus exogenous slow-release melatonin (6 mg) or placebo for sleep disturbance and depressed mood. International Clinical Psychopharmacology. 2010;25(3):132-42. Source: PsycINFO. [pmid: 20195158].
3065 Serrano-Blanco A, Gabarron E, Garcia-Bayo I, et al. Effectiveness and cost-effectiveness of antidepressant treatment in primary health care: a six-month randomised study comparing fluoxetine to imipramine. J Affect Disord. Apr. 2006;91(2-3):153-63. Source: PubMed. [pmid: 16458976].
3066 Serretti A, Chiesa A, Calati R, et al. A preliminary investigation of the influence of CREB1 gene on treatment resistance in major depression. Journal of affective disorders. 2011;128(1-2):56-63. Source: EMBASE. [pmid: 20643483].
3067 Serretti A, Cusin C, Benedetti F, et al. Insomnia improvement during antidepressant treatment and CLOCK gene polymorphism. American Journal of Medical Genetics Neuropsychiatric Genetics. 2005;137(1):36-9. Source: EMBASE.
3068 Serretti A, Jori MC, Casadei G, et al. Delineating psychopathologic clusters within dysthymia: a study of 512 out-patients without major depression. Journal Of Affective Disorders. 1999;56(1):17-25. Source: EMBASE. [pmid: 10626776].
3069 Serretti A, Lattuada E, Zanardi R, et al. Patterns of symptom improvement during antidepressant treatment of delusional depression. Psychiatry Res. May. 15. 2000;94(2):185-90. Source: PubMed. [pmid: 10808044].
3070 Serretti A, Olgiati P, Liebman MN, et al. Clinical prediction of antidepressant response in mood disorders: linear multivariate vs. neural network models. Psychiatry Res. Aug. 30. 2007;152(2-3):223-31. Source: PubMed. [pmid: 17445910].
3071 Serretti A, Zanardi R, Cusin C, et al. Tryptophan hydroxylase gene associated with paroxetine antidepressant activity. Eur Neuropsychopharmacol. Oct. 2001;11(5):375-80. Source: PubMed. [pmid: 11597824].
3072 Serretti A, Zanardi R, Mandelli L, et al. A neural network model for combining clinical predictors of antidepressant response in mood disorders. Journal of Affective Disorders. 2007;98(3):239-45. Source: EMBASE. [pmid: 16970992].
3073 Serretti A, Zanardi R, Rossini D, et al. Influence of tryptophan hydroxylase and serotonin transporter genes on fluvoxamine antidepressant activity. Mol Psychiatry. Sep. 2001;6(5):586-92. Source: PubMed. [pmid: 11526473].
3074 Seth R, Jennings AL, Bindman J, et al. Combination treatment with noradrenalin and serotonin reuptake inhibitors in resistant depression. Br J Psychiatry. Oct. 1992;161:562-5. Source: PubMed. [pmid: 1327396].
3075 Settle EC Jr. Akathisia and sertraline. J Clin Psychiatry. Aug. 1993;54(8):321. Source: PubMed. [pmid: 8253701].
3076 Settle EC Jr. Bupropion sustained release: side effect profile. J Clin Psychiatry. Suppl 4. 1998;59:32-6. Source: PubMed. [pmid: 9554319].
3077 Settle EC, Stahl SM, Batey SR, et al. Safety profile of sustained-release bupropion in depression: results of three clinical trials. Clin Ther. Mar. 1999;21(3):454-63. Source: PubMed. [pmid: 10321415].
3078 Seymour PM. Long-term treatment of an addictive personality. Bull Menninger Clin. Fall. 2003;67(4):328-46. Source: PubMed. [pmid: 14733449].
3079 Seyringer ME, Kasper S. Ranking antidepressants. Lancet. May. 23. 2009;373(9677):1760-1. author reply 1-2. Source: PubMed. [pmid: 19465224].
3080 Shad MU, Harvey AT, Lucot JB. A possible pharmacokinetic interaction between fluoxetine and acetylsalicylic acid. J Clin Psychiatry. Dec. 1997;58(12):549-50. Source: PubMed. [pmid: 9448661].
3081 Shader RI, Oesterheld JR. Case 2: Dizzy Giuseppi or the vertiginous virtuoso. J Clin Psychopharmacol. Dec. 1994;14(6):437. Source: PubMed. [pmid: 7884033].
3082 Shalev H, Ben-Zion I, Shiber A. A case of mirtazapine-induced spontaneous orgasms in a female patient. J Psychopharmacol. Jan. 2009;23(1):109-10. Source: PubMed. [pmid: 18208938].
3083 Shaligram D, Alqassem T, Koby E. Desvenlafaxine as a possible cause of acquired hemophilia. General Hospital Psychiatry. 2010;32(6):646.e13-.e15. Source: EMBASE. [pmid: 21112459].
3084 Shang CY, Soong WT, Lin HN. Hypokalemia with venlafaxine. J Clin Psychiatry. Nov. 2002;63(11):1049-50. Source: PubMed. [pmid: 12469691].
3085 Shapira B, Nemets B, Trachtenberg A, et al. Phenytoin as an augmentation for SSRI failures: a small controlled study. J Affect Disord. Nov. 2006;96(1-2):123-6. Source: PubMed. [pmid: 16814397].
3086 Shapiro PA, Lesperance F, Frasure-Smith N, et al. An open-label preliminary trial of sertraline for treatment of major depression after acute myocardial infarction (the SADHAT Trial). Sertraline Anti-Depressant Heart Attack Trial. Am Heart J. Jun. 1999;137(6):1100-6. Source: PubMed. [pmid: 10347338].
3087 Sharma V. Venlafaxine: loss of antidepressant effect and its management. J Clin Psychiatry. Jul. 1998;59(7):381-2. Source: PubMed. [pmid: 9714268].
3088 Sharp DJ, Chew-Graham CA, Tylee A, et al. A pragmatic randomised controlled trial to compare antidepressants with a community-based psychosocial intervention for the treatment of women with postnatal depression: The RESPOND trial. Health Technology Assessment. 2010;14(43):1-181. Source: EMBASE.
3089 Shaw DM, Thomas DR, Briscoe MH, et al. A comparison of the antidepressant action of citalopram and amitriptyline. Br J Psychiatry. Oct. 1986;149:515-7. Source: PubMed. [pmid: 3545354].
3090 Sheehan D, Dunbar GC, Fuell DL. The effect of paroxetine on anxiety and agitation associated with depression. Psychopharmacol Bull. 1992;28(2):139-43. Source: PubMed. [pmid: 1387484].
3091 Sheehan DV. Venlafaxine extended release (XR) in the treatment of generalized anxiety disorder. J Clin Psychiatry. Suppl 22. 1999;60:23-8. Source: PubMed. [pmid: 10634352].
3092 Sheehan DV. Attaining remission in generalized anxiety disorder: venlafaxine extended release comparative data. J Clin Psychiatry. Suppl 19. 2001;62:26-31. Source: PubMed. [pmid: 11577788].
3093 Sheehan DV, Eaddy M, Sarnes M, et al. Evaluating the economic consequences of early antidepressant treatment discontinuation: a comparison between controlled-release and immediate-release paroxetine. J Clin Psychopharmacol. Oct. 2004;24(5):544-8. Source: PubMed. [pmid: 15349013].
3094 Sheehan DV, Eaddy MT, Shah MB, et al. Differences in total medical costs across the SSRIs for the treatment of depression and anxiety. Am J Manag Care. Oct. 2005;11(12 Suppl):S354-61. Source: PubMed. [pmid: 16236017].
3095 Sheffrin M, Driscoll HC, Lenze EJ, et al. Pilot study of augmentation with aripiprazole for incomplete response in late-life depression: getting to remission. J Clin Psychiatry. Feb. 2009;70(2):208-13. Source: PubMed. [pmid: 19210951].
3096 Sheikh JI, Cassidy EL, Doraiswamy PM, et al. Efficacy, safety, and tolerability of sertraline in patients with late-life depression and comorbid medical illness. J Am Geriatr Soc. Jan. 2004;52(1):86-92. Source: PubMed. [pmid: 14687320].
3097 Sheikh JI, Londborg P, Clary CM, et al. The efficacy of sertraline in panic disorder: combined results from two fixed-dose studies. Int Clin Psychopharmacol. Nov. 2000;15(6):335-42. Source: PubMed. [pmid: 11110009].
3098 Sheline Y, Bardgett ME, Csernansky JG. Correlated reductions in cerebrospinal fluid 5-HIAA and MHPG concentrations after treatment with selective serotonin reuptake inhibitors. J Clin Psychopharmacol. Feb. 1997;17(1):11-4. Source: PubMed. [pmid: 9004051].
3099 Sheline YI, Pieper CF, Barch DM, et al. Support for the vascular depression hypothesis in late-life depression: results of a 2-site, prospective, antidepressant treatment trial. Arch Gen Psychiatry. Mar. 2010;67(3):277-85. Source: PubMed. [pmid: 20194828].
3100 Shelton C, Entsuah R, Padmanabhan SK, et al. Venlafaxine XR demonstrates higher rates of sustained remission compared to fluoxetine, paroxetine or placebo. Int Clin Psychopharmacol. Jul. 2005;20(4):233-8. Source: PubMed. [pmid: 15933485].
3101 Shelton RC. Augmentation strategies to increase antidepressant efficacy. Journal of Clinical Psychiatry. 01. 01. 2007;68:18-22. Source: PsycINFO. [pmid: 17900205].
3102 Shelton RC. ‘The role of L-methylfolate in depressive disorders’: Commentary. Primary Psychiatry. Jan. 2009. 2009;16(1):8. Source: PsycINFO.
3103 Shelton RC, Andorn AC, Mallinckrodt CH, et al. Evidence for the efficacy of duloxetine in treating mild, moderate, and severe depression. Int Clin Psychopharmacol. Nov. 2007;22(6):348-55. Source: PubMed. [pmid: 17917553].
3104 Shelton RC, Davidson J, Yonkers KA, et al. The undertreatment of dysthymia. J Clin Psychiatry. Feb. 1997;58(2):59-65. Source: PubMed. [pmid: 9062374].
3105 Shelton RC, Haman KL, Rapaport MH, et al. A randomized, double-blind, active-control study of sertraline versus venlafaxine XR in major depressive disorder. J Clin Psychiatry. 2006;67(11):1674-81. Source: PubMed. [pmid: 17196045].
3106 Shelton RC, Prakash A, Mallinckrodt CH, et al. Patterns of depressive symptom response in duloxetine-treated outpatients with mild, moderate or more severe depression. Int J Clin Pract. Aug. 2007;61(8):1337-48. Source: PubMed. [pmid: 17627710].
3107 Shelton RC, Williamson DJ, Corya SA, et al. Olanzapine/fluoxetine combination for treatment-resistant depression: a controlled study of SSRI and nortriptyline resistance. J Clin Psychiatry. Oct. 2005;66(10):1289-97. Source: PubMed. [pmid: 16259543].
3108 Shen J, Chung SA, Kayumov L, et al. Polysomnographic and symptomatological analyses of major depressive disorder patients treated with mirtazapine. Can J Psychiatry. Jan. 2006;51(1):27-34. Source: PubMed. [pmid: 16491981].
3109 Shen J, Moller HJ, Wang X, et al. Mirtazapine, a sedating antidepressant, and improved driving safety in patients with major depressive disorder: a prospective, randomized trial of 28 patients. J Clin Psychiatry. Mar. 2009;70(3):370-7. Source: PubMed. [pmid: 19192466].
3110 Sherrod RA, Collins A, Wynn S, et al. Dissecting dementia, depression, and drug effects in older adults. J Psychosoc Nurs Ment Health Serv. Jan. 2010;48(1):39-47. Source: PubMed. [pmid: 20102132].
3111 Shinkai K, Yoshimura R, Ueda N, et al. Associations between baseline plasma MHPG (3-methoxy-4-hydroxyphenylglycol) levels and clinical responses with respect to milnacipran versus paroxetine treatment. J Clin Psychopharmacol. Feb. 2004;24(1):11-7. Source: PubMed. [pmid: 14709941].
3112 Showraki M. Pregabalin in the treatment of depression. Journal of Psychopharmacology. Nov. 2007. 2007;21(8):883-4. Source: PsycINFO. [pmid: 17984164].
3113 Shrivastava RK, Cohn C, Crowder J, et al. Long-term safety and clinical acceptability of venlafaxine and imipramine in outpatients with major depression. J Clin Psychopharmacol. Oct. 1994;14(5):322-9. Source: PubMed. [pmid: 7806687].
3114 Shrivastava RK, Shrivastava SH, Overweg N, et al. A double-blind comparison of paroxetine, imipramine, and placebo in major depression. J Clin Psychiatry. Feb. 1992;53(Suppl):48-51. Source: PubMed. [pmid: 1531825].
3115 Sicras-Mainar A, Navarro-Artieda R, Blanca-Tamayo M, et al. Comparison of escitalopram vs. citalopram and venlafaxine in the treatment of major depression in Spain: Clinical and economic consequences. Current Medical Research and Opinion. 2010;26(12):2757-64. Source: EMBASE. [pmid: 21034375].
3116 Sidwell RU, Swift S, Yan CL, et al. Treatment of toxic epidermal necrolysis with intravenous immunoglobulin. Int J Clin Pract. Sep. 2003;57(7):643-5. Source: PubMed. [pmid: 14529073].
3117 Sihvo S, Isometsa E, Kiviruusu O, et al. Antidepressant utilisation patterns and determinants of short-term and non-psychiatric use in the Finnish general adult population. Journal of Affective Disorders. 2008;110(1-2):94-105. Source: EMBASE. [pmid: 18276016].
3118 Silverstone PH, Entsuah R, Hackett D. Two items on the Hamilton Depression rating scale are effective predictors of remission: comparison of selective serotonin reuptake inhibitors with the combined serotonin/norepinephrine reuptake inhibitor, venlafaxine. Int Clin Psychopharmacol. Nov. 2002;17(6):273-80. Source: PubMed. [pmid: 12409680].
3119 Silverstone PH, Ravindran A. Once-daily venlafaxine extended release (XR) compared with fluoxetine in outpatients with depression and anxiety. Venlafaxine XR 360 Study Group. J Clin Psychiatry. Jan. 1999;60(1):22-8. Source: PubMed. [pmid: 10074873].
3120 Silverstone PH, Salinas E. Efficacy of venlafaxine extended release in patients with major depressive disorder and comorbid generalized anxiety disorder. J Clin Psychiatry. Jul. 2001;62(7):523-9. Source: PubMed. [pmid: 11488362].
3121 Simis S, Nitrini R. Cognitive improvement after treatment of depressive symptoms in the acute phase of stroke. Arq Neuropsiquiatr. Jun. 2006;64(2B):412-7. Source: PubMed. [pmid: 16917611].
3122 Simon GE, Heiligenstein J, Revicki D, et al. Long-term outcomes of initial antidepressant drug choice in a “real world” randomized trial. Arch Fam Med. Jul-Aug. 1999;8(4):319-25. Source: PubMed. [pmid: 10418538].
3123 Simon GE, Heiligenstein JH, Grothaus L, et al. Should anxiety and insomnia influence antidepressant selection: a randomized comparison of fluoxetine and imipramine. J Clin Psychiatry. Feb. 1998;59(2):49-55. Source: PubMed. [pmid: 9501885].
3124 Simon GE, Savarino J, Operskalski B, et al. Suicide risk during antidepressent treatment. American Journal of Psychiatry. 2006;163(1):41-7. Source: PubMed. [pmid: 16390887].
3125 Simon JS, Aguiar LM, Kunz NR, et al. Extended-release venlafaxine in relapse prevention for patients with major depressive disorder. J Psychiatr Res. May-Jun. 2004;38(3):249-57. Source: PubMed. [pmid: 15003430].
3126 Simon JS, Evans DL, Nemeroff CB. The dexamethasone suppression test and antidepressant response in major depression. J Psychiatr Res. 1987;21(3):313-7. Source: PubMed. [pmid: 3681765].
3127 Simon JS, Sheehan D, Thase ME, et al. Comparison of efficacy and tolerability of paroxetine vs venlafaxine. 2005. Source: Scopus.
3128 Simon NM, Shear MK, Fagiolini A, et al. Impact of concurrent naturalistic pharmacotherapy on psychotherapy of complicated grief. Psychiatry Research. 2008;159(1-2):31-6. Source: EMBASE. [pmid: 18336918].
3129 Simon NM, Thompson EH, Pollack MH, et al. Complicated grief: a case series using escitalopram. Am J Psychiatry. Nov. 2007;164(11):1760-1. Source: PubMed. [pmid: 17974946].
3130 Simon NM, Zalta AK, Worthington JJ 3rd, et al. Preliminary support for gender differences in response to fluoxetine for generalized anxiety disorder. Depress Anxiety. 2006;23(6):373-6. Source: PubMed. [pmid: 17068858].
3131 Simpson GM, El Sheshai A, Rady A, et al. Sertraline as monotherapy in the treatment of psychotic and nonpsychotic depression. J Clin Psychiatry. Aug. 2003;64(8):959-65. Source: PubMed. [pmid: 12927014].
3132 Singh P, Kumar R. Assessment of the effectiveness of sustained release Bupropion and intensive physician advice in smoking cessation. Lung India. 2010;27(1):11-8. Source: EMBASE. [pmid: 20539765].
3133 Sipkoff M. Health plans walk a clinical tightrope when treating adolescents for depression. Manag Care. Feb. 2010;19(2):8-10. Source: PubMed. [pmid: 20550045].
3134 Sir A, D'Souza RF, Uguz S, et al. Randomized trial of sertraline versus venlafaxine XR in major depression: efficacy and discontinuation symptoms. J Clin Psychiatry. Oct. 2005;66(10):1312-20. Source: Handsearch. [pmid: 16259546].
3135 Sit D, Perel JM, Luther JF, et al. Disposition of chiral and racemic fluoxetine and norfluoxetine across childbearing. Journal of Clinical Psychopharmacology. 2010;30(4):381-6. Source: EMBASE. [pmid: 20631556].
3136 Skarstein J. A ‘trouble-blind’ placebo controlled comparative study between two new antidepressant agents (Seroxat (R) (paroxetine) and Tolvon (R) (mianserin)). <ORIGINAL>. EN ‘TROUBLE-BLIND’ PLACEBOKONTROLLERT SAMMENLIKNENDE UNDERSOKELSE MELLOM TO NYE ANTIDEPRESSIVER. Tidsskrift For Den Norske Laegeforening. 1998;118(2):265-6. Source: EMBASE. [pmid: 9485626].
3137 Skinner EP, Cantrell R, Chaffin J, et al. Adherence with once-daily bupropion XL versus twice-daily bupropoion SR. J Am Pharm Assoc. 2005;45265. Source: Handsearch.
3138 Skrabal MZ, Stading JA, Monaghan MS. Rhabdomyolysis associated with simvastatin-nefazodone therapy. South Med J. Oct. 2003;96(10):1034-5. Source: PubMed. [pmid: 14570351].
3139 Slaughter JR, Parker JC, Martens MP, et al. Clinical outcomes following a trial of sertraline in rheumatoid arthritis. Psychosomatics. Jan-Feb. 2002;43(1):36-41. Source: PubMed. [pmid: 11927756].
3140 Slawek J, Wichowicz HM, Cubala WJ, et al. Psychogenic axial myoclonus: Report on two cases. Neurological Sciences. 2010;31(2):219-22. Source: EMBASE. [pmid: 20135184].
3141 Smajkic A, Weine S, Duric-Bijedic Z, et al. Sertralilne, paroxetine and venlafaxine in refugee post traumatic stress disorder with depression symptoms. Med Arh. 2001;55(1 Suppl 1):35-8. Source: PubMed. [pmid: 11795192].
3142 Small GW, Birkett M, Meyers BS, et al. Impact of physical illness on quality of life and antidepressant response in geriatric major depression. Fluoxetine Collaborative Study Group. J Am Geriatr Soc. Oct. 1996;44(10):1220-5. Source: PubMed. [pmid: 8856002].
3143 Small GW, Hamilton SH, Bystritsky A, et al. Clinical response predictors in a double-blind, placebo-controlled trial of fluoxetine for geriatric major depression. Fluoxetine Collaborative Study Group. Int Psychogeriatr. 1995;7(Suppl):41-53. Source: PubMed. [pmid: 8580391].
3144 Small GW, Schneider LS, Hamilton SH, et al. Site variability in a multisite geriatric depression trial. Journal of Geriatric Psychiatry. 1996;11(12):1089-95. Source: EMBASE.
3145 Smedh K, Spigset O, Allard P, et al. Platelet [3H]paroxetine and [3H]lysergic acid diethylamide binding in seasonal affective disorder and the effect of bright light therapy. Biol Psychiatry. Feb. 15. 1999;45(4):464-70. Source: PubMed. [pmid: 10071719].
3146 Smeraldi E. Amisulpride in the treatment of dysthymia: Preliminary results in a comparative double-blind study with fluoxetine. Nuova Rivista Di Neurologia. 1995;5(6 Suppl 2):22-6. Source: EMBASE.
3147 Smeraldi E. Amisulpride versus fluoxetine in patients with dysthymia or major depression in partial remission: a double-blind, comparative study. J Affect Disord. Feb. 1998;48(1):47-56. Source: PubMed. [pmid: 9495601].
3148 Smeraldi E, Haefele E, Crespi G, et al. Amisulpride versus fluoxetine in dysthymia: Preliminary results of a double-blind comparative study. European Psychiatry. 1996;11(Suppl 3):141s-3s. Source: EMBASE.
3149 Smeraldi E, Zanardi R, Benedetti F, et al. Polymorphism within the promoter of the serotonin transporter gene and antidepressant efficacy of fluvoxamine. Mol Psychiatry. Nov. 1998;3(6):508-11. Source: PubMed. [pmid: 9857976].
3150 Smesny S, Baur K, Rudolph N, et al. Alterations of niacin skin sensitivity in recurrent unipolar depressive disorder. Journal of affective disorders. 2010;124(3):335-40. Source: EMBASE. [pmid: 20116108].
3151 Smith AJ, Sketris I, Cooke C, et al. A comparison of antidepressant use in Nova Scotia, Canada and Australia. Pharmacoepidemiol Drug Saf. Jul. 2008;17(7):697-706. Source: PubMed. [pmid: 18181227].
3152 Smith Caroline A, Hay Phillipa PJ, MacPherson H. Acupuncture for depression. Cochrane Database of Systematic Reviews. 2010;(1). Source: The Cochrane Library.
3153 Smith CN, Frascino JC, Kripke DL, et al. Losing memories overnight: A unique form of human amnesia. Neuropsychologia. 2010;48(10):2833-40. Source: EMBASE. [pmid: 20493889].
3154 Smith D, Dempster C, Glanville J, et al. Efficacy and tolerability of venlafaxine compared with selective serotonin reuptake inhibitors and other antidepressants: a meta-analysis. Br J Psychiatry. May. 2002;180:396-404. Source: PubMed. [pmid: 11983635].
3155 Smith DM, Levitte SS. Association of fluoxetine and return of sexual potency in three elderly men. J Clin Psychiatry. Aug. 1993;54(8):317-9. Source: PubMed. [pmid: 8253700].
3156 Smith GS, Reynolds CF 3rd, Houck PR, et al. Cerebral glucose metabolic response to combined total sleep deprivation and antidepressant treatment in geriatric depression: a randomized, placebo-controlled study. Psychiatry Res. Jan. 30. 2009;171(1):1-9. Source: PubMed. [pmid: 19087899].
3157 Smith WT, Glaudin V. A placebo-controlled trial of paroxetine in the treatment of major depression. J Clin Psychiatry. Feb. 1992;53(Suppl):36-9. Source: PubMed. [pmid: 1531822].
3158 Smith WT, Glaudin V, Panagides J, et al. Mirtazapine vs. amitriptyline vs. placebo in the treatment of major depressive disorder. Psychopharmacol Bull. 1990;26(2):191-6. Source: PubMed. [pmid: 2236455].
3159 Smith WT, Londborg PD, Glaudin V, et al. Short-term augmentation of fluoxetine with clonazepam in the treatment of depression: a double-blind study. Am J Psychiatry. Oct. 1998;155(10):1339-45. Source: PubMed. [pmid: 9766764].
3160 Smith WT, Londborg PD, Glaudin V, et al. Is extended clonazepam cotherapy of fluoxetine effective for outpatients with major depression?. J Affect Disord. Aug. 2002;70(3):251-9. Source: PubMed. [pmid: 12128237].
3161 Smits K, Smits L, Peeters F, et al. Serotonin transporter polymorphisms and the occurrence of adverse events during treatment with selective serotonin reuptake inhibitors. Int Clin Psychopharmacol. May. 2007;22(3):137-43. Source: PubMed. [pmid: 17414739].
3162 Snedecor SJ, Botteman MF, Schaefer K, et al. Economic outcomes of eszopiclone treatment in insomnia and comorbid major depressive disorder. The journal of mental health policy and economics. 2010;(1):27-35. Source: The Cochrane Library. [pmid: 20571180].
3163 Sneed JR, Culang ME, Keilp JG, et al. Antidepressant medication and executive dysfunction: a deleterious interaction in late-life depression. Am J Geriatr Psychiatry. 2010;18(2):128-35. Source: PubMed. [pmid: 20104069].
3164 Sneed JR, Keilp JG, Brickman AM, et al. The specificity of neuropsychological impairment in predicting antidepressant non-response in the very old depressed. Int J Geriatr Psychiatry. Mar. 2008;23(3):319-23. Source: PubMed. [pmid: 17726720].
3165 Sneed JR, Roose SP, Keilp JG, et al. Response inhibition predicts poor antidepressant treatment response in very old depressed patients. Am J Geriatr Psychiatry. Jul. 2007;15(7):553-63. Source: PubMed. [pmid: 17586780].
3166 Soares CN, Kornstein SG, Thase ME, et al. Assessing the efficacy of desvenlafaxine for improving functioning and well-being outcome measures in patients with major depressive disorder: a pooled analysis of 9 double-blind, placebo-controlled, 8-week clinical trials. J Clin Psychiatry. Oct. 2009;70(10):1365-71. Source: PubMed. [pmid: 19906341].
3167 Soares CN, Poitras JR, Prouty J, et al. Efficacy of citalopram as a monotherapy or as an adjunctive treatment to estrogen therapy for perimenopausal and postmenopausal women with depression and vasomotor symptoms. J Clin Psychiatry. Apr. 2003;64(4):473-9. Source: PubMed. [pmid: 12716252].
3168 Soares CN, Thase ME, Clayton A, et al. Desvenlafaxine and escitalopram for the treatment of postmenopausal women with major depressive disorder. Menopause. 2010;17(4):700-11. Source: PubMed. [pmid: 20539246].
3169 Sobis J, Jarzab M, Hese RT, et al. Therapeutic efficacy assessment of weak variable magnetic fields with low value of induction in patients with drug-resistant depression. J Affect Disord. Jun. 2010;123(1-3):321-6. Source: PubMed. [pmid: 19896204].
3170 Sobocki P, Ekman M, Ovanfors A, et al. The cost-utility of maintenance treatment with venlafaxine in patients with recurrent major depressive disorder. International Journal of Clinical Practice. 2008;62(4):623-32. Source: Scopus. [pmid: 18284439].
3171 Sogaard J, Lane R, Latimer P, et al. A 12-week study comparing moclobemide and sertraline in the treatment of outpatients with atypical depression. J Psychopharmacol. Dec. 1999;13(4):406-14. Source: PubMed. [pmid: 10667618].
3172 Sokolski KN. Adjunctive aripiprazole for bupropion-resistant major depression. Annals of Pharmacotherapy (USA). 01. 01. 2008;42(Feb):1124-9. PsycINFO.
3173 Sokolski KN, Gripeos D. Remission of chronic severe selective serotonin-reuptake inhibitor/selective norepinephrine-reuptake inhibitor refractory depression following adjunctive aripiprazole. Annals of Pharmacotherapy (USA). 09. 01. 2008;42(Sep):1348-9. Source: PsycINFO.
3174 Solai LK, Mulsant BH, Pollock BG, et al. Effect of sertraline on plasma nortriptyline levels in depressed elderly. J Clin Psychiatry. Oct. 1997;58(10):440-3. Source: PubMed. [pmid: 9375595].
3175 Solai LK, Pollock BG, Mulsant BH, et al. Effect of nortriptyline and paroxetine on CYP2D6 activity in depressed elderly patients. J Clin Psychopharmacol. Oct. 2002;22(5):481-6. Source: PubMed. [pmid: 12352271].
3176 Solomon DA, Leon AC, Mueller TI, et al. Tachyphylaxis in unipolar major depressive disorder. Journal of Clinical Psychiatry. 2005;66(3):283-90. Source: EMBASE. [pmid: 15766292].
3177 Solyom L, Solyom C, Ledwidge B. The fluoxetine treatment of low-weight, chronic bulimia nervosa. J Clin Psychopharmacol. Dec. 1990;10(6):421-5. Source: PubMed. [pmid: 2286712].
3178 Solyom L, Solyom C, Ledwidge B. Fluoxetine in panic disorder. Can J Psychiatry. Jun. 1991;36(5):378-80. Source: PubMed. [pmid: 1884341].
3179 Solyom L, Solyom C, Ledwidge B. Fluoxetine treatment of obsessive-compulsive disorder. Can J Psychiatry. Dec. 1991;36(10):723-7. Source: PubMed. [pmid: 1790516].
3180 Sommer BR, Fenn H, Pompei P, et al. Safety of antidepressants in the elderly. Expert Opin Drug Saf. Jul. 2003;2(4):367-83. Source: PubMed. [pmid: 12904093].
3181 Sondergaard MP, Jarden JO, Martiny K, et al. Dose response to adjunctive light therapy in citalopram-treated patients with post-stroke depression. A randomised, double-blind pilot study. Psychother Psychosom. 2006;75(4):244-8. Source: PubMed. [pmid: 16785774].
3182 Song C, Halbreich U, Han C, et al. Imbalance between pro- and anti-inflammatory cytokines, and between Th1 and Th2 cytokines in depressed patients: the effect of electroacupuncture or fluoxetine treatment. Pharmacopsychiatry. Sep. 2009;42(5):182-8. Source: PubMed. [pmid: 19724980].
3183 Song Y, Zhou D, Fan J, et al. Effects of electroacupuncture and fluoxetine on the density of GTP-binding-proteins in platelet membrane in patients with major depressive disorder. J Affect Disord. Mar. 2007;98(3):253-7. Source: PubMed. [pmid: 16919758].
3184 Sonnenberg CM, Deeg DJ, Comijs HC, et al. Trends in antidepressant use in the older population: results from the LASA-study over a period of 10 years. J Affect Disord. Dec. 2008;111(2-3):299-305. Source: PubMed. [pmid: 18442857].
3185 Sopko MA Jr, Ehret MJ, Grgas M. Desvenlafaxine: another “me too” drug?. Ann Pharmacother. Oct. 2008;42(10):1439-46. Source: PubMed. [pmid: 18698015].
3186 Souetre E, Martin P, Lozet H, et al. Quality of life in depressed patients: comparison of fluoxetine and major tricyclic antidepressants. Int Clin Psychopharmacol. Mar. 1996;11(1):45-52. Source: PubMed. [pmid: 8732313].
3187 Soutullo CA, McElroy SL, Keck PE Jr. Hypomania associated with mirtazapine augmentation of sertraline. J Clin Psychiatry. Jun. 1998;59(6):320. Source: PubMed. [pmid: 9671349].
3188 Spalletta G, Ripa A, Bria P, et al. Response of emotional unawareness after stroke to antidepressant treatment. Am J Geriatr Psychiatry. Mar. 2006;14(3):220-7. Source: PubMed. [pmid: 16505126].
3189 Spielmans GI. Duloxetine does not relieve painful physical symptoms in depression: a meta-analysis. Psychother Psychosom. 2008;77(1):12-6. Source: PubMed. [pmid: 18087203].
3190 Spielmans GI, McFall JP. A Comparative Meta-Analysis of Clinical Global Impressions Change in Antidepressant Trials. Journal of Nervous and Mental Disease. Nov. 2006. 2006;194(11):845-52. Source: PsycINFO. [pmid: 17102709].
3191 Spigset O, Adielsson G. Combined serotonin syndrome and hyponatraemia caused by a citalopram-buspirone interaction. Int Clin Psychopharmacol. Jan. 1997;12(1):61-3. Source: PubMed. [pmid: 9179637].
3192 Spigset O, Carieborg L, Ohman R, et al. Excretion of citalopram in breast milk. Br J Clin Pharmacol. Sep. 1997;44(3):295-8. Source: PubMed. [pmid: 9296327].
3193 Spigset O, Ohman R. A case of fluvoxamine intoxication demonstrating nonlinear elimination pharmacokinetics. J Clin Psychopharmacol. Jun. 1996;16(3):254-5. Source: PubMed. [pmid: 8784660].
3194 Spillmann M, Borus JS, Davidson KG, et al. Sociodemographic predictors of response to antidepressant treatment. Int J Psychiatry Med. 1997;27(2):129-36. Source: PubMed. [pmid: 9565719].
3195 Spina E, Campo GM, Avenoso A, et al. Interaction between fluvoxamine and imipramine/desipramine in four patients. Ther Drug Monit. Jun. 1992;14(3):194-6. Source: PubMed. [pmid: 1412604].
3196 Spina E, Pollicino AM, Avenoso A, et al. Fluvoxamine-induced alterations in plasma concentrations of imipramine and desipramine in depressed patients. Int J Clin Pharmacol Res. 1993;13(3):167-71. Source: PubMed. [pmid: 8225700].
3197 Spittlehouse JK, Pearson JF, Luty SE, et al. Measures of temperament and character are differentially impacted on by depression severity. J Affect Disord. Oct. 2010;126(1-2):140-6. Source: PubMed. [pmid: 20381156].
3198 Sprenger D. Buspirone augmentation of a selective serotonin reuptake inhibitor: efficacy in two depressed patients with comorbid anxiety and type I alcohol dependence. J Clin Psychopharmacol. Oct. 1997;17(5):425-6. Source: PubMed. [pmid: 9315996].
3199 Spring B, Doran N, Pagoto S, et al. Fluoxetine, smoking, and history of major depression: A randomized controlled trial. J Consult Clin Psychol. Feb. 2007;75(1):85-94. Source: PubMed. [pmid: 17295567].
3200 Sramek JJ, Kashkin K, Jasinsky O, et al. Placebo-controlled study of ABT-200 versus fluoxetine in the treatment of major depressive disorder. Depression. 1995;3(4):199-203. Source: EMBASE.
3201 Staab JP, Evans DL. Efficacy of venlafaxine in geriatric depression. Depress Anxiety. Suppl 1. 2000;12:63-8. Source: PubMed. [pmid: 11098416].
3202 Stahl S, Zivkov M, Reimitz PE, et al. Meta-analysis of randomized, double-blind, placebo-controlled, efficacy and safety studies of mirtazapine versus amitriptyline in major depression. Acta Psychiatr Scand Suppl. 1997;391:22-30. Source: PubMed. [pmid: 9265948].
3203 Stahl SM. Placebo-controlled comparison of the selective serotonin reuptake inhibitors citalopram and sertraline. Biol Psychiatry. Nov. 1. 2000;48(9):894-901. Source: PubMed. [pmid: 11074227].
3204 Stahl SM. Antidepressant Treatment of Psychotic Major Depression: Potential Role of the ς Receptor. CNS Spectrums. Apr. 2005. 2005;10(4):319-23. Source: PsycINFO. [pmid: 15788959].
3205 Stahl SM, Entsuah R, Rudolph RL. Comparative efficacy between venlafaxine and SSRIs: a pooled analysis of patients with depression. Biol Psychiatry. Dec. 15. 2002;52(12):1166-74. Source: PubMed. [pmid: 12488062].
3206 Stain-Malmgren R, Khoury AE, Aberg-Wistedt A, et al. Serotonergic function in major depression and effect of sertraline and paroxetine treatment. Int Clin Psychopharmacol. Mar. 2001;16(2):93-101. Source: PubMed. [pmid: 11236074].
3207 Stamenkovic M, Blasbichier T, Riederer F, et al. Fluoxetine treatment in patients with recurrent brief depression. Int Clin Psychopharmacol. Jul. 2001;16(4):221-6. Source: PubMed. [pmid: 11459336].
3208 Stamenkovic M, Pezawas L, de Zwaan M, et al. Mirtazapine in recurrent brief depression. Int Clin Psychopharmacol. Jan. 1998;13(1):39-40. Source: PubMed. [pmid: 9988366].
3209 Staner L, Kerkhofs M, Detroux D, et al. Acute, subchronic and withdrawal sleep EEG changes during treatment with paroxetine and amitriptyline: a double-blind randomized trial in major depression. Sleep. Jul. 1995;18(6):470-7. Source: PubMed. [pmid: 7481419].
3210 Stang P, Suppapanaya N, Hogue SL, et al. Persistence with once-daily versus twice-daily bupropion for the treatment of depression in a large managed-care population. Am J Ther. May-Jun. 2007;14(3):241-6. Source: PubMed. [pmid: 17515697].
3211 Stang P, Young S, Hogue S. Better patient persistence with once-daily bupropion compared with twice-daily bupropion. Am J Ther. Jan-Feb. 2007;14(1):20-4. Source: PubMed. [pmid: 17303971].
3212 Stanley N, Fairweather DB, Hindmarch I. Effects of fluoxetine and dothiepin on 24-hour activity in depressed patients. Neuropsychobiology. 1999;39(1):44-8. Source: PubMed. [pmid: 9892859].
3213 Stark P, Hardison CD. A review of multicenter controlled studies of fluoxetine vs. imipramine and placebo in outpatients with major depressive disorder. J Clin Psychiatry. Mar. 1985;46(3 Pt 2):53-8. Source: PubMed. [pmid: 3882682].
3214 Stassen HH, Angst J, Delini-Stula A. Fluoxetine versus moclobemide: cross-comparison between the time courses of improvement. Pharmacopsychiatry. Mar. 1999;32(2):56-60. Source: PubMed. [pmid: 10333163].
3215 Stead Lindsay F, Lancaster T. Interventions to reduce harm from continued tobacco use. Cochrane Database of Systematic Reviews. 2007;(3). Source: The Cochrane Library.
3216 Stedman CA, Begg EJ, Kennedy MA, et al. Cytochrome P450 2D6 genotype does not predict SSRI (fluoxetine or paroxetine) induced hyponatraemia. Hum Psychopharmacol. Jun. 2002;17(4):187-90. Source: PubMed. [pmid: 12404686].
3217 Stedman M, Pettinati HM, Brown ES, et al. A double-blind, placebo-controlled study with quetiapine as adjunct therapy with lithium or divalproex in bipolar I patients with coexisting alcohol dependence. Alcoholism: Clinical and Experimental Research. 2010;34(10):1822-31. Source: EMBASE.
3218 Stefanini E, Fadda F, Medda L, et al. Selective inhibition of serotonin uptake by trazodone, a new antidepressant agent. Life Sci. Jun. 15. 1976;18(12):1459-65. Source: PubMed. [pmid: 940426].
3219 Steffens DC, Doraiswamy PM, McQuoid DR. Bupropion SR in the naturalistic treatment of elderly patients with major depression. Int J Geriatr Psychiatry. Sep. 2001;16(9):862-5. Source: PubMed. [pmid: 11571765].
3220 Stein A, Hinz M, Uncini T. Amino acid-responsive Crohn's disease: A case study. 2010:3171-7. Source: Handsearch.
3221 Stein DJ, Andersen EW, Lader M. Escitalopram versus paroxetine for social anxiety disorder: An analysis of efficacy for different symptom dimensions. European Neuropsychopharmacology. 2006;16(1):33-8. Source: Scopus. [pmid: 16014329].
3222 Stein MB, Kline NA, Matloff JL. Adjunctive olanzapine for SSRI-resistant combat-related PTSD: a double-blind, placebo-controlled study. Am J Psychiatry. Oct. 2002;159(10):1777-9. Source: PubMed. [pmid: 12359687].
3223 Stein MD, Herman DS, Kettavong M, et al. Antidepressant treatment does not improve buprenorphine retention among opioid-dependent persons. Journal of substance abuse treatment. 2010;39(2):157-66. Source: EMBASE. [pmid: 20598836].
3224 Stein MD, Solomon DA, Anderson BJ, et al. Persistence of antidepressant treatment effects in a pharmacotherapy plus psychotherapy trial for active injection drug users. Am J Addict. Jul-Sep. 2005;14(4):346-57. Source: PubMed. [pmid: 16188715].
3225 Steinacher L, Vandel P, Zullino DF, et al. Carbamazepine augmentation in depressive patients non-responding to citalopram: a pharmacokinetic and clinical pilot study. Eur Neuropsychopharmacol. Jun. 2002;12(3):255-60. Source: PubMed. [pmid: 12007677].
3226 Steinberg M, Munro CA, Samus Q, et al. Patient predictors of response to treatment of depression in Alzheimer's disease: the DIADS study. Int J Geriatr Psychiatry. Feb. 2004;19(2):144-50. Source: PubMed. [pmid: 14758580].
3227 Steinmeyer EM, Moller HJ. Facet theoretic analysis of the Hamilton-D scale. J Affect Disord. May. 1992;25(1):53-61. Source: PubMed. [pmid: 1385599].
3228 Stephenson DA, Harris B, Davies RH, et al. The impact of antidepressants on sleep and anxiety: A comparative study of fluoxetine and dothiepin using the Leeds Sleep Evaluation Questionnaire. Hum Psychopharmacol. 2000;15(7):529-34. Source: EMBASE. [pmid: 12404623].
3229 Stern WC, Harto-Truax N, Bauer N. Efficacy of bupropion in tricyclic-resistant or intolerant patients. J Clin Psychiatry. May. 1983;44(5 Pt 2):148-52. Source: PubMed. [pmid: 6406447].
3230 Sternbach H. Fluoxetine-associated potentiation of calcium-channel blockers. J Clin Psychopharmacol. Dec. 1991;11(6):390-1. Source: PubMed. [pmid: 1770159].
3231 Sternbach H. The serotonin syndrome. Am J Psychiatry. Jun. 1991;148(6):705-13. Source: PubMed. [pmid: 2035713].
3232 Stewart DE. Hepatic adverse reactions associated with nefazodone. Can J Psychiatry. 2002. May. 2002;47(4):375-7. Source: Handsearch. [pmid: 12025437].
3233 Stewart DE. Physical symptoms of depression: unmet needs in special populations. J Clin Psychiatry. Suppl 7. 2003;64:12-6. Source: PubMed. [pmid: 12755647].
3234 Stewart DE. Venlafaxine and sour date nut. Am J Psychiatry. Jun. 2004;161(6):1129-30. Source: PubMed. [pmid: 15169710].
3235 Stewart DE, Wohlreich MM, Mallinckrodt CH, et al. Duloxetine in the treatment of major depressive disorder: comparisons of safety and tolerability in male and female patients. J Affect Disord. 2006;94(1-3):183-9. Source: PubMed. [pmid: 16780958].
3236 Stewart JW, Deliyannides DA, McGrath PJ. Is duloxetine effective treatment for depression with atypical features?. Int Clin Psychopharmacol. Nov. 2008;23(6):333-6. Source: PubMed. [pmid: 18854721].
3237 Stewart JW, McGrath PJ, Deliyannides RA, et al. Does dual antidepressant therapy as initial treatment hasten and increase remission from depression?. J Psychiatr Pract. Sep. 2009;15(5):337-45. Source: PubMed. [pmid: 19820552].
3238 Stewart JW, McGrath PJ, Fava M, et al. Do atypical features affect outcome in depressed outpatients treated with citalopram?. Int J Neuropsychopharmacol. Feb. 2010;13(1):15-30. Source: PubMed. [pmid: 19341509].
3239 Stewart JW, Quitkin FM, McGrath PJ, et al. Use of pattern analysis to predict differential relapse of remitted patients with major depression during 1 year of treatment with fluoxetine or placebo. Arch Gen Psychiatry. Apr. 1998;55(4):334-43. Source: PubMed. [pmid: 9554429].
3240 Stockler MR, O'Connell R, Nowak AK, et al. Effect of sertraline on symptoms and survival in patients with advanced cancer, but without major depression: a placebo-controlled double-blind randomised trial. Lancet Oncol. Jul. 2007;8(7):603-12. Source: PubMed. [pmid: 17548243].
3241 Stoffers J, Völlm Birgit A, Rücker G, et al. Pharmacological interventions for borderline personality disorder. Cochrane Database of Systematic Reviews. 2010;(6). Source: The Cochrane Library.
3242 Stokes PE. A primary care perspective on management of acute and long-term depression. J Clin Psychiatry. Aug. 1993;54(Suppl):74-84. discussion 5-7. Source: PubMed. [pmid: 8253708].
3243 Stoll AL, Pillay SS, Diamond L, et al. Methylphenidate augmentation of serotonin selective reuptake inhibitors: a case series. J Clin Psychiatry. Feb. 1996;57(2):72-6. Source: PubMed. [pmid: 8591972].
3244 Stone M, Laughren T, Jones ML, et al. Risk of suicidality in clinical trials of antidepressants in adults: Analysis of proprietary data submitted to US Food and Drug Administration. Bmj. 2009;339(7718):431-4. Source: Scopus.
3245 Stone MB, Jones ML. Clinical Review: Relationship Between Antidepressant Drugs and Suicidality in Adults. 2006. 1-64. Source: Scopus.
3246 Storch DD. Successful use of VNS for depression [15]. Psychiatric Services. 2006;57(10):1518-9. Source: EMBASE. [pmid: 17035589].
3247 Stott PC, Blagden MD, Aitken CA. Depression and associated anxiety in primary care: A double-blind comparison of paroxetine and amitriptyline. European Neuropsychopharmacology. 1993;3(3):324-5. Source: EMBASE.
3248 Strachan J, Shepherd J. Hyponatraemia associated with the use of selective serotonin re-uptake inhibitors. Aust N Z J Psychiatry. Apr. 1998;32(2):295-8. Source: PubMed. [pmid: 9588311].
3249 Straton JB, Cronholm P. Are paroxetine, fluoxetine, and sertraline equally effective for depression?. J Fam Pract. Mar. 2002;51(3):285. Source: PubMed. [pmid: 11978244].
3250 Stratta P, Bolino F, Cupillari M, et al. A double-blind parallel study comparing fluoxetine with imipramine in the treatment of atypical depression. Int Clin Psychopharmacol. Winter. 1991;6(3):193-6. Source: PubMed. [pmid: 1806625].
3251 Strauss WL, Unis AS, Cowan C, et al. Fluorine magnetic resonance spectroscopy measurement of brain fluvoxamine and fluoxetine in pediatric patients treated for pervasive developmental disorders. Am J Psychiatry. May. 2002;159(5):755-60. Source: PubMed. [pmid: 11986128].
3252 Strik JJ, Honig A, Lousberg R, et al. Cardiac side-effects of two selective serotonin reuptake inhibitors in middle-aged and elderly depressed patients. Int Clin Psychopharmacol. Nov. 1998;13(6):263-7. Source: PubMed. [pmid: 9861576].
3253 Strik JJ, Honig A, Lousberg R, et al. Efficacy and safety of fluoxetine in the treatment of patients with major depression after first myocardial infarction: findings from a double-blind, placebo-controlled trial. Psychosom Med. Nov-Dec. 2000;62(6):783-9. Source: PubMed. [pmid: 11138997].
3254 Strohle A, Pasini A, Romeo E, et al. Fluoxetine decreases concentrations of 3 alpha, 5 alpha-tetrahydrodeoxycorticosterone (THDOC) in major depression. J Psychiatr Res. May-Jun. 2000;34(3):183-6. Source: PubMed. [pmid: 10867112].
3255 Strombom I, Wernicke JF, Seeger J, et al. Hepatic effects of duloxetine-III: analysis of hepatic events using external data sources. Curr Drug Saf. May. 2008;3(2):154-62. Source: PubMed. [pmid: 18690993].
3256 Strunk DR, Stewart MO, Hollon SD, et al. Can pharmacotherapists be too supportive? A process study of active medication and placebo in the treatment of depression. Psychol Med. Aug. 2010;40(8):1379-87. Source: PubMed. [pmid: 19891806].
3257 Stulz N, Thase ME, Klein DN, et al. Differential effects of treatments for chronic depression: a latent growth model reanalysis. J Consult Clin Psychol. Jun. 2010;78(3):409-19. Source: PubMed. [pmid: 20515216].
3258 Stuppaeck CH, Geretsegger C, Whitworth AB, et al. A multicenter double-blind trial of paroxetine versus amitriptyline in depressed inpatients. J Clin Psychopharmacol. Aug. 1994;14(4):241-6. Source: PubMed. [pmid: 7962679].
3259 Su JA, Chou SY, Chang CJ, et al. Changes in consultation-liaison psychiatry in the first five years of opearation of a newly-opened hospital. Chang Gung Medical Journal. 2010;33(3):292-300. Source: EMBASE. [pmid: 20584507].
3260 Suchowersky O, deVries JD, editors. Interaction of fluoxetine and selegiline. Can J Psychiatry. Aug. 1990;35(6):571-2. Source: PubMed. [pmid: 2119876].
3261 Sugiyama N, Sasayama D, Amano N. Remarkable antidepressant augmentation effect of raloxifene, a selective estrogen receptor modulator, in a partial responder to fluvoxamine: a case report. J Clin Psychiatry. Apr. 2007;68(4):636-7. Source: PubMed. [pmid: 17474826].
3262 Sullivan EM, Griffiths RI, Frank RG, et al. One-year costs of second-line therapies for depression. J Clin Psychiatry. Apr. 2000;61(4):290-8. Source: PubMed. [pmid: 10830151].
3263 Sullivan G. Increased libido in three men treated with trazodone. J Clin Psychiatry. May. 1988;49(5):202-3. Source: PubMed. [pmid: 3366758].
3264 Sullivan MD, Katon WJ, Russo JE, et al. Patient beliefs predict response to paroxetine among primary care patients with dysthymia and minor depression. J Am Board Fam Pract. Jan-Feb. 2003;16(1):22-31. Source: PubMed. [pmid: 12583647].
3265 Sunder KR, Wisner KL, Hanusa BH, et al. Postpartum depression recurrence versus discontinuation syndrome: observations from a randomized controlled trial. J Clin Psychiatry. Sep. 2004;65(9):1266-8. Source: PubMed. [pmid: 15367055].
3266 Suri R, Altshuler L, Hendrick V, et al. The impact of depression and fluoxetine treatment on obstetrical outcome. Arch Women Ment Health. Jul. 2004;7(3):193-200. Source: PubMed.
3267 Suri R, Hellemann G, Cohen L, et al. Saliva Estriol Levels in Women with and Without Prenatal Antidepressant Treatment. Biological Psychiatry. 2008;64(6):533-7. Source: EMBASE. [pmid: 18495086].
3268 Suri RA, Altshuler LL, Rasgon NL, et al. Efficacy and response time to sertraline versus fluoxetine in the treatment of unipolar major depressive disorder. Journal Of Clinical Psychiatry. 2000;61(12):942-6. Source: EMBASE. [pmid: 11206600].
3269 Sussman N. Venlafaxine XR therapy for major depression and anxiety disorders. The clinical implications that its advantages pose. Postgrad Med. Nov. 1999;106(6 Suppl):31-6. Source: PubMed. [pmid: 19667502].
3270 Suzuki Y, Fukui N, Sawamura K, et al. Concentration-response relationship for fluvoxamine using remission as an endpoint: a receiver operating characteristics curve analysis in major depression. J Clin Psychopharmacol. Jun. 2008;28(3):325-8. Source: PubMed. [pmid: 18480690].
3271 Swartz JR, Miller BL, Lesser IM, et al. Frontotemporal dementia: treatment response to serotonin selective reuptake inhibitors. J Clin Psychiatry. May. 1997;58(5):212-6. Source: PubMed. [pmid: 9184615].
3272 Swiecicki L, Szafranski T. Side effects after phototherapy implementation in addition to fluoxetine or sertraline treatment: a report of two cases. World J Biol Psychiatry. Apr. 2002;3(2):109-11. Source: PubMed. [pmid: 12479085].
3273 Szabo CP. Fluoxetine and sumatriptan: possibly a counterproductive combination. J Clin Psychiatry. Jan. 1995;56(1):37-8. Source: PubMed. [pmid: 7836342].
3274 Szanto K, Mulsant BH, Houck P, et al. Occurrence and course of suicidality during short-term treatment of late-life depression. Arch Gen Psychiatry. Jun. 2003;60(6):610-7. Source: PubMed. [pmid: 12796224].
3275 Szegedi A, Kohnen R, Dienel A, et al. Acute treatment of moderate to severe depression with hypericum extract WS 5570 (St John's wort): randomised controlled double blind non-inferiority trial versus paroxetine. Bmj. Mar. 5. 2005;330(7490):503. Source: PubMed. [pmid: 15708844].
3276 Szegedi A, Muller MJ, Anghelescu I, et al. Early improvement under mirtazapine and paroxetine predicts later stable response and remission with high sensitivity in patients with major depression. J Clin Psychiatry. Apr. 2003;64(4):413-20. Source: PubMed. [pmid: 12716243].
3277 Szegedi A, Rujescu D, Tadic A, et al. The catechol-O-methyltransferase Val108/158Met polymorphism affects short-term treatment response to mirtazapine, but not to paroxetine in major depression. Pharmacogenomics J. 2005;5(1):49-53. Source: PubMed. [pmid: 15520843].
3278 Szegedi A, Wetzel H, Angersbach D, et al. A double-blind study comparing paroxetine and maprotiline in depressed outpatients. Pharmacopsychiatry. May. 1997;30(3):97-105. Source: PubMed. [pmid: 9211571].
3279 Szegedi A, Wetzel H, Angersbach D, et al. Response to treatment in minor and major depression: results of a double-blind comparative study with paroxetine and maprotiline. J Affect Disord. Sep. 1997;45(3):167-78. Source: PubMed. [pmid: 9298430].
3280 Tadic A, Gorbulev S, Dahmen N, et al. Rationale and design of the randomised clinical trial comparing early medication change (EMC) strategy with treatment as usual (TAU) in patients with Major Depressive Disorder - the EMC trial. Trials. 2010;11. Source: EMBASE.
3281 Tadic A, Helmreich I, Mergl R, et al. Early improvement is a predictor of treatment outcome in patients with mild major, minor or subsyndromal depression. J Affect Disord. Jan. 2010;120(1-3):86-93. Source: PubMed. [pmid: 19428118].
3282 Tadic A, Muller MJ, Rujescu D, et al. The MAOA T941G polymorphism and short-term treatment response to mirtazapine and paroxetine in major depression. Am J Med Genet B Neuropsychiatr Genet. Apr. 5. 2007;144B(3):325-31. Source: PubMed. [pmid: 17192957].
3283 Tadić A, Rujescu D, Müller MJ, et al. Association analysis between variants of the interleukin-1β and the interleukin-1 receptor antagonist gene and antidepressant treatment response in major depression. Neuropsychiatric Disease and Treatment. 2008. 2008;4(1):269-76. Source: PsycINFO. [pmid: 18728809].
3284 Tadic A, Rujescu D, Muller MJ, et al. A monoamine oxidase B gene variant and short-term antidepressant treatment response. Prog Neuropsychopharmacol Biol Psychiatry. Oct. 1. 2007;31(7):1370-7. Source: PubMed. [pmid: 17640790].
3285 Takahashi T, Yucel M, Lorenzetti V, et al. Volumetric MRI study of the insular cortex in individuals with current and past major depression. Journal of affective disorders. 2010;121(3):231-8. Source: EMBASE. [pmid: 19540599].
3286 Takahashi T, Yucel M, Lorenzetti V, et al. An MRI study of the superior temporal subregions in patients with current and past major depression. Progress in Neuro-Psychopharmacology and Biological Psychiatry. 2010;34(1):98-103. Source: EMBASE. [pmid: 19835925].
3287 Takebayashi M, Hashimoto R, Hisaoka K, et al. Plasma levels of vascular endothelial growth factor and fibroblast growth factor 2 in patients with major depressive disorders. Journal of Neural Transmission. 2010;117(9):1119-22. Source: EMBASE. [pmid: 20690032].
3288 Takeshima M, Kitamura T, Kitamura M, et al. Impact of depressive mixed state in an emergency psychiatry setting: A marker of bipolar disorder and a possible risk factor for emergency hospitalization. Journal of Affective Disorders. 2008;111(1):52-60. Source: EMBASE. [pmid: 18355924].
3289 Talarowska M, Florkowski A, Zboralski K, et al. Auditory-verbal declarative and operating memory among patients suffering from depressive disorders - preliminary study. Advances in Medical Sciences. 2010;55(2):317-27. Source: EMBASE. [pmid: 21163755].
3290 Tam LW, Parry BL. Does estrogen enhance the antidepressant effects of fluoxetine?. Journal Of Affective Disorders. 2003;77(1):87-92. Source: EMBASE. [pmid: 14550939].
3291 Tamayo JM, Gomez G, Barrios R, et al. Differential time course efficacy on dysphoric and physical symptoms of the intermittent dosing of fluoxetine in the premenstrual dysphoric disorder. J Clin Psychopharmacol. Aug. 2004;24(4):469-71. Source: PubMed. [pmid: 15232351].
3292 Tamayo JM, Sutton VK, Mattei MA, et al. Effectiveness and Safety of the Combination of Fluoxetine and Olanzapine in Outpatients With Bipolar Depression <it>An Open</it>-<it>Label</it>, <it>Randomized</it>, <it>Flexible</it>-<it>Dose Study in Puerto Rico</it>. Journal of Clinical Psychopharmacology (USA). 2009;29358. Source: Handsearch.
3293 Tamminen TT, Lehtinen VV. A double-blind parallel study to compare fluoxetine with doxepin in the treatment of major depressive disorders. Int Clin Psychopharmacol. Jan. Suppl 1. 1989;4:51-6. Source: PubMed. [pmid: 2783699].
3294 Tan ZL, Bao AM, Tao M, et al. Circadian rhythm of salivary serotonin in patients with major depressive disorder. Neuro Endocrinol Lett. Aug. 2007;28(4):395-400. Source: PubMed. [pmid: 17693970].
3295 Taner E, Demir EY, Cosar B. Comparison of the effectiveness of reboxetine versus fluoxetine in patients with atypical depression: a single-blind, randomized clinical trial. Adv Ther. Nov-Dec. 2006;23(6):974-87. Source: PubMed. [pmid: 17276965].
3296 Taneri Z, Kohler R. Fluoxetine versus nomifensine in outpatients with neurotic or reactive depressive disorder. Int Clin Psychopharmacol. Jan. Suppl 1. 1989;4:57-61. Source: PubMed. [pmid: 2783700].
3297 Taragano F, Lyketsos CG, Paz J, et al. An open-label trial of sertraline for the treatment of major depression in primary care. Ann Clin Psychiatry. Jun. 1999;11(2):67-71. Source: PubMed. [pmid: 10440523].
3298 Taragano FE, Bagnatti P, Allegri RF. A double-blind, randomized clinical trial to assess the augmentation with nimodipine of antidepressant therapy in the treatment of “vascular depression”. Int Psychogeriatr. Sep. 2005;17(3):487-98. Source: PubMed. [pmid: 16252380].
3299 Taragano FE, Lyketsos CG, Mangone CA, et al. A double-blind, randomized, fixed-dose trial of fluoxetine vs. amitriptyline in the treatment of major depression complicating Alzheimer's disease. Psychosomatics. May-Jun. 1997;38(3):246-52. Source: PubMed. [pmid: 9136253].
3300 Tardieu S, Bottero A, Blin P, et al. Roles and practices of general practitioners and psychiatrists in management of depression in the community. BMC Fam Pract. 2006;7:6. Source: PubMed.
3301 Targownik LE, Bolton JM, Metge CJ, et al. Selective serotonin reuptake inhibitors are associated with a modest increase in the risk of upper gastrointestinal bleeding. Am J Gastroenterol. Jun. 2009;104(6):1475-82. Source: PubMed. [pmid: 19491861].
3302 Tarn M, Edwards JG, Sedgwick EM. Fluoxetine, amitriptyline and the electroencephalogram. J Affect Disord. Sep. 1993;29(1):7-10. Source: PubMed. [pmid: 8254147].
3303 Tarricone R, Fattore G, Gerzeli S, et al. The costs of pharmacological treatment for major depression. The Italian Prospective Multicentre Observational Incidence-Based Study. Pharmacoeconomics. Feb. 2000;17(2):167-74. Source: PubMed. [pmid: 10947339].
3304 Tauscher-Wisniewski S, Disch D, Plewes J, et al. Evaluating suicide-related adverse events in clinical trials of fluoxetine treatment in adults for indications other than major depressive disorder. Psychological Medicine. 2007;37(11):1585-93. Source: Scopus. [pmid: 17640442].
3305 Taylor BP, Bruder GE, Stewart JW, et al. Psychomotor slowing as a predictor of fluoxetine nonresponse in depressed outpatients. Am J Psychiatry. Jan. 2006;163(1):73-8. Source: PubMed. [pmid: 16390892].
3306 Taylor D, Ellison Z, Ementon Shaw L, et al. Co-administration of citalopram and clozapine: effect on plasma clozapine levels. Int Clin Psychopharmacol. Jan. 1998;13(1):19-21. Source: PubMed. [pmid: 9988363].
3307 Taylor FB, Prather MR. The efficacy of nefazodone augmentation for treatment-resistant depression with anxiety symptoms or anxiety disorder. Depress Anxiety. 2003;18(2):83-8. Source: PubMed. [pmid: 12964175].
3308 Taylor IC, McConnell JG. Severe hyponatraemia associated with selective serotonin reuptake inhibitors. Scott Med J. Oct. 1995;40(5):147-8. Source: PubMed. [pmid: 8578303].
3309 Taylor MJ, Carney SM, Goodwin GM, et al. Folate for depressive disorders: systematic review and meta-analysis of randomized controlled trials. J Psychopharmacol. Jun. 2004;18(2):251-6. Source: PubMed. [pmid: 15260915].
3310 Taylor MJ, Freemantle N, Geddes JR, et al. Early onset of selective serotonin reuptake inhibitor antidepressant action: Systematic review and meta-analysis. Archives of General Psychiatry. 2006;63(11):1217-23. Source: Scopus. [pmid: 17088502].
3311 Taylor MJ, Norbury R, Murphy S, et al. Lack of effect of citalopram on magnetic resonance spectroscopy measures of glutamate and glutamine in frontal cortex of healthy volunteers. J Psychopharmacol. Aug. 2010;24(8):1217-21. Source: PubMed. [pmid: 19423614].
3312 Taylor MJ, Rudkin L, Hawton K. Strategies for managing antidepressant-induced sexual dysfunction: Systematic review of randomised controlled trials. J Affect Disord. 2005. Sep. 12. Source: PubMed.
3313 Taylor WD, Kuchibhatla M, Payne ME, et al. Frontal white matter anisotropy and antidepressant remission in late-life depression. PLoS One. 2008;3(9):e3267. Source: PubMed. [pmid: 18813343].
3314 Teicher MH, Glod C, Cole JO. Emergence of intense suicidal preoccupation during fluoxetine treatment. Am J Psychiatry. Feb. 1990;147(2):207-10. Source: PubMed. [pmid: 2301661].
3315 ten Klooster PM, Drossaers-Bakker KW, Taal E, et al. Patient-perceived satisfactory improvement (PPSI): interpreting meaningful change in pain from the patient's perspective. Pain. Mar. 2006;121(1-2):151-7. Source: PubMed. [pmid: 16472915].
3316 Tengstrand M, Star K, Van Puijenbroek EP, et al. Alopecia in association with lamotrigine use: An analysis of individual case safety reports in a global database. Drug Safety. 2010;33(8):653-8. Source: EMBASE. [pmid: 20635823].
3317 Terao T. Comparison of manic switch onset during fluoxetine and trazodone treatment. Biol Psychiatry. Mar. 15. 1993;33(6):477-8. Source: PubMed. [pmid: 8490074].
3318 Terao T. Rapid synergistic effects of lithium and antidepressants. Psychopharmacology (Berl). Nov. 1995;122(2):206-7. Source: PubMed. [pmid: 8848539].
3319 Terao T. Unusual weight fluctuation under corticosteroid and psychotropic treatment. Psychiatry Clin Neurosci. Oct. 2008;62(5):617-9. Source: PubMed. [pmid: 18950384].
3320 Terra JL, Montgomery SA. Fluvoxamine prevents recurrence of depression: results of a long-term, double-blind, placebo-controlled study. Int Clin Psychopharmacol. Mar. 1998;13(2):55-62. Source: PubMed. [pmid: 9669185].
3321 Tesar GE. Treating depression in a mother of five: what to do when the first step fails. Cleve Clin J Med. Jun. 2005;72(6):501-6. Source: PubMed. [pmid: 16018291].
3322 Tew JD Jr, Mulsant BH, Houck PR, et al. Impact of prior treatment exposure on response to antidepressant treatment in late life. Am J Geriatr Psychiatry. Nov. 2006;14(11):957-65. Source: PubMed. [pmid: 17068318].
3323 Thakore JH, Barnes C, Joyce J, et al. Effects of antidepressant treatment on corticotropin-induced cortisol responses in patients with melancholic depression. Psychiatry Res. Nov. 14. 1997;73(1-2):27-32. Source: PubMed. [pmid: 9463836].
3324 Thakore JH, Dinan TG. Effect of fluoxetine on dexamethasone-induced growth hormone release in depression: a double-blind, placebo-controlled study. Am J Psychiatry. Apr. 1995;152(4):616-8. Source: PubMed. [pmid: 7694914].
3325 Thapa PB, Gideon P, Cost TW, et al. Antidepressants and the risk of falls among nursing home residents. N Engl J Med. Sep. 24. 1998;339(13):875-82. Source: PubMed. [pmid: 9744971].
3326 Thase ME. Efficacy and tolerability of once-daily venlafaxine extended release (XR) in outpatients with major depression. The Venlafaxine XR 209 Study Group. J Clin Psychiatry. Sep. 1997;58(9):393-8. Source: PubMed. [pmid: 9378690].
3327 Thase ME. Effects of venlafaxine on blood pressure: a meta-analysis of original data from 3744 depressed patients. J Clin Psychiatry. Oct. 1998;59(10):502-8. Source: PubMed. [pmid: 9818630].
3328 Thase ME. The clinical, psychosocial, and pharmacoeconomic ramifications of remission. Am J Manag Care. Sep. 2001;7(11 Suppl):S377-85. Source: PubMed. [pmid: 11570028].
3329 Thase ME. Effectiveness of antidepressants: comparative remission rates. J Clin Psychiatry. Suppl 2. 2003;64:3-7. Source: PubMed.
3330 Thase ME. Managing depressive and anxiety disorders with escitalopram. Expert Opinion on Pharmacotherapy. 2006;7(4):429-40. Source: Scopus. [pmid: 16503815].
3331 Thase ME. Update on partial response in depression. J Clin Psychiatry. Suppl 6. 2009;70:4-9. Source: PubMed. [pmid: 19922738].
3332 Thase ME, Blomgren SL, Birkett MA, et al. Fluoxetine treatment of patients with major depressive disorder who failed initial treatment with sertraline. J Clin Psychiatry. Jan. 1997;58(1):16-21. Source: PubMed. [pmid: 9055832].
3333 Thase ME, Clayton AH, Haight BR, et al. A double-blind comparison between bupropion XL and venlafaxine XR: sexual functioning, antidepressant efficacy, and tolerability. J Clin Psychopharmacol. 2006;26(5):482-8. Source: PubMed. [pmid: 16974189].
3334 Thase ME, Corya SA, Osuntokun O, et al. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, and fluoxetine in treatment-resistant major depressive disorder. J Clin Psychiatry. Feb. 2007;68(2):224-36. Source: PubMed. [pmid: 17335320].
3335 Thase ME, Entsuah AR, Rudolph RL. Remission rates during treatment with venlafaxine or selective serotonin reuptake inhibitors. Br J Psychiatry. Mar. 2001;178:234-41. Source: PubMed. [pmid: 11230034].
3336 Thase ME, Entsuah R, Cantillon M, et al. Relative Antidepressant Efficacy of Venlafaxine and SSRIs: Sex-Age Interactions. J Womens Health (Larchmt). Sep. 2005;14(7):609-16. Source: PubMed. [pmid: 16181017].
3337 Thase ME, Fava M, DeBattista C, et al. Modafinil augmentation of SSRI therapy in patients with major depressive disorder and excessive sleepiness and fatigue: a 12-week, open-label, extension study. CNS Spectr. Feb. 2006;11(2):93-102. Source: PubMed. [pmid: 16520686].
3338 Thase ME, Fava M, DeBattista C, et al. ‘Serious Adverse Events and the Modafinil Augmentation Study’: The Authors respond. CNS Spectrums. May. 2006. 2006;11(5):340-2. Source: PsycINFO. [pmid: 16791971].
3339 Thase ME, Fava M, Halbreich U, et al. A placebo-controlled, randomized clinical trial comparing sertraline and imipramine for the treatment of dysthymia. Arch Gen Psychiatry. Sep. 1996;53(9):777-84. Source: PubMed. [pmid: 8792754].
3340 Thase ME, Feighner JP, Lydiard RB. Citalopram treatment of fluoxetine nonresponders. J Clin Psychiatry. Sep. 2001;62(9):683-7. Source: PubMed. [pmid: 11681763].
3341 Thase ME, Ferguson JM, Lydiard RB, et al. Citalopram treatment of paroxetine-intolerant depressed patients. Depress Anxiety. 2002;16(3):128-33. Source: PubMed. [pmid: 12415538].
3342 Thase ME, Friedman ES, Biggs MM, et al. Cognitive therapy versus medication in augmentation and switch strategies as second-step treatments: a STAR*D report. Am J Psychiatry. May. 2007;164(5):739-52. Source: PubMed. [pmid: 17475733].
3343 Thase ME, Friedman ES, Fasiczka AL, et al. Treatment of men with major depression: a comparison of sequential cohorts treated with either cognitive-behavioral therapy or newer generation antidepressants. J Clin Psychiatry. Jul. 2000;61(7):466-72. Source: PubMed. [pmid: 10937603].
3344 Thase ME, Friedman ES, Howland RH. Venlafaxine and treatment-resistant depression. Depress Anxiety. Suppl 1. 2000;12:55-62. Source: PubMed. [pmid: 11098415].
3345 Thase ME, Gelenberg A, Kornstein SG, et al. Comparing venlafaxine extended release and fluoxetine for preventing the recurrence of major depression: Results from the PREVENT study. J Psychiatr Res. 2010. Source: PubMed.
3346 Thase ME, Haight BR, Richard N, et al. Remission rates following antidepressant therapy with bupropion or selective serotonin reuptake inhibitors: A meta-analysis of original data from 7 randomized controlled trials. Journal of Clinical Psychiatry. 2005;66(8):974-81. Source: Scopus. [pmid: 16086611].
3347 Thase ME, Kornstein SG, Germain JM, et al. An integrated analysis of the efficacy of desvenlafaxine compared with placebo in patients with major depressive disorder. CNS Spectr. 2009;14(3):144-54. Source: PubMed. [pmid: 19407711].
3348 Thase ME, Nierenberg AA, Keller MB, et al. Efficacy of mirtazapine for prevention of depressive relapse: a placebo-controlled double-blind trial of recently remitted high-risk patients. J Clin Psychiatry. Oct. 2001;62(10):782-8. Source: PubMed. [pmid: 11816867].
3349 Thase ME, Nierenberg AA, Vrijland P, et al. Remission with mirtazapine and selective serotonin reuptake inhibitors: A meta-analysis of individual patient data from 15 controlled trials of acute phase treatment of major depression. International Clinical Psychopharmacology. 2010;25(4):189-98. Source: PsycINFO. [pmid: 20531012].
3350 Thase ME, Rush AJ. When at first you don't succeed: sequential strategies for antidepressant nonresponders. J Clin Psychiatry. Suppl 13. 1997;58:23-9. Source: PubMed. [pmid: 9402916].
3351 Thase ME, Rush AJ, Howland RH, et al. Double-blind switch study of imipramine or sertraline treatment of antidepressant-resistant chronic depression. Arch Gen Psychiatry. Mar. 2002;59(3):233-9. Source: PubMed. [pmid: 11879161].
3352 Thase ME, Rush AJ, Manber R, et al. Differential effects of nefazodone and cognitive behavioral analysis system of psychotherapy on insomnia associated with chronic forms of major depression. J Clin Psychiatry. Jun. 2002;63(6):493-500. Source: PubMed. [pmid: 12088160].
3353 Thase ME, Shelton RC, Khan A. Treatment with venlafaxine extended release after SSRI nonresponse or intolerance: a randomized comparison of standard- and higher-dosing strategies. J Clin Psychopharmacol. Jun. 2006;26(3):250-8. Source: PubMed. [pmid: 16702889].
3354 Thase ME, Tran PV, Wiltse C, et al. Cardiovascular profile of duloxetine, a dual reuptake inhibitor of serotonin and norepinephrine. J Clin Psychopharmacol. Apr. 2005;25(2):132-40. Source: PubMed. [pmid: 15738744].
3355 Thiels C, Linden M, Grieger F, et al. Gender differences in routine treatment of depressed outpatients with the selective serotonin reuptake inhibitor sertraline. Int Clin Psychopharmacol. Jan. 2005;20(1):1-7. Source: PubMed. [pmid: 15602108].
3356 Thompson C. Bridging the gap between psychiatric practice and primary care. Int Clin Psychopharmacol. Oct. Suppl 2. 1992;7:31-6. Source: PubMed. [pmid: 1484176].
3357 Thompson C. Management of depression in real-life settings: knowledge gained from large-scale clinical trials. Int Clin Psychopharmacol. Jun. Suppl 3. 1994;9:21-5. Source: PubMed. [pmid: 7963447].
3358 Thompson C. Discontinuation of antidepressant therapy: emerging complications and their relevance. J Clin Psychiatry. Oct. 1998;59(10):541-8. Source: PubMed. [pmid: 9818638].
3359 Thompson C, Peveler RC, Stephenson D, et al. Compliance with antidepressant medication in the treatment of major depressive disorder in primary care: a randomized comparison of fluoxetine and a tricyclic antidepressant. Am J Psychiatry. Mar. 2000;157(3):338-43. Source: PubMed. [pmid: 10698807].
3360 Thompson M, Samuels S. Rhabdomyolysis with simvastatin and nefazodone. Am J Psychiatry. Sep. 2002;159(9):1607. Source: PubMed. [pmid: 12202291].
3361 Thorell LH, Kjellman B, Arned M, et al. Light treatment of seasonal affective disorder in combination with citalopram or placebo with 1-year follow-up. Int Clin Psychopharmacol. May. Suppl 2. 1999;14:S7-11. Source: PubMed. [pmid: 10471167].
3362 Tignol J. A double-blind, randomized, fluoxetine-controlled, multicenter study of paroxetine in the treatment of depression. J Clin Psychopharmacol. Dec. 1993;13(6 Suppl 2):18S-22S. Source: PubMed. [pmid: 8106650].
3363 Timmerman L, de Beurs P, Tan BK, et al. A double-blind comparative clinical trial of citalopram vs maprotiline in hospitalized depressed patients. Int Clin Psychopharmacol. Jul. 1987;2(3):239-53. Source: PubMed. [pmid: 2447151].
3364 Tint A, Haddad PM, Anderson IM. The effect of rate of antidepressant tapering on the incidence of discontinuation symptoms: a randomised study. J Psychopharmacol. May. 2008;22(3):330-2. Source: PubMed. [pmid: 18515448].
3365 Tobiansky RI, Lloyd GG, Tobiansky I, et al. ECT seizure threshold and fluoxetine. Br J Psychiatry. Feb. 1995;166(2):263. Source: PubMed. [pmid: 7728376].
3366 Todder D, Caliskan S, Baune BT. Longitudinal changes of day-time and nighttime gross motor activity in clinical responders and non-responders of major depression. World J Biol Psychiatry. 2009;10(4):276-84. Source: PubMed. [pmid: 19921969].
3367 Tohen M, Case M, Trivedi MH, et al. Olanzapine/fluoxetine combination in patients with treatment-resistant depression: rapid onset of therapeutic response and its predictive value for subsequent overall response in a pooled analysis of 5 studies. J Clin Psychiatry. Apr. 2010;71(4):451-62. Source: PubMed. [pmid: 20361905].
3368 Tollefson GD, Bosomworth JC, Heiligenstein JH, et al. A double-blind, placebo-controlled clinical trial of fluoxetine in geriatric patients with major depression. The Fluoxetine Collaborative Study Group. Int Psychogeriatr. Spring. 1995;7(1):89-104. Source: PubMed. [pmid: 7579025].
3369 Tollefson GD, Greist JH, Jefferson JW, et al. Is baseline agitation a relative contraindication for a selective serotonin reuptake inhibitor: a comparative trial of fluoxetine versus imipramine. J Clin Psychopharmacol. Dec. 1994;14(6):385-91. Source: PubMed. [pmid: 7884018].
3370 Tollefson GD, Heiligenstein JH, Tollefson SL, et al. Is there a relationship between baseline and treatment-associated changes in [3H]-IMI platelet binding and clinical response in major depression?. Neuropsychopharmacology. Jan. 1996;14(1):47-53. Source: PubMed. [pmid: 8719029].
3371 Tollefson GD, Holman SL. Analysis of the Hamilton Depression Rating Scale factors from a double-blind, placebo-controlled trial of fluoxetine in geriatric major depression. Int Clin Psychopharmacol. Winter. 1993;8(4):253-9. Source: PubMed. [pmid: 8277144].
3372 Tollefson GD, Holman SL, Sayler ME, et al. Fluoxetine, placebo, and tricyclic antidepressants in major depression with and without anxious features. J Clin Psychiatry. 1994;55(2):50-9. Source: PubMed. [pmid: 8077155].
3373 Tollefson GD, Rampey AH Jr, Beasley CM Jr, et al. Absence of a relationship between adverse events and suicidality during pharmacotherapy for depression. J Clin Psychopharmacol. Jun. 1994;14(3):163-9. Source: PubMed. [pmid: 8027412].
3374 Tollefson GD, Saxena S, Luxenberg M, et al. A retrospective evaluation of plasma trazodone concentrations and clinical response in a primary care clinic. Hillside J Clin Psychiatry. 1988;10(2):183-7. Source: PubMed. [pmid: 3224945].
3375 Tollefson GD, Souetre E, Thomander L, et al. Comorbid anxious signs and symptoms in major depression: impact on functional work capacity and comparative treatment outcomes. Int Clin Psychopharmacol. Winter. 1993;8(4):281-93. Source: PubMed. [pmid: 8277149].
3376 Tollefson GD, Tollefson SL, Sayler ME, et al. Absence of emergent suicidal ideation during treatment: A comparative, controlled, double-blind analysis employing several distinct antidepressants. Depression. 1994;2(2):73-9. Source: EMBASE.
3377 Tomaselli G, Modestin J. Repetition of serotonin syndrome after reexposure to SSRI--a case report. Pharmacopsychiatry. Sep. 2004;37(5):236-8. Source: PubMed. [pmid: 15359377].
3378 Tome MB, Cloninger CR, Watson JP, et al. Serotonergic autoreceptor blockade in the reduction of antidepressant latency: personality variables and response to paroxetine and pindolol. J Affect Disord. Jul. 1997;44(2-3):101-9. Source: PubMed. [pmid: 9241570].
3379 Tome MB, Isaac MT. One year real world prospective follow-up study of a major depressive episode of patients treated with paroxetine and pindolol or paroxetine for 6 weeks. Int Clin Psychopharmacol. Jul. 1998;13(4):169-74. Source: PubMed. [pmid: 9727727].
3380 Tome MB, Isaac MT, Harte R, et al. Paroxetine and pindolol: a randomized trial of serotonergic autoreceptor blockade in the reduction of antidepressant latency. Int Clin Psychopharmacol. Mar. 1997;12(2):81-9. Source: PubMed. [pmid: 9219043].
3381 Torrens M, Fonseca F, Mateu G, et al. Efficacy of antidepressants in substance use disorders with and without comorbid depression A systematic review and meta-analysis. Drug and Alcohol Dependence. Apr. 2005. 2005;78(1):1-22. Source: PsycINFO. [pmid: 15769553].
3382 Torta R, Siri I, Caldera P. Sertraline effectiveness and safety in depressed oncological patients. Support Care Cancer. Jan. 2008;16(1):83-91. Source: PubMed. [pmid: 17874143].
3383 Tourian KA, Jiang Q, Ninan PT. Analysis of the effect of desvenlafaxine on anxiety symptoms associated with major depressive disorder: pooled data from 9 short-term, double-blind, placebo-controlled trials. CNS Spectr. Mar. 2010;15(3):187-93. Source: PubMed. [pmid: 20414167].
3384 Tourian KA, Padmanabhan K, Groark J, et al. Retrospective analysis of suicidality in patients treated with the antidepressant desvenlafaxine. J Clin Psychopharmacol. Aug. 2010;30(4):411-6. Source: PubMed. [pmid: 20631558].
3385 Tourian KA, Padmanabhan SK, Groark J, et al. Desvenlafaxine 50 and 100 mg/d in the treatment of major depressive disorder: an 8-week, phase III, multicenter, randomized, double-blind, placebo-controlled, parallel-group trial and a post hoc pooled analysis of three studies. Clin Ther. 2009;31(Pt 1):1405-23. Source: PubMed. [pmid: 19698901].
3386 Tournier M, Greenfield B, Galbaud du Fort G, et al. Patterns of antidepressant use in Quebec children and adolescents: Trends and predictors. Psychiatry Research. 2010;179(1):57-63. Source: EMBASE. [pmid: 20621363].
3387 Trappler B, Cohen CI. Use of SSRIs in “very old” depressed nursing home residents. Am J Geriatr Psychiatry. Winter. 1998;6(1):83-9. Source: PubMed. [pmid: 9469218].
3388 Trappler B, Miyashiro AM. Bupropion-amantadine-associated neurotoxicity. J Clin Psychiatry. Jan. 2000;61(1):61-2. Source: PubMed. [pmid: 10695649].
3389 Tribo MJ, Andion O, Ros S, et al. Clinical characteristics and psychopathological profile of patients with vulvodynia: an observational and descriptive study. Dermatology. 2008;216(1):24-30. Source: PubMed. [pmid: 18032895].
3390 Trick L, Stanley N, Rigney U, et al. A double-blind, randomized, 26-week study comparing the cognitive and psychomotor effects and efficacy of 75 mg (37.5 mg b.i.d.) venlafaxine and 75 mg (25 mg mane, 50 mg nocte) dothiepin in elderly patients with moderate major depression being treated in general practice. J Psychopharmacol. Jun. 2004;18(2):205-14. Source: PubMed. [pmid: 15260909].
3391 Trifirò G, Dieleman J, Sen EF, et al. Risk of ischemic stroke associated with antidepressant drug use in elderly persons. Journal of Clinical Psychopharmacology. 2010;30(3):252-8. Source: PubMed. [pmid: 20473059].
3392 Triggs WJ, Ricciuti N, Ward HE, et al. Right and left dorsolateral pre-frontal rTMS treatment of refractory depression: A randomized, sham-controlled trial. Psychiatry Research. 2010;178(3):467-74. Source: EMBASE. [pmid: 20643486].
3393 Trivedi MH. Major depressive disorder: Remission of associated symptoms. Journal of Clinical Psychiatry. 2006;67(SUPPL. 6):27-32. Source: Scopus. [pmid: 16848674].
3394 Trivedi MH, Corey-Lisle PK, Guo Z, et al. Remission, response without remission, and nonresponse in major depressive disorder: impact on functioning. Int Clin Psychopharmacol. May. 2009;24(3):133-8. Source: PubMed. [pmid: 19318972].
3395 Trivedi MH, Dunner DL, Kornstein SG, et al. Psychosocial outcomes in patients with recurrent major depressive disorder during 2years of maintenance treatment with venlafaxine extended release. Journal of affective disorders. 2010;126(3):420-9. Source: PsycINFO. [pmid: 20510459].
3396 Trivedi MH, Fava M, Wisniewski SR, et al. Medication augmentation after the failure of SSRIs for depression. N Engl J Med. 2006;354(12):1243-52. Source: PubMed. [pmid: 16554526].
3397 Trivedi MH, Hollander E, Nutt D, et al. Clinical evidence and potential neurobiological underpinnings of unresolved symptoms of depression. Journal of Clinical Psychiatry. 02. 01. 2008;69(Feb):246-58. Source: PsycINFO. [pmid: 18363453].
3398 Trivedi MH, Kurian BT, Grannemann BD. Clinical predictors in major depressive disorder. Primary Psychiatry. 2007;14(6):47-53. Source: EMBASE.
3399 Trivedi MH, Morris DW, Grannemann BD, et al. Symptom clusters as predictors of late response to antidepressant treatment. J Clin Psychiatry. Aug. 2005;66(8):1064-70. Source: PubMed. [pmid: 16086624].
3400 Trivedi MH, Pigotti TA, Perera P, et al. Effectiveness of low doses of paroxetine controlled release in the treatment of major depressive disorder. J Clin Psychiatry. Oct. 2004;65(10):1356-64. Source: PubMed. [pmid: 15491239].
3401 Trivedi MH, Rush AJ, Armitage R, et al. Effects of fluoxetine on the polysomnogram in outpatients with major depression. Neuropsychopharmacology. May. 1999;20(5):447-59. Source: PubMed. [pmid: 10192825].
3402 Trivedi MH, Rush AJ, Carmody TJ, et al. Do bupropion SR and sertraline differ in their effects on anxiety in depressed patients?. J Clin Psychiatry. Oct. 2001;62(10):776-81. Source: PubMed. [pmid: 11816866].
3403 Trivedi MH, Rush AJ, Gaynes BN, et al. Maximizing the adequacy of medication treatment in controlled trials and clinical practice: STAR(*)D measurement-based care. Neuropsychopharmacology. Dec. 2007;32(12):2479-89. Source: PubMed. [pmid: 17406651].
3404 Trivedi MH, Rush AJ, Pan JY, et al. Which depressed patients respond to nefazodone and when?. J Clin Psychiatry. Mar. 2001;62(3):158-63. Source: PubMed. [pmid: 11305700].
3405 Trivedi MH, Rush AJ, Wisniewski SR, et al. Evaluation of outcomes with citalopram for depression using measurement-based care in STAR*D: implications for clinical practice. Am J Psychiatry. Jan. 2006;163(1):28-40. Source: PubMed. [pmid: 16390886].
3406 Trivedi MH, Rush AJ, Wisniewski SR, et al. Factors associated with health-related quality of life among outpatients with major depressive disorder: A STAR*D report. Journal of Clinical Psychiatry. 2006;67(2):185-95. Source: Scopus. [pmid: 16566612].
3407 Trivedi MH, Thase ME, Osuntokun O, et al. An integrated analysis of olanzapine/fluoxetine combination in clinical trials of treatment-resistant depression. J Clin Psychiatry. Mar. 2009;70(3):387-96. Source: PubMed. [pmid: 19284928].
3408 Trivedi MH, Wan GJ, Mallick R, et al. Cost and effectiveness of venlafaxine extended-release and selective serotonin reuptake inhibitors in the acute phase of outpatient treatment for major depressive disorder. J Clin Psychopharmacol. Oct. 2004;24(5):497-506. Source: PubMed. [pmid: 15349005].
3409 Trkulja V. Is escitalopram really relevantly superior to citalopram in treatment of major depressive disorder? A meta-analysis of head-to-head randomized trials. Croat Med J. 2010;51(1):61-73. Source: PubMed. [pmid: 20162747].
3410 Trockel M, Burg M, Jaffe A, et al. Smoking behavior postmyocardial infarction among ENRICHD trial participants: cognitive behavior therapy intervention for depression and low perceived social support compared with care as usual. Psychosom Med. Oct. 2008;70(8):875-82. Source: PubMed. [pmid: 18842753].
3411 Tsai SJ, Hong CJ, Liou YJ, et al. Plasminogen activator inhibitor-1 gene is associated with major depression and antidepressant treatment response. Pharmacogenet Genomics. Oct. 2008;18(10):869-75. Source: PubMed. [pmid: 18794724].
3412 Tsai SJ, Hong CJ, Liou YJ, et al. Tryptophan hydroxylase 2 gene is associated with major depression and antidepressant treatment response. Progress in Neuro Psychopharmacology and Biological Psychiatry. 2009;33(4):637-41. Source: EMBASE. [pmid: 19272410].
3413 Tsai SJ, Hong CJ, Yu YW, et al. Association study of serotonin 1B receptor (A-161T) genetic polymorphism and suicidal behaviors and response to fluoxetine in major depressive disorder. Neuropsychobiology. 2004;50(3):235-8. Source: PubMed. [pmid: 15365222].
3414 Tsai SJ, Gau YTA, Hong CJ, et al. Sexually dimorphic effect of catechol-O-methyltransferase val158met polymorphism on clinical response to fluoxetine in major depressive patients. Journal of Affective Disorders. Feb. 2009. 2009;113(1):183-7. Source: PsycINFO. [pmid: 18533273].
3415 Tsutsui S, Okuse S, Sasaki D, et al. Clinical evaluation of sertraline hydrochloride, a selective serotonin reuptake inhibitor in the treatment of depression and depressive state: A double blind, group comparison study of sertraline hydrochloride vs. trazodone hydrochloride. Japanese Journal of Neuropsychopharmacology. 1997;19(6):549-68. Source: EMBASE.
3416 Tulen JH, Bruijn JA, de Man KJ, et al. Cardiovascular variability in major depressive disorder and effects of imipramine or mirtazapine (Org 3770). J Clin Psychopharmacol. Apr. 1996;16(2):135-45. Source: PubMed. [pmid: 8690829].
3417 Tulen JH, Volkers AC, van den Broek WW, et al. Sustained effects of phenelzine and tranylcypromine on orthostatic challenge in antidepressant-refractory depression. J Clin Psychopharmacol. Oct. 2006;26(5):542-4. Source: PubMed. [pmid: 16974207].
3418 Tural U, Onder E. Fluoxetine once every third day in the treatment of major depressive disorder. Eur Arch Psychiatry Clin Neurosci. Dec. 2003;253(6):307-12. Source: PubMed. [pmid: 14714120].
3419 Turkcapar MH, Orsel S, Iscan EN, et al. Moclobemide and sertraline in the treatment of melancholic and nonmelancholic major depression: A comparative study. Hum Psychopharmacol. 1998;13(1):21-7. Source: EMBASE.
3420 Turkington D, Smith PP, Grant J. Idiopathic genital pain and fluvoxamine. Br J Psychiatry. Jun. 1992;160:871. Source: PubMed. [pmid: 1617380].
3421 Turner E, Moreno SG, Sutton AJ. Ranking antidepressants. Lancet. May. 23. 2009;373(9677):1760. author reply 1-2. Source: PubMed. [pmid: 19465223].
3422 Turner R. Quality of life: experience with sertraline. Int Clin Psychopharmacol. Jun. Suppl 3. 1994;9:27-31. Source: PubMed. [pmid: 7963448].
3423 Turner-Stokes L, Hassan N, Pierce K, et al. Managing depression in brain injury rehabilitation: the use of an integrated care pathway and preliminary report of response to sertraline. Clin Rehabil. May. 2002;16(3):261-8. Source: PubMed. [pmid: 12017513].
3424 Tylee A, Beaumont G, Bowden MW, et al. A double-blind, randomized, 12-week comparison study of the safety and efficacy of venlafaxine and fluoxetine in moderate to severe major depression in general practice. Primary Care Psychiatry. 1997;3(1):51-8. Source: EMBASE.
3425 Tyra JM, Greenawald MH. TCAs or SSRIs as initial therapy for depression?. J Fam Pract. Nov. 1999;48(11):845-6. Source: PubMed. [pmid: 10907616].
3426 Tzanakaki M, Guazzelli M, Nimatoudis I, et al. Increased remission rates with venlafaxine compared with fluoxetine in hospitalized patients with major depression and melancholia. Int Clin Psychopharmacol. 2000;15(1):29-34. Source: PubMed. [pmid: 10836283].
3427 Tzeng DS, Chien CC, Lung FW, et al. MAOA gene polymorphisms and response to mirtazapine in major depression. Hum Psychopharmacol. 2009;24(4):293-300. Source: PubMed. [pmid: 19382113].
3428 Uchida H, Takeuchi H, Suzuki T, et al. Combined treatment with sulpiride and paroxetine for accelerated response in patients with major depressive disorder. J Clin Psychopharmacol. 2005;25(6):545-51. Source: PubMed. [pmid: 16282835].
3429 Uchida N, Chong MY, Tan CH, et al. International study on antidepressant prescription pattern at 20 teaching hospitals and major psychiatric institutions in East Asia: Analysis of 1898 cases from China, Japan, Korea, Singapore and Taiwan. Psychiatry Clin Neurosci. Oct. 2007;61(5):522-8. Source: PubMed. [pmid: 17875031].
3430 Ueda N, Yoshimura R, Shinkai K, et al. Higher plasma 5-hydroxyindoleacetic acid levels are associated with SSRI-induced nausea. Neuropsychobiology. 2003;48(1):31-4. Source: PubMed. [pmid: 12886038].
3431 Uehlinger C, Barrelet L, Touabi M, et al. Alopecia and mood stabilizers: two case reports. Eur Arch Psychiatry Clin Neurosci. 1992;242(2-3):85-8. Source: PubMed. [pmid: 1486112].
3432 Uguz F. Successful treatment of comorbid obsessive-compulsive disorder with aripiprazole in three patients with bipolar disorder. General Hospital Psychiatry. 2010;32(5):556-8. Source: EMBASE. [pmid: 20851277].
3433 Uher R, Farmer A, Henigsberg N, et al. Adverse reactions to antidepressants. Br J Psychiatry. Sep. 2009;195(3):202-10. Source: PubMed. [pmid: 19721108].
3434 Uher R, Maier W, Hauser J, et al. Differential efficacy of escitalopram and nortriptyline on dimensional measures of depression. Br J Psychiatry. 2009;194(3):252-9. Source: PubMed. [pmid: 19252156].
3435 Uher R, Muthen B, Souery D, et al. Trajectories of change in depression severity during treatment with antidepressants. Psychol Med. Aug. 2010;40(8):1367-77. Source: PubMed. [pmid: 19863842].
3436 US Food and Drug Administration. Electronic Orange Book. 2004. 2004(http://www.fda.gov/cder/ob/default.htm). Source: Handsearch.
3437 Usher RW, Beasley CM Jr, Bosomworth JC. Efficacy and safety of morning versus evening fluoxetine administration. J Clin Psychiatry. Mar. 1991;52(3):134-6. Source: PubMed. [pmid: 2005078].
3438 Ushiroyama T, Ikeda A, Ueki M. Evaluation of double-blind comparison of fluvoxamine and paroxetine in the treatment of depressed outpatients in menopause transition. J Med. 2004;35(1-6):151-62. Source: PubMed. [pmid: 18084873].
3439 Uzbekov MG, Misionzhnik EY, Maximova NM, et al. Biochemical profile in patients with anxious depression under the treatment with serotonergic antidepressants with different mechanisms of action. Human Psychopharmacology: Clinical and Experimental. Mar. 2006. 2006;21(2):109-15. Source: PsycINFO. [pmid: 16342231].
3440 Vaccaro M, Borgia F, Barbuzza O, et al. Photodistributed eruptive telangiectasia: an uncommon adverse drug reaction to venlafaxine. Br J Dermatol. Oct. 2007;157(4):822-4. Source: PubMed. [pmid: 17655739].
3441 Vaishnavi S, Connor K, Davidson JR. An abbreviated version of the Connor-Davidson Resilience Scale (CD-RISC), the CD-RISC2: psychometric properties and applications in psychopharmacological trials. Psychiatry Res. Aug. 30. 2007;152(2-3):293-7. Source: PubMed. [pmid: 17459488].
3442 Vakili K, Pillay SS, Lafer B, et al. Hippocampal volume in primary unipolar major depression: a magnetic resonance imaging study. Biol Psychiatry. Jun. 15. 2000;47(12):1087-90. Source: PubMed. [pmid: 10862809].
3443 Van Apeldoorn FJ, Timmerman ME, Mersch PPA, et al. A randomized trial of cognitive-behavioral therapy or selective serotonin reuptake inhibitor or both combined for panic disorder with or without agoraphobia: Treatment results through 1-year follow-up. Journal of Clinical Psychiatry. 2010;71(5):574-86. Source: EMBASE. [pmid: 20492852].
3444 van Baardewijk M, Vis PM, Einarson TR. Cost effectiveness of duloxetine compared with venlafaxine-XR in the treatment of major depressive disorder. Curr Med Res Opin. Aug. 2005;21(8):1271-9. Source: PubMed. [pmid: 16083537].
3445 van Balkom AJ, de Beurs E, Koele P, et al. Long-term benzodiazepine use is associated with smaller treatment gain in panic disorder with agoraphobia. J Nerv Ment Dis. Feb. 1996;184(2):133-5. Source: PubMed. [pmid: 8596113].
3446 Van Bemmel AL, Beersma DG, Van den Hoofdakker RH. Changes in EEG power density of non-REM sleep in depressed patients during treatment with trazodone. J Affect Disord. Oct. 9. 1995;35(1-2):11-9. Source: PubMed. [pmid: 8557883].
3447 van Bemmel AL, Havermans RG, van Diest R. Effects of trazodone on EEG sleep and clinical state in major depression. Psychopharmacology (Berl). 1992;107(4):569-74. Source: PubMed. [pmid: 1603901].
3448 van Calker D, Zobel I, Dykierek P, et al. Time course of response to antidepressants: predictive value of early improvement and effect of additional psychotherapy. J Affect Disord. Apr. 2009;114(1-3):243-53. Source: PubMed. [pmid: 18849079].
3449 Van de Merwe TJ, Silverstone T, Ankier SI. Electrophysiological and haemodynamic changes with trazodone, amitriptyline and placebo in depressed out-patients. Curr Med Res Opin. 1984;9(5):339-52. Source: PubMed. [pmid: 6529913].
3450 van de Merwe TJ, Silverstone T, Ankier SI, et al. A double-blind non-crossover placebo-controlled study between group comparison of trazodone and amitriptyline on cardiovascular function in major depressive disorder. Psychopathology. Suppl 2. 1984;17:64-76. Source: PubMed. [pmid: 6371879].
3451 van den Brink RH, van Melle JP, Honig A, et al. Treatment of depression after myocardial infarction and the effects on cardiac prognosis and quality of life: rationale and outline of the Myocardial INfarction and Depression-Intervention Trial (MIND-IT). Am Heart J. Aug. 2002;144(2):219-25. Source: PubMed. [pmid: 12177637].
3452 van den Broek WW, Birkenhager TK, Mulder PG, et al. A double-blind randomized study comparing imipramine with fluvoxamine in depressed inpatients. Psychopharmacology (Berl). Oct. 2004;175(4):481-6. Source: PubMed. [pmid: 15243735].
3453 Van Der Loos MLM, Mulder P, Hartong EGTM, et al. Efficacy and safety of two treatment algorithms in bipolar depression consisting of a combination of lithium, lamotrigine or placebo and paroxetine. Acta psychiatrica Scandinavica. 2010;122(3):246-54. Source: EMBASE. [pmid: 20136801].
3454 van Gurp G, Meterissian GB, Haiek LN, et al. St John's wort or sertraline? Randomized controlled trial in primary care. Can Fam Physician. May. 2002;48:905-12. Source: PubMed. [pmid: 12053635].
3455 van Heeringen K, Zivkov M. Pharmacological treatment of depression in cancer patients. A placebo-controlled study of mianserin. Br J Psychiatry. Oct. 1996;169(4):440-3. Source: PubMed. [pmid: 8894194].
3456 Van HL, Schoevers RA, Kool S, et al. Does early response predict outcome in psychotherapy and combined therapy for major depression?. J Affect Disord. Jan. 2008;105(1-3):261-5. Source: PubMed. [pmid: 17521743].
3457 Van Houdenhove B, Onghena P, Floris M, et al. An open study of sertraline in acute and continuation treatment of depressed out-patients. J Int Med Res. Nov-Dec. 1997;25(6):340-53. Source: PubMed. [pmid: 9427167].
3458 Van Hunsel F, Wauters A, Vandoolaeghe E, et al. Lower total serum protein, albumin, and beta- and gamma-globulin in major and treatment-resistant depression: effects of antidepressant treatments. Psychiatry Res. Dec. 20. 1996;65(3):159-69. Source: PubMed. [pmid: 9029664].
3459 van Marwijk HW, Ader H, de Haan M, et al. Primary care management of major depression in patients aged > or =55 years: outcome of a randomised clinical trial. Br J Gen Pract. Oct. 2008;58(555):680-6. I. II. discussion 7. Source: PubMed. [pmid: 18826778].
3460 Van Moffaert M, Bartholome F, Cosyns P, et al. A controlled comparison of sertraline and fluoxetine in acute and continuation treatment of major depression. Human Psychopharmacology. 1995;10:393-405. Source: Handsearch.
3461 van Moffaert M, de Wilde J, Vereecken A, et al. Mirtazapine is more effective than trazodone: a double-blind controlled study in hospitalized patients with major depression. Int Clin Psychopharmacol. Mar. 1995;10(1):3-9. Source: PubMed. [pmid: 7622801].
3462 Van Moffaert M, Pregaldien JL, Von Frenckell R, et al. A double-blind comparison of nefazodone and imipramine in the treatment of depressed patients. New Trends in Experimental & Clinical Psychiatry. 1994;10(2):85-7. Source: EMBASE.
3463 Van Wyck Fleet J, Manberg PJ, Miller LL, et al. Overview of clinically significant adverse reactions to bupropion. J Clin Psychiatry. May. 1983;44(5 Pt 2):191-6. Source: PubMed. [pmid: 6406456].
3464 van Zyl LT, Lesperance F, Frasure-Smith N, et al. Platelet and endothelial activity in comorbid major depression and coronary artery disease patients treated with citalopram: the Canadian Cardiac Randomized Evaluation of Antidepressant and Psychotherapy Efficacy Trial (CREATE) biomarker sub-study. J Thromb Thrombolysis. Jan. 2009;27(1):48-56. Source: PubMed. [pmid: 18188512].
3465 Vandel P, Haffen E, Nezelof S, et al. Clomipramine, fluoxetine and CYP2D6 metabolic capacity in depressed patients. Hum Psychopharmacol. Jul. 2004;19(5):293-8. Source: PubMed. [pmid: 15252821].
3466 Vandel S, Bertschy G, Baumann P, et al. Fluvoxamine and fluoxetine: interaction studies with amitriptyline, clomipramine and neuroleptics in phenotyped patients. Pharmacol Res. Jun. 1995;31(6):347-53. Source: PubMed. [pmid: 8685072].
3467 Vandel S, Bonin B, Bechtel P, et al. Maprotiline versus fluvoxamine: Comparison between their actions on hypothalamic-pituitary-thyroid axis. <ORIGINAL>. MAPROTILINE VERSUS FLUVOXAMINE: COMPARAISON ENTRE LEURS ACTIONS SUR L'AXE HYPOTHALAMO-HYPOPHYSO-THYROIDIEN. Encephale. 1997;23(1):48-55. Source: EMBASE. [pmid: 9172968].
3468 Vanderburg DG, Batzar E, Fogel I, et al. A pooled analysis of suicidality in double-blind, placebo-controlled studies of sertraline in adults. J Clin Psychiatry. 2009;70(5):674-83. Source: PubMed. [pmid: 19552866].
3469 Vanderkooy JD, Kennedy SH, Bagby RM. Antidepressant side effects in depression patients treated in a naturalistic setting: a study of bupropion, moclobemide, paroxetine, sertraline, and venlafaxine. Can J Psychiatry. Mar. 2002;47(2):174-80. Source: PubMed. [pmid: 11926080].
3470 Vanderwerker LC, Laff RE, Kadan-Lottick NS, et al. Psychiatric disorders and mental health service use among caregivers of advanced cancer patients. Journal of Clinical Oncology. 2005;23(28):6899-907. Source: EMBASE. [pmid: 16129849].
3471 Vandoolaeghe E, van Hunsel F, Nuyten D, et al. Auditory event related potentials in major depression: prolonged P300 latency and increased P200 amplitude. J Affect Disord. Mar. 1998;48(2-3):105-13. Source: PubMed. [pmid: 9543199].
3472 Vanelle JM, Attar-Levy D, Poirier MF, et al. Controlled efficacy study of fluoxetine in dysthymia. Br J Psychiatry. Apr. 1997;170:345-50. Source: PubMed. [pmid: 9246253].
3473 Vanelle JM, Poirier MF, Benkelfat C, et al. Diagnostic and therapeutic value of testing stimulation of thyroid-stimulating hormone by thyrotropin-releasing hormone in 100 depressed patients. Acta Psychiatr Scand. Feb. 1990;81(2):156-61. Source: PubMed. [pmid: 2109497].
3474 Vanelli M, Coca-Perraillon M. Role of patient experience in antidepressant adherence: a retrospective data analysis. Clin Ther. 2008;30(9):1737-45. Source: PubMed. [pmid: 18840380].
3475 Vanoli A, Lane CJ, Harrison C, et al. Adequacy of venlafaxine dose prescribing in major depression and hospital resources implications. J Psychopharmacol. Jun. 2008;22(4):434-40. Source: PubMed. [pmid: 18635723].
3476 Varghese S, Kumar A, Sagar R. Ultradian pattern bipolar affective disorder and chronic antidepressant use. [1]. Journal of Postgraduate Medicine. 2007;53(3). Source: EMBASE.
3477 Varia I, Venkataraman S, Hellegers C, et al. Effect of mirtazapine orally disintegrating tablets on health-related quality of life in elderly depressed patients with comorbid medical disorders: a pilot study. Psychopharmacol Bull. 2007;40(1):47-56. Source: PubMed. [pmid: 17285095].
3478 Varner RV, Ruiz P, Small DR. Black and white patients response to antidepressant treatment for major depression. Psychiatr Q. Summer. 1998;69(2):117-25. Source: PubMed. [pmid: 9627929].
3479 Vartiainen H, Leinonen E. Double-blind study of mirtazapine and placebo in hospitalized patients with major depression. Eur Neuropsychopharmacol. Jun. 1994;4(2):145-50. Source: PubMed. [pmid: 7919944].
3480 Vasa RA, Carlino AR, Pine DS. Pharmacotherapy of Depressed Children and Adolescents: Current Issues and Potential Directions. Biological Psychiatry. Jun. 2006. 2006;59(11):1021-8. Source: PsycINFO. [pmid: 16406250].
3481 Vasudev K, Macritchie K, Geddes J, et al. Topiramate for acute affective episodes in bipolar disorder. Cochrane Database of Systematic Reviews. 2006;(1). Source: The Cochrane Library.
3482 Vaughan DA. Interaction of fluoxetine with tricyclic antidepressants. Am J Psychiatry. Nov. 1988;145(11):1478. Source: PubMed. [pmid: 3263809].
3483 Vazquez MJ, Carretero Quevedo B. Pneumonitis related to venlafaxine. Psychosomatics. Jan-Feb. 2008;49(1):84-5. Source: PubMed. [pmid: 18212183].
3484 Venditti LN, Arcelus A, Birnbaum H, et al. The impact of antidepressant use on social functioning: reboxetine versus fluoxetine. Int Clin Psychopharmacol. Sep. 2000;15(5):279-89. Source: PubMed. [pmid: 10993130].
3485 Ventura D, Armstrong EP, Skrepnek GH, et al. Escitalopram versus sertraline in the treatment of major depressive disorder: a randomized clinical trial. Curr Med Res Opin. 2007;23(2):245-50. Source: PubMed. [pmid: 17288677].
3486 Vera M, Perez-Pedrogo C, Huertas SE, et al. Collaborative care for depressed patients with chronic medical conditions: a randomized trial in Puerto Rico. Psychiatr Serv. Feb. 2010;61(2):144-50. Source: PubMed. [pmid: 20123819].
3487 Vercoulen JH, Swanink CM, Zitman FG, et al. Randomised, double-blind, placebo-controlled study of fluoxetine in chronic fatigue syndrome. Lancet. Mar. 30. 1996;347(9005):858-61. Source: PubMed. [pmid: 8622391].
3488 Verger P, Saliba B, Rouillon F, et al. Determinants of coprescription of anxiolytics with antidepressants in general practice. Canadian Journal of Psychiatry. 2008;53(2):94-103. Source: EMBASE.
3489 Verhoeven WM, Veendrik-Meekes MJ, Jacobs GA, et al. Citalopram in mentally retarded patients with depression: a long-term clinical investigation. Eur Psychiatry. Mar. 2001;16(2):104-8. Source: PubMed. [pmid: 11311174].
3490 Vermeiden M, van den Broek WW, Mulder PG, et al. Influence of gender and menopausal status on antidepressant treatment response in depressed inpatients. J Psychopharmacol. Apr. 2010;24(4):497-502. Source: PubMed. [pmid: 19423613].
3491 Versiani M, Moreno R, Ramakers-van Moorsel CJ, et al. Comparison of the effects of mirtazapine and fluoxetine in severely depressed patients. CNS Drugs. 2005;19(2):137-46. Source: PubMed. [pmid: 15697327].
3492 Versiani M, Ontiveros A, Mazzotti G, et al. Fluoxetine versus amitriptyline in the treatment of major depression with associated anxiety (anxious depression): a double-blind comparison. Int Clin Psychopharmacol. Nov. 1999;14(6):321-7. Source: PubMed. [pmid: 10565798].
3493 Ververs T, Kaasenbrood H, Visser G, et al. Prevalence and patterns of antidepressant drug use during pregnancy. Eur J Clin Pharmacol. Oct. 2006;62(10):863-70. Source: PubMed. [pmid: 16896784].
3494 Vestergaard P, Rejnmark L, Mosekilde L. Selective serotonin reuptake inhibitors and other antidepressants and risk of fracture. Calcified Tissue International. 2008;82(2):92-101. Source: PubMed. [pmid: 18219438].
3495 Vezmar S, Miljkovic B, Vucicevic K, et al. Pharmacokinetics and efficacy of fluvoxamine and amitriptyline in depression. J Pharmacol Sci. 2009;110(1):98-104. Source: PubMed. [pmid: 19444001].
3496 Victor TA, Furey ML, Fromm SJ, et al. Relationship between amygdala responses to masked faces and mood state and treatment in major depressive disorder. Arch Gen Psychiatry. Nov. 2010;67(11):1128-38. Source: PubMed. [pmid: 21041614].
3497 Vignatelli L, D'Alessandro R, Candelise L. Antidepressant drugs for narcolepsy. Cochrane Database of Systematic Reviews. 2008;(1). Source: The Cochrane Library.
3498 Viikki M, Anttila S, Kampman O, et al. Vascular endothelial growth factor (VEGF) polymorphism is associated with treatment resistant depression. Neuroscience Letters. 2010;477(3):105-8. Source: EMBASE. [pmid: 20417690].
3499 Viikki M, Kampman O, Illi A, et al. TPH1 218A/C polymorphism is associated with major depressive disorder and its treatment response. Neuroscience Letters. 2010;468(1):80-4. Source: EMBASE. [pmid: 19874868].
3500 Vilaplana J, Botey E, Lecha M, et al. Photosensitivity induced by paroxetine. Contact Dermatitis. Aug. 2002;47(2):118-9. Source: PubMed. [pmid: 12455545].
3501 Vincent A, Douville M, Baruch P. Serum sickness induced by fluoxetine. Am J Psychiatry. Nov. 1991;148(11):1602-3. Source: PubMed. [pmid: 1928481].
3502 Vis PM, van Baardewijk M, Einarson TR. Duloxetine and venlafaxine-XR in the treatment of major depressive disorder: a meta-analysis of randomized clinical trials. Ann Pharmacother. 2005;39(11):1798-807. Source: PubMed. [pmid: 16189284].
3503 Voils CI, Steffens DC, Flint EP, et al. Social support and locus of control as predictors of adherence to antidepressant medication in an elderly population. American Journal of Geriatric Psychiatry. 2005;13(2):157-65. Source: EMBASE. [pmid: 15703325].
3504 Volkers AC, Tulen JH, van den Broek WW, et al. Effects of imipramine, fluvoxamine and depressive mood on autonomic cardiac functioning in major depressive disorder. Pharmacopsychiatry. Jan. 2004;37(1):18-25. Source: PubMed. [pmid: 14750044].
3505 Volkers AC, Tulen JHM, Van Den Broek WW, et al. 24-Hour motor activity after treatment with imipramine or fluvoxamine in major depressive disorder. European Neuropsychopharmacology. 2002;12(4):273-8. Source: EMBASE. [pmid: 12126865].
3506 Volpe FM. An 8-week, open-label trial of duloxetine for comorbid major depressive disorder and chronic headache. J Clin Psychiatry. Sep. 2008;69(9):1449-54. Source: PubMed. [pmid: 19193344].
3507 von Ammon Cavanaugh S. Drug-drug interactions of fluoxetine with tricyclics. Psychosomatics. Summer. 1990;31(3):273-6. Source: PubMed. [pmid: 2388981].
3508 von Bardeleben U, Holsboer F, Gerken A, et al. Mood elevating effect of fluoxetine in a diagnostically homogeneous inpatient population with major depressive disorder. Int Clin Psychopharmacol. Jan. Suppl 1. 1989;4:31-5. Source: PubMed. [pmid: 2644337].
3509 von Knorring L, Akerblad AC, Bengtsson F, et al. Cost of depression: effect of adherence and treatment response. Eur Psychiatry. Sep. 2006;21(6):349-54. Source: PubMed. [pmid: 16777385].
3510 Voon V, Lang AE. Antidepressant treatment outcomes of psychogenic movement disorder. J Clin Psychiatry. Dec. 2005;66(12):1529-34. Source: PubMed. [pmid: 16401153].
3511 Vuorilehto MS, Melartin TK, Isometsä ET. Suicidal behaviour among primary-care patients with depressive disorders. Psychological Medicine. 2006;36(2):203-10. Source: Scopus. [pmid: 16420714].
3512 Wachtel LE, Griffin M, Reti IM. Electroconvulsive therapy in a man with autism experiencing severe depression, catatonia, and self-injury. Journal of ECT. 2010;26(1):70-3. Source: EMBASE. [pmid: 19483640].
3513 Wada K, Sasaki T, Jitsuiki H, et al. Manic/hypomanic switch during acute antidepressant treatment for unipolar depression. Journal of Clinical Psychopharmacology. 2006;26(5):512-5. Source: EMBASE. [pmid: 16974195].
3514 Wade A, Aitken CA. Efficacy, tolerability and effect on sleep of morning and evening doses of paroxetine in depressed patients. Br J Clin Res. 1993;4:105-11. Source: EMBASE.
3515 Wade A, Crawford GM, Angus M, et al. A randomized, double-blind, 24-week study comparing the efficacy and tolerability of mirtazapine and paroxetine in depressed patients in primary care. Int Clin Psychopharmacol. May. 2003;18(3):133-41. Source: PubMed. [pmid: 12702891].
3516 Wade A, Despiegel N, Heldbo Reines E. Escitalopram in the long-term treatment of major depressive disorder. Ann Clin Psychiatry. Apr-Jun. 2006;18(2):83-9. Source: PubMed. [pmid: 16754413].
3517 Wade A, Gembert K, Florea I. A comparative study of the efficacy of acute and continuation treatment with escitalopram versus duloxetine in patients with major depressive disorder. Curr Med Res Opin. 2007;23(7):1605-14. Source: PubMed. [pmid: 17559755].
3518 Wade A, Michael Lemming O, Bang Hedegaard K. Escitalopram 10 mg/day is effective and well tolerated in a placebo-controlled study in depression in primary care. Int Clin Psychopharmacol. May. 2002;17(3):95-102. Source: PubMed. [pmid: 11981349].
3519 Wade AG, Fernandez JL, Francois C, et al. Escitalopram and duloxetine in major depressive disorder: a pharmacoeconomic comparison using UK cost data. Pharmacoeconomics. 2008;26(11):969-81. Source: PubMed. [pmid: 18850765].
3520 Wade AG, Saragoussi D, Despiegel N, et al. Healthcare expenditure in severely depressed patients treated with escitalopram, generic SSRIs or venlafaxine in the UK. Current Medical Research and Opinion. 2010;26(5):1161-70. Source: EMBASE. [pmid: 20297951].
3521 Wade AG, Schlaepfer TE, Andersen HF, et al. Clinical milestones predict symptom remission over 6-month and choice of treatment of patients with major depressive disorder (MDD). J Psychiatr Res. Feb. 2009;43(5):568-75. Source: PubMed. [pmid: 18954875].
3522 Wade AG, Toumi I, Hemels MEH. A Pharmacoeconomic Evaluation of Escitalopram Versus Citalopram in the Treatment of Severe Depression in the United Kingdom. Clinical Therapeutics: The International Peer-Reviewed Journal of Drug Therapy. Apr. 2005. 2005;27(4):486-96. Source: PsycINFO.
3523 Wagner G, Koch K, Schachtzabel C, et al. Differential effects of serotonergic and noradrenergic antidepressants on brain activity during a cognitive control task and neurofunctional prediction of treatment outcome in patients with depression. J Psychiatry Neurosci. Jul. 2010;35(4):247-57. Source: PubMed. [pmid: 20598238].
3524 Wagner GJ, Maguen S, Rabkin JG. Ethnic differences in response to fluoxetine in a controlled trial with depressed HIV-positive patients. Psychiatr Serv. Feb. 1998;49(2):239-40. Source: PubMed. [pmid: 9575014].
3525 Wagner GJ, Rabkin JG, Rabkin R. A comparative analysis of standard and alternative antidepressants in the treatment of human immunodeficiency virus patients. Compr Psychiatry. Nov-Dec. 1996;37(6):402-8. Source: PubMed. [pmid: 8932964].
3526 Wagner KD, Ambrosini P, Rynn M, et al. Efficacy of sertraline in the treatment of children and adolescents with major depressive disorder: two randomized controlled trials. Jama. Aug. 27. 2003;290(8):1033-41. Source: PubMed. [pmid: 12941675].
3527 Wagner W, Plekkenpol B, Gray TE, et al. Review of fluvoxamine safety database. Drugs. Suppl 2. 1992;43:48-53. discussion -4. Source: PubMed. [pmid: 1378374].
3528 Wagstaff AJ, Cheer SM, Matheson AJ, et al. Spotlight on paroxetine in psychiatric disorders in adults. CNS Drugs. 2002;16(6):425-34. Source: PubMed. [pmid: 12027788].
3529 Wagstaff AJ, Goa KL. Once-weekly fluoxetine. Drugs. 2001;61(15):2221-8. discussion 9-30. Source: PubMed. [pmid: 11772132].
3530 Waintraub L, Septien L, Azoulay P. Efficacy and safety of tianeptine in major depression: evidence from a 3-month controlled clinical trial versus paroxetine. CNS Drugs. 2002;16(1):65-75. Source: PubMed. [pmid: 11772119].
3531 Wakabayashi Y, Uchida S, Funato H, et al. State-dependent changes in the expression levels of NCAM-140 and L1 in the peripheral blood cells of bipolar disorders, but not in the major depressive disorders. Progress in Neuro Psychopharmacology and Biological Psychiatry. 2008;32(5):1199-205. Source: EMBASE. [pmid: 18430502].
3532 Wakelin JS. Fluvoxamine in the treatment of the older depressed patient; double-blind, placebo-controlled data. Int Clin Psychopharmacol. Jul. 1986;1(3):221-30. Source: PubMed. [pmid: 3104446].
3533 Wakeno M, Kato M, Okugawa G, et al. The alpha 2A-adrenergic receptor gene polymorphism modifies antidepressant responses to milnacipran. J Clin Psychopharmacol. Oct. 2008;28(5):518-24. Source: PubMed. [pmid: 18794646].
3534 Walczak DD, Apter JT, Halikas JA, et al. The oral dose-effect relationship for fluvoxamine: a fixed-dose comparison against placebo in depressed outpatients. Ann Clin Psychiatry. Sep. 1996;8(3):139-51. Source: PubMed. [pmid: 8899132].
3535 Wålinder J, Prochazka J, Odén A, et al. Mirtazapine naturalistic depression study (in Sweden)--MINDS(S): Clinical efficacy and safety. Human Psychopharmacology: Clinical and Experimental. Apr. 2006. 2006;21(3):151-8. Source: PsycINFO. [pmid: 16444795].
3536 Walker EM, Rodriguez AI, Kohn B, et al. Acupuncture versus venlafaxine for the management of vasomotor symptoms in patients with hormone receptor-positive breast cancer: A randomized controlled trial. Journal of Clinical Oncology. 2010;28(4):634-40. Source: EMBASE. [pmid: 20038728].
3537 Walker JB, Klein RM, Yee SL. Type II error and antidepressants. J Clin Psychiatry. May. 2001;62(5):373-5. Source: PubMed. [pmid: 11411822].
3538 Walker PW, Cole JO, Gardner EA, et al. Improvement in fluoxetine-associated sexual dysfunction in patients switched to bupropion. J Clin Psychiatry. Dec. 1993;54(12):459-65. Source: PubMed. [pmid: 8276736].
3539 Waller DA, Gullion CM, Petty F, et al. Tridimensional Personality Questionnaire and serotonin in bulimia nervosa. Psychiatry Res. Jul. 1993;48(1):9-15. Source: PubMed. [pmid: 8416020].
3540 Walley T, Pirmohamed M, Proudlove C, et al. Interaction of metoprolol and fluoxetine. Lancet. Apr. 10. 1993;341(8850):967-8. Source: PubMed. [pmid: 8096308].
3541 Walsh ND, Williams SC, Brammer MJ, et al. A longitudinal functional magnetic resonance imaging study of verbal working memory in depression after antidepressant therapy. Biol Psychiatry. Dec. 1. 2007;62(11):1236-43. Source: PubMed. [pmid: 17601497].
3542 Walters G, Reynolds CF 3rd, Mulsant BH, et al. Continuation and maintenance pharmacotherapy in geriatric depression: an open-trial comparison of paroxetine and nortriptyline in patients older than 70 years. J Clin Psychiatry. Suppl 20. 1999;60:21-5. Source: PubMed. [pmid: 10513854].
3543 Wamboldt MZ, Kalin NH, Weiler SJ. Consistent reversal of abnormal DSTs after different antidepressant therapies in a patient with dementia. Am J Psychiatry. Jan. 1985;142(1):100-3. Source: PubMed. [pmid: 3966566].
3544 Wan DD, Kundhur D, Solomons K, et al. Mirtazapine for treatment-resistant depression: a preliminary report. J Psychiatry Neurosci. Jan. 2003;28(1):55-9. Source: PubMed. [pmid: 12587851].
3545 Wan GJ, Crown WH, Berndt ER, et al. Treatment costs of venlafaxine and selective serotonin-reuptake inhibitors for depression and anxiety. Manag Care Interface. Jun. 2002;15(6):24-30. Source: PubMed. [pmid: 12087603].
3546 Wang TS, Chou YH, Shiah IS. Combined treatment of olanzapine and mirtazapine in anorexia nervosa associated with major depression. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 2006;30(2):306-9. Source: PubMed. [pmid: 16314020].
3547 Warden D, Rush AJ, Trivedi M, et al. Quality improvement methods as applied to a multicenter effectiveness trial--STAR*D. Contemp Clin Trials. Feb. 2005;26(1):95-112. Source: PubMed. [pmid: 15837455].
3548 Warden D, Rush AJ, Trivedi MH, et al. The STAR*D Project results: a comprehensive review of findings. Curr Psychiatry Rep. Dec. 2007;9(6):449-59. Source: PubMed. [pmid: 18221624].
3549 Warden D, Rush AJ, Wisniewski SR, et al. What predicts attrition in second step medication treatments for depression?: a STAR*D Report. Int J Neuropsychopharmacol. 2009;12(4):459-73. Source: PubMed. [pmid: 18611293].
3550 Warden D, Trivedi MH, Wisniewski SR, et al. Predictors of attrition during initial (citalopram) treatment for depression: a STAR*D report. Am J Psychiatry. 2007;164(8):1189-97. Source: PubMed. [pmid: 17671281].
3551 Warden D, Trivedi MH, Wisniewski SR, et al. Early adverse events and attrition in selective serotonin reuptake inhibitor treatment: A suicide assessment methodology study report. Journal of Clinical Psychopharmacology. 2010;30(3):259-66. Source: PsycINFO. [pmid: 20473060].
3552 Warnock JK, Bundren JC, Morris DW. Depressive symptoms associated with gonadotropin-releasing hormone agonists. Depress Anxiety. 1998;7(4):171-7. Source: PubMed. [pmid: 9706454].
3553 Warrington SJ. Clinical implications of the pharmacology of sertraline. Int Clin Psychopharmacol. Dec. Suppl 2. 1991;6:11-21. Source: PubMed. [pmid: 1806626].
3554 Wasilewski BW. Homeopathic remedies as placebo alternatives--verification on the example of treatment of menopause-related vegetative and emotional disturbances. Sci Eng Ethics. Jan. 2004;10(1):179-88. Source: PubMed. [pmid: 14986784].
3555 Waslick B. Psychopharmacology interventions for pediatric anxiety disorders: A research update. Child and Adolescent Psychiatric Clinics of North America. 2006;15(1):51-71. Source: Scopus. [pmid: 16321725].
3556 Watanabe N, Barbui C, Churchill R, et al. Mirtazapine versus other anti-depressive agents for depression (Protocol). Cochrane Database of Systematic Reviews. 2006;(3). Source: Scopus.
3557 Watanabe N, Omori IM, Nakagawa A, et al. Mirtazapine versus other antidepressants in the acute-phase treatment of adults with major depression: Systematic review and meta-analysis. Journal of Clinical Psychiatry. 2008;69(9):1404-15. Source: PsycINFO. [pmid: 19193341].
3558 Watanabe N, Omori IM, Nakagawa A, et al. Safety reporting and adverse-event profile of mirtazapine described in randomized controlled trials in comparison with other classes of antidepressants in the acute-phase treatment of adults with depression: systematic review and meta-analysis. CNS Drugs. 2010;24(1):35-53. Source: PubMed. [pmid: 20030418].
3559 Waters CH. Fluoxetine and selegiline--lack of significant interaction. Can J Neurol Sci. Aug. 1994;21(3):259-61. Source: PubMed. [pmid: 8000982].
3560 Waugh J, Goa KL. Escitalopram : a review of its use in the management of major depressive and anxiety disorders. CNS Drugs. 2003;17(5):343-62. Source: PubMed. [pmid: 12665392].
3561 Weber E, Stack J, Pollock BG, et al. Weight change in older depressed patients during acute pharmacotherapy with paroxetine and nortriptyline: a double-blind randomized trial. Am J Geriatr Psychiatry. Summer. 2000;8(3):245-50. Source: PubMed. [pmid: 10910424].
3562 Weber-Hamann B, Gilles M, Lederbogen F, et al. Improved insulin sensitivity in 80 nondiabetic patients with MDD after clinical remission in a double-blind, randomized trial of amitriptyline and paroxetine. J Clin Psychiatry. Dec. 2006;67(12):1856-61. Source: PubMed. [pmid: 17194262].
3563 Weber-Hamann B, Gilles M, Schilling C, et al. Improved insulin sensitivity in 51 nondiabetic depressed inpatients remitting during antidepressive treatment with mirtazapine and venlafaxine. J Clin Psychopharmacol. Oct. 2008;28(5):581-4. Source: PubMed. [pmid: 18794665].
3564 Wehmeier PM, Kluge M, Maras A, et al. Fluoxetine versus trimipramine in the treatment of depression in geriatric patients. Pharmacopsychiatry. Jan. 2005;38(1):13-6. Source: PubMed. [pmid: 15706460].
3565 Weigmann H, Gerek S, Zeisig A, et al. Fluvoxamine but not sertraline inhibits the metabolism of olanzapine: evidence from a therapeutic drug monitoring service. Ther Drug Monit. Aug. 2001;23(4):410-3. Source: PubMed. [pmid: 11477325].
3566 Weihs KL, Houser TL, Batey SR, et al. Continuation phase treatment with bupropion SR effectively decreases the risk for relapse of depression. Biol Psychiatry. May. 1. 2002;51(9):753-61. Source: PubMed. [pmid: 11983189].
3567 Weihs KL, Settle EC Jr, Batey SR, et al. Bupropion sustained release versus paroxetine for the treatment of depression in the elderly. J Clin Psychiatry. Mar. 2000;61(3):196-202. Source: PubMed. [pmid: 10817105].
3568 Weilburg JB, Rosenbaum JF, Biederman J, et al. Fluoxetine added to non-MAOI antidepressants converts nonresponders to responders: a preliminary report. J Clin Psychiatry. Dec. 1989;50(12):447-9. Source: PubMed. [pmid: 2600061].
3569 Weiner AL, Tilden FF Jr, McKay CA Jr. Serotonin syndrome: case report and review of the literature. Conn Med. Nov. 1997;61(11):717-21. Source: PubMed. [pmid: 9419960].
3570 Weinmann S, Becker T, Koesters M. Re-evaluation of the efficacy and tolerability of venlafaxine vs SSRI: meta-analysis (Structured abstract). Psychopharmacology. 2008;(4):511-20. Source: Handsearch. [pmid: 17955213].
3571 Weintraub D. Nortriptyline toxicity secondary to interaction with bupropion sustained-release. Depress Anxiety. 2001;13(1):50-2. Source: PubMed. [pmid: 11233461].
3572 Weintraub D, Rosenberg PB, Drye LT, et al. Sertraline for the treatment of depression in alzheimer disease: Week-24 outcomes. American Journal of Geriatric Psychiatry. 2010;18(4):332-40. Source: EMBASE. [pmid: 20220589].
3573 Weintraub D, Streim JE, Datto CJ, et al. Effect of increasing the dose and duration of sertraline trial in the treatment of depressed nursing home residents. J Geriatr Psychiatry Neurol. Jun. 2003;16(2):109-11. Source: PubMed. [pmid: 12801161].
3574 Weintraub D, Taraborelli D, Morales KH, et al. Escitalopram for major depression in Parkinson's disease: an open-label, flexible-dosage study. J Neuropsychiatry Clin Neurosci. Summer. 2006;18(3):377-83. Source: PubMed. [pmid: 16963587].
3575 Weisler RH, Johnston JA, Lineberry CG, et al. Comparison of bupropion and trazodone for the treatment of major depression. J Clin Psychopharmacol. Jun. 1994;14(3):170-9. Source: PubMed. [pmid: 8027413].
3576 Weller EB, Tucker S, Weller RA. The selective serotonin reuptake inhibitors controversy in the treatment of depression in children. Curr Psychiatry Rep. Apr. 2005;7(2):87-90. Source: PubMed. [pmid: 15802083].
3577 Wellington K, Perry CM. Venlafaxine extended-release: a review of its use in the management of major depression. CNS Drugs. 2001;15(8):643-69. Source: PubMed. [pmid: 11524036].
3578 Welton NJ, Caldwell DM, Adamopoulos E, et al. Mixed treatment comparison meta-analysis of complex interventions: psychological interventions in coronary heart disease. Am J Epidemiol. May. 1. 2009;169(9):1158-65. Source: PubMed. [pmid: 19258485].
3579 Wenger TL, Stern WC. The cardiovascular profile of bupropion. J Clin Psychiatry. May. 1983;44(5 Pt 2):176-82. Source: PubMed. [pmid: 6406453].
3580 Wernicke JF, Dunlop SR, Dornseif BE, et al. Low-dose fluoxetine therapy for depression. Psychopharmacol Bull. 1988;24(1):183-8. Source: PubMed. [pmid: 3290940].
3581 Wernicke JF, Dunlop SR, Dornseif BE, et al. Fixed-dose fluoxetine therapy for depression. Psychopharmacol Bull. 1987;23(1):164-8. Source: PubMed. [pmid: 3496625].
3582 Wernicke JF, Gahimer J, Yalcin I, et al. Safety and adverse event profile of duloxetine. Expert Opin Drug Saf. Nov. 2005;4(6):987-93. Source: PubMed. [pmid: 16255658].
3583 Wernicke JF, Sayler ME, Koke SC, et al. Fluoxetine and concomitant centrally acting medication use during clinical trials of depression: the absence of an effect related to agitation and suicidal behavior. Depress Anxiety. 1997;6(1):31-9. Source: PubMed. [pmid: 9394873].
3584 Wheadon DE, Rampey AHJ, Thompson VL, et al. Lack of association between fluoxetine and suicidality in bulimia nervosa. J Clin Psychiatry. 1992;53(7):235-41. Source: EMBASE. [pmid: 1639742].
3585 Wheatley D. Trazodone in depression. Int Pharmacopsychiatry. 1980;15(4):240-6. Source: PubMed. [pmid: 7021449].
3586 Wheatley D. Trazodone: alternative dose regimens and sleep. Pharmatherapeutica. 1984;3(9):607-12. Source: PubMed. [pmid: 6374681].
3587 Wheatley D. St John's Wort in depression: The patient's dilemma. Primary Care & Community Psychiatry. 2006. 2006;11(3):137-42. Source: PsycINFO.
3588 Wheatley DP, van Moffaert M, Timmerman L, et al. Mirtazapine: efficacy and tolerability in comparison with fluoxetine in patients with moderate to severe major depressive disorder. Mirtazapine-Fluoxetine Study Group. J Clin Psychiatry. Jun. 1998;59(6):306-12. Source: PubMed. [pmid: 9671343].
3589 White K, Wykoff W, Tynes LL, et al. Fluvoxamine in the treatment of tricyclic-resistant depression. Psychiatr J Univ Ott. Sep. 1990;15(3):156-8. Source: PubMed. [pmid: 2123039].
3590 Whitehead AM, Ashford JJ. Fluvoxamine in the treatment of depressive illness. A series of double-blind hospital based comparative studies carried out in the UK. Br J Clin Pract. Spring. 1992;46(1):21-3. Source: PubMed. [pmid: 1419548].
3591 Whitmyer VG, Dunner DL, Kornstein SG, et al. A comparison of initial duloxetine dosing strategies in patients with major depressive disorder. J Clin Psychiatry. Dec. 2007;68(12):1921-30. Source: PubMed. [pmid: 18162024].
3592 Whittington CJ, Kendall T, Fonagy P, et al. Selective serotonin reuptake inhibitors in childhood depression: systematic review of published versus unpublished data. Lancet. Apr. 24. 2004;363(9418):1341-5. Source: PubMed. [pmid: 15110490].
3593 Whyte EM, Basinski J, Farhi P, et al. Geriatric depression treatment in nonresponders to selective serotonin reuptake inhibitors. J Clin Psychiatry. Dec. 2004;65(12):1634-41. Source: PubMed. [pmid: 15641868].
3594 Whyte EM, Romkes M, Mulsant BH, et al. CYP2D6 genotype and venlafaxine-XR concentrations in depressed elderly. Int J Geriatr Psychiatry. Jun. 2006;21(6):542-9. Source: PubMed. [pmid: 16642541].
3595 Whyte IM, Dawson AH, Buckley NA. Relative toxicity of venlafaxine and selective serotonin reuptake inhibitors in overdose compared to tricyclic antidepressants. Qjm. May. 2003;96(5):369-74. Source: PubMed. [pmid: 12702786].
3596 Wiethoff K, Bauer M, Baghai TC, et al. Prevalence and treatment outcome in anxious versus nonanxious depression: Results from the German algorithm project. Journal of Clinical Psychiatry. 2010;71(8):1047-54. Source: EMBASE. [pmid: 20673545].
3597 Wiggins A, Oakley Browne M, Bearsley-Smith C, et al. Depressive disorders among adolescents managed in a child and adolescent mental health service. Australasian Psychiatry. 2010;18(2):134-41. Source: EMBASE. [pmid: 20059307].
3598 Wijkstra J, Burger H, van den Broek WW, et al. Treatment of unipolar psychotic depression: a randomized, double-blind study comparing imipramine, venlafaxine, and venlafaxine plus quetiapine. Acta Psychiatr Scand. 2010;121(3):190-200. Source: PubMed. [pmid: 19694628].
3599 Wijkstra J, Burger H, van den Broek WW, et al. Long-term response to successful acute pharmacological treatment of psychotic depression. J Affect Disord. Jun. 2010;123(1-3):238-42. Source: PubMed. [pmid: 19880189].
3600 Willetts J, Lippa A, Beer B. Clinical development of citalopram. J Clin Psychopharmacol. Oct. 1999;19(5 Suppl 1):36S-46S. Source: PubMed. [pmid: 10507507].
3601 Williams JW Jr, Barrett J, Oxman T, et al. Treatment of dysthymia and minor depression in primary care: A randomized controlled trial in older adults. Jama. Sep. 27. 2000;284(12):1519-26. Source: PubMed. [pmid: 11000645].
3602 Williams JW, Mulrow CD, Chiquette E, et al. A systematic review of newer pharmacotherapies for depression in adults: evidence report summary. Annals Internal Medicine. 2000. May. 2. 2000;132(9):743-56. Source: Handsearch.
3603 Williams R, Edwards RA, Newburn GM, et al. A double-blind comparison of moclobemide and fluoxetine in the treatment of depressive disorders. Int Clin Psychopharmacol. Jan. 1993;7(3-4):155-8. Source: PubMed. [pmid: 8468437].
3604 Williams TI, Salkovskis PM, Forrester L, et al. A randomised controlled trial of cognitive behavioural treatment for obsessive compulsive disorder in children and adolescents. European Child and Adolescent Psychiatry. 2010;19(5):449-56. Source: EMBASE. [pmid: 19921305].
3605 Willner P, Hale AS, Argyropoulos S. Dopaminergic mechanism of antidepressant action in depressed patients. J Affect Disord. May. 2005;86(1):37-45. Source: PubMed. [pmid: 15820269].
3606 Wilson KC, Mottram PG, Ashworth L, et al. Older community residents with depression: long-term treatment with sertraline. Randomised, double-blind, placebo-controlled study. Br J Psychiatry. Jun. 2003;182:492-7. Source: PubMed. [pmid: 12777339].
3607 Winokur A, Baker RA, Simmons J, et al. Comparative sleep improving effects of mirtazapine vs SSRIs in depressed patients: A meta-analysis of individual patient data. 8th World Congress of the World Federation of Societies of Biological Psychiatry. Vienna, Austria. World J Biol Psychiatry. 2005:S1366-7. Source: Scopus.
3608 Winokur A, DeMartinis NA 3rd, McNally DP, et al. Comparative effects of mirtazapine and fluoxetine on sleep physiology measures in patients with major depression and insomnia. J Clin Psychiatry. Oct. 2003;64(10):1224-9. Source: PubMed. [pmid: 14658972].
3609 Wirshing WC, Van Putten T, Rosenberg J, et al. Fluoxetine, akathisia, and suicidality: is there a causal connection?. Arch Gen Psychiatry. Jul. 1992;49(7):580-1. Source: PubMed. [pmid: 1627050].
3610 Wirz-Justice A, Schroder CM, Gasio PF, et al. The circadian rest-activity cycle in korsakoff psychosis. American Journal of Geriatric Psychiatry. 2010;18(1):33-41. Source: EMBASE. [pmid: 19910886].
3611 Wirz-Justice A, van der Velde P, Bucher A, et al. Comparison of light treatment with citalopram in winter depression: a longitudinal single case study. Int Clin Psychopharmacol. Nov. 1992;7(2):109-16. Source: PubMed. [pmid: 1487622].
3612 Wise TN, Perahia DGS, Pangallo BA, et al. Effects of the antidepressant duloxetine on body weight: Analyses of 10 clinical studies. Primary Care Companion to the Journal of Clinical Psychiatry. 2006;8(5):269-78. Source: EMBASE.
3613 Wise TN, Wiltse CG, Iosifescu DV, et al. The safety and tolerability of duloxetine in depressed elderly patients with and without medical comorbidity. Int J Clin Pract. 2007;61(8):1283-93. Source: PubMed. [pmid: 17590215].
3614 Wisner KL, Hanusa BH, Perel JM, et al. Postpartum depression: a randomized trial of sertraline versus nortriptyline. J Clin Psychopharmacol. Aug. 2006;26(4):353-60. Source: PubMed. [pmid: 16855451].
3615 Wisner KL, Perel JM, Peindl KS, et al. Prevention of postpartum depression: a pilot randomized clinical trial. Am J Psychiatry. Jul. 2004;161(7):1290-2. Source: PubMed. [pmid: 15229064].
3616 Wisniewski SR, Chen CC, Kim E, et al. Global benefit-risk analysis of adjunctive aripiprazole in the treatment of patients with major depressive disorder. Pharmacoepidemiol Drug Saf. Oct. 2009;18(10):965-72. Source: PubMed. [pmid: 19662630].
3617 Wisniewski SR, Eng H, Meloro L, et al. Web-based communications and management of a multi-center clinical trial: the Sequenced Treatment Alternatives to Relieve Depression (STAR*D) project. Clin Trials. 2004;1(4):387-98. Source: PubMed. [pmid: 16279277].
3618 Wisniewski SR, Fava M, Trivedi MH, et al. Acceptability of second-step treatments to depressed outpatients: a STAR*D report. Am J Psychiatry. May. 2007;164(5):753-60. Source: PubMed. [pmid: 17475734].
3619 Wisniewski SR, Leon AC, Otto MW, et al. Prevention of missing data in clinical research studies. Biol Psychiatry. Jun. 1. 2006;59(11):997-1000. Source: PubMed. [pmid: 16566901].
3620 Wisniewski SR, Rush AJ, Balasubramani GK, et al. Self-rated global measure of the frequency, intensity, and burden of side effects. J Psychiatr Pract. Mar. 2006;12(2):71-9. Source: PubMed. [pmid: 16728903].
3621 Wisniewski SR, Rush AJ, Bryan C, et al. Comparison of quality of life measures in a depressed population. J Nerv Ment Dis. Mar. 2007;195(3):219-25. Source: PubMed. [pmid: 17468681].
3622 Wisniewski SR, Rush AJ, Nierenberg AA, et al. Can phase III trial results of antidepressant medications be generalized to clinical practice? A STAR*D report. Am J Psychiatry. May. 2009;166(5):599-607. Source: PubMed. [pmid: 19339358].
3623 Wisniewski SR, Stegman D, Trivedi M, et al. Methods of testing feasibility for sequenced treatment alternatives to relieve depression (STAR*D). J Psychiatr Res. May-Jun. 2004;38(3):241-8. Source: PubMed. [pmid: 15003429].
3624 Wohlreich MM, Mallinckrodt CH, Prakash A, et al. Duloxetine for the treatment of major depressive disorder: safety and tolerability associated with dose escalation. Depress Anxiety. 2007;24(1):41-52. Source: PubMed. [pmid: 16845641].
3625 Wohlreich MM, Mallinckrodt CH, Watkin JG, et al. Duloxetine for the long-term treatment of major depressive disorder in patients aged 65 and older: an open-label study. BMC Geriatr. Dec. 7. 2004;4:11. Source: PubMed. [pmid: 15585058].
3626 Wohlreich MM, Mallinckrodt CH, Watkin JG, et al. Immediate switching of antidepressant therapy: results from a clinical trial of duloxetine. Ann Clin Psychiatry. Oct-Dec. 2005;17(4):259-68. Source: PubMed. [pmid: 16402760].
3627 Wohlreich MM, Martinez JM, Mallinckrodt CH, et al. An open-label study of duloxetine for the treatment of major depressive disorder: comparison of switching versus initiating treatment approaches. J Clin Psychopharmacol. Dec. 2005;25(6):552-60. Source: PubMed. [pmid: 16282837].
3628 Wohlreich MM, Sullivan MD, Mallinckrodt CH, et al. Duloxetine for the treatment of recurrent major depressive disorder in elderly patients: treatment outcomes in patients with comorbid arthritis. Psychosomatics. 2009;50(4):402-12. Source: PubMed. [pmid: 19687181].
3629 Wolf R, Dykierek P, Gattaz WF, et al. Differential effects of trimipramine and fluoxetine on sleep in geriatric depression. Pharmacopsychiatry. Mar. 2001;34(2):60-5. Source: PubMed. [pmid: 11302565].
3630 Wolfersdorf M, Barg T, Konig F, et al. Paroxetine as antidepressant in combined antidepressant-neuroleptic therapy in delusional depression: observation of clinical use. Pharmacopsychiatry. Mar. 1995;28(2):56-60. Source: PubMed. [pmid: 7624387].
3631 Wolfersdorf M, Barg T, Konig F, et al. Paroxetine in the treatment of inpatients with non-delusional endogenous or neurotic depression. Schweiz Arch Neurol Psychiatr. 1994;145(6):15-8. Source: PubMed.
3632 Wong ML, Whelan F, Deloukas P, et al. Phosphodiesterase genes are associated with susceptibility to major depression and antidepressant treatment response. Proc Natl Acad Sci U S A. Oct. 10. 2006;103(41):15124-9. Source: PubMed. [pmid: 17008408].
3633 Wood A. Pharmacotherapy of bulimia nervosa--experience with fluoxetine. Int Clin Psychopharmacol. Winter. 1993;8(4):295-9. Source: PubMed. [pmid: 8277150].
3634 Woolley SB, Fredman L, Goethe JW, et al. Hospital patients' perceptions during treatment and early discontinuation of serotonin selective reuptake inhibitor antidepressants. Journal of Clinical Psychopharmacology. 2010;30(6):716-9. Source: PsycINFO. [pmid: 21105288].
3635 Workman EA, Short DD. Bupropion-induced carbohydrate craving and weight gain. Am J Psychiatry. Oct. 1992;149(10):1407-8. Source: PubMed. [pmid: 1530081].
3636 Wroblewski BA, Guidos A, Leary J, et al. Control of depression with fluoxetine and antiseizure medication in a brain-injured patient. Am J Psychiatry. Feb. 1992;149(2):273. Source: PubMed. [pmid: 1734754].
3637 Wroolie TE, Williams KE, Keller J, et al. Mood and neuropsychological changes in women with midlife depression treated with escitalopram. J Clin Psychopharmacol. Aug. 2006;26(4):361-6. Source: PubMed. [pmid: 16855452].
3638 Wu E, Greenberg P, Yang E, et al. Comparison of treatment persistence, hospital utilization and costs among major depressive disorder geriatric patients treated with escitalopram versus other SSRI/SNRI antidepressants. Curr Med Res Opin. Oct. 2008;24(10):2805-13. Source: PubMed. [pmid: 18755054].
3639 Wu E, Greenberg PE, Yang E, et al. Comparison of escitalopram versus citalopram for the treatment of major depressive disorder in a geriatric population. Curr Med Res Opin. Sep. 2008;24(9):2587-95. Source: PubMed. [pmid: 18674407].
3640 Wu EQ, Ben-Hamadi R, Yu AP, et al. Healthcare utilization and costs incurred by patients with major depression after being switched from escitalopram to another SSRI for non-medical reasons. Journal of Medical Economics. 2010;13(2):314-23. Source: EMBASE. [pmid: 20504111].
3641 Wu WH, Huo SJ, Cheng CY, et al. Association study of the 5-HT(6) receptor polymorphism (C267T) and symptomatology and antidepressant response in major depressive disorders. Neuropsychobiology. 2001;44(4):172-5. Source: PubMed. [pmid: 11702016].
3642 Wu YS, Chen YC, Lu RB. Venlafaxine vs. paroxetine in the acute phase of treatment for major depressive disorder among Han Chinese population in Taiwan. J Clin Pharm Ther. Aug. 2007;32(4):353-63. Source: PubMed. [pmid: 17635337].
3643 Yalug I, Kirmizi-Alsan E, Tufan AE. Adult onset paper pica in the context of anorexia nervosa with major depressive disorder and a history of childhood geophagia: A case report. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Aug. 2007. 2007;31(6):1341-2. Source: PsycINFO. [pmid: 17590254].
3644 Yamada K, Yagi G, Kanba S. Effectiveness of herbal medicine (Rokumigan and Hachimijiogan) for fatigue or loss of energy in patients with partial remitted major depressive disorder. Psychiatry and Clinical Neurosciences. 2005;59(5):610-2. Source: EMBASE. [pmid: 16194267].
3645 Yang H, Chuzi S, Sinicropi-Yao L, et al. Type of residual symptom and risk of relapse during the continuation/maintenance phase treatment of major depressive disorder with the selective serotonin reuptake inhibitor fluoxetine. Eur Arch Psychiatry Clin Neurosci. Mar. 2010;260(2):145-50. Source: PubMed. [pmid: 19572158].
3646 Yang H, Sinicropi-Yao L, Chuzi S, et al. Residual sleep disturbance and risk of relapse during the continuation/maintenance phase treatment of major depressive disorder with the selective serotonin reuptake inhibitor fluoxetine. Annals of General Psychiatry. 2010;9. Source: PsycINFO.
3647 Yang LP, Plosker GL. Desvenlafaxine extended release. CNS Drugs. 2008;22(12):1061-9. Source: PubMed. [pmid: 18998743].
3648 Yasui-Furukori N, Kaneko S. Digitalis intoxication induced by paroxetine co-administration. Lancet. Mar. 4. 2006;367(9512):788. Source: PubMed. [pmid: 16517279].
3649 Yates WR, Mitchell J, John Rush A, et al. Clinical Features of Depression in Outpatients With and Without Co-Occurring General Medical Conditions in STAR*D: Confirmatory Analysis. Prim Care Companion J Clin Psychiatry. 2007;9(1):7-15. Source: PubMed. [pmid: 17599162].
3650 Yates WR, Mitchell J, Rush AJ, et al. Clinical features of depressed outpatients with and without co-occurring general medical conditions in STAR*D. Gen Hosp Psychiatry. Nov-Dec. 2004;26(6):421-9. Source: PubMed. [pmid: 15567207].
3651 Yazicioglu B, Akkaya C, Sarandol A, et al. A comparison of the efficacy and tolerability of reboxetine and sertraline versus venlafaxine in major depressive disorder: a randomized, open-labeled clinical trial. Prog Neuropsychopharmacol Biol Psychiatry. Sep. 30. 2006;30(7):1271-6. Source: PubMed. [pmid: 16820257].
3652 Yen CF, Lee Y, Tang TC, et al. Predictive value of self-stigma, insight, and perceived adverse effects of medication for the clinical outcomes in patients with depressive disorders. Journal of Nervous and Mental Disease. 2009;197(3):172-7. Source: EMBASE. [pmid: 19282683].
3653 Yeragani VK, Pesce V, Jayaraman A, et al. Major depression with ischemic heart disease: effects of paroxetine and nortriptyline on long-term heart rate variability measures. Biol Psychiatry. Sep. 1. 2002;52(5):418-29. Source: PubMed. [pmid: 12242058].
3654 Yeragani VK, Roose S, Mallavarapu M, et al. Major depression with ischemic heart disease: effects of paroxetine and nortriptyline on measures of nonlinearity and chaos of heart rate. Neuropsychobiology. 2002;46(3):125-35. Source: PubMed. [pmid: 12422059].
3655 Yevtushenko VY, Belous AI, Yevtushenko YG, et al. Efficacy and tolerability of escitalopram versus citalopram in major depressive disorder: a 6-week, multicenter, prospective, randomized, double-blind, active-controlled study in adult outpatients. Clin Ther. 2007;29(11):2319-32. Source: PubMed. [pmid: 18158074].
3656 Yildiz A, Mantar A, Simsek S, et al. Combination of pharmacotherapy with electroconvulsive therapy in prevention of depressive relapse: a pilot controlled trial. J ECT. Jun. 2010;26(2):104-10. Source: PubMed. [pmid: 19935091].
3657 Yohannes AM, Connolly MJ, Baldwin RC. A feasibility study of antidepressant drug therapy in depressed elderly patients with chronic obstructive pulmonary disease. Int J Geriatr Psychiatry. May. 2001;16(5):451-4. Source: PubMed. [pmid: 11376459].
3658 Yonkers KA, Halbreich U, Freeman E, et al. Sertraline in the treatment of premenstrual dysphoric disorder. Psychopharmacol Bull. 1996;32(1):41-6. Source: PubMed. [pmid: 8927673].
3659 Yonkers KA, Lin H, Howell HB, et al. Pharmacologic treatment of postpartum women with new-onset major depressive disorder: a randomized controlled trial with paroxetine. J Clin Psychiatry. 2008;69(4):659-65. Source: PubMed. [pmid: 18363420].
3660 Yoon SJ, Pae CU, Kim DJ, et al. Mirtazapine for patients with alcohol dependence and comorbid depressive disorders: a multicentre, open label study. Prog Neuropsychopharmacol Biol Psychiatry. Sep. 30. 2006;30(7):1196-201. Source: PubMed. [pmid: 16624467].
3661 Yoshida K, Sugawara Y, Higuchi H. Dramatic remission of treatment-resistant depression after the cessation of tricyclic antidepressants. Pharmacopsychiatry. May. 2006;39(3):114. Source: PubMed. [pmid: 16721702].
3662 Yoshimura R, Mitoma M, Sugita A, et al. Effects of paroxetine or milnacipran on serum brain-derived neurotrophic factor in depressed patients. Prog Neuropsychopharmacol Biol Psychiatry. Jun. 30. 2007;31(5):1034-7. Source: PubMed. [pmid: 17459550].
3663 Yoshimura R, Ueda N, Nakamura J, et al. Interaction between fluvoxamine and cotinine or caffeine. Neuropsychobiology. 2002;45(1):32-5. Source: PubMed. [pmid: 11803239].
3664 Yoshimura R, Umene-Nakano W, Ueda N, et al. No difference in adherence to paroxetine between depressed patients with early remission and those with late remission based on monitoring of plasma paroxetine concentrations. Hum Psychopharmacol. Aug. 2010;25(6):487-90. Source: PubMed. [pmid: 20725911].
3665 Yoshimura R, Umene-Nakano W, Ueda N, et al. Addition of risperidone to sertraline improves sertraline-resistant refractory depression without influencing plasma concentrations of sertraline and desmethylsertraline. Hum Psychopharmacol. Dec. 2008;23(8):707-13. Source: PubMed. [pmid: 18803170].
3666 Young AH, McElroy SL, Bauer M, et al. A double-blind, placebo-controlled study of quetiapine and lithium monotherapy in adults in the acute phase of bipolar depression (EMBOLDEN I). Journal of Clinical Psychiatry. 2010;71(2):150-62. Source: EMBASE. [pmid: 20122369].
3667 Young EA, Altemus M, Lopez JF, et al. HPA axis activation in major depression and response to fluoxetine: a pilot study. Psychoneuroendocrinology. Oct. 2004;29(9):1198-204. Source: PubMed. [pmid: 15219644].
3668 Young EA, Kornstein SG, Harvey AT, et al. Influences of hormone-based contraception on depressive symptoms in premenopausal women with major depression. Psychoneuroendocrinology. Aug. 2007;32(7):843-53. Source: PubMed. [pmid: 17629629].
3669 Young EA, Kornstein SG, Marcus SM, et al. Sex differences in response to citalopram: a STAR*D report. J Psychiatr Res. 2009;43(5):503-11. Source: PubMed. [pmid: 18752809].
3670 Young HN, Bell RA, Epstein RM, et al. Types of information physicians provide when prescribing antidepressants. Journal of General Internal Medicine. 2006;21(11):1172-7. Source: EMBASE. [pmid: 17026727].
3671 Young JP, Coleman A, Lader MH. A controlled comparison of fluoxetine and amitriptyline in depressed out-patients. Br J Psychiatry. Sep. 1987;151:337-40. Source: PubMed. [pmid: 3322468].
3672 Young SA, Hurt PH, Benedek DM, et al. Treatment of premenstrual dysphoric disorder with sertraline during the luteal phase: a randomized, double-blind, placebo-controlled crossover trial. J Clin Psychiatry. Feb. 1998;59(2):76-80. Source: PubMed. [pmid: 9501889].
3673 Yu YW, Tsai SJ, Hong CJ, et al. Association study of a monoamine oxidase a gene promoter polymorphism with major depressive disorder and antidepressant response. Neuropsychopharmacology. Sep. 2005;30(9):1719-23. Source: PubMed. [pmid: 15956990].
3674 Yu YW, Tsai SJ, Liou YJ, et al. Association study of two serotonin 1A receptor gene polymorphisms and fluoxetine treatment response in Chinese major depressive disorders. Eur Neuropsychopharmacol. Oct. 2006;16(7):498-503. Source: PubMed. [pmid: 16458487].
3675 Yu-Isenberg KS, Fontes CL, Wan GJ, et al. Acute and continuation treatment adequacy with venlafaxine extended release compared with fluoxetine. Pharmacotherapy. Jan. 2004;24(1):33-40. Source: PubMed. [pmid: 14740786].
3676 Yuksel FV, Tuzer V, Goka E. Escitalopram intoxication. Eur Psychiatry. Jan. 2005;20(1):82. Source: PubMed. [pmid: 15642453].
3677 Zaharia MD, Ravindran AV, Griffiths J, et al. Lymphocyte proliferation among major depressive and dysthymic patients with typical or atypical features. J Affect Disord. Apr. 2000;58(1):1-10. Source: PubMed. [pmid: 10760553].
3678 Zajecka J, Dunner DL, Gelenberg AJ, et al. Sexual function and satisfaction in the treatment of chronic major depression with nefazodone, psychotherapy, and their combination. J Clin Psychiatry. Aug. 2002;63(8):709-16. Source: PubMed. [pmid: 12197452].
3679 Zajecka J, Fawcett J, Amsterdam J, et al. Safety of abrupt discontinuation of fluoxetine: a randomized, placebo-controlled study. J Clin Psychopharmacol. Jun. 1998;18(3):193-7. Source: PubMed. [pmid: 9617977].
3680 Zajecka J, Mitchell S, Fawcett J. Treatment-emergent changes in sexual function with selective serotonin reuptake inhibitors as measured with the Rush Sexual Inventory. Psychopharmacol Bull. 1997;33(4):755-60. Source: PubMed. [pmid: 9493488].
3681 Zajecka JM. The effect of nefazodone on comorbid anxiety symptoms associated with depression: experience in family practice and psychiatric outpatient settings. J Clin Psychiatry. Suppl 2. 1996;57:10-4. Source: PubMed. [pmid: 8626357].
3682 Zajecka JM, Jeffries H, Fawcett J. The efficacy of fluoxetine combined with a heterocyclic antidepressant in treatment-resistant depression: a retrospective analysis. J Clin Psychiatry. Aug. 1995;56(8):338-43. Source: PubMed. [pmid: 7635848].
3683 Zanardi R, Artigas F, Franchini L, et al. How long should pindolol be associated with paroxetine to improve the antidepressant response?. J Clin Psychopharmacol. Dec. 1997;17(6):446-50. Source: PubMed. [pmid: 9408806].
3684 Zanardi R, Benedetti F, Di Bella D, et al. Efficacy of paroxetine in depression is influenced by a functional polymorphism within the promoter of the serotonin transporter gene. J Clin Psychopharmacol. Feb. 2000;20(1):105-7. Source: PubMed. [pmid: 10653220].
3685 Zanardi R, Cusin C, Rossini D, et al. Comparison of response to fluvoxamine in nondemented elderly compared to younger patients affected by major depression. J Clin Psychopharmacol. Dec. 2003;23(6):535-9. Source: PubMed. [pmid: 14624182].
3686 Zanardi R, Franchini L, Gasperini M, et al. Double-blind controlled trial of sertraline versus paroxetine in the treatment of delusional depression. Am J Psychiatry. Dec. 1996;153(12):1631-3. Source: PubMed. [pmid: 8942464].
3687 Zanardi R, Franchini L, Serretti A, et al. Venlafaxine versus fluvoxamine in the treatment of delusional depression: a pilot double-blind controlled study. J Clin Psychiatry. Jan. 2000;61(1):26-9. Source: PubMed. [pmid: 10695642].
3688 Zanardi R, Serretti A, Rossini D, et al. Factors affecting fluvoxamine antidepressant activity: influence of pindolol and 5-HTTLPR in delusional and nondelusional depression. Biol Psychiatry. Sep. 1. 2001;50(5):323-30. Source: PubMed. [pmid: 11543734].
3689 Zanarini MC, Frankenburg FR, Parachini EA. A preliminary, randomized trial of fluoxetine, olanzapine, and the olanzapine-fluoxetine combination in women with borderline personality disorder. J Clin Psychiatry. Jul. 2004;65(7):903-7. Source: PubMed. [pmid: 15291677].
3690 Zaninelli R, Bauer M, Jobert M, et al. Changes in quantitatively assessed tremor during treatment of major depression with lithium augmented by paroxetine or amitriptyline. J Clin Psychopharmacol. Apr. 2001;21(2):190-8. Source: PubMed. [pmid: 11270916].
3691 Zaninelli R, Meister W. The treatment of depression with paroxetine in psychiatric practice in Germany: the possibilities and current limitations of drug monitoring. Pharmacopsychiatry. Jan. 1997;30(1 Suppl):9-20. Source: PubMed. [pmid: 9035223].
3692 Zarate CA, Kando JC, Tohen M, et al. Does intolerance or lack of response with fluoxetine predict the same will happen with sertraline?. J Clin Psychiatry. Feb. 1996;57(2):67-71. Source: PubMed. [pmid: 8591971].
3693 Zetin M, Hoepner CT. Relevance of exclusion criteria in antidepressant clinical trials: A replication study. Journal of Clinical Psychopharmacology. 2007;27(3):295-301. Source: EMBASE. [pmid: 17502778].
3694 Zhalkovsky B, Walker D, Bourgeois JA. Seizure activity and enzyme elevations after venlafaxine overdose. J Clin Psychopharmacol. Dec. 1997;17(6):490-1. Source: PubMed. [pmid: 9408815].
3695 Zhang G, Ruan J. Treatment of mental depression due to liver-qi stagnancy with herbal decoction and by magnetic therapy at the acupoints--a report of 45 cases. J Tradit Chin Med. Mar. 2004;24(1):20-1. Source: PubMed. [pmid: 15119163].
3696 Zhang WJ, Yang XB, Zhong BL. Combination of Acupuncture and Fluoxetine for Depression: A Randomized, Double-Blind, Sham-Controlled Trial. Journal of Alternative and Complementary Medicine: Research on Paradigm, Practice, and Policy (USA). 2009:15837. Source: Handsearch.
3697 Zhang Y, Chow V, Vitry AI, et al. Antidepressant use and depressive symptomatology among older people from the Australian longitudinal study of ageing. International Psychogeriatrics. 2010;22(3):437-44. Source: PsycINFO. [pmid: 20105349].
3698 Zheng H, Zhang L, Li L, et al. High-frequency rTMS treatment increases left prefrontal myo-inositol in young patients with treatment-resistant depression. Progress in Neuro-Psychopharmacology and Biological Psychiatry. 2010;34(7):1189-95. Source: EMBASE. [pmid: 20600472].
3699 Zhu H, Halaris A, Madakasira S, et al. Effect of bupropion on immunodensity of putative imidazoline receptors on platelets of depressed patients. J Psychiatr Res. Jul-Aug. 1999;33(4):323-33. Source: PubMed. [pmid: 10404470].
3700 Ziere G, Dieleman JP, Van Der Cammen TJM, et al. Selective serotonin reuptake inhibiting antidepressants are associated with an increased risk of nonvertebral fractures. Journal of clinical psychopharmacology. 2008;28(4):411-7. Source: PubMed. [pmid: 18626268].
3701 Ziffra MS, Gilmer WS. STAR*D : Lessons learned for primary care. New York, NY, ETATS-UNIS. MBL Communications. 2007. Source: Handsearch.
3702 Zimmerman M, Breen RB, Posternak MA. An open-label study of citalopram in the treatment of pathological gambling. J Clin Psychiatry. Jan. 2002;63(1):44-8. Source: PubMed. [pmid: 11838625].
3703 Zimmerman M, Posternak MA, Attiullah N, et al. Why isn't bupropion the most frequently prescribed antidepressant?. J Clin Psychiatry. May. 2005;66(5):603-10. Source: PubMed. [pmid: 15889947].
3704 Zisook S, Ganadjian K, Moutier C, et al. Sequenced Treatment Alternatives to Relieve Depression (STAR*D): lessons learned. J Clin Psychiatry. Jul. 2008;69(7):1184-5. Source: PubMed. [pmid: 18687018].
3705 Zisook S, Kasckow JW, Lanouette NM, et al. Augmentation with citalopram for suicidal ideation in middle-aged and older outpatients with schizophrenia and schizoaffective disorder who have subthreshold depressive symptoms: A randomized controlled trial. Journal of Clinical Psychiatry. 2010;71(7):915-22. Source: EMBASE. [pmid: 20361918].
3706 Zisook S, Lesser I, Stewart JW, et al. Effect of age at onset on the course of major depressive disorder. Am J Psychiatry. Oct. 2007;164(10):1539-46. Source: PubMed. [pmid: 17898345].
3707 Zisook S, Montross L, Kasckow J, et al. Subsyndromal depressive symptoms in middle-aged and older persons with schizophrenia. Am J Geriatr Psychiatry. Dec. 2007;15(12):1005-14. Source: PubMed. [pmid: 18056819].
3708 Zisook S, Peterkin J, Goggin KJ, et al. Treatment of major depression in HIV-seropositive men. HIV Neurobehavioral Research Center Group. J Clin Psychiatry. May. 1998;59(5):217-24. Source: PubMed. [pmid: 9632030].
3709 Zisook S, Rush AJ, Albala A, et al. Factors that differentiate early vs. later onset of major depression disorder. Psychiatry Res. Dec. 15. 2004;129(2):127-40. Source: PubMed. [pmid: 15590040].
3710 Zisook S, Rush AJ, Lesser I, et al. Preadult onset vs. adult onset of major depressive disorder: a replication study. Acta Psychiatr Scand. Mar. 2007;115(3):196-205. Source: PubMed. [pmid: 17302619].
3711 Zisook S, Shuchter SR, Pedrelli P, et al. Bupropion sustained release for bereavement: results of an open trial. J Clin Psychiatry. Apr. 2001;62(4):227-30. Source: PubMed. [pmid: 11379835].
3712 Zitman FG, Couvee JE. Chronic benzodiazepine use in general practice patients with depression: an evaluation of controlled treatment and taper-off: report on behalf of the Dutch Chronic Benzodiazepine Working Group. Br J Psychiatry. Apr. 2001;178:317-24. Source: PubMed. [pmid: 11282810].
3713 Zivkov M. Org 3770 versus amitriptyline: A 6-week randomized double-blind multicentre trial in hospitalized depressed patients. Hum Psychopharmacol. 1995;10(3):173-80. Source: EMBASE.
3714 Zobel A, Schuhmacher A, Jessen F, et al. DNA sequence variants of the FKBP5 gene are associated with unipolar depression. International Journal of Neuropsychopharmacology. 2010;13(5):649-60. Source: EMBASE. [pmid: 20047716].
3715 Zohar J, Keegstra H, Barrelet L. Fluvoxamine as effective as clomipramine against symptoms of severe depression: results from a multicentre, double-blind study. Hum Psychopharmacol. Mar. 2003;18(2):113-9. Source: PubMed. [pmid: 12590404].
3716 Zou YF, Wang Y, Liu P, et al. Association of BDNF Val66Met polymorphism with both baseline HRQOL scores and improvement in HRQOL scores in Chinese major depressive patients treated with fluoxetine. Hum Psychopharmacol. Mar. 2010;25(2):145-52. Source: PubMed. [pmid: 20196181].
3717 Zou YF, Wang Y, Liu P, et al. Association of brain-derived neurotrophic factor genetic Val66Met polymorphism with severity of depression, efficacy of fluoxetine and its side effects in Chinese major depressive patients. Neuropsychobiology. 2010;61(2):71-8. Source: PubMed. [pmid: 20016225].
3718 Zourkova A, Hadasova E. Relationship between CYP 2D6 metabolic status and sexual dysfunction in paroxetine treatment. J Sex Marital Ther. Oct-Dec. 2002;28(5):451-61. Source: PubMed. [pmid: 12378847].
3719 Zubieta JK, Pande AC, Demitrack MA. Two year follow-up of atypical depression. J Psychiatr Res. Jan-Feb. 1999;33(1):23-9. Source: PubMed. [pmid: 10094236].
3720 Zung WW. Review of placebo-controlled trials with bupropion. J Clin Psychiatry. May. 1983;44(5 Pt 2):104-14. Source: PubMed. [pmid: 6406436].
3721 Zupancic M, Guilleminault C. Agomelatine: A preliminary review of a new antidepressant. CNS Drugs. 2006;20(12):981-92. Source: Scopus. [pmid: 17140278].
3722 Zygmont M, Prigerson HG, Houck PR, et al. A post hoc comparison of paroxetine and nortriptyline for symptoms of traumatic grief. J Clin Psychiatry. May. 1998;59(5):241-5. Source: PubMed. [pmid: 9632035].