# Studies Included in Mixed-Treatment Comparisons and Meta-analyses

Studies Included in Mixed Treatment Comparisons and Meta-Analyses (based on change in HAM-D)

Trial | Drug | Dosage | Number randomized | Number of responders^a^ | Quality Rating
Alves et al., 1999^1^ | Fluoxetine | 20-40 mg/d | 47 | 35 | Fair
Alves et al., 1999^1^ | Venlafaxine | 75-150 mg/d | 40 | 35 | Fair
Benkert et al., 2000^2^ | Paroxetine | 15-45 mg/d | 136 | 66 | Fair
Benkert et al., 2000^2^ | Mirtazapine | 20-40 mg/d | 139 | 74 | Fair
Bennie et al., 1995^3^ | Fluoxetine | 20-40 mg/d | 144 | 63 | Fair
Bennie et al., 1995^3^ | Sertraline | 50-100 mg/d | 142 | 73 | Fair
Bielski et al., 2004^4^ | Venlafaxine | 225 mg/d | 100 | 47 | Fair
Bielski et al., 2004^4^ | Escitalopram | 20 mg/d | 98 | 59 | Fair
Blumenthal et al., 2007^5,b^ | Placebo | NA | 49 | 16 | Fair
Blumenthal et al., 2007^5,b^ | Sertraline | 50-200 mg/d | 49 | 19 | Fair
Boulenger et al., 2006^6,b^ | Escitalopram | 10-20 mg/d | 232 | 175 | Fair
Boulenger et al., 2006^6,b^ | Paroxetine | 20-40 mg/d | 227 | 146 | Fair
Boyer et al., 2008^7^ | Placebo | NA | 161 | 40 | Fair
Boyer et al., 2008^7^ | Desvenlafaxine | 50 mg/d, 100 mg/d | 324^c^ | 205^c^ | Fair
Brannan et al., 2005^8^ | Placebo | NA | 141 | 54 | Fair
Brannan et al., 2005^8^ | Duloxetine | 60 mg/d | 141 | 55 | Fair
Chouinard et al., 1999^9^ | Fluoxetine | 20-80 mg/d | 101 | 67 | Fair
Chouinard et al., 1999^9^ | Paroxetine | 20-50 mg/d | 102 | 67 | Fair
Cohn et al., 1996^10^ | Placebo | NA | 42 | 15 | Fair
Cohn et al., 1996^10^ | Nefazodone | 200-600 mg/d | 39 | 25 | Fair
Coleman et al., 1999^11^ | Placebo | NA | 124 | 66 | Fair
Coleman et al., 1999^11^ | Bupropion | 150-400 mg/d | 122 | 78 | Fair
Coleman et al., 1999^11^ | Sertraline | 50-200 mg/d | 118 | 66 | Fair
Coleman et al., 2001^12^ | Placebo | NA | 152 | 73 | Fair
Coleman et al., 2001^12^ | Bupropion | 150-400 mg/d | 150 | 76 | Fair
Coleman et al., 2001^12^ | Fluoxetine | 50-200 mg/d | 154 | 83 | Fair
Croft et al., 1999^13^ | Placebo | NA | 121 | 55 | Fair
Croft et al., 1999^13^ | Bupropion | 150-400 mg/d | 120 | 77 | Fair
Croft et al., 1999^13^ | Sertraline | 50-200 mg/d | 119 | 79 | Fair
De Nayer et al., 2002^14^ | Fluoxetine | 20 mg/d | 73 | 34 | Fair
De Nayer et al., 2002^14^ | Venlafaxine | 75 mg/d | 73 | 48 | Fair
De Wilde et al., 1993^15^ | Fluoxetine | 20-60 mg/d | 50 | 26 | Fair
De Wilde et al., 1993^15^ | Paroxetine | 20-40 mg/d | 50 | 25 | Fair
Detke et al., 2002^16^ | Placebo | NA | 139 | 49 | Fair
Detke et al., 2002^16^ | Duloxetine | 60 mg/d | 128 | 64 | Fair
Detke et al., 2002^17^ | Placebo | NA | 122 | 26 | Fair
Detke et al., 2002^17^ | Duloxetine | 60 mg/d | 123 | 54 | Fair
Detke et al., 2004^18^ | Placebo | NA | 93 | 41 | Fair
Detke et al., 2004^18^ | Duloxetine | 80mg/d, 120 mg/d | 188^c^ | 126^c^ | Fair
Detke et al., 2004^18^ | Paroxetine | 20 mg/d | 86 | 63 | Fair
Dierick et al., 1996^19^ | Fluoxetine | 20 mg/d | 161 | 95 | Fair
Dierick et al., 1996^19^ | Venlafaxine | 75-150 mg/d | 153 | 107 | Fair
Fava et al., 1998^20^ | Placebo | NA | 19 | 10 | Fair
Fava et al., 1998^20^ | Fluoxetine | 20-80 mg/d | 54 | 31 | Fair
Fava et al., 1998^20^ | Paroxetine | 20-50 mg/d | 55 | 32 | Fair
Fava et al., 2002^21^ | Paroxetine | 20-60 mg/d | 96 | 64 | Fair
Fava et al., 2002^21^ | Fluoxetine | 20-60 mg/d | 92 | 57 | Fair
Fava et al., 2002^21^ | Sertraline | 50-200 mg/d | 96 | 70 | Fair
Feiger et al., 1996^22^ | Sertraline | 50-200 mg/d | 82 | 41 | Fair
Feiger et al., 1996^22^ | Nefazodone | 100-600 mg/d | 78 | 42 | Fair
Feiger et al., 2009^23^ | Placebo | NA | 121 | 36 | Good
Feiger et al., 2009^23^ | Desvenlafaxine | 200-400 mg/d | 123 | 46 | Good
Feighner et al., 1991^24^ | Fluoxetine | 20-80 mg/d | 62 | 35 | Fair
Feighner et al., 1991^24^ | Bupropion | 225-450 mg/d | 61 | 37 | Fair
Fontaine et al., 1994^25^ | Placebo | NA | 45 | 14 | Fair
Fontaine et al., 1994^25^ | Nefazodone | 100-500 mg/d | 90 | 41 | Fair
Gagiano, 1993^26^ | Fluoxetine | 20-60 mg/d | 45 | 27 | Fair
Gagiano, 1993^26^ | Paroxetine | 20-40 mg/d | 45 | 30 | Fair
Goldstein et al., 2002^27^ | Placebo | NA | 70 | 24 | Fair
Goldstein et al., 2002^27^ | Duloxetine | 40-120 mg/d | 70 | 32 | Fair
Goldstein et al., 2002^27^ | Fluoxetine | 20 mg/d | 33 | 15 | Fair
Haffmans et al., 1996^28^ | Fluvoxamine | 100-200 mg/d | 109 | 31 | Fair
Haffmans et al., 1996^28^ | Citalopram | 20-40 mg/d | 108 | 33 | Fair
Halikas et al., 1995^29^ | Mirtazapine | 5-35 mg/d | 50 | 25 | Fair
Halikas et al., 1995^29^ | Trazodone | 40-280 mg/d | 50 | 20 | Fair
Halikas et al., 1995^29^ | Placebo | NA | 50 | 18 | Fair
Hicks et al., 2002^30^ | Paroxetine | 20-40 mg/d | 20 | 16 | Fair
Hicks et al., 2002^30^ | Nefazodone | 400-600 mg/d | 20 | 11 | Fair
Hong et al., 2003^31^ | Fluoxetine | 20-40 mg/d | 66 | 30 | Fair
Hong et al., 2003^31^ | Mirtazapine | 15-45 mg/d | 66 | 35 | Fair
Hypericum Depression Trial Study Group, 2002^32^ | Placebo | NA | 116 | 13 | Good
Hypericum Depression Trial Study Group, 2002^32^ | Sertraline | 50-100 mg/d | 111 | 26 | Good
Kasper et al., 2005^33^ | Trazodone | 150-450 mg/d | 55 | 48 | Fair
Kasper et al., 2005^33^ | Paroxetine | 20-40 mg/d | 53 | 48 | Fair
Khan et al., 2007^34^ | Duloxetine | 60 mg/d | 138 | 66 | Fair
Khan et al., 2007^34^ | Escitalopram | 10-20 mg/d | 140 | 83 | Fair
Lee et al., 2007^35^ | Duloxetine | 60 mg/d | 238 | 144 | Fair
Lee et al., 2007^35^ | Paroxetine | 20 mg/d | 240 | 157 | Fair
Liebowitz et al., 2007^36^ | Placebo | NA | 122 | 39 | Good
Liebowitz et al., 2007^36^ | Desvenlafaxine | 100-200 mg/d | 125 | 52 | Good
Lydiard et al., 1989^37^ | Placebo | NA | 18 | 5 | Fair
Lydiard et al., 1989^37^ | Fluvoxamine | 100-300 mg/d | 18 | 9 | Fair
Lydiard et al., 1997^38^ | Placebo | NA | 129 | 43 | Fair
Lydiard et al., 1997^38^ | Sertraline | 50-200 mg/d | 132 | 65 | Fair
Mao et al., 2008^39^ | Fluoxetine | 20 mg/d | 117 | 89 | Fair
Mao et al., 2008^39^ | Escitalopram | 10 mg/d | 123 | 94 | Fair
Mehtonen et al., 2000^40^ | Venlafaxine | 75-150 mg/d | 75 | 49 | Good
Mehtonen et al., 2000^40^ | Sertraline | 50-100 mg/d | 72 | 41 | Good
Munizza et al., 2006^41^ | Sertraline | 50-100 mg/d | 60 | 37 | Fair
Munizza et al., 2006^41^ | Trazodone | 150-450 mg/d | 62 | 46 | Fair
Nemeroff and Thase, 2007^42^ | Placebo | NA | 102 | 37 | Fair
Nemeroff and Thase, 2007^42^ | Fluoxetine | 20-60 mg/d | 104 | 45 | Fair
Nemeroff and Thase, 2007^42^ | Venlafaxine | 75-225 mg/d | 102 | 51 | Fair
Newhouse et al., 2000^43^ | Fluoxetine | 20-40 mg/d | 119 | 84 | Fair
Newhouse et al., 2000^43^ | Sertraline | 50-100 mg/d | 117 | 85 | Fair
Nierenberg et al., 2007^44^ | Placebo | NA | 137 | 44 | Fair
Nierenberg et al., 2007^44^ | Duloxetine | 40-60 mg/d | 273 | 117 | Fair
Nierenberg et al., 2007^44^ | Escitalopram | 10-20 mg/d | 274 | 112 | Fair
Olie et al., 1997^45^ | Placebo | NA | 129 | 45 | Fair
Olie et al., 1997^45^ | Sertraline | 50-200 mg/d | 129 | 70 | Fair
Perahia et al., 2006^46^ | Placebo | NA | 99 | 51 | Fair
Perahia et al., 2006^46^ | Duloxetine | 80mg/d, 120 mg/d | 196^c^ | 129^c^ | Fair
Perahia et al., 2006^46^ | Paroxetine | 20 mg/d | 97 | 59 | Fair
Reimherr et al., 1990^47^ | Placebo | NA | 150 | 49 | Fair
Reimherr et al., 1990^47^ | Sertraline | 20-200 mg/d | 149 | 77 | Fair
Rickels et al., 1989^48^ | Placebo | NA | 56 | 12 | Fair
Rickels et al., 1989^48^ | Paroxetine | 10-50 mg/d | 55 | 24 | Fair
Rudolph and Feiger, 1999^49^ | Placebo | NA | 98 | 41 | Fair
Rudolph and Feiger, 1999^49^ | Fluoxetine | 20-60 mg/d | 103 | 52 | Fair
Rudolph and Feiger, 1999^49^ | Venlafaxine | 75-225 mg/d | 100 | 54 | Fair
Rush et al., 2001^50^ | Sertraline | 50-200 mg/d | 126 | 93 | Fair
Rush et al., 2001^50^ | Bupropion | 100-300 mg/d | 122 | 81 | Fair
Sechter et al., 1999^51^ | Fluoxetine | 20-60 mg/d | 120 | 35 | Fair
Sechter et al., 1999^51^ | Sertraline | 50-150 mg/d | 118 | 48 | Fair
Septien-Velez et al., 2007^52^ | Placebo | NA | 126 | 48 | Good
Septien-Velez et al., 2007^52^ | Desvenlafaxine | 200mg/d, 400mg/d | 249^c^ | 142^c^ | Good
Shelton et al., 2006^53^ | Venlafaxine | 75-225 mg/d | 78 | 49 | Fair
Shelton et al., 2006^53^ | Sertraline | 50-150 mg/d | 82 | 45 | Fair
Sir et al., 2005^54^ | Venlafaxine | 75-225 mg/d | 84 | 56 | Good
Sir et al., 2005^54^ | Sertraline | 50-150 mg/d | 79 | 56 | Good
Thase, 1997^55^ | Placebo | NA | 102 | 29 | Fair
Thase, 1997^55^ | Venlafaxine | 75-225mg/d | 95 | 53 | Fair
Tollefson et al., 1993^56^ | Fluoxetine | 20 mg/d | 335 | 121 | Fair
Tollefson et al., 1993^56^ | Placebo | NA | 336 | 91 | Fair
Tourian et al., 2009^57^ | Placebo | NA | 164 | 61 | Fair
Tourian et al., 2009^57^ | Duloxetine | 60 mg/d | 159 | 74 | Fair
Tourian et al., 2009^57^ | Desvenlafaxine | 50mg/d, 100 mg/d | 315^c^ | 132^c^ | Fair
van Moffaert et al., 1995^58^ | Trazodone | 150-450 mg/d | 100 | 51 | Fair
van Moffaert et al., 1995^58^ | Mirtazapine | 24-72 mg/d | 100 | 61 | Fair
Ventura et al., 2007^59^ | Escitalopram | 10 mg/d | 107 | 75 | Fair
Ventura et al., 2007^59^ | Sertraline | 50-200 mg/d | 108 | 74 | Fair
Wade et al., 2007^60^ | Duloxetine | 60 mg/d | 151 | 81 | Fair
Wade et al., 2007^60^ | Escitalopram | 20 mg/d | 144 | 94 | Fair
Weihs et al., 2000^61^ | Bupropion | 100-300 mg/d | 48 | 34 | Fair
Weihs et al., 2000^61^ | Paroxetine | 10-40 mg/d | 52 | 40 | Fair
Weisler et al., 1994^62^ | Trazodone | 150-400 mg/d | 61 | 21 | Fair
Weisler et al., 1994^62^ | Bupropion | 225-450 mg/d | 63 | 33 | Fair
Wernicke et al., 1988^63^ | Placebo | NA | 78 | 18 | Fair
Wernicke et al., 1988^63^ | Fluoxetine | 5-40 mg/d | 285 | 132 | Fair

a Calculated based on number of patients randomized

b Data was received from authors

c Arms of the same drug with different dosage are summed together

Twenty studies64-83 met inclusion criteria for the mixed-treatment comparison, but did not report sufficient HAM-D information for our analysis.

Studies Included in KQ1 Meta-Analysis (based on change in HAM-D)

Trial | Drug | Dosage | Number randomized | Number of responders^a^ | Quality Rating
Alves et al., 1999^1^ | Fluoxetine | 20-40 mg/d | 47 | 35 | Fair
Alves et al., 1999^1^ | | | | | Fair
Alves et al., 1999^1^ | Venlafaxine | 75-150 mg/d | 40 | 35 | Fair
Bennie et al., 1995^3^ | Fluoxetine | 20-40 mg/d | 144 | 63 | Fair
Bennie et al., 1995^3^ | | | | | Fair
Bennie et al., 1995^3^ | Sertraline | 50-100 mg/d | 142 | 73 | Fair
Chouinard et al., 1999^9^ | Fluoxetine | 20-80 mg/d | 101 | 67 | Fair
Chouinard et al., 1999^9^ | | | | | Fair
Chouinard et al., 1999^9^ | Paroxetine | 20-50 mg/d | 102 | 67 | Fair
De Nayer et al., 2002^14^ | Fluoxetine | 20 mg/d | 73 | 34 | Fair
De Nayer et al., 2002^14^ | | | | | Fair
De Nayer et al., 2002^14^ | Venlafaxine | 75 mg/d | 73 | 48 | Fair
De Wilde et al., 1993^15^ | Fluoxetine | 20-60 mg/d | 50 | 26 | Fair
De Wilde et al., 1993^15^ | | | | | Fair
De Wilde et al., 1993^15^ | Paroxetine | 20-40 mg/d | 50 | 25 | Fair
Detke et al., 2004^18^ | Placebo | NA | 93 | 41 | Fair
Detke et al., 2004^18^ | | | | | Fair
Detke et al., 2004^18^ | Duloxetine | 80mg/d, 120 mg/d | 188^c^ | 126^c^ | Fair
Detke et al., 2004^18^ | | | | | Fair
Detke et al., 2004^18^ | Paroxetine | 20 mg/d | 86 | 63 | Fair
Detke et al., 2004^18^ | | | | | Fair
Dierick et al., 1996^19^ | Fluoxetine | 20 mg/d | 161 | 95 | Fair
Dierick et al., 1996^19^ | | | | | Fair
Dierick et al., 1996^19^ | Venlafaxine | 75-150 mg/d | 153 | 107 | Fair
Fava et al., 1998^20^ | Placebo | NA | 19 | 10 | Fair
Fava et al., 1998^20^ | | | | | Fair
Fava et al., 1998^20^ | Fluoxetine | 20-80 mg/d | 54 | 31 | Fair
Fava et al., 1998^20^ | | | | | Fair
Fava et al., 1998^20^ | Paroxetine | 20-50 mg/d | 55 | 32 | Fair
Fava et al., 2002^21^ | Paroxetine | 20-60 mg/d | 96 | 64 | Fair
Fava et al., 2002^21^ | | | | | Fair
Fava et al., 2002^21^ | Fluoxetine | 20-60 mg/d | 92 | 57 | Fair
Fava et al., 2002^21^ | | | | | Fair
Fava et al., 2002^21^ | Sertraline | 50-200 mg/d | 96 | 70 | Fair
Gagiano, 1993^26^ | Fluoxetine | 20-60 mg/d | 45 | 27 | Fair
Gagiano, 1993^26^ | | | | | Fair
Gagiano, 1993^26^ | Paroxetine | 20-40 mg/d | 45 | 30 | Fair
Lee et al., 2007^35^ | Duloxetine | 60 mg/d | 238 | 144 | Fair
Lee et al., 2007^35^ | | | | | Fair
Lee et al., 2007^35^ | Paroxetine | 20 mg/d | 240 | 157 | Fair
Mehtonen et al., 2000^40^ | Venlafaxine | 75-150 mg/d | 75 | 49 | Good
Mehtonen et al., 2000^40^ | | | | | Good
Mehtonen et al., 2000^40^ | Sertraline | 50-100 mg/d | 72 | 41 | Good
Newhouse et al., 2000^43^ | Fluoxetine | 20-40 mg/d | 119 | 84 | Fair
Newhouse et al., 2000^43^ | | | | | Fair
Newhouse et al., 2000^43^ | Sertraline | 50-100 mg/d | 117 | 85 | Fair
Perahia et al., 2006^46^ | Placebo | NA | 99 | 51 | Fair
Perahia et al., 2006^46^ | | | | | Fair
Perahia et al., 2006^46^ | Duloxetine | 80mg/d, 120 mg/d | 196^c^ | 129^c^ | Fair
Perahia et al., 2006^46^ | | | | | Fair
Perahia et al., 2006^46^ | Paroxetine | 20 mg/d | 97 | 59 | Fair
Rudolph and Feiger, 1999^49^ | Placebo | NA | 98 | 41 | Fair
Rudolph and Feiger, 1999^49^ | | | | | Fair
Rudolph and Feiger, 1999^49^ | Fluoxetine | 20-60 mg/d | 103 | 52 | Fair
Rudolph and Feiger, 1999^49^ | | | | | Fair
Rudolph and Feiger, 1999^49^ | Venlafaxine | 75-225 mg/d | 100 | 54 | Fair
Sechter et al., 1999^51^ | Fluoxetine | 20-60 mg/d | 120 | 35 | Fair
Sechter et al., 1999^51^ | | | | | Fair
Sechter et al., 1999^51^ | Sertraline | 50-150 mg/d | 118 | 48 | Fair
Shelton et al., 2006^53^ | Venlafaxine | 75-225 mg/d | 78 | 49 | Fair
Shelton et al., 2006^53^ | | | | | Fair
Shelton et al., 2006^53^ | Sertraline | 50-150 mg/d | 82 | 45
Silverstone and Ravindran, 1999^84^ | Fluoxetine | 20-60 | 119 | 74 | Fair
Silverstone and Ravindran, 1999^84^ | | | | | Fair
Silverstone and Ravindran, 1999^84^ | Venlafaxine | 75-225 | 122 | 82 | Fair
Sir et al., 2005^54^ | Venlafaxine | 75-225 mg/d | 84 | 56 | Good
Sir et al., 2005^54^ | | | | | Good
Sir et al., 2005^54^ | Sertraline | 50-150 mg/d | 79 | 56 | Good

a Calculated based on number of patients randomized

c Arms of the same drug with different dosage are summed together

Studies Included in KQ1 Meta-Analysis (based on change in MADRS)

Trial | Drug | Dosage | Number randomized | Number of responders^a^ | Quality Rating
Burke et al., 2002^85^ | Escitalopram | 10 mg/d, 20 mg/d | 244 | 122 | Fair
Burke et al., 2002^85^ | Citalopram | 40 mg/d | 125 | 57 | Fair
Colonna et al., 2005^86^ | Escitalopram | 10 mg/d | 175 | 104 | Fair
Colonna et al., 2005^86^ | Citalopram | 20 mg/d | 182 | 96 | Fair
Lepola et al., 2003^87^ | Escitalopram | 10-20 mg/d | 155 | 99 | Fair
Lepola et al., 2003^87^ | Citalopram | 20-40 mg/d | 160 | 84 | Fair
Moore et al., 2005^88^ | Escitalopram | 20 mg/d | 142 | 105 | Fair
Moore et al., 2005^88^ | Citalopram | 40 mg/d | 152 | 87 | Fair
Unpublished Study SCT MD-02^89^ | Escitalopram | 10 – 20 mg/d | 125 | 57 | Fair
Unpublished Study SCT MD-02^89^ | Citalopram | 20-40 mg/d | 123 | 61 | Fair
Yevtushenko et al., 2007^90^ | Escitalopram | 10 mg/d | 109 | 103 | Fair
Yevtushenko et al., 2007^90^ | Citalopram | 20 mg/d | 110 | 90 | Fair

a Calculated based on number of patients randomized

Studies Included in KQ4 Meta-Analysis: Nausea and Vomiting

Trial | VEN n | SSRI n | VEN n nausea | SSRI n nauseea | VEN n nausea+ vomiting | SSRI n nausea+ vomiting | Quality Rating
Alves et al., 1999^1^ | 40 | 47 | 13 | 13 | 19 | 14 | Fair
Ballus et al., 2000^80^ | 41 | 43 | 11 | 4 | 17 | 5 | Fair
Bielski et al., 2004^4^ | 100 | 98 | 24 | 6 | 24 | 6 | Fair
Clerc et al., 1994^91^ | 34 | 34 | 3 | 4 | 3 | 4 | Poor
Costa e Silvia, 1998^92^ | 196 | 186 | 57 | 35 | 57 | 35 | Fair
De Nayer et al., 2002^14^ | 73 | 73 | 21 | 16 | 21 | 16 | Fair
Dierick et al., 1996^19^ | 153 | 161 | 43 | 23 | 43 | 23 | Fair
McPartlin et al., 1998^82^ | 183 | 178 | 46 | 44 | 56 | 56 | Fair
Mehtonen et al., 2000^40^ | 75 | 72 | 27 | 21 | 27 | 21 | Good
Nemeroff and Thase, 2007^42^ | 100 | 102 | 40 | 22 | 51 | 27 | Fair
Rudolph and Feiger, 1999^49^ | 100 | 103 | 36 | 21 | 36 | 21 | Fair
Schatzberg and Roose, 2006^93^ | 102 | 100 | 46 | 23 | 55 | 25 | Fair
Silverstone and Ravindran, 1999^84^ | 128 | 121 | 52 | 39 | 50 | 39 | Fair
Shelton et al., 2006^53^ | 78 | 82 | 12 | 12 | 12 | 12 | Fair
Sir et al., 2005^54^ | 84 | 79 | 40 | 41 | 40 | 41 | Good
Tylee et al., 1997^94^ | 171 | 170 | 59 | 31 | 81 | 40 | Fair
Tzanakaki et al., 2000^95^ | 55 | 54 | 3 | 8 | 3 | 11 | Fair

Studies Included in KQ4 Meta-Analysis: Overall Loss to Follow-up

VENLAFAXINE VS. SSRIs
Trial | Total # | VEN # LTF | Total # | SSRIs # LTF | Quality Rating
Alves et al., 1999^1^ | 40 | 10 | 47 | 9 | Fair
Ballus et al., 2000^80^ | 41 | 16 | 43 | 11 | Fair
Bielski et al., 2004^4^ | 100 | 34 | 98 | 26 | Fair
Clerc et al., 1994^91^ | 34 | 6 | 34 | 12 | Poor
Costa e Silvia, 1998^92^ | 196 | 29 | 186 | 18 | Fair
De Nayer et al., 2002^14^ | 73 | 24 | 73 | 29 | Fair
Dierick et al., 1996^19^ | 153 | 38 | 161 | 40 | Fair
McPartlin et al., 1998^82^ | 183 | 48 | 178 | 52 | Fair
Mehtonen et al., 2000^40^ | 75 | 16 | 72 | 12 | Good
Montgomery et al., 2004^76^ | 145 | 19 | 148 | 21 | Fair
Nemeroff et al., 2007^42^ | 102 | 24 | 104 | 19 | Fair
Owens et al., 2008^96^ | 44 | 12 | 42 | 10 | Fair
Rudolph and Feiger, 1999^49^ | 100 | 19 | 103 | 29 | Fair
Schatzberg and Roose, 2006^93^ | 104 | 37 | 100 | 30 | Fair
Shelton et al., 2006^53^ | 78 | 11 | 82 | 19 | Fair
Silverstone and Ravindran, 1999^84^ | 128 | 37 | 121 | 32 | Fair
Sir et al., 2005^54^ | 84 | 25 | 79 | 13 | Good
Tylee et al., 1997^94^ | 171 | 47 | 170 | 46 | Fair

MIRTAZAPINE VS. SSRIs
Trial | Total # | MIR # LTF | Total # | SSRIs # LTF | Quality Rating
Behnke et al., 2003^77^ | 176 | 41 | 170 | 32 | Fair
Benkert et al., 2000^2^ | 139 | 30 | 136 | 33 | Fair
Blier et al., 2009^97^ | 21 | 0 | 19 | 2 | Fair
Hong et al., 2003^31^ | 66 | 30 | 66 | 22 | Fair
Leinonen et al., 1999^98^ | 137 | 18 | 133 | 8 | Fair
Schatzberg and Roose, 2006^93^ | 128 | 29 | 126 | 39 | Fair
Versiani, 2005^75^ | 147 | 16 | 152 | 21 | Fair
Wheatley et al., 1998^69^ | 66 | 17 | 67 | 21 | Fair

BUPROPION VS. SSRIs
Trial | Total # | BUP # LTF | Total # | SSRIs # LTF | Quality Rating
Coleman et al., 2001^12^ | 150 | 56 | 154 | 57 | Fair
Coleman et al., 1999^11^ | 122 | 27 | 118 | 43 | Fair
Croft et al., 1999^13^ | 120 | 36 | 119 | 39 | Fair
Feighner et al., 1991^24^ | 61 | 16 | 62 | 18 | Fair
Kavoussi et al., 1997^99^ | 122 | 35 | 126 | 43 | Fair
Kennedy, 2006^100^ | 65 | 8 | 66 | 13 | Fair
Weihs et al., 2000^61^ | 48 | 8 | 52 | 8 | Fair

DULOXETINE VS. SSRIs
Trial | Total # | DUL # LTF | Total # | SSRIs # LTF | Quality Rating
Detke et al., 2004^18^ | 188 | 21 | 86 | 10 | Fair
Goldstein et al., 2002^27^ | 70 | 24 | 33 | 12 | Fair
Khan et al., 2007^34^ | 138 | 46 | 140 | 21 | Fair
Lee et al., 2007^35^ | 238 | 72 | 240 | 57 | Fair
Nierenberg et al., 2007^44^ | 273 | 85 | 274 | 66 | Fair
Perahia et al., 2006^46^ | 200 | 23 | 97 | 11 | Fair
Wade et al., 2007^60^ | 151 | 37 | 144 | 32 | Fair

NEFAZODONE VS. SSRIs
Trial | Total # | NEF # LTF | Total # | SSRIs # LTF | Quality Rating
Baldwin et al., 1996^73^ | 105 | 28 | 101 | 28 | Fair
Feiger et al., 1996^22^ | 78 | 19 | 82 | 20 | Fair
Hicks et al., 2002^30^ | 20 | 5 | 20 | 3 | Fair
Rush et al., 1998^101^ | 64 | 11 | 61 | 10 | Fair

TRAZODONE VS. SSRIs
Trial | Total # | TRAZ # LTF | Total # | SSRIs # LTF | Quality Rating
Beasley et al., 1991^102^ | 61 | 20 | 65 | 23 | Fair
Kasper et al., 2005^33^ | 55 | 5 | 53 | 0 | Fair

VENLAFAXINE VS. SSRIs
Trial | Total # | VEN # LTF | Total # | SSRIs # LTF | Quality Rating
Munizza et al., 2006^41^ | 62 | 5 | 60 | 8 | Fair
Perry et al., 1989^68^ | 19 | 4 | 21 | 4 | Fair

Studies Included in KQ4 Meta-Analysis: Loss to Follow-up Due to Adverse Events

VENLAFAXINE VS. SSRIs
Trial | Total # | VEN # disc. AEs | Total # | SSRIs # disc. AEs | Quality Rating
Allard et al., 2004^103^ | 76 | 6 | 75 | 3 | Fair
Alves et al., 1999^1^ | 40 | 3 | 47 | 1 | Fair
Ballus et al., 2000^80^ | 41 | 6 | 43 | 3 | Fair
Bielski et al., 2004^4^ | 100 | 16 | 98 | 4 | Fair
Clerc et al., 1994^91^ | 34 | 1 | 34 | 5 | Poor
Costa e Silvia, 1998^92^ | 196 | 14 | 186 | 7 | Fair
De Nayer et al., 2002^14^ | 73 | 8 | 73 | 9 | Fair
Dierick et al., 1996^19^ | 153 | 14 | 161 | 7 | Fair
McPartlin et al., 1998^82^ | 183 | 22 | 178 | 29 | Fair
Mehtonen et al., 2000^40^ | 75 | 12 | 72 | 5 | Good
Montgomery et al., 2004^76^ | 145 | 16 | 148 | 11 | Fair
Nemeroff et al., 2007^42^ | 102 | 12 | 104 | 7 | Fair
Owens et al., 2008^96^ | 44 | 4 | 42 | 2 | Fair
Rudolph and Feiger, 1999^49^ | 100 | 6 | 103 | 9 | Fair
Schatzberg and Roose, 2006^93^ | 104 | 28 | 100 | 19 | Fair
Shelton et al., 2006^53^ | 78 | 3 | 82 | 1 | Fair
Silverstone and Ravindran, 1999^84^ | 128 | 13 | 121 | 8 | Fair
Sir et al., 2005^54^ | 84 | 5 | 79 | 3 | Good
Tylee et al., 1997^94^ | 171 | 36 | 170 | 24 | Fair

MIRTAZAPINE VS. SSRIs
Trial | Total # | MIR # disc. AEs | Total # | SSRIs # disc. AEs | Quality Rating
Behnke et al., 2003^77^ | 176 | 21 | 170 | 5 | Fair
Benkert et al., 2000^2^ | 139 | 12 | 136 | 10 | Fair
Blier et al., 2009^97^ | 21 | 0 | 19 | 1 | Fair
Hong et al., 2003^31^ | 66 | 13 | 66 | 8 | Fair
Leinonen et al., 1999^98^ | 137 | 5 | 133 | 4 | Fair
Schatzberg et al., 2002^104^ | 128 | 19 | 126 | 33 | Fair
Versiani, 2005^75^ | 147 | 4 | 152 | 4 | Fair
Wheatley et al., 1998^69^ | 66 | 7 | 67 | 9 | Fair

BUPROPION VS. SSRIs
Trial | Total # | BUP # disc. AEs | Total # | SSRIs # disc. AEs | Quality Rating
Coleman et al., 2001^12^ | 150 | 13 | 154 | 6 | Fair
Coleman et al., 1999^11^ | 122 | 7 | 118 | 9 | Fair
Croft et al., 1999^13^ | 120 | 8 | 119 | 4 | Fair
Feighner et al., 1991^24^ | 61 | 6 | 62 | 4 | Fair
Kavoussi et al., 1997^99^ | 122 | 4 | 126 | 17 | Fair
Weihs et al., 2000^61^ | 48 | 4 | 52 | 3 | Fair

DULOXETINE VS. SSRIs
Trial | Total # | DUL # disc. AEs | Total # | SSRIs # disc. AEs | Quality Rating
Detke et al., 2004^18^ | 188 | 7 | 86 | 3 | Fair
Goldstein et al., 2002^27^ | 70 | 7 | 33 | 1 | Fair
Khan et al., 2007^34^ | 138 | 17 | 140 | 3 | Fair
Lee et al., 2007^35^ | 238 | 20 | 240 | 17 | Fair
Nierenberg et al., 2007^44^ | 273 | 20 | 274 | 14 | Fair
Perahia et al., 2006^46^ | 200 | 4 | 97 | 1 | Fair
Wade et al., 2007^60^ | 151 | 26 | 144 | 13 | Fair

NEFAZODONE VS. SSRIs
Trial | Total # | NEF # disc. AEs | Total # | SSRIs # disc. AEs | Quality Rating
Baldwin et al., 1996^73^ | 105 | 15 | 101 | 13 | Fair
Feiger et al., 1996^22^ | 78 | 15 | 82 | 10 | Fair
Hicks et al., 2002^30^ | 20 | 4 | 20 | 1 | Fair
Rush et al., 1998^101^ | 64 | 6 | 61 | 5 | Fair

TRAZODONE VS. SSRIs
Trial | Total # | TRAZ # disc. AEs | Total # | SSRIs # disc. AEs | Quality Rating
Beasley et al., 1991^102^ | 61 | 6 | 65 | 9 | Fair
Kasper et al., 2005^33^ | 55 | 3 | 53 | 0 | Fair
Munizza et al., 2006^41^ | 62 | 2 | 60 | 6 | Fair
Perry et al., 1989^68^ | 19 | 2 | 21 | 2 | Fair

Studies Included in KQ4 Meta-Analysis: Loss to Follow-up Due to Lack of Efficacy

VENLAFAXINE VS. SSRIs
Trial | Total # | VEN # disc. lack of efficacy | Total # | SSRIs # disc. lack of efficacy | Quality Rating
Alves et al., 1999^1^ | 40 | 0 | 47 | 2 | Fair
Ballus et al., 2000^80^ | 41 | 2 | 43 | 4 | Fair
Clerc et al., 1994^91^ | 34 | 3 | 34 | 6 | Poor
Costa e Silvia, 1998^92^ | 196 | 5 | 186 | 2 | Fair
De Nayer et al., 2002^14^ | 73 | 5 | 73 | 10 | Fair
Dierick et al., 1996^19^ | 153 | 9 | 161 | 14 | Fair
McPartlin et al., 1998^82^ | 183 | 2 | 178 | 5 | Fair
Mehtonen et al., 2000^40^ | 75 | 6 | 72 | 4 | Good
Montgomery et al., 2004^76^ | 145 | 3 | 148 | 6 | Fair
Nemeroff et al., 2007^42^ | 102 | 4 | 104 | 4 | Fair
Rudolph and Feiger, 1999^49^ | 100 | 3 | 103 | 7 | Fair
Silverstone and Ravindran, 1999^84^ | 128 | 6 | 121 | 6 | Fair
Schatzberg and Roose, 2006^93^ | 104 | 2 | 100 | 6 | Fair
Tylee et al., 1997^94^ | 171 | 4 | 170 | 7 | Fair

MIRTAZAPINE VS. SSRIs
Trial | Total # | MIR # disc. lack of efficacy | Total # | SSRIs # disc. lack of efficacy | Quality Rating
Benkert et al., 2000^2^ | 139 | 3 | 136 | 7 | Fair
Hong et al., 2003^31^ | 66 | 0 | 66 | 2 | Fair
Leinonen et al., 1999^98^ | 137 | 4 | 133 | 1 | Fair
Schatzberg and Roose, 2006^93^ | 128 | 5 | 126 | 0 | Fair
Versiani, 2005^75^ | 147 | 10 | 152 | 12 | Fair
Wheatley et al., 1998^69^ | 66 | 3 | 67 | 5 | Fair

BUPROPION VS. SSRIs
Trial | Total # | BUP # disc. lack of efficacy | Total # | SSRIs # disc. lack of efficacy | Quality Rating
Coleman et al., 2001^12^ | 150 | 4 | 154 | 7 | Fair
Coleman et al., 1999^11^ | 122 | 3 | 118 | 7 | Fair
Croft et al., 1999^13^ | 120 | 2 | 119 | 2 | Fair
Feighner et al., 1991^24^ | 61 | 1 | 62 | 2 | Fair
Kavoussi et al., 1997^99^ | 122 | 8 | 126 | 6 | Fair

DULOXETINE VS. SSRIs
Trial | Total # | DUL # disc. lack of efficacy | Total # | SSRIs # disc. lack of efficacy | Quality Rating
Goldstein et al., 2002^27^ | 70 | 2 | 33 | 3 | Fair
Khan et al., 2007^34^ | 138 | 2 | 140 | 1 | Fair
Lee et al., 2007^35^ | 238 | 1 | 240 | 1 | Fair
Nierenberg et al., 2007^44^ | 273 | 9 | 274 | 4 | Fair
Perahia et al., 2006^46^ | 200 | 5 | 97 | 1 | Fair
Wade et al., 2007^60^ | 151 | 2 | 144 | 7 | Fair

NEFAZODONE VS. SSRIs
Trial | Total # | NEF # disc. lack of efficacy | Total # | SSRIs # disc. lack of efficacy | Quality Rating
Baldwin et al., 1996^73^ | 105 | 3 | 101 | 1 | Fair
Feiger et al., 1996^22^ | 78 | 0 | 82 | 2 | Fair
Hicks et al., 2002^30^ | 20 | 0 | 20 | 2 | Fair

TRAZODONE VS. SSRIs
Trial | Total # | TRAZ # disc. lack of efficacy | Total # | SSRIs # disc. lack of efficacy | Quality Rating
Beasley et al., 1991^102^ | 61 | 4 | 65 | 4 | Fair
Kasper et al., 2005^33^ | 55 | 1 | 53 | 0 | Fair
Munizza et al., 2006^41^ | 62 | 1 | 60 | 0 | Fair

## References

1 Alves C, Cachola I, Brandao J. Efficacy and tolerability of venlafaxine and fluoxetine in outpatients with major depression. Primary Care Psychiatry. 1999;5(2):57-63.
2 Benkert O, Szegedi A, Kohnen R. Mirtazapine compared with paroxetine in major depression. J Clin Psychiatry. Sep. 2000;61(9):656-63. [pmid: 11030486].
3 Bennie EH, Mullin JM, Martindale JJ. A double-blind multicenter trial comparing sertraline and fluoxetine in outpatients with major depression. J Clin Psychiatry. Jun. 1995;56(6):229-37. [pmid: 7775364].
4 Bielski RJ, Ventura D, Chang CC. A double-blind comparison of escitalopram and venlafaxine extended release in the treatment of major depressive disorder. J Clin Psychiatry. Sep. 2004;65(9):1190-6. [pmid: 15367045].
5 Blumenthal JA, Babyak MA, Doraiswamy PM, et al. Exercise and pharmacotherapy in the treatment of major depressive disorder. Psychosom Med. Sep-Oct. 2007;69(7):587-96. [pmid: 17846259].
6 Boulenger JP, Huusom AK, Florea I, et al. A comparative study of the efficacy of long-term treatment with escitalopram and paroxetine in severely depressed patients. Curr Med Res Opin. Jul. 2006;22(7):1331-41. [pmid: 16834832].
7 Boyer P, Montgomery S, Lepola U, et al. Efficacy, safety, and tolerability of fixed-dose desvenlafaxine 50 and 100 mg/day for major depressive disorder in a placebo-controlled trial. Int Clin Psychopharmacol. Sep. 2008;23(5):243-53. [pmid: 18703933].
8 Brannan SK, Mallinckrodt CH, Brown EB, et al. Duloxetine 60 mg once-daily in the treatment of painful physical symptoms in patients with major depressive disorder. J Psychiatr Res. Jan. 2005;39(1):43-53. [pmid: 15504423].
9 Chouinard G, Saxena B, Belanger MC, et al. A Canadian multicenter, double-blind study of paroxetine and fluoxetine in major depressive disorder. J Affect Disord. Jul. 1999;54(1-2):39-48. [pmid: 10403145].
10 Cohn CK, Robinson DS, Roberts DL, et al. Responders to antidepressant drug treatment: a study comparing nefazodone, imipramine, and placebo in patients with major depression. J Clin Psychiatry. Suppl 2. 1996;57:15-8. [pmid: 8626358].
11 Coleman CC, Cunningham LA, Foster VJ, et al. Sexual dysfunction associated with the treatment of depression: a placebo-controlled comparison of bupropion sustained release and sertraline treatment. Ann Clin Psychiatry. Dec. 1999;11(4):205-15. [pmid: 10596735].
12 Coleman CC, King BR, Bolden-Watson C, et al. A placebo-controlled comparison of the effects on sexual functioning of bupropion sustained release and fluoxetine. Clin Ther. Jul. 2001;23(7):1040-58. [pmid: 11519769].
13 Croft H, Settle E Jr, Houser T, et al. A placebo-controlled comparison of the antidepressant efficacy and effects on sexual functioning of sustained-release bupropion and sertraline. Clin Ther. Apr. 1999;21(4):643-58. [pmid: 10363731].
14 De Nayer A, Geerts S, Ruelens L, et al. Venlafaxine compared with fluoxetine in outpatients with depression and concomitant anxiety. Int J Neuropsychopharmacol. Jun. 2002;5(2):115-20. [pmid: 12135535].
15 De Wilde J, Spiers R, Mertens C, et al. A double-blind, comparative, multicentre study comparing paroxetine with fluoxetine in depressed patients. Acta Psychiatr Scand. Feb. 1993;87(2):141-5. [pmid: 8447241].
16 Detke MJ, Lu Y, Goldstein DJ, et al. Duloxetine 60 mg once daily dosing versus placebo in the acute treatment of major depression. J Psychiatr Res. Nov-Dec. 2002;36(6):383-90. [pmid: 12393307].
17 Detke MJ, Lu Y, Goldstein DJ, et al. Duloxetine, 60 mg once daily, for major depressive disorder: a randomized double-blind placebo-controlled trial. J Clin Psychiatry. Apr. 2002;63(4):308-15. [pmid: 12000204].
18 Detke MJ, Wiltse CG, Mallinckrodt CH, et al. Duloxetine in the acute and long-term treatment of major depressive disorder: a placebo- and paroxetine-controlled trial. Eur Neuropsychopharmacol. Dec. 2004;14(6):457-70. [pmid: 15589385].
19 Dierick M, Ravizza L, Realini R, et al. A double-blind comparison of venlafaxine and fluoxetine for treatment of major depression in outpatients. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1996;20(1):57-71. [pmid: 8861177].
20 Fava M, Amsterdam JD, Deltito JA, et al. A double-blind study of paroxetine, fluoxetine, and placebo in outpatients with major depression. Ann Clin Psychiatry. Dec. 1998;10(4):145-50. [pmid: 9988054].
21 Fava M, Hoog SL, Judge RA, et al. Acute efficacy of fluoxetine versus sertraline and paroxetine in major depressive disorder including effects of baseline insomnia. J Clin Psychopharmacol. Apr. 2002;22(2):137-47. [pmid: 11910258].
22 Feiger A, Kiev A, Shrivastava RK, et al. Nefazodone versus sertraline in outpatients with major depression: focus on efficacy, tolerability, and effects on sexual function and satisfaction. J Clin Psychiatry. Suppl 2. 1996;57:53-62. [pmid: 8626364].
23 Feiger AD, Tourian KA, Rosas GR, et al. A placebo-controlled study evaluating the efficacy and safety of flexible-dose desvenlafaxine treatment in outpatients with major depressive disorder. CNS Spectr. Jan. 2009;14(1):41-50. [pmid: 19169187].
24 Feighner JP, Gardner EA, Johnston JA, et al. Double-blind comparison of bupropion and fluoxetine in depressed outpatients. J Clin Psychiatry. Aug. 1991;52(8):329-35. [pmid: 1907963].
25 Fontaine R, Ontiveros A, Elie R, et al. A double-blind comparison of nefazodone, imipramine, and placebo in major depression. J Clin Psychiatry. Jun. 1994;55(6):234-41. [pmid: 8071277].
26 Gagiano CA. A double blind comparison of paroxetine and fluoxetine in patients with major depression. Br J Clin Res. 1993;4:145-52.
27 Goldstein DJ, Mallinckrodt C, Lu Y, et al. Duloxetine in the treatment of major depressive disorder: a double-blind clinical trial. J Clin Psychiatry. Mar. 2002;63(3):225-31. [pmid: 11926722].
28 Haffmans PM, Timmerman L, Hoogduin CA. Efficacy and tolerability of citalopram in comparison with fluvoxamine in depressed outpatients: a double-blind, multicentre study. The LUCIFER Group. Int Clin Psychopharmacol. Sep. 1996;11(3):157-64. [pmid: 8923094].
29 Halikas JA. Org 3770 (mirtazapine) versus trazodone: A placebo controlled trial in depressed elderly patients. Hum Psychopharmacol. 1995;10(Suppl 2):S125-S33.
30 Hicks JA, Argyropoulos SV, Rich AS, et al. Randomised controlled study of sleep after nefazodone or paroxetine treatment in outpatients with depression. Br J Psychiatry. Jun. 2002;180:528-35. [pmid: 12042232].
31 Hong CJ, Hu WH, Chen CC, et al. A double-blind, randomized, group-comparative study of the tolerability and efficacy of 6 weeks' treatment with mirtazapine or fluoxetine in depressed Chinese patients. J Clin Psychiatry. Aug. 2003;64(8):921-6. [pmid: 12927007].
32 Hypericum Depression Trial Study Group. Effect of Hypericum perforatum (St John's wort) in major depressive disorder: a randomized controlled trial. JAMA. Apr. 10. 2002;287(14):1807-14. [pmid: 11939866].
33 Kasper S, Olivieri L, Di Loreto G, et al. A comparative, randomised, double-blind study of trazodone prolonged-release and paroxetine in the treatment of patients with major depressive disorder. Curr Med Res Opin. Aug. 2005;21(8):1139-46. [pmid: 16083521].
34 Khan A, Bose A, Alexopoulos GS, et al. Double-blind comparison of escitalopram and duloxetine in the acute treatment of major depressive disorder. Clin Drug Investig. 2007;27(7):481-92. [pmid: 17563128].
35 Lee P, Shu L, Xu X, et al. Once-daily duloxetine 60 mg in the treatment of major depressive disorder: multicenter, double-blind, randomized, paroxetine-controlled, non-inferiority trial in China, Korea, Taiwan and Brazil. Psychiatry Clin Neurosci. Jun. 2007;61(3):295-307. [pmid: 17472599].
36 Liebowitz MR, Yeung PP, Entsuah R. A randomized, double-blind, placebo-controlled trial of desvenlafaxine succinate in adult outpatients with major depressive disorder. J Clin Psychiatry. Nov. 2007;68(11):1663-72. [pmid: 18052559].
37 Lydiard RB, Laird LK, Morton WA Jr, et al. Fluvoxamine, imipramine, and placebo in the treatment of depressed outpatients: effects on depression. Psychopharmacol Bull. 1989;25(1):68-70. [pmid: 2505304].
38 Lydiard RB, Stahl SM, Hertzman M, et al. A double-blind, placebo-controlled study comparing the effects of sertraline versus amitriptyline in the treatment of major depression. J Clin Psychiatry. Nov. 1997;58(11):484-91. [pmid: 9413414].
39 Mao PX, Tang YL, Jiang F, et al. Escitalopram in major depressive disorder: a multicenter, randomized, double-blind, fixed-dose, parallel trial in a Chinese population. Depress Anxiety. 2008;25(1):46-54. [pmid: 17149753].
40 Mehtonen OP, Sogaard J, Roponen P, et al. Randomized, double-blind comparison of venlafaxine and sertraline in outpatients with major depressive disorder. Venlafaxine 631 Study Group. J Clin Psychiatry. Feb. 2000;61(2):95-100. [pmid: 10732656].
41 Munizza C, Olivieri L, Di Loreto G, et al. A comparative, randomized, double-blind study of trazodone prolonged-release and sertraline in the treatment of major depressive disorder. Curr Med Res Opin. Sep. 2006;22(9):1703-13. [pmid: 16968574].
42 Nemeroff CB, Thase ME. A double-blind, placebo-controlled comparison of venlafaxine and fluoxetine treatment in depressed outpatients. J Psychiatr Res. 2007;41(3-4):351-9. Epub 2005 Sep 12. [pmid: 16165158].
43 Newhouse PA, Krishnan KR, Doraiswamy PM, et al. A double-blind comparison of sertraline and fluoxetine in depressed elderly outpatients. J Clin Psychiatry. Aug. 2000;61(8):559-68. [pmid: 10982198].
44 Nierenberg AA, Greist JH, Mallinckrodt CH, et al. Duloxetine versus escitalopram and placebo in the treatment of patients with major depressive disorder: onset of antidepressant action, a non-inferiority study. Curr Med Res Opin. Feb. 2007;23(2):401-16. [pmid: 17288694].
45 Olie JP, Gunn KP, Katz E. A double-blind placebo-controlled multicentre study of sertraline in the acute and continuation treatment of major depression. European Psychiatry. 1997;12(1):34-41. [pmid: 19698503].
46 Perahia DG, Wang F, Mallinckrodt CH, et al. Duloxetine in the treatment of major depressive disorder: a placebo- and paroxetine-controlled trial. Eur Psychiatry. Sep. 2006;21(6):367-78. [pmid: 16697153].
47 Reimherr FW, Chouinard G, Cohn CK, et al. Antidepressant efficacy of sertraline: a double-blind, placebo- and amitriptyline-controlled, multicenter comparison study in outpatients with major depression. J Clin Psychiatry. Dec. Suppl B. 1990;51:18-27. [pmid: 2258378].
48 Rickels K, Amsterdam J, Clary C, et al. A placebo-controlled, double-blind, clinical trial of paroxetine in depressed outpatients. Acta Psychiatr Scand Suppl. 1989;350:117-23. [pmid: 2530761].
49 Rudolph RL, Feiger AD. A double-blind, randomized, placebo-controlled trial of once-daily venlafaxine extended release (XR) and fluoxetine for the treatment of depression. J Affect Disord. Dec. 1999;56(2-3):171-81. [pmid: 10701474].
50 Rush AJ, Trivedi MH, Carmody TJ, et al. Response in relation to baseline anxiety levels in major depressive disorder treated with bupropion sustained release or sertraline. Neuropsychopharmacology. Jul. 2001;25(1):131-8. [pmid: 11377926].
51 Sechter D, Troy S, Paternetti S, et al. A double-blind comparison of sertraline and fluoxetine in the treatment of major depressive episode in outpatients. Eur Psychiatry. Mar. 1999;14(1):41-8. [pmid: 10572324].
52 Septien-Velez L, Pitrosky B, Padmanabhan SK, et al. A randomized, double-blind, placebo-controlled trial of desvenlafaxine succinate in the treatment of major depressive disorder. Int Clin Psychopharmacol. Nov. 2007;22(6):338-47. [pmid: 17917552].
53 Shelton RC, Haman KL, Rapaport MH, et al. A randomized, double-blind, active-control study of sertraline versus venlafaxine XR in major depressive disorder. J Clin Psychiatry. Nov. 2006;67(11):1674-81. [pmid: 17196045].
54 Sir A, D'Souza RF, Uguz S, et al. Randomized trial of sertraline versus venlafaxine XR in major depression: efficacy and discontinuation symptoms. J Clin Psychiatry. Oct. 2005;66(10):1312-20. [pmid: 16259546].
55 Thase ME. Efficacy and tolerability of once-daily venlafaxine extended release (XR) in outpatients with major depression. The Venlafaxine XR 209 Study Group. J Clin Psychiatry. Sep. 1997;58(9):393-8. [pmid: 9378690].
56 Tollefson GD, Holman SL. Analysis of the Hamilton Depression Rating Scale factors from a double-blind, placebo-controlled trial of fluoxetine in geriatric major depression. Int Clin Psychopharmacol. Winter. 1993;8(4):253-9. [pmid: 8277144].
57 Tourian KA, Padmanabhan SK, Groark J, et al. Desvenlafaxine 50 and 100 mg/d in the treatment of major depressive disorder: an 8-week, phase III, multicenter, randomized, double-blind, placebo-controlled, parallel-group trial and a post hoc pooled analysis of three studies. Clin Ther. Jun. 2009;31(Pt 1):1405-23. [pmid: 19698901].
58 van Moffaert M, de Wilde J, Vereecken A, et al. Mirtazapine is more effective than trazodone: a double-blind controlled study in hospitalized patients with major depression. Int Clin Psychopharmacol. Mar. 1995;10(1):3-9. [pmid: 7622801].
59 Ventura D, Armstrong EP, Skrepnek GH, et al. Escitalopram versus sertraline in the treatment of major depressive disorder: a randomized clinical trial. Curr Med Res Opin. Feb. 2007;23(2):245-50. [pmid: 17288677].
60 Wade A, Gembert K, Florea I. A comparative study of the efficacy of acute and continuation treatment with escitalopram versus duloxetine in patients with major depressive disorder. Curr Med Res Opin. Jul. 2007;23(7):1605-14. [pmid: 17559755].
61 Weihs KL, Settle EC Jr, Batey SR, et al. Bupropion sustained release versus paroxetine for the treatment of depression in the elderly. J Clin Psychiatry. Mar. 2000;61(3):196-202. [pmid: 10817105].
62 Weisler RH, Johnston JA, Lineberry CG, et al. Comparison of bupropion and trazodone for the treatment of major depression. J Clin Psychopharmacol. Jun. 1994;14(3):170-9. [pmid: 8027413].
63 Wernicke JF, Dunlop SR, Dornseif BE, et al. Low-dose fluoxetine therapy for depression. Psychopharmacol Bull. 1988;24(1):183-8. [pmid: 3290940].
64 Cutler AJ, Montgomery SA, Feifel D, et al. Extended release quetiapine fumarate monotherapy in major depressive disorder: a placebo- and duloxetine-controlled study. J Clin Psychiatry. Apr. 2009;70(4):526-39. [pmid: 19358790].
65 DeMartinis NA, Yeung PP, Entsuah R, et al. A double-blind, placebo-controlled study of the efficacy and safety of desvenlafaxine succinate in the treatment of major depressive disorder. J Clin Psychiatry. May. 2007;68(5):677-88. [pmid: 17503976].
66 Liebowitz MR, Manley AL, Padmanabhan SK, et al. Efficacy, safety, and tolerability of desvenlafaxine 50 mg/day and 100 mg/day in outpatients with major depressive disorder. Curr Med Res Opin. Jul. 2008;24(7):1877-90. [pmid: 18507895].
67 Moreno RA, Teng CT, Almeida KM, et al. Hypericum perforatum versus fluoxetine in the treatment of mild to moderate depression: a randomized double-blind trial in a Brazilian sample. Rev Bras Psiquiatr. Mar. 2006;28(1):29-32. [pmid: 16612487].
68 Perry PJ, Garvey MJ, Kelly MW, et al. A comparative trial of fluoxetine versus trazodone in outpatients with major depression. J Clin Psychiatry. Aug. 1989;50(8):290-4. [pmid: 2668259].
69 Wheatley DP, van Moffaert M, Timmerman L, et al. Mirtazapine: efficacy and tolerability in comparison with fluoxetine in patients with moderate to severe major depressive disorder. Mirtazapine-Fluoxetine Study Group. J Clin Psychiatry. Jun. 1998;59(6):306-12. [pmid: 9671343].
70 Kiev A, Feiger A. A double-blind comparison of fluvoxamine and paroxetine in the treatment of depressed outpatients. J Clin Psychiatry. Apr. 1997;58(4):146-52. [pmid: 9164424].
71 Rapaport M, Coccaro E, Sheline Y, et al. A comparison of fluvoxamine and fluoxetine in the treatment of major depression. J Clin Psychopharmacol. Oct. 1996;16(5):373-8. [pmid: 8889909].
72 Patris M, Bouchard JM, Bougerol T, et al. Citalopram versus fluoxetine: a double-blind, controlled, multicentre, phase III trial in patients with unipolar major depression treated in general practice. Int Clin Psychopharmacol. Jun. 1996;11(2):129-36. [pmid: 8803650].
73 Baldwin DS, Hawley CJ, Abed RT, et al. A multicenter double-blind comparison of nefazodone and paroxetine in the treatment of outpatients with moderate-to-severe depression. J Clin Psychiatry. Suppl 2. 1996;57:46-52. [pmid: 8626363].
74 Cunningham LA, Borison RL, Carman JS, et al. A comparison of venlafaxine, trazodone, and placebo in major depression. J Clin Psychopharmacol. Apr. 1994;14(2):99-106. [pmid: 8195464].
75 Versiani M, Moreno R, Ramakers-van Moorsel CJ, et al. Comparison of the effects of mirtazapine and fluoxetine in severely depressed patients. CNS Drugs. 2005;19(2):137-46. [pmid: 15697327].
76 Montgomery SA, Huusom AK, Bothmer J. A randomised study comparing escitalopram with venlafaxine XR in primary care patients with major depressive disorder. Neuropsychobiology. 2004;50(1):57-64. [pmid: 15179022].
77 Behnke K, Sogaard J, Martin S, et al. Mirtazapine orally disintegrating tablet versus sertraline: a prospective onset of action study. J Clin Psychopharmacol. Aug. 2003;23(4):358-64. [pmid: 12920411].
78 Dalery J, Honig A. Fluvoxamine versus fluoxetine in major depressive episode: a double-blind randomised comparison. Hum Psychopharmacol. Jul. 2003;18(5):379-84. [pmid: 12858325].
79 Guelfi JD, Ansseau M, Timmerman L, et al. Mirtazapine versus venlafaxine in hospitalized severely depressed patients with melancholic features. J Clin Psychopharmacol. Aug. 2001;21(4):425-31. [pmid: 11476127].
80 Ballus C, Quiros G, De Flores T, et al. The efficacy and tolerability of venlafaxine and paroxetine in outpatients with depressive disorder or dysthymia. Int Clin Psychopharmacol. Jan. 2000;15(1):43-8. [pmid: 10836286].
81 Nemeroff CB, Ninan PT, Ballenger J, et al. Double-blind multicenter comparison of fluvoxamine versus sertraline in the treatment of depressed outpatients. Depression. 1995;3(4):163-9.
82 McPartlin GM, Reynolds A, Anderson C, et al. A comparison of once-daily venlafaxine XR and paroxetine in depressed outpatients treated in general practice. Primary Care Psychiatry. 1998;4(3):127-32.
83 Van Moffaert M, Bartholome F, Cosyns P, et al. A controlled comparison of sertraline and fluoxetine in acute and continuation treatment of major depression. Human Psychopharmacol. 1995;10:393-405.
84 Silverstone PH, Ravindran A. Once-daily venlafaxine extended release (XR) compared with fluoxetine in outpatients with depression and anxiety. Venlafaxine XR 360 Study Group. J Clin Psychiatry. Jan. 1999;60(1):22-8. [pmid: 10074873].
85 Burke WJ, Gergel I, Bose A. Fixed-dose trial of the single isomer SSRI escitalopram in depressed outpatients. J Clin Psychiatry. Apr. 2002;63(4):331-6. [pmid: 12000207].
86 Colonna L, Andersen HF, Reines EH. A randomized, double-blind, 24-week study of escitalopram (10 mg/day) versus citalopram (20 mg/day) in primary care patients with major depressive disorder. Curr Med Res Opin. Oct. 2005;21(10):1659-68. [pmid: 16238906].
87 Lepola UM, Loft H, Reines EH. Escitalopram (10-20 mg/day) is effective and well tolerated in a placebo-controlled study in depression in primary care. Int Clin Psychopharmacol. Jul. 2003;18(4):211-7. [pmid: 12817155].
88 Moore N, Verdoux H, Fantino B. Prospective, multicentre, randomized, double-blind study of the efficacy of escitalopram versus citalopram in outpatient treatment of major depressive disorder. Int Clin Psychopharmacol. May. 2005;20(3):131-7. [pmid: 15812262].
89 FDA Center for Drug Evaluation and Research. Stastical Review of NDA 21-323 (Escitalopram Oxalate). 2001. http://www.fda.gov/cder/foi/nda/2002/21-323.pdf_Lexapro_Statr.pdf.
90 Yevtushenko VY, Belous AI, Yevtushenko YG, et al. Efficacy and tolerability of escitalopram versus citalopram in major depressive disorder: a 6-week, multicenter, prospective, randomized, double-blind, active-controlled study in adult outpatients. Clin Ther. Nov. 2007;29(11):2319-32. [pmid: 18158074].
91 Clerc GE, Ruimy P, Verdeau-Palles J. A double-blind comparison of venlafaxine and fluoxetine in patients hospitalized for major depression and melancholia. The Venlafaxine French Inpatient Study Group. Int Clin Psychopharmacol. Sep. 1994;9(3):139-43. [pmid: 7814822].
92 Costa e Silva J. Randomized, double-blind comparison of venlafaxine and fluoxetine in outpatients with major depression. J Clin Psychiatry. Jul. 1998;59(7):352-7. [pmid: 9714263].
93 Schatzberg A, Roose S. A double-blind, placebo-controlled study of venlafaxine and fluoxetine in geriatric outpatients with major depression. Am J Geriatr Psychiatry. Apr. 2006;14(4):361-70. [pmid: 16582045].
94 Tylee A, Beaumont G, Bowden MW, et al. A double-blind, randomized, 12-week comparison study of the safety and efficacy of venlafaxine and fluoxetine in moderate to severe major depression in general practice. Primary Care Psychiatry. 1997;3(1):51-8.
95 Tzanakaki M, Guazzelli M, Nimatoudis I, et al. Increased remission rates with venlafaxine compared with fluoxetine in hospitalized patients with major depression and melancholia. Int Clin Psychopharmacol. Jan. 2000;15(1):29-34. [pmid: 10836283].
96 Owens MJ, Krulewicz S, Simon JS, et al. Estimates of serotonin and norepinephrine transporter inhibition in depressed patients treated with paroxetine or venlafaxine. Neuropsychopharmacology. Dec. 2008;33(13):3201-12. [pmid: 18418363].
97 Blier P, Gobbi G, Turcotte JE, et al. Mirtazapine and paroxetine in major depression: a comparison of monotherapy versus their combination from treatment initiation. Eur Neuropsychopharmacol. Jul. 2009;19(7):457-65. [pmid: 19345072].
98 Leinonen E, Skarstein J, Behnke K, et al. Efficacy and tolerability of mirtazapine versus citalopram: a double-blind, randomized study in patients with major depressive disorder. Nordic Antidepressant Study Group. Int Clin Psychopharmacol. Nov. 1999;14(6):329-37. [pmid: 10565799].
99 Kavoussi RJ, Segraves RT, Hughes AR, et al. Double-blind comparison of bupropion sustained release and sertraline in depressed outpatients. J Clin Psychiatry. Dec. 1997;58(12):532-7. [pmid: 9448656].
100 Kennedy SH, Fulton KA, Bagby RM, et al. Sexual function during bupropion or paroxetine treatment of major depressive disorder. Can J Psychiatry. Mar. 2006;51(4):234-42. [pmid: 16629348].
101 Rush AJ, Armitage R, Gillin JC, et al. Comparative effects of nefazodone and fluoxetine on sleep in outpatients with major depressive disorder. Biol Psychiatry. Jul. 1. 1998;44(1):3-14. [pmid: 9646878].
102 Beasley CM Jr, Dornseif BE, Pultz JA, et al. Fluoxetine versus trazodone: efficacy and activating-sedating effects. J Clin Psychiatry. Jul. 1991;52(7):294-9. [pmid: 2071559].
103 Allard P, Gram L, Timdahl K, et al. Efficacy and tolerability of venlafaxine in geriatric outpatients with major depression: a double-blind, randomised 6-month comparative trial with citalopram. Int J Geriatr Psychiatry. Dec. 2004;19(12):1123-30. [pmid: 15526307].
104 Schatzberg AF, Kremer C, Rodrigues HE, et al. Double-blind, randomized comparison of mirtazapine and paroxetine in elderly depressed patients. Am J Geriatr Psychiatry. Sep-Oct. 2002;10(5):541-50. [pmid: 12213688].