# Poor-Quality Studies

## Characteristics of Studies with Poor Internal Validity

To assess the quality (internal validity or risk of bias) of studies, we used predefined criteria based on those described in the AHRQ Methods Guide for Comparative Effectiveness Reviews (ratings: good, fair, poor).1 Elements of quality assessment for trials included, among others, the methods used for randomization, allocation concealment, and blinding; the similarity of compared groups at baseline; maintenance of comparable groups; overall and differential loss to follow-up; and the use of intention-to-treat analysis. We assessed observational studies based on the potential for selection bias (methods of selection of subjects and loss to follow-up), potential for measurement bias (equality, validity, and reliability of ascertainment of outcomes), adjustment for potential confounders, and statistical analysis.

In general terms, a “good” study has the least bias and results are considered to be valid. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. The fair-quality category is likely to be broad, so studies with this rating will vary in their strengths and weaknesses. A “poor” rating indicates significant bias (stemming from, e.g., serious errors in design, analysis reporting large amounts of missing information, or discrepancies in reporting) that may invalidate the study's results.

To systematically rate studies, we designed and used a structured data abstraction form. Trained reviewers abstracted data from each study and assigned an initial quality rating. A second reviewer read each abstracted article, evaluated the accuracy, completeness, and consistency of the data abstraction, and independently rated the quality. If differences in quality ratings could not be resolved by discussion, a third senior reviewer was involved. The full research team talked regularly during the article abstraction period to discuss global issues related to the data abstraction process. The following lists all the studies reviewed and rated as poor quality, with their design and primary reasons for the final rating.

Study | Design | Primary Reasons for Poor Quality Rating
Aguglia et al., 1993^2^ | RCT | High LTF
Amini et al., 2005^3^ | RCT | No ITT analysis
Ashman et al., 2009^4^ | RCT | No ITT analysis
Brown, et al., 2005^5^ | RCT | No ITT analysis
Byerley, et al., 1988^6^ | RCT | No ITT analysis
Claghorn, 1992^7^ | RCT | No ITT analysis
Claghorn, et al., 1996^8^ | RCT | High LTF and no ITT analysis
Claghorn and Lesem, 1995^9^ | RCT | High LTF
Clerc et al., 1994^10^ | RCT | High differential attrition
Cohn, et al., 1990^11^ | RCT | No ITT analysis
Cohn and Wilcox, 1992^12^ | RCT | No ITT analysis
Corrigan, et al., 2000^13^ | RCT | High differential attrition
Croft, et al., 2002^14^ | RCT | High LTF
Dube, et al., 2010^15^ | RCT | High LTF
Dunbar, et al., 1993^16^ | RCT | No ITT analysis
Dunbar, et al., 1991^17^ | RCT | High LTF
Elliott, et al., 1998^18^ | RCT | High LTF
Evans, et al., 1997^19^ | RCT | High LTF
Fabre, et al., 1996^20^ | RCT | High LTF
Fabre, 1992^21^ | RCT | High differential attrition
Fabre, et al., 1995^22^ | RCT | High LTF
Fabre and Putman, 1987^23^ | RCT | High LTF
Falk et al., 1989^24^ | RCT | High LTF
Fava, et al., 1997^25^ | RCT | No ITT analysis
Fava, et al., 2005^26^ | RCT | High LTF
Feighner, et al., 1998^27^ | RCT | High LTF
Feighner, 1992^28^ | RCT | High LTF
Feighner;Boyer, 1992^29^ | RCT | High LTF
Feighner, et al., 1993^30^ | RCT | High LTF
Ferrando et al., 1997^31^ | RCT | No ITT analysis
Flament and Lane, 2001^32^ | RCT | No ITT analysis
Garakani et al., 2008^33^ | RCT | No ITT analysis
Gastpar et al., 2006^34^ | RCT | No ITT analysis
Goldstein et al., 2004^35^ | RCT | High LTF
Grigoriadis et al., 2003^36^ | Observational | No ITT analysis
Gülseren et al., 2005^37^ | RCT | No ITT analysis
Hegerl, et al., 2010^38^ | RCT | High attrition
Kasper, et al., 2010^39^ | Pooled analysis | No systematic literature search
Lapierre, et al., 1987^40^ | RCT | No ITT analysis
March, et al., 1990^41^ | RCT | No ITT analysis
McGrath, et al., 2000^42^ | RCT | High differential attrition
Mesters et al., 1993^43^ | RCT | No ITT analysis
Montgomery et al., 2007^44^ Montgomery, et al., 2008^45^ | Systematic Review | Publication bias
Muijen, et al., 1988^46^ | RCT | No ITT analysis
Nyth, et al., 1992^47^ | RCT | No ITT analysis
Oslin et al., 2003^48^ | RCT | High attrition
Petracca, et al., 2001^49^ | RCT | No ITT analysis
Pettinati, et al., 2010^50^ | RCT | High attrition
Ravindran, et al., 1995^51^ | RCT | High attrition
Reimherr, et al., 1998^52^ | RCT | High attrition
Rickels, et al., 1992^53^ | RCT | No ITT analysis
Rickels and Case, 1982^54^ | RCT | No ITT analysis
Rickels, et al., 1994^55^ | RCT | High attrition, no ITT
Roscoe et al., 2005^56^ | RCT | No ITT analysis
Rosenbaum et al., 1998^57^ | Observational | No ITT analysis
Roth, et al., 1990^58^ | RCT | No ITT analysis
Roy-Byrne, et al., 2000^59^ | RCT | High attrition
Rudolph, et al., 1998^60^ | RCT | High attrition
Schmitz et al., 2001^61^ | RCT | High LTF
Schweizer, et al., 1991^62^ | RCT | High attrition
Smith and Glaudin, 1992^63^ | RCT | High attrition
Smith, et al., 1990^64^ | RCT | High attrition
Spielmans, 2008^65^ | Systematic Review | No quality assessment of included studies, lack of clear and comprehensive search strategy
Stahl et al., 2000^66^ | RCT | High attrition
Thase et al., 2001^67^ | Pooled analysis | No systematic literature search
Thase et al., 2006^68^ | RCT | High LTF
Tollefson et al., 1994^69^ Beasley et al., 1991^70^ | Meta-analysis | No systematic literature search
Trkulja, 2010^71^ | RCT | No dual literature review
Vartiainen and Leinonen, 1994^72^ | RCT | High attrition, no ITT
Wade et al., 2003^73^ | RCT | High LTF
Wagner et al., 1998^74^ | RCT | No ITT analysis
Weintraub, et al., 2010^75^ | | High attrition and imputations
Wernicke, et al., 1987^76^ | RCT | No ITT analysis
Winokur et al., 2003^77^ | RCT | No ITT analysis
Zanardi et al., 1996^78^ | RCT | High LTF

ITT, intent to treat analysis; LTF, loss to followup; RCT, randomized controlled trial.

## References

1 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
2 Aguglia E, Casacchia M, Cassano GB, et al. Double-blind study of the efficacy and safety of sertraline versus fluoxetine in major depression. Int Clin Psychopharmacol. Fall. 1993;8(3):197-202. [pmid: 8263318].
3 Amini H, Aghayan S, Jalili SA, et al. Comparison of mirtazapine and fluoxetine in the treatment of major depressive disorder: a double-blind, randomized trial. J Clin Pharm Ther. Apr. 2005;30(2):133-8. [pmid: 15811165].
4 Ashman TA, Cantor JB, Gordon WA, et al. A randomized controlled trial of sertraline for the treatment of depression in persons with traumatic brain injury. Arch Phys Med Rehabil. 2009;90(5):733-40. [pmid: 19406291].
5 Brown ES, Vigil L, Khan DA, et al. A randomized trial of citalopram versus placebo in outpatients with asthma and major depressive disorder: a proof of concept study. Biol Psychiatry. Dec. 1. 2005;58(11):865-70. [pmid: 15993860].
6 Byerley WF, Reimherr FW, Wood DR, et al. Fluoxetine, a selective serotonin uptake inhibitor, for the treatment of outpatients with major depression. J Clin Psychopharmacol. Apr. 1988;8(2):112-5. [pmid: 3286684].
7 Claghorn JL. The safety and efficacy of paroxetine compared with placebo in a double-blind trial of depressed outpatients. J Clin Psychiatry. Feb. 1992;53(Suppl):33-5. [pmid: 1531821].
8 Claghorn JL, Earl CQ, Walczak DD, et al. Fluvoxamine maleate in the treatment of depression: a single-center, double-blind, placebo-controlled comparison with imipramine in outpatients. J Clin Psychopharmacol. Apr. 1996;16(2):113-20. [pmid: 8690826].
9 Claghorn JL, Lesem MD. A double-blind placebo-controlled study of Org 3770 in depressed outpatients. J Affect Disord. Jun. 8. 1995;34(3):165-71. [pmid: 7560544].
10 Clerc GE, Ruimy P, Verdeau-Palles J. A double-blind comparison of venlafaxine and fluoxetine in patients hospitalized for major depression and melancholia. The Venlafaxine French Inpatient Study Group. Int Clin Psychopharmacol. Sep. 1994;9(3):139-43. [pmid: 7814822].
11 Cohn JB, Crowder JE, Wilcox CS, et al. A placebo- and imipramine-controlled study of paroxetine. Psychopharmacol Bull. 1990;26(2):185-9. [pmid: 2146697].
12 Cohn JB, Wilcox CS. Paroxetine in major depression: a double-blind trial with imipramine and placebo. J Clin Psychiatry. Feb. 1992;53(Suppl):52-6. [pmid: 1531826].
13 Corrigan MH, Denahan AQ, Wright CE, et al. Comparison of pramipexole, fluoxetine, and placebo in patients with major depression. Depress Anxiety. 2000;11(2):58-65. [pmid: 10812530].
14 Croft H, Houser TL, Jamerson BD, et al. Effect on body weight of bupropion sustained-release in patients with major depression treated for 52 weeks. Clin Ther. Apr. 2002;24(4):662-72. [pmid: 12017410].
15 Dube S, Dellva MA, Jones M, et al. A study of the effects of LY2216684, a selective norepinephrine reuptake inhibitor, in the treatment of major depression. J Psychiatr Res. 2010;44(6):356-63. [pmid: 19909980].
16 Dunbar GC, Claghorn JL, Kiev A, et al. A comparison of paroxetine and placebo in depressed outpatients. Acta Psychiatr Scand. May. 1993;87(5):302-5. [pmid: 8517168].
17 Dunbar GC, Cohn JB, Fabre LF, et al. A comparison of paroxetine, imipramine and placebo in depressed out-patients. Br J Psychiatry. Sep. 1991;159:394-8. [pmid: 1835664].
18 Elliott AJ, Uldall KK, Bergam K, et al. Randomized, placebo-controlled trial of paroxetine versus imipramine in depressed HIV-positive outpatients. Am J Psychiatry. Mar. 1998;155(3):367-72. [pmid: 9501747].
19 Evans M, Hammond M, Wilson K, et al. Placebo-controlled treatment trial of depression in elderly physically ill patients. Int J Geriatr Psychiatry. Aug. 1997;12(8):817-24. [pmid: 9283926].
20 Fabre L, Birkhimer LJ, Zaborny BA, et al. Fluvoxamine versus imipramine and placebo: a double-blind comparison in depressed patients. Int Clin Psychopharmacol. Jun. 1996;11(2):119-27. [pmid: 8803649].
21 Fabre LF. A 6-week, double-blind trial of paroxetine, imipramine, and placebo in depressed outpatients. J Clin Psychiatry. Feb. 1992;53(Suppl):40-3. [pmid: 1531823].
22 Fabre LF, Abuzzahab FS, Amin M, et al. Sertraline safety and efficacy in major depression: a double-blind fixed-dose comparison with placebo. Biol Psychiatry. Nov. 1. 1995;38(9):592-602. [pmid: 8573661].
23 Fabre LF, Putman HP 3rd. A fixed-dose clinical trial of fluoxetine in outpatients with major depression. J Clin Psychiatry. Oct. 1987;48(10):406-8. [pmid: 3312176].
24 Falk WE, Rosenbaum JF, Otto MW, et al. Fluoxetine versus trazodone in depressed geriatric patients. J Geriatr Psychiatry Neurol. Oct-Dec. 1989;2(4):208-14. [pmid: 2699556].
25 Fava M, Mulroy R, Alpert J, et al. Emergence of adverse events following discontinuation of treatment with extended-release venlafaxine. Am J Psychiatry. Dec. 1997;154(12):1760-2. [pmid: 9396960].
26 Fava M, Alpert J, Nierenberg AA, et al. A Double-blind, randomized trial of St John's wort, fluoxetine, and placebo in major depressive disorder. J Clin Psychopharmacol. Oct. 2005;25(5):441-7. [pmid: 16160619].
27 Feighner J, Targum SD, Bennett ME, et al. A double-blind, placebo-controlled trial of nefazodone in the treatment of patients hospitalized for major depression. J Clin Psychiatry. May. 1998;59(5):246-53. [pmid: 9632036].
28 Feighner JP. A double-blind comparison of paroxetine, imipramine and placebo in depressed outpatients. Int Clin Psychopharmacol. Jun. Suppl 4. 1992;6:31-5. [pmid: 1431008].
29 Feighner JP, Boyer WF. Paroxetine in the treatment of depression: a comparison with imipramine and placebo. J Clin Psychiatry. Feb. 1992;53(Suppl):44-7. [pmid: 1531824].
30 Feighner JP, Cohn JB, Fabre LF Jr, et al. A study comparing paroxetine placebo and imipramine in depressed patients. J Affect Disord. Jun. 1993;28(2):71-9. [pmid: 8354771].
31 Ferrando SJ, Goldman JD, Charness WE. Selective serotonin reuptake inhibitor treatment of depression in symptomatic HIV infection and AIDS. Improvements in affective and somatic symptoms. Gen Hosp Psychiatry. Mar. 1997;19(2):89-97. [pmid: 9097063].
32 Flament MF, Lane R. Acute antidepressant response to fluoxetine and sertraline in psychiatric outpatients with psychomotor agitation. International Journal of Psychiatry in Clinical Practice. 2001;5(2):103-9.
33 Garakani A, Martinez JM, Marcus S, et al. A randomized, double-blind, and placebo-controlled trial of quetiapine augmentation of fluoxetine in major depressive disorder. Int Clin Psychopharmacol. 2008;23(5):269-75. [pmid: 18703936].
34 Gastpar M, Singer A, Zeller K. Comparative efficacy and safety of a once-daily dosage of hypericum extract STW3-VI and citalopram in patients with moderate depression: a double-blind, randomised, multicentre, placebo-controlled study. Pharmacopsychiatry. 2006;39(2):66-75. [pmid: 16555167].
35 Goldstein DJ, Lu Y, Detke MJ, et al. Duloxetine in the treatment of depression: a double-blind placebo-controlled comparison with paroxetine. J Clin Psychopharmacol. Aug. 2004;24(4):389-99. [pmid: 15232330].
36 Grigoriadis S, Kennedy SH, Bagby RM. A comparison of antidepressant response in younger and older women. J Clin Psychopharmacol. Aug. 2003;23(4):405-7. [pmid: 12920418].
37 Gulseren L, Gulseren S, Hekimsoy Z, et al. Comparison of fluoxetine and paroxetine in type II diabetes mellitus patients. Arch Med Res. Mar-Apr. 2005;36(2):159-65. [pmid: 15847950].
38 Hegerl U, Hautzinger M, Mergl R, et al. Effects of pharmacotherapy and psychotherapy in depressed primary-care patients: A randomized, controlled trial including a patients' choice arm. International Journal of Neuropsychopharmacology. 2010;13(1):31-44. [pmid: 19341510].
39 Kasper S, Montgomery SA, Moller HJ, et al. Longitudinal analysis of the suicidal behaviour risk in short-term placebo-controlled studies of mirtazapine in major depressive disorder. World J Biol Psychiatry. 2010;11(1):36-44. [pmid: 20146649].
40 Lapierre YD, Browne M, Horn E, et al. Treatment of major affective disorder with fluvoxamine. J Clin Psychiatry. Feb. 1987;48(2):65-8. [pmid: 3100510].
41 March JS, Kobak KA, Jefferson JW, et al. A double-blind, placebo-controlled trial of fluvoxamine versus imipramine in outpatients with major depression. J Clin Psychiatry. May. 1990;51(5):200-2. [pmid: 2110560].
42 McGrath PJ, Stewart JW, Janal MN, et al. A placebo-controlled study of fluoxetine versus imipramine in the acute treatment of atypical depression. Am J Psychiatry. Mar. 2000;157(3):344-50. [pmid: 10698808].
43 Mesters P, Cosyns P, Dejaiffe G, et al. Assessment of quality of life in the treatment of major depressive disorder with fluoxetine, 20 mg, in ambulatory patients aged over 60 years. Int Clin Psychopharmacol. Winter. 1993;8(4):337-40. [pmid: 8277160].
44 Montgomery SA, Baldwin DS, Blier P, et al. Which antidepressants have demonstrated superior efficacy? A review of the evidence. International Clinical Psychopharmacology. 2007;22(6):323-9. [pmid: 17917550].
45 Montgomery SA, Baldwin DS, Blier P, et al. Which antidepressants have demonstrated superior efficacy? A review of the evidence: Erratum. International Clinical Psychopharmacology. 2008;23(1):61.
46 Muijen M, Roy D, Silverstone T, et al. A comparative clinical trial of fluoxetine, mianserin and placebo in depressed outpatients. Acta Psychiatr Scand. Sep. 1988;78(3):384-90. [pmid: 3057817].
47 Nyth AL, Gottfries CG, Lyby K, et al. A controlled multicenter clinical study of citalopram and placebo in elderly depressed patients with and without concomitant dementia. Acta Psychiatr Scand. Aug. 1992;86(2):138-45. [pmid: 1529737].
48 Oslin DW, Ten Have TR, Streim JE, et al. Probing the safety of medications in the frail elderly: evidence from a randomized clinical trial of sertraline and venlafaxine in depressed nursing home residents. J Clin Psychiatry. Aug. 2003;64(8):875-82. [pmid: 12927001].
49 Petracca GM, Chemerinski E, Starkstein SE. A double-blind, placebo-controlled study of fluoxetine in depressed patients with Alzheimer's disease. Int Psychogeriatr. Jun. 2001;13(2):233-40. [pmid: 11495397].
50 Pettinati HM, Oslin DW, Kampman KM, et al. A double-blind, placebo-controlled trial combining sertraline and naltrexone for treating co-occurring depression and alcohol dependence. Am J Psychiatry. 2010;167(6):668-75. [pmid: 20231324].
51 Ravindran AV, Teehan MD, Bakish D, et al. The impact of sertraline, desipramine, and placebo on psychomotor functioning in depression. Hum Psychopharmacol. 1995;10(4):273-81.
52 Reimherr FW, Cunningham LA, Batey SR, et al. A multicenter evaluation of the efficacy and safety of 150 and 300 mg/d sustained-release bupropion tablets versus placebo in depressed outpatients. Clin Ther. May-Jun. 1998;20(3):505-16. [pmid: 9663366].
53 Rickels K, Amsterdam J, Clary C, et al. The efficacy and safety of paroxetine compared with placebo in outpatients with major depression. J Clin Psychiatry. Feb. 1992;53(Suppl):30-2. [pmid: 1531820].
54 Rickels K, Case WG. Trazodone in depressed outpatients. Am J Psychiatry. Jun. 1982;139(6):803-6. [pmid: 7044154].
55 Rickels K, Schweizer E, Clary C, et al. Nefazodone and imipramine in major depression: a placebo-controlled trial. Br J Psychiatry. Jun. 1994;164(6):802-5. [pmid: 7952987].
56 Roscoe JA, Morrow GR, Hickok JT, et al. Effect of paroxetine hydrochloride (Paxil) on fatigue and depression in breast cancer patients receiving chemotherapy. Breast Cancer Res Treat. Feb. 2005;89(3):243-9. [pmid: 15754122].
57 Rosenbaum JF, Fava M, Hoog SL, et al. Selective serotonin reuptake inhibitor discontinuation syndrome: a randomized clinical trial. Biol Psychiatry. Jul. 15. 1998;44(2):77-87. [pmid: 9646889].
58 Roth D, Mattes J, Sheehan KH, et al. A double-blind comparison of fluvoxamine, desipramine and placebo in outpatients with depression. Prog Neuropsychopharmacol Biol Psychiatry. 1990;14(6):929-39. [pmid: 2126144].
59 Roy-Byrne PP, Pages KP, Russo JE, et al. Nefazodone treatment of major depression in alcohol-dependent patients: a double-blind, placebo-controlled trial. J Clin Psychopharmacol. Apr. 2000;20(2):129-36. [pmid: 10770449].
60 Rudolph RL, Fabre LF, Feighner JP, et al. A randomized, placebo-controlled, dose-response trial of venlafaxine hydrochloride in the treatment of major depression. J Clin Psychiatry. Mar. 1998;59(3):116-22. [pmid: 9541154].
61 Schmitz JM, Averill P, Stotts AL, et al. Fluoxetine treatment of cocaine-dependent patients with major depressive disorder. Drug Alcohol Depend. Aug. 1. 2001;63(3):207-14. [pmid: 11418225].
62 Schweizer E, Weise C, Clary C, et al. Placebo-controlled trial of venlafaxine for the treatment of major depression. J Clin Psychopharmacol. Aug. 1991;11(4):233-6. [pmid: 1918421].
63 Smith WT, Glaudin V. A placebo-controlled trial of paroxetine in the treatment of major depression. J Clin Psychiatry. Feb. 1992;53(Suppl):36-9. [pmid: 1531822].
64 Smith WT, Glaudin V, Panagides J, et al. Mirtazapine vs. amitriptyline vs. placebo in the treatment of major depressive disorder. Psychopharmacol Bull. 1990;26(2):191-6. [pmid: 2236455].
65 Spielmans GI. Duloxetine does not relieve painful physical symptoms in depression: a meta-analysis. Psychother Psychosom. 2008;77(1):12-6. [pmid: 18087203].
66 Stahl SM. Placebo-controlled comparison of the selective serotonin reuptake inhibitors citalopram and sertraline. Biol Psychiatry. Nov. 1. 2000;48(9):894-901. [pmid: 11074227].
67 Thase ME, Entsuah AR, Rudolph RL. Remission rates during treatment with venlafaxine or selective serotonin reuptake inhibitors. Br J Psychiatry. Mar. 2001;178:234-41. [pmid: 11230034].
68 Thase ME, Clayton AH, Haight BR, et al. A double-blind comparison between bupropion XL and venlafaxine XR: sexual functioning, antidepressant efficacy, and tolerability. J Clin Psychopharmacol. 2006;26(5):482-8. [pmid: 16974189].
69 Tollefson GD, Rampey AH Jr, Beasley CM Jr, et al. Absence of a relationship between adverse events and suicidality during pharmacotherapy for depression. J Clin Psychopharmacol. Jun. 1994;14(3):163-9. [pmid: 8027412].
70 Beasley CM Jr, Dornseif BE, Bosomworth JC, et al. Fluoxetine and suicide: a meta-analysis of controlled trials of treatment for depression. Bmj. Sep. 21. 1991;303(6804):685-92. [pmid: 1833012].
71 Trkulja V. Is escitalopram really relevantly superior to citalopram in treatment of major depressive disorder? A meta-analysis of head-to-head randomized trials. Croat Med J. 2010;51(1):61-73. [pmid: 20162747].
72 Vartiainen H, Leinonen E. Double-blind study of mirtazapine and placebo in hospitalized patients with major depression. Eur Neuropsychopharmacol. Jun. 1994;4(2):145-50. [pmid: 7919944].
73 Wade A, Crawford GM, Angus M, et al. A randomized, double-blind, 24-week study comparing the efficacy and tolerability of mirtazapine and paroxetine in depressed patients in primary care. Int Clin Psychopharmacol. May. 2003;18(3):133-41. [pmid: 12702891].
74 Wagner GJ, Maguen S, Rabkin JG. Ethnic differences in response to fluoxetine in a controlled trial with depressed HIV-positive patients. Psychiatr Serv. Feb. 1998;49(2):239-40. [pmid: 9575014].
75 Weintraub D, Rosenberg PB, Drye LT, et al. Sertraline for the treatment of depression in alzheimer disease: Week-24 outcomes. American Journal of Geriatric Psychiatry. 2010;18(4):332-40. [pmid: 20220589].
76 Wernicke JF, Dunlop SR, Dornseif BE, et al. Fixed-dose fluoxetine therapy for depression. Psychopharmacol Bull. 1987;23(1):164-8. [pmid: 3496625].
77 Winokur A, DeMartinis NA 3rd, McNally DP, et al. Comparative effects of mirtazapine and fluoxetine on sleep physiology measures in patients with major depression and insomnia. J Clin Psychiatry. Oct. 2003;64(10):1224-9. [pmid: 14658972].
78 Zanardi R, Franchini L, Gasperini M, et al. Double-blind controlled trial of sertraline versus paroxetine in the treatment of delusional depression. Am J Psychiatry. Dec. 1996;153(12):1631-3. [pmid: 8942464].