# Evidence Tables

## INDEX FOR THE EVIDENCE TABLES

In this Appendix, we present two Evidence Tables:

Evidence Table 1 Randomized controlled trials and observational studies

Evidence Table 2 Systematic evidence reviews and meta-analyses

Within each of the Evidence Tables, the studies are presented in alphabetical order by first author. When more than one article is cited, the main article is cited first, followed by the subsequent published articles or subgroup analyses.

Below we provide an index for each study included as evidence for each Key Question, including a note of when a particular citation is located under the main article for that particular study in the Evidence Table. A glossary for the Evidence Tables follows.

### Key Question 1 Studies

Aberg-Wistedt et al., 2000^1^

Allard et al., 2004^2^

Alves, Cachola and Brandao, 1999^3^

Baldwin et al., 1996^4^

Baldwin et al., 2006^5^

Ballus et al., 2000^6^

Barrett et al., 2001^7^

Beasley et al., 1991^8^

Behnke et al., 2003^9^

Benkert et al., 2000^10^

Benkert et al., 2006^11^

Bennie et al., 1995^12^

Bielski et al., 2004^13^

Blier et al., 2009^14^

Boulenger et al., 2006^15^

Boyer et al., 1998^16^

Burke et al., 2002^17^

Cassano et al., 2002^18^

Chouinard et al., 1999^19^

Coleman et al., 1999^20^

Coleman et al., 2001^21^

Colonna et al., 2005^22^

Costa e Silva, 1998^23^

Croft et al., 1999^24^

Cunningham, 1997 25

Cunningham et al., 1994^26^

Dalery and Honig, 2003^27^

De Nayer et al., 2002^28^

De Wilde et al., 1993^29^

Detke et al., 2004^30^

Devanand et al., 2005^31^

Dierick et al., 1996^32^

Ekselius et al., 1997^33^

Fava et al., 1998^34^

Fava et al., 2002^35^

FDA Center for Drug Evaluation and Research, 2001^36^

Feiger et al., 1996^37^

Feighner et al., 1991^38^

Finkel, 1999 39 Found under Newhouse 2000^40^

Gagiano, 1993^41^

Gillin et al., 1997^42^

Golden et al., 2002^43^

Goldstein et al., 2002^44^

Guelfi et al., 2001^45^

Haffmans et al., 1996^46^

Halikas 1995^47^

Hewett et al., 2009^48^

Hewett et al., 2010^49^

Hicks et al., 2002^50^

Hong et al., 2003^51^

Judd et al., 2004^52^

Kasper et al., 2005^53^

Kasper et al., 2005^54^

Kavoussi et al., 1997^55^

Kennedy et al., 2006^56^

Khan et al., 2007^57^

Kiev and Feiger, 1997^58^

Kocsis et al., 1997^59^ Found under Thase 1996^60^

Lee et al., 2007^61^

Leinonen et al., 1999^62^

Lepola et al., 2003^63^

Mao et al., 2008^64^

McPartlin et al., 1998^65^

Mehtonen et al., 2000^66^

Montgomery et al., 2004^67^

Moore et al., 2005^68^

Munizza et al., 2006^69^

Nemeroff et al., 1995^70^

Nemeroff and Thase, 2007^71^

Newhouse et al., 2000^40^

Nierenberg et al., 2007^72^

Owens et al., 2008^73^

Patris et al., 1996^74^

Perahia et al., 2006^75^

Perry et al., 1989^76^

Rapaport et al., 1996^77^

Rapaport et al., 2003^78^

Ravindran et al., 2000^79^

Rossini et al., 2005^80^

Rudolph and Feiger, 1999^81^

Rush et al., 2001^82^ Found under Kavoussi 1997^55^

Schatzberg et al., 2002^83^

Schmidt et al., 2000^84^

Schone and Ludwig, 1993^85^

Sechter et al., 1999^86^

Shelton et al., 2006^87^

Silverstone and Ravindran, 1999^88^

Sir et al., 2005^89^

Thase et al., 1996^60^

Tignol, 1993^90^

Tourian et al., 2009^91^

Tylee et al., 1997^92^

Tzanakaki et al., 2000^93^

Ushiroyama et al., 2004 94

Van Moffaert et al., 1995^95^

van Moffaert et al., 1995^96^

Vanelle et al., 1997^97^

Ventura et al., 2007^98^

Versiani et al., 2005^99^

Wade et al., 2007^100^

Weihs et al., 2000^101^

Weisler et al., 1994^102^

Wheatley et al., 1998^103^

Williams et al., 2000^104^

Yevtushenko et al., 2007^105^

### Key Question 2 Studies

Baldomero et al., 2005^106^

Baldwin et al., 2006^5^

Claghorn and Feighner, 1993^107^

Corya et al., 2006^108^

Cunningham et al., 1994^26^

Dinan, 2001^109^ Found under Schmidt 2000^84^

Doogan and Caillard, 1992^110^

Fang,et al., 2010^111^

Fava, 2009^112^ Found under Kocsis 2007^113^

Fava et al., 2006^114^ Found under Perahia115

Feiger et al., 1999^116^

Franchini et al., 1997^117^

Franchini et al., 2000^118^ Found under Franchini 1997^117^

Gelenberg et al., 2003^119^

Gilaberte et al., 2001^120^

Gorwood et al., 2007^121^

Hochstrasser et al., 2001^122^

Kamijima et al., 2006^123^

Keller, 2007^124^ Found under Kocsis 2007^113^

Keller et al., 1998^125^

Keller et al., 2007^126^ Found under Kocsis 2007^113^

Klysner et al., 2002^127^

Kocsis et al., 2002^128^ Found under Keller 1998^125^

Kocsis et al., 2007^113^

Kornstein et al., 2006^129^

Kornstein et al., 2008^130^ Found under Kocsis 2007^113^

Kornstein 2008^131^ Found under Kocsis 2007^113^

Lenox-Smith and Jiang, 2008^132^

Lepine et al., 2004^133^

Lin et al., 2008^134^

Lustman et al., 2006^135^

McGrath et al., 2006^136^

Michelson et al., 1999^137^

Montgomery et al., 2004^138^

Montgomery and Dunbar, 1993^139^

Montgomery and Rasmussen, 1992^140^

Perahia et al., 2006^115^

Perahia et al., 2009^141^

Poirier and Boyer, 1999^142^

Rapaport et al., 2004^143^

Reimherr et al., 1998^144^

Reynolds et al., 2006^145^

Rickels et al., 2010^146^

Robert and Montgomery, 1995^147^

Rush et al., 2006^148^

Rush et al., 2006^149^ Found under Rush 2006^148^

Schmidt et al., 2000^84^

Schmidt et al., 2002^150^ Found under Schmidt 2000^84^

Simon et al., 2004^151^

Soares et al., 2010^152^

Terra and Montgomery, 1998^153^

Thase et al., 2010 154 Found under Kocsis 2007^113^

Thase et al., 2001^155^

Trivedi et al., 2006^156^ Found under Rush 2006^148^

Van Moffaert et al., 1995^95^

Weihs et al., 2002^157^

Wilson et al., 2003^158^

### Key Question 3 Studies

Baldwin et al., 1996^4^

Beasley et al., 1991^8^

Boulenger et al., 2010^159^ Found under Boulenger 2006^15^

Brannan et al., 2005^160^

Brecht et al., 2007^161^

Chouinard et al., 1999^19^

Cunningham et al., 1994^26^

DeNayer et al., 2002^28^

Detke et al., 2002^162^

Detke et al., 2002^163^

Detke et al., 2004^30^

Fava et al., 2000^164^

Fava et al., 2002^35^

Fava et al., 2006^114^

Flament et al., 1999^165^

Gillen et al., 1997^42^

Jefferson et al., 2006^166^

Khan et al., 1998^167^

Krebs et al., 2008^168^ See Evidence Table 2

Leinonen et al., 1999^62^

Mao et al., 2008^64^

McCall et al., 2010^169^

Raskin et al., 2008^170^ Found under Raskin 2007^171^

Raskin et al., 2007^171^

Rush et al., 2001^82^ Found under Kavoussi, 1997^55^

Silverstone and Ravindran, 1999^88^

Silverstone and Salinas, 2001^172^ Found under Silverstone and Ravindran, 1999^88^

Tzanakaki et al., 2000^93^

Versiani et al., 2005^99^

### Key Question 4 Studies

Aberg-Wistedt et al., 2000^1^

Andersohn et al., 2009^173^

Aursnes et al. 2005^174^ See Evidence Table 2

Baldwin et al., 2006^5^

Barbui et al., 2009^175^ See Evidence Table 2

Behnke et al., 2003^9^

Benkert et al., 2006^11^

Benkert, Szegedi, and Kohnen, 2000^10^

Blier et al., 2009^14^

Boulenger et al., 2006^15^

Brambilla et al., 2005^176^ See Evidence Table 2

Buckley and McManus, 2002^177^

Cipriani et al., 2010^178^ See Evidence Table 2

Claxton et al., 2000^179^

Clayton et al., 2002^180^

Clayton et al., 2006^181^

Clayton et al., 2007^182^

Coleman et al., 1999^20^

Coleman et al., 2001^21^

Croft et al., 1999^24^

CSM Expert Working Group, 2004^183^

Cunningham, 1997^25^

Delgado et al., 2005^184^

Didham et al., 2005^185^

Dunner et al., 1998^186^

Ekselius et al., 1997^33^

Ekselius and von Knorring, 2001^187^ Found under Ekselius 1997^33^

Fava et al., 1998^34^

Fava et al., 2002^35^

Fava et al., 2000^188^

Feiger et al., 1996^37^

Feighner et al., 1991^38^

Ferguson et al., 2001^189^

Fergusson et al., 2005^190^ See Evidence Table 2

Gibbons et al., 2007^191^

Golden et al., 2002^43^

Goldstein et al.,1997^192^

Greist et al., 2004^193^ See Evidence Table 2

Guelfi et al., 2001^45^

Gunnell, Saperia, and Ashby, 2005^194^ See Evidence Table 2

Haffmans, Timmerman, and Hoogduin, 1996^46^

Halikas, 1995^47^

Hewett et al., 2009^48^

Hong et al., 2003^51^

Jick et al., 1992^195^

Jick et al., 1995^196^

Jick et al., 2004^197^

Johnston et al., 1991^198^

Judge et al., 2002^199^

Kasper et al., 2009^200^ See Evidence Table 2

Kavoussi et al., 1997^55^

Kennedy et al., 2000^201^

Kennedy et al., 2006^56^

Khan et al., 2003^202^ See Evidence Table 2

Khan et al., 2007^57^

Lee et al., 2007 61

Lopez-Iibor 1993^203^

Mackay et al., 1997^204^

Mackay et al., 1999^205^

Mackay et al., 1999^206^

Mao et al., 2008^64^

Martinez et al., 2005^207^

Martinez et al., 2010^208^

Meijer et al., 2002^209^

Michelson et al., 1999^137^

Montejo et al., 2001^210^

Montgomery and Andersen, 2006^211^

Munizza et al., 2006^69^

Nemeroff et al., 1995^70^

Nemeroff and Thase, 2007^71^

Nierenberg et al., 2007^72^

Nieuwstraten and Dolovich, 2001^212^ See Evidence Table 2

Olfson and Marcus, 2008^213^

Pedersen, 2005^214^ See Evidence Table 2

Perahia et al., 2005^215^ See Evidence Table 2

Perahia et al., 2006^75^

Philipp et al., 2000^216^

Rahme et al., 2008^217^

Rapaport et al., 1996^77^

Rapaport et al., 2003^78^

Reimherr et al., 1998^144^

Rush et al., 2001^82^ Found under Kavoussi 1997^55^

Schatzberg et al., 2002^83^

Schmidt et al., 2000^84^

Schneeweiss et al., 2010^218^

Segraves et al., 2000^219^ Found under Kavoussi et al., 1997^55^

Shelton et al., 2006^87^

Simon et al., 2006^220^

Stang et al., 2007^221^

Thapa et al., 1998^222^

Tourian et al., 2009^91^

Vanderburg et al., 2009^223^ See Evidence Table 2

Ventura et al., 2007^98^

Versiani et al., 2005^99^

Vestergaard et al., 2008^224^ See Evidence Table 2

Weihs et al., 2000^101^

Weisler et al., 1994^102^

Wheatley et al., 1998^103^

Whyte et al., 2003^225^

Wise et al., 2006^226^ See Evidence Table 2

Yevtushenko et al., 2007^105^

Zajecka et al., 1998^227^

### Key Question 5 Studies

Aberg-Wistedt et al., 2000^1^

Allard et al., 2004^2^

Andersen et al., 1994^228^

Barrett et al., 2001^7^

Bush et al., 2005^229^ See Evidence Table 2

Cassano et al., 2002^18^

Devanand et al., 2005^31^

Doraiswamy, 2001 230 Found under Weihs 2000^101^

Echeverry, et al., 2009^231^

Ehde et al., 2008^232^

Finkel et al., 1999^39^ Found under Newhouse 2000^40^

Geretsegger et al., 1994^233^ Found under Schone 1993^85^

Glassman et al., 2002^234^

Gorwood et al., 2007^121^

Gual et al., 2003^235^

Halikas et al., 1995^47^

Hernandez-Avila, et al., 2004^236^

Honig et al., 2007^237^

Kasper et al., 2005^53^

Kennedy et al., 2006^56^

Kranzler et al., 2006^238^

Lesperance et al., 2007^239^

Li et al., 2008^240^

Lustman et al., 2006^135^

Lyketsos et al., 2003^241^

Moak et al., 2003^242^

Murray et al., 2005^243^

Newhouse et al., 2000^244^

O'Connor et al., 2010^245^

Petrakis et al., 1998^246^

Rabkin et al., 2004^247^

Rapaport et al., 2003^78^

Rosenberg et al., 2010^248^

Rossini et al., 2005^80^

Schatzberg et al., 2002^83^

Schatzberg and Roose, 2006^249^

Schone and Ludwig, 1993^85^

Silverstone and Salinas, 2001^172^ Found under Silverstone and Ravindran 1999^172^

Strik et al., 2000^250^

Weihs et al., 2000^101^

Williams et al., 2000^104^

Wilson et al., 2003^158^

Wohlreich et al., 2009^251^ Found under Raskin, 2007^171^

## GLOSSARY

A/S: Aktieselskap (Company type in Denmark)
AD: antidepressant
AE: adverse event
AG: (Pharma AG)
AGECAT: computerised diagnostic system for use with the Geriatric Mental State
AIDS: acquired immune deficiency syndrome
AMT: awake and moving time
ARV: antiretroviral
ASEX: acute phase treatment-emergent dysfunction
ATVI: aortic time velocity interval
BDI: Beck Depression Inventory
BMI: body mass index
BP: blood pressure
BPI: Brief Pain Inventory
BPI-SF: Brief Pain Inventory-Short Form
bpm: beats per minute
BQOL: Battelle Quality of Life Measure
BSI: Brief Symptom Inventory of Depression
BUP SR: bupropion sustained release
BUP: bupropion
CAD: coronary artery disease
CBT: cognitive-behavioral therapy
CDC: Centers for Disease Control and Prevention
CDIS: Computerized Diagnostic Interview Survey
CES-D: Center for Epidemiologic Studies-Depression
CGI: Clinical Global Impressions
CGI–I: Clinical Global Impressions Improvement Scale
CGI–S: Clinical Global Impressions Severity Scale
CI: confidence interval
CIHR: Canadian Institutes of Health Research
CIT: citalopram
cm: centimeter
CR: controlled release
CSDD: Cornell Scale for Depression in Dementia
CSFQ: Changes in Sexual Functioning Questionnaire
CYP450: cytochrome P450
D: drug
DBP: diastolic blood pressure
DEAE(s): discontinuation-emergent adverse events
DES: desvenlafaxine
DESS: Discontinuation-Emergent Signs and Symptoms checklist
df: degrees of freedom
diff: difference(s)
DLRF: Daily Living and Role Functioning (health related quality of life measure on Q-LES-Q)
DSM: Diagnostic and Statistical Manual of Mental Disorders
DSM-III: Diagnostic and Statistical Manual of Mental Disorders, version III
DSM-III-R: Diagnostic and Statistical Manual of Mental Disorders, version III revised
DSM–IV: Diagnostic and Statistical Manual of Mental Disorders, version IV
DSP: deliberate self-poisoning
DUL: duloxetine
ECG: electrocardiogram
ECT: electroconvulsive therapy
EEG: electroencephalogram
ER: extended release
ESC: escitalopram
ESZ: eszopiclone
FDA: Food and Drug Administration
FEWP: Free and Easy Wanderer Plus
FLUOX: fluoxetine
FLUV: fluvoxamine
FOT: final on-therapy
FSQ: Functional Status Questionnaire
FX: Function
GAD: Generalized Anxiety Disorder
GAF: Global Assessment of Functioning
GBS: Gottfrey-Brane-Steen scale
GDS: Geriatric Depression Scale
GHC: group health cooperative
GLF: general life functioning
GmBH: company with limited liability in Germany
GP: general physician
GPRD: General Practice Research Database
GSI: General Symptomatic Index
HAD: Hospital Anxiety and Depression Scale
HAM–A: Hamilton Rating Scale for Anxiety
HAM–D: Hamilton Rating Scale for Depression
HAM-D-17: Hamilton Rating Scale for Depression (17 item)
HAM-D-21: Hamilton Rating Scale for Depression (21 item)
HAM-D24: Hamilton Rating Scale for Depression (24 item)
HCAb: hepatitis C surface antibody
HF: heart failure
HgA1C: glycosylated hemoglobin
HIV: Human immunodeficiency virus
HR: Hazard Ratio
HSCL-D: Hopkins Depression Scale
HTN: hypertension
ICD10: International Classification of Diseases – 10^th^ revision
ICD-9 CM: International Classification for Diseases – 9th revision Clinical Modification
IDS: Inventory for Depressive Symptomatology
IDS-C: Inventory for Depressive Symptomatology - Clinician Rated
IDS-IVR: Inventory of Depressive Symptomatology - Self Report
IDS-SR: Inventory for Depressive Symptomatology - Self Report
IMI: imipramine
Inc: Incorporated
IPT: Interpersonal psychotherapy
IR SD-F: Investigator Rated Sexual Desire and Functioning Scale
IR: immediate release
ITT: intent to treat
kg: kilogram
KQ: key question
LOCF: last-observation-carried-forward
LTF: loss to follow-up
mADCS-CGIC: modified Alzheimer's Disease Cooperative Study-Clinical Global Impression of Change
MADRS: Montgomery Asberg Depression Rating Scale
MAF: Multidimensional
MAOI: monoamine oxidase inhibitor
m-CPP: meta-chlorophenylpiperazine
MD: medical doctor
MDD: major depressive disorder
MDE: major depressive episode
MEI: Motivation and Energy Inventory
MFIS: Modified Fatigue Impact Scale
mg: milligram
mg/d: milligram per day
MHRA: Medicine and Healthcare Regulatory Agency
MI: myocardial infarction
mil: milnacipran
MINI: Mini International Neuropsychiatric Interview
MIR: mirtazapine
mmHG: millimeters of mercury
MMRM: mixed-effect model repeated measures
MMSE: Mini Mental State Examination
mo(s): month(s)
MRI: Magnetic Resonance Imaging
MS: multiple sclerosis
N: number
N/A: not applicable
NEF: nefazodone
NIH: National Institute of Health
NIHM: Health Diagnostic Interview Schedule
NIMH: National Institute of Mental Health
NNH: number needed to harm
NNT: number needed to treat
NoVASC: no other comorbid vascular illness
NR: not reported
NS: not sig
NSAIDs: non-steroidal anti-inflammatory drug(s)
NV: (NV Organon)
NV: Naamloze Vennootschap (dutch company type)
NYHA: New York Heart Association
OB/GYN: Obstetrics/Gynecology
OCD: obsessive compulsive disorder
ODT: oral disintegrating tablets
OR: odds ratio
P: statistical test: probability (P-value)
PAR: paroxetine
PBO: placebo
PCP: primary care physician
PDQ: Perceived Deficits Questionnaire
PGI: Patient Global Impression
PGIS: Patient Global Improvement Scale
Phys-SFR: Physicians Sexual Functioning Rating
PSD: poststroke depression
PTSD: post traumatic stress disorder
px: prescription
QD: every day
QIDS-C-16: Quick Inventory of Depressive Symptomatology – clinician rated
QLDS: Quality of Life in Depression Scale
Q-LES-Q: Quality of Life Enjoyment and Satisfaction Questionnaire
QOL: quality of life
QRS: time of ventricular contraction
QTcF: Fridericia-corrected time of ventricular contraction
RCT: randomized controlled trial
RD: Risk difference
RNZCGP: Royal New Zealand College of General Practitioners
RR: relative risk
RRR: relative risk ratio
Rx: prescription
SADHART-CHF: Sertraline Against Depression and Heart Disease in Chronic Heart Failure
SAE: serious adverse event
SCAG: Sandoz Clinical Assessment Geriatric scale
SCID: Structured Clinical Interview for DSM-III Revised
SCL-20: Symptom Check List
SD: standard deviation
SDS: Self rating Depression Scale
SDS: Sheehan Disability Scale
SE: standard error
SER: Sertraline
SES: standard error of skewness
SEM: standard error of measurement
SF-36: Medical Outcomes Study Health Survey - Short Form 36
sig: significant/significantly
SIP: Sickness Impact Profile
SNRI: serotonin norepinephrine reuptake inhibitor
SR: sustained release
SSI: Somatic Symptom Inventory
SSRI: selective serotonin reuptake inhibitor
TCA(s): tricyclic antidepressant(s)
TMT-A: Trail Making Test – Part A
TMT-B: Trail Making Test – Part B
TRA: trazodone
TRD: Treatment Refractory Depression
TST: total sleep time
txt: treatment
UK: United Kingdom
UKU: Utvalg for Kliniske Undersogelse (Side Effect Scale)
US: United States
USA: United States of America
UT: Utah
VA: Veterans' Administration
VAMP: previous name of the General Practitioners Research Database
VAS: visual analog scale
VASC: patients with a history of cardiovascular illness (excluding hypertension)
VAS-PI: Visual Analog Scale – Pain Intensity
VEN ER: venlafaxine extended release
VEN XR: venlafaxine extended release
VEN: venlafaxine
VF: verbal fluency test
VHA: Veteran Health Administration
vs.: versus
w/o: without
WHO: World Health Organization
WHO-S: World Health Organization – Item Well-Being Index
wk(s): week(s)
WMS: Wechsler Memory Scale
x: times
XL: extended release
yr(s): year(s)
z: statistical test: z test
ZDS: Zung self rating depression scale

## References

1 Aberg-Wistedt A, Agren H, Ekselius L, et al. Sertraline versus paroxetine in major depression: clinical outcome after six months of continuous therapy. J Clin Psychopharmacol. Dec. 2000;20(6):645-52. [pmid: 11106136].
2 Allard P, Gram L, Timdahl K, et al. Efficacy and tolerability of venlafaxine in geriatric outpatients with major depression: a double-blind, randomised 6-month comparative trial with citalopram. Int J Geriatr Psychiatry. Dec. 2004;19(12):1123-30. [pmid: 15526307].
3 Alves C, Cachola I, Brandao J. Efficacy and tolerability of venlafaxine and fluoxetine in outpatients with major depression. Primary Care Psychiatry. 1999;5(2):57-63.
4 Baldwin DS, Hawley CJ, Abed RT, et al. A multicenter double-blind comparison of nefazodone and paroxetine in the treatment of outpatients with moderate-to-severe depression. J Clin Psychiatry. Suppl 2. 1996;57:46-52. [pmid: 8626363].
5 Baldwin DS, Cooper JA, Huusom AK, et al. A double-blind, randomized, parallel-group, flexible-dose study to evaluate the tolerability, efficacy and effects of treatment discontinuation with escitalopram and paroxetine in patients with major depressive disorder. Int Clin Psychopharmacol. May. 2006;21(3):159-69. [pmid: 16528138].
6 Ballus C, Quiros G, De Flores T, et al. The efficacy and tolerability of venlafaxine and paroxetine in outpatients with depressive disorder or dysthymia. Int Clin Psychopharmacol. Jan. 2000;15(1):43-8. [pmid: 10836286].
7 Barrett JE, Williams JW Jr, Oxman TE, et al. Treatment of dysthymia and minor depression in primary care: a randomized trial in patients aged 18 to 59 years. J Fam Pract. May. 2001;50(5):405-12. [pmid: 11350703].
8 Beasley CM Jr, Dornseif BE, Pultz JA, et al. Fluoxetine versus trazodone: efficacy and activating-sedating effects. J Clin Psychiatry. Jul. 1991;52(7):294-9. [pmid: 2071559].
9 Behnke K, Sogaard J, Martin S, et al. Mirtazapine orally disintegrating tablet versus sertraline: a prospective onset of action study. J Clin Psychopharmacol. Aug. 2003;23(4):358-64. [pmid: 12920411].
10 Benkert O, Szegedi A, Kohnen R. Mirtazapine compared with paroxetine in major depression. J Clin Psychiatry. Sep. 2000;61(9):656-63. [pmid: 11030486].
11 Benkert O, Szegedi A, Philipp M, et al. Mirtazapine orally disintegrating tablets versus venlafaxine extended release: a double-blind, randomized multicenter trial comparing the onset of antidepressant response in patients with major depressive disorder. J Clin Psychopharmacol. Feb. 2006;26(1):75-8. [pmid: 16415711].
12 Bennie EH, Mullin JM, Martindale JJ. A double-blind multicenter trial comparing sertraline and fluoxetine in outpatients with major depression. J Clin Psychiatry. Jun. 1995;56(6):229-37. [pmid: 7775364].
13 Bielski RJ, Ventura D, Chang CC. A double-blind comparison of escitalopram and venlafaxine extended release in the treatment of major depressive disorder. J Clin Psychiatry. Sep. 2004;65(9):1190-6. [pmid: 15367045].
14 Blier P, Gobbi G, Turcotte JE, et al. Mirtazapine and paroxetine in major depression: a comparison of monotherapy versus their combination from treatment initiation. Eur Neuropsychopharmacol. Jul. 2009;19(7):457-65. [pmid: 19345072].
15 Boulenger JP, Huusom AK, Florea I, et al. A comparative study of the efficacy of long-term treatment with escitalopram and paroxetine in severely depressed patients. Curr Med Res Opin. Jul. 2006;22(7):1331-41. [pmid: 16834832].
16 Boyer P, Danion JM, Bisserbe JC, et al. Clinical and economic comparison of sertraline and fluoxetine in the treatment of depression. A 6-month double-blind study in a primary-care setting in France. Pharmacoeconomics. Jan. 1998;13(1 Pt 2):157-69. [pmid: 10184835].
17 Burke WJ, Gergel I, Bose A. Fixed-dose trial of the single isomer SSRI escitalopram in depressed outpatients. J Clin Psychiatry. Apr. 2002;63(4):331-6. [pmid: 12000207].
18 Cassano GB, Puca F, Scapicchio PL, et al. Paroxetine and fluoxetine effects on mood and cognitive functions in depressed nondemented elderly patients. J Clin Psychiatry. May. 2002;63(5):396-402. [pmid: 12019663].
19 Chouinard G, Saxena B, Belanger MC, et al. A Canadian multicenter, double-blind study of paroxetine and fluoxetine in major depressive disorder. J Affect Disord. Jul. 1999;54(1-2):39-48. [pmid: 10403145].
20 Coleman CC, Cunningham LA, Foster VJ, et al. Sexual dysfunction associated with the treatment of depression: a placebo-controlled comparison of bupropion sustained release and sertraline treatment. Ann Clin Psychiatry. Dec. 1999;11(4):205-15. [pmid: 10596735].
21 Coleman CC, King BR, Bolden-Watson C, et al. A placebo-controlled comparison of the effects on sexual functioning of bupropion sustained release and fluoxetine. Clin Ther. Jul. 2001;23(7):1040-58. [pmid: 11519769].
22 Colonna L, Andersen HF, Reines EH. A randomized, double-blind, 24-week study of escitalopram (10 mg/day) versus citalopram (20 mg/day) in primary care patients with major depressive disorder. Curr Med Res Opin. Oct. 2005;21(10):1659-68. [pmid: 16238906].
23 Costa e Silva J. Randomized, double-blind comparison of venlafaxine and fluoxetine in outpatients with major depression. J Clin Psychiatry. Jul. 1998;59(7):352-7. [pmid: 9714263].
24 Croft H, Settle E Jr, Houser T, et al. A placebo-controlled comparison of the antidepressant efficacy and effects on sexual functioning of sustained-release bupropion and sertraline. Clin Ther. Apr. 1999;21(4):643-58. [pmid: 10363731].
25 Cunningham LA. Once-daily venlafaxine extended release (XR) and venlafaxine immediate release (IR) in outpatients with major depression. Venlafaxine XR 208 Study Group. Ann Clin Psychiatry. Sep. 1997;9(3):157-64. [pmid: 9339881].
26 Cunningham LA, Borison RL, Carman JS, et al. A comparison of venlafaxine, trazodone, and placebo in major depression. J Clin Psychopharmacol. Apr. 1994;14(2):99-106. [pmid: 8195464].
27 Dalery J, Honig A. Fluvoxamine versus fluoxetine in major depressive episode: a double-blind randomised comparison. Hum Psychopharmacol. Jul. 2003;18(5):379-84. [pmid: 12858325].
28 De Nayer A, Geerts S, Ruelens L, et al. Venlafaxine compared with fluoxetine in outpatients with depression and concomitant anxiety. Int J Neuropsychopharmacol. Jun. 2002;5(2):115-20. [pmid: 12135535].
29 De Wilde J, Spiers R, Mertens C, et al. A double-blind, comparative, multicentre study comparing paroxetine with fluoxetine in depressed patients. Acta Psychiatr Scand. Feb. 1993;87(2):141-5. [pmid: 8447241].
30 Detke MJ, Wiltse CG, Mallinckrodt CH, et al. Duloxetine in the acute and long-term treatment of major depressive disorder: a placebo- and paroxetine-controlled trial. Eur Neuropsychopharmacol. Dec. 2004;14(6):457-70. [pmid: 15589385].
31 Devanand DP, Nobler MS, Cheng J, et al. Randomized, double-blind, placebo-controlled trial of fluoxetine treatment for elderly patients with dysthymic disorder. Am J Geriatr Psychiatry. Jan. 2005;13(1):59-68. [pmid: 15653941].
32 Dierick M, Ravizza L, Realini R, et al. A double-blind comparison of venlafaxine and fluoxetine for treatment of major depression in outpatients. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1996;20(1):57-71. [pmid: 8861177].
33 Ekselius L, von Knorring L, Eberhard G. A double-blind multicenter trial comparing sertraline and citalopram in patients with major depression treated in general practice. Int Clin Psychopharmacol. Nov. 1997;12(6):323-31. [pmid: 9547134].
34 Fava M, Amsterdam JD, Deltito JA, et al. A double-blind study of paroxetine, fluoxetine, and placebo in outpatients with major depression. Ann Clin Psychiatry. Dec. 1998;10(4):145-50. [pmid: 9988054].
35 Fava M, Hoog SL, Judge RA, et al. Acute efficacy of fluoxetine versus sertraline and paroxetine in major depressive disorder including effects of baseline insomnia. J Clin Psychopharmacol. Apr. 2002;22(2):137-47. [pmid: 11910258].
36 FDA Center for Drug Evaluation and Research. Stastical Review of NDA 21-323 (Escitalopram Oxalate). 2001. http://www.fda.gov/cder/foi/nda/2002/21-323.pdf_Lexapro_Statr.pdf.
37 Feiger A, Kiev A, Shrivastava RK, et al. Nefazodone versus sertraline in outpatients with major depression: focus on efficacy, tolerability, and effects on sexual function and satisfaction. J Clin Psychiatry. Suppl 2. 1996;57:53-62. [pmid: 8626364].
38 Feighner JP, Gardner EA, Johnston JA, et al. Double-blind comparison of bupropion and fluoxetine in depressed outpatients. J Clin Psychiatry. Aug. 1991;52(8):329-35. [pmid: 1907963].
39 Finkel SI, Richter EM, Clary CM, et al. Comparative efficacy of sertraline vs. fluoxetine in patients age 70 or over with major depression. Am J Geriatr Psychiatry. Summer. 1999;7(3):221-7. [pmid: 10438693].
40 Newhouse PA, Krishnan KR, Doraiswamy PM, et al. A double-blind comparison of sertraline and fluoxetine in depressed elderly outpatients. J Clin Psychiatry. Aug. 2000;61(8):559-68. [pmid: 10982198].
41 Gagiano CA. A double blind comparison of paroxetine and fluoxetine in patients with major depression. Br J Clin Res. 1993;4:145-52.
42 Gillin JC, Rapaport M, Erman MK, et al. A comparison of nefazodone and fluoxetine on mood and on objective, subjective, and clinician-rated measures of sleep in depressed patients: a double-blind, 8-week clinical trial. J Clin Psychiatry. May. 1997;58(5):185-92. [pmid: 9184611].
43 Golden RN, Nemeroff CB, McSorley P, et al. Efficacy and tolerability of controlled-release and immediate-release paroxetine in the treatment of depression. J Clin Psychiatry. Jul. 2002;63(7):577-84. [pmid: 12143913].
44 Goldstein DJ, Mallinckrodt C, Lu Y, et al. Duloxetine in the treatment of major depressive disorder: a double-blind clinical trial. J Clin Psychiatry. Mar. 2002;63(3):225-31. [pmid: 11926722].
45 Guelfi JD, Ansseau M, Timmerman L, et al. Mirtazapine versus venlafaxine in hospitalized severely depressed patients with melancholic features. J Clin Psychopharmacol. Aug. 2001;21(4):425-31. [pmid: 11476127].
46 Haffmans PM, Timmerman L, Hoogduin CA. Efficacy and tolerability of citalopram in comparison with fluvoxamine in depressed outpatients: a double-blind, multicentre study. The LUCIFER Group. Int Clin Psychopharmacol. Sep. 1996;11(3):157-64. [pmid: 8923094].
47 Halikas JA. Org 3770 (mirtazapine) versus trazodone: A placebo controlled trial in depressed elderly patients. Hum Psychopharmacol. 1995;10(Suppl 2):S125-S33.
48 Hewett K, Chrzanowski W, Schmitz M, et al. Eight-week, placebo-controlled, double-blind comparison of the antidepressant efficacy and tolerability of bupropion XR and venlafaxine XR. J Psychopharmacol. Jul. 2009;23(5):531-8. [pmid: 18635695].
49 Hewett K, Gee MD, Krishen A, et al. Double-blind, placebo-controlled comparison of the antidepressant efficacy and tolerability of bupropion XR and venlafaxine XR. J Psychopharmacol. Aug. 2010;24(8):1209-16. [pmid: 19939870].
50 Hicks JA, Argyropoulos SV, Rich AS, et al. Randomised controlled study of sleep after nefazodone or paroxetine treatment in out-patients with depression. Br J Psychiatry. Jun. 2002;180:528-35. [pmid: 12042232].
51 Hong CJ, Hu WH, Chen CC, et al. A double-blind, randomized, group-comparative study of the tolerability and efficacy of 6 weeks' treatment with mirtazapine or fluoxetine in depressed Chinese patients. J Clin Psychiatry. Aug. 2003;64(8):921-6. [pmid: 12927007].
52 Judd LL, Rapaport MH, Yonkers KA, et al. Randomized, placebo-controlled trial of fluoxetine for acute treatment of minor depressive disorder. Am J Psychiatry. Oct. 2004;161(10):1864-71. [pmid: 15465984].
53 Kasper S, de Swart H, Friis Andersen H. Escitalopram in the treatment of depressed elderly patients. Am J Geriatr Psychiatry. Oct. 2005;13(10):884-91. [pmid: 16223967].
54 Kasper S, Olivieri L, Di Loreto G, et al. A comparative, randomised, double-blind study of trazodone prolonged-release and paroxetine in the treatment of patients with major depressive disorder. Curr Med Res Opin. Aug. 2005;21(8):1139-46. [pmid: 16083521].
55 Kavoussi RJ, Segraves RT, Hughes AR, et al. Double-blind comparison of bupropion sustained release and sertraline in depressed outpatients. J Clin Psychiatry. Dec. 1997;58(12):532-7. [pmid: 9448656].
56 Kennedy SH, Fulton KA, Bagby RM, et al. Sexual function during bupropion or paroxetine treatment of major depressive disorder. Can J Psychiatry. Mar. 2006;51(4):234-42. [pmid: 16629348].
57 Khan A, Bose A, Alexopoulos GS, et al. Double-blind comparison of escitalopram and duloxetine in the acute treatment of major depressive disorder. Clin Drug Investig. 2007;27(7):481-92. [pmid: 17563128].
58 Kiev A, Feiger A. A double-blind comparison of fluvoxamine and paroxetine in the treatment of depressed outpatients. J Clin Psychiatry. Apr. 1997;58(4):146-52. [pmid: 9164424].
59 Kocsis JH, Zisook S, Davidson J, et al. Double-blind comparison of sertraline, imipramine, and placebo in the treatment of dysthymia: psychosocial outcomes. Am J Psychiatry. Mar. 1997;154(3):390-5. [pmid: 9054788].
60 Thase ME, Fava M, Halbreich U, et al. A placebo-controlled, randomized clinical trial comparing sertraline and imipramine for the treatment of dysthymia. Arch Gen Psychiatry. Sep. 1996;53(9):777-84. [pmid: 8792754].
61 Lee P, Shu L, Xu X, et al. Once-daily duloxetine 60 mg in the treatment of major depressive disorder: multicenter, double-blind, randomized, paroxetine-controlled, non-inferiority trial in China, Korea, Taiwan and Brazil. Psychiatry Clin Neurosci. Jun. 2007;61(3):295-307. [pmid: 17472599].
62 Leinonen E, Skarstein J, Behnke K, et al. Efficacy and tolerability of mirtazapine versus citalopram: a double-blind, randomized study in patients with major depressive disorder. Nordic Antidepressant Study Group. Int Clin Psychopharmacol. Nov. 1999;14(6):329-37. [pmid: 10565799].
63 Lepola UM, Loft H, Reines EH. Escitalopram (10-20 mg/day) is effective and well tolerated in a placebo-controlled study in depression in primary care. Int Clin Psychopharmacol. Jul. 2003;18(4):211-7. [pmid: 12817155].
64 Mao PX, Tang YL, Jiang F, et al. Escitalopram in major depressive disorder: a multicenter, randomized, double-blind, fixed-dose, parallel trial in a Chinese population. Depress Anxiety. 2008;25(1):46-54. [pmid: 17149753].
65 McPartlin GM, Reynolds A, Anderson C, et al. A comparison of once-daily venlafaxine XR and paroxetine in depressed outpatients treated in general practice. Primary Care Psychiatry. 1998;4(3):127-32.
66 Mehtonen OP, Sogaard J, Roponen P, et al. Randomized, double-blind comparison of venlafaxine and sertraline in outpatients with major depressive disorder. Venlafaxine 631 Study Group. J Clin Psychiatry. Feb. 2000;61(2):95-100. [pmid: 10732656].
67 Montgomery SA, Huusom AK, Bothmer J. A randomised study comparing escitalopram with venlafaxine XR in primary care patients with major depressive disorder. Neuropsychobiology. 2004;50(1):57-64. [pmid: 15179022].
68 Moore N, Verdoux H, Fantino B. Prospective, multicentre, randomized, double-blind study of the efficacy of escitalopram versus citalopram in outpatient treatment of major depressive disorder. Int Clin Psychopharmacol. May. 2005;20(3):131-7. [pmid: 15812262].
69 Munizza C, Olivieri L, Di Loreto G, et al. A comparative, randomized, double-blind study of trazodone prolonged-release and sertraline in the treatment of major depressive disorder. Curr Med Res Opin. Sep. 2006;22(9):1703-13. [pmid: 16968574].
70 Nemeroff CB, Ninan PT, Ballenger J, et al. Double-blind multicenter comparison of fluvoxamine versus sertraline in the treatment of depressed outpatients. Depression. 1995;3(4):163-9.
71 Nemeroff CB, Thase ME. A double-blind, placebo-controlled comparison of venlafaxine and fluoxetine treatment in depressed outpatients. J Psychiatr Res. 2007;41(3-4):351-9. Epub 2005 Sep 12. [pmid: 16165158].
72 Nierenberg AA, Greist JH, Mallinckrodt CH, et al. Duloxetine versus escitalopram and placebo in the treatment of patients with major depressive disorder: onset of antidepressant action, a non-inferiority study. Curr Med Res Opin. Feb. 2007;23(2):401-16. [pmid: 17288694].
73 Owens MJ, Krulewicz S, Simon JS, et al. Estimates of serotonin and norepinephrine transporter inhibition in depressed patients treated with paroxetine or venlafaxine. Neuropsychopharmacology. Dec. 2008;33(13):3201-12. [pmid: 18418363].
74 Patris M, Bouchard JM, Bougerol T, et al. Citalopram versus fluoxetine: a double-blind, controlled, multicentre, phase III trial in patients with unipolar major depression treated in general practice. Int Clin Psychopharmacol. Jun. 1996;11(2):129-36. [pmid: 8803650].
75 Perahia DG, Wang F, Mallinckrodt CH, et al. Duloxetine in the treatment of major depressive disorder: a placebo- and paroxetine-controlled trial. Eur Psychiatry. Sep. 2006;21(6):367-78. [pmid: 16697153].
76 Perry PJ, Garvey MJ, Kelly MW, et al. A comparative trial of fluoxetine versus trazodone in outpatients with major depression. J Clin Psychiatry. Aug. 1989;50(8):290-4. [pmid: 2668259].
77 Rapaport M, Coccaro E, Sheline Y, et al. A comparison of fluvoxamine and fluoxetine in the treatment of major depression. J Clin Psychopharmacol. Oct. 1996;16(5):373-8. [pmid: 8889909].
78 Rapaport MH, Schneider LS, Dunner DL, et al. Efficacy of controlled-release paroxetine in the treatment of late-life depression. J Clin Psychiatry. Sep. 2003;64(9):1065-74. [pmid: 14628982].
79 Ravindran AV, Guelfi JD, Lane RM, et al. Treatment of dysthymia with sertraline: a double-blind, placebo-controlled trial in dysthymic patients without major depression. J Clin Psychiatry. Nov. 2000;61(11):821-7. [pmid: 11105734].
80 Rossini D, Serretti A, Franchini L, et al. Sertraline versus fluvoxamine in the treatment of elderly patients with major depression: a double-blind, randomized trial. J Clin Psychopharmacol. Oct. 2005;25(5):471-5. [pmid: 16160624].
81 Rudolph RL, Feiger AD. A double-blind, randomized, placebo-controlled trial of once-daily venlafaxine extended release (XR) and fluoxetine for the treatment of depression. J Affect Disord. Dec. 1999;56(2-3):171-81. [pmid: 10701474].
82 Rush AJ, Trivedi MH, Carmody TJ, et al. Response in relation to baseline anxiety levels in major depressive disorder treated with bupropion sustained release or sertraline. Neuropsychopharmacology. Jul. 2001;25(1):131-8. [pmid: 11377926].
83 Schatzberg AF, Kremer C, Rodrigues HE, et al. Double-blind, randomized comparison of mirtazapine and paroxetine in elderly depressed patients. Am J Geriatr Psychiatry. Sep-Oct. 2002;10(5):541-50. [pmid: 12213688].
84 Schmidt ME, Fava M, Robinson JM, et al. The efficacy and safety of a new enteric-coated formulation of fluoxetine given once weekly during the continuation treatment of major depressive disorder. J Clin Psychiatry. Nov. 2000;61(11):851-7. [pmid: 11105738].
85 Schone W, Ludwig M. A double-blind study of paroxetine compared with fluoxetine in geriatric patients with major depression. J Clin Psychopharmacol. Dec. 1993;13(6 Suppl 2):34S-9S. [pmid: 8106654].
86 Sechter D, Troy S, Paternetti S, et al. A double-blind comparison of sertraline and fluoxetine in the treatment of major depressive episode in outpatients. Eur Psychiatry. Mar. 1999;14(1):41-8. [pmid: 10572324].
87 Shelton RC, Haman KL, Rapaport MH, et al. A randomized, double-blind, active-control study of sertraline versus venlafaxine XR in major depressive disorder. J Clin Psychiatry. Nov. 2006;67(11):1674-81. [pmid: 17196045].
88 Silverstone PH, Ravindran A. Once-daily venlafaxine extended release (XR) compared with fluoxetine in outpatients with depression and anxiety. Venlafaxine XR 360 Study Group. J Clin Psychiatry. Jan. 1999;60(1):22-8. [pmid: 10074873].
89 Sir A, D'Souza RF, Uguz S, et al. Randomized trial of sertraline versus venlafaxine XR in major depression: efficacy and discontinuation symptoms. J Clin Psychiatry. Oct. 2005;66(10):1312-20. [pmid: 16259546].
90 Tignol J. A double-blind, randomized, fluoxetine-controlled, multicenter study of paroxetine in the treatment of depression. J Clin Psychopharmacol. Dec. 1993;13(6 Suppl 2):18S-22S. [pmid: 8106650].
91 Tourian KA, Padmanabhan SK, Groark J, et al. Desvenlafaxine 50 and 100 mg/d in the treatment of major depressive disorder: an 8-week, phase III, multicenter, randomized, double-blind, placebo-controlled, parallel-group trial and a post hoc pooled analysis of three studies. Clin Ther. Jun. 2009;31(Pt 1):1405-23. [pmid: 19698901].
92 Tylee A, Beaumont G, Bowden MW, et al. A double-blind, randomized, 12-week comparison study of the safety and efficacy of venlafaxine and fluoxetine in moderate to severe major depression in general practice. Primary Care Psychiatry. 1997;3(1):51-8.
93 Tzanakaki M, Guazzelli M, Nimatoudis I, et al. Increased remission rates with venlafaxine compared with fluoxetine in hospitalized patients with major depression and melancholia. Int Clin Psychopharmacol. Jan. 2000;15(1):29-34. [pmid: 10836283].
94 Ushiroyama T, Ikeda A, Ueki M. Evaluation of double-blind comparison of fluvoxamine and paroxetine in the treatment of depressed outpatients in menopause transition. J Med. 2004;35(1-6):151-62. [pmid: 18084873].
95 Van Moffaert M, Bartholome F, Cosyns P, et al. A controlled comparison of sertraline and fluoxetine in acute and continuation treatment of major depression. Human Psychopharmacol. 1995;10:393-405.
96 van Moffaert M, de Wilde J, Vereecken A, et al. Mirtazapine is more effective than trazodone: a double-blind controlled study in hospitalized patients with major depression. Int Clin Psychopharmacol. Mar. 1995;10(1):3-9. [pmid: 7622801].
97 Vanelle JM, Attar-Levy D, Poirier MF, et al. Controlled efficacy study of fluoxetine in dysthymia. Br J Psychiatry. Apr. 1997;170:345-50. [pmid: 9246253].
98 Ventura D, Armstrong EP, Skrepnek GH, et al. Escitalopram versus sertraline in the treatment of major depressive disorder: a randomized clinical trial. Curr Med Res Opin. Feb. 2007;23(2):245-50. [pmid: 17288677].
99 Versiani M, Moreno R, Ramakers-van Moorsel CJ, et al. Comparison of the effects of mirtazapine and fluoxetine in severely depressed patients. CNS Drugs. 2005;19(2):137-46. [pmid: 15697327].
100 Wade A, Gembert K, Florea I. A comparative study of the efficacy of acute and continuation treatment with escitalopram versus duloxetine in patients with major depressive disorder. Curr Med Res Opin. Jul. 2007;23(7):1605-14. [pmid: 17559755].
101 Weihs KL, Settle EC Jr, Batey SR, et al. Bupropion sustained release versus paroxetine for the treatment of depression in the elderly. J Clin Psychiatry. Mar. 2000;61(3):196-202. [pmid: 10817105].
102 Weisler RH, Johnston JA, Lineberry CG, et al. Comparison of bupropion and trazodone for the treatment of major depression. J Clin Psychopharmacol. Jun. 1994;14(3):170-9. [pmid: 8027413].
103 Wheatley DP, van Moffaert M, Timmerman L, et al. Mirtazapine: efficacy and tolerability in comparison with fluoxetine in patients with moderate to severe major depressive disorder. Mirtazapine-Fluoxetine Study Group. J Clin Psychiatry. Jun. 1998;59(6):306-12. [pmid: 9671343].
104 Williams JW Jr, Barrett J, Oxman T, et al. Treatment of dysthymia and minor depression in primary care: A randomized controlled trial in older adults. JAMA. Sep. 27. 2000;284(12):1519-26. [pmid: 11000645].
105 Yevtushenko VY, Belous AI, Yevtushenko YG, et al. Efficacy and tolerability of escitalopram versus citalopram in major depressive disorder: a 6-week, multicenter, prospective, randomized, double-blind, active-controlled study in adult outpatients. Clin Ther. Nov. 2007;29(11):2319-32. [pmid: 18158074].
106 Baldomero EB, Ubago JG, Cercos CL, et al. Venlafaxine extended release versus conventional antidepressants in the remission of depressive disorders after previous antidepressant failure: ARGOS study. Depress Anxiety. Aug. 10. 2005;22(2):68-76. [pmid: 16094658].
107 Claghorn JL, Feighner JP. A double-blind comparison of paroxetine with imipramine in the long-term treatment of depression. J Clin Psychopharmacol. Dec. 1993;13(6 Suppl 2):23S-7S. [pmid: 8106652].
108 Corya SA, Williamson D, Sanger TM, et al. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, fluoxetine, and venlafaxine in treatment-resistant depression. Depress Anxiety. 2006;23(6):364-72. [pmid: 16710853].
109 Dinan TG. Efficacy and safety of weekly treatment with enteric-coated fluoxetine in patients with major depressive disorder. J Clin Psychiatry. Suppl 22. 2001;62:48-52. [pmid: 11599649].
110 Doogan DP, Caillard V. Sertraline in the prevention of depression. Br J Psychiatry. Feb. 1992;160:217-22. [pmid: 1540762].
111 Fang Y, Yuan C, Xu Y, et al. Comparisons of the efficacy and tolerability of extended-release venlafaxine, mirtazapine, and paroxetine in treatment-resistant depression: a double-blind, randomized pilot study in a Chinese population. J Clin Psychopharmacol. Aug. 2010;30(4):357-64. [pmid: 20571433].
112 Fava M, Wiltse C, Walker D, et al. Predictors of relapse in a study of duloxetine treatment in patients with major depressive disorder. J Affect Disord. Mar. 2009;113(3):263-71. [pmid: 18625521].
113 Kocsis JH, Thase ME, Trivedi MH, et al. Prevention of recurrent episodes of depression with venlafaxine ER in a 1-year maintenance phase from the PREVENT Study. J Clin Psychiatry. Jul. 2007;68(7):1014-23. [pmid: 17685736].
114 Fava M, Detke MJ, Balestrieri M, et al. Management of depression relapse: reinitiation of duloxetine treatment or dose increase. J Psychiatr Res. Jun. 2006;40(4):328-36. [pmid: 16678205].
115 Perahia DG, Gilaberte I, Wang F, et al. Duloxetine in the prevention of relapse of major depressive disorder: double-blind placebo-controlled study. Br J Psychiatry. Apr. 2006;188:346-53. [pmid: 16582061].
116 Feiger AD, Bielski RJ, Bremner J, et al. Double-blind, placebo-substitution study of nefazodone in the prevention of relapse during continuation treatment of outpatients with major depression. Int Clin Psychopharmacol. Jan. 1999;14(1):19-28. [pmid: 10221638].
117 Franchini L, Gasperini M, Perez J, et al. A double-blind study of long-term treatment with sertraline or fluvoxamine for prevention of highly recurrent unipolar depression. J Clin Psychiatry. Mar. 1997;58(3):104-7. [pmid: 9108811].
118 Franchini L, Gasperini M, Zanardi R, et al. Four-year follow-up study of sertraline and fluvoxamine in long-term treatment of unipolar subjects with high recurrence rate. J Affect Disord. Jun. 2000;58(3):233-6. [pmid: 10802132].
119 Gelenberg AJ, Trivedi MH, Rush AJ, et al. Randomized, placebo-controlled trial of nefazodone maintenance treatment in preventing recurrence in chronic depression. Biol Psychiatry. Oct. 15. 2003;54(8):806-17. [pmid: 14550680].
120 Gilaberte I, Montejo AL, de la Gandara J, et al. Fluoxetine in the prevention of depressive recurrences: a double-blind study. J Clin Psychopharmacol. Aug. 2001;21(4):417-24. [pmid: 11476126].
121 Gorwood P, Weiller E, Lemming O, et al. Escitalopram prevents relapse in older patients with major depressive disorder. Am J Geriatr Psychiatry. Jul. 2007;15(7):581-93. [pmid: 17586783].
122 Eckert L, Lançon C. Duloxetine compared with fluoxetine and venlafaxine: Use of meta-regression analysis for indirect comparisons. BMC Psychiatry. Jul. 24. 2006;6:30. [pmid: 16867188].
123 Kamijima K, Burt T, Cohen G, et al. A placebo-controlled, randomized withdrawal study of sertraline for major depressive disorder in Japan. Int Clin Psychopharmacol. Jan. 2006;21(1):1-9. [pmid: 16317311].
124 Keller MB, Trivedi MH, Thase ME, et al. The Prevention of Recurrent Episodes of Depression with Venlafaxine for Two Years (PREVENT) study: outcomes from the acute and continuation phases. Biol Psychiatry. Dec. 15. 2007;62(12):1371-9. [pmid: 17825800].
125 Keller MB, Kocsis JH, Thase ME, et al. Maintenance phase efficacy of sertraline for chronic depression: a randomized controlled trial. JAMA. Nov. 18. 1998;280(19):1665-72. [pmid: 9831997].
126 Keller MB, Trivedi MH, Thase ME, et al. The Prevention of Recurrent Episodes of Depression with Venlafaxine for Two Years (PREVENT) Study: Outcomes from the 2-year and combined maintenance phases. J Clin Psychiatry. Aug. 2007;68(8):1246-56. [pmid: 17854250].
127 Klysner R, Bent-Hansen J, Hansen HL, et al. Efficacy of citalopram in the prevention of recurrent depression in elderly patients: placebo-controlled study of maintenance therapy. Br J Psychiatry. Jul. 2002;181:29-35. [pmid: 12091260].
128 Kocsis JH, Schatzberg A, Rush AJ, et al. Psychosocial outcomes following long-term, double-blind treatment of chronic depression with sertraline vs placebo. Arch Gen Psychiatry. Aug. 2002;59(8):723-8. [pmid: 12150648].
129 Kornstein SG, Bose A, Li D, et al. Escitalopram maintenance treatment for prevention of recurrent depression: a randomized, placebo-controlled trial. J Clin Psychiatry. Nov. 2006;67(11):1767-75. [pmid: 17196058].
130 Kornstein SG, Kocsis JH, Ahmed S, et al. Assessing the efficacy of 2 years of maintenance treatment with venlafaxine extended release 75-225 mg/day in patients with recurrent major depression: a secondary analysis of data from the PREVENT study. Int Clin Psychopharmacol. Nov. 2008;23(6):357-63. [pmid: 18854724].
131 Kornstein SG. Maintenance therapy to prevent recurrence of depression: summary and implications of the PREVENT study. Expert Rev Neurother. May. 2008;8(5):737-42. [pmid: 18457530].
132 Lenox-Smith AJ, Jiang Q. Venlafaxine extended release versus citalopram in patients with depression unresponsive to a selective serotonin reuptake inhibitor. Int Clin Psychopharmacol. 2008;23(3):113-9. [pmid: 18408525].
133 Lepine JP, Caillard V, Bisserbe JC, et al. A randomized, placebo-controlled trial of sertraline for prophylactic treatment of highly recurrent major depressive disorder. Am J Psychiatry. May. 2004;161(5):836-42. [pmid: 15121648].
134 Lin CH, Lin KS, Lin CY, et al. Time to rehospitalization in patients with major depressive disorder taking venlafaxine or fluoxetine. J Clin Psychiatry. Jan. 2008;69(1):54-9. [pmid: 18312038].
135 Lustman PJ, Clouse RE, Nix BD, et al. Sertraline for prevention of depression recurrence in diabetes mellitus: a randomized, double-blind, placebo-controlled trial. Arch Gen Psychiatry. May. 2006;63(5):521-9. [pmid: 16651509].
136 McGrath PJ, Stewart JW, Quitkin FM, et al. Predictors of relapse in a prospective study of fluoxetine treatment of major depression. Am J Psychiatry. Sep. 2006;163(9):1542-8. [pmid: 16946178].
137 Michelson D, Amsterdam JD, Quitkin FM, et al. Changes in weight during a 1-year trial of fluoxetine. Am J Psychiatry. Aug. 1999;156(8):1170-6. [pmid: 10450256].
138 Montgomery SA, Entsuah R, Hackett D, et al. Venlafaxine versus placebo in the preventive treatment of recurrent major depression. J Clin Psychiatry. Mar. 2004;65(3):328-36. [pmid: 15096071].
139 Montgomery SA, Dunbar G. Paroxetine is better than placebo in relapse prevention and the prophylaxis of recurrent depression. Int Clin Psychopharmacol. Fall. 1993;8(3):189-95. [pmid: 8263317].
140 Montgomery SA, Rasmussen JG. Citalopram 20 mg, citalopram 40 mg and placebo in the prevention of relapse of major depression. Int Clin Psychopharmacol. Jun. 1992;8:181-8. [pmid: 1431025].
141 Perahia DG, Maina G, Thase ME, et al. Duloxetine in the prevention of depressive recurrences: a randomized, double-blind, placebo-controlled trial. J Clin Psychiatry. May. 2009;70(5):706-16. [pmid: 19552867].
142 Poirier MF, Boyer P. Venlafaxine and paroxetine in treatment-resistant depression. Double-blind, randomised comparison. Br J Psychiatry. Jul. 1999;175:12-6. [pmid: 10621762].
143 Rapaport MH, Bose A, Zheng H. Escitalopram continuation treatment prevents relapse of depressive episodes. J Clin Psychiatry. Jan. 2004;65(1):44-9. [pmid: 14744167].
144 Reimherr FW, Amsterdam JD, Quitkin FM, et al. Optimal length of continuation therapy in depression: a prospective assessment during long-term fluoxetine treatment. Am J Psychiatry. Sep. 1998;155(9):1247-53. [pmid: 9734550].
145 Reynolds CF 3rd, Dew MA, Pollock BG, et al. Maintenance treatment of major depression in old age. N Engl J Med. Mar. 16. 2006;354(11):1130-8. [pmid: 16540613].
146 Rickels K, Montgomery SA, Tourian KA, et al. Desvenlafaxine for the prevention of relapse in major depressive disorder: results of a randomized trial. J Clin Psychopharmacol. Feb. 2010;30(1):18-24. [pmid: 20075643].
147 Robert P, Montgomery SA. Citalopram in doses of 20-60 mg is effective in depression relapse prevention: a placebo-controlled 6 month study. Int Clin Psychopharmacol. Mar. Suppl 1. 1995;10:29-35. [pmid: 7622809].
148 Rush AJ, Trivedi MH, Wisniewski SR, et al. Bupropion-SR, sertraline, or venlafaxine-XR after failure of SSRIs for depression. N Engl J Med. Mar. 23. 2006;354(12):1231-42. [pmid: 16554525].
149 Rush AJ, Trivedi MH, Wisniewski SR, et al. Acute and Longer-Term Outcomes in Depressed Outpatients Requiring One or Several Treatment Steps: A STAR*D Report. Am J Psychiatry. Nov. 2006;163(11):1905-17. [pmid: 17074942].
150 Schmidt ME, Fava M, Zhang S, et al. Treatment approaches to major depressive disorder relapse. Part 1: dose increase. Psychother Psychosom. Jul-Aug. 2002;71(4):190-4. [pmid: 12097783].
151 Simon JS, Aguiar LM, Kunz NR, et al. Extended-release venlafaxine in relapse prevention for patients with major depressive disorder. J Psychiatr Res. May-Jun. 2004;38(3):249-57. [pmid: 15003430].
152 Soares CN, Thase ME, Clayton A, et al. Desvenlafaxine and escitalopram for the treatment of postmenopausal women with major depressive disorder. Menopause. Jul. 2010;17(4):700-11. [pmid: 20539246].
153 Terra JL, Montgomery SA. Fluvoxamine prevents recurrence of depression: results of a long-term, double-blind, placebo-controlled study. Int Clin Psychopharmacol. Mar. 1998;13(2):55-62. [pmid: 9669185].
154 Thase ME, Gelenberg A, Kornstein SG, et al. Comparing venlafaxine extended release and fluoxetine for preventing the recurrence of major depression: Results from the PREVENT study. J Psychiatr Res. 2010. Aug. 28. [pmid: 20801464].
155 Thase ME, Nierenberg AA, Keller MB, et al. Efficacy of mirtazapine for prevention of depressive relapse: a placebo-controlled double-blind trial of recently remitted high-risk patients. J Clin Psychiatry. Oct. 2001;62(10):782-8. [pmid: 11816867].
156 Trivedi MH, Fava M, Wisniewski SR, et al. Medication augmentation after the failure of SSRIs for depression. N Engl J Med. Mar. 23. 2006;354(12):1243-52. [pmid: 16554526].
157 Weihs KL, Houser TL, Batey SR, et al. Continuation phase treatment with bupropion SR effectively decreases the risk for relapse of depression. Biol Psychiatry. May. 1. 2002;51(9):753-61. [pmid: 11983189].
158 Wilson KC, Mottram PG, Ashworth L, et al. Older community residents with depression: long-term treatment with sertraline. Randomised, double-blind, placebo-controlled study. Br J Psychiatry. Jun. 2003;182:492-7. [pmid: 12777339].
159 Boulenger JP, Hermes A, Huusom AK, et al. Baseline anxiety effect on outcome of SSRI treatment in patients with severe depression: escitalopram vs paroxetine. Curr Med Res Opin. Mar. 2010;26(3):605-14. [pmid: 20067433].
160 Brannan SK, Mallinckrodt CH, Brown EB, et al. Duloxetine 60 mg once-daily in the treatment of painful physical symptoms in patients with major depressive disorder. J Psychiatr Res. Jan. 2005;39(1):43-53. [pmid: 15504423].
161 Brecht S, Courtecuisse C, Debieuvre C, et al. Efficacy and safety of duloxetine 60 mg once daily in the treatment of pain in patients with major depressive disorder and at least moderate pain of unknown etiology: a randomized controlled trial. J Clin Psychiatry. Nov. 2007;68(11):1707-16. [pmid: 18052564].
162 Detke MJ, Lu Y, Goldstein DJ, et al. Duloxetine 60 mg once daily dosing versus placebo in the acute treatment of major depression. J Psychiatr Res. Nov-Dec. 2002;36(6):383-90. [pmid: 12393307].
163 Detke MJ, Lu Y, Goldstein DJ, et al. Duloxetine, 60 mg once daily, for major depressive disorder: a randomized double-blind placebo-controlled trial. J Clin Psychiatry. Apr. 2002;63(4):308-15. [pmid: 12000204].
164 Fava M, Rosenbaum JF, Hoog SL, et al. Fluoxetine versus sertraline and paroxetine in major depression: tolerability and efficacy in anxious depression. J Affect Disord. Aug. 2000;59(2):119-26. [pmid: 10837880].
165 Flament MF, Lane RM, Zhu R, et al. Predictors of an acute antidepressant response to fluoxetine and sertraline. Int Clin Psychopharmacol. Sep. 1999;14(5):259-75. [pmid: 10529069].
166 Jefferson JW, Rush AJ, Nelson JC, et al. Extended-release bupropion for patients with major depressive disorder presenting with symptoms of reduced energy, pleasure, and interest: findings from a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Jun. 2006;67(6):865-73. [pmid: 16848645].
167 Khan A, Upton GV, Rudolph RL, et al. The use of venlafaxine in the treatment of major depression and major depression associated with anxiety: a dose-response study. Venlafaxine Investigator Study Group. J Clin Psychopharmacol. Feb. 1998;18(1):19-25. [pmid: 9472838].
168 Krebs EE, Gaynes BN, Gartlehner G, et al. Treating the physical symptoms of depression with second-generation antidepressants: a systematic review and metaanalysis. Psychosomatics. May-Jun. 2008;49(3):191-8. [pmid: 18448772].
169 McCall WV, Blocker JN, D'Agostino R Jr, et al. Treatment of insomnia in depressed insomniacs: Effects on health-related quality of life, objective and self-reported sleep, and depression. Journal of Clinical Sleep Medicine. 2010;6(4):322-9. [pmid: 20726279].
170 Raskin J, Xu JY, Kajdasz DK. Time to response for duloxetine 60 mg once daily versus placebo in elderly patients with major depressive disorder. Int Psychogeriatr. Apr. 2008;20(2):309-27. [pmid: 17588276].
171 Raskin J, Wiltse CG, Siegal A, et al. Efficacy of duloxetine on cognition, depression, and pain in elderly patients with major depressive disorder: an 8-week, double-blind, placebo-controlled trial. Am J Psychiatry. Jun. 2007;164(6):900-9. [pmid: 17541049].
172 Silverstone PH, Salinas E. Efficacy of venlafaxine extended release in patients with major depressive disorder and comorbid generalized anxiety disorder. J Clin Psychiatry. Jul. 2001;62(7):523-9. [pmid: 11488362].
173 Andersohn F, Schade R, Suissa S, et al. Long-term use of antidepressants for depressive disorders and the risk of diabetes mellitus. Am J Psychiatry. May. 2009;166(5):591-8. [pmid: 19339356].
174 Aursnes I, Tvete IF, Gaasemyr J, et al. Suicide attempts in clinical trials with paroxetine randomised against placebo. BMC Med. Aug. 22. 2005;3:14. [pmid: 16115311].
175 Barbui C, Esposito E, Cipriani A. Selective serotonin reuptake inhibitors and risk of suicide: A systematic review of observational studies. Can Med Assoc J. 2009;180(3):291-7. [pmid: 19188627].
176 Brambilla P, Cipriani A, Hotopf M, et al. Side-effect profile of fluoxetine in comparison with other SSRIs, tricyclic and newer antidepressants: a meta-analysis of clinical trial data. Pharmacopsychiatry. Mar. 2005;38(2):69-77. [pmid: 15744630].
177 Buckley NA, McManus PR. Fatal toxicity of serotoninergic and other antidepressant drugs: analysis of United Kingdom mortality data. BMJ. Dec. 7. 2002;325(7376):1332-3. [pmid: 12468481].
178 Cipriani A, La Ferla T, Furukawa TA, et al. Sertraline versus other antidepressive agents for depression. Cochrane Database Syst Rev. 2010;(4):CD006117. [pmid: 20393946].
179 Claxton A, de Klerk E, Parry M, et al. Patient compliance to a new enteric-coated weekly formulation of fluoxetine during continuation treatment of major depressive disorder. J Clin Psychiatry. Dec. 2000;61(12):928-32. [pmid: 11206598].
180 Clayton AH, Pradko JF, Croft HA, et al. Prevalence of sexual dysfunction among newer antidepressants. J Clin Psychiatry. Apr. 2002;63(4):357-66. [pmid: 12000211].
181 Clayton AH, Croft HA, Horrigan JP, et al. Bupropion extended release compared with escitalopram: effects on sexual functioning and antidepressant efficacy in 2 randomized, double-blind, placebo-controlled studies. J Clin Psychiatry. May. 2006;67(5):736-46. [pmid: 16841623].
182 Clayton A, Kornstein S, Prakash A, et al. Changes in sexual functioning associated with duloxetine, escitalopram, and placebo in the treatment of patients with major depressive disorder. J Sex Med. Jul. 2007;4(4 Pt 1):917-29. [pmid: 17627739].
183 Expert Working Group of the Committee on Safety of Medicines (CSM). Report of the CSM expert working group on the safety of selective serotonin reuptake inhibitor antidepressants. United Kingdom. Author. 2004.
184 Delgado PL, Brannan SK, Mallinckrodt CH, et al. Sexual functioning assessed in 4 double-blind placebo- and paroxetine-controlled trials of duloxetine for major depressive disorder. J Clin Psychiatry. Jun. 2005;66(6):686-92. [pmid: 15960560].
185 Didham RC, McConnell DW, Blair HJ, et al. Suicide and self-harm following prescription of SSRIs and other antidepressants: confounding by indication. Br J Clin Pharmacol. Nov. 2005;60(5):519-25. [pmid: 16236042].
186 Dunner DL, Zisook S, Billow AA, et al. A prospective safety surveillance study for bupropion sustained-release in the treatment of depression. J Clin Psychiatry. Jul. 1998;59(7):366-73. [pmid: 9714265].
187 Ekselius L, von Knorring L. Effect on sexual function of long-term treatment with selective serotonin reuptake inhibitors in depressed patients treated in primary care. J Clin Psychopharmacol. Apr. 2001;21(2):154-60. [pmid: 11270911].
188 Fava M, Judge R, Hoog SL, et al. Fluoxetine versus sertraline and paroxetine in major depressive disorder: changes in weight with long-term treatment. J Clin Psychiatry. Nov. 2000;61(11):863-7. [pmid: 11105740].
189 Ferguson JM, Shrivastava RK, Stahl SM, et al. Reemergence of sexual dysfunction in patients with major depressive disorder: double-blind comparison of nefazodone and sertraline. J Clin Psychiatry. Jan. 2001;62(1):24-9. [pmid: 11235924].
190 Fergusson D, Doucette S, Glass KC, et al. Association between suicide attempts and selective serotonin reuptake inhibitors: systematic review of randomised controlled trials. BMJ. Feb. 19. 2005;330(7488):396. [pmid: 15718539].
191 Gibbons RD, Brown CH, Hur K, et al. Relationship between antidepressants and suicide attempts: An analysis of the veterans health administration data sets. Am J Psychiatry. 2007;164(7):1044-9. [pmid: 17606656].
192 Goldstein DJ, Hamilton SH, Masica DN, et al. Fluoxetine in medically stable, depressed geriatric patients: effects on weight. J Clin Psychopharmacol. Oct. 1997;17(5):365-9. [pmid: 9315987].
193 Greist J, McNamara RK, Mallinckrodt CH, et al. Incidence and duration of antidepressant-induced nausea: duloxetine compared with paroxetine and fluoxetine. Clin Ther. Sep. 2004;26(9):1446-55. [pmid: 15531007].
194 Gunnell D, Saperia J, Ashby D. Selective serotonin reuptake inhibitors (SSRIs) and suicide in adults: meta-analysis of drug company data from placebo controlled, randomised controlled trials submitted to the MHRA's safety review. BMJ. Feb. 19. 2005;330(7488):385. [pmid: 15718537].
195 Jick H, Ulcickas M, Dean A. Comparison of frequencies of suicidal tendencies among patients receiving fluoxetine, lofepramine, mianserin, or trazodone. Pharmacotherapy. 1992;12(6):451-4. [pmid: 1492009].
196 Jick SS, Dean AD, Jick H. Antidepressants and suicide. BMJ. Jan. 28. 1995;310(6974):215-8. [pmid: 7677826].
197 Jick H, Kaye JA, Jick SS. Antidepressants and the risk of suicidal behaviors. JAMA. Jul. 21. 2004;292(3):338-43. [pmid: 15265848].
198 Johnston JA, Lineberry CG, Ascher JA, et al. A 102-center prospective study of seizure in association with bupropion. J Clin Psychiatry. Nov. 1991;52(11):450-6. [pmid: 1744061].
199 Judge R, Parry MG, Quail D, et al. Discontinuation symptoms: comparison of brief interruption in fluoxetine and paroxetine treatment. Int Clin Psychopharmacol. Sep. 2002;17(5):217-25. [pmid: 12177584].
200 Kasper S, Baldwin DS, Larsson Lonn S, et al. Superiority of escitalopram to paroxetine in the treatment of depression. Eur Neuropsychopharmacol. 2009;19(4):229-37. [pmid: 19185467].
201 Kennedy SH, Eisfeld BS, Dickens SE, et al. Antidepressant-induced sexual dysfunction during treatment with moclobemide, paroxetine, sertraline, and venlafaxine. J Clin Psychiatry. Apr. 2000;61(4):276-81. [pmid: 10830148].
202 Khan A, Khan S, Kolts R, et al. Suicide rates in clinical trials of SSRIs, other antidepressants, and placebo: analysis of FDA reports. Am J Psychiatry. Apr. 2003;160(4):790-2. [pmid: 12668373].
203 Lopez-Iibor JJ. Reduced suicidality with paroxetine. European Psychiatry. 1993;8(Suppl 1):17S-9S.
204 Mackay FJ, Dunn NR, Wilton LV, et al. A comparison of fluvoxamine, fluoxetine, sertraline and paroxetine examined by observational cohort studies. Pharmacoepidemiol Drug Saf. Jul. 1997;6(4):235-46. [pmid: 15073774].
205 Mackay FJ, Dunn NR, Mann RD. Antidepressants and the serotonin syndrome in general practice. Br J Gen Pract. Nov. 1999;49(448):871-4. [pmid: 10818650].
206 Mackay FR, Dunn NR, Martin RM, et al. Newer antidepressants: a comparison of tolerability in general practice. Br J Gen Pract. Nov. 1999;49(448):892-6. [pmid: 10818655].
207 Martinez C, Rietbrock S, Wise L, et al. Antidepressant treatment and the risk of fatal and non-fatal self harm in first episode depression: nested case-control study. BMJ. Feb. 19. 2005;330(7488):389. [pmid: 15718538].
208 Martinez C, Assimes TL, Mines D, et al. Use of venlafaxine compared with other antidepressants and the risk of sudden cardiac death or near death: a nested case-control study. BMJ. 340:c249. [pmid: 20139216].
209 Meijer WE, Heerdink ER, van Eijk JT, et al. Adverse events in users of sertraline: results from an observational study in psychiatric practice in The Netherlands. Pharmacoepidemiol Drug Saf. Dec. 2002;11(8):655-62. [pmid: 12512241].
210 Montejo AL, Llorca G, Izquierdo JA, et al. Incidence of sexual dysfunction associated with antidepressant agents: a prospective multicenter study of 1022 outpatients. Spanish Working Group for the Study of Psychotropic-Related Sexual Dysfunction. J Clin Psychiatry. Suppl 3. 2001;62:10-21. [pmid: 11229449].
211 Montgomery SA, Andersen HF. Escitalopram versus venlafaxine XR in the treatment of depression. Int Clin Psychopharmacol. Sep. 2006;21(5):297-309. [pmid: 16877901].
212 Nieuwstraten CE, Dolovich LR. Bupropion versus selective serotonin-reuptake inhibitors for treatment of depression. Ann Pharmacother. Dec. 2001;35(12):1608-13. [pmid: 11793630].
213 Olfson M, Marcus SC. A case-control study of antidepressants and attempted suicide during early phase treatment of major depressive episodes. J Clin Psychiatry. 2008;69(3):425-32. [pmid: 18294025].
214 Pedersen AG. Escitalopram and suicidality in adult depression and anxiety. Int Clin Psychopharmacol. May. 2005;20(3):139-43. [pmid: 15812263].
215 Perahia DG, Kajdasz DK, Desaiah D, et al. Symptoms following abrupt discontinuation of duloxetine treatment in patients with major depressive disorder. J Affect Disord. Dec. 2005;89(1-3):207-12. [pmid: 16266753].
216 Philipp M, Tiller JW, Baier D, et al. Comparison of moclobemide with selective serotonin reuptake inhibitors (SSRIs) on sexual function in depressed adults. The Australian and German Study Groups. Eur Neuropsychopharmacol. Sep. 2000;10(5):305-14. [pmid: 10974600].
217 Rahme E, Dasgupta K, Turecki G, et al. Risks of suicide and poisoning among elderly patients prescribed selective serotonin reuptake inhibitors: a retrospective cohort study. J Clin Psychiatry. Mar. 2008;69(3):349-57. [pmid: 18278986].
218 Schneeweiss S, Patrick AR, Solomon DH, et al. Variation in the risk of suicide attempts and completed suicides by antidepressant agent in adults: a propensity score-adjusted analysis of 9 years' data. Arch Gen Psychiatry. May. 2010;67(5):497-506. [pmid: 20439831].
219 Segraves RT, Kavoussi R, Hughes AR, et al. Evaluation of sexual functioning in depressed outpatients: a double-blind comparison of sustained-release bupropion and sertraline treatment. J Clin Psychopharmacol. Apr. 2000;20(2):122-8. [pmid: 10770448].
220 Simon GE, Savarino J, Operskalski B, et al. Suicide risk during antidepressent treatment. Am J Psychiatry. 2006;163(1):41-7. [pmid: 16390887].
221 Stang P, Young S, Hogue S. Better patient persistence with once-daily bupropion compared with twice-daily bupropion. Am J Ther. Jan-Feb. 2007;14(1):20-4. [pmid: 17303971].
222 Thapa PB, Gideon P, Cost TW, et al. Antidepressants and the risk of falls among nursing home residents. N Engl J Med. Sep. 24. 1998;339(13):875-82. [pmid: 9744971].
223 Vanderburg DG, Batzar E, Fogel I, et al. A pooled analysis of suicidality in double-blind, placebo-controlled studies of sertraline in adults. J Clin Psychiatry. May. 2009;70(5):674-83. [pmid: 19552866].
224 Vestergaard P, Rejnmark L, Mosekilde L. Selective serotonin reuptake inhibitors and other antidepressants and risk of fracture. Calcif Tissue Int. 2008;82(2):92-101. [pmid: 18219438].
225 Whyte IM, Dawson AH, Buckley NA. Relative toxicity of venlafaxine and selective serotonin reuptake inhibitors in overdose compared to tricyclic antidepressants. QJM. May. 2003;96(5):369-74. [pmid: 12702786].
226 Wise TN, Perahia DGS, Pangallo BA, et al. Effects of the antidepressant duloxetine on body weight: Analyses of 10 clinical studies. Primary Care Companion to the Journal of Clinical Psychiatry. 2006;8(5):269-78.
227 Zajecka J, Fawcett J, Amsterdam J, et al. Safety of abrupt discontinuation of fluoxetine: a randomized, placebo-controlled study. J Clin Psychopharmacol. Jun. 1998;18(3):193-7. [pmid: 9617977].
228 Andersen G, Vestergaard K, Lauritzen L. Effective treatment of poststroke depression with the selective serotonin reuptake inhibitor citalopram. Stroke. Jun. 1994;25(6):1099-104. [pmid: 8202964].
229 Bush DE, Ziegelstein RC, Patel UV, et al. Post-myocardial infarction depression. Evid Rep Technol Assess (Summ). May. 2005;(123):1-8. [pmid: 15989376].
230 Doraiswamy PM, Khan ZM, Donahue RM, et al. Quality of life in geriatric depression: a comparison of remitters, partial responders, and nonresponders. Am J Geriatr Psychiatry. Fall. 2001;9(4):423-8. [pmid: 11739069].
231 Echeverry D, Duran P, Bonds C, et al. Effect of pharmacological treatment of depression on A1C and quality of life in low-income hispanics and African Americans with diabetes: A randomized, double-blind, placebo-controlled trial. Diabetes Care. 2009;32(12):2156-60. [pmid: 19729522].
232 Ehde DM, Kraft GH, Chwastiak L, et al. Efficacy of paroxetine in treating major depressive disorder in persons with multiple sclerosis. Gen Hosp Psychiatry. Jan-Feb. 2008;30(1):40-8. [pmid: 18164939].
233 Geretsegger C, Bohmer F, Ludwig M. Paroxetine in the elderly depressed patient: randomized comparison with fluoxetine of efficacy, cognitive and behavioural effects. Int Clin Psychopharmacol. Spring. 1994;9(1):25-9. [pmid: 8195578].
234 Glassman AH, O'Connor CM, Califf RM, et al. Sertraline treatment of major depression in patients with acute MI or unstable angina. JAMA. Aug. 14. 2002;288(6):701-9. [pmid: 12169073].
235 Gual A, Balcells M, Torres M, et al. Sertraline for the prevention of relapse in detoxicated alcohol dependent patients with a comorbid depressive disorder: a randomized controlled trial. Alcohol Alcohol. Nov-Dec. 2003;38(6):619-25. [pmid: 14633652].
236 Hernandez-Avila CA, Modesto-Lowe V, Feinn R, et al. Nefazodone treatment of comorbid alcohol dependence and major depression. Alcohol Clin Exp Res. Mar. 2004;28(3):433-40. [pmid: 15084901].
237 Honig A, Kuyper AM, Schene AH, et al. Treatment of post-myocardial infarction depressive disorder: a randomized, placebo-controlled trial with mirtazapine. Psychosom Med. Sep-Oct. 2007;69(7):606-13. [pmid: 17846258].
238 Kranzler HR, Mueller T, Cornelius J, et al. Sertraline treatment of co-occurring alcohol dependence and major depression. J Clin Psychopharmacol. Feb. 2006;26(1):13-20. [pmid: 16415699].
239 Lesperance F, Frasure-Smith N, Koszycki D, et al. Effects of citalopram and interpersonal psychotherapy on depression in patients with coronary artery disease: the Canadian Cardiac Randomized Evaluation of Antidepressant and Psychotherapy Efficacy (CREATE) trial. JAMA. Jan. 24. 2007;297(4):367-79. [pmid: 17244833].
240 Li LT, Wang SH, Ge HY, et al. The beneficial effects of the herbal medicine Free and Easy Wanderer Plus (FEWP) and fluoxetine on post-stroke depression. J Altern Complement Med. Sep. 2008;14(7):841-6. [pmid: 18721085].
241 Lyketsos CG, DelCampo L, Steinberg M, et al. Treating depression in Alzheimer disease: efficacy and safety of sertraline therapy, and the benefits of depression reduction: the DIADS. Arch Gen Psychiatry. Jul. 2003;60(7):737-46. [pmid: 12860778].
242 Moak DH, Anton RF, Latham PK, et al. Sertraline and cognitive behavioral therapy for depressed alcoholics: results of a placebo-controlled trial. J Clin Psychopharmacol. Dec. 2003;23(6):553-62. [pmid: 14624185].
243 Murray V, von Arbin M, Bartfai A, et al. Double-blind comparison of sertraline and placebo in stroke patients with minor depression and less severe major depression. J Clin Psychiatry. Jun. 2005;66(6):708-16. [pmid: 15960563].
244 Ludwig J, Marcotte DE. Anti-depressants, suicide, and drug regulation. J Policy Anal Manage. 2005;24(2):249-72. [pmid: 15776534].
245 O'Connor CM, Jiang W, Kuchibhatla M, et al. Safety and efficacy of sertraline for depression in patients with heart failure: Results of the SADHART-CHF (Sertraline against depression and heart disease in chronic heart failure) trial. J Am Coll Cardiol. 2010;56(9):692-9. [pmid: 20723799].
246 Petrakis I, Carroll KM, Nich C, et al. Fluoxetine treatment of depressive disorders in methadone-maintained opioid addicts. Drug Alcohol Depend. May. 1. 1998;50(3):221-6. [pmid: 9649975].
247 Rabkin JG, Wagner GJ, McElhiney MC, et al. Testosterone versus fluoxetine for depression and fatigue in HIV/AIDS: a placebo-controlled trial. J Clin Psychopharmacol. Aug. 2004;24(4):379-85. [pmid: 15232328].
248 Rosenberg PB, Drye LT, Martin BK, et al. Sertraline for the treatment of depression in alzheimer disease. Am J Geriatr Psychiatry. 2010;18(2):136-45. [pmid: 20087081].
249 Schatzberg A, Roose S. A double-blind, placebo-controlled study of venlafaxine and fluoxetine in geriatric outpatients with major depression. Am J Geriatr Psychiatry. Apr. 2006;14(4):361-70. [pmid: 16582045].
250 Strik JJ, Honig A, Lousberg R, et al. Efficacy and safety of fluoxetine in the treatment of patients with major depression after first myocardial infarction: findings from a double-blind, placebo-controlled trial. Psychosom Med. Nov-Dec. 2000;62(6):783-9. [pmid: 11138997].
251 Wohlreich MM, Sullivan MD, Mallinckrodt CH, et al. Duloxetine for the treatment of recurrent major depressive disorder in elderly patients: treatment outcomes in patients with comorbid arthritis. Psychosomatics. Jul-Aug. 2009;50(4):402-12. [pmid: 19687181].
252 Fava M, McCall WV, Krystal A, et al. Eszopiclone co-administered with fluoxetine in patients with insomnia coexisting with major depressive disorder. Biol Psychiatry. Jun. 1. 2006;59(11):1052-60. [pmid: 16581036].
253 Hochstrasser B, Isaksen PM, Koponen H, et al. Prophylactic effect of citalopram in unipolar, recurrent depression: placebo-controlled study of maintenance therapy. Br J Psychiatry. Apr. 2001;178:304-10. [pmid: 11282808].
254 Fava M, Rush AJ, Alpert JE, et al. Difference in treatment outcome in outpatients with anxious versus nonanxious depression: a STAR*D report. Am J Psychiatry. Mar. 2008;165(3):342-51. [pmid: 18172020].
255 Murray V, Von Arbin M, Bartfai A, et al. Double-blind comparison of sertraline and placebo in stroke patients with minor depression and less severe major depression. J Clin Psychiatry. 2005;66(6):708-16. [pmid: 15960563].
256 Pigott TA, Prakash A, Arnold LM, et al. Duloxetine versus escitalopram and placebo: an 8-month, double-blind trial in patients with major depressive disorder. Curr Med Res Opin. Jun. 2007;23(6):1303-18. [pmid: 17559729].
257 Raskin J, Wiltse CG, Dinkel JJ, et al. Safety and tolerability of duloxetine at 60 mg once daily in elderly patients with major depressive disorder. J Clin Psychopharmacol. Feb. 2008;28(1):32-8. [pmid: 18204338].
258 Wise TN, Wiltse CG, Iosifescu DV, et al. The safety and tolerability of duloxetine in depressed elderly patients with and without medical comorbidity. Int J Clin Pract. Aug. 2007;61(8):1283-93. [pmid: 17590215].
259 Berk M, du Plessis AD, Birkett M, et al. An open-label study of duloxetine hydrochloride, a mixed serotonin and noradrenaline reuptake inhibitor, in patients with DSM-III-R major depressive disorder. Lilly Duloxetine Depression Study Group. Int Clin Psychopharmacol. May. 1997;12(3):137-40. [pmid: 9248869].
260 Fava M, Rush AJ, Wisniewski SR, et al. A comparison of mirtazapine and nortriptyline following two consecutive failed medication treatments for depressed outpatients: a STAR*D report. Am J Psychiatry. Jul. 2006;163(7):1161-72. [pmid: 16816220].
261 Nierenberg AA, Fava M, Trivedi MH, et al. A comparison of lithium and T3 augmentation following two failed medication treatments for depression: A STAR*D report. Am J Psychiatry. 2006;163(9):1519-30. [pmid: 16946176].
262 McGrath PJ, Stewart JW, Fava M, et al. Tranylcypromine versus venlafaxine plus mirtazapine following three failed antidepressant medication trials for depression: a STAR*D report. Am J Psychiatry. Sep. 2006;163(9):1531-41. quiz 666. [pmid: 16946177].
263 Rush AJ, Wisniewski SR, Warden D, et al. Selecting among second-step antidepressant medication monotherapies: predictive value of clinical, demographic, or first-step treatment features. Arch Gen Psychiatry. Aug. 2008;65(8):870-80. [pmid: 18678792].
264 Warden D, Rush AJ, Wisniewski SR, et al. What predicts attrition in second step medication treatments for depression?: a STAR*D Report. Int J Neuropsychopharmacol. May. 2009;12(4):459-73. [pmid: 18611293].
265 Goldstein DJ, Lu Y, Detke MJ, et al. Duloxetine in the treatment of depression: a double-blind placebo-controlled comparison with paroxetine. J Clin Psychopharmacol. Aug. 2004;24(4):389-99. [pmid: 15232330].