# Excluded Studies

## Foreign Languages (6)

1 Berlanga C, Arechavaleta B, Heinze G, et al. A double-blind comparison of nefazodone and fluoxetine in the treatment of depressed outpatients. Salud Mental. 1997;20(3):1-8.
2 Bremner JD. Double-blind comparison of mirtazapine, amitriptyline and placebo in major depression. <ORIGINAL>. DOPPELBLINDVERGLEICH VON MIRTAZAPIN, AMITRIPTYLIN UND PLAZEBO BEI ‘MAJOR DEPRESSION”. Nervenheilkunde. 1996;15(8):533-40.
3 Peters UH, Lenhard P, Metzm M. Therapy of depression in the psychiatrist's office - A double-blind multicenter study. Nervenheilkunde. 1990;9(1):28-31.
4 Schone W, Ludwig M. Paratoxetine in the treatment of geriatric depressed patients - A double-blind comparison with fluoxetine. <ORIGINAL>. PAROXETIN IN DER DEPRESSIONSBEHANDLUNG GERIATRISCHER PATIENTEN - EINE DOPPELBLINDE VERGLEICHSSTUDIE MIT FLUOXETIN. Fortschr Neurol Psychiatr. 1994;62(Suppl 1):16-8. [pmid: 7959520].
5 Skarstein J. A ‘trouble-blind’ placebo controlled comparative study between two new antidepressant agents (Seroxat (R) (paroxetine) and Tolvon (R) (mianserin)). <ORIGINAL>. EN ‘TROUBLE-BLIND’ PLACEBOKONTROLLERT SAMMENLIKNENDE UNDERSOKELSE MELLOM TO NYE ANTIDEPRESSIVER. Tidsskrift For Den Norske Laegeforening. 1998;118(2):265-6. [pmid: 9485626].
6 Tsutsui S, Okuse S, Sasaki D, et al. Clinical evaluation of sertraline hydrochloride, a selective serotonin reuptake inhibitor in the treatment of depression and depressive state: A double blind, group comparison study of sertraline hydrochloride vs. trazodone hydrochloride. Japanese Journal of Neuropsychopharmacology. 1997;19(6):549-68.

## Too Short of Duration (10)

1 Agius M, Gardner J, Liu K, et al. An audit to compare discharge rates and suicidality between antidepressant monotherapies prescribed for unipolar depression. Psychiatr Danub. Jun. 2010;22(2):350-3. [pmid: 20562780].
2 Ahrold TK, Meston CM. Effects of SNS activation on SSRI-induced sexual side effects differ by SSRI. J Sex Marital Ther. 2009;35(4):311-9. [pmid: 19466669].
3 Kluge M, Schussler P, Steiger A. Duloxetine increases stage 3 sleep and suppresses rapid eye movement (REM) sleep in patients with major depression. Eur Neuropsychopharmacol. Jul. 2007;17(8):527-31. [pmid: 17337164].
4 Leo R, Di Lorenzo G, Tesauro M, et al. Association between enhanced soluble CD40 ligand and proinflammatory and prothrombotic states in major depressive disorder: pilot observations on the effects of selective serotonin reuptake inhibitor therapy. J Clin Psychiatry. Nov. 2006;67(11):1760-6. [pmid: 17196057].
5 Papakostas GI, Clain A, Ameral VE, et al. Fluoxetine-clonazepam cotherapy for anxious depression: an exploratory, post-hoc analysis of a randomized, double blind study. Int Clin Psychopharmacol. 2010;25(1):17-21. [pmid: 19898245].
6 Perahia DG, Quail D, Desaiah D, et al. Switching to duloxetine from selective serotonin reuptake inhibitor antidepressants: a multicenter trial comparing 2 switching techniques. J Clin Psychiatry. Jan. 2008;69(1):95-105. [pmid: 18312043].
7 Pinto C, Trivedi JK, Vankar GK, et al. An open-label multicentric study of the tolerability and response to escitalopram treatment in Indian patients with major depressive disorder. J Indian Med Assoc. Jul. 2007;105(7):364. 6. 8 passim. [pmid: 18178988].
8 Shen J, Moller HJ, Wang X, et al. Mirtazapine, a sedating antidepressant, and improved driving safety in patients with major depressive disorder: a prospective, randomized trial of 28 patients. J Clin Psychiatry. Mar. 2009;70(3):370-7. [pmid: 19192466].
9 Warden D, Trivedi MH, Wisniewski SR, et al. Early adverse events and attrition in selective serotonin reuptake inhibitor treatment: A suicide assessment methodology study report. J Clin Psychopharmacol. 2010;30(3):259-66. [pmid: 20473060].
10 Weber-Hamann B, Gilles M, Schilling C, et al. Improved insulin sensitivity in 51 nondiabetic depressed inpatients remitting during antidepressive treatment with mirtazapine and venlafaxine. J Clin Psychopharmacol. Oct. 2008;28(5):581-4. [pmid: 18794665].

## Wrong Population (82)

1 Agosti V, McGrath PJ. Comparison of the effects of fluoxetine, imipramine and placebo on personality in atypical depression. J Affect Disord. Sep. 2002;71(1-3):113-20. [pmid: 12167507].
2 Amsterdam JD, Shults J. Comparison of short-term venlafaxine versus lithium monotherapy for bipolar II major depressive episode: a randomized open-label study. J Clin Psychopharmacol. Apr. 2008;28(2):171-81. [pmid: 18344727].
3 Amsterdam JD, Shults J. Does tachyphylaxis occur after repeated antidepressant exposure in patients with Bipolar II major depressive episode?. J Affect Disord. May. 2009;115(1-2):234-40. [pmid: 18694599].
4 Amsterdam JD, Shults J. Efficacy and safety of long-term fluoxetine versus lithium monotherapy of bipolar II disorder: A randomized, double-blind, placebo-substitution study. Am J Psychiatry. 2010;167(7):792-800. [pmid: 20360317].
5 Amsterdam JD, Shults J. Fluoxetine monotherapy of bipolar type II and bipolar NOS major depression: a double-blind, placebo-substitution, continuation study. Int Clin Psychopharmacol. Sep. 2005;20(5):257-64. [pmid: 16096516].
6 Applebee GA, Attarian HP, Schenck CH. An angry bed partner. J Clin Sleep Med. 2009;5(5):477-9. [pmid: 19961035].
7 Arnold LM, Rosen A, Pritchett YL, et al. A randomized, double-blind, placebo-controlled trial of duloxetine in the treatment of women with fibromyalgia with or without major depressive disorder. Pain. Dec. 15. 2005;119(1-3):5-15. [pmid: 16298061].
8 Bakish D, Cavazzoni P, Chudzik J, et al. Effects of selective serotonin reuptake inhibitors on platelet serotonin parameters in major depressive disorder. Biol Psychiatry. Jan. 15. 1997;41(2):184-90. [pmid: 9018388].
9 Baldwin DS, Reines EH, Guiton C, et al. Escitalopram therapy for major depression and anxiety disorders. Ann Pharmacother. 2007;41(10):1583-92. [pmid: 17848424].
10 Bigos KL, Pollock BG, Aizenstein HJ, et al. Acute 5-HT reuptake blockade potentiates human amygdala reactivity. Neuropsychopharmacology. Dec. 2008;33(13):3221-5. [pmid: 18463627].
11 Black DW, Wesner R, Gabel J. The abrupt discontinuation of fluvoxamine in patients with panic disorder. J Clin Psychiatry. Apr. 1993;54(4):146-9. [pmid: 8486592].
12 Brent D, Emslie G, Clarke G, et al. Switching to another SSRI or to venlafaxine with or without cognitive behavioral therapy for adolescents with SSRI-resistant depression - The TORDIA randomized controlled trial. Journal of the American Medical Association (USA). 08. 01. 2008;299(Aug):901-13.
13 Cankurtaran ES, Ozalp E, Soygur H, et al. Mirtazapine improves sleep and lowers anxiety and depression in cancer patients: superiority over imipramine. Support Care Cancer. Nov. 2008;16(11):1291-8. [pmid: 18299900].
14 Cheung A, Kusumakar V, Kutcher S, et al. Maintenance study for adolescent depression. J Child Adolesc Psychopharmacol. Aug. 2008;18(4):389-94. [pmid: 18759650].
15 Clayton AH, Stewart RS, Fayyad R, et al. Sex differences in clinical presentation and response in panic disorder: pooled data from sertraline treatment studies. Arch Women Ment Health. 2005. Nov. 15.
16 Cohn JB, Wilcox C. A comparison of fluoxetine, imipramine, and placebo in patients with major depressive disorder. J Clin Psychiatry. Mar. 1985;46(3 Pt 2):26-31. [pmid: 3882677].
17 Cornelius JR, Bukstein OG, Douaihy AB, et al. Double-blind fluoxetine trial in comorbid MDD-CUD youth and young adults. Drug Alcohol Depend. 2010;112(1-2):39-45. [pmid: 20576364].
18 Cornelius JR, Chung T, Martin C, et al. Cannabis withdrawal is common among treatment-seeking adolescents with cannabis dependence and major depression, and is associated with rapid relapse to dependence. Addict Behav. Nov. 2008;33(11):1500-5. [pmid: 18313860].
19 Cox LS, Patten CA, Niaura RS, et al. Efficacy of bupropion for relapse prevention in smokers with and without a past history of major depression. J Gen Intern Med. Aug. 2004;19(8):828-34. [pmid: 15242467].
20 Dell'Osso B, Hadley S, Allen A, et al. Escitalopram in the treatment of impulsive-compulsive internet usage disorder: an open-label trial followed by a double-blind discontinuation phase. J Clin Psychiatry. Mar. 2008;69(3):452-6. [pmid: 18312057].
21 Dudley M, Goldney R, Hadzi-Pavlovic D. Are adolescents dying by suicide taking SSRI antidepressants? A review of observational studies. Australasian Psychiatry. 2010;18(3):242-5. [pmid: 20482427].
22 Dutta R, Boydell J, Kennedy N, et al. Suicide and other causes of mortality in bipolar disorder: A longitudinal study. Psychological Medicine. 2007;37(6):839-47. [pmid: 17349107].
23 Eaddy M, Bramley T, Regan T. Time to antidepressant discontinuation: a comparison of controlled-release paroxetine and immediate-release selective serotonin-reuptake inhibitors. Manag Care Interface. Dec. 2003;16(12):22-7. [pmid: 14750459].
24 Einarson A, Choi J, Einarson TR, et al. Incidence of major malformations in infants following antidepressant exposure in pregnancy: Results of a large prospective cohort study. Canadian Journal of Psychiatry. 2009;54(4):242-6.
25 El-Khalili N, Joyce M, Atkinson S, et al. Extended-release quetiapine fumarate (quetiapine XR) as adjunctive therapy in major depressive disorder (MDD) in patients with an inadequate response to ongoing antidepressant treatment: A multicentre, randomized, double-blind, placebo-controlled study. International Journal of Neuropsychopharmacology. 2010;13(7):917-32. [pmid: 20175941].
26 Evans ME. Depression in elderly physically ill in-patients: a 12-month prospective study. Int Clin Psychopharmacol. Winter. 1993;8(4):333-6. [pmid: 8277159].
27 Fiedorowicz JG, Takezawa K, Robinson RG. Risk factors for and correlates of poststroke depression following discontinuation of antidepressants. J Neuropsychiatry Clin Neurosci. Fall. 2007;19(4):399-405. [pmid: 18070842].
28 Fieve RR, Goodnick PJ, Peselow E, et al. Fluoxetine response: endpoint vs pattern analysis. Int Clin Psychopharmacol. Oct. 1986;1(4):320-3. [pmid: 3549877].
29 Gentile S, Bellantuono C. Selective serotonin reuptake inhibitor exposure during early pregnancy and the risk of fetal major malformations: focus on paroxetine. J Clin Psychiatry. 2009;70(3):414-22. [pmid: 19254517].
30 Gibbons RD, Hur K, Bhaumik DK, et al. The relationship between antidepressant medication use and rate of suicide. Archives of General Psychiatry. 2005;62(2):165-72. [pmid: 15699293].
31 Goldberg HL, Finnerty RJ. Trazodone in the treatment of neurotic depression. J Clin Psychiatry. Dec. 1980;41(12 Pt 1):430-4. [pmid: 7440519].
32 Goodman WK, Price LH, Delgado PL, et al. Specificity of serotonin reuptake inhibitors in the treatment of obsessive-compulsive disorder. Comparison of fluvoxamine and desipramine. Arch Gen Psychiatry. Jun. 1990;47(6):577-85. [pmid: 2112374].
33 Habra ME, Baker B, Frasure-Smith N, et al. First episode of major depressive disorder and vascular factors in coronary artery disease patients: Baseline characteristics and response to antidepressant treatment in the CREATE trial. J Psychosom Res. Aug. 2010;69(2):133-41. [pmid: 20624511].
34 Hammad TA, Laughren TP, Racoosin JA. Suicide rates in short-term randomized controlled trials of newer antidepressants. Journal of Clinical Psychopharmacology. 2006;26(2):203-7. [pmid: 16633153].
35 Hetrick Sarah E, Merry Sally N, McKenzie J, et al. Selective serotonin reuptake inhibitors (SSRIs) for depressive disorders in children and adolescents. Cochrane Database of Systematic Reviews. 2007;(3).
36 Juurlink DN, Mamdani MM, Kopp A, et al. The risk of suicide with selective serotonin reuptake inhibitors in the elderly. American Journal of Psychiatry. 2006;163(5):813-21. [pmid: 16648321].
37 Kasckow J, Fellows I, Golshan S, et al. Treatment of subsyndromal depressive symptoms in middle-age and older patients with schizophrenia: Effect of age on response. Am J Geriatr Psychiatry. 2010;18(9):853-7. [pmid: 20808103].
38 Kimmick GG, Lovato J, McQuellon R, et al. Randomized, double-blind, placebo-controlled, crossover study of sertraline (Zoloft) for the treatment of hot flashes in women with early stage breast cancer taking tamoxifen. Breast J. Mar-Apr. 2006;12(2):114-22. [pmid: 16509835].
39 Kraus JE, Horrigan JP, Carpenter DJ, et al. Clinical features of patients with treatment-emergent suicidal behavior following initiation of paroxetine therapy. J Affect Disord. Jan. 2010;120(1-3):40-7. [pmid: 19439363].
40 Lash TL, Cronin-Fenton D, Ahern TP, et al. Breast cancer recurrence risk related to concurrent use of SSRI antidepressants and tamoxifen. Acta Oncol. 2010;49(3):305-12. [pmid: 20156115].
41 Lavretsky H, Siddarth P, Irwin MR. Improving depression and enhancing resilience in family dementia caregivers: A pilot randomized placebo-controlled trial of escitalopram. The American Journal of Geriatric Psychiatry. 2010;18(2):154-62. [pmid: 20104071].
42 Lenox-Smith AJ, Reynolds A. A double-blind, randomised, placebo controlled study of venlafaxine XL in patients with generalised anxiety disorder in primary care. Br J Gen Pract. Oct. 2003;53(495):772-7. [pmid: 14601352].
43 Leon AC, Keller MB, Warshaw MG, et al. Prospective study of fluoxetine treatment and suicidal behavior in affectively ill subjects. Am J Psychiatry. Feb. 1999;156(2):195-201. [pmid: 9989554].
44 Lepola UM, Wade AG, Leinonen EV, et al. A controlled, prospective, 1-year trial of citalopram in the treatment of panic disorder. J Clin Psychiatry. Oct. 1998;59(10):528-34. [pmid: 9818634].
45 Lerman C, Niaura R, Collins BN, et al. Effect of bupropion on depression symptoms in a smoking cessation clinical trial. Psychol Addict Behav. Dec. 2004;18(4):362-6. [pmid: 15631608].
46 Lin CC. Duloxetine treatment of social anxiety disorder with comorbid major depression. J Clin Psychopharmacol. Oct. 2008;28(5):591-2. author reply 2-3. [pmid: 18794669].
47 Lydiatt WM, Denman D, McNeilly DP, et al. A randomized, placebo-controlled trial of citalopram for the prevention of major depression during treatment for head and neck cancer. Arch Otolaryngol Head Neck Surg. May. 2008;134(5):528-35. [pmid: 18490576].
48 March JS, Team T, Silva S, et al. The Treatment for Adolescents with Depression Study (TADS) - Long-term effectiveness and safety outcomes. Archives of General Psychiatry (USA). 10. 01. 2007;64(Oct):1132-44.
49 Markowitz JC, Kocsis JH, Bleiberg KL, et al. A comparative trial of psychotherapy and pharmacotherapy for “pure” dysthymic patients. J Affect Disord. Dec. 2005;89(1-3):167-75. [pmid: 16263177].
50 Martiny K, Lunde M, Simonsen C, et al. Relapse prevention by citalopram in SAD patients responding to 1 week of light therapy. A placebo-controlled study. Acta Psychiatr Scand. Mar. 2004;109(3):230-4. [pmid: 14984396].
51 Maschi S, Clavenna A, Campi R, et al. Neonatal outcome following pregnancy exposure to antidepressants: A prospective controlled cohort study. BJOG: An International Journal of Obstetrics and Gynaecology. 2008;115(2):283-9. [pmid: 17903222].
52 McElroy SL, Weisler RH, Chang W, et al. A Double-Blind, Placebo-Controlled Study of Quetiapine and Paroxetine as Monotherapy in Adults with Bipolar Depression (EMBOLDEN II). J Clin Psychiatry. 2010;71(2):163-74. [pmid: 20122366].
53 Menkes DB, Taghavi E, Mason PA, et al. Fluoxetine's spectrum of action in premenstrual syndrome. Int Clin Psychopharmacol. Summer. 1993;8(2):95-102. [pmid: 8345163].
54 Meyers BS, Flint AJ, Rothschild AJ, et al. A double-blind randomized controlled trial of olanzapine plus sertraline vs olanzapine plus placebo for psychotic depression: the study of pharmacotherapy of psychotic depression (STOP-PD). Arch Gen Psychiatry. 2009;66(8):838-47. [pmid: 19652123].
55 Modell JG, Rosenthal NE, Harriett AE, et al. Seasonal affective disorder and its prevention by anticipatory treatment with bupropion XL. Biol Psychiatry. Oct. 15. 2005;58(8):658-67. [pmid: 16271314].
56 Montejo AL, Prieto N, Terleira A, et al. Better sexual acceptability of agomelatine (25 and 50 mg) compared with paroxetine (20 mg) in healthy male volunteers. An 8-week, placebo-controlled study using the PRSEXDQ-SALSEX scale. J Psychopharmacol (Oxf). 2010;24(1):111-20.
57 Morasco BJ, Loftis JM, Indest DW, et al. Prophylactic antidepressant treatment in patients with hepatitis C on antiviral therapy: a double-blind, placebo-controlled trial. Psychosomatics. Sep-Oct. 2010;51(5):401-8. [pmid: 20833939].
58 Morasco BJ, Rifai MA, Loftis JM, et al. A randomized trial of paroxetine to prevent interferon-alpha-induced depression in patients with hepatitis C. J Affect Disord. Nov. 2007;103(1-3):83-90. [pmid: 17292481].
59 Moscovitch A, Blashko CA, Eagles JM, et al. A placebo-controlled study of sertraline in the treatment of outpatients with seasonal affective disorder. Psychopharmacology (Berl). Feb. 2004;171(4):390-7. [pmid: 14504682].
60 Nakhai-Pour HR, Broy P, Berard A. Use of antidepressants during pregnancy and the risk of spontaneous abortion. CMAJ. 2010;182(10):1031-7. [pmid: 20513781].
61 Narushima K, Kosier JT, Robinson RG. Preventing poststroke depression: a 12-week double-blind randomized treatment trial and 21-month follow-up. J Nerv Ment Dis. May. 2002;190(5):296-303. [pmid: 12011609].
62 Navari RM, Brenner MC, Wilson MN. Treatment of depressive symptoms in patients with early stage breast cancer undergoing adjuvant therapy. Breast Cancer Research and Treatment. 2008;112(1):197-201. [pmid: 18064563].
63 Niedermaier N, Bohrer E, Schulte K, et al. Prevention and treatment of poststroke depression with mirtazapine in patients with acute stroke. J Clin Psychiatry. Dec. 2004;65(12):1619-23. [pmid: 15641866].
64 Parker G, Tully L, Olley A, et al. SSRIs as mood stabilizers for Bipolar II Disorder? A proof of concept study. J Affect Disord. Jun. 2006;92(2-3):205-14. [pmid: 16516304].
65 Pedersen AG. Citalopram and suicidality in adult major depression and anxiety disorders. Nordic Journal of Psychiatry. 2006;60(5):392-9. [pmid: 17038305].
66 Pedersen LH, Henriksen TB, Olsen J. Fetal exposure to antidepressants and normal milestone development at 6 and 19 months of age. Pediatrics. 2010;125(3):e600-e8. [pmid: 20176667].
67 Post RM, Altshuler LL, Leverich GS, et al. Mood switch in bipolar depression: comparison of adjunctive venlafaxine, bupropion and sertraline. Br J Psychiatry. Aug. 2006;189:124-31. [pmid: 16880481].
68 Rayner L, Price A, Evans A, et al. Antidepressants for depression in physically ill people. Cochrane Database of Systematic Reviews. 2010;(3).
69 Robinson RG, Jorge RE, Moser DJ, et al. Escitalopram and problem-solving therapy for prevention of poststroke depression: a randomized controlled trial. JAMA. May. 28. 2008;299(20):2391-400. [pmid: 18505948].
70 Rothbaum BO, Killeen TK, Davidson JR, et al. Placebo-controlled trial of rispeyidone augmentation for selective seyotonin seyotonin inhibitor-resistant civilian posttraumatic stress disorder. J Clin Psychiatry. 04. 01. 2008;69(Apr):520-5. [pmid: 18278987].
71 Roy-Byrne PP, Perera P, Pitts CD, et al. Paroxetine response and tolerability among ethnic minority patients with mood or anxiety disorders: a pooled analysis. J Clin Psychiatry. Oct. 2005;66(10):1228-33. [pmid: 16259535].
72 Royall DR, Cordes JA, Roman G, et al. Sertraline improves executive function in patients with vascular cognitive impairment. J Neuropsychiatry Clin Neurosci. 2009;21(4):445-54. [pmid: 19996254].
73 Safarinejad MR. The effects of the adjunctive bupropion on male sexual dysfunction induced by a selective serotonin reuptake inhibitor: a double-blind placebo-controlled and randomized study. BJU Int. 2010;106(6):840-7. [pmid: 20067456].
74 San L, Arranz B. Mirtazapine: Only for depression?. Acta Neuropsychiatrica. Jun-Aug. 2006. 2006;18(3):130-43.
75 Sheikh JI, Cassidy EL, Doraiswamy PM, et al. Efficacy, safety, and tolerability of sertraline in patients with late-life depression and comorbid medical illness. J Am Geriatr Soc. Jan. 2004;52(1):86-92. [pmid: 14687320].
76 Soares CN, Poitras JR, Prouty J, et al. Efficacy of citalopram as a monotherapy or as an adjunctive treatment to estrogen therapy for perimenopausal and postmenopausal women with depression and vasomotor symptoms. J Clin Psychiatry. Apr. 2003;64(4):473-9. [pmid: 12716252].
77 Stone M, Laughren T, Jones ML, et al. Risk of suicidality in clinical trials of antidepressants in adults: Analysis of proprietary data submitted to US Food and Drug Administration. BMJ. 2009;339(7718):431-4.
78 Varghese S, Kumar A, Sagar R. Ultradian pattern bipolar affective disorder and chronic antidepressant use. [1]. J Postgrad Med. 2007;53(3).
79 Waters CH. Fluoxetine and selegiline--lack of significant interaction. Can J Neurol Sci. Aug. 1994;21(3):259-61. [pmid: 8000982].
80 Wijkstra J, Burger H, van den Broek WW, et al. Treatment of unipolar psychotic depression: a randomized, double-blind study comparing imipramine, venlafaxine, and venlafaxine plus quetiapine. Acta Psychiatr Scand. 2010;121(3):190-200. [pmid: 19694628].
81 Yonkers KA, Lin H, Howell HB, et al. Pharmacologic treatment of postpartum women with new-onset major depressive disorder: a randomized controlled trial with paroxetine. J Clin Psychiatry. 2008;69(4):659-65. [pmid: 18363420].
82 Zanardi R, Franchini L, Serretti A, et al. Venlafaxine versus fluvoxamine in the treatment of delusional depression: a pilot double-blind controlled study. J Clin Psychiatry. Jan. 2000;61(1):26-9. [pmid: 10695642].

## Wrong Drug (120)

1 Ahrold TK, Meston CM. Effects of SNS activation on SSRI-induced sexual side effects differ by SSRI. J Sex Marital Ther. 2009;35(4):311-9. [pmid: 19466669].
2 Alexopoulos GS, Canuso CM, Gharabawi GM, et al. Placebo-controlled study of relapse prevention with risperidone augmentation in older patients with resistant depression. Am J Geriatr Psychiatry. Jan. 2008;16(1):21-30. [pmid: 17928573].
3 Almeida OP, Alfonso H, Hankey GJ, et al. Depression, antidepressant use and mortality in later life: The health in men study. PLoS One. 2010;5(6).
4 Appelberg BG, Syvalahti EK, Koskinen TE, et al. Patients with severe depression may benefit from buspirone augmentation of selective serotonin reuptake inhibitors: results from a placebo-controlled, randomized, double-blind, placebo wash-in study. J Clin Psychiatry. Jun. 2001;62(6):448-52. [pmid: 11465522].
5 Atlantis E, Browning C, Sims J, et al. Diabetes incidence associated with depression and antidepressants in the Melbourne Longitudinal Studies on Healthy Ageing (MELSHA). Int J Geriatr Psychiatry. 2010;25(7):688-96. [pmid: 19806604].
6 Balon R, Yeragani VK, Pohl R, et al. Sexual dysfunction during antidepressant treatment. J Clin Psychiatry. Jun. 1993;54(6):209-12. [pmid: 8331089].
7 Barbosa L, Berk M, Vorster M. A double-blind, randomized, placebo-controlled trial of augmentation with lamotrigine or placebo in patients concomitantly treated with fluoxetine for resistant major depressive episodes. J Clin Psychiatry. Apr. 2003;64(4):403-7. [pmid: 12716240].
8 Barge-Schaapveld DQ, Nicolson NA, van der Hoop RG, et al. Changes in daily life experience associated with clinical improvement in depression. J Affect Disord. May. 17. 1995;34(2):139-54. [pmid: 7665806].
9 Bascara L. A double-blind study to compare the effectiveness and tolerability of paroxetine and amitriptyline in depressed patients. Acta Psychiatr Scand Suppl. 1989;350:141-2. [pmid: 2530771].
10 Basoglu C, Ates MA, Alguel A, et al. Adjuvant Folate with Escitalopram Treatment and Homocystein, Folate, Vitamin B-12 Levels in Patients with Major Depressive Disorder. Bulletin of Clinical Psychopharmacology. 2009:19135.
11 Bauer M, El-Khalili N, Datto C, et al. A pooled analysis of two randomised, placebo-controlled studies of extended release quetiapine fumarate adjunctive to antidepressant therapy in patients with major depressive disorder. J Affect Disord. 2010;127(1-3):19-30. [pmid: 20884063].
12 Baumann P, Nil R, Souche A, et al. A double-blind, placebo-controlled study of citalopram with and without lithium in the treatment of therapy-resistant depressive patients: a clinical, pharmacokinetic, and pharmacogenetic investigation. J Clin Psychopharmacol. Aug. 1996;16(4):307-14. [pmid: 8835706].
13 Bech P, Allerup P, Gram LF, et al. The Diagnostic Melancholia Scale (DMS): dimensions of endogenous and reactive depression with relationship to the Newcastle Scales. J Affect Disord. Mar-Apr. 1988;14(2):161-70. [pmid: 2966830].
14 Berman RM, Darnell AM, Miller HL, et al. Effect of pindolol in hastening response to fluoxetine in the treatment of major depression: a double-blind, placebo-controlled trial. Am J Psychiatry. Jan. 1997;154(1):37-43. [pmid: 8988956].
15 Berman RM, Fava M, Thase ME, et al. Aripiprazole augmentation in major depressive disorder: a double-blind, placebo-controlled study in patients with inadequate response to antidepressants. CNS Spectr. Apr. 2009;14(4):197-206. [pmid: 19407731].
16 Berman RM, Marcus RN, Swanink R, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder: a multicenter, randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Jun. 2007;68(6):843-53. [pmid: 17592907].
17 Beuzen JN, Ravily VF, Souetre EJ, et al. Impact of fluoxetine on work loss in depression. Int Clin Psychopharmacol. Winter. 1993;8(4):319-21. [pmid: 8277155].
18 Blom MB, Jonker K, Dusseldorp E, et al. Combination treatment for acute depression is superior only when psychotherapy is added to medication. Psychother Psychosom. 2007;76(5):289-97. [pmid: 17700049].
19 Bordet R, Thomas P, Dupuis B. Effect of pindolol on onset of action of paroxetine in the treatment of major depression: intermediate analysis of a double-blind, placebo-controlled trial. Reseau de Recherche et d'Experimentation Psychopharmacologique. Am J Psychiatry. Oct. 1998;155(10):1346-51. [pmid: 9766765].
20 Bot M, Pouwer F, Assies J, et al. Eicosapentaenoic acid as an add-on to antidepressant medication for co-morbid major depression in patients with diabetes mellitus: A randomized, double-blind placebo-controlled study. J Affect Disord. 2010;126(1-2):282-6. [pmid: 20466431].
21 Brady KT, Lydiard RB, Kellner CH, et al. A comparison of the effects of imipramine and fluvoxamine on the thyroid axis. Biol Psychiatry. Dec. 1. 1994;36(11):778-9. [pmid: 7858077].
22 Butters MA, Becker JT, Nebes RD, et al. Changes in cognitive functioning following treatment of late-life depression. Am J Psychiatry. Dec. 2000;157(12):1949-54. [pmid: 11097959].
23 Byrne MM. Meta-analysis of early phase II studies with paroxetine in hospitalized depressed patients. Acta Psychiatr Scand Suppl. 1989;350:138-9. [pmid: 2530768].
24 Carney PA, Healy D, Leonard BE. A double-blind study to compare trazodone with amitriptyline in depressed patients. Psychopathology. Suppl 2. 1984;17:37-8. [pmid: 6371877].
25 Carney RM, Freedland KE, Rubin EH, et al. Omega-3 augmentation of sertraline in treatment of depression in patients with coronary heart disease: a randomized controlled trial. Jama. 2009;302(15):1651-7. [pmid: 19843899].
26 Carvalho LA, Gorenstein C, Moreno R, et al. Effect of antidepressants on melatonin metabolite in depressed patients. J Psychopharmacol. May. 2009;23(3):315-21. [pmid: 18562432].
27 Claghorn JL, Johnstone EE, Studebaker SL, et al. The effectiveness of 6-azamianserin (Org 3770) in depressed outpatients. Psychopharmacol Bull. 1987;23(1):160-1. [pmid: 3602313].
28 Clayton AH, Zajecka J, Ferguson JM, et al. Lack of sexual dysfunction with the selective noradrenaline reuptake inhibitor reboxetine during treatment for major depressive disorder. Int Clin Psychopharmacol. May. 2003;18(3):151-6. [pmid: 12702894].
29 Cohn CK, Shrivastava R, Mendels J, et al. Double-blind, multicenter comparison of sertraline and amitriptyline in elderly depressed patients. J Clin Psychiatry. Dec. Suppl B. 1990;51:28-33. [pmid: 2258379].
30 Coppen A, Bailey J. Enhancement of the antidepressant action of fluoxetine by folic acid: a randomised, placebo controlled trial. J Affect Disord. Nov. 2000;60(2):121-30. [pmid: 10967371].
31 Crossley NA, Bauer M. Acceleration and augmentation of antidepressants with lithium for depressive disorders: Two meta-analyses of randomized, placebo-controlled trials. J Clin Psychiatry. Jun. 2007. 2007;68(6):935-40. [pmid: 17592920].
32 Dam J, Ryde L, Svejso J, et al. Morning fluoxetine plus evening mianserin versus morning fluoxetine plus evening placebo in the acute treatment of major depression. Pharmacopsychiatry. Mar. 1998;31(2):48-54. [pmid: 9562208].
33 Dew MA, Whyte EM, Lenze EJ, et al. Recovery from major depression in older adults receiving augmentation of antidepressant pharmacotherapy. Am J Psychiatry. Jun. 2007;164(6):892-9. [pmid: 17541048].
34 Dombrovski AY, Cyranowski JM, Mulsant BH, et al. Which symptoms predict recurrence of depression in women treated with maintenance interpersonal psychotherapy?. Depress Anxiety. 2008;25(12):1060-6. [pmid: 18781665].
35 Dubini A, Bosc M, Polin V. Do noradrenaline and serotonin differentially affect social motivation and behaviour?. Eur Neuropsychopharmacol. Apr. Suppl 1. 1997;7:S49-55. discussion S71-3. [pmid: 9169310].
36 Dunner DL, Amsterdam JD, Shelton RC, et al. Efficacy and tolerability of adjunctive ziprasidone in treatment-resistant depression: a randomized, open-label, pilot study. J Clin Psychiatry. Jul. 2007;68(7):1071-7. [pmid: 17685744].
37 El-Khalili N, Joyce M, Atkinson S, et al. Extended-release quetiapine fumarate (quetiapine XR) as adjunctive therapy in major depressive disorder (MDD) in patients with an inadequate response to ongoing antidepressant treatment: A multicentre, randomized, double-blind, placebo-controlled study. International Journal of Neuropsychopharmacology. 2010;13(7):917-32. [pmid: 20175941].
38 Elgamal S, MacQueen G. Galantamine as an adjunctive treatment in major depression. Journal of Clinical Psychopharmacology (USA). 03. 01. 2008;28(Mar):357-9.
39 Farabaugh A, Mischoulon D, Fava M, et al. The relationship between early changes in the HAMD-17 anxiety/somatization factor items and treatment outcome among depressed outpatients. Int Clin Psychopharmacol. Mar. 2005;20(2):87-91. [pmid: 15729083].
40 Fawcett J, Barkin RL. A meta-analysis of eight randomized, double-blind, controlled clinical trials of mirtazapine for the treatment of patients with major depression and symptoms of anxiety. J Clin Psychiatry. Mar. 1998;59(3):123-7. [pmid: 9541155].
41 Ferreri M, Lavergne F, Berlin I, et al. Benefits from mianserin augmentation of fluoxetine in patients with major depression non-responders to fluoxetine alone. Acta Psychiatr Scand. Jan. 2001;103(1):66-72. [pmid: 11202131].
42 Flint AJ, Rifat SL. Maintenance treatment for recurrent depression in late life. A four-year outcome study. Am J Geriatr Psychiatry. Spring. 2000;8(2):112-6. [pmid: 10804071].
43 Flint AJ, Rifat SL. Two-year outcome of elderly patients with anxious depression. Psychiatry Res. Jan. 15. 1997;66(1):23-31. [pmid: 9061801].
44 Ginestet D. Fluoxetine in endogenous depression and melancholia versus clomipramine. Int Clin Psychopharmacol. Jan. Suppl 1. 1989;4:37-40. [pmid: 2644338].
45 Ginsberg DL. Adjunctive ropinirole for treatment-resistant depression. Primary Psychiatry. 2005;12(8):26-7.
46 Ginsberg DL. Vardenafil Treatment of Sertraline-Induced Anorgasmia in a Woman. Primary Psychiatry. Jan. 2005. 2005;12(1):17-8.
47 Green TD, Reynolds CF 3rd, Mulsant BH, et al. Accelerating antidepressant response in geriatric depression: a post hoc comparison of combined sleep deprivation and paroxetine versus monotherapy with paroxetine, nortriptyline, or placebo. J Geriatr Psychiatry Neurol. Summer. 1999;12(2):67-71. [pmid: 10483927].
48 Guillibert E, Pelicier Y, Archambault JC, et al. A double-blind, multicentre study of paroxetine versus clomipramine in depressed elderly patients. Acta Psychiatr Scand Suppl. 1989;350:132-4. [pmid: 2530766].
49 Guy W, Wilson WH, Ban TA, et al. A double-blind clinical trial of fluvoxamine and imipramine in patients with primary depression. Psychopharmacol Bull. Winter. 1984;20(1):73-8. [pmid: 6425916].
50 Hart S, Fonareva I, Merluzzi N, et al. Treatment for depression and its relationship to improvement in quality of life and psychological well-being in multiple sclerosis patients. Qual Life Res. Apr. 2005;14(3):695-703. [pmid: 16022063].
51 Harvey AT, Silkey BS, Kornstein SG, et al. Acute worsening of chronic depression during a double-blind, randomized clinical trial of antidepressant efficacy: differences by sex and menopausal status. J Clin Psychiatry. Jun. 2007;68(6):951-8. [pmid: 17592923].
52 Holtzheimer PE 3rd, Meeks TW, Kelley ME, et al. A double blind, placebo-controlled pilot study of galantamine augmentation of antidepressant treatment in older adults with major depression. Int J Geriatr Psychiatry. Jun. 2008;23(6):625-31. [pmid: 18058832].
53 Husain MM, Rush JA, Wisniewski SR, et al. Family history of depression and therapeutic outcome: findings from STAR*D. J Clin Psychiatry. Feb. 2009;70(2):185-95. [pmid: 19192454].
54 Katona CL, Abou-Saleh MT, Harrison DA, et al. Placebo-controlled trial of lithium augmentation of fluoxetine and lofepramine. Br J Psychiatry. Jan. 1995;166(1):80-6. [pmid: 7894881].
55 Kennedy S. Flibanserin: Initial evidence of efficacy on sexual dysfunction, in patients with major depressive disorder. Journal of Sexual Medicine. 2010;7(10):3449-59. [pmid: 20646181].
56 Kerr JS, Fairweather DB, Hindmarch I. Effects of fluoxetine on psychomotor performance, cognitive function and sleep in depressed patients. Int Clin Psychopharmacol. Winter. 1993;8(4):341-3. [pmid: 8277161].
57 Kok RM, Nolen WA, Heeren TJ. Venlafaxine versus nortriptyline in the treatment of elderly depressed inpatients: a randomised, double-blind, controlled trial. Int J Geriatr Psychiatry. Dec. 2007;22(12):1247-54. [pmid: 17562523].
58 Kopf D, Westphal S, Luley CW, et al. Lipid metabolism and insulin resistance in depressed patients: significance of weight, hypercortisolism, and antidepressant treatment. J Clin Psychopharmacol. Oct. 2004;24(5):527-31. [pmid: 15349009].
59 Lavretsky H, Park S, Siddarth P, et al. Methylphenidate-enhanced antidepressant response to citalopram in the elderly: a double-blind, placebo-controlled pilot trial. Am J Geriatr Psychiatry. Feb. 2006;14(2):181-5. [pmid: 16473984].
60 Levitan RD, Shen JH, Jindal R, et al. Preliminary randomized double-blind placebo-controlled trial of tryptophan combined with fluoxetine to treat major depressive disorder: antidepressant and hypnotic effects. J Psychiatry Neurosci. Sep. 2000;25(4):337-46. [pmid: 11022398].
61 Lewis-Hall FC, Wilson MG, Tepner RG, et al. Fluoxetine vs. tricyclic antidepressants in women with major depressive disorder. J Womens Health. Jun. 1997;6(3):337-43. [pmid: 9201668].
62 Licht RW, Qvitzau S. Treatment strategies in patients with major depression not responding to first-line sertraline treatment. A randomised study of extended duration of treatment, dose increase or mianserin augmentation. Psychopharmacology (Berl). May. 2002;161(2):143-51. [pmid: 11981594].
63 Loonen AJ, Doorschot CH, Oostelbos MC, et al. Lack of drug interactions between mirtazapine and risperidone in psychiatric patients: a pilot study. Eur Neuropsychopharmacol. Dec. 1999;10(1):51-7. [pmid: 10647097].
64 Marcus RN, McQuade RD, Carson WH, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder: a second multicenter, randomized, double-blind, placebo-controlled study. J Clin Psychopharmacol. Apr. 2008;28(2):156-65. [pmid: 18344725].
65 Michelson D, Adler LA, Amsterdam JD, et al. Addition of atomoxetine for depression incompletely responsive to sertraline: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Apr. 2007;68(4):582-7. [pmid: 17474814].
66 Miranda J, Green BL, Krupnick JL, et al. One-year outcomes of a randomized clinical trial treating depression in low-income minority women. J Consult Clin Psychol. Feb. 2006;74(1):99-111. [pmid: 16551147].
67 Mittmann N, Herrmann N, Einarson TR, et al. The efficacy, safety and tolerability of antidepressants in late life depression: a meta-analysis. J Affect Disord. Dec. 1997;46(3):191-217. [pmid: 9547117].
68 Montgomery SA, Kennedy SH, Burrows GD, et al. Absence of discontinuation symptoms with agomelatine and occurrence of discontinuation symptoms with paroxetine: a randomized, double-blind, placebo-controlled discontinuation study. Int Clin Psychopharmacol. Sep. 2004;19(5):271-80. [pmid: 15289700].
69 Muhonen LH, Lonnqvist J, Lahti J, et al. Age at onset of first depressive episode as a predictor for escitalopram treatment of major depression comorbid with alcohol dependence. Psychiatry Res. May. 15. 2009;167(1-2):115-22. [pmid: 19346004].
70 Mulder RT, Frampton CM, Luty SE, et al. Eighteen months of drug treatment for depression: predicting relapse and recovery. J Affect Disord. Apr. 2009;114(1-3):263-70. [pmid: 18805590].
71 Mulder RT, Joyce PR, Frampton CM, et al. Antidepressant treatment is associated with a reduction in suicidal ideation and suicide attempts. Acta Psychiatr Scand. Aug. 2008;118(2):116-22. [pmid: 18384467].
72 Nathan RS, Perel JM, Pollock BG, et al. The role of neuropharmacologic selectivity in antidepressant action: fluvoxamine versus desipramine. J Clin Psychiatry. Sep. 1990;51(9):367-72. [pmid: 2120201].
73 Nelson JC, Mankoski R, Baker RA, et al. Effects of aripiprazole adjunctive to standard antidepressant treatment on the core symptoms of depression: a post-hoc, pooled analysis of two large, placebo-controlled studies. J Affect Disord. Jan. 2010;120(1-3):133-40. [pmid: 19656577].
74 Nelson JC, Mazure CM, Jatlow PI, et al. Combining norepinephrine and serotonin reuptake inhibition mechanisms for treatment of depression: a double-blind, randomized study. Biol Psychiatry. Feb. 1. 2004;55(3):296-300. [pmid: 14744472].
75 Normann C, Hummel B, Scharer LO, et al. Lamotrigine as adjunct to paroxetine in acute depression: a placebo-controlled, double-blind study. J Clin Psychiatry. Apr. 2002;63(4):337-44. [pmid: 12000208].
76 Nowak G, Siwek M, Dudek D, et al. Effect of zinc supplementation on antidepressant therapy in unipolar depression: a preliminary placebo-controlled study. Pol J Pharmacol. Nov-Dec. 2003;55(6):1143-7. [pmid: 14730113].
77 Onder E, Tural U. Faster response in depressive patients treated with fluoxetine alone than in combination with buspirone. J Affect Disord. Sep. 2003;76(1-3):223-7. [pmid: 12943952].
78 Oslin DW. Treatment of late-life depression complicated by alcohol dependence. Am J Geriatr Psychiatry. Jun. 2005;13(6):491-500. [pmid: 15956269].
79 Otero FJ, Hernandez HC, Martinez AMJ, et al. Fluoxetine/bentazepam combination in the treatment of dysthymic disorders. Ther Res Clin Exp. May. 1994;55(5):519-31.
80 Papakostas GI, Montgomery SA, Thase ME, et al. Comparing the rapidity of response during treatment of major depressive disorder with bupropion and the SSRIs: a pooled survival analysis of 7 double-blind, randomized clinical trials. J Clin Psychiatry. Dec. 2007;68(12):1907-12. [pmid: 18162022].
81 Perry EB, Berman RM, Sanacora G, et al. Pindolol augmentation in depressed patients resistant to selective serotonin reuptake inhibitors: a double-blind, randomized, controlled trial. J Clin Psychiatry. Feb. 2004;65(2):238-43. [pmid: 15003079].
82 Poelinger W, Haber H. Fluoxetine 40 mg vs maprotiline 75 mg in the treatment of out-patients with depressive disorders. Int Clin Psychopharmacol. Jan. Suppl 1. 1989;4:47-50. [pmid: 2644340].
83 Pohl R, Balon R, Jayaraman A, et al. Effect of fluoxetine, pemoline and placebo on heart period and QT variability in normal humans. J Psychosom Res. Sep. 2003;55(3):247-51. [pmid: 12932798].
84 Preskorn SH, Baker B, Kolluri S, et al. An innovative design to establish proof of concept of the antidepressant effects of the NR2B subunit selective N-methyl-D-aspartate antagonist, CP-101,606, in patients with treatment-refractory major depressive disorder. J Clin Psychopharmacol. Dec. 2008;28(6):631-7. [pmid: 19011431].
85 Raja M, Azzoni A. Are antidepressants warranted in the treatment of patients who present suicidal behavior?. Human Psychopharmacology. 2008;23(8):661-8. [pmid: 19016273].
86 Ramaekers JG, Ansseau M, Muntjewerff ND, et al. Considering the P450 cytochrome system as determining combined effects of antidepressants and benzodiazepines on actual driving performance of depressed outpatients. Int Clin Psychopharmacol. May. 1997;12(3):159-69. [pmid: 9248873].
87 Resler G, Lavie R, Campos J, et al. Effect of folic acid combined with fluoxetine in patients with major depression on plasma homocysteine and vitamin B12, and serotonin levels in lymphocytes. Neuroimmunomodulation. 2008;15(3):145-52. [pmid: 18716414].
88 Reynolds CF 3rd, Frank E, Perel JM, et al. High relapse rate after discontinuation of adjunctive medication for elderly patients with recurrent major depression. Am J Psychiatry. Nov. 1996;153(11):1418-22. [pmid: 8890674].
89 Roberts RL, Mulder RT, Joyce PR, et al. No evidence of increased adverse drug reactions in cytochrome P450 CYP2D6 poor metabolizers treated with fluoxetine or nortriptyline. Hum Psychopharmacol. Jan. 2004;19(1):17-23. [pmid: 14716707].
90 Rocca P, Marchiaro L, Rasetti R, et al. A comparison of paroxetine versus paroxetine plus amisulpride in the treatment of dysthymic disorder: efficacy and psychosocial outcomes. Psychiatry Res. Oct. 10. 2002;112(2):145-52. [pmid: 12429360].
91 Rooney A, Grant R. Pharmacological treatment of depression in patients with a primary brain tumour. Cochrane Database of Systematic Reviews. 2010;(3).
92 Roose SP, Glassman AH, Attia E, et al. Cardiovascular effects of fluoxetine in depressed patients with heart disease. Am J Psychiatry. May. 1998;155(5):660-5. [pmid: 9585718].
93 Sanacora G, Berman RM, Cappiello A, et al. Addition of the alpha2-antagonist yohimbine to fluoxetine: effects on rate of antidepressant response. Neuropsychopharmacology. Jun. 2004;29(6):1166-71. [pmid: 15010697].
94 Santos MA, Rocha FL, Hara C. Efficacy and safety of antidepressant augmentation with lamotrigine in patients with treatment-resistant depression: A randomized, placebo-controlled, double-blind study. Primary Care Companion to the Journal of Clinical Psychiatry. 2008;10(3):187-90.
95 Sayyah M, Feizy F, Boostani H. A preliminary randomized double-blind clinical trial on efficacy of estrogen after hysterectomy in postmenopausal women with major depression disorder. Minerva Psichiatr. 2010;51(2):73-7.
96 Scardigli G, Jans G. Comparative double-blind study on efficacy and side-effects of trazodone, nomifensine, mianserin in elderly patients. Adv Biochem Psychopharmacol. 1982;32:229-36. [pmid: 7046366].
97 Scharf MB, Sachais BA. Sleep laboratory evaluation of the effects and efficacy of trazodone in depressed insomniac patients. J Clin Psychiatry. Sep. 1990;51(Suppl):13-7. [pmid: 2211559].
98 Schneider LS, Small GW, Hamilton SH, et al. Estrogen replacement and response to fluoxetine in a multicenter geriatric depression trial. Fluoxetine Collaborative Study Group. Am J Geriatr Psychiatry. Spring. 1997;5(2):97-106. [pmid: 9106373].
99 Segraves RT. Psychiatric drugs and inhibited female orgasm. J Sex Marital Ther. Fall. 1988;14(3):202-7. [pmid: 2902230].
100 Serrano-Bianco A, Gabarron E, Garcia-Bayo I, et al. Effectiveness and cost-effectiveness of antidepressant treatment in primary health care: a six-month randomised study comparing fluoxetine to imipramine. J Affect Disord. Apr. 2006;91(2-3):153-63. [pmid: 16458976].
101 Sheffrin M, Driscoll HC, Lenze EJ, et al. Pilot study of augmentation with aripiprazole for incomplete response in late-life depression: getting to remission. J Clin Psychiatry. Feb. 2009;70(2):208-13. [pmid: 19210951].
102 Smith WT, Londborg PD, Glaudin V, et al. Is extended clonazepam cotherapy of fluoxetine effective for outpatients with major depression?. J Affect Disord. Aug. 2002;70(3):251-9. [pmid: 12128237].
103 Smith WT, Londborg PD, Glaudin V, et al. Short-term augmentation of fluoxetine with clonazepam in the treatment of depression: a double-blind study. Am J Psychiatry. Oct. 1998;155(10):1339-45. [pmid: 9766764].
104 Snedecor SJ, Botteman MF, Schaefer K, et al. Economic outcomes of eszopiclone treatment in insomnia and comorbid major depressive disorder. The journal of mental health policy and economics. 2010;(1):27-35. [pmid: 20571180].
105 Solai LK, Mulsant BH, Pollock BG, et al. Effect of sertraline on plasma nortriptyline levels in depressed elderly. J Clin Psychiatry. Oct. 1997;58(10):440-3. [pmid: 9375595].
106 Stahl S, Zivkov M, Reimitz PE, et al. Meta-analysis of randomized, double-blind, placebo-controlled, efficacy and safety studies of mirtazapine versus amitriptyline in major depression. Acta Psychiatr Scand Suppl. 1997;391:22-30. [pmid: 9265948].
107 Stein MD, Solomon DA, Anderson BJ, et al. Persistence of antidepressant treatment effects in a pharmacotherapy plus psychotherapy trial for active injection drug users. Am J Addict. Jul-Sep. 2005;14(4):346-57. [pmid: 16188715].
108 Storch DD. Successful use of VNS for depression. [15]. Psychiatr Serv. 2006;57(10):1518-9. [pmid: 17035589].
109 Stratta P, Bolino F, Cupillari M, et al. A double-blind parallel study comparing fluoxetine with imipramine in the treatment of atypical depression. Int Clin Psychopharmacol. Winter. 1991;6(3):193-6. [pmid: 1806625].
110 Taragano FE, Bagnatti P, Allegri RF. A double-blind, randomized clinical trial to assess the augmentation with nimodipine of antidepressant therapy in the treatment of “vascular depression”. Int Psychogeriatr. Sep. 2005;17(3):487-98. [pmid: 16252380].
111 Taylor MJ, Carney SM, Goodwin GM, et al. Folate for depressive disorders: systematic review and meta-analysis of randomized controlled trials. J Psychopharmacol. Jun. 2004;18(2):251-6. [pmid: 15260915].
112 Taylor MJ, Rudkin L, Hawton K. Strategies for managing antidepressant-induced sexual dysfunction: Systematic review of randomised controlled trials. J Affect Disord. 2005. Sep. 12.
113 Trivedi MH, Thase ME, Osuntokun O, et al. An integrated analysis of olanzapine/fluoxetine combination in clinical trials of treatment-resistant depression. J Clin Psychiatry. Mar. 2009;70(3):387-96. [pmid: 19284928].
114 Uher R, Farmer A, Henigsberg N, et al. Adverse reactions to antidepressants. Br J Psychiatry. Sep. 2009;195(3):202-10. [pmid: 19721108].
115 van de Merwe TJ, Silverstone T, Ankier SI, et al. A double-blind non-crossover placebo-controlled study between group comparison of trazodone and amitriptyline on cardiovascular function in major depressive disorder. Psychopathology. Suppl 2. 1984;17:64-76. [pmid: 6371879].
116 Ververs T, Kaasenbrood H, Visser G, et al. Prevalence and patterns of antidepressant drug use during pregnancy. Eur J Clin Pharmacol. Oct. 2006;62(10):863-70. [pmid: 16896784].
117 Wagner GJ, Rabkin JG, Rabkin R. A comparative analysis of standard and alternative antidepressants in the treatment of human immunodeficiency virus patients. Compr Psychiatry. Nov-Dec. 1996;37(6):402-8. [pmid: 8932964].
118 Weigmann H, Gerek S, Zeisig A, et al. Fluvoxamine but not sertraline inhibits the metabolism of olanzapine: evidence from a therapeutic drug monitoring service. Ther Drug Monit. Aug. 2001;23(4):410-3. [pmid: 11477325].
119 Wijkstra J, Burger H, van den Broek WW, et al. Treatment of unipolar psychotic depression: a randomized, double-blind study comparing imipramine, venlafaxine, and venlafaxine plus quetiapine. Acta Psychiatr Scand. 2010;121(3):190-200. [pmid: 19694628].
120 Yazicioglu B, Akkaya C, Sarandol A, et al. A comparison of the efficacy and tolerability of reboxetine and sertraline versus venlafaxine in major depressive disorder: a randomized, open-labeled clinical trial. Prog Neuropsychopharmacol Biol Psychiatry. Sep. 30. 2006;30(7):1271-6. [pmid: 16820257].

## Wrong Outcome(191)

1 Ackerman DL, Greenland S, Bystritsky A, et al. Characteristics of fluoxetine versus placebo responders in a randomized trial of geriatric depression. Psychopharmacol Bull. 1997;33(4):707-14. [pmid: 9493483].
2 Ahrold TK, Meston CM. Effects of SNS activation on SSRI-induced sexual side effects differ by SSRI. J Sex Marital Ther. 2009;35(4):311-9. [pmid: 19466669].
3 Almeida OP, Alfonso H, Hankey GJ, et al. Depression, antidepressant use and mortality in later life: The health in men study. PLoS One. 2010;5(6).
4 Almeida OP, Waterreus A, Hankey GJ. Preventing depression after stroke: Results from a randomized placebo-controlled trial. J Clin Psychiatry. Jul. 2006;67(7):1104-9. [pmid: 16889454].
5 Amsterdam JD, Brunswick DJ. Site variability in treatment outcome in antidepressant trials. Prog Neuropsychopharmacol Biol Psychiatry. Jun. 2002;26(5):989-93. [pmid: 12369275].
6 Argyropoulos SV, Hicks JA, Nash JR, et al. Correlation of subjective and objective sleep measurements at different stages of the treatment of depression. Psychiatry Res. Sep. 30. 2003;120(2):179-90. [pmid: 14527649].
7 Armitage R, Yonkers K, Cole D, et al. A multicenter, double-blind comparison of the effects of nefazodone and fluoxetine on sleep architecture and quality of sleep in depressed outpatients. J Clin Psychopharmacol. Jun. 1997;17(3):161-8. [pmid: 9169959].
8 Arroll B, Macgillivray S, Ogston S, et al. Efficacy and tolerability of tricyclic antidepressants and SSRIs compared with placebo for treatment of depression in primary care: a meta-analysis. Ann Fam Med. Sep-Oct. 2005;3(5):449-56. [pmid: 16189062].
9 Bair MJ, Robinson RL, Eckert GJ, et al. Impact of pain on depression treatment response in primary care. Psychosom Med. Jan-Feb. 2004;66(1):17-22. [pmid: 14747633].
10 Baldwin DS, Montgomery SA, Nil R, et al. Discontinuation symptoms in depression and anxiety disorders. International Journal of Neuropsychopharmacology. 2007;10(1):73-84. [pmid: 16359583].
11 Barak Y, Kimhi R, Weizman R. Is selectivity for serotonin uptake associated with a reduced emergence of manic episodes in depressed patients?. Int Clin Psychopharmacol. Jan. 2000;15(1):53-6. [pmid: 10836288].
12 Basoglu C, Ates MA, Alguel A, et al. Adjuvant Folate with Escitalopram Treatment and Homocystein, Folate, Vitamin B-12 Levels in Patients with Major Depressive Disorder. Bulletin of Clinical Psychopharmacology. 2009:19135.
13 Basterzi AD, Yazici K, Asian E, et al. Effects of fluoxetine and venlafaxine on serum brain derived neurotrophic factor levels in depressed patients. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 17. 2009;33(2):281-5. [pmid: 19110026].
14 Basterzi AD, Yazici K, Buturak V, et al. Effects of venlafaxine and fluoxetine on lymphocyte subsets in patients with major depressive disorder: a flow cytometric analysis. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 1. 2010;34(1):70-5. [pmid: 19804808].
15 Beasley CM Jr, Koke SC, Nilsson ME, et al. Adverse events and treatment discontinuations in clinical trials of fluoxetine in major depressive disorder: an updated meta-analysis. Clin Ther. Nov. 2000;22(11):1319-30. [pmid: 11117656].
16 Bech P. Meta-analysis of placebo-controlled trials with mirtazapine using the core items of the Hamilton Depression Scale as evidence of a pure antidepressive effect in the short-term treatment of major depression. Int J Neuropsychopharmacol. Dec. 2001;4(4):337-45. [pmid: 11806859].
17 Bent-Hansen J, Lunde M, Klysner R, et al. The validity of the depression rating scales in discriminating between citalopram and placebo in depression recurrence in the maintenance therapy of elderly unipolar patients with major depression. Pharmacopsychiatry. Nov. 2003;36(6):313-6. [pmid: 14663657].
18 Berman RM, Anand A, Cappiello A, et al. The use of pindolol with fluoxetine in the treatment of major depression: final results from a double-blind, placebo-controlled trial. Biol Psychiatry. May. 1. 1999;45(9):1170-7. [pmid: 10331109].
19 Bigos KL, Pollock BG, Aizenstein HJ, et al. Acute 5-HT reuptake blockade potentiates human amygdala reactivity. Neuropsychopharmacology. Dec. 2008;33(13):3221-5. [pmid: 18463627].
20 Bogner HR, Lin JY, Morales KH. Patterns of early adherence to the antidepressant citalopram among older primary care patients: the prospect study. Int J Psychiatry Med. 2006;36(1):103-19. [pmid: 16927582].
21 Borkowska A, Drozdz W, Ziolkowska-Kochan M, et al. Enhancing effect of mirtazapine on cognitive functions associated with prefrontal cortex in patients with recurrent depression. Neuropsychopharmacol Hung. Oct. 2007;9(3):131-6. [pmid: 18399031].
22 Boulton DW, Balch AH, Royzman K, et al. The pharmacokinetics of standard antidepressants with aripiprazole as adjunctive therapy: studies in healthy subjects and in patients with major depressive disorder. J Psychopharmacol. Apr. 2010;24(4):537-46. [pmid: 18832427].
23 Brown WA, Dornseif BE, Wernicke JF. Placebo response in depression: a search for predictors. Psychiatry Res. Dec. 1988;26(3):259-64. [pmid: 3065807].
24 Brunswick DJ, Amsterdam JD, Fawcett J, et al. Fluoxetine and norfluoxetine plasma concentrations during relapse-prevention treatment. J Affect Disord. Apr. 2002;68(2-3):243-9. [pmid: 12063152].
25 Burke WJ, Dewan V, Wengel SP, et al. The use of selective serotonin reuptake inhibitors for depression and psychosis complicating dementia. Int J Geriatr Psychiatry. May. 1997;12(5):519-25. [pmid: 9193959].
26 Burke WJ, Hendricks SE, McArthur-Campbell D, et al. Fluoxetine and norfluoxetine serum concentrations and clinical response in weekly versus daily dosing. Psychopharmacol Bull. 1996;32(1):27-32. [pmid: 8927671].
27 Burke WJ, Hendricks SE, McArthur-Miller D, et al. Weekly dosing of fluoxetine for the continuation phase of treatment of major depression: results of a placebo-controlled, randomized clinical trial. J Clin Psychopharmacol. Aug. 2000;20(4):423-7. [pmid: 10917403].
28 Camacho F, Kong MC, Sheehan DV, et al. Expenditures associated with dose titration at initiation of therapy in patients with major depressive disorder: A retrospective analysis of a large managed care claims database. P and T. 2010;35(8):452-60. 68. [pmid: 20844695].
29 Candrian M, Schwartz F, Farabaugh A, et al. Personality disorders and perceived stress in major depressive disorder. Psychiatry Res. Aug. 15. 2008;160(2):184-91. [pmid: 18573540].
30 Carney RM, Blumenthal JA, Freedland KE, et al. Depression and late mortality after myocardial infarction in the Enhancing Recovery in Coronary Heart Disease (ENRICHD) study. Psychosom Med. Jul-Aug. 2004;66(4):466-74. [pmid: 15272090].
31 Carvalho LA, Gorenstein C, Moreno R, et al. Effect of antidepressants on melatonin metabolite in depressed patients. J Psychopharmacol. May. 2009;23(3):315-21. [pmid: 18562432].
32 Casciano J, Doyle J, Arikian S, et al. The health economic impact of antidepressant usage from a payer's perspective: a multinational study. Int J Clin Pract. Jun. 2001;55(5):292-9. [pmid: 11452675].
33 Cook IA, Leuchter AF, Witte E, et al. Neurophysiologic predictors of treatment response to fluoxetine in major depression. Psychiatry Res. Mar. 22. 1999;85(3):263-73. [pmid: 10333379].
34 Cookson J, Gilaberte I, Desaiah D, et al. Treatment benefits of duloxetine in major depressive disorder as assessed by number needed to treat. Int Clin Psychopharmacol. Sep. 2006;21(5):267-73. [pmid: 16877897].
35 Cornelius JR, Chung T, Martin C, et al. Cannabis withdrawal is common among treatment-seeking adolescents with cannabis dependence and major depression, and is associated with rapid relapse to dependence. Addict Behav. Nov. 2008;33(11):1500-5. [pmid: 18313860].
36 Cornelius JR, Salloum IM, Ehler JG, et al. Double-blind fluoxetine in depressed alcoholic smokers. Psychopharmacol Bull. 1997;33(1):165-70. [pmid: 9133770].
37 Cravello L, Caltagirone C, Spalletta G. The SNRI venlafaxine improves emotional unawareness in patients with post-stroke depression. Hum Psychopharmacol. Jun. 2009;24(4):331-6. [pmid: 19330795].
38 Davidson J, Watkins L, Owens M, et al. Effects of paroxetine and venlafaxine XR on heart rate variability in depression. J Clin Psychopharmacol. Oct. 2005;25(5):480-4. [pmid: 16160626].
39 de Carvalho GA, Bahls SC, Boeving A, et al. Effects of selective serotonin reuptake inhibitors on thyroid function in depressed patients with primary hypothyroidism or normal thyroid function. Thyroid. Jul. 2009;19(7):691-7. [pmid: 19583486].
40 de Jonge P, Honig A, van Melle JP, et al. Nonresponse to treatment for depression following myocardial infarction: association with subsequent cardiac events. Am J Psychiatry. Sep. 2007;164(9):1371-8. [pmid: 17728422].
41 De Las Cuevas C, de la Rosa MA, Troyano JM, et al. Are psychotropics drugs used in pregnancy?. Pharmacoepidemiol Drug Saf. Sep. 2007;16(9):1018-23. [pmid: 17455181].
42 Debus JR, Rush AJ, Himmel C, et al. Fluoxetine versus trazodone in the treatment of outpatients with major depression. J Clin Psychiatry. Nov. 1988;49(11):422-6. [pmid: 3053668].
43 Desmarais JE, Looper KJ. Interactions between tamoxifen and antidepressants via cytochrome P450 2D6. J Clin Psychiatry. Dec. 2009;70(12):1688-97. [pmid: 20141708].
44 Djulus J, Koren G, Einarson TR, et al. Exposure to mirtazapine during pregnancy: a prospective, comparative study of birth outcomes. J Clin Psychiatry. Aug. 2006;67(8):1280-4. [pmid: 16965209].
45 Dunlop SR, Dornseif BE, Wernicke JF, et al. Pattern analysis shows beneficial effect of fluoxetine treatment in mild depression. Psychopharmacol Bull. 1990;26(2):173-80. [pmid: 2236453].
46 Dunner DL, D'Souza DN, Kajdasz DK, et al. Is treatment-associated hypomania rare with duloxetine: secondary analysis of controlled trials in non-bipolar depression. J Affect Disord. Jul. 2005;87(1):115-9. [pmid: 15967235].
47 Durham LK, Webb SM, Milos PM, et al. The serotonin transporter polymorphism, 5HTTLPR, is associated with a faster response time to sertraline in an elderly population with major depressive disorder. Psychopharmacology (Berl). Aug. 2004;174(4):525-9. [pmid: 12955294].
48 Dursun SM, Bird D, Ronson KE. Nefazodone treatment of dysthymic disorder an open, long-term, prospective pilot study. Prog Neuropsychopharmacol Biol Psychiatry. May. 2002;26(4):671-6. [pmid: 12188098].
49 Eick TJ, Kofoed L. An unusual indication for a single-subject clinical trial. J Nerv Ment Dis. Oct. 1994;182(10):587-90. [pmid: 7931209].
50 Ekselius L, Bengtsson F, von Knorring L. Non-compliance with pharmacotherapy of depression is associated with a sensation seeking personality. Int Clin Psychopharmacol. Sep. 2000;15(5):273-8. [pmid: 10993129].
51 Ekselius L, von Knorring L. Personality disorder comorbidity with major depression and response to treatment with sertraline or citalopram. Int Clin Psychopharmacol. Sep. 1998;13(5):205-11. [pmid: 9817625].
52 Entsuah AR, Bradley MM, Littman GS. Cumulative mean change procedure: application to a comparative trial of venlafaxine, imipramine, and placebo in the treatment of major depression. Prog Neuropsychopharmacol Biol Psychiatry. Jul. 1994;18(4):695-706. [pmid: 7938560].
53 Entsuah AR, Rudolph RL, Hackett D, et al. Efficacy of venlafaxine and placebo during long-term treatment of depression: a pooled analysis of relapse rates. Int Clin Psychopharmacol. Jun. 1996;11(2):137-45. [pmid: 8803651].
54 Entsuah R, Chitra R. A benefit-risk analysis of once-daily venlafaxine extended release (XR) and venlafaxine immediate release (IR) in outpatients with major depression. Psychopharmacol Bull. 1997;33(4):671-6. [pmid: 9493478].
55 Fava M, Labbate LA, Abraham ME, et al. Hypothyroidism and hyperthyroidism in major depression revisited. J Clin Psychiatry. May. 1995;56(5):186-92. [pmid: 7737957].
56 Fava M, Nierenberg AA, Quitkin FM, et al. A preliminary study on the efficacy of sertraline and imipramine on anger attacks in atypical depression and dysthymia. Psychopharmacol Bull. 1997;33(1):101-3. [pmid: 9133758].
57 Ferguson JM, Wesnes KA, Schwartz GE. Reboxetine versus paroxetine versus placebo: effects on cognitive functioning in depressed patients. Int Clin Psychopharmacol. Jan. 2003;18(1):9-14. [pmid: 12490769].
58 Fernandez JL, Montgomery S, Francois C. Evaluation of the cost effectiveness of escitalopram versus venlafaxine XR in major depressive disorder. Pharmacoeconomics. 2005;23(2):155-67. [pmid: 15748090].
59 Fieve RR, Goodnick PJ, Peselow ED, et al. Pattern analysis of antidepressant response to fluoxetine. J Clin Psychiatry. Nov. 1986;47(11):560-2. [pmid: 3533909].
60 Fisch C, Knoebel SB. Electrocardiographic findings in sertraline depression trials. Drug Invest. 1992;4(4):305-12.
61 Garriock HA, Hamilton SP. Genetic studies of drug response and side effects in the STAR*D study, part 2. J Clin Psychiatry. Sep. 2009;70(9):1323-5. [pmid: 19818256].
62 Gau YT, Liou YJ, Yu YW, et al. Evidence for association between genetic variants of p75 neurotrophin receptor (p75NTR) gene and antidepressant treatment response in Chinese major depressive disorder. Am J Med Genet B Neuropsychiatr Genet. Jul. 5. 2008;147B(5):594-9. [pmid: 18081157].
63 Gentile S, Bellantuono C. Selective serotonin reuptake inhibitor exposure during early pregnancy and the risk of fetal major malformations: focus on paroxetine. J Clin Psychiatry. 2009;70(3):414-22. [pmid: 19254517].
64 Gershon S, Georgotas A, Newton R, et al. Clinical evaluation of two new antidepressants. Adv Biochem Psychopharmacol. 1982;32:57-68. [pmid: 6211943].
65 Glassman AH, Bigger JT Jr, Gaffney M. Psychiatric characteristics associated with long-term mortality among 361 patients having an acute coronary syndrome and major depression: seven-year follow-up of SADHART participants. Arch Gen Psychiatry. Sep. 2009;66(9):1022-9. [pmid: 19736359].
66 Glassman AH, Bigger JT, Gaffney M, et al. Onset of major depression associated with acute coronary syndromes: relationship of onset, major depressive disorder history, and episode severity to sertraline benefit. Arch Gen Psychiatry. 2006;63(3):283-8. [pmid: 16520433].
67 Glassman AH, Bigger JT, Gaffney M, et al. Heart rate variability in acute coronary syndrome patients with major depression: influence of sertraline and mood improvement. Arch Gen Psychiatry. Sep. 2007;64(9):1025-31. [pmid: 17768267].
68 Goodnick PJ, Fieve RR, Peselow ED, et al. Double-blind treatment of major depression with fluoxetine: use of pattern analysis and relation of HAM-D score to CGI change. Psychopharmacol Bull. 1987;23(1):162-3. [pmid: 3496624].
69 Greenberg RP, Bornstein RF, Zborowski MJ, et al. A meta-analysis of fluoxetine outcome in the treatment of depression. J Nerv Ment Dis. Oct. 1994;182(10):547-51. [pmid: 7931201].
70 Grossman R, Reynolds D, Goodman M, et al. Efficacy of open-label venlafaxine in subjects with major depressive disorder: associations with neuroendocrine response to serotonergic and noradrenergic probes. Psychiatry Res. Sep. 30. 2004;128(2):203-6. [pmid: 15488964].
71 Gualtieri CT, Johnson LG. Bupropion normalizes cognitive performance in patients with depression. MedGenMed. 2007;9(1):22. [pmid: 17435629].
72 Habra ME, Baker B, Frasure-Smith N, et al. First episode of major depressive disorder and vascular factors in coronary artery disease patients: Baseline characteristics and response to antidepressant treatment in the CREATE trial. J Psychosom Res. Aug. 2010;69(2):133-41. [pmid: 20624511].
73 Hamed A, Lee A, Ren XS, et al. Use of antidepressant medications: are there differences in psychiatric visits among patient treatments in the Veterans Administration?. Med Care. Jun. 2004;42(6):551-9. [pmid: 15167323].
74 Hamilton SP, Nunes EV, Janal M, et al. The effect of sertraline on methadone plasma levels in methadone-maintenance patients. Am J Addict. Winter. 2000;9(1):63-9. [pmid: 10914294].
75 Harvey AT, Silkey BS, Kornstein SG, et al. Acute worsening of chronic depression during a double-blind, randomized clinical trial of antidepressant efficacy: differences by sex and menopausal status. J Clin Psychiatry. Jun. 2007;68(6):951-8. [pmid: 17592923].
76 Haukka J, Arffman M, Partonen T, et al. Antidepressant use and mortality in Finland: A register-linkage study from a nationwide cohort. European Journal of Clinical Pharmacology. 2009;65(7):715-20. [pmid: 19259654].
77 Hayes RL, Gerner RH, Fairbanks L, et al. ECG findings in geriatric depressives given trazodone, placebo, or imipramine. J Clin Psychiatry. May. 1983;44(5):180-3. [pmid: 6343360].
78 Heiligenstein JH, Faries DE, Rush AJ, et al. Latency to rapid eye movement sleep as a predictor of treatment response to fluoxetine and placebo in nonpsychotic depressed outpatients. Psychiatry Res. Jun. 1994;52(3):327-39. [pmid: 7991725].
79 Heiligenstein JH, Tollefson GD, Faries DE. A double-blind trial of fluoxetine, 20 mg, and placebo in out-patients with DSM-III-R major depression and melancholia. Int Clin Psychopharmacol. Winter. 1993;8(4):247-51. [pmid: 8277143].
80 Hellerstein DJ, Kocsis JH, Chapman D, et al. Double-blind comparison of sertraline, imipramine, and placebo in the treatment of dysthymia: effects on personality. Am J Psychiatry. Sep. 2000;157(9):1436-44. [pmid: 10964860].
81 Himmelhoch JM, Schechtman K, Auchenbach R. The role of trazodone in the treatment of depressed cardiac patients. Psychopathology. Suppl 2. 1984;17:51-63. [pmid: 6201941].
82 Hirschfeld RM, Mallinckrodt C, Lee TC, et al. Time course of depression-symptom improvement during treatment with duloxetine. Depress Anxiety. 2005;21(4):170-7. [pmid: 16035056].
83 Hochberg HM, Kanter D, Houser VP. Electrocardiographic findings during extended clinical trials of fluvoxamine in depression: one years experience. Pharmacopsychiatry. Nov. 1995;28(6):253-6. [pmid: 8773292].
84 Hoflich G, Kasper S, Danos P, et al. Thyroid hormones, body temperature, and antidepressant treatment. Biol Psychiatry. Apr. 15. 1992;31(8):859-62. [pmid: 1643199].
85 Hunter AM, Leuchter AF, Morgan ML, et al. Changes in brain function (quantitative EEG cordance) during placebo lead-in and treatment outcomes in clinical trials for major depression. Am J Psychiatry. Aug. 2006;163(8):1426-32. [pmid: 16877657].
86 Hunter AM, Muthén BO, Cook IA, et al. Antidepressant response trajectories and quantitative electroencephalography (QEEG) biomarkers in major depressive disorder. J Psychiatr Res. 2010;(2):90-8. [pmid: 19631948].
87 Husain MM, Rush AJ, Trivedi MH, et al. Pain in depression: STAR*D study findings. J Psychosom Res. Aug. 2007;63(2):113-22. [pmid: 17662746].
88 Hybels CF, Steffens DC, McQuoid DR, et al. Residual symptoms in older patients treated for major depression. Int J Geriatr Psychiatry. 2005;20(12):1196-202. [pmid: 16315146].
89 Jamerson BD, Krishnan KR, Roberts J, et al. Effect of bupropion SR on specific symptom clusters of depression: analysis of the 31-item Hamilton Rating Scale for depression. Psychopharmacol Bull. Spring. 2003;37(2):67-78. [pmid: 14566216].
90 Kato M, Zanardi R, Rossini D, et al. 5-HT2A gene variants influence specific and different aspects of antidepressant response in Japanese and Italian mood disorder patients. Psychiatry Res. May. 15. 2009;167(1-2):97-105. [pmid: 19361869].
91 Katon W, Russo J, Frank E, et al. Predictors of nonresponse to treatment in primary care patients with dysthymia. Gen Hosp Psychiatry. Jan-Feb. 2002;24(1):20-7. [pmid: 11814530].
92 Khan A, Brodhead AE, Kolts RL, et al. Severity of depressive symptoms and response to antidepressants and placebo in antidepressant trials. J Psychiatr Res. 2005;39(2):145-50. [pmid: 15589562].
93 Khandker RK, Kruzikas DT, McLaughlin TP. Pharmacy and medical costs associated with switching between venlafaxine and SSRI antidepressant therapy for the treatment of major depressive disorder. J Manag Care Pharm. Jun. 2008;14(5):426-41. [pmid: 18597572].
94 Kimmick GG, Lovato J, McQuellon R, et al. Randomized, double-blind, placebo-controlled, crossover study of sertraline (Zoloft) for the treatment of hot flashes in women with early stage breast cancer taking tamoxifen. Breast J. Mar-Apr. 2006;12(2):114-22. [pmid: 16509835].
95 Koran LM, Hamilton SH, Hertzman M, et al. Predicting response to fluoxetine in geriatric patients with major depression. J Clin Psychopharmacol. Dec. 1995;15(6):421-7. [pmid: 8748431].
96 Kraus JE, Horrigan JP, Carpenter DJ, et al. Clinical features of patients with treatment-emergent suicidal behavior following initiation of paroxetine therapy. J Affect Disord. Jan. 2010;120(1-3):40-7. [pmid: 19439363].
97 Kraus T, Haack M, Schuld A, et al. Body weight, the tumor necrosis factor system, and leptin production during treatment with mirtazapine or venlafaxine. Pharmacopsychiatry. Nov. 2002;35(6):220-5. [pmid: 12518269].
98 Kreider MS, Bushnell WD, Oakes R, et al. A double-blind, randomized study to provide safety information on switching fluoxetine-treated patients to paroxetine without an intervening washout period. J Clin Psychiatry. Apr. 1995;56(4):142-5. [pmid: 7713852].
99 Kulp W, von der Schulenburg JM, Greiner W. Cost-effectiveness of outpatient treatment in depressive patients with escitalopram in Germany. Eur J Health Econ. Dec. 2005;6(4):317-21. [pmid: 16267659].
100 Lam RW, Gorman CP, Michalon M, et al. Multicenter, placebo-controlled study of fluoxetine in seasonal affective disorder. Am J Psychiatry. Dec. 1995;152(12):1765-70. [pmid: 8526243].
101 Lasch K, Joish VN, Zhu YP, et al. Validation of the sleep impact scale in patients with major depressive disorder and insomnia. Current Medical Research and Opinion (England). 2009;25:1699.
102 Lash TL, Cronin-Fenton D, Ahern TP, et al. Breast cancer recurrence risk related to concurrent use of SSRI antidepressants and tamoxifen. Acta Oncol. 2010;49(3):305-12. [pmid: 20156115].
103 Leo R, Di Lorenzo G, Tesauro M, et al. Association between enhanced soluble CD40 ligand and proinflammatory and prothrombotic states in major depressive disorder: pilot observations on the effects of selective serotonin reuptake inhibitor therapy. J Clin Psychiatry. Nov. 2006;67(11):1760-6. [pmid: 17196057].
104 Leuchter AF, Cook IA, Gilmer WS, et al. Effectiveness of a quantitative electroencephalographic biomarker for predicting differential response or remission with escitalopram and bupropion in major depressive disorder. Psychiatry Res. Sep. 30. 2009. 2009;169(2):132-8. [pmid: 19709754].
105 Leuchter AF, Morgan M, Cook IA, et al. Pretreatment neurophysiological and clinical characteristics of placebo responders in treatment trials for major depression. Psychopharmacology (Berl). Dec. 2004;177(1-2):15-22. [pmid: 15252704].
106 Linden RD, Wilcox CS, Heiser JF, et al. Are selective serotonin reuptake inhibitors well tolerated in somatizing depressives?. Psychopharmacol Bull. 1994;30(2):151-6. [pmid: 7831448].
107 Liu KS, Snavely DB, Ball WA, et al. Is bigger better for depression trials?. J Psychiatr Res. Jul. 2008;42(8):622-30. [pmid: 17825841].
108 Lydiatt WM, Denman D, McNeilly DP, et al. A randomized, placebo-controlled trial of citalopram for the prevention of major depression during treatment for head and neck cancer. Arch Otolaryngol Head Neck Surg. May. 2008;134(5):528-35. [pmid: 18490576].
109 Malone DC. A budget-impact and cost-effectiveness model for second-line treatment of major depression. J Manag Care Pharm. Jul. 2007;13(6 Suppl A):S8-18. [pmid: 17874482].
110 March JS, Team T, Silva S, et al. The Treatment for Adolescents with Depression Study (TADS) - Long-term effectiveness and safety outcomes. Archives of General Psychiatry (USA). 10. 01. 2007;64(Oct):1132-44.
111 Marie-Mitchell A, Leuchter AF, Chou CP, et al. Predictors of improved mood over time in clinical trials for major depression. Psychiatry Res. Jun. 30. 2004;127(1-2):73-84. [pmid: 15261707].
112 Martin-Merino E, Ruigomez A, Garcia Rodriguez LA, et al. Depression and treatment with antidepressants are associated with the development of gastro-oesophageal reflux disease. Aliment Pharmacol Ther. 2010;31(10):1132-40. [pmid: 20199498].
113 Mayer LS, Bay RC, Politis A, et al. Comparison of three rating scales as outcome measures for treatment trials of depression in Alzheimer disease: findings from DIADS. Int J Geriatr Psychiatry. Oct. 2006;21(10):930-6. [pmid: 16955427].
114 McFarlane A, Kamath MV, Fallen EL, et al. Effect of sertraline on the recovery rate of cardiac autonomic function in depressed patients after acute myocardial infarction. Am Heart J. Oct. 2001;142(4):617-23. [pmid: 11579351].
115 Melartin TK, Rytsälä HJ, Leskelä US, et al. Continuity is the main challenge in treating major depressive disorder in psychiatric care. J Clin Psychiatry. 2005;66(2):220-7. [pmid: 15705008].
116 Michelson D, Amsterdam J, Apter J, et al. Hormonal markers of stress response following interruption of selective serotonin reuptake inhibitor treatment. Psychoneuroendocrinology. Feb. 2000;25(2):169-77. [pmid: 10674280].
117 Michelson D, Bancroft J, Targum S, et al. Female sexual dysfunction associated with antidepressant administration: a randomized, placebo-controlled study of pharmacologic intervention. Am J Psychiatry. Feb. 2000;157(2):239-43. [pmid: 10671393].
118 Miranda J, Green BL, Krupnick JL, et al. One-year outcomes of a randomized clinical trial treating depression in low-income minority women. J Consult Clin Psychol. Feb. 2006;74(1):99-111. [pmid: 16551147].
119 Mitchell AJ, Subramaniam H. Prognosis of depression in old age compared to middle age: a systematic review of comparative studies. Am J Psychiatry. Sep. 2005;162(9):1588-601. [pmid: 16135616].
120 Montgomery SA, Pedersen V, Tanghoj P, et al. The optimal dosing regimen for citalopram--a meta-analysis of nine placebo-controlled studies. Int Clin Psychopharmacol. Mar. Suppl 1. 1994;9:35-40. [pmid: 8021436].
121 Murphy GM Jr, Hollander SB, Rodrigues HE, et al. Effects of the serotonin transporter gene promoter polymorphism on mirtazapine and paroxetine efficacy and adverse events in geriatric major depression. Arch Gen Psychiatry. Nov. 2004;61(11):1163-9. [pmid: 15520364].
122 Nelson JC, Mankoski R, Baker RA, et al. Effects of aripiprazole adjunctive to standard antidepressant treatment on the core symptoms of depression: a post-hoc, pooled analysis of two large, placebo-controlled studies. J Affect Disord. Jan. 2010;120(1-3):133-40. [pmid: 19656577].
123 Nierenberg AA, Husain MM, Trivedi MH, et al. Residual symptoms after remission of major depressive disorder with citalopram and risk of relapse: a STAR*D report. Psychol Med. Jan. 2010;40(1):41-50. [pmid: 19460188].
124 Nierenberg AA, Pava JA, Clancy K, et al. Are neurovegetative symptoms stable in relapsing or recurrent atypical depressive episodes?. Biol Psychiatry. Oct. 15. 1996;40(8):691-6. [pmid: 8894060].
125 Nofzinger EA, Reynolds CF 3rd, Thase ME, et al. REM sleep enhancement by bupropion in depressed men. Am J Psychiatry. Feb. 1995;152(2):274-6. [pmid: 7840365].
126 Oakley F, Khin NA, Parks R, et al. Improvement in activities of daily living in elderly following treatment for post-bereavement depression. Acta Psychiatr Scand. Mar. 2002;105(3):231-4. [pmid: 11939978].
127 Ott GE, Rao U, Lin KM, et al. Effect of treatment with bupropion on EEG sleep: relationship to antidepressant response. Int J Neuropsychopharmacol. Sep. 2004;7(3):275-81. [pmid: 15122973].
128 Oxman TE, Hull JG. Social support and treatment response in older depressed primary care patients. J Gerontol B Psychol Sci Soc Sci. Jan. 2001;56(1):P35-45. [pmid: 11192336].
129 Papakostas GI, losifescu DV, Petersen T, et al. Serum cholesterol in the continuation phase of pharmacotherapy with fluoxetine in remitted major depressive disorder. J Clin Psychopharmacol. Aug. 2004;24(4):467-9. [pmid: 15232350].
130 Papakostas GI, Petersen T, Denninger JW, et al. Treatment-related adverse events and outcome in a clinical trial of fluoxetine for major depressive disorder. Ann Clin Psychiatry. Sep-Dec. 2003;15(3-4):187-92. [pmid: 14971864].
131 Papakostas GI, Petersen T, losifescu DV, et al. Obesity among outpatients with major depressive disorder. Int J Neuropsychopharmacol. Mar. 2005;8(1):59-63. [pmid: 15361263].
132 Perlis RH, Alpert J, Nierenberg AA, et al. Clinical and sociodemographic predictors of response to augmentation, or dose increase among depressed outpatients resistant to fluoxetine 20 mg/day. Acta Psychiatr Scand. Dec. 2003;108(6):432-8. [pmid: 14616224].
133 Perlis RH, Moorjani P, Fagerness J, et al. Pharmacogenetic analysis of genes implicated in rodent models of antidepressant response: association of TREK1 and treatment resistance in the STAR(*)D study. Neuropsychopharmacology. Nov. 2008;33(12):2810-9. [pmid: 18288090].
134 Pierson K, Addington D, Addington J, et al. Serum monitoring of antipsychotic drug levels during concomitant administration of sertraline and antipsychotic medication. Can J Psychiatry. Oct. 2006;51(11):715-8. [pmid: 17121171].
135 Polsky D, Onesirosan P, Bauer MS, et al. Duration of therapy and health care costs of fluoxetine, paroxetine, and sertraline in 6 health plans. J Clin Psychiatry. Feb. 2002;63(2):156-64. [pmid: 11874218].
136 Quitkin FM, Petkova E, McGrath PJ, et al. When should a trial of fluoxetine for major depression be declared failed?. Am J Psychiatry. Apr. 2003;160(4):734-40. [pmid: 12668363].
137 Rasanen P, Hakko H, Jokelainen J, et al. Outcome of different types of long-term antidepressant treatments: a 3-year follow-up study of 14182 patients. J Affect Disord. Sep. 1999;55(1):67-71. [pmid: 10512609].
138 Reimherr FW, Wood DR, Byerley B, et al. Characteristics of responders to fluoxetine. Psychopharmacol Bull. Winter. 1984;20(1):70-2. [pmid: 6371874].
139 Reis M, Aberg-Wistedt A, Agren H, et al. Serum disposition of sertraline, N-desmethylsertraline and paroxetine: a pharmacokinetic evaluation of repeated drug concentration measurements during 6 months of treatment for major depression. Hum Psychopharmacol. Jul. 2004;19(5):283-91. [pmid: 15252820].
140 Resler G, Lavie R, Campos J, et al. Effect of folic acid combined with fluoxetine in patients with major depression on plasma homocysteine and vitamin B12, and serotonin levels in lymphocytes. Neuroimmunomodulation. 2008;15(3):145-52. [pmid: 18716414].
141 Rickels K, Derivan A, Entsuah R, et al. Rapid onset of antidepressant activity with venlafaxine treatment. Depression. 1995;3(3):146-53.
142 Robinson RG, Jorge RE, Moser DJ, et al. Escitalopram and problem-solving therapy for prevention of poststroke depression: a randomized controlled trial. JAMA. May. 28. 2008;299(20):2391-400. [pmid: 18505948].
143 Romeo R, Patel A, Knapp M, et al. The cost-effectiveness of mirtazapine versus paroxetine in treating people with depression in primary care. Int Clin Psychopharmacol. May. 2004;19(3):125-34. [pmid: 15107654].
144 Rosenberg PB, Mielke MM, Lyketsos CG. Caregiver assessment of patients' depression in Alzheimer disease: longitudinal analysis in a drug treatment study. Am J Geriatr Psychiatry. Sep. 2005;13(9):822-6. [pmid: 16166413].
145 Ruhe HG, Booij J, v Weert HC, et al. Evidence why paroxetine dose escalation is not effective in major depressive disorder: a randomized controlled trial with assessment of serotonin transporter occupancy. Neuropsychopharmacology. Mar. 2009;34(4):999-1010. [pmid: 18830236].
146 Rush AJ, Fava M, Wisniewski SR, et al. Sequenced treatment alternatives to relieve depression (STAR*D): rationale and design. Control Clin Trials. Feb. 2004;25(1):119-42. [pmid: 15061154].
147 Salloway S, Correia S, Boyle P, et al. MRI subcortical hyperintensities in old and very old depressed outpatients: the important role of age in late-life depression. J Neurol Sci. Nov. 15. 2002;203-204:227-33. [pmid: 12417389].
148 Salzman C, Jimerson D, Vasile R, et al. Response to SSRI antidepressants correlates with reduction in plasma HVA: pilot study. Biol Psychiatry. Oct. 15. 1993;34(8):569-71. [pmid: 8274586].
149 Schins A, Hamulyak K, Scharpe S, et al. Whole blood serotonin and platelet activation in depressed post-myocardial infarction patients. Life Sci. Dec. 24. 2004;76(6):637-50. [pmid: 15567189].
150 Serretti A, Cusin C, Benedetti F, et al. Insomnia improvement during antidepressant treatment and CLOCK gene polymorphism. American Journal of Medical Genetics Neuropsychiatric Genetics. 2005;137(1):36-9.
151 Sheehan DV, Eaddy MT, Shah MB, et al. Differences in total medical costs across the SSRIs for the treatment of depression and anxiety. Am J Manag Care. Oct. 2005;11(12 Suppl):S354-61. [pmid: 16236017].
152 Sit D, Perel JM, Luther JF, et al. Disposition of chiral and racemic fluoxetine and norfluoxetine across childbearing. J Clin Psychopharmacol. 2010;30(4):381-6. [pmid: 20631556].
153 Smajkic A, Weine S, Duric-Bijedic Z, et al. Sertralilne, paroxetine and venlafaxine in refugee post traumatic stress disorder with depression symptoms. Med Arh. 2001;55(1 Suppl 1):35-8. [pmid: 11795192].
154 Small GW, Hamilton SH, Bystritsky A, et al. Clinical response predictors in a double-blind, placebo-controlled trial of fluoxetine for geriatric major depression. Fluoxetine Collaborative Study Group. Int Psychogeriatr. 1995;7(Suppl):41-53. [pmid: 8580391].
155 Small GW, Schneider LS, Hamilton SH, et al. Site variability in a multisite geriatric depression trial. Journal of Geriatric Psychiatry. 1996;11(12):1089-95.
156 Smeraldi E, Zanardi R, Benedetti F, et al. Polymorphism within the promoter of the serotonin transporter gene and antidepressant efficacy of fluvoxamine. Mol Psychiatry. Nov. 1998;3(6):508-11. [pmid: 9857976].
157 Snedecor SJ, Botteman MF, Schaefer K, et al. Economic outcomes of eszopiclone treatment in insomnia and comorbid major depressive disorder. The journal of mental health policy and economics. 2010;(1):27-35. [pmid: 20571180].
158 Sneed JR, Keilp JG, Brickman AM, et al. The specificity of neuropsychological impairment in predicting antidepressant non-response in the very old depressed. Int J Geriatr Psychiatry. Mar. 2008;23(3):319-23. [pmid: 17726720].
159 Sneed JR, Roose SP, Keilp JG, et al. Response inhibition predicts poor antidepressant treatment response in very old depressed patients. Am J Geriatr Psychiatry. Jul. 2007;15(7):553-63. [pmid: 17586780].
160 Spalletta G, Ripa A, Bria P, et al. Response of emotional unawareness after stroke to antidepressant treatment. Am J Geriatr Psychiatry. Mar. 2006;14(3):220-7. [pmid: 16505126].
161 Stain-Malmgren R, Khoury AE, Aberg-Wistedt A, et al. Serotonergic function in major depression and effect of sertraline and paroxetine treatment. Int Clin Psychopharmacol. Mar. 2001;16(2):93-101. [pmid: 11236074].
162 Stein MD, Herman DS, Kettavong M, et al. Antidepressant treatment does not improve buprenorphine retention among opioid-dependent persons. J Subst Abuse Treat. 2010;39(2):157-66. [pmid: 20598836].
163 Stewart JW, Quitkin FM, McGrath PJ, et al. Use of pattern analysis to predict differential relapse of remitted patients with major depression during 1 year of treatment with fluoxetine or placebo. Arch Gen Psychiatry. Apr. 1998;55(4):334-43. [pmid: 9554429].
164 Strik JJ, Honig A, Lousberg R, et al. Cardiac side-effects of two selective serotonin reuptake inhibitors in middle-aged and elderly depressed patients. Int Clin Psychopharmacol. Nov. 1998;13(6):263-7. [pmid: 9861576].
165 Sullivan MD, Katon WJ, Russo JE, et al. Patient beliefs predict response to paroxetine among primary care patients with dysthymia and minor depression. J Am Board Fam Pract. Jan-Feb. 2003;16(1):22-31. [pmid: 12583647].
166 Tadic A, Muller MJ, Rujescu D, et al. The MAOA T941G polymorphism and short-term treatment response to mirtazapine and paroxetine in major depression. Am J Med Genet B Neuropsychiatr Genet. Apr. 5. 2007;144B(3):325-31. [pmid: 17192957].
167 Tadic A, Rujescu D, Muller MJ, et al. A monoamine oxidase B gene variant and short-term antidepressant treatment response. Prog Neuropsychopharmacol Biol Psychiatry. Oct. 1. 2007;31(7):1370-7. [pmid: 17640790].
168 Taylor WD, Kuchibhatla M, Payne ME, et al. Frontal white matter anisotropy and antidepressant remission in late-life depression. PLoS One. 2008;3(9):e3267. [pmid: 18813343].
169 Thase ME. Effects of venlafaxine on blood pressure: a meta-analysis of original data from 3744 depressed patients. J Clin Psychiatry. Oct. 1998;59(10):502-8. [pmid: 9818630].
170 Thase ME, Tran PV, Wiltse C, et al. Cardiovascular profile of duloxetine, a dual reuptake inhibitor of serotonin and norepinephrine. J Clin Psychopharmacol. Apr. 2005;25(2):132-40. [pmid: 15738744].
171 Trivedi MH, Dunner DL, Kornstein SG, et al. Psychosocial outcomes in patients with recurrent major depressive disorder during 2years of maintenance treatment with venlafaxine extended release. Journal of affective disorders. 2010;126(3):420-9. [pmid: 20510459].
172 Trivedi MH, Hollander E, Nutt D, et al. Clinical evidence and potential neurobiological underpinnings of unresolved symptoms of depression. J Clin Psychiatry. 02. 01. 2008;69(Feb):246-58. [pmid: 18363453].
173 Trivedi MH, Rush AJ, Pan JY, et al. Which depressed patients respond to nefazodone and when?. J Clin Psychiatry. Mar. 2001;62(3):158-63. [pmid: 11305700].
174 Trivedi MH, Rush AJ, Wisniewski SR, et al. Factors associated with health-related quality of life among outpatients with major depressive disorder: A STAR*D report. J Clin Psychiatry. 2006;67(2):185-95. [pmid: 16566612].
175 Trivedi MH, Wan GJ, Mallick R, et al. Cost and effectiveness of venlafaxine extended-release and selective serotonin reuptake inhibitors in the acute phase of outpatient treatment for major depressive disorder. J Clin Psychopharmacol. Oct. 2004;24(5):497-506. [pmid: 15349005].
176 Uchida H, Takeuchi H, Suzuki T, et al. Combined treatment with sulpiride and paroxetine for accelerated response in patients with major depressive disorder. J Clin Psychopharmacol. 2005;25(6):545-51. [pmid: 16282835].
177 Uher R, Farmer A, Henigsberg N, et al. Adverse reactions to antidepressants. Br J Psychiatry. Sep. 2009;195(3):202-10. [pmid: 19721108].
178 van Marwijk HW, Ader H, de Haan M, et al. Primary care management of major depression in patients aged > or =55 years: outcome of a randomised clinical trial. Br J Gen Pract. Oct. 2008;28(555):680-6. I. II. discussion 7. [pmid: 18826778].
179 van Zyl LT, Lesperance F, Frasure-Smith N, et al. Platelet and endothelial activity in comorbid major depression and coronary artery disease patients treated with citalopram: the Canadian Cardiac Randomized Evaluation of Antidepressant and Psychotherapy Efficacy Trial (CREATE) biomarker sub-study. J Thromb Thrombolysis. Jan. 2009;27(1):48-56. [pmid: 18188512].
180 Vanelli M, Coca-Perraillon M. Role of patient experience in antidepressant adherence: a retrospective data analysis. Clin Ther. 2008;30(9):1737-45. [pmid: 18840380].
181 Varner RV, Ruiz P, Small DR. Black and white patients response to antidepressant treatment for major depression. Psychiatr Q. Summer. 1998;69(2):117-25. [pmid: 9627929].
182 Ververs T, Kaasenbrood H, Visser G, et al. Prevalence and patterns of antidepressant drug use during pregnancy. Eur J Clin Pharmacol. Oct. 2006;62(10):863-70. [pmid: 16896784].
183 Wade AG, Fernandez JL, Francois C, et al. Escitalopram and duloxetine in major depressive disorder: a pharmacoeconomic comparison using UK cost data. Pharmacoeconomics. 2008;26(11):969-81. [pmid: 18850765].
184 Wade AG, Saragoussi D, Despiegel N, et al. Healthcare expenditure in severely depressed patients treated with escitalopram, generic SSRIs or venlafaxine in the UK. Curr Med Res Opin. 2010;26(5):1161-70. [pmid: 20297951].
185 Wade AG, Schlaepfer TE, Andersen HF, et al. Clinical milestones predict symptom remission over 6-month and choice of treatment of patients with major depressive disorder (MDD). J Psychiatr Res. Feb. 2009;43(5):568-75. [pmid: 18954875].
186 Wade AG, Toumi I, Hemels MEH. A Pharmacoeconomic Evaluation of Escitalopram Versus Citalopram in the Treatment of Severe Depression in the United Kingdom. Clinical Therapeutics: The International Peer-Reviewed Journal of Drug Therapy. Apr. 2005. 2005;27(4):486-96.
187 Warden D, Trivedi MH, Wisniewski SR, et al. Early adverse events and attrition in selective serotonin reuptake inhibitor treatment: A suicide assessment methodology study report. J Clin Psychopharmacol. 2010;30(3):259-66. [pmid: 20473060].
188 Wu E, Greenberg P, Yang E, et al. Comparison of treatment persistence, hospital utilization and costs among major depressive disorder geriatric patients treated with escitalopram versus other SSRI/SNRI antidepressants. Curr Med Res Opin. Oct. 2008;24(10):2805-13. [pmid: 18755054].
189 Wu EQ, Ben-Hamadi R, Yu AP, et al. Healthcare utilization and costs incurred by patients with major depression after being switched from escitalopram to another SSRI for non-medical reasons. Journal of Medical Economics. 2010;13(2):314-23. [pmid: 20504111].
190 Yu-Isenberg KS, Fontes CL, Wan GJ, et al. Acute and continuation treatment adequacy with venlafaxine extended release compared with fluoxetine. Pharmacotherapy. Jan. 2004;24(1):33-40. [pmid: 14740786].
191 Zaharia MD, Ravindran AV, Griffiths J, et al. Lymphocyte proliferation among major depressive and dysthymic patients with typical or atypical features. J Affect Disord. Apr. 2000;58(1):1-10. [pmid: 10760553].

## Wrong Publication(239)

1 The brain tells: early signs of depression recovery. Harv Ment Health Lett. Nov. 2002;19(5):6.
2 Novel selective serotonin reuptake inhibitors, Part II. J Clin Psychiatry. Jun. 1992;53(6):216-21. [pmid: 1535073].
3 Safety and efficacy of paroxetine in elderly patients. Geriatrics. Nov. Suppl 2. 1993;48:13-5.
4 SSRIs: Prozac and company - part II. Harv Ment Health Lett. Nov. 2000;17(5):1-3.
5 Abraham G. Massive weight gain and hostility force mirtazapine stoppage. Can J Psychiatry. Aug. 2002;47(6):582. [pmid: 12211888].
6 Albert R, Ebert D. Full efficacy of SSRI treatment in refractory dysthymia is achieved only after 16 weeks. J Clin Psychiatry. Apr. 1996;57(4):176. [pmid: 8601556].
7 Alevizos B, Vaidakis N, Alevizos E. Increased libido with the combined use of venlafaxine and mirtazapine. J Clin Psychopharmacol. Apr. 2005;25(2):194-6. [pmid: 15738758].
8 Alonso M, Val E, Rapaport MH. An open-label study of SSRI treatment in depressed hispanic and non-Hispanic women. J Clin Psychiatry. Jan. 1997;58(1):31. [pmid: 9055837].
9 Altman EM, Manos GH. Serotonin syndrome associated with citalopram and meperidine. Psychosomatics. Jul-Aug. 2007;48(4):361-3. [pmid: 17600178].
10 Altshuler LL. Fluoxetine-associated panic attacks. J Clin Psychopharmacol. Dec. 1994;14(6):433-4. [pmid: 7884030].
11 Altshuler LL, Pierre JM, Wirshing WC, et al. Sertraline and akathisia. J Clin Psychopharmacol. Aug. 1994;14(4):278-9. [pmid: 7962686].
12 Andersohn F, Willich SN. Interaction of serotonin reuptake inhibitors with tamoxifen. BMJ. 2010;340:c783. [pmid: 20142323].
13 Anghelescu I, Klawe C, Dahmen N. Venlafaxine in a patient with idiopathic leukopenia and mirtazapine-induced severe neutropenia. J Clin Psychiatry. Sep. 2002;63(9):838. [pmid: 12363126].
14 Applebee GA, Attarian HP, Schenck CH. An angry bed partner. J Clin Sleep Med. 2009;5(5):477-9. [pmid: 19961035].
15 Artigas F, Perez V, Alvarez E. Pindolol induces a rapid improvement of depressed patients treated with serotonin reuptake inhibitors. Arch Gen Psychiatry. Mar. 1994;51(3):248-51. [pmid: 8122960].
16 Ashleigh EA, Fesler FA. Fluoxetine and suicidal preoccupation. Am J Psychiatry. Dec. 1992;149(12):1750. [pmid: 1443254].
17 Ashton AK. Lack of desipramine toxicity with citalopram. J Clin Psychiatry. Feb. 2000;61(2):144. [pmid: 10732663].
18 Avorn J. Depression in the elderly--falls and pitfalls. N Engl J Med. Sep. 24. 1998;339(13):918-20. [pmid: 9744979].
19 Bajbouj M, Danker-Hopfe H. Maintenance treatment of depression in old age. N Engl J Med. Jun. 8. 2006;354(23):2505-6. author reply -6. [pmid: 16764055].
20 Baldessarini RJ, Pompili M, Tondo L. Suicidal risk in antidepressant drug trials. Arch Gen Psychiatry. 2006;63(3):246-8. [pmid: 16520428].
21 Ballesteros J, Callado LF, Gutiérrez M. An independent meta-analysis using summary data for clinical response, remission, and discontinuation for any reason from the 6 pivotal phase III randomized clinical trials of duloxetine in major depressive disorder. J Clin Psychopharmacol. Apr. 2007. 2007;27(2):219-21. [pmid: 17414254].
22 Bauer M, Hellweg R, Baumgartner A. Fluoxetine-induced akathisia does not reappear after switch to paroxetine. J Clin Psychiatry. Dec. 1996;57(12):593-4. [pmid: 9010125].
23 Benazzi F. Fluoxetine and olanzapine for resistant depression. American Journal of Psychiatry. 2002;159(1):155-6. [pmid: 11772722].
24 Benazzi F. Hemorrhages during escitalopram-venlafaxine-mirtazapine combination treatment of depression. Can J Psychiatry. Mar. 2005;50(3):184. [pmid: 15830829].
25 Benazzi F. Severe anticholinergic side effects with venlafaxine-fluoxetine combination. Can J Psychiatry. Nov. 1997;42(9):980-1. [pmid: 9429070].
26 Benazzi F. Urinary retention with fluoxetine-haloperidol combination in a young patient. Can J Psychiatry. Nov. 1996;41(9):606-7. [pmid: 8946091].
27 Benazzi F. Venlafaxine-fluoxetine-nortriptyline interaction. J Psychiatry Neurosci. Jul. 1997;22(4):278-9. [pmid: 9262050].
28 Benazzi F. Venlafaxine-fluoxetine interaction. J Clin Psychopharmacol. Feb. 1999;19(1):96-8. [pmid: 9934950].
29 Benazzi F. Venlafaxine drug-drug interactions in clinical practice. J Psychiatry Neurosci. May. 1998;23(3):181-2. [pmid: 9595894].
30 Bhanji NH. Serotonin syndrome following low-dose sertraline. Can J Psychiatry. Dec. 2000;45(10):936-7. [pmid: 11190366].
31 Blier P, Ward HE, Tremblay P. Combination of antidepressant from treatment initiation for depression. American Psychiatric Association annual meeting. 2006.
32 Bobo WV, Shelton RC. Fluoxetine and olanzapine combination therapy in treatment-resistant major depression: review of efficacy and safety data. Expert Opin Pharmacother. Sep. 2009;10(13):2145-59. [pmid: 19640209].
33 Bolukbasi O, Akyol A. Spontaneous erections and libido increase associated with venlafaxine. Eur J Neurol. Jul. 1999;6(4):527-8. [pmid: 10362913].
34 Bossini L, Fagiolini A, Valdagno M, et al. Sexual disorders in subjects treated for mood and anxiety diseases. [8]. J Clin Psychopharmacol. 2007;27(3):310-2. [pmid: 17502785].
35 Bouman WP, Johnson H, Trescoli-Serrano C, et al. Recurrent hyponatremia associated with sertraline and lofepramine. Am J Psychiatry. Apr. 1997;154(4):580. [pmid: 9090354].
36 Bourgeois JA. Reversible hyponatremia and venlafaxine. Psychosomatics. Sep-Oct. 2005;46(5):495-6. [pmid: 16145194].
37 Brent D. Antidepressants and suicidal behavior: Cause or cure?. Am J Psychiatry. 2007;164(7):989-91. [pmid: 17606644].
38 Browne JL, Rice JL, Evans DL, et al. Triiodothyronine augmentation of the antidepressant effect of the nontricyclic antidepressant trazodone. J Nerv Ment Dis. Sep. 1990;178(9):598-9. [pmid: 2394983].
39 Buni TM. Treatment of dysthymia. J Fam Pract. Jun. 1997;44(6):528-9. [pmid: 9191617].
40 Burrai C, Bocchetta A, del Zompo M. Mania and fluvoxamine. Am J Psychiatry. Sep. 1991;148(9):1263-4. [pmid: 1909099].
41 Bushell I, Newton W. SSRI or tricyclics for depression?. J Fam Pract. Oct. 1996;43(4):345-6. [pmid: 8874367].
42 Carroll BJ. Citalopram and the Curate's egg in geriatric depression. Am J Psychiatry. Sep. 2005;162(9):1762. author reply -3. [pmid: 16135653].
43 Carroll BJ. Sertraline and the Cheshire cat in geriatric depression. Am J Psychiatry. Jun. 2004;161(6):1145-6. [pmid: 15169734].
44 Chelben J, Strous RD, Lustig M, et al. Remission of SSRI-induced akathisia after switch to nefazodone. J Clin Psychiatry. Jul. 2001;62(7):570-1. [pmid: 11488371].
45 Christensen RC. Adverse interaction of paroxetine and cyproheptadine. J Clin Psychiatry. Sep. 1995;56(9):433-4. [pmid: 7665546].
46 Chuang YF, Chiu YL, Hwang TJ, et al. Delirium and multiple electrolyte abnormalities associated with high dose paroxetine exposure. Psychiatry Clin Neurosci. Oct. 2006;60(5):642-3. [pmid: 16958954].
47 Cipriani A, Barbui C, Geddes JR. Suicide, depression, and antidepressants. Br Med J. 2005;330(7488):373-4. [pmid: 15718515].
48 Cohen BJ, Mahelsky M, Adler L. More cases of SIADH with fluoxetine. Am J Psychiatry. Jul. 1990;147(7):948-9. [pmid: 2356883].
49 Cohen LS, Altshuler LL, Harlow BL, et al. Relapse of major depression during pregnancy in women who maintain or discontinue antidepressant treatment: Commentary. Obstet Gynecol Surv. 2006;61(6):368-70.
50 Coplan JD, Gorman JM. Detectable levels of fluoxetine metabolites after discontinuation: an unexpected serotonin syndrome. Am J Psychiatry. May. 1993;150(5):837. [pmid: 8480837].
51 Cornelius JR, Bukstein OG, Salloum IM, et al. Fluoxetine in depressed AUD adolescents: a 1-year follow-up evaluation. J Child Adolesc Psychopharmacol. Spring. 2004;14(1):33-8. [pmid: 15142389].
52 Cowen PJ, Ogilvie AD, Gama J. Efficacy, safety and tolerability of duloxetine 60 mg once daily in major depression. Curr Med Res Opin. 2005;21(3):345-55. [pmid: 15811202].
53 Crews JR, Potts NL, Schreiber J, et al. Hyponatremia in a patient treated with sertraline. Am J Psychiatry. Oct. 1993;150(10):1564. [pmid: 8379571].
54 Crowe D, Collins JP, Rosse RB. Thyroid hormone supplementation of fluoxetine treatment. J Clin Psychopharmacol. Apr. 1990;10(2):150-1. [pmid: 2341594].
55 D'Mello DA, Meland R, Ransom S. Nefazodone and hypotension: complication or coincidence. J Clin Psychopharmacol. Apr. 1997;17(2):136. [pmid: 10950489].
56 de Jong J, Hoogenboom B, van Troostwijk LD, et al. Interaction of olanzapine with fluvoxamine. Psychopharmacology (Berl). May. 2001;155(2):219-20. [pmid: 11401013].
57 DeVane CL, Markowitz JS, Hardesty SJ, et al. Fluvoxamine-induced theophylline toxicity. Am J Psychiatry. Sep. 1997;154(9):1317-8. [pmid: 9286199].
58 Devarajan S. Interaction of fluoxetine and chloral hydrate. Can J Psychiatry. Oct. 1992;37(8):590-1. [pmid: 1423165].
59 Divinsky M. A clinical dilemma. Can Fam Physician. Mar. 1996;42:406. [pmid: 8616279].
60 Dolder C, Nelson M, Stump A. Pharmacological and clinical profile of newer antidepressants: implications for the treatment of elderly patients. Drugs Aging. Aug. 1. 2010;27(8):625-40. [pmid: 20658791].
61 Droulers A, Bodak N, Oudjhani M, et al. Decrease of valproic acid concentration in the blood when coprescribed with fluoxetine. J Clin Psychopharmacol. Apr. 1997;17(2):139-40. [pmid: 10950492].
62 Duggal HS, Fetchko J. Serotonin syndrome and atypical antipsychotics. Am J Psychiatry. Apr. 2002;159(4):672-3. [pmid: 11925312].
63 Elgamal S, MacQueen G. Galantamine as an adjunctive treatment in major depression. Journal of Clinical Psychopharmacology (USA). 03. 01. 2008;28(Mar):357-9.
64 Entsuah R, Derivan A, Kikta D. Early onset of antidepressant action of venlafaxine: pattern analysis in intent-to-treat patients. Clin Ther. May-Jun. 1998;20(3):517-26. [pmid: 9663367].
65 Extein IL. Recent fluoxetine treatment and complications of tricyclic therapy. Am J Psychiatry. Nov. 1991;148(11):1601-2. [pmid: 1928480].
66 Fava GA, Ruini C, Sonino N. Management of recurrent depression in primary care. Psychother Psychosom. Jan-Feb. 2003;72(1):3-9. [pmid: 12466632].
67 Fava M, Rush AJ, Thase ME, et al. 15 Years of clinical experience with bupropion HCl: From bupropion to bupropion SR to bupropion XL. Primary Care Companion to the Journal of Clinical Psychiatry. 2005;7(3):106-13.
68 Fichtner CG, Jobe TH, Braun BG. Does fluoxetine have a therapeutic window?. Lancet. Aug. 24. 1991;338(8765):520-1. [pmid: 1678484].
69 Finfgeld DL. SSRI-related hyponatremia among aging adults. J Psychosoc Nurs Ment Health Serv. Apr. 2003;41(4):12-6. [pmid: 12698818].
70 Finnegan KT, Gabiola JM. Fluoxetine overdose. Am J Psychiatry. Dec. 1988;145(12):1604. [pmid: 3264119].
71 Fisfalen ME, Hsiung RC. Glucose dysregulation and mirtazapine-induced weight gain. Am J Psychiatry. Apr. 2003;160(4):797. [pmid: 12668379].
72 Flint AJ, Crosby J, Genik JL. Recurrent hyponatremia associated with fluoxetine and paroxetine. Am J Psychiatry. Jan. 1996;153(1):134. [pmid: 8540575].
73 Franco K, Malhotra S. Poststroke depression. Am J Psychiatry. Apr. 2001;158(4):658-60. [pmid: 11282720].
74 Frank C. Recognition and treatment of serotonin syndrome. Can Fam Physician. Jul. 2008;54(7):988-92. [pmid: 18625822].
75 Freeman MP. An imperfect literature and evidence-based medicine. J Clin Psychiatry. Mar. 2009;70(3):412-3. [pmid: 19317958].
76 Gagiano CA, Muller PG, Fourie J, et al. The therapeutic efficacy of paroxetine: (a) an open study in patients with major depression not responding to antidepressants; (b) a double-blind comparison with amitriptyline in depressed outpatients. Acta Psychiatr Scand Suppl. 1989;350:130-1. [pmid: 2530765].
77 Gallimore C. Pharmacological Management of Treatment-Resistant Depression Alternative therapies often required to alleviate symptoms. Journal of the Pharmacy Society of Wisconsin (USA). 01. 01. 2008;(NOV-DEC):18-22.
78 Gentile S. Quetiapine-fluvoxamine combination during pregnancy and while breastfeeding. Arch Womens Ment Health. May. 2006;9(3):158-9. [pmid: 16683078].
79 Gillman K. Venlafaxine-lithium toxicity: suitability for use in the elderly. J Clin Pharm Ther. Oct. 2007;32(5):529-31. [pmid: 17875121].
80 Gilmer WS, Kemp DE. STAR*D: What have we learned thus far?. International Drug Therapy Newsletter (USA). 10. 01. 2006;41(Oct).
81 Ginsberg DL. Adjunctive ropinirole for treatment-resistant depression. Primary Psychiatry. 2005;12(8):26-7.
82 Ginsberg DL. Vardenafil Treatment of Sertraline-Induced Anorgasmia in a Woman. Primary Psychiatry. Jan. 2005. 2005;12(1):17-8.
83 Goldberg JF, Sacks MH, Kocsis JH. Attenuation of response to serotonin reuptake inhibitors. Am J Psychiatry. Jun. 1995;152(6):954. [pmid: 7755133].
84 Goldstein DJ. Duloxetine in the treatment of major depressive disorder. Neuropsychiatric Disease and Treatment. 2007. 2007;3(2):193-209. [pmid: 19300553].
85 Goldstein L, Barker M, Segall F, et al. Seizure and transient SIADH associated with sertraline. Am J Psychiatry. May. 1996;153(5):732. [pmid: 8615425].
86 Gonzalez-Pinto A, Imaz H, De Heredia JL, et al. Mania and tramadol-fluoxetine combination. Am J Psychiatry. Jun. 2001;158(6):964-5. [pmid: 11384912].
87 Gulsun M, Doruk A. Mirtazapine-induced akathisia. J Clin Psychopharmacol. Aug. 2008;28(4):467. [pmid: 18626283].
88 Gupta AK, Saravay SM. Venlafaxine-induced hyponatremia. J Clin Psychopharmacol. Jun. 1997;17(3):223-5. [pmid: 9169969].
89 Gupta S, Ghaly N, Dewan M. Augmenting fluoxetine with dextroamphetamine to treat refractory depression. Hosp Community Psychiatry. Mar. 1992;43(3):281-3. [pmid: 1555827].
90 Gupta S, Major LF. Hair loss associated with fluoxetine. Br J Psychiatry. Nov. 1991;159:737-8. [pmid: 1756373].
91 Hadikusumo B, Ng B. Serotonin syndrome induced by duloxetine. Aust N Z J Psychiatry. Jun. 2009;43(6):581-2. [pmid: 19452666].
92 Hargrave R, Martinez D, Bernstein AJ. Fluoxetine-induced seizures. Psychosomatics. Spring. 1992;33(2):236-9. [pmid: 1557494].
93 Hendrick V, Altshuler L. Management of major depression during pregnancy. Am J Psychiatry. Oct. 2002;159(10):1667-73. [pmid: 12359670].
94 Henry NL, Stearns V, Flockhart DA, et al. Drug interactions and pharmacogenomics in the treatment of breast cancer and depression. Am J Psychiatry. Oct. 2008;165(10):1251-5. [pmid: 18829880].
95 Himmerich H, Fulda S, Schaaf L, et al. Changes in weight and glucose tolerance during treatment with mirtazapine. Diabetes Care. Jan. 2006;29(1):170. [pmid: 16373922].
96 Hirschfeld RM. Efficacy of SSRIs and newer antidepressants in severe depression: comparison with TCAs. J Clin Psychiatry. May. 1999;60(5):326-35. [pmid: 10362442].
97 Hollister LE, Krajewski K, Rustin T, et al. Drugs for cocaine dependence: not easy. Arch Gen Psychiatry. Nov. 1992;49(11):905-6. [pmid: 1444730].
98 Holshoe JM. Antidepressants and sleep: a review. Perspect Psychiatr Care. Jul. 2009;45(3):191-7. [pmid: 19566691].
99 Hon D, Preskorn SH. Mania during fluoxetine treatment for recurrent depression. Am J Psychiatry. Dec. 1989;146(12):1638-9. [pmid: 2589562].
100 Howland RH. Electroencephalography technology for predicting response to antidepressant medications. J Psychosoc Nurs Ment Health Serv. Oct. 2006. 2006;44(10):11-4.
101 Hunziker ME, Suehs BT, Bettinger TL, et al. Duloxetine hydrochloride: a new dual-acting medication for the treatment of major depressive disorder. Clin Ther. 2005;27(8):1126-43. [pmid: 16199241].
102 Hwang JP, Yang CH, Tsai SJ. Comparison study of venlafaxine and paroxetine for the treatment of depression in elderly Chinese inpatients. Int J Geriatr Psychiatry. Feb. 2004;19(2):189-90. [pmid: 14758586].
103 Imperadore G, Cipriani A, Signoretti A, et al. Citalopram versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2007;(2).
104 indicated Na. Antidepressant efficacy may be enhanced with dual reuptake inhibition. South African Psychiatry Review. Feb. 2006. 2006;9(1):65.
105 Isaac MT, Tome MB. Pindolol-paroxetine combination. Am J Psychiatry. Dec. 1997;154(12):1790-1. [pmid: 9396965].
106 Isaac MT, Tome MB. Selective serotonin reuptake inhibitors plus pindolol. Lancet. Jul. 26. 1997;350(9073):288-9. [pmid: 9242815].
107 Ishii M, Tatsuzawa Y, Yoshino A, et al. Serotonin syndrome induced by augmentation of SSRI with methylphenidate. Psychiatry Clin Neurosci. Apr. 2008;62(2):246. [pmid: 18412855].
108 Jacob S, Spinler SA. Hyponatremia associated with selective serotonin-reuptake inhibitors in older adults. Ann Pharmacother. Sep. 2006;40(9):1618-22. [pmid: 16896026].
109 Jakob F, Wolf J. EPMS under antidepressive therapy with fluvoxamine and concomitant antibiotic therapy with clindamycin. Pharmacopsychiatry. May. 2007;40(3):129. [pmid: 17541891].
110 Jarvik LF. Trazodone for treatment of older depressed patients: comment. J Clin Psychopharmacol. Dec. 1988;8(6):449-50. [pmid: 3069883].
111 Jerome L. Bupropion and drug-induced parkinsonism. Can J Psychiatry. Aug. 2001;46(6):560-1. [pmid: 11526815].
112 Jimenez-Genchi A. Immediate switching from moclobemide to duloxetine may induce serotonin syndrome. J Clin Psychiatry. Nov. 2006;67(11):1821-2. [pmid: 17196070].
113 John AP, Koloth R. Severe serotonin toxicity and manic switch induced by combined use of tramadol and paroxetine. Aust N Z J Psychiatry. Feb. 2007;41(2):192-3. [pmid: 17484083].
114 Kaneda Y, Ohmori T, Okabe H. Possible mild serotonin syndrome related to co-prescription of tandospirone and trazodone. Gen Hosp Psychiatry. Mar-Apr. 2001;23(2):98-101. [pmid: 11354048].
115 Karnik NS, Maldonado JR. Antidepressant and statin interactions: a review and case report of simvastatin and nefazodone-induced rhabdomyolysis and transaminitis. Psychosomatics. Nov-Dec. 2005;46(6):565-8. [pmid: 16288136].
116 Kaufeler R, Meier B, Brattstrom A. Efficacy and tolerability of Ze 117 St. John's wort extract in comparison with placebo, imipramine and fluoxetine for the treatment of mild to moderate depression according to ICD-10. An overview. Pharmacopsychiatry. Jul. Suppl 1. 2001;34:S49-50. [pmid: 11518076].
117 Keller MB. Citalopram therapy for depression: a review of 10 years of European experience and data from U.S. clinical trials. J Clin Psychiatry. Dec. 2000;61(12):896-908. [pmid: 11206593].
118 Kellett JM. Fluvoxamine: an antidepressant for the elderly?. J Psychiatry Neurosci. Jul. 1991;16(2 Suppl 1):26-9. [pmid: 1931933].
119 Khan A, Shad MU, Preskorn SH. Lack of sertraline efficacy probably due to an interaction with carbamazepine. J Clin Psychiatry. Jul. 2000;61(7):526-7. [pmid: 10937612].
120 Kirsch MA, Louie AK. Paroxetine and irritable bowel syndrome. Am J Psychiatry. Sep. 2000;157(9):1523-4. [pmid: 10964877].
121 Kito S, Koga Y. Visual hallucinations and amnesia associated with zolpidem triggered by fluvoxamine: a possible interaction. Int Psychogeriatr. Dec. 2006;18(4):749-51. [pmid: 17026779].
122 Koga M, Kodaka F, Miyata H, et al. Symptoms of delusion: the effects of discontinuation of low-dose venlafaxine. Acta Psychiatr Scand. Oct. 2009;120(4):329-31. [pmid: 19573048].
123 Kok R, Nolen W, Heeren T. Cardiovascular changes associated with venlafaxine in the treatment of late-life depression. Am J Geriatr Psychiatry. Aug. 2007;15(8):725. author reply 6. [pmid: 17670999].
124 Konitsiotis S, Pappa S, Mantas C, et al. Acute reversible dyskinesia induced by mirtazapine. Mov Disord. Jun. 2005;20(6):771. [pmid: 15732128].
125 Kumar S. Prophylaxis of depression in older people. Br J Psychiatry. Oct. 2003;183:365. author reply. [pmid: 14519617].
126 Kyomen HH, Whitfield TH. Psychosis in the elderly. Am J Psychiatry. Feb. 2009;166(2):146-50. [pmid: 19188291].
127 Labbate LA. Bupropion-SR-induced increased libido and spontaneous orgasm. Can J Psychiatry. Aug. 1998;43(6):644-5. [pmid: 9729695].
128 Lanes T, Ravaris CL. Prolonged ECT seizure duration in a patient taking trazodone. Am J Psychiatry. Mar. 1993;150(3):525. [pmid: 8434678].
129 Langlois RP, Paquette D. Sustained bradycardia during fluvoxamine and buspirone intoxication. Can J Psychiatry. Mar. 1994;39(2):126-7. [pmid: 8149317].
130 Lapierre YD. Controlling acute episodes of depression. Int Clin Psychopharmacol. Dec. Suppl 2. 1991;6:23-35. [pmid: 1806627].
131 Leentjens AF, Vreeling FW, Luijckx GJ, et al. SSRIs in the treatment of depression in Parkinson's disease. Int J Geriatr Psychiatry. Jun. 2003;18(6):552-4. [pmid: 12789682].
132 Lefkowitz D, Kilgo G, Lee S. Seizures and trazodone therapy. Arch Gen Psychiatry. May. 1985;42(5):523. [pmid: 3985762].
133 Leroi I, Walentynowicz MA. Fluoxetine-imipramine interaction. Can J Psychiatry. Jun. 1996;41(5):318-9. [pmid: 8793156].
134 Leung M, Remick R. Sertraline-associated hyponatremia. Can J Psychiatry. Oct. 1995;40(8):497-8. [pmid: 8681276].
135 Levsky ME, Schwartz JB. Sertraline-induced hyponatremia in an older patient. J Am Geriatr Soc. Dec. 1998;46(12):1582-3. [pmid: 9848826].
136 Liberek C, Aubry JM, Baud P. Manic switch and serotonin syndrome with venlafaxine-lithium-valproate association. Therapie. Nov-Dec. 2006;61(6):531-3. [pmid: 17348610].
137 Lin CC. Duloxetine treatment of social anxiety disorder with comorbid major depression. J Clin Psychopharmacol. Oct. 2008;28(5):591-2. author reply 2-3. [pmid: 18794669].
138 Linet LS. Treatment of a refractory depression with a combination of fluoxetine and d-amphetamine. Am J Psychiatry. Jun. 1989;146(6):803-4. [pmid: 2786343].
139 Liu CY, Yang YY, Wang SJ, et al. Fluoxetine-related suicidality and muscle aches in a patient with poststroke depression. J Clin Psychopharmacol. Dec. 1996;16(6):466-7. [pmid: 8959479].
140 Lock JD, Gwirtsman HE, Targ EF. Possible adverse drug interactions between fluoxetine and other psychotropics. J Clin Psychopharmacol. Oct. 1990;10(5):383-4. [pmid: 2258459].
141 Lucena MI, Blanco E, Corrales MA, et al. Interaction of fluoxetine and valproic acid. Am J Psychiatry. Apr. 1998;155(4):575. [pmid: 9546010].
142 Luis Blay S. Depression and psoriasis comorbidity. Treatment with paroxetine: two case reports. Ann Clin Psychiatry. Oct-Dec. 2006;18(4):271-2. [pmid: 17162628].
143 Lydiard RB, Anton RF, Cunningham T. Interactions between sertraline and tricyclic antidepressants. Am J Psychiatry. Jul. 1993;150(7):1125-6. [pmid: 8317590].
144 Malek-Ahmadi P, Allen SA. Paroxetine-molindone interaction. J Clin Psychiatry. Feb. 1995;56(2):82-3. [pmid: 7852260].
145 Marcus SC, Olfson M. Psychosocial functioning of medicaid recipients with major depression. [3]. Psychiatr Serv. 2006;57(7):1046-7. [pmid: 16816296].
146 Marsland TW, Newton W. Are there differences by gender in response to pharmacotherapy for depression?. J Fam Pract. Dec. 2000;49(12):1149. [pmid: 11132066].
147 Masand P, Gupta S, Dewan M. Suicidal ideation related to fluoxetine treatment. N Engl J Med. Feb. 7. 1991;324(6):420. [pmid: 1987466].
148 McCue RE, Joseph M. Venlafaxine- and trazodone-induced serotonin syndrome. Am J Psychiatry. Dec. 2001;158(12):2088-9. [pmid: 11729039].
149 McIntosh D. A mild case of serotonin syndrome?. Can J Psychiatry. Aug. 2000;45(6):571-2. [pmid: 10986578].
150 Michael A, Owen A. Venlafaxine-induced increased libido and spontaneous erections. Br J Psychiatry. Feb. 1997;170:193. [pmid: 9093519].
151 Mirassou MM. Rectal antidepressant medication in the treatment of depression. J Clin Psychiatry. Jan. 1998;59(1):29. [pmid: 9491063].
152 Mizoguchi Y, Monji A. Low-dose-trazodone-induced disorganized type psychosis. J Neuropsychiatry Clin Neurosci. Spring. 2005;17(2):253-4. [pmid: 15939985].
153 Möller HJ. Is there evidence for negative effects of antidepressants on suicidality in depressive patients? A systematic review. Eur Arch Psychiatry Clin Neurosci. 2006;256(8):476-96. [pmid: 17143567].
154 Morales N, Vermette H. Serotonin syndrome associated with linezolid treatment after discontinuation of fluoxetine. Psychosomatics. May-Jun. 2005;46(3):274-5. [pmid: 15883150].
155 Moss JH. A novel placebo lead-in behavior strategy for sertraline dosing in a depressed patient highly sensitive to medication side effects. J Clin Psychiatry. Sep. 1997;58(9):405-6. [pmid: 9378695].
156 Moustgaard G. Treatment-refractory depression successfully treated with the combination of mirtazapine and lithium. J Clin Psychopharmacol. Apr. 2000;20(2):268. [pmid: 10770470].
157 Mowla A, Ghanizadeh A, Pani A. A comparison of effects of fluoxetine and nortriptyline on the symptoms of major depressive disorder. J Clin Psychopharmacol. Apr. 2006;26(2):209-11. [pmid: 16633155].
158 Mulsant BH. Onset of confusion in the context of late-life depression. J Psychiatry Neurosci. Mar. 2007;32(2):152. [pmid: 17353943].
159 Mussig K, Morike K, Haring HU. Severe and symptomatic hyponatremia following duloxetine treatment. J Psychopharmacol. May. 2009;23(3):338-9. [pmid: 18562431].
160 Nose M, Cipriani A, Furukawa TA, et al. Duloxetine versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2007;(2).
161 Noveske FG, Hahn KR, Flynn RJ. Possible toxicity of combined fluoxetine and lithium. Am J Psychiatry. Nov. 1989;146(11):1515. [pmid: 2510522].
162 O'Brien SM. A possible role of recurrent major depression in risk of fracture. Arch Intern Med. Nov. 26. 2007;167(21):2370. author reply-1. [pmid: 18040002].
163 Okada F, Okajima K. Increased sexual desire during fluvoxamine treatment. Can J Psychiatry. Oct. 2000;45(8):762-3. [pmid: 11086562].
164 Olfson M, Shaffer D. SSRI prescriptions and the rate of suicide. Am J Psychiatry. 2007;164(12):1907-8. [pmid: 18056247].
165 Olivera AO. Sertraline and akathisia: spontaneous resolution. Biol Psychiatry. Jan. 15. 1997;41(2):241-2. [pmid: 9018398].
166 Olver JS, Burrows GD, Norman TR. The treatment of depression with different formulations of venlafaxine: a comparative analysis. Hum Psychopharmacol. Jan. 2004;19(1):9-16. [pmid: 14716706].
167 Omori I, Watanabe N, Nakagawa A, et al. Fluvoxamine versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2006;(3).
168 Ozdemir S, Yalug I, Aker AT. Serotonin syndrome associated with sertraline monotherapy at therapeutic doses. Prog Neuropsychopharmacol Biol Psychiatry. Apr. 1. 2008;32(3):897-8. [pmid: 18077070].
169 Panzer PG, Fullilove MT. Belinda's puzzle: assembling the pieces of an illness. Am J Psychiatry. May. 1997;154(5):677-80. [pmid: 9137125].
170 Papadimitriou GN, Theleritis CG, Papageorgiou CC, et al. Acute adverse cutaneous reaction after the concomitant use of venlafaxine and orphenadrine citrate plus paracetamol in a depressed patient. J Eur Acad Dermatol Venereol. Sep. 2006;20(8):1019. [pmid: 16922966].
171 Papakostas GI, Kornstein SG, Clayton AH, et al. Relative antidepressant efficacy of bupropion and the selective serotonin reuptake inhibitors in major depressive disorder: gender-age interactions. Int Clin Psychopharmacol. 2007;22(4):226-9. [pmid: 17519646].
172 Park YM, Lee HJ, Kang SG, et al. Tardive dyskinesia associated with long-term administration of escitalopram and itopride in major depressive disorder. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 17. 2009;33(2):380-1. [pmid: 19121360].
173 Paton C, Ferrier IN. SSRIs and gastrointestinal bleeding. Bmj. Sep. 10. 2005;331(7516):529-30. [pmid: 16150746].
174 Pearson HJ. Interaction of fluoxetine with carbamazepine. J Clin Psychiatry. Mar. 1990;51(3):126. [pmid: 2353956].
175 Perahia DGS, Pritchett YL, Desaiah D, et al. Efficacy of duloxetine in painful symptoms: An analgesic or antidepressant effect?. Int Clin Psychopharmacol. Nov. 2006. 2006;21(6):311-7. [pmid: 17012978].
176 Pinkofsky HB, Stone KD, Reeves RR. Serotonin, cigarettes, and nausea. J Clin Psychopharmacol. Dec. 1997;17(6):492. [pmid: 9408816].
177 Pitchot W, Ansseau M. Shock-like sensations associated with duloxetine discontinuation. Ann Clin Psychiatry. Jul-Sep. 2008;20(3):175. [pmid: 18633745].
178 Postolache TT, Rosenthal RN, Hellerstein DJ, et al. Early augmentation of sertraline with methylphenidate. J Clin Psychiatry. Feb. 1999;60(2):123-4. [pmid: 10084641].
179 Prospero-Garcia KA, Torres-Ruiz A, Ramirez-Bermudez J, et al. Fluoxetine-mirtazapine interaction may induce restless legs syndrome: report of 3 cases from a clinical trial. J Clin Psychiatry. Nov. 2006;67(11):1820. [pmid: 17196069].
180 Pukadan D, Antony J, Mohandas E, et al. Use of escitalopram in psychogenic excoriation. Aust N Z J Psychiatry. May. 2008;42(5):435-6. [pmid: 18499934].
181 Purdon SE, Snaterse M. Selective serotonin reuptake inhibitor modulation of clozapine effects on cognition in schizophrenia. Can J Psychiatry. Feb. 1998;43(1):84-5. [pmid: 9494753].
182 Rajagopalan M. Comparison of venlafaxine and imipramine in depressive illness. Acta Psychiatr Scand. May. 1998;97(5):384-5. [pmid: 9611090].
183 Rajji TK, Mulsant BH, Lotrich FE, et al. Use of antidepressants in late-life depression. Drugs Aging. 2008;25(10):841-53. [pmid: 18808208].
184 Ramasubbu R. Minor strokes related to paroxetine discontinuation in an elderly subject: emergent adverse events. Can J Psychiatry. May. 2003;48(4):281-2. [pmid: 12776398].
185 Ratan DA. Fluoxetine and suicidal ideation. J Clin Psychopharmacol. Feb. 1997;17(1):61-2. [pmid: 9004066].
186 Ravindran LN, Eisfeld BS, Kennedy SH. Combining mirtazapine and duloxetine in treatment-resistant depression improves outcomes and sexual function. Journal of Clinical Psychopharmacology (USA). 01. 01. 2008;28(Jan):107-8.
187 Reed SM, Glick JW. Fluoxetine and reactivation of the herpes simplex virus. Am J Psychiatry. Jul. 1991;148(7):949-50. [pmid: 1647143].
188 Rigonatti SP, Boggio PS, Myczkowski ML, et al. Transcranial direct stimulation and fluoxetine for the treatment of depression. Eur Psychiatry. Jan. 2008;23(1):74-6. [pmid: 18023968].
189 Roose SP. Tolerability and patient compliance. J Clin Psychiatry. Suppl 17. 1999;60:14-7. discussion 46-8. [pmid: 10446736].
190 Ropert R. Fluoxetine versus clomipramine in major depressive disorders. Int Clin Psychopharmacol. 1989;4(Suppl):189-95.
191 Rush AJ. Limitations in efficacy of antidepressant monotherapy. J Clin Psychiatry. Suppl 10. 2007;68:8-10. [pmid: 17900203].
192 Sansone RA, Sansone LA. Bupropion-induced neck and shoulder pain. Pharmacopsychiatry. Sep. 2009;42(5):203-4. [pmid: 19724984].
193 Santos PM, Lopez-Garcia P, Navarro JS, et al. False positive phencyclidine results caused by venlafaxine. Am J Psychiatry. Feb. 2007;164(2):349. [pmid: 17267806].
194 Saraf M, Schrader G. Seizure associated with sertraline. Aust N Z J Psychiatry. Dec. 1999;33(6):944-5. [pmid: 10619229].
195 Schouten WE, Sepers JM. Hyponatraemia associated with the use of a selective serotonin-reuptake inhibitor in an older patient. Age Ageing. Jan. 2001;30(1):94. [pmid: 11322690].
196 Schraml F, Benedetti G, Hoyle K, et al. Fluoxetine and nortriptyline combination therapy. Am J Psychiatry. Dec. 1989;146(12):1636-7. [pmid: 2589560].
197 Schweitzer I, Maguire K, Ng C. Sexual side-effects of contemporary antidepressants: review. Aust N Z J Psychiatry. Sep. 2009;43(9):795-808. [pmid: 19670052].
198 Segraves RT, Segraves KB, Bubna CN. Sexual function in patients taking bupropion sustained release. J Clin Psychiatry. 1995;56(8):374. [pmid: 7635855].
199 Selzer JA. Fluoxetine, suicidal ideation, and aggressive behavior. Am J Psychiatry. May. 1992;149(5):708-9. [pmid: 1575263].
200 Settle EC Jr. Akathisia and sertraline. J Clin Psychiatry. Aug. 1993;54(8):321. [pmid: 8253701].
201 Shad MU, Harvey AT, Lucot JB. A possible pharmacokinetic interaction between fluoxetine and acetylsalicylic acid. J Clin Psychiatry. Dec. 1997;58(12):549-50. [pmid: 9448661].
202 Shader RI, Oesterheld JR. Case 2: Dizzy Giuseppi or the vertiginous virtuoso. J Clin Psychopharmacol. Dec. 1994;14(6):437. [pmid: 7884033].
203 Shang CY, Soong WT, Lin HN. Hypokalemia with venlafaxine. J Clin Psychiatry. Nov. 2002;63(11):1049-50. [pmid: 12469691].
204 Sharma V. Venlafaxine: loss of antidepressant effect and its management. J Clin Psychiatry. Jul. 1998;59(7):381-2. [pmid: 9714268].
205 Simon JS, Sheehan D, Thase ME, et al. Comparison of efficacy and tolerability of paroxetine vs venlafaxine. 2005.
206 Sopko MA Jr, Ehret MJ, Grgas M. Desvenlafaxine: another “me too” drug?. Ann Pharmacother. Oct. 2008;42(10):1439-46. [pmid: 18698015].
207 Soutullo CA, McElroy SL, Keck PE Jr. Hypomania associated with mirtazapine augmentation of sertraline. J Clin Psychiatry. Jun. 1998;59(6):320. [pmid: 9671349].
208 Sternbach H. Fluoxetine-associated potentiation of calcium-channel blockers. J Clin Psychopharmacol. Dec. 1991;11(6):390-1. [pmid: 1770159].
209 Stone MB, Jones ML. Clinical Review:Relationship Between Antidepressant Drugs and Suicidality in Adults. 2006:1-64.
210 Storch DD. Successful use of VNS for depression. [15]. Psychiatr Serv. 2006;57(10):1518-9. [pmid: 17035589].
211 Straton JB, Cronholm P. Are paroxetine, fluoxetine, and sertraline equally effective for depression?. J Fam Pract. Mar. 2002;51(3):285. [pmid: 11978244].
212 Terao T. Rapid synergistic effects of lithium and antidepressants. Psychopharmacology (Berl). Nov. 1995;122(2):206-7. [pmid: 8848539].
213 Thompson C. Bridging the gap between psychiatric practice and primary care. Int Clin Psychopharmacol. Oct. Suppl 2. 1992;7:31-6. [pmid: 1484176].
214 Thompson C. Discontinuation of antidepressant therapy: emerging complications and their relevance. J Clin Psychiatry. Oct. 1998;59(10):541-8. [pmid: 9818638].
215 Thompson C. Management of depression in real-life settings: knowledge gained from large-scale clinical trials. Int Clin Psychopharmacol. Jun. Suppl 3. 1994;9:21-5. [pmid: 7963447].
216 Thompson M, Samuels S. Rhabdomyolysis with simvastatin and nefazodone. Am J Psychiatry. Sep. 2002;159(9):1607. [pmid: 12202291].
217 Trappler B, Miyashiro AM. Bupropion-amantadine-associated neurotoxicity. J Clin Psychiatry. Jan. 2000;61(1):61-2. [pmid: 10695649].
218 Trivedi MH. Major depressive disorder: Remission of associated symptoms. J Clin Psychiatry. 2006;67(SUPPL. 6):27-32. [pmid: 16848674].
219 Turkington D, Smith PP, Grant J. Idiopathic genital pain and fluvoxamine. Br J Psychiatry. Jun. 1992;160:871. [pmid: 1617380].
220 Vaccaro M, Borgia F, Barbuzza O, et al. Photodistributed eruptive telangiectasia: an uncommon adverse drug reaction to venlafaxine. Br J Dermatol. Oct. 2007;157(4):822-4. [pmid: 17655739].
221 Varghese S, Kumar A, Sagar R. Ultradian pattern bipolar affective disorder and chronic antidepressant use. [1]. J Postgrad Med. 2007;53(3).
222 Vaughan DA. Interaction of fluoxetine with tricyclic antidepressants. Am J Psychiatry. Nov. 1988;145(11):1478. [pmid: 3263809].
223 Vilaplana J, Botey E, Lecha M, et al. Photosensitivity induced by paroxetine. Contact Dermatitis. Aug. 2002;47(2):118-9. [pmid: 12455545].
224 Walley T, Pirmohamed M, Proudlove C, et al. Interaction of metoprolol and fluoxetine. Lancet. Apr. 10. 1993;341(8850):967-8. [pmid: 8096308].
225 Watanabe N, Barbui C, Churchill R, et al. Mirtazapine versus other anti-depressive agents for depression (Protocol). Cochrane Database of Systematic Reviews. 2006;(3).
226 Weber-Hamann B, Gilles M, Schilling C, et al. Improved insulin sensitivity in 51 nondiabetic depressed inpatients remitting during antidepressive treatment with mirtazapine and venlafaxine. J Clin Psychopharmacol. Oct. 2008;28(5):581-4. [pmid: 18794665].
227 Weintraub D. Nortriptyline toxicity secondary to interaction with bupropion sustained-release. Depress Anxiety. 2001;13(1):50-2. [pmid: 11233461].
228 Wenger TL, Stern WC. The cardiovascular profile of bupropion. J Clin Psychiatry. May. 1983;44(5 Pt 2):176-82. [pmid: 6406453].
229 Wheatley D. Trazodone in depression. Int Pharmacopsychiatry. 1980;15(4):240-6. [pmid: 7021449].
230 Willetts J, Lippa A, Beer B. Clinical development of citalopram. J Clin Psychopharmacol. Oct. 1999;19(5 Suppl 1):36S-46S. [pmid: 10507507].
231 Wirshing WC, Van Putten T, Rosenberg J, et al. Fluoxetine, akathisia, and suicidality: is there a causal connection?. Arch Gen Psychiatry. Jul. 1992;49(7):580-1. [pmid: 1627050].
232 Workman EA, Short DD. Bupropion-induced carbohydrate craving and weight gain. Am J Psychiatry. Oct. 1992;149(10):1407-8. [pmid: 1530081].
233 Yang LP, Plosker GL. Desvenlafaxine extended release. CNS Drugs. 2008;22(12):1061-9. [pmid: 18998743].
234 Yasui-Furukori N, Kaneko S. Digitalis intoxication induced by paroxetine coadministration. Lancet. Mar. 4. 2006;367(9512):788. [pmid: 16517279].
235 Yuksel FV, Tuzer V, Goka E. Escitalopram intoxication. Eur Psychiatry. Jan. 2005;20(1):82. [pmid: 15642453].
236 Zanardi R, Benedetti F, Di Bella D, et al. Efficacy of paroxetine in depression is influenced by a functional polymorphism within the promoter of the serotonin transporter gene. J Clin Psychopharmacol. Feb. 2000;20(1):105-7. [pmid: 10653220].
237 Zhalkovsky B, Walker D, Bourgeois JA. Seizure activity and enzyme elevations after venlafaxine overdose. J Clin Psychopharmacol. Dec. 1997;17(6):490-1. [pmid: 9408815].
238 Ziffra MS, Gilmer WS. STAR*D : Lessons learned for primary care. New York, NY, ETATS-UNIS. MBL Communications. 2007.
239 Zisook S, Ganadjian K, Moutier C, et al. Sequenced Treatment Alternatives to Relieve Depression (STAR*D): lessons learned. J Clin Psychiatry. Jul. 2008;69(7):1184-5. [pmid: 18687018].

## Does Not Address Outcomes of Interest (277)

1 Ahrold TK, Meston CM. Effects of SNS activation on SSRI-induced sexual side effects differ by SSRI. J Sex Marital Ther. 2009;35(4):311-9. [pmid: 19466669].
2 Akiskal HS, Benazzi F. Does the FDA proposed list of possible correlates of suicidality associated with antidepressants apply to an adult private practice population?. J Affect Disord. 2006;94(1-3):105-10. [pmid: 16766043].
3 Alexopoulos GS, Canuso CM, Gharabawi GM, et al. Placebo-controlled study of relapse prevention with risperidone augmentation in older patients with resistant depression. Am J Geriatr Psychiatry. Jan. 2008;16(1):21-30. [pmid: 17928573].
4 Almeida OP, Waterreus A, Hankey GJ. Preventing depression after stroke: Results from a randomized placebo-controlled trial. J Clin Psychiatry. Jul. 2006;67(7):1104-9. [pmid: 16889454].
5 Altintoprak AE, Zorlu N, Coskunol H, et al. Effectiveness and tolerability of mirtazapine and amitriptyline in alcoholic patients with co-morbid depressive disorder: a randomized, double-blind study. Hum Psychopharmacol. 2008;23(4):313-9. [pmid: 18327889].
6 Altman EM, Manos GH. Serotonin syndrome associated with citalopram and meperidine. Psychosomatics. Jul-Aug. 2007;48(4):361-3. [pmid: 17600178].
7 Amsterdam JD, Shults J. Comparison of short-term venlafaxine versus lithium monotherapy for bipolar II major depressive episode: a randomized open-label study. J Clin Psychopharmacol. Apr. 2008;28(2):171-81. [pmid: 18344727].
8 Amsterdam JD, Shults J. Does tachyphylaxis occur after repeated antidepressant exposure in patients with Bipolar II major depressive episode?. J Affect Disord. May. 2009;115(1-2):234-40. [pmid: 18694599].
9 Andersohn F, Willich SN. Interaction of serotonin reuptake inhibitors with tamoxifen. BMJ. 2010;340:c783. [pmid: 20142323].
10 Applebee GA, Attarian HP, Schenck CH. An angry bed partner. J Clin Sleep Med. 2009;5(5):477-9. [pmid: 19961035].
11 Arias B, Serretti A, Mandelli L, et al. Dysbindin gene (DTNBP1) in major depression: association with clinical response to selective serotonin reuptake inhibitors. Pharmacogenet Genomics. Feb. 2009;19(2):121-8. [pmid: 19065121].
12 Arnold LM, Rosen A, Pritchett YL, et al. A randomized, double-blind, placebo-controlled trial of duloxetine in the treatment of women with fibromyalgia with or without major depressive disorder. Pain. Dec. 15. 2005;119(1-3):5-15. [pmid: 16298061].
13 Bajbouj M, Danker-Hopfe H. Maintenance treatment of depression in old age. N Engl J Med. Jun. 8. 2006;354(23):2505-6. author reply -6. [pmid: 16764055].
14 Baldessarini RJ, Pompili M, Tondo L. Suicidal risk in antidepressant drug trials. Arch Gen Psychiatry. 2006;63(3):246-8. [pmid: 16520428].
15 Baldwin DS, Montgomery SA, Nil R, et al. Discontinuation symptoms in depression and anxiety disorders. International Journal of Neuropsychopharmacology. 2007;10(1):73-84. [pmid: 16359583].
16 Ballesteros J, Callado LF, Gutiérrez M. An independent meta-analysis using summary data for clinical response, remission, and discontinuation for any reason from the 6 pivotal phase III randomized clinical trials of duloxetine in major depressive disorder. J Clin Psychopharmacol. Apr. 2007. 2007;27(2):219-21. [pmid: 17414254].
17 Barbui C, Furukawa TA, Cipriani A. Effectiveness of paroxetine in the treatment of acute major depression in adults: A systematic re-examination of published and unpublished data from randomized trials. Can Med Assoc J. 2008;178(3):296-305. [pmid: 18227449].
18 Barone P, Scarzella L, Marconi R, et al. Pramipexole versus sertraline in the treatment of depression in Parkinson's disease: a national multicenter parallel-group randomized study. J Neurol. May. 2006;253(5):601-7. [pmid: 16607468].
19 Basoglu C, Ates MA, Alguel A, et al. Adjuvant Folate with Escitalopram Treatment and Homocystein, Folate, Vitamin B-12 Levels in Patients with Major Depressive Disorder. Bulletin of Clinical Psychopharmacology. 2009;19135.
20 Basterzi AD, Yazici K, Aslan E, et al. Effects of fluoxetine and venlafaxine on serum brain derived neurotrophic factor levels in depressed patients. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 17. 2009;33(2):281-5. [pmid: 19110026].
21 Bech P, Lonn SL, Overo KF. Relapse prevention and residual symptoms: A closer analysis of placebo-controlled continuation studies with escitalopram in major depressive disorder, generalized anxiety disorder, social anxiety disorder, and obsessive-compulsive disorder. J Clin Psychiatry. 2010;71(2):121-9. [pmid: 19961809].
22 Begre S, Traber M, Gerber M, et al. Change in pain severity with open label venlafaxine use in patients with a depressive symptomatology: an observational study in primary care. Eur Psychiatry. Apr. 2008;23(3):178-86. [pmid: 18328675].
23 Berlanga C, Flores-Ramos M. Different gender response to serotonergic and noradrenergic antidepressants. A comparative study of the efficacy of citalopram and reboxetine. J Affect Disord. Oct. 2006;95(1-3):119-23. [pmid: 16782204].
24 Berman RM, Fava M, Thase ME, et al. Aripiprazole augmentation in major depressive disorder: a double-blind, placebo-controlled study in patients with inadequate response to antidepressants. CNS Spectr. Apr. 2009;14(4):197-206. [pmid: 19407731].
25 Berman RM, Marcus RN, Swanink R, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder: a multicenter, randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Jun. 2007;68(6):843-53. [pmid: 17592907].
26 Bigos KL, Pollock BG, Aizenstein HJ, et al. Acute 5-HT reuptake blockade potentiates human amygdala reactivity. Neuropsychopharmacology. Dec. 2008;33(13):3221-5. [pmid: 18463627].
27 Binneman B, Feltner D, Kolluri S, et al. A 6-week randomized, placebo-controlled trial of CP-316,311 (a selective CRH1 antagonist) in the treatment of major depression. Am J Psychiatry. May. 2008;165(5):617-20. [pmid: 18413705].
28 Blier P, Ward HE, Tremblay P. Combination of antidepressant from treatment initiation for depression. American Psychiatric Association annual meeting. 2006.
29 Blom MB, Jonker K, Dusseldorp E, et al. Combination treatment for acute depression is superior only when psychotherapy is added to medication. Psychother Psychosom. 2007;76(5):289-97. [pmid: 17700049].
30 Bobo WV, Shelton RC. Fluoxetine and olanzapine combination therapy in treatment-resistant major depression: review of efficacy and safety data. Expert Opin Pharmacother. Sep. 2009;10(13):2145-59. [pmid: 19640209].
31 Bodnar LM, Sunder KR, Wisner KL. Treatment with selective serotonin reuptake inhibitors during pregnancy: deceleration of weight gain because of depression or drug?. Am J Psychiatry. Jun. 2006;163(6):986-91. [pmid: 16741197].
32 Bogner HR, Lin JY, Morales KH. Patterns of early adherence to the antidepressant citalopram among older primary care patients: the prospect study. Int J Psychiatry Med. 2006;36(1):103-19. [pmid: 16927582].
33 Borkowska A, Drozdz W, Ziolkowska-Kochan M, et al. Enhancing effect of mirtazapine on cognitive functions associated with prefrontal cortex in patients with recurrent depression. Neuropsychopharmacol Hung. Oct. 2007;9(3):131-6. [pmid: 18399031].
34 Bradley RH, Barkin RL, Jerome J, et al. Efficacy of venlafaxine for the long term treatment of chronic pain with associated major depressive disorder. Am J Ther. Sep-Oct. 2003;10(5):318-23. [pmid: 12975715].
35 Brent D. Antidepressants and suicidal behavior: Cause or cure?. Am J Psychiatry. 2007;164(7):989-91. [pmid: 17606644].
36 Brent D, Emslie G, Clarke G, et al. Switching to another SSRI or to venlafaxine with or without cognitive behavioral therapy for adolescents with SSRI-resistant depression - The TORDIA randomized controlled trial. Journal of the American Medical Association (USA). 08. 01. 2008;299(Aug):901-13.
37 Brown ES, Murray M, Carmody TJ, et al. The Quick Inventory of Depressive Symptomatology-Self-report: a psychometric evaluation in patients with asthma and major depressive disorder. Ann Allergy Asthma Immunol. May. 2008;100(5):433-8. [pmid: 18517074].
38 Candrian M, Schwartz F, Farabaugh A, et al. Personality disorders and perceived stress in major depressive disorder. Psychiatry Res. Aug. 15. 2008;160(2):184-91. [pmid: 18573540].
39 Cankurtaran ES, Ozalp E, Soygur H, et al. Mirtazapine improves sleep and lowers anxiety and depression in cancer patients: superiority over imipramine. Support Care Cancer. Nov. 2008;16(11):1291-8. [pmid: 18299900].
40 Carney RM, Freedland KE, Rubin EH, et al. Omega-3 augmentation of sertraline in treatment of depression in patients with coronary heart disease: a randomized controlled trial. Jama. 2009;302(15):1651-7. [pmid: 19843899].
41 Carvalho LA, Gorenstein C, Moreno R, et al. Effect of antidepressants on melatonin metabolite in depressed patients. J Psychopharmacol. May. 2009;23(3):315-21. [pmid: 18562432].
42 Casciano J, Doyle J, Arikian S, et al. The health economic impact of antidepressant usage from a payer's perspective: a multinational study. Int J Clin Pract. Jun. 2001;55(5):292-9. [pmid: 11452675].
43 Cheung A, Kusumakar V, Kutcher S, et al. Maintenance study for adolescent depression. J Child Adolesc Psychopharmacol. Aug. 2008;18(4):389-94. [pmid: 18759650].
44 Chuang YF, Chiu YL, Hwang TJ, et al. Delirium and multiple electrolyte abnormalities associated with high dose paroxetine exposure. Psychiatry Clin Neurosci. Oct. 2006;60(5):642-3. [pmid: 16958954].
45 Cipriani A, Barbui C, Geddes JR. Suicide, depression, and antidepressants. Br Med J. 2005;330(7488):373-4. [pmid: 15718515].
46 Cookson J, Gilaberte I, Desaiah D, et al. Treatment benefits of duloxetine in major depressive disorder as assessed by number needed to treat. Int Clin Psychopharmacol. Sep. 2006;21(5):267-73. [pmid: 16877897].
47 Cornelius JR, Chung T, Martin C, et al. Cannabis withdrawal is common among treatment-seeking adolescents with cannabis dependence and major depression, and is associated with rapid relapse to dependence. Addict Behav. Nov. 2008;33(11):1500-5. [pmid: 18313860].
48 Cowen PJ, Ogilvie AD, Gama J. Efficacy, safety and tolerability of duloxetine 60 mg once daily in major depression. Curr Med Res Opin. 2005;21(3):345-55. [pmid: 15811202].
49 Cravello L, Caltagirone C, Spalletta G. The SNRI venlafaxine improves emotional unawareness in patients with post-stroke depression. Hum Psychopharmacol. Jun. 2009;24(4):331-6. [pmid: 19330795].
50 Crossley NA, Bauer M. Acceleration and augmentation of antidepressants with lithium for depressive disorders: Two meta-analyses of randomized, placebo-controlled trials. J Clin Psychiatry. Jun. 2007. 2007;68(6):935-40. [pmid: 17592920].
51 Dahlberg M, Lundin K. Antidepressants and the Suicide Rate: Is There Really a Connection?. Upsulla University (Sweden) Economics Department. 2005:4.
52 de Carvalho GA, Bahls SC, Boeving A, et al. Effects of selective serotonin reuptake inhibitors on thyroid function in depressed patients with primary hypothyroidism or normal thyroid function. Thyroid. Jul. 2009;19(7):691-7. [pmid: 19583486].
53 de Jonge P, Honig A, van Melle JP, et al. Nonresponse to treatment for depression following myocardial infarction: association with subsequent cardiac events. Am J Psychiatry. Sep. 2007;164(9):1371-8. [pmid: 17728422].
54 De Las Cuevas C, de la Rosa MA, Troyano JM, et al. Are psychotropics drugs used in pregnancy?. Pharmacoepidemiol Drug Saf. Sep. 2007;16(9):1018-23. [pmid: 17455181].
55 Dell'Osso B, Hadley S, Allen A, et al. Escitalopram in the treatment of impulsive-compulsive internet usage disorder: an open-label trial followed by a double-blind discontinuation phase. J Clin Psychiatry. Mar. 2008;69(3):452-6. [pmid: 18312057].
56 Demyttenaere K, Albert A, Mesters P, et al. What happens with adverse events during 6 months of treatment with selective serotonin reuptake inhibitors?. J Clin Psychiatry. 2005;66(7):859-63. [pmid: 16013901].
57 Demyttenaere K, Andersen HF, Reines EH. Impact of escitalopram treatment on Quality of Life Enjoyment and Satisfaction Questionnaire scores in major depressive disorder and generalized anxiety disorder. Int Clin Psychopharmacol. Sep. 2008;23(5):276-86. [pmid: 18703937].
58 Dew MA, Whyte EM, Lenze EJ, et al. Recovery from major depression in older adults receiving augmentation of antidepressant pharmacotherapy. Am J Psychiatry. Jun. 2007;164(6):892-9. [pmid: 17541048].
59 Djulus J, Koren G, Einarson TR, et al. Exposure to mirtazapine during pregnancy: a prospective, comparative study of birth outcomes. J Clin Psychiatry. Aug. 2006;67(8):1280-4. [pmid: 16965209].
60 Dombrovski AY, Cyranowski JM, Mulsant BH, et al. Which symptoms predict recurrence of depression in women treated with maintenance interpersonal psychotherapy?. Depress Anxiety. 2008;25(12):1060-6. [pmid: 18781665].
61 Dotoli D, Spagnolo C, Bongiorno F, et al. Relapse during a 6-month continuation treatment with fluvoxamine in an Italian population: the role of clinical, psychosocial and genetic variables. Prog Neuropsychopharmacol Biol Psychiatry. May. 2006;30(3):442-8. [pmid: 16431008].
62 Dunner DL, Amsterdam JD, Shelton RC, et al. Efficacy and tolerability of adjunctive ziprasidone in treatment-resistant depression: a randomized, open-label, pilot study. J Clin Psychiatry. Jul. 2007;68(7):1071-7. [pmid: 17685744].
63 Dunner DL, Wilson M, Fava M, et al. Long-term tolerability and effectiveness of duloxetine in the treatment of major depressive disorder. Depress Anxiety. 2008;25(5):E1-8. [pmid: 17621644].
64 Dutta R, Boydell J, Kennedy N, et al. Suicide and other causes of mortality in bipolar disorder: A longitudinal study. Psychological Medicine. 2007;37(6):839-47. [pmid: 17349107].
65 Eaddy M, Bramley T, Regan T. Time to antidepressant discontinuation: a comparison of controlled-release paroxetine and immediate-release selective serotonin-reuptake inhibitors. Manag Care Interface. Dec. 2003;16(12):22-7. [pmid: 14750459].
66 Eker SS, Kirli S, Akkaya C, et al. Are there differences between serotonergic, noradrenergic and dual acting antidepressants in the treatment of depressed women?. World J Biol Psychiatry. 2009;10(4 Pt 2):400-8. [pmid: 19670086].
67 Elgamal S, MacQueen G. Galantamine as an adjunctive treatment in major depression. Journal of Clinical Psychopharmacology (USA). 03. 01. 2008;28(Mar):357-9.
68 Entsuah R, Gorman JM. Global benefit-risk assessment of antidepressants: venlafaxine XR and fluoxetine. J Psychiatr Res. May-Jun. 2002;36(3):111-8. [pmid: 11886688].
69 Fava M, Graves LM, Benazzi F, et al. A cross-sectional study of the prevalence of cognitive and physical symptoms during long-term antidepressant treatment. J Clin Psychiatry. 2006;67(11):1754-9. [pmid: 17196056].
70 Fava M, Martinez JM, Greist J, et al. The efficacy and tolerability of duloxetine in the treatment of anxious versus non-anxious depression: a post-hoc analysis of an open-label outpatient study. Ann Clin Psychiatry. Jul-Sep. 2007;19(3):187-95. [pmid: 17729021].
71 Fava M, Rush AJ, Thase ME, et al. 15 Years of clinical experience with bupropion HCl: From bupropion to bupropion SR to bupropion XL. Primary Care Companion to the Journal of Clinical Psychiatry. 2005;7(3):106-13.
72 Fiedorowicz JG, Takezawa K, Robinson RG. Risk factors for and correlates of poststroke depression following discontinuation of antidepressants. J Neuropsychiatry Clin Neurosci. Fall. 2007;19(4):399-405. [pmid: 18070842].
73 Frank C. Recognition and treatment of serotonin syndrome. Can Fam Physician. Jul. 2008;54(7):988-92. [pmid: 18625822].
74 Freeman MP. An imperfect literature and evidence-based medicine. J Clin Psychiatry. Mar. 2009;70(3):412-3. [pmid: 19317958].
75 Friedman RA, Leon AC. Expanding the black box - depression, antidepressants, and the risk of suicide. N Engl J Med. 2007;356(23):2343-6. [pmid: 17485726].
76 Gallimore C. Pharmacological Management of Treatment-Resistant Depression Alternative therapies often required to alleviate symptoms. Journal of the Pharmacy Society of Wisconsin (USA). 01. 01. 2008;(NOV-DEC):18-22.
77 Garcia Campayo J. Effectiveness of mirtazapine in the treatment of depression with associated somatic symptoms. Actas Esp Psiquiatr. Jan-Feb. 2008;36(1):25-32. [pmid: 18286397].
78 Garcia-Cebrian A, Bauer M, Montejo AL, et al. Factors influencing depression endpoints research (FINDER): Study design and population characteristics. European Psychiatry. 2008;23(1):57-65. [pmid: 18086518].
79 Garriock HA, Hamilton SP. Genetic studies of drug response and side effects in the STAR*D study, part 2. J Clin Psychiatry. Sep. 2009;70(9):1323-5. [pmid: 19818256].
80 Gau YT, Liou YJ, Yu YW, et al. Evidence for association between genetic variants of p75 neurotrophin receptor (p75NTR) gene and antidepressant treatment response in Chinese major depressive disorder. Am J Med Genet B Neuropsychiatr Genet. Jul. 5. 2008;147B(5):594-9. [pmid: 18081157].
81 Gaynes BN, Rush AJ, Trivedi MH, et al. Primary versus specialty care outcomes for depressed outpatients managed with measurement-based care: results from STAR*D. J Gen Intern Med. May. 2008;23(5):551-60. [pmid: 18247097].
82 Gentile S. Quetiapine-fluvoxamine combination during pregnancy and while breastfeeding. Arch Womens Ment Health. May. 2006;9(3):158-9. [pmid: 16683078].
83 Gillman K. Venlafaxine-lithium toxicity: suitability for use in the elderly. J Clin Pharm Ther. Oct. 2007;32(5):529-31. [pmid: 17875121].
84 Gilmer WS, Gollan JK, Wisniewski SR, et al. Does the duration of index episode affect the treatment outcome of major depressive disorder? A STAR*D report. J Clin Psychiatry. Aug. 2008;69(8):1246-56. [pmid: 18681756].
85 Gilmer WS, Kemp DE. STAR*D: What have we learned thus far?. International Drug Therapy Newsletter (USA). 10. 01. 2006;41(Oct).
86 Ginsberg DL. Vardenafil Treatment of Sertraline-Induced Anorgasmia in a Woman. Primary Psychiatry. Jan. 2005. 2005;12(1):17-8.
87 Glassman AH, Bigger JT Jr, Gaffney M. Psychiatric characteristics associated with long-term mortality among 361 patients having an acute coronary syndrome and major depression: seven-year follow-up of SADHART participants. Arch Gen Psychiatry. Sep. 2009;66(9):1022-9. [pmid: 19736359].
88 Glassman AH, Bigger JT, Gaffney M, et al. Heart rate variability in acute coronary syndrome patients with major depression: influence of sertraline and mood improvement. Arch Gen Psychiatry. Sep. 2007;64(9):1025-31. [pmid: 17768267].
89 Goldstein DJ. Duloxetine in the treatment of major depressive disorder. Neuropsychiatric Disease and Treatment. 2007. 2007;3(2):193-209. [pmid: 19300553].
90 Granger AL, Fehnel SE, Hogue SL, et al. An assessment of patient preference and adherence to treatment with Wellbutrin SR: a web-based survey. J Affect Disord. Feb. 2006;90(2-3):217-21. [pmid: 16360216].
91 Gualtieri CT, Johnson LG. Bupropion normalizes cognitive performance in patients with depression. MedGenMed. 2007;9(1):22. [pmid: 17435629].
92 Gulsun M, Doruk A. Mirtazapine-induced akathisia. J Clin Psychopharmacol. Aug. 2008;28(4):467. [pmid: 18626283].
93 Hadikusumo B, Ng B. Serotonin syndrome induced by duloxetine. Aust N Z J Psychiatry. Jun. 2009;43(6):581-2. [pmid: 19452666].
94 Hall WD, Lucke J. How have the selective serotonin reuptake inhibitor antidepressants affected suicide mortality?. Aust N Z J Psychiatry. Nov-Dec. 2006;40(11-12):941-50. [pmid: 17054562].
95 Harvey AT, Silkey BS, Kornstein SG, et al. Acute worsening of chronic depression during a double-blind, randomized clinical trial of antidepressant efficacy: differences by sex and menopausal status. J Clin Psychiatry. Jun. 2007;68(6):951-8. [pmid: 17592923].
96 Hellerstein DJ, Batchelder S, Kreditor D, et al. Bupropion sustained-release for the treatment of dysthymic disorder: an open-label study. J Clin Psychopharmacol. Jun. 2001;21(3):325-9. [pmid: 11386496].
97 Henry NL, Stearns V, Flockhart DA, et al. Drug interactions and pharmacogenomics in the treatment of breast cancer and depression. Am J Psychiatry. Oct. 2008;165(10):1251-5. [pmid: 18829880].
98 Himmerich H, Fulda S, Schaaf L, et al. Changes in weight and glucose tolerance during treatment with mirtazapine. Diabetes Care. Jan. 2006;29(1):170. [pmid: 16373922].
99 Holshoe JM. Antidepressants and sleep: a review. Perspect Psychiatr Care. Jul. 2009;45(3):191-7. [pmid: 19566691].
100 Holtzheimer PE 3rd, Meeks TW, Kelley ME, et al. A double blind, placebo-controlled pilot study of galantamine augmentation of antidepressant treatment in older adults with major depression. Int J Geriatr Psychiatry. Jun. 2008;23(6):625-31. [pmid: 18058832].
101 Hong Ng C, Norman TR, Naing KO, et al. A comparative study of sertraline dosages, plasma concentrations, efficacy and adverse reactions in Chinese versus Caucasian patients. Int Clin Psychopharmacol. Mar. 2006;21(2):87-92. [pmid: 16421459].
102 Howland RH. Electroencephalography technology for predicting response to antidepressant medications. J Psychosoc Nurs Ment Health Serv. Oct. 2006. 2006;44(10):11-4.
103 Hunter AM, Leuchter AF, Morgan ML, et al. Changes in brain function (quantitative EEG cordance) during placebo lead-in and treatment outcomes in clinical trials for major depression. Am J Psychiatry. Aug. 2006;163(8):1426-32. [pmid: 16877657].
104 Husain MM, Rush AJ, Trivedi MH, et al. Pain in depression: STAR*D study findings. J Psychosom Res. Aug. 2007;63(2):113-22. [pmid: 17662746].
105 Husain MM, Rush JA, Wisniewski SR, et al. Family history of depression and therapeutic outcome: findings from STAR*D. J Clin Psychiatry. Feb. 2009;70(2):185-95. [pmid: 19192454].
106 Hybels CF, Steffens DC, McQuoid DR, et al. Residual symptoms in older patients treated for major depression. Int J Geriatr Psychiatry. 2005;20(12):1196-202. [pmid: 16315146].
107 Imperadore G, Cipriani A, Signoretti A, et al. Citalopram versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2007;(2).
108 indicated Na. Antidepressant efficacy may be enhanced with dual reuptake inhibition. South African Psychiatry Review. Feb. 2006. 2006;9(1):65.
109 Ishii M, Tatsuzawa Y, Yoshino A, et al. Serotonin syndrome induced by augmentation of SSRI with methylphenidate. Psychiatry Clin Neurosci. Apr. 2008;62(2):246. [pmid: 18412855].
110 Jacob S, Spinler SA. Hyponatremia associated with selective serotonin-reuptake inhibitors in older adults. Ann Pharmacother. Sep. 2006;40(9):1618-22. [pmid: 16896026].
111 Jakob F, Wolf J. EPMS under antidepressive therapy with fluvoxamine and concomitant antibiotic therapy with clindamycin. Pharmacopsychiatry. May. 2007;40(3):129. [pmid: 17541891].
112 Jimenez-Genchi A. Immediate switching from moclobemide to duloxetine may induce serotonin syndrome. J Clin Psychiatry. Nov. 2006;67(11):1821-2. [pmid: 17196070].
113 John AP, Koloth R. Severe serotonin toxicity and manic switch induced by combined use of tramadol and paroxetine. Aust N Z J Psychiatry. Feb. 2007;41(2):192-3. [pmid: 17484083].
114 Kasper S, Spadone C, Verpillat P, et al. Onset of action of escitalopram compared with other antidepressants: Results of a pooled analysis. Int Clin Psychopharmacol. Mar. 2006. 2006;21(2):105-10. [pmid: 16421462].
115 Kato M, Zanardi R, Rossini D, et al. 5-HT2A gene variants influence specific and different aspects of antidepressant response in Japanese and Italian mood disorder patients. Psychiatry Res. May. 15. 2009;167(1-2):97-105. [pmid: 19361869].
116 Khan A, Brodhead AE, Kolts RL, et al. Severity of depressive symptoms and response to antidepressants and placebo in antidepressant trials. J Psychiatr Res. 2005;39(2):145-50. [pmid: 15589562].
117 Khandker RK, Kruzikas DT, McLaughlin TP. Pharmacy and medical costs associated with switching between venlafaxine and SSRI antidepressant therapy for the treatment of major depressive disorder. J Manag Care Pharm. Jun. 2008;14(5):426-41. [pmid: 18597572].
118 Kimmick GG, Lovato J, McQuellon R, et al. Randomized, double-blind, placebo-controlled, crossover study of sertraline (Zoloft) for the treatment of hot flashes in women with early stage breast cancer taking tamoxifen. Breast J. Mar-Apr. 2006;12(2):114-22. [pmid: 16509835].
119 Kito S, Koga Y. Visual hallucinations and amnesia associated with zolpidem triggered by fluvoxamine: a possible interaction. Int Psychogeriatr. Dec. 2006;18(4):749-51. [pmid: 17026779].
120 Kluge M, Schussler P, Steiger A. Duloxetine increases stage 3 sleep and suppresses rapid eye movement (REM) sleep in patients with major depression. Eur Neuropsychopharmacol. Jul. 2007;17(8):527-31. [pmid: 17337164].
121 Kocsis JH, Leon AC, Markowitz JC, et al. Patient preference as a moderator of outcome for chronic forms of major depressive disorder treated with nefazodone, cognitive behavioral analysis system of psychotherapy, or their combination. J Clin Psychiatry. Mar. 2009;70(3):354-61. [pmid: 19192474].
122 Koga M, Kodaka F, Miyata H, et al. Symptoms of delusion: the effects of discontinuation of low-dose venlafaxine. Acta Psychiatr Scand. Oct. 2009;120(4):329-31. [pmid: 19573048].
123 Kok R, Nolen W, Heeren T. Cardiovascular changes associated with venlafaxine in the treatment of late-life depression. Am J Geriatr Psychiatry. Aug. 2007;15(8):725. author reply 6. [pmid: 17670999].
124 Kok RM, Nolen WA, Heeren TJ. Venlafaxine versus nortriptyline in the treatment of elderly depressed inpatients: a randomised, double-blind, controlled trial. Int J Geriatr Psychiatry. Dec. 2007;22(12):1247-54. [pmid: 17562523].
125 Kok RM, Nolen WA, Heeren TJ. Outcome of late-life depression after 3 years of sequential treatment. Acta Psychiatr Scand. Apr. 2009;119(4):274-81. [pmid: 19053970].
126 Konitsiotis S, Pappa S, Mantas C, et al. Acute reversible dyskinesia induced by mirtazapine. Mov Disord. Jun. 2005;20(6):771. [pmid: 15732128].
127 Kornstein SG, Dunner DL, Meyers AL, et al. A randomized, double-blind study of increasing or maintaining duloxetine dose in patients without remission of major depressive disorder after initial duloxetine therapy. J Clin Psychiatry. Sep. 2008;69(9):1383-92. [pmid: 19193339].
128 Kozel FA, Trivedi MH, Wisniewski SR, et al. Treatment outcomes for older depressed patients with earlier versus late onset of first depressive episode: a Sequenced Treatment Alternatives to Relieve Depression (STAR*D) report. Am J Geriatr Psychiatry. Jan. 2008;16(1):58-64. [pmid: 18165462].
129 Kulisevsky J, Pagonabarraga J, Pascual-Sedano B, et al. Motor changes during sertraline treatment in depressed patients with Parkinson's disease*. Eur J Neurol. Sep. 2008;15(9):953-9. [pmid: 18637826].
130 Kulp W, von der Schulenburg JM, Greiner W. Cost-effectiveness of outpatient treatment in depressive patients with escitalopram in Germany. Eur J Health Econ. Dec. 2005;6(4):317-21. [pmid: 16267659].
131 Kyomen HH, Whitfield TH. Psychosis in the elderly. Am J Psychiatry. Feb. 2009;166(2):146-50. [pmid: 19188291].
132 Lam RW, Andersen HF. The influence of baseline severity on efficacy of escitalopram and citalopram in the treatment of major depressive disorder: an extended analysis. Pharmacopsychiatry. Sep. 2006;39(5):180-4. [pmid: 16944409].
133 Langworth S, Bodlund O, Agren H. Efficacy and tolerability of reboxetine compared with citalopram: a double-blind study in patients with major depressive disorder. J Clin Psychopharmacol. Apr. 2006;26(2):121-7. [pmid: 16633139].
134 Lasch K, Joish VN, Zhu Y, et al. Validation of the sleep impact scale in patients with major depressive disorder and insomnia. Curr Med Res Opin. Jul. 2009;25(7):1699-710. [pmid: 19505198].
135 Lasch K, Joish VN, Zhu YP, et al. Validation of the sleep impact scale in patients with major depressive disorder and insomnia. Current Medical Research and Opinion (England). 2009;25:1699.
136 Lavretsky H, Park S, Siddarth P, et al. Methylphenidate-enhanced antidepressant response to citalopram in the elderly: a double-blind, placebo-controlled pilot trial. Am J Geriatr Psychiatry. Feb. 2006;14(2):181-5. [pmid: 16473984].
137 Leo R, Di Lorenzo G, Tesauro M, et al. Association between enhanced soluble CD40 ligand and proinflammatory and prothrombotic states in major depressive disorder: pilot observations on the effects of selective serotonin reuptake inhibitor therapy. J Clin Psychiatry. Nov. 2006;67(11):1760-6. [pmid: 17196057].
138 Lerman C, Niaura R, Collins BN, et al. Effect of bupropion on depression symptoms in a smoking cessation clinical trial. Psychol Addict Behav. Dec. 2004;18(4):362-6. [pmid: 15631608].
139 Leuchter AF, Cook IA, Gilmer WS, et al. Effectiveness of a quantitative electroencephalographic biomarker for predicting differential response or remission with escitalopram and bupropion in major depressive disorder. Psychiatry Res. Sep. 30. 2009. 2009;169(2):132-8. [pmid: 19709754].
140 Leuchter AF, Lesser IM, Trivedi MH, et al. An open pilot study of the combination of escitalopram and bupropion-SR for outpatients with major depressive disorder. J Psychiatr Pract. Sep. 2008;14(5):271-80. [pmid: 18832958].
141 Leykin Y, Amsterdam JD, DeRubeis RJ, et al. Progressive resistance to a selective serotonin reuptake inhibitor but not to cognitive therapy in the treatment of major depression. J Consult Clin Psychol. Apr. 2007;75(2):267-76. [pmid: 17469884].
142 Liberek C, Aubry JM, Baud P. Manic switch and serotonin syndrome with venlafaxine-lithium-valproate association. Therapie. Nov-Dec. 2006;61(6):531-3. [pmid: 17348610].
143 Lieberman DZ, Montgomery SA, Tourian KA, et al. A pooled analysis of two placebo-controlled trials of desvenlafaxine in major depressive disorder. Int Clin Psychopharmacol. Jul. 2008;23(4):188-97. [pmid: 18545056].
144 Lin CC. Duloxetine treatment of social anxiety disorder with comorbid major depression. J Clin Psychopharmacol. Oct. 2008;28(5):591-2. author reply 2-3. [pmid: 18794669].
145 Liu KS, Snavely DB, Ball WA, et al. Is bigger better for depression trials?. J Psychiatr Res. Jul. 2008;42(8):622-30. [pmid: 17825841].
146 Luis Blay S. Depression and psoriasis comorbidity. Treatment with paroxetine: two case reports. Ann Clin Psychiatry. Oct-Dec. 2006;18(4):271-2. [pmid: 17162628].
147 Lustman PJ, Williams MM, Sayuk GS, et al. Factors influencing glycemic control in type 2 diabetes during acute- and maintenance-phase treatment of major depressive disorder with bupropion. Diabetes Care. Mar. 2007;30(3):459-66. [pmid: 17327305].
148 Mallinckrodt CH, Prakash A, Houston JP, et al. Differential antidepressant symptom efficacy: placebo-controlled comparisons of duloxetine and SSRIs (fluoxetine, paroxetine, escitalopram). Neuropsychobiology. 2007;56(2-3):73-85. [pmid: 18037817].
149 Malone DC. A budget-impact and cost-effectiveness model for second-line treatment of major depression. J Manag Care Pharm. Jul. 2007;13(6 Suppl A):S8-18. [pmid: 17874482].
150 Mandelli L, Serretti A, Zanardi R, et al. Antidepressant response in the elderly. Psychiatry Res. Jul. 30. 2007;152(1):37-44. [pmid: 17383015].
151 March JS, Team T, Silva S, et al. The Treatment for Adolescents with Depression Study (TADS) - Long-term effectiveness and safety outcomes. Archives of General Psychiatry (USA). 10. 01. 2007;64(Oct):1132-44.
152 Marcus RN, McQuade RD, Carson WH, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder: a second multicenter, randomized, double-blind, placebo-controlled study. J Clin Psychopharmacol. Apr. 2008;28(2):156-65. [pmid: 18344725].
153 Markowitz JC, Kocsis JH, Bleiberg KL, et al. A comparative trial of psychotherapy and pharmacotherapy for “pure” dysthymic patients. J Affect Disord. Dec. 2005;89(1-3):167-75. [pmid: 16263177].
154 Mayer LS, Bay RC, Politis A, et al. Comparison of three rating scales as outcome measures for treatment trials of depression in Alzheimer disease: findings from DIADS. Int J Geriatr Psychiatry. Oct. 2006;21(10):930-6. [pmid: 16955427].
155 McGrath PJ, Khan AY, Trivedi MH, et al. Response to a selective serotonin reuptake inhibitor (citalopram) in major depressive disorder with melancholic features: a STAR*D report. J Clin Psychiatry. Dec. 2008;69(12):1847-55. [pmid: 19026268].
156 Melartin TK, Rytsälä HJ, Leskelä US, et al. Continuity is the main challenge in treating major depressive disorder in psychiatric care. J Clin Psychiatry. 2005;66(2):220-7. [pmid: 15705008].
157 Meyers BS, Flint AJ, Rothschild AJ, et al. A double-blind randomized controlled trial of olanzapine plus sertraline vs olanzapine plus placebo for psychotic depression: the study of pharmacotherapy of psychotic depression (STOP-PD). Arch Gen Psychiatry. 2009;66(8):838-47. [pmid: 19652123].
158 Michelson D, Adler LA, Amsterdam JD, et al. Addition of atomoxetine for depression incompletely responsive to sertraline: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Apr. 2007;68(4):582-7. [pmid: 17474814].
159 Miranda J, Green BL, Krupnick JL, et al. One-year outcomes of a randomized clinical trial treating depression in low-income minority women. J Consult Clin Psychol. Feb. 2006;74(1):99-111. [pmid: 16551147].
160 Mohamed S, Osatuke K, Aslam M, et al. Escitalopram for comorbid depression and anxiety in elderly patients: A 12-week, open-label, flexible-dose, pilot trial. Am J Geriatr Pharmacother. Sep. 2006;4(3):201-9. [pmid: 17062320].
161 Möller HJ. Is there evidence for negative effects of antidepressants on suicidality in depressive patients? A systematic review. Eur Arch Psychiatry Clin Neurosci. 2006;256(8):476-96. [pmid: 17143567].
162 Moncrieff J, Kirsch I. Efficacy of antidepressants in adults. Br Med J. 2005;331(7509):155-7. [pmid: 16020858].
163 Monte S, Macchia A, Romero M, et al. Antidepressants and cardiovascular outcomes in patients without known cardiovascular risk. Eur J Clin Pharmacol. 2009;65(11):1131-8. [pmid: 19597805].
164 Morales N, Vermette H. Serotonin syndrome associated with linezolid treatment after discontinuation of fluoxetine. Psychosomatics. May-Jun. 2005;46(3):274-5. [pmid: 15883150].
165 Morasco BJ, Rifai MA, Loftis JM, et al. A randomized trial of paroxetine to prevent interferon-alpha-induced depression in patients with hepatitis C. J Affect Disord. Nov. 2007;103(1-3):83-90. [pmid: 17292481].
166 Mottram P, Wilson K, Strobl J. Antidepressants for depressed elderly. Cochrane Database Syst Rev. 2006;(1).
167 Mowla A, Ghanizadeh A, Pani A. A comparison of effects of fluoxetine and nortriptyline on the symptoms of major depressive disorder. J Clin Psychopharmacol. Apr. 2006;26(2):209-11. [pmid: 16633155].
168 Muhonen LH, Lonnqvist J, Juva K, et al. Double-blind, randomized comparison of memantine and escitalopram for the treatment of major depressive disorder comorbid with alcohol dependence. J Clin Psychiatry. Mar. 2008;69(3):392-9. [pmid: 18348597].
169 Muhonen LH, Lonnqvist J, Lahti J, et al. Age at onset of first depressive episode as a predictor for escitalopram treatment of major depression comorbid with alcohol dependence. Psychiatry Res. May. 15. 2009;167(1-2):115-22. [pmid: 19346004].
170 Mulder RT, Frampton CM, Luty SE, et al. Eighteen months of drug treatment for depression: predicting relapse and recovery. J Affect Disord. Apr. 2009;114(1-3):263-70. [pmid: 18805590].
171 Mulder RT, Joyce PR, Frampton CM, et al. Antidepressant treatment is associated with a reduction in suicidal ideation and suicide attempts. Acta Psychiatr Scand. Aug. 2008;118(2):116-22. [pmid: 18384467].
172 Mulsant BH. Onset of confusion in the context of late-life depression. J Psychiatry Neurosci. Mar. 2007;32(2):152. [pmid: 17353943].
173 Musselman DL, Somerset WI, Guo Y, et al. A double-blind, multicenter, parallel-group study of paroxetine, desipramine, or placebo in breast cancer patients (stages I, II, III, and IV) with major depression. J Clin Psychiatry. Feb. 2006;67(2):288-96. [pmid: 16566626].
174 Mussig K, Morike K, Haring HU. Severe and symptomatic hyponatremia following duloxetine treatment. J Psychopharmacol. May. 2009;23(3):338-9. [pmid: 18562431].
175 Nemeroff CB, Entsuah R, Benattia I, et al. Comprehensive analysis of remission (COMPARE) with venlafaxine versus SSRIs. Biol Psychiatry. Feb. 15. 2008;63(4):424-34. [pmid: 17888885].
176 Ng J, Sansone RA, McDonald S. Akathisia and abnormal movements of the upper extremities with venlafaxine and methimazole. Gen Hosp Psychiatry. 2009;31(4):388-90. [pmid: 19555803].
177 Nose M, Cipriani A, Furukawa TA, et al. Duloxetine versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2007;(2).
178 O'Brien SM. A possible role of recurrent major depression in risk of fracture. Arch Intern Med. Nov. 26. 2007;167(21):2370. author reply-1. [pmid: 18040002].
179 Olfson M, Shaffer D. SSRI prescriptions and the rate of suicide. Am J Psychiatry. 2007;164(12):1907-8. [pmid: 18056247].
180 Olie JP, Tonnoir B, Menard F, et al. A prospective study of escitalopram in the treatment of major depressive episodes in the presence or absence of anxiety. Depress Anxiety. 2007;24(5):318-24. [pmid: 17041922].
181 Olver JS, Burrows GD, Norman TR. The treatment of depression with different formulations of venlafaxine: a comparative analysis. Hum Psychopharmacol. Jan. 2004;19(1):9-16. [pmid: 14716706].
182 Omori I, Watanabe N, Nakagawa A, et al. Fluvoxamine versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2006;(3).
183 Ott GE, Rao U, Lin KM, et al. Effect of treatment with bupropion on EEG sleep: relationship to antidepressant response. Int J Neuropsychopharmacol. Sep. 2004;7(3):275-81. [pmid: 15122973].
184 Ozdemir S, Yalug I, Aker AT. Serotonin syndrome associated with sertraline monotherapy at therapeutic doses. Prog Neuropsychopharmacol Biol Psychiatry. Apr. 1. 2008;32(3):897-8. [pmid: 18077070].
185 Papadimitriou GN, Theleritis CG, Papageorgiou CC, et al. Acute adverse cutaneous reaction after the concomitant use of venlafaxine and orphenadrine citrate plus paracetamol in a depressed patient. J Eur Acad Dermatol Venereol. Sep. 2006;20(8):1019. [pmid: 16922966].
186 Papakostas GI, Clain A, Ameral VE, et al. Fluoxetine-clonazepam cotherapy for anxious depression: an exploratory, post-hoc analysis of a randomized, double blind study. Int Clin Psychopharmacol. 2010;25(1):17-21. [pmid: 19898245].
187 Papakostas GI, Crawford CM, Scalia MJ, et al. Timing of clinical improvement and symptom resolution in the treatment of major depressive disorder. A replication of findings with the use of a double-blind, placebo-controlled trial of Hypericum perforatum versus fluoxetine. Neuropsychobiology. 2007;56(2-3):132-7. [pmid: 18259086].
188 Papakostas GI, McGrath P, Stewart J, et al. Psychic and somatic anxiety symptoms as predictors of response to fluoxetine in major depressive disorder. Psychiatry Res. Oct. 30. 2008;161(1):116-20. [pmid: 18755514].
189 Papakostas GI, Montgomery SA, Thase ME, et al. Comparing the rapidity of response during treatment of major depressive disorder with bupropion and the SSRIs: a pooled survival analysis of 7 double-blind, randomized clinical trials. J Clin Psychiatry. Dec. 2007;68(12):1907-12. [pmid: 18162022].
190 Papakostas GI, Trivedi MH, Alpert JE, et al. Efficacy of bupropion and the selective serotonin reuptake inhibitors in the treatment of anxiety symptoms in major depressive disorder: a metaanalysis of individual patient data from 10 double-blind, randomized clinical trials. J Psychiatr Res. Jan. 2008;42(2):134-40. [pmid: 17631898].
191 Park YM, Lee HJ, Kang SG, et al. Tardive dyskinesia associated with long-term administration of escitalopram and itopride in major depressive disorder. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 17. 2009;33(2):380-1. [pmid: 19121360].
192 Parker G, Tully L, Olley A, et al. SSRIs as mood stabilizers for Bipolar II Disorder? A proof of concept study. J Affect Disord. Jun. 2006;92(2-3):205-14. [pmid: 16516304].
193 Parry BL. Perimenopausal depression. Am J Psychiatry. Jan. 2008;165(1):23-7. [pmid: 18178752].
194 Perahia DG, Quail D, Desaiah D, et al. Switching to duloxetine from selective serotonin reuptake inhibitor antidepressants: a multicenter trial comparing 2 switching techniques. J Clin Psychiatry. Jan. 2008;69(1):95-105. [pmid: 18312043].
195 Perahia DG, Quail D, Desaiah D, et al. Switching to duloxetine in selective serotonin reuptake inhibitor non- and partial-responders: effects on painful physical symptoms of depression. J Psychiatr Res. Feb. 2009;43(5):512-8. [pmid: 18707693].
196 Perahia DGS, Pritchett YL, Desaiah D, et al. Efficacy of duloxetine in painful symptoms: An analgesic or antidepressant effect?. Int Clin Psychopharmacol. Nov. 2006. 2006;21(6):311-7. [pmid: 17012978].
197 Perlis RH, Moorjani P, Fagerness J, et al. Pharmacogenetic analysis of genes implicated in rodent models of antidepressant response: association of TREK1 and treatment resistance in the STAR(*)D study. Neuropsychopharmacology. Nov. 2008;33(12):2810-9. [pmid: 18288090].
198 Perry R, Cassagnol M. Desvenlafaxine: A new serotonin-norepinephrine reuptake inhibitor for the treatment of adults with major depressive disorder. Clin Ther. 2009;31(SUPPL. 1):1374-404. [pmid: 19698900].
199 Perugi G, Romano A, Tusini G. Short-term and long-term treatment in depressive syndromes: Focus on antidepressants tolerability. Trattamento farmacologico a breve e lungo termine nelle sindromi depressive: Focus sulla tollerabilità degli antidepressivi. 2007;13(3):378-86.
200 Pierson K, Addington D, Addington J, et al. Serum monitoring of antipsychotic drug levels during concomitant administration of sertraline and antipsychotic medication. Can J Psychiatry. Oct. 2006;51(11):715-8. [pmid: 17121171].
201 Pinquart M, Duberstein PR, Lyness JM. Treatments for later-life depressive conditions: A meta-analytic comparison of pharmacotherapy and psychotherapy. Am J Psychiatry. 2006;163(9):1493-501. [pmid: 16946172].
202 Pinto C, Trivedi JK, Vankar GK, et al. An open-label multicentric study of the tolerability and response to escitalopram treatment in Indian patients with major depressive disorder. J Indian Med Assoc. Jul. 2007;105(7):364-6. 8 passim. [pmid: 18178988].
203 Pitchot W, Ansseau M. Shock-like sensations associated with duloxetine discontinuation. Ann Clin Psychiatry. Jul-Sep. 2008;20(3):175. [pmid: 18633745].
204 Post RM, Altshuler LL, Leverich GS, et al. Mood switch in bipolar depression: comparison of adjunctive venlafaxine, bupropion and sertraline. Br J Psychiatry. Aug. 2006;189:124-31. [pmid: 16880481].
205 Posternak MA, Zimmerman M. Dual Reuptake Inhibitors Incur Lower Rates of Tachyphylaxis Than Selective Serotonin Reuptake Inhibitors: A Retrospective Study. J Clin Psychiatry. Jun. 2005. 2005;66(6):705-7. [pmid: 15960562].
206 Preskorn SH, Baker B, Kolluri S, et al. An innovative design to establish proof of concept of the antidepressant effects of the NR2B subunit selective N-methyl-D-aspartate antagonist, CP-101,606, in patients with treatment-refractory major depressive disorder. J Clin Psychopharmacol. Dec. 2008;28(6):631-7. [pmid: 19011431].
207 Prospero-Garcia KA, Torres-Ruiz A, Ramirez-Bermudez J, et al. Fluoxetine-mirtazapine interaction may induce restless legs syndrome: report of 3 cases from a clinical trial. J Clin Psychiatry. Nov. 2006;67(11):1820. [pmid: 17196069].
208 Pukadan D, Antony J, Mohandas E, et al. Use of escitalopram in psychogenic excoriation. Aust N Z J Psychiatry. May. 2008;42(5):435-6. [pmid: 18499934].
209 Ravindran LN, Eisfeld BS, Kennedy SH. Combining mirtazapine and duloxetine in treatment-resistant depression improves outcomes and sexual function. Journal of Clinical Psychopharmacology (USA). 01. 01. 2008;28(Jan):107-8.
210 Resler G, Lavie R, Campos J, et al. Effect of folic acid combined with fluoxetine in patients with major depression on plasma homocysteine and vitamin B12, and serotonin levels in lymphocytes. Neuroimmunomodulation. 2008;15(3):145-52. [pmid: 18716414].
211 Rigonatti SP, Boggio PS, Myczkowski ML, et al. Transcranial direct stimulation and fluoxetine for the treatment of depression. Eur Psychiatry. Jan. 2008;23(1):74-6. [pmid: 18023968].
212 Rothbaum BO, Killeen TK, Davidson JR, et al. Placebo-controlled trial of rispeyidone augmentation for selective seyotonin seyotonin inhibitor-resistant civilian posttraumatic stress disorder. J Clin Psychiatry. 04. 01. 2008;69(Apr):520-5. [pmid: 18278987].
213 Royall DR, Cordes JA, Roman G, et al. Sertraline improves executive function in patients with vascular cognitive impairment. J Neuropsychiatry Clin Neurosci. 2009;21(4):445-54. [pmid: 19996254].
214 Rudolph RL. Achieving remission from depression with venlafaxine and venlafaxine extended release: a literature review of comparative studies with selective serotonin reuptake inhibitors. Acta Psychiatr Scand Suppl. 2002;(415):24-30. [pmid: 12492770].
215 Ruhe HG, Booij J, v Weert HC, et al. Evidence why paroxetine dose escalation is not effective in major depressive disorder: a randomized controlled trial with assessment of serotonin transporter occupancy. Neuropsychopharmacology. Mar. 2009;34(4):999-1010. [pmid: 18830236].
216 Rush AJ. Limitations in efficacy of antidepressant monotherapy. J Clin Psychiatry. Suppl 10. 2007;68:8-10. [pmid: 17900203].
217 San L, Arranz B. Mirtazapine: Only for depression?. Acta Neuropsychiatrica. Jun-Aug. 2006. 2006;18(3):130-43.
218 Sansone RA, Sansone LA. Bupropion-induced neck and shoulder pain. Pharmacopsychiatry. Sep. 2009;42(5):203-4. [pmid: 19724984].
219 Santos MA, Rocha FL, Hara C. Efficacy and safety of antidepressant augmentation with lamotrigine in patients with treatment-resistant depression: A randomized, placebo-controlled, double-blind study. Primary Care Companion to the Journal of Clinical Psychiatry. 2008;10(3):187-90.
220 Santos PM, Lopez-Garcia P, Navarro JS, et al. False positive phencyclidine results caused by venlafaxine. Am J Psychiatry. Feb. 2007;164(2):349. [pmid: 17267806].
221 Schule C, Baghai TC, Eser D, et al. Lithium but not carbamazepine augments antidepressant efficacy of mirtazapine in unipolar depression: an open-label study. World J Biol Psychiatry. 2009;10(4 Pt 2):390-9. [pmid: 18609420].
222 Schweitzer I, Maguire K, Ng C. Sexual side-effects of contemporary antidepressants: review. Aust N Z J Psychiatry. Sep. 2009;43(9):795-808. [pmid: 19670052].
223 Seo HJ, Jung YE, Woo YS, et al. Effect of augmented atypical antipsychotics on weight change in patients with major depressive disorder in a naturalistic setting. Hum Psychopharmacol. Mar. 2009;24(2):135-43. [pmid: 19156709].
224 Serrano-Blanco A, Gabarron E, Garcia-Bayo I, et al. Effectiveness and cost-effectiveness of antidepressant treatment in primary health care: a six-month randomised study comparing fluoxetine to imipramine. J Affect Disord. Apr. 2006;91(2-3):153-63. [pmid: 16458976].
225 Serretti A, Cusin C, Benedetti F, et al. Insomnia improvement during antidepressant treatment and CLOCK gene polymorphism. American Journal of Medical Genetics Neuropsychiatric Genetics. 2005;137(1):36-9.
226 Sheehan DV, Eaddy MT, Shah MB, et al. Differences in total medical costs across the SSRIs for the treatment of depression and anxiety. Am J Manag Care. Oct. 2005;11(12 Suppl):S354-61. [pmid: 16236017].
227 Sheffrin M, Driscoll HC, Lenze EJ, et al. Pilot study of augmentation with aripiprazole for incomplete response in late-life depression: getting to remission. J Clin Psychiatry. Feb. 2009;70(2):208-13. [pmid: 19210951].
228 Shelton RC, Andorn AC, Mallinckrodt CH, et al. Evidence for the efficacy of duloxetine in treating mild, moderate, and severe depression. Int Clin Psychopharmacol. Nov. 2007;22(6):348-55. [pmid: 17917553].
229 Shelton RC, Prakash A, Mallinckrodt CH, et al. Patterns of depressive symptom response in duloxetine-treated outpatients with mild, moderate or more severe depression. Int J Clin Pract. Aug. 2007;61(8):1337-48. [pmid: 17627710].
230 Shen J, Moller HJ, Wang X, et al. Mirtazapine, a sedating antidepressant, and improved driving safety in patients with major depressive disorder: a prospective, randomized trial of 28 patients. J Clin Psychiatry. Mar. 2009;70(3):370-7. [pmid: 19192466].
231 Simon JS, Sheehan D, Thase ME, et al. Comparison of efficacy and tolerability of paroxetine vs venlafaxine. 2005.
232 Smith GS, Reynolds CF 3rd, Houck PR, et al. Cerebral glucose metabolic response to combined total sleep deprivation and antidepressant treatment in geriatric depression: a randomized, placebo-controlled study. Psychiatry Res. Jan. 30. 2009;171(1):1-9. [pmid: 19087899].
233 Snedecor SJ, Botteman MF, Schaefer K, et al. Economic outcomes of eszopiclone treatment in insomnia and comorbid major depressive disorder. The journal of mental health policy and economics. 2010;(1):27-35. [pmid: 20571180].
234 Sneed JR, Keilp JG, Brickman AM, et al. The specificity of neuropsychological impairment in predicting antidepressant non-response in the very old depressed. Int J Geriatr Psychiatry. Mar. 2008;23(3):319-23. [pmid: 17726720].
235 Sneed JR, Roose SP, Keilp JG, et al. Response inhibition predicts poor antidepressant treatment response in very old depressed patients. Am J Geriatr Psychiatry. Jul. 2007;15(7):553-63. [pmid: 17586780].
236 Solomon DA, Leon AC, Mueller TI, et al. Tachyphylaxis in unipolar major depressive disorder. J Clin Psychiatry. 2005;66(3):283-90. [pmid: 15766292].
237 Sopko MA Jr, Ehret MJ, Grgas M. Desvenlafaxine: another “me too” drug?. Ann Pharmacother. Oct. 2008;42(10):1439-46. [pmid: 18698015].
238 Spalletta G, Ripa A, Bria P, et al. Response of emotional unawareness after stroke to antidepressant treatment. Am J Geriatr Psychiatry. Mar. 2006;14(3):220-7. [pmid: 16505126].
239 Stone MB, Jones ML. Clinical Review: Relationship Between Antidepressant Drugs and Suicidality in Adults. 2006:1-64.
240 Tadic A, Muller MJ, Rujescu D, et al. The MAOA T941G polymorphism and short-term treatment response to mirtazapine and paroxetine in major depression. Am J Med Genet B Neuropsychiatr Genet. Apr. 5. 2007;144B(3):325-31. [pmid: 17192957].
241 Tadic A, Rujescu D, Muller MJ, et al. A monoamine oxidase B gene variant and short-term antidepressant treatment response. Prog Neuropsychopharmacol Biol Psychiatry. Oct. 1. 2007;31(7):1370-7. [pmid: 17640790].
242 Taylor MJ, Freemantle N, Geddes JR, et al. Early onset of selective serotonin reuptake inhibitor antidepressant action: Systematic review and meta-analysis. Arch Gen Psychiatry. 2006;63(11):1217-23. [pmid: 17088502].
243 Taylor WD, Kuchibhatla M, Payne ME, et al. Frontal white matter anisotropy and antidepressant remission in late-life depression. PLoS One. 2008;3(9):e3267. [pmid: 18813343].
244 Tew JD Jr, Mulsant BH, Houck PR, et al. Impact of prior treatment exposure on response to antidepressant treatment in late life. Am J Geriatr Psychiatry. Nov. 2006;14(11):957-65. [pmid: 17068318].
245 Thase ME, Corya SA, Osuntokun O, et al. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, and fluoxetine in treatment-resistant major depressive disorder. J Clin Psychiatry. Feb. 2007;68(2):224-36. [pmid: 17335320].
246 Thase ME, Fava M, DeBattista C, et al. Modafinil augmentation of SSRI therapy in patients with major depressive disorder and excessive sleepiness and fatigue: a 12-week, open-label, extension study. CNS Spectr. 2006;11(2):93-102. [pmid: 16520686].
247 Thase ME, Shelton RC, Khan A. Treatment with venlafaxine extended release after SSRI nonresponse or intolerance: a randomized comparison of standard- and higher-dosing strategies. J Clin Psychopharmacol. Jun. 2006;26(3):250-8. [pmid: 16702889].
248 Trivedi MH. Major depressive disorder: Remission of associated symptoms. J Clin Psychiatry. 2006;67(SUPPL. 6):27-32. [pmid: 16848674].
249 Trivedi MH, Corey-Lisle PK, Guo Z, et al. Remission, response without remission, and nonresponse in major depressive disorder: impact on functioning. Int Clin Psychopharmacol. May. 2009;24(3):133-8. [pmid: 19318972].
250 Trivedi MH, Hollander E, Nutt D, et al. Clinical evidence and potential neurobiological underpinnings of unresolved symptoms of depression. J Clin Psychiatry. 02. 01. 2008;69(Feb):246-58. [pmid: 18363453].
251 Trivedi MH, Rush AJ, Wisniewski SR, et al. Factors associated with health-related quality of life among outpatients with major depressive disorder: A STAR*D report. J Clin Psychiatry. 2006;67(2):185-95. [pmid: 16566612].
252 Trivedi MH, Thase ME, Osuntokun O, et al. An integrated analysis of olanzapine/fluoxetine combination in clinical trials of treatment-resistant depression. J Clin Psychiatry. Mar. 2009;70(3):387-96. [pmid: 19284928].
253 Trivedi MH, Wan GJ, Mallick R, et al. Cost and effectiveness of venlafaxine extended-release and selective serotonin reuptake inhibitors in the acute phase of outpatient treatment for major depressive disorder. J Clin Psychopharmacol. Oct. 2004;24(5):497-506. [pmid: 15349005].
254 Uher R, Farmer A, Henigsberg N, et al. Adverse reactions to antidepressants. Br J Psychiatry. Sep. 2009;195(3):202-10. [pmid: 19721108].
255 Vaccaro M, Borgia F, Barbuzza O, et al. Photodistributed eruptive telangiectasia: an uncommon adverse drug reaction to venlafaxine. Br J Dermatol. Oct. 2007;157(4):822-4. [pmid: 17655739].
256 van Marwijk HW, Ader H, de Haan M, et al. Primary care management of major depression in patients aged > or =55 years: outcome of a randomised clinical trial. Br J Gen Pract. Oct. 2008;58(555):680-6. I. II. discussion 7. [pmid: 18826778].
257 van Zyl LT, Lesperance F, Frasure-Smith N, et al. Platelet and endothelial activity in comorbid major depression and coronary artery disease patients treated with citalopram: the Canadian Cardiac Randomized Evaluation of Antidepressant and Psychotherapy Efficacy Trial (CREATE) biomarker sub-study. J Thromb Thrombolysis. Jan. 2009;27(1):48-56. [pmid: 18188512].
258 Vazquez MJ, Carretero Quevedo B. Pneumonitis related to venlafaxine. Psychosomatics. Jan-Feb. 2008;49(1):84-5. [pmid: 18212183].
259 Ververs T, Kaasenbrood H, Visser G, et al. Prevalence and patterns of antidepressant drug use during pregnancy. Eur J Clin Pharmacol. Oct. 2006;62(10):863-70. [pmid: 16896784].
260 Wade AG, Fernandez JL, Francois C, et al. Escitalopram and duloxetine in major depressive disorder: a pharmacoeconomic comparison using UK cost data. Pharmacoeconomics. 2008;26(11):969-81. [pmid: 18850765].
261 Wade AG, Schlaepfer TE, Andersen HF, et al. Clinical milestones predict symptom remission over 6-month and choice of treatment of patients with major depressive disorder (MDD). J Psychiatr Res. Feb. 2009;43(5):568-75. [pmid: 18954875].
262 Wålinder J, Prochazka J, Odén A, et al. Mirtazapine naturalistic depression study (in Sweden)--MINDS(S): Clinical efficacy and safety. Human Psychopharmacology: Clinical and Experimental. Apr. 2006. 2006;21(3):151-8. [pmid: 16444795].
263 Warden D, Trivedi MH, Wisniewski SR, et al. Predictors of attrition during initial (citalopram) treatment for depression: a STAR*D report. Am J Psychiatry. 2007;164(8):1189-97. [pmid: 17671281].
264 Watanabe N, Barbui C, Churchill R, et al. Mirtazapine versus other anti-depressive agents for depression (Protocol). Cochrane Database of Systematic Reviews. 2006;(3).
265 Weber-Hamann B, Gilles M, Schilling C, et al. Improved insulin sensitivity in 51 nondiabetic depressed inpatients remitting during antidepressive treatment with mirtazapine and venlafaxine. J Clin Psychopharmacol. Oct. 2008;28(5):581-4. [pmid: 18794665].
266 Weintraub D, Taraborelli D, Morales KH, et al. Escitalopram for major depression in Parkinson's disease: an open-label, flexible-dosage study. J Neuropsychiatry Clin Neurosci. Summer. 2006;18(3):377-83. [pmid: 16963587].
267 Winokur A, Baker RA, Simmons J, et al. Comparative sleep improving effects of mirtazapine vs SSRIs in depressed patients: A meta-analysis of individual patient data. 8th World Congress of the World Federation of Societies of Biological Psychiatry. Vienna, Austria. World J Biol Psychiatry. 2005:S1366-7.
268 Wisniewski SR, Rush AJ, Nierenberg AA, et al. Can phase III trial results of antidepressant medications be generalized to clinical practice? A STAR*D report. Am J Psychiatry. May. 2009;166(5):599-607. [pmid: 19339358].
269 Wohlreich MM, Mallinckrodt CH, Prakash A, et al. Duloxetine for the treatment of major depressive disorder: safety and tolerability associated with dose escalation. Depress Anxiety. 2007;24(1):41-52. [pmid: 16845641].
270 Wohlreich MM, Martinez JM, Mallinckrodt CH, et al. An open-label study of duloxetine for the treatment of major depressive disorder: comparison of switching versus initiating treatment approaches. J Clin Psychopharmacol. Dec. 2005;25(6):552-60. [pmid: 16282837].
271 Wu E, Greenberg P, Yang E, et al. Comparison of treatment persistence, hospital utilization and costs among major depressive disorder geriatric patients treated with escitalopram versus other SSRI/SNRI antidepressants. Curr Med Res Opin. Oct. 2008;24(10):2805-13. [pmid: 18755054].
272 Wu E, Greenberg PE, Yang E, et al. Comparison of escitalopram versus citalopram for the treatment of major depressive disorder in a geriatric population. Curr Med Res Opin. Sep. 2008;24(9):2587-95. [pmid: 18674407].
273 Wu YS, Chen YC, Lu RB. Venlafaxine vs. paroxetine in the acute phase of treatment for major depressive disorder among Han Chinese population in Taiwan. J Clin Pharm Ther. Aug. 2007;32(4):353-63. [pmid: 17635337].
274 Yang LP, Plosker GL. Desvenlafaxine extended release. CNS Drugs. 2008;22(12):1061-9. [pmid: 18998743].
275 Yasui-Furukori N, Kaneko S. Digitalis intoxication induced by paroxetine coadministration. Lancet. Mar. 4. 2006;367(9512):788. [pmid: 16517279].
276 Yazicioglu B, Akkaya C, Sarandol A, et al. A comparison of the efficacy and tolerability of reboxetine and sertraline versus venlafaxine in major depressive disorder: a randomized, open-labeled clinical trial. Prog Neuropsychopharmacol Biol Psychiatry. Sep. 30. 2006;30(7):1271-6. [pmid: 16820257].
277 Zisook S, Ganadjian K, Moutier C, et al. Sequenced Treatment Alternatives to Relieve Depression (STAR*D): lessons learned. J Clin Psychiatry. Jul. 2008;69(7):1184-5. [pmid: 18687018].

## Wrong Design (408)

1 Acharya N, Rosen AS, Polzer JP, et al. Duloxetine: meta-analyses of suicidal behaviors and ideation in clinical trials for major depressive disorder. J Clin Psychopharmacol. 2006;26(6):587-94. [pmid: 17110815].
2 Agius M, Gardner J, Liu K, et al. An audit to compare discharge rates and suicidality between antidepressant monotherapies prescribed for unipolar depression. Psychiatr Danub. Jun. 2010;22(2):350-3. [pmid: 20562780].
3 Akiskal HS, Benazzi F. Does the FDA proposed list of possible correlates of suicidality associated with antidepressants apply to an adult private practice population?. J Affect Disord. 2006;94(1-3):105-10. [pmid: 16766043].
4 Altamura AC, Montgomery SA, Wernicke JF. The evidence for 20mg a day of fluoxetine as the optimal dose in the treatment of depression. Br J Psychiatry Suppl. 1988;(3):109-12. [pmid: 3074862].
5 Amore M, Ricci M, Zanardi R, et al. Long-term treatment of geropsychiatric depressed patients with venlafaxine. J Affect Disord. Dec. 1997;46(3):293-6. [pmid: 9547127].
6 Anderson RJ, Gott BM, Sayuk GS, et al. Antidepressant pharmacotherapy in adults with type 2 diabetes: rates and predictors of initial response. Diabetes Care. Mar. 2010;33(3):485-9. [pmid: 20032276].
7 Appelhof BC, Brouwer JP, van Dyck R, et al. Triiodothyronine addition to paroxetine in the treatment of major depressive disorder. J Clin Endocrinol Metab. Dec. 2004;89(12):6271-6. [pmid: 15579788].
8 Applebee GA, Attarian HP, Schenck CH. An angry bed partner. J Clin Sleep Med. 2009;5(5):477-9. [pmid: 19961035].
9 Arnold LM, Meyers AL, Sunderajan P, et al. The effect of pain on outcomes in a trial of duloxetine treatment of major depressive disorder. Ann Clin Psychiatry. Oct-Dec. 2008;20(4):187-93. [pmid: 19034749].
10 Arranz FJ, Ros S. Effects of comorbidity and polypharmacy on the clinical usefulness of sertraline in elderly depressed patients: an open multicentre study. J Affect Disord. Dec. 1997;46(3):285-91. [pmid: 9547126].
11 Atlantis E, Browning C, Sims J, et al. Diabetes incidence associated with depression and antidepressants in the Melbourne Longitudinal Studies on Healthy Ageing (MELSHA). Int J Geriatr Psychiatry. 2010;25(7):688-96. [pmid: 19806604].
12 Aursnes I, Gjertsen MK. Common adverse events associated with an SSRI: meta-analysis of early paroxetine data. Pharmacoepidemiol Drug Saf. Jul. 2008;17(7):707-13. [pmid: 18383561].
13 Bailey RK, Mallinckrodt CH, Wohlreich MM, et al. Duloxetine in the treatment of major depressive disorder: comparisons of safety and efficacy. J Natl Med Assoc. 2006;98(3):437-47. [pmid: 16573311].
14 Baldwin DS, Hawley CJ, Mellors K. A randomized, double-blind controlled comparison of nefazodone and paroxetine in the treatment of depression: safety, tolerability and efficacy in continuation phase treatment. J Psychopharmacol. Sep. 2001;15(3):161-5. [pmid: 11565622].
15 Baldwin DS, Montgomery SA, Nil R, et al. Discontinuation symptoms in depression and anxiety disorders. International Journal of Neuropsychopharmacology. 2007;10(1):73-84. [pmid: 16359583].
16 Bandelow B, Andersen HF, Dolberg OT. Escitalopram in the treatment of anxiety symptoms associated with depression. Depress Anxiety. 2007;24(1):53-61. [pmid: 16937393].
17 Barbui C, Furukawa TA, Cipriani A. Effectiveness of paroxetine in the treatment of acute major depression in adults: A systematic re-examination of published and unpublished data from randomized trials. Can Med Assoc J. 2008;178(3):296-305. [pmid: 18227449].
18 Bauer M, Tharmanathan P, Volz HP, et al. The effect of venlafaxine compared with other antidepressants and placebo in the treatment of major depression: a meta-analysis. Eur Arch Psychiatry Clin Neurosci. 2009;259(3):172-85. [pmid: 19165525].
19 Beasley CM Jr, Nilsson ME, Koke SC, et al. Efficacy, adverse events, and treatment discontinuations in fluoxetine clinical studies of major depression: a meta-analysis of the 20-mg/day dose. J Clin Psychiatry. Oct. 2000;61(10):722-8. [pmid: 11078032].
20 Beasley CM Jr, Potvin JH. Fluoxetine: activating and sedating effects. Int Clin Psychopharmacol. Winter. 1993;8(4):271-5. [pmid: 8277147].
21 Beasley CM Jr, Sayler ME, Cunningham GE, et al. Fluoxetine in tricyclic refractory major depressive disorder. J Affect Disord. Nov. 1990;20(3):193-200. [pmid: 2148340].
22 Beasley CM Jr, Sayler ME, Weiss AM, et al. Fluoxetine: activating and sedating effects at multiple fixed doses. J Clin Psychopharmacol. Oct. 1992;12(5):328-33. [pmid: 1479050].
23 Beasley CM Jr, Ball SG, Nilsson ME, et al. Fluoxetine and adult suicidality revisited: An updated meta-analysis using expanded data sources from placebo-controlled trials. Journal of Clinical Psychopharmacology. 2007;27(6):682-6. [pmid: 18004137].
24 Bech P, Lonn SL, Overo KF. Relapse prevention and residual symptoms: A closer analysis of placebo-controlled continuation studies with escitalopram in major depressive disorder, generalized anxiety disorder, social anxiety disorder, and obsessive-compulsive disorder. J Clin Psychiatry. 2010;71(2):121-9. [pmid: 19961809].
25 Begre S, Traber M, Gerber M, et al. Change in pain severity with open label venlafaxine use in patients with a depressive symptomatology: an observational study in primary care. Eur Psychiatry. Apr. 2008;23(3):178-86. [pmid: 18328675].
26 Benedetti F, Campori E, Colombo C, et al. Fluvoxamine treatment of major depression associated with multiple sclerosis. J Neuropsychiatry Clin Neurosci. Summer. 2004;16(3):364-6. [pmid: 15377746].
27 Berk M, du Plessis AD, Birkett M, et al. An open-label study of duloxetine hydrochloride, a mixed serotonin and noradrenaline reuptake inhibitor, in patients with DSM-III-R major depressive disorder. Lilly Duloxetine Depression Study Group. Int Clin Psychopharmacol. May. 1997;12(3):137-40. [pmid: 9248869].
28 Bertschy G, Ragama-Pardos E, Muscionico M, et al. Trazodone addition for insomnia in venlafaxine-treated, depressed inpatients: a semi-naturalistic study. Pharmacol Res. Jan. 2005;51(1):79-84. [pmid: 15519538].
29 Binneman B, Feltner D, Kolluri S, et al. A 6-week randomized, placebo-controlled trial of CP-316,311 (a selective CRH1 antagonist) in the treatment of major depression. Am J Psychiatry. May. 2008;165(5):617-20. [pmid: 18413705].
30 Biswas PN, Wilton LV, Shakir SA. The pharmacovigilance of mirtazapine: results of a prescription event monitoring study on 13554 patients in England. J Psychopharmacol. Mar. 2003;17(1):121-6. [pmid: 12680749].
31 Bodnar LM, Sunder KR, Wisner KL. Treatment with selective serotonin reuptake inhibitors during pregnancy: deceleration of weight gain because of depression or drug?. Am J Psychiatry. Jun. 2006;163(6):986-91. [pmid: 16741197].
32 Bogetto F, Bellino S, Revello RB, et al. Discontinuation syndrome in dysthymic patients treated with selective serotonin reuptake inhibitors: a clinical investigation. CNS Drugs. 2002;16(4):273-83. [pmid: 11945110].
33 Bogner HR, Lin JY, Morales KH. Patterns of early adherence to the antidepressant citalopram among older primary care patients: the prospect study. Int J Psychiatry Med. 2006;36(1):103-19. [pmid: 16927582].
34 Borkowska A, Drozdz W, Ziolkowska-Kochan M, et al. Enhancing effect of mirtazapine on cognitive functions associated with prefrontal cortex in patients with recurrent depression. Neuropsychopharmacol Hung. Oct. 2007;9(3):131-6. [pmid: 18399031].
35 Bossini L, Fagiolini A, Valdagno M, et al. Sexual disorders in subjects treated for mood and anxiety diseases. [8]. J Clin Psychopharmacol. 2007;27(3):310-2. [pmid: 17502785].
36 Bot M, Pouwer F, Assies J, et al. Eicosapentaenoic acid as an add-on to antidepressant medication for co-morbid major depression in patients with diabetes mellitus: A randomized, double-blind placebo-controlled study. J Affect Disord. 2010;126(1-2):282-6. [pmid: 20466431].
37 Bourin M. Use of paroxetine for the treatment of depression and anxiety disorders in the elderly: a review. Hum Psychopharmacol. Apr. 2003;18(3):185-90. [pmid: 12672169].
38 Bradley RH, Barkin RL, Jerome J, et al. Efficacy of venlafaxine for the long term treatment of chronic pain with associated major depressive disorder. Am J Ther. Sep-Oct. 2003;10(5):318-23. [pmid: 12975715].
39 Brannan SK, Mallinckrodt CH, Detke MJ, et al. Onset of action for duloxetine 60 mg once daily: double-blind, placebo-controlled studies. J Psychiatr Res. Mar. 2005;39(2):161-72. [pmid: 15589564].
40 Brecht S, Kajdasz D, Ball S, et al. Clinical impact of duloxetine treatment on sleep in patients with major depressive disorder. Int Clin Psychopharmacol. 2008;23(6):317-24. [pmid: 18854719].
41 Brown C, Battista DR, Sereika SM, et al. How can you improve antidepressant adherence?. J Fam Pract. 2007;56(5):356-63. [pmid: 17475165].
42 Brunton S, Wang F, Edwards SB, et al. Profile of adverse events with duloxetine treatment: A pooled analysis of placebo-controlled studies. Drug Saf. 2010;33(5):393-407. [pmid: 20397739].
43 Bryan C, Songer T, Brooks MM, et al. The impact of diabetes on depression treatment outcomes. Gen Hosp Psychiatry. 2010;32(1):33-41. [pmid: 20114126].
44 Camacho F, Kong MC, Sheehan DV, et al. Expenditures associated with dose titration at initiation of therapy in patients with major depressive disorder: A retrospective analysis of a large managed care claims database. P and T. 2010;35(8):452-60. 68. [pmid: 20844695].
45 Candrian M, Schwartz F, Farabaugh A, et al. Personality disorders and perceived stress in major depressive disorder. Psychiatry Res. Aug. 15. 2008;160(2):184-91. [pmid: 18573540].
46 Carvalho LA, Gorenstein C, Moreno R, et al. Effect of antidepressants on melatonin metabolite in depressed patients. J Psychopharmacol. May. 2009;23(3):315-21. [pmid: 18562432].
47 Chuang YF, Chiu YL, Hwang TJ, et al. Delirium and multiple electrolyte abnormalities associated with high dose paroxetine exposure. Psychiatry Clin Neurosci. Oct. 2006;60(5):642-3. [pmid: 16958954].
48 Cipriani A, Brambilla P, Furukawa Toshi A, et al. Fluoxetine versus other types of pharmacotherapy for depression. Cochrane Database of Systematic Reviews. 2005;(4).
49 Cipriani A, Furukawa TA, Geddes JR, et al. Does randomized evidence support sertraline as first-line antidepressant for adults with acute major depression? A systematic review and meta-analysis. J Clin Psychiatry. 2008;69(11):1732-42. [pmid: 19026250].
50 Cipriani A, Furukawa TA, Salanti G, et al. Comparative efficacy and acceptability of 12 new-generation antidepressants: a multiple-treatments meta-analysis. Lancet. 2009;373(9665):746-58. [pmid: 19185342].
51 Cipriani A, Pontarollo F, Signoretti A, et al. Escitalopram versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2007;(2).
52 Cipriani A, Santilli C, Furukawa Toshi A, et al. Escitalopram versus other antidepressive agents for depression. Cochrane Database of Systematic Reviews. 2009;(2).
53 Clayton AH, Kornstein SG, Rosas G, et al. An integrated analysis of the safety and tolerability of desvenlafaxine compared with placebo in the treatment of major depressive disorder. CNS Spectr. 2009;14(4):183-95. [pmid: 19407730].
54 Cornelius JR, Bukstein OG, Douaihy AB, et al. Double-blind fluoxetine trial in comorbid MDD-CUD youth and young adults. Drug Alcohol Depend. 2010;112(1-2):39-45. [pmid: 20576364].
55 Cravello L, Caltagirone C, Spalletta G. The SNRI venlafaxine improves emotional unawareness in patients with post-stroke depression. Hum Psychopharmacol. Jun. 2009;24(4):331-6. [pmid: 19330795].
56 Cutler AJ, Montgomery SA, Feifel D, et al. Extended release quetiapine fumarate monotherapy in major depressive disorder: a placebo- and duloxetine-controlled study. J Clin Psychiatry. 2009;70(4):526-39. [pmid: 19358790].
57 de Jonge P, Honig A, van Melle JP, et al. Nonresponse to treatment for depression following myocardial infarction: association with subsequent cardiac events. Am J Psychiatry. Sep. 2007;164(9):1371-8. [pmid: 17728422].
58 de Vasconcelos Cunha UG, Lopes Rocha F, Avila de Melo R, et al. A placebo-controlled double-blind randomized study of venlafaxine in the treatment of depression in dementia. Dement Geriatr Cogn Disord. 2007;24(1):36-41. [pmid: 17495474].
59 Delini-Stula A, Van Oers H, Van Willigenburg A, et al. Treating depression with different galenical drug formulations: Does it make a difference? The comparison of mirtazapine fast dissolving formulation (FDT) with conventional mirtazapine tablets (CT). International Journal of Psychiatry in Clinical Practice. 2009;13(2):109-16.
60 Demyttenaere K, Andersen HF, Reines EH. Impact of escitalopram treatment on Quality of Life Enjoyment and Satisfaction Questionnaire scores in major depressive disorder and generalized anxiety disorder. Int Clin Psychopharmacol. Sep. 2008;23(5):276-86. [pmid: 18703937].
61 Denko TC, Friedman ES. Augmentation strategies in STAR*D : A review. 2007;14(1):5.
62 Denninger JW, Papakostas GI, Mahal Y, et al. Somatic symptoms in outpatients with major depressive disorder treated with fluoxetine. Psychosomatics. Jul-Aug. 2006;47(4):348-52. [pmid: 16844895].
63 Dew MA, Whyte EM, Lenze EJ, et al. Recovery from major depression in older adults receiving augmentation of antidepressant pharmacotherapy. Am J Psychiatry. Jun. 2007;164(6):892-9. [pmid: 17541048].
64 Dichter GS, Tomarken AJ, Freid CM, et al. Do venlafaxine XR and paroxetine equally influence negative and positive affect?. J Affect Disord. Apr. 2005;85(3):333-9. [pmid: 15780704].
65 Dotoli D, Spagnolo C, Bongiorno F, et al. Relapse during a 6-month continuation treatment with fluvoxamine in an Italian population: the role of clinical, psychosocial and genetic variables. Prog Neuropsychopharmacol Biol Psychiatry. May. 2006;30(3):442-8. [pmid: 16431008].
66 Dudley M, Goldney R, Hadzi-Pavlovic D. Are adolescents dying by suicide taking SSRI antidepressants? A review of observational studies. Australasian Psychiatry. 2010;18(3):242-5. [pmid: 20482427].
67 Dunner DL, Wilson M, Fava M, et al. Long-term tolerability and effectiveness of duloxetine in the treatment of major depressive disorder. Depress Anxiety. 2008;25(5):E1-8. [pmid: 17621644].
68 Eaddy M, Bramley T, Regan T. Time to antidepressant discontinuation: a comparison of controlled-release paroxetine and immediate-release selective serotonin-reuptake inhibitors. Manag Care Interface. Dec. 2003;16(12):22-7. [pmid: 14750459].
69 Eker SS, Kirli S, Akkaya C, et al. Are there differences between serotonergic, noradrenergic and dual acting antidepressants in the treatment of depressed women?. World J Biol Psychiatry. 2009;10(4 Pt 2):400-8. [pmid: 19670086].
70 Entsuah R, Chitra R. A benefit-risk analysis of once-daily venlafaxine extended release (XR) and venlafaxine immediate release (IR) in outpatients with major depression. Psychopharmacol Bull. 1997;33(4):671-6. [pmid: 9493478].
71 Entsuah R, Gorman JM. Global benefit-risk assessment of antidepressants: venlafaxine XR and fluoxetine. J Psychiatr Res. May-Jun. 2002;36(3):111-8. [pmid: 11886688].
72 Faramarzi M, Alipor A, Esmaelzadeh S, et al. Treatment of depression and anxiety in infertile women: cognitive behavioral therapy versus fluoxetine. J Affect Disord. 2008;108(1-2):159-64. [pmid: 17936366].
73 Fava M, Graves LM, Benazzi F, et al. A cross-sectional study of the prevalence of cognitive and physical symptoms during long-term antidepressant treatment. J Clin Psychiatry. 2006;67(11):1754-9. [pmid: 17196056].
74 Fava M, Martinez JM, Greist J, et al. The efficacy and tolerability of duloxetine in the treatment of anxious versus non-anxious depression: a post-hoc analysis of an open-label outpatient study. Ann Clin Psychiatry. Jul-Sep. 2007;19(3):187-95. [pmid: 17729021].
75 Fava M, Rush AJ, Alpert JE, et al. Difference in treatment outcome in outpatients with anxious versus nonanxious depression: a STAR*D report. Am J Psychiatry. 2008;165(3):342-51. [pmid: 18172020].
76 Fava M, Rush AJ, Wisniewski SR, et al. A comparison of mirtazapine and nortriptyline following two consecutive failed medication treatments for depressed outpatients: a STAR*D report. Am J Psychiatry. 2006;163(7):1161-72. [pmid: 16816220].
77 Fraguas R, da Silva Telles RM, Alves TC, et al. A double-blind, placebo-controlled treatment trial of citalopram for major depressive disorder in older patients with heart failure: the relevance of the placebo effect and psychological symptoms. Contemp Clin Trials. 2009;30(3):205-11. [pmid: 19470312].
78 Frank C. Recognition and treatment of serotonin syndrome. Can Fam Physician. Jul. 2008;54(7):988-92. [pmid: 18625822].
79 Furukawa TA, Cipriani A, Barbui C, et al. Long-term treatment of depression with antidepressants: A systematic narrative review. The Canadian Journal of Psychiatry. La Revue canadienne de psychiatrie. 2007;52(9):545-52.
80 Gallimore C. Pharmacological Management of Treatment-Resistant Depression Alternative therapies often required to alleviate symptoms. Journal of the Pharmacy Society of Wisconsin (USA). 01. 01. 2008;(NOV-DEC):18-22.
81 Garcia-Cebrian A, Bauer M, Montejo AL, et al. Factors influencing depression endpoints research (FINDER): Study design and population characteristics. European Psychiatry. 2008;23(1):57-65. [pmid: 18086518].
82 Garcia Campayo J. Effectiveness of mirtazapine in the treatment of depression with associated somatic symptoms. Actas Esp Psiquiatr. Jan-Feb. 2008;36(1):25-32. [pmid: 18286397].
83 Garriock HA, Hamilton SP. Genetic studies of drug response and side effects in the STAR*D study, part 2. J Clin Psychiatry. Sep. 2009;70(9):1323-5. [pmid: 19818256].
84 Gartlehner G, Hansen RA, Carey TS, et al. Discontinuation rates for selective serotonin reuptake inhibitors and other second-generation antidepressants in outpatients with major depressive disorder: A systematic review and metaanalysis. International Clinical Psychopharmacology. 2005;20(2):59-69. [pmid: 15729080].
85 Gartlehner G, Thaler K, Hansen RA, et al. The general and comparative efficacy and safety of duloxetine in major depressive disorder: a systematic review and meta-analysis. Drug Saf. 2009;32(12):1159-73. [pmid: 19916583].
86 Gartlehner G, Thieda P, Hansen RA, et al. Comparative risk for harms of second-generation antidepressants : a systematic review and meta-analysis. Drug Saf. 2008;31(10):851-65. [pmid: 18759509].
87 Gaynes BN, Rush AJ, Trivedi MH, et al. Primary versus specialty care outcomes for depressed outpatients managed with measurement-based care: results from STAR*D. J Gen Intern Med. May. 2008;23(5):551-60. [pmid: 18247097].
88 Gilmer WS, Gollan JK, Wisniewski SR, et al. Does the duration of index episode affect the treatment outcome of major depressive disorder? A STAR*D report. J Clin Psychiatry. Aug. 2008;69(8):1246-56. [pmid: 18681756].
89 Girardi P, Pompili M, Innamorati M, et al. Duloxetine in acute major depression: review of comparisons to placebo and standard antidepressants using dissimilar methods. Hum Psychopharmacol. 2009;24(3):177-90. [pmid: 19229839].
90 Goethe JW, Woolley SB, Cardoni AA, et al. Selective serotonin reuptake inhibitor discontinuation: side effects and other factors that influence medication adherence. J Clin Psychopharmacol. Oct. 2007;27(5):451-8. [pmid: 17873676].
91 Granger AL, Fehnel SE, Hogue SL, et al. An assessment of patient preference and adherence to treatment with Wellbutrin SR: a web-based survey. J Affect Disord. Feb. 2006;90(2-3):217-21. [pmid: 16360216].
92 Gualtieri CT, Johnson LG. Bupropion normalizes cognitive performance in patients with depression. MedGenMed. 2007;9(1):22. [pmid: 17435629].
93 Hansen R, Gaynes B, Thieda P, et al. Meta-analysis of major depressive disorder relapse and recurrence with second-generation antidepressants. Psychiatr Serv. 2008;59(10):1121-30. [pmid: 18832497].
94 Hellerstein DJ, Batchelder S, Kreditor D, et al. Bupropion sustained-release for the treatment of dysthymic disorder: an open-label study. J Clin Psychopharmacol. Jun. 2001;21(3):325-9. [pmid: 11386496].
95 Hellerstein DJ, Batchelder ST, Hyler S, et al. Escitalopram versus placebo in the treatment of dysthymic disorder. Int Clin Psychopharmacol. 2010;25(3):143-8. [pmid: 21811192].
96 Herrera-Guzman I, Herrera-Abarca JE, Gudayol-Ferre E, et al. Effects of selective serotonin reuptake and dual serotonergic-noradrenergic reuptake treatments on attention and executive functions in patients with major depressive disorder. Psychiatry Res. 2010;177(3):323-9. [pmid: 20385412].
97 Himmerich H, Fulda S, Schaaf L, et al. Changes in weight and glucose tolerance during treatment with mirtazapine. Diabetes Care. Jan. 2006;29(1):170. [pmid: 16373922].
98 Hong Ng C, Norman TR, Naing KO, et al. A comparative study of sertraline dosages, plasma concentrations, efficacy and adverse reactions in Chinese versus Caucasian patients. Int Clin Psychopharmacol. Mar. 2006;21(2):87-92. [pmid: 16421459].
99 Hunter AM, Muthén BO, Cook IA, et al. Antidepressant response trajectories and quantitative electroencephalography (QEEG) biomarkers in major depressive disorder. J Psychiatr Res. 2010;(2):90-8. [pmid: 19631948].
100 Husain MM, Rush AJ, Trivedi MH, et al. Pain in depression: STAR*D study findings. J Psychosom Res. Aug. 2007;63(2):113-22. [pmid: 17662746].
101 Jacob S, Spinler SA. Hyponatremia associated with selective serotonin-reuptake inhibitors in older adults. Ann Pharmacother. Sep. 2006;40(9):1618-22. [pmid: 16896026].
102 Jakob F, Wolf J. EPMS under antidepressive therapy with fluvoxamine and concomitant antibiotic therapy with clindamycin. Pharmacopsychiatry. May. 2007;40(3):129. [pmid: 17541891].
103 Kang EH, Lee IS, Chung SK, et al. Mirtazapine versus venlafaxine for the treatment of somatic symptoms associated with major depressive disorder: a randomized, open-labeled trial. Psychiatry Res. 2009;169(2):118-23. [pmid: 19695711].
104 Kasper S, Lemming OM, de Swart H. Escitalopram in the long-term treatment of major depressive disorder in elderly patients. Neuropsychobiology. 2006;54(3):152-9. [pmid: 17230032].
105 Kelin K, Berk M, Spann M, et al. Duloxetine 60 mg/day for the prevention of depressive recurrences: Post hoc analyses from a recurrence prevention study. Int J Clin Pract. 2010;64(6):719-26. [pmid: 20345508].
106 Kelly CM, Juurlink DN, Gomes T, et al. Selective serotonin reuptake inhibitors and breast cancer mortality in women receiving tamoxifen: a population based cohort study. BMJ. 2010;340:c693. [pmid: 20142325].
107 Kennedy SH, Andersen HF, Lam RW. Efficacy of escitalopram in the treatment of major depressive disorder compared with conventional selective serotonin reuptake inhibitors and venlafaxine XR: a meta-analysis. J Psychiatry Neurosci. 2006;31(2):122-31. [pmid: 16575428].
108 Khan A, Schwartz KA, Kolts RL, et al. BMI, sex, and antidepressant response. J Affect Disord. 2007;99(1-3):101-6. [pmid: 17010444].
109 Khandker RK, Kruzikas DT, McLaughlin TP. Pharmacy and medical costs associated with switching between venlafaxine and SSRI antidepressant therapy for the treatment of major depressive disorder. J Manag Care Pharm. Jun. 2008;14(5):426-41. [pmid: 18597572].
110 Kito S, Koga Y. Visual hallucinations and amnesia associated with zolpidem triggered by fluvoxamine: a possible interaction. Int Psychogeriatr. Dec. 2006;18(4):749-51. [pmid: 17026779].
111 Kluge M, Schussler P, Steiger A. Duloxetine increases stage 3 sleep and suppresses rapid eye movement (REM) sleep in patients with major depression. Eur Neuropsychopharmacol. Jul. 2007;17(8):527-31. [pmid: 17337164].
112 Kocsis JH, Leon AC, Markowitz JC, et al. Patient preference as a moderator of outcome for chronic forms of major depressive disorder treated with nefazodone, cognitive behavioral analysis system of psychotherapy, or their combination. J Clin Psychiatry. Mar. 2009;70(3):354-61. [pmid: 19192474].
113 Koga M, Kodaka F, Miyata H, et al. Symptoms of delusion: the effects of discontinuation of low-dose venlafaxine. Acta Psychiatr Scand. Oct. 2009;120(4):329-31. [pmid: 19573048].
114 Kok RM, Nolen WA, Heeren TJ. Outcome of late-life depression after 3 years of sequential treatment. Acta Psychiatr Scand. Apr. 2009;119(4):274-81. [pmid: 19053970].
115 Kornstein SG, Clayton AH, Soares CN, et al. Analysis by age and sex of efficacy data from placebo-controlled trials of desvenlafaxine in outpatients with major depressive disorder. J Clin Psychopharmacol. 2010;30(3):294-9. [pmid: 20473066].
116 Kornstein SG, Dunner DL, Meyers AL, et al. A randomized, double-blind study of increasing or maintaining duloxetine dose in patients without remission of major depressive disorder after initial duloxetine therapy. J Clin Psychiatry. Sep. 2008;69(9):1383-92. [pmid: 19193339].
117 Kornstein SG, Li D, Mao Y, et al. Escitalopram versus SNRI antidepressants in the acute treatment of major depressive disorder: Integrative analysis of four double-blind, randomized clinical trials. CNS Spectrums. 2009;14(6):326-33. [pmid: 19668123].
118 Kornstein SG, Wohlreich MM, Mallinckrodt CH, et al. Duloxetine efficacy for major depressive disorder in male vs. female patients: data from 7 randomized, double-blind, placebo-controlled trials. J Clin Psychiatry. 2006;67(5):761-70. [pmid: 16841626].
119 Kozel FA, Trivedi MH, Wisniewski SR, et al. Treatment outcomes for older depressed patients with earlier versus late onset of first depressive episode: a Sequenced Treatment Alternatives to Relieve Depression (STAR*D) report. Am J Geriatr Psychiatry. Jan. 2008;16(1):58-64. [pmid: 18165462].
120 Kroenke K, Messina N 3rd, Benattia I, et al. Venlafaxine extended release in the short-term treatment of depressed and anxious primary care patients with multisomatoform disorder. J Clin Psychiatry. 2006;67(1):72-80. [pmid: 16426091].
121 Kulisevsky J, Pagonabarraga J, Pascual-Sedano B, et al. Motor changes during sertraline treatment in depressed patients with Parkinson's disease*. Eur J Neurol. Sep. 2008;15(9):953-9. [pmid: 18637826].
122 Lam RW, Andersen HF. The influence of baseline severity on efficacy of escitalopram and citalopram in the treatment of major depressive disorder: an extended analysis. Pharmacopsychiatry. Sep. 2006;39(5):180-4. [pmid: 16944409].
123 Lam RW, Lonn SL, Despiegel N. Escitalopram versus serotonin noradrenaline reuptake inhibitors as second step treatment for patients with major depressive disorder: A pooled analysis. Int Clin Psychopharmacol. 2010;25(4):199-203. [pmid: 20357664].
124 Lesser I, Rosales A, Zisook S, et al. Depression outcomes of Spanish- and english-speaking Hispanic outpatients in STAR*D. Psychiatr Serv. 2008;59(11):1273-84. [pmid: 18971403].
125 Lesser IM, Castro DB, Gaynes BN, et al. Ethnicity/race and outcome in the treatment of depression: results from STAR*D. Med Care. 2007;45(11):1043-51. [pmid: 18049344].
126 Lesser IM, Myers HF, Lin KM, et al. Ethnic differences in antidepressant response: a prospective multi-site clinical trial. Depress Anxiety. 2010;27(1):56-62. [pmid: 19960492].
127 Leuchter AF, Husain MM, Cook IA, et al. Painful physical symptoms and treatment outcome in major depressive disorder: A STAR*D (Sequenced Treatment Alternatives to Relieve Depression) report. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2010;40(2):239-51.
128 Leuchter AF, Lesser IM, Trivedi MH, et al. An open pilot study of the combination of escitalopram and bupropion-SR for outpatients with major depressive disorder. J Psychiatr Pract. Sep. 2008;14(5):271-80. [pmid: 18832958].
129 Lewis-Fernández R, Blanco C, Mallinckrodt CH, et al. Duloxetine in the treatment of major depressive disorder: Comparisons of safety and efficacy in US Hispanic and majority Caucasian patients. Journal of Clinical Psychiatry. 2006;67(9):1379-90. [pmid: 17017824].
130 Liberek C, Aubry JM, Baud P. Manic switch and serotonin syndrome with venlafaxine-lithium-valproate association. Therapie. Nov-Dec. 2006;61(6):531-3. [pmid: 17348610].
131 Lieberman DZ, Montgomery SA, Tourian KA, et al. A pooled analysis of two placebo-controlled trials of desvenlafaxine in major depressive disorder. Int Clin Psychopharmacol. Jul. 2008;23(4):188-97. [pmid: 18545056].
132 Liu KS, Snavely DB, Ball WA, et al. Is bigger better for depression trials?. J Psychiatr Res. Jul. 2008;42(8):622-30. [pmid: 17825841].
133 Lustman PJ, Williams MM, Sayuk GS, et al. Factors influencing glycemic control in type 2 diabetes during acute- and maintenance-phase treatment of major depressive disorder with bupropion. Diabetes Care. Mar. 2007;30(3):459-66. [pmid: 17327305].
134 IJ MA, Huijbregts KML, Van Marwijk HWJ, et al. Cost-effectiveness of collaborative care including PST and an antidepressant treatment algorithm for the treatment of major depressive disorder in primary care; A randomised clinical trial. BMC Health Services Research. 2007;7(34).
135 Mallinckrodt CH, Prakash A, Andorn AC, et al. Duloxetine for the treatment of major depressive disorder: a closer look at efficacy and safety data across the approved dose range. J Psychiatr Res. 2006;40(4):337-48. [pmid: 16271726].
136 Mallinckrodt CH, Prakash A, Houston JP, et al. Differential antidepressant symptom efficacy: placebo-controlled comparisons of duloxetine and SSRIs (fluoxetine, paroxetine, escitalopram). Neuropsychobiology. 2007;56(2-3):73-85. [pmid: 18037817].
137 Malvini L, Cipriani A, Furukawa TA, et al. Sertraline versus other antidepressive agents for depression. (Protocol). Cochrane Database of Systematic Reviews. 2006;(3).
138 Marangell LB, Clauw DJ, Choy E, et al. Comparative pain and mood effects in patients with comorbid fibromyalgia and major depressive disorder: Secondary analyses of four pooled randomized controlled trials of duloxetine. Pain. 2011;152(1):31-7. [pmid: 20598442].
139 McGrath PJ, Khan AY, Trivedi MH, et al. Response to a selective serotonin reuptake inhibitor (citalopram) in major depressive disorder with melancholic features: a STAR*D report. J Clin Psychiatry. Dec. 2008;69(12):1847-55. [pmid: 19026268].
140 McGrath PJ, Stewart JW, Fava M, et al. Tranylcypromine versus venlafaxine plus mirtazapine following three failed antidepressant medication trials for depression: a STAR*D report. Am J Psychiatry. 2006;163(9):1531-41. quiz 666. [pmid: 16946177].
141 McIntyre A, Gendron A, McIntyre A. Quetiapine adjunct to selective serotonin reuptake inhibitors or venlafaxine in patients with major depression, comorbid anxiety, and residual depressive symptoms: a randomized, placebo-controlled pilot study. Depress Anxiety. 2007;24(7):487-94. [pmid: 17177199].
142 Melartin TK, Rytsälä HJ, Leskelä US, et al. Continuity is the main challenge in treating major depressive disorder in psychiatric care. J Clin Psychiatry. 2005;66(2):220-7. [pmid: 15705008].
143 Menza M, DeFonzo Dobkin R, Marin H, et al. The impact of treatment of depression on quality of life, disability and relapse in patients with Parkinson's disease. Movement Disorders. 2009;24(9):1325-32. [pmid: 19412944].
144 Menza M, Dobkin RD, Marin H, et al. A controlled trial of antidepressants in patients with Parkinson disease and depression. Neurology. 2009;72(10):886-92. [pmid: 19092112].
145 Mohamed S, Osatuke K, Aslam M, et al. Escitalopram for comorbid depression and anxiety in elderly patients: A 12-week, open-label, flexible-dose, pilot trial. Am J Geriatr Pharmacother. Sep. 2006;4(3):201-9. [pmid: 17062320].
146 Moreno RA, Teng CT, Almeida KM, et al. Hypericum perforatum versus fluoxetine in the treatment of mild to moderate depression: a randomized double-blind trial in a Brazilian sample. Rev Bras Psiquiatr. 2006;28(1):29-32. [pmid: 16612487].
147 Mukai Y, Tampi RR. Treatment of depression in the elderly: A review of the recent literature on the efficacy of single- versus dual-action antidepressants. Clinical Therapeutics. 2009;31(5):945-61. [pmid: 19539096].
148 Mulder RT, Frampton CM, Luty SE, et al. Eighteen months of drug treatment for depression: predicting relapse and recovery. J Affect Disord. Apr. 2009;114(1-3):263-70. [pmid: 18805590].
149 Mulsant BH. Onset of confusion in the context of late-life depression. J Psychiatry Neurosci. Mar. 2007;32(2):152. [pmid: 17353943].
150 Nelson JC. Anxiety does not predict response to duloxetine in major depression: results of a pooled analysis of individual patient data from 11 placebo-controlled trials. Depress Anxiety. 2010;27(1):12-8. [pmid: 20013987].
151 Nelson JC, Delucchi K, Schneider L. Suicidal thinking and behavior during treatment with sertraline in late-life depression. Am J Geriatr Psychiatry. 2007;15(7):573-80. [pmid: 17586782].
152 Nelson JC, Delucchi K, Schneider LS. Efficacy of second generation antidepressants in late-life depression: a meta-analysis of the evidence. Am J Geriatr Psychiatry. 2008;16(7):558-67. [pmid: 18591576].
153 Ng J, Sansone RA, McDonald S. Akathisia and abnormal movements of the upper extremities with venlafaxine and methimazole. Gen Hosp Psychiatry. 2009;31(4):388-90. [pmid: 19555803].
154 Nierenberg AA, Fava M, Trivedi MH, et al. A comparison of lithium and T3 augmentation following two failed medication treatments for depression: A STAR*D report. American Journal of Psychiatry. 2006;163(9):1519-30. [pmid: 16946176].
155 Nierenberg AA, Husain MM, Trivedi MH, et al. Residual symptoms after remission of major depressive disorder with citalopram and risk of relapse: a STAR*D report. Psychol Med. Jan. 2010;40(1):41-50. [pmid: 19460188].
156 Olie JP, Tonnoir B, Menard F, et al. A prospective study of escitalopram in the treatment of major depressive episodes in the presence or absence of anxiety. Depress Anxiety. 2007;24(5):318-24. [pmid: 17041922].
157 Olver JS, Burrows GD, Norman TR. The treatment of depression with different formulations of venlafaxine: a comparative analysis. Hum Psychopharmacol. Jan. 2004;19(1):9-16. [pmid: 14716706].
158 Omori Ichiro M, Watanabe N, Nakagawa A, et al. Fluvoxamine versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2010;(3).
159 Omori IM, Watanabe N, Nakagawa A, et al. Efficacy, tolerability and side-effect profile of fluvoxamine for major depression: Meta-analysis. Journal of Psychopharmacology. 2009;23(5):539-50. [pmid: 18562407].
160 Ott GE, Rao U, Lin KM, et al. Effect of treatment with bupropion on EEG sleep: relationship to antidepressant response. Int J Neuropsychopharmacol. Sep. 2004;7(3):275-81. [pmid: 15122973].
161 Papakostas GI, Homberger CH, Fava M. A meta-analysis of clinical trials comparing mirtazapine with selective serotonin reuptake inhibitors for the treatment of major depressive disorder. J Psychopharmacol. 2008;22(8):843-8. [pmid: 18308801].
162 Papakostas GI, McGrath P, Stewart J, et al. Psychic and somatic anxiety symptoms as predictors of response to fluoxetine in major depressive disorder. Psychiatry Res. Oct. 30. 2008;161(1):116-20. [pmid: 18755514].
163 Papakostas GI, Nutt DJ, Hallett LA, et al. Resolution of sleepiness and fatigue in major depressive disorder: A comparison of bupropion and the selective serotonin reuptake inhibitors. Biol Psychiatry. 2006;60(12):1350-5. [pmid: 16934768].
164 Parry BL. Perimenopausal depression. Am J Psychiatry. Jan. 2008;165(1):23-7. [pmid: 18178752].
165 Perahia DG, Kajdasz DK, Royer MG, et al. Duloxetine in the treatment of major depressive disorder: an assessment of the relationship between outcomes and episode characteristics. Int Clin Psychopharmacol. 2006;21(5):285-95. [pmid: 16877900].
166 Perahia DG, Kajdasz DK, Walker DJ, et al. Duloxetine 60 mg once daily in the treatment of milder major depressive disorder. Int J Clin Pract. 2006;60(5):613-20. [pmid: 16700869].
167 Perahia DG, Pritchett YL, Kajdasz DK, et al. A randomized, double-blind comparison of duloxetine and venlafaxine in the treatment of patients with major depressive disorder. J Psychiatr Res. 2008;42(1):22-34. [pmid: 17445831].
168 Perahia DG, Quail D, Desaiah D, et al. Switching to duloxetine from selective serotonin reuptake inhibitor antidepressants: a multicenter trial comparing 2 switching techniques. J Clin Psychiatry. Jan. 2008;69(1):95-105. [pmid: 18312043].
169 Perahia DG, Quail D, Desaiah D, et al. Switching to duloxetine in selective serotonin reuptake inhibitor non- and partial-responders: effects on painful physical symptoms of depression. J Psychiatr Res. Feb. 2009;43(5):512-8. [pmid: 18707693].
170 Perlis RH, Beasley CM Jr, Wines JD Jr, et al. Treatment-associated suicidal ideation and adverse effects in an open, multicenter trial of fluoxetine for major depressive episodes. Psychother Psychosom. 2007;76(1):40-6. [pmid: 17170562].
171 Pinto C, Trivedi JK, Vankar GK, et al. An open-label multicentric study of the tolerability and response to escitalopram treatment in Indian patients with major depressive disorder. J Indian Med Assoc. Jul. 2007;105(7):364. 6. 8 passim. [pmid: 18178988].
172 Plesnicar BK. Efficacy and tolerability of venlafaxine extended release in patients with major depressive disorder. Psychiatr Danub. Sep. 2010;22(3):413-7. [pmid: 20856184].
173 Pompili M, Baldessarini RJ, Tondo L, et al. Response to intravenous antidepressant treatment by suicidal vs. nonsuicidal depressed patients. J Affect Disord. Apr. 2010;122(1-2):154-8. [pmid: 19709752].
174 Preskorn SH, Baker B, Kolluri S, et al. An innovative design to establish proof of concept of the antidepressant effects of the NR2B subunit selective N-methyl-D-aspartate antagonist, CP-101,606, in patients with treatment-refractory major depressive disorder. J Clin Psychopharmacol. Dec. 2008;28(6):631-7. [pmid: 19011431].
175 Rajji TK, Mulsant BH, Lotrich FE, et al. Use of antidepressants in late-life depression. Drugs Aging. 2008;25(10):841-53. [pmid: 18808208].
176 Rapoport MJ, Mitchell RA, McCullagh S, et al. A randomized controlled trial of antidepressant continuation for major depression following traumatic brain injury. J Clin Psychiatry. 2010;71(9):1125-30. [pmid: 20441723].
177 Ravindran LN, Eisfeld BS, Kennedy SH. Combining mirtazapine and duloxetine in treatment-resistant depression improves outcomes and sexual function. Journal of Clinical Psychopharmacology (USA). 01. 01. 2008;28(Jan):107-8.
178 Rottach KG, Schaner BM, Kirch MH, et al. Restless legs syndrome as side effect of second generation antidepressants. J Psychiatr Res. Nov. 2008;43(1):70-5. [pmid: 18468624].
179 Royall DR, Cordes JA, Roman G, et al. Sertraline improves executive function in patients with vascular cognitive impairment. J Neuropsychiatry Clin Neurosci. 2009;21(4):445-54. [pmid: 19996254].
180 Rudolph RL. Achieving remission from depression with venlafaxine and venlafaxine extended release: a literature review of comparative studies with selective serotonin reuptake inhibitors. Acta Psychiatr Scand Suppl. 2002;(415):24-30. [pmid: 12492770].
181 Ruhe HG, Booij J, v Weert HC, et al. Evidence why paroxetine dose escalation is not effective in major depressive disorder: a randomized controlled trial with assessment of serotonin transporter occupancy. Neuropsychopharmacology. Mar. 2009;34(4):999-1010. [pmid: 18830236].
182 Rush AJ. Limitations in efficacy of antidepressant monotherapy. J Clin Psychiatry. Suppl 10. 2007;68:8-10. [pmid: 17900203].
183 Rush AJ, Wisniewski SR, Warden D, et al. Selecting among second-step antidepressant medication monotherapies: predictive value of clinical, demographic, or first-step treatment features. Arch Gen Psychiatry. 2008;65(8):870-80. [pmid: 18678792].
184 Rutherford B, Sneed J, Devanand D, et al. Antidepressant study design affects patient expectancy: a pilot study. Psychol Med. May. 2010;40(5):781-8. [pmid: 19732481].
185 Sawada N, Uchida H, Suzuki T, et al. Persistence and compliance to antidepressant treatment in patients with depression: a chart review. BMC Psychiatry. 2009;9:38. [pmid: 19531229].
186 Schmitt L, Tonnoir B, Arbus C. Safety and efficacy of oral escitalopram as continuation treatment of intravenous citalopram in patients with major depressive disorder. Neuropsychobiology. 2006;54(4):201-7. [pmid: 17337913].
187 Schule C, Baghai TC, Eser D, et al. Lithium but not carbamazepine augments antidepressant efficacy of mirtazapine in unipolar depression: an open-label study. World J Biol Psychiatry. 2009;10(4 Pt 2):390-9. [pmid: 18609420].
188 Seo HJ, Jung YE, Woo YS, et al. Effect of augmented atypical antipsychotics on weight change in patients with major depressive disorder in a naturalistic setting. Hum Psychopharmacol. Mar. 2009;24(2):135-43. [pmid: 19156709].
189 Sheffrin M, Driscoll HC, Lenze EJ, et al. Pilot study of augmentation with aripiprazole for incomplete response in late-life depression: getting to remission. J Clin Psychiatry. Feb. 2009;70(2):208-13. [pmid: 19210951].
190 Sheline YI, Pieper CF, Barch DM, et al. Support for the vascular depression hypothesis in late-life depression: results of a 2-site, prospective, antidepressant treatment trial. Arch Gen Psychiatry. Mar. 2010;67(3):277-85. [pmid: 20194828].
191 Shelton RC, Andorn AC, Mallinckrodt CH, et al. Evidence for the efficacy of duloxetine in treating mild, moderate, and severe depression. Int Clin Psychopharmacol. Nov. 2007;22(6):348-55. [pmid: 17917553].
192 Shelton RC, Prakash A, Mallinckrodt CH, et al. Patterns of depressive symptom response in duloxetine-treated outpatients with mild, moderate or more severe depression. Int J Clin Pract. Aug. 2007;61(8):1337-48. [pmid: 17627710].
193 Shen J, Moller HJ, Wang X, et al. Mirtazapine, a sedating antidepressant, and improved driving safety in patients with major depressive disorder: a prospective, randomized trial of 28 patients. J Clin Psychiatry. Mar. 2009;70(3):370-7. [pmid: 19192466].
194 Sicras-Mainar A, Navarro-Artieda R, Blanca-Tamayo M, et al. Comparison of escitalopram vs. citalopram and venlafaxine in the treatment of major depression in Spain: Clinical and economic consequences. Curr Med Res Opin. 2010;26(12):2757-64. [pmid: 21034375].
195 Solomon DA, Leon AC, Mueller TI, et al. Tachyphylaxis in unipolar major depressive disorder. J Clin Psychiatry. 2005;66(3):283-90. [pmid: 15766292].
196 Sopko MA Jr, Ehret MJ, Grgas M. Desvenlafaxine: another “me too” drug?. Ann Pharmacother. Oct. 2008;42(10):1439-46. [pmid: 18698015].
197 Spalletta G, Ripa A, Bria P, et al. Response of emotional unawareness after stroke to antidepressant treatment. Am J Geriatr Psychiatry. Mar. 2006;14(3):220-7. [pmid: 16505126].
198 Stewart DE, Wohlreich MM, Mallinckrodt CH, et al. Duloxetine in the treatment of major depressive disorder: comparisons of safety and tolerability in male and female patients. J Affect Disord. 2006;94(1-3):183-9. [pmid: 16780958].
199 Strombom I, Wernicke JF, Seeger J, et al. Hepatic effects of duloxetine-III: analysis of hepatic events using external data sources. Curr Drug Saf. May. 2008;3(2):154-62. [pmid: 18690993].
200 Taylor WD, Kuchibhatla M, Payne ME, et al. Frontal white matter anisotropy and antidepressant remission in late-life depression. PLoS One. 2008;3(9):e3267. [pmid: 18813343].
201 Tew JD Jr, Mulsant BH, Houck PR, et al. Impact of prior treatment exposure on response to antidepressant treatment in late life. Am J Geriatr Psychiatry. Nov. 2006;14(11):957-65. [pmid: 17068318].
202 Thase ME, Kornstein SG, Germain JM, et al. An integrated analysis of the efficacy of desvenlafaxine compared with placebo in patients with major depressive disorder. CNS Spectr. 2009;14(3):144-54. [pmid: 19407711].
203 Thase ME, Nierenberg AA, Vrijland P, et al. Remission with mirtazapine and selective serotonin reuptake inhibitors: A meta-analysis of individual patient data from 15 controlled trials of acute phase treatment of major depression. Int Clin Psychopharmacol. 2010;25(4):189-98. [pmid: 20531012].
204 Thase ME, Shelton RC, Khan A. Treatment with venlafaxine extended release after SSRI nonresponse or intolerance: a randomized comparison of standard- and higher-dosing strategies. J Clin Psychopharmacol. Jun. 2006;26(3):250-8. [pmid: 16702889].
205 Tollefson GD, Holman SL. Analysis of the Hamilton Depression Rating Scale factors from a double-blind, placebo-controlled trial of fluoxetine in geriatric major depression. Int Clin Psychopharmacol. Winter. 1993;8(4):253-9. [pmid: 8277144].
206 Tourian KA, Jiang Q, Ninan PT. Analysis of the effect of desvenlafaxine on anxiety symptoms associated with major depressive disorder: pooled data from 9 short-term, double-blind, placebo-controlled trials. CNS Spectr. Mar. 2010;15(3):187-93. [pmid: 20414167].
207 Tourian KA, Padmanabhan K, Groark J, et al. Retrospective analysis of suicidality in patients treated with the antidepressant desvenlafaxine. J Clin Psychopharmacol. Aug. 2010;30(4):411-6. [pmid: 20631558].
208 Trivedi MH, Corey-Lisle PK, Guo Z, et al. Remission, response without remission, and nonresponse in major depressive disorder: impact on functioning. Int Clin Psychopharmacol. May. 2009;24(3):133-8. [pmid: 19318972].
209 Trivedi MH, Wan GJ, Mallick R, et al. Cost and effectiveness of venlafaxine extended-release and selective serotonin reuptake inhibitors in the acute phase of outpatient treatment for major depressive disorder. J Clin Psychopharmacol. Oct. 2004;24(5):497-506. [pmid: 15349005].
210 Vazquez MJ, Carretero Quevedo B. Pneumonitis related to venlafaxine. Psychosomatics. Jan-Feb. 2008;49(1):84-5. [pmid: 18212183].
211 Wade A, Despiegel N, Heldbo Reines E. Escitalopram in the long-term treatment of major depressive disorder. Ann Clin Psychiatry. Apr-Jun. 2006;18(2):83-9. [pmid: 16754413].
212 Wade AG, Toumi I, Hemels MEH. A Pharmacoeconomic Evaluation of Escitalopram Versus Citalopram in the Treatment of Severe Depression in the United Kingdom. Clinical Therapeutics: The International Peer-Reviewed Journal of Drug Therapy. Apr. 2005. 2005;27(4):486-96.
213 Wålinder J, Prochazka J, Odén A, et al. Mirtazapine naturalistic depression study (in Sweden)--MINDS(S): Clinical efficacy and safety. Human Psychopharmacology: Clinical and Experimental. Apr. 2006. 2006;21(3):151-8. [pmid: 16444795].
214 Watanabe N, Omori IM, Nakagawa A, et al. Mirtazapine versus other antidepressants in the acute-phase treatment of adults with major depression: Systematic review and meta-analysis. Journal of Clinical Psychiatry. 2008;69(9):1404-15. [pmid: 19193341].
215 Watanabe N, Omori IM, Nakagawa A, et al. Safety reporting and adverse-event profile of mirtazapine described in randomized controlled trials in comparison with other classes of antidepressants in the acute-phase treatment of adults with depression: systematic review and meta-analysis. CNS Drugs. 2010;24(1):35-53. [pmid: 20030418].
216 Weinmann S, Becker T, Koesters M. Re-evaluation of the efficacy and tolerability of venlafaxine vs SSRI: meta-analysis (Structured abstract). Psychopharmacology. 2008;(4):511-20. [pmid: 17955213].
217 Weintraub D, Taraborelli D, Morales KH, et al. Escitalopram for major depression in Parkinson's disease: an open-label, flexible-dosage study. J Neuropsychiatry Clin Neurosci. Summer. 2006;18(3):377-83. [pmid: 16963587].
218 Wohlreich MM, Mallinckrodt CH, Prakash A, et al. Duloxetine for the treatment of major depressive disorder: safety and tolerability associated with dose escalation. Depress Anxiety. 2007;24(1):41-52. [pmid: 16845641].
219 Wohlreich MM, Mallinckrodt CH, Watkin JG, et al. Immediate switching of antidepressant therapy: results from a clinical trial of duloxetine. Ann Clin Psychiatry. Oct-Dec. 2005;17(4):259-68. [pmid: 16402760].
220 Wohlreich MM, Martinez JM, Mallinckrodt CH, et al. An open-label study of duloxetine for the treatment of major depressive disorder: comparison of switching versus initiating treatment approaches. J Clin Psychopharmacol. Dec. 2005;25(6):552-60. [pmid: 16282837].
221 Wu E, Greenberg P, Yang E, et al. Comparison of treatment persistence, hospital utilization and costs among major depressive disorder geriatric patients treated with escitalopram versus other SSRI/SNRI antidepressants. Curr Med Res Opin. Oct. 2008;24(10):2805-13. [pmid: 18755054].
222 Wu E, Greenberg PE, Yang E, et al. Comparison of escitalopram versus citalopram for the treatment of major depressive disorder in a geriatric population. Curr Med Res Opin. Sep. 2008;24(9):2587-95. [pmid: 18674407].
223 Wu YS, Chen YC, Lu RB. Venlafaxine vs. paroxetine in the acute phase of treatment for major depressive disorder among Han Chinese population in Taiwan. J Clin Pharm Ther. Aug. 2007;32(4):353-63. [pmid: 17635337].
224 Yang LP, Plosker GL. Desvenlafaxine extended release. CNS Drugs. 2008;22(12):1061-9. [pmid: 18998743].
225 Yasui-Furukori N, Kaneko S. Digitalis intoxication induced by paroxetine coadministration. Lancet. Mar. 4. 2006;367(9512):788. [pmid: 16517279].
226 Young EA, Kornstein SG, Marcus SM, et al. Sex differences in response to citalopram: a STAR*D report. J Psychiatr Res. 2009;43(5):503-11. [pmid: 18752809].
227 Blumenfield M, Levy NB, Spinowitz B, et al. Fluoxetine in depressed patients on dialysis. Int J Psychiatry Med. 1997;27(1):71-80. [pmid: 9565715].
228 Bremner JD, Smith WT. Org 3770 VS amitriptyline in the continuation treatment of depression: A placebo controlled trial. European Journal of Psychiatry. 1996;10(1):5-15.
229 Brown WA, Harrison W. Are patients who are intolerant to one serotonin selective reuptake inhibitor intolerant to another?. J Clin Psychiatry. Jan. 1995;56(1):30-4. [pmid: 7836337].
230 Brown WA, Harrison W. Are patients who are intolerant to one SSRI intolerant to another?. Psychopharmacol Bull. 1992;28(3):253-6. [pmid: 1480728].
231 Burrows AB, Salzman C, Satlin A, et al. A randomized, placebo-controlled trial of paroxetine in nursing home residents with non-major depression. Depress Anxiety. 2002;15(3):102-10. [pmid: 12001178].
232 Burt VK, Wohlreich MM, Mallinckrodt CH, et al. Duloxetine for the treatment of major depressive disorder in women ages 40 to 55 years. Psychosomatics. Jul-Aug. 2005;46(4):345-54. [pmid: 16000678].
233 Caley CF, Weber SS. Paroxetine: a selective serotonin reuptake inhibiting antidepressant. Ann Pharmacother. Oct. 1993;27(10):1212-22. [pmid: 8251692].
234 Carpenter LL, Jocic Z, Hall JM, et al. Mirtazapine augmentation in the treatment of refractory depression. J Clin Psychiatry. Jan. 1999;60(1):45-9. [pmid: 10074878].
235 Cassano P, Soares CN, Cusin C, et al. Antidepressant response and well-being in pre-, peri- and postmenopausal women with major depressive disorder treated with fluoxetine. Psychother Psychosom. 2005;74(6):362-5. [pmid: 16244512].
236 Catalano MC, Catalano G, Kanfer SN, et al. The effect of sertraline on routine blood chemistry values. Clin Neuropharmacol. Sep-Oct. 2000;23(5):267-70. [pmid: 11154094].
237 Cervera-Enguix S, Baca-Baldomero E, Garcia-Calvo C, et al. Depression in primary care: effectiveness of venlafaxine extended-release in elderly patients; Observational study. Arch Gerontol Geriatr. May-Jun. 2004;38(3):271-80. [pmid: 15066313].
238 Clayton AH, Warnock JK, Kornstein SG, et al. A placebo-controlled trial of bupropion SR as an antidote for selective serotonin reuptake inhibitor-induced sexual dysfunction. J Clin Psychiatry. Jan. 2004;65(1):62-7. [pmid: 14744170].
239 Coogan PF, Palmer JR, Strom BL, et al. Use of selective serotonin reuptake inhibitors and the risk of breast cancer. Am J Epidemiol. 2005;162(9):835-8. [pmid: 16177141].
240 Cornelius JR, Salloum IM, Cornelius MD, et al. Fluoxetine trial in suicidal depressed alcoholics. Psychopharmacol Bull. 1993;29(2):195-9. [pmid: 8290665].
241 Cornelius JR, Salloum IM, Ehler JG, et al. Fluoxetine in depressed alcoholics. A double-blind, placebo-controlled trial. Arch Gen Psychiatry. Aug. 1997;54(8):700-5. [pmid: 9283504].
242 Cornelius JR, Salloum IM, Haskett RF, et al. Fluoxetine versus placebo in depressed alcoholics: a 1-year follow-up study. Addict Behav. Mar-Apr. 2000;25(2):307-10. [pmid: 10795957].
243 Cornelius JR, Salloum IM, Thase ME, et al. Fluoxetine versus placebo in depressed alcoholic cocaine abusers. Psychopharmacol Bull. 1998;34(1):117-21. [pmid: 9564208].
244 Currier MB, Molina G, Kato M. Citalopram treatment of major depressive disorder in Hispanic HIV and AIDS patients: a prospective study. Psychosomatics. May-Jun. 2004;45(3):210-6. [pmid: 15123845].
245 Davidson JR, Meoni P, Haudiquet V, et al. Achieving remission with venlafaxine and fluoxetine in major depression: its relationship to anxiety symptoms. Depress Anxiety. 2002;16(1):4-13. [pmid: 12203668].
246 de Klerk E. Patient compliance with enteric-coated weekly fluoxetine during continuation treatment of major depressive disorder. J Clin Psychiatry. Suppl 22. 2001;62:43-7. [pmid: 11599648].
247 de Montigny C, Silverstone PH, Debonnel G, et al. Venlafaxine in treatment-resistant major depression: a Canadian multicenter, open-label trial. J Clin Psychopharmacol. Oct. 1999;19(5):401-6. [pmid: 10505581].
248 DeBattista C, Solvason HB, Poirier J, et al. A prospective trial of bupropion SR augmentation of partial and non-responders to serotonergic antidepressants. J Clin Psychopharmacol. Feb. 2003;23(1):27-30. [pmid: 12544372].
249 Devanand DP, Pelton GH, Marston K, et al. Sertraline treatment of elderly patients with depression and cognitive impairment. Int J Geriatr Psychiatry. Feb. 2003;18(2):123-30. [pmid: 12571820].
250 Diaz-Martinez A, Benassinni O, Ontiveros A, et al. A randomized, open-label comparison of venlafaxine and fluoxetine in depressed outpatients. Clin Ther. May-Jun. 1998;20(3):467-76. [pmid: 9663362].
251 Dornseif BE, Dunlop SR, Potvin JH, et al. Effect of dose escalation after low-dose fluoxetine therapy. Psychopharmacol Bull. 1989;25(1):71-9. [pmid: 2672072].
252 Duboff EA. Long-term treatment of major depressive disorder with paroxetine. J Clin Psychopharmacol. Dec. 1993;13(6 Suppl 2):28S-33S. [pmid: 8106653].
253 Dunner DL, Goldstein DJ, Mallinckrodt C, et al. Duloxetine in treatment of anxiety symptoms associated with depression. Depress Anxiety. 2003;18(2):53-61. [pmid: 12964171].
254 Dunner DL, Hendricksen HE, Bea C, et al. Dysthymic disorder: treatment with citalopram. Depress Anxiety. 2002;15(1):18-22. [pmid: 11816048].
255 Dunner DL, Wohlreich MM, Mallinckrodt CH, et al. Clinical consequences of initial duloxetine dosing strategies: comparison of 30 and 60 mg QD starting doses. Current Therapeutic Research. 2005;66(6):522-40.
256 Elliott AJ, Russo J, Bergam K, et al. Antidepressant efficacy in HIV-seropositive outpatients with major depressive disorder: an open trial of nefazodone. J Clin Psychiatry. Apr. 1999;60(4):226-31. [pmid: 10221282].
257 Elliott AJ, Russo J, Roy-Byrne PP. The effect of changes in depression on health related quality of life (HRQoL) in HIV infection. Gen Hosp Psychiatry. Jan-Feb. 2002;24(1):43-7. [pmid: 11814533].
258 Entsuah AR, Huang H, Thase ME. Response and remission rates in different subpopulations with major depressive disorder administered venlafaxine, selective serotonin reuptake inhibitors, or placebo. J Clin Psychiatry. Nov. 2001;62(11):869-77. [pmid: 11775046].
259 Entsuah AR, Rudolph RL, Chitra R. Effectiveness of venlafaxine treatment in a broad spectrum of depressed patients: a meta-analysis. Psychopharmacol Bull. 1995;31(4):759-66. [pmid: 8851650].
260 Fann JR, Uomoto JM, Katon WJ. Sertraline in the treatment of major depression following mild traumatic brain injury. J Neuropsychiatry Clin Neurosci. Spring. 2000;12(2):226-32. [pmid: 11001601].
261 Fava M, Dunner DL, Greist JH, et al. Efficacy and safety of mirtazapine in major depressive disorder patients after SSRI treatment failure: an open-label trial. J Clin Psychiatry. Jun. 2001;62(6):413-20. [pmid: 11465517].
262 Fava M, Mallinckrodt CH, Detke MJ, et al. The effect of duloxetine on painful physical symptoms in depressed patients: do improvements in these symptoms result in higher remission rates?. J Clin Psychiatry. Apr. 2004;65(4):521-30. [pmid: 15119915].
263 Fava M, Papakostas GI, Petersen T, et al. Switching to bupropion in fluoxetine-resistant major depressive disorder. Ann Clin Psychiatry. Mar. 2003;15(1):17-22. [pmid: 12839429].
264 Fava M, Rappe SM, Pava JA, et al. Relapse in patients on long-term fluoxetine treatment: response to increased fluoxetine dose. J Clin Psychiatry. Feb. 1995;56(2):52-5. [pmid: 7852252].
265 Fava M, Schmidt ME, Zhang S, et al. Treatment approaches to major depressive disorder relapse. Part 2: reinitiation of antidepressant treatment. Psychother Psychosom. Jul-Aug. 2002;71(4):195-9. [pmid: 12097784].
266 Fawcett J, Marcus RN, Anton SF, et al. Response of anxiety and agitation symptoms during nefazodone treatment of major depression. J Clin Psychiatry. 1995;56(Suppl):637-42.
267 Feiger AD, Flament MF, Boyer P, et al. Sertraline versus fluoxetine in the treatment of major depression: a combined analysis of five double-blind comparator studies. Int Clin Psychopharmacol. Jul. 2003;18(4):203-10. [pmid: 12817154].
268 Feighner JP, Entsuah AR, McPherson MK. Efficacy of once-daily venlafaxine extended release (XR) for symptoms of anxiety in depressed outpatients. J Affect Disord. Jan. 1998;47(1-3):55-62. [pmid: 9476744].
269 Feldmann HS, Denber HC. Long-term study of fluvoxamine: a new rapid-acting antidepressant. Int Pharmacopsychiatry. 1982;17(2):114-22. [pmid: 6809683].
270 Fontaine R, Ontiveros A, Elie R, et al. Lithium carbonate augmentation of desipramine and fluoxetine in refractory depression. Biol Psychiatry. May. 1. 1991;29(9):946-8. [pmid: 1904782].
271 Franchini L, Rossini D, Bongiorno F, et al. Will a second prophylactic treatment with a higher dosage of the same antidepressant either prevent or delay new depressive episodes?. Psychiatry Res. Sep. 25. 2000;96(1):81-5. [pmid: 10980329].
272 Gelenberg AJ, McGahuey C, Laukes C, et al. Mirtazapine substitution in SSRI-induced sexual dysfunction. J Clin Psychiatry. May. 2000;61(5):356-60. [pmid: 10847310].
273 Giannelli A, Rabboni M, Zarattini F, et al. A combination of hypothalamic phospholipid liposomes with trazodone for treatment of depression. An open controlled study. Acta Psychiatr Scand. Jan. 1989;79(1):52-8. [pmid: 2648767].
274 Goldstein DJ, Lu Y, Detke MJ, et al. Effects of duloxetine on painful physical symptoms associated with depression. Psychosomatics. Jan-Feb. 2004;45(1):17-28. [pmid: 14709757].
275 Greco T, Eckert G, Kroenke K. The outcome of physical symptoms with treatment of depression. J Gen Intern Med. Aug. 2004;19(8):813-8. [pmid: 15242465].
276 Halaris AE, Stern W, Harto-Truax N. Clinical efficacy of the new antidepressant bupropion (Wellbutrin). [proceedings]. Psychopharmacol Bull. Jan. 1981;17(1):140-2. [pmid: 6785817].
277 Harrison CL, Ferrier N, Young AH. Tolerability of high-dose venlafaxine in depressed patients. J Psychopharmacol. Jun. 2004;18(2):200-4. [pmid: 15260908].
278 Harto NE, Spera KF, Branconnier RJ. Fluoxetine-induced reduction of body mass in patients with major depressive disorder. Psychopharmacol Bull. 1988;24(2):220-3. [pmid: 3264922].
279 Hebenstreit GF, Fellerer K, Zochling R, et al. A pharmacokinetic dose titration study in adult and elderly depressed patients. Acta Psychiatr Scand Suppl. 1989;350:81-4. [pmid: 2530795].
280 Heiligenstein JH, Tollefson GD, Faries DE. Response patterns of depressed outpatients with and without melancholia: a double-blind, placebo-controlled trial of fluoxetine versus placebo. J Affect Disord. Mar. 1994;30(3):163-73. [pmid: 8006243].
281 Hellerstein DJ, Yanowitch P, Rosenthal J, et al. Long-term treatment of double depression: a preliminary study with serotonergic antidepressants. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1994;18(1):139-47. [pmid: 8115668].
282 Hellerstein DJ, Yanowitch P, Rosenthal J, et al. A randomized double-blind study of fluoxetine versus placebo in the treatment of dysthymia. Am J Psychiatry. Aug. 1993;150(8):1169-75. [pmid: 8328559].
283 Houck C. An open-label pilot study of fluvoxamine for mixed anxiety-depression. Psychopharmacol Bull. 1998;34(2):225-7. [pmid: 9641005].
284 Hudson JI, Wohlreich MM, Kajdasz DK, et al. Safety and tolerability of duloxetine in the treatment of major depressive disorder: analysis of pooled data from eight placebo-controlled clinical trials. Human Psychopharmacology: Clinical and Experimental. 2005;20(5):327-41. [pmid: 15912562].
285 Huyse FJ, Zwaan WA, Kupka R. The applicability of antidepressants in the depressed medically ill: an open clinical trial with fluoxetine. J Psychosom Res. Oct. 1994;38(7):695-703. [pmid: 7877124].
286 Iosifescu DV, Nierenberg AA, Alpert JE, et al. Comorbid medical illness and relapse of major depressive disorder in the continuation phase of treatment. Psychosomatics. Sep-Oct. 2004;45(5):419-25. [pmid: 15345787].
287 Jacobsen FM. Fluoxetine-induced sexual dysfunction and an open trial of yohimbine. J Clin Psychiatry. Apr. 1992;53(4):119-22. [pmid: 1564046].
288 Jindal RD, Friedman ES, Berman SR, et al. Effects of sertraline on sleep architecture in patients with depression. J Clin Psychopharmacol. Dec. 2003;23(6):540-8. [pmid: 14624183].
289 Joffe RT, Levitt AJ, Sokolov ST, et al. Response to an open trial of a second SSRI in major depression. J Clin Psychiatry. Mar. 1996;57(3):114-5. [pmid: 8617695].
290 Joffe RT, Marshall AM, Lee DK. A large open-label study of venlafaxine in depressed outpatients by community-based physicians. J Clin Psychiatry. Oct. 1998;59(10):515-20. [pmid: 9818632].
291 Joliat MJ, Schmidt ME, Fava M, et al. Long-term treatment outcomes of depression with associated anxiety: efficacy of continuation treatment with fluoxetine. J Clin Psychiatry. 2004;65(3):373-8. [pmid: 15096077].
292 Joo JH, Lenze EJ, Mulsant BH, et al. Risk factors for falls during treatment of late-life depression. J Clin Psychiatry. Oct. 2002;63(10):936-41. [pmid: 12416604].
293 Judge R, Plewes JM, Kumar V, et al. Changes in energy during treatment of depression: an analysis of fluoxetine in double-blind, placebo-controlled trials. J Clin Psychopharmacol. Dec. 2000;20(6):666-72. [pmid: 11106139].
294 Kaynak H, Kaynak D, Gozukirmizi E, et al. The effects of trazodone on sleep in patients treated with stimulant antidepressants. Sleep Med. Jan. 2004;5(1):15-20. [pmid: 14725822].
295 Kirby D, Harrigan S, Ames D. Hyponatraemia in elderly psychiatric patients treated with Selective Serotonin Reuptake Inhibitors and venlafaxine: a retrospective controlled study in an inpatient unit. Int J Geriatr Psychiatry. Mar. 2002;17(3):231-7. [pmid: 11921151].
296 Klieser E, Lehmann E. Experimental comparison between the effect of standardized trazodone-amitriptyline and placebo treatment in vitalized depressive patients. Psychopharmacology (Berl). 1988;95(Suppl):S3-5. [pmid: 3133710].
297 Krishnan KR, Doraiswamy PM, Clary CM. Clinical and treatment response characteristics of late-life depression associated with vascular disease: a pooled analysis of two multicenter trials with sertraline. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 2001;25(2):347-61. [pmid: 11294481].
298 Kroenke K, West SL, Swindle R, et al. Similar effectiveness of paroxetine, fluoxetine, and sertraline in primary care: a randomized trial. Jama. Dec. 19. 2001;286(23):2947-55. [pmid: 11743835].
299 Kuhn KU, Quednow BB, Thiel M, et al. Antidepressive treatment in patients with temporal lobe epilepsy and major depression: a prospective study with three different antidepressants. Epilepsy Behav. Dec. 2003;4(6):674-9. [pmid: 14698701].
300 Lader M, Andersen HF, Baekdal T. The effect of escitalopram on sleep problems in depressed patients. Hum Psychopharmacol. Jul. 2005;20(5):349-54. [pmid: 15912558].
301 Lam RW, Hossie H, Solomons K, et al. Citalopram and bupropion-SR: combining versus switching in patients with treatment-resistant depression. J Clin Psychiatry. Mar. 2004;65(3):337-40. [pmid: 15096072].
302 Landen M, Hogberg P, Thase ME. Incidence of sexual side effects in refractory depression during treatment with citalopram or paroxetine. J Clin Psychiatry. Jan. 2005;66(1):100-6. [pmid: 15669895].
303 Lauritzen L, Odgaard K, Clemmesen L, et al. Relapse prevention by means of paroxetine in ECT-treated patients with major depression: a comparison with imipramine and placebo in medium-term continuation therapy. Acta Psychiatr Scand. Oct. 1996;94(4):241-51. [pmid: 8911559].
304 Lenderking WR, Tennen H, Nackley JF, et al. The effects of venlafaxine on social activity level in depressed outpatients. J Clin Psychiatry. Mar. 1999;60(3):157-63. [pmid: 10192590].
305 Leo RJ. Movement disorders associated with the serotonin selective reuptake inhibitors. J Clin Psychiatry. Oct. 1996;57(10):449-54. [pmid: 8909330].
306 Lepola U, Wade A, Andersen HF. Do equivalent doses of escitalopram and citalopram have similar efficacy? A pooled analysis of two positive placebo-controlled studies in major depressive disorder. Int Clin Psychopharmacol. May. 2004;19(3):149-55. [pmid: 15107657].
307 Lesperance F, Frasure-Smith N, Laliberte MA, et al. An open-label study of nefazodone treatment of major depression in patients with congestive heart failure. Can J Psychiatry. Nov. 2003;48(10):695-701. [pmid: 14674053].
308 Letizia C, Kapik B, Flanders WD. Suicidal risk during controlled clinical investigations of fluvoxamine. J Clin Psychiatry. Sep. 1996;57(9):415-21. [pmid: 9746450].
309 Linden M, Gothe H, Dittmann RW, et al. Early termination of antidepressant drug treatment. J Clin Psychopharmacol. Oct. 2000;20(5):523-30. [pmid: 11001236].
310 Llorca PM, Azorin JM, Despiegel N, et al. Efficacy of escitalopram in patients with severe depression: a pooled analysis. Int J Clin Pract. Mar. 2005;59(3):268-75. [pmid: 15857321].
311 Louie AK, Lewis TB, Lannon RA. Use of low-dose fluoxetine in major depression and panic disorder. J Clin Psychiatry. Nov. 1993;54(11):435-8. [pmid: 8270588].
312 Lowe B, Schenkel I, Bair MJ, et al. Efficacy, predictors of therapy response, and safety of sertraline in routine clinical practice: prospective, open-label, non-interventional postmarketing surveillance study in 1878 patients. J Affect Disord. Aug. 2005;87(2-3):271-9. [pmid: 15979151].
313 Lyketsos CG, Sheppard JM, Steele CD, et al. Randomized, placebo-controlled, double-blind clinical trial of sertraline in the treatment of depression complicating Alzheimer's disease: initial results from the Depression in Alzheimer's Disease study. Am J Psychiatry. Oct. 2000;157(10):1686-9. [pmid: 11007727].
314 Magai C, Kennedy G, Cohen CI, et al. A controlled clinical trial of sertraline in the treatment of depression in nursing home patients with late-stage Alzheimer's disease. Am J Geriatr Psychiatry. Winter. 2000;8(1):66-74. [pmid: 10648297].
315 Mallinckrodt CH, Goldstein DJ, Detke MJ, et al. Duloxetine: A New Treatment for the Emotional and Physical Symptoms of Depression. Prim Care Companion J Clin Psychiatry. Feb. 2003;5(1):19-28. [pmid: 15156243].
316 Mallinckrodt CH, Watkin JG, Liu C, et al. Duloxetine in the treatment of Major Depressive Disorder: a comparison of efficacy in patients with and without melancholic features. BMC Psychiatry. Jan. 4. 2005;5(1):1. [pmid: 15631624].
317 Marcus RN, Mendels J. Nefazodone in the treatment of severe, melancholic, and recurrent depression. J Clin Psychiatry. 1996;57(Suppl):219-23.
318 Mauri MC, Fiorentini A, Cerveri G, et al. Long-term efficacy and therapeutic drug monitoring of sertraline in major depression. Hum Psychopharmacol. Jul. 2003;18(5):385-8. [pmid: 12858326].
319 McGrath PJ, Stewart JW, Petkova E, et al. Predictors of relapse during fluoxetine continuation or maintenance treatment of major depression. J Clin Psychiatry. Jul. 2000;61(7):518-24. [pmid: 10937611].
320 Mendels J, Kiev A, Fabre LF. Double-blind comparison of citalopram and placebo in depressed outpatients with melancholia. Depress Anxiety. 1999;9(2):54-60. [pmid: 10207659].
321 Menting JE, Honig A, Verhey FR, et al. Selective serotonin reuptake inhibitors (SSRIs) in the treatment of elderly depressed patients: a qualitative analysis of the literature on their efficacy and side-effects. Int Clin Psychopharmacol. Sep. 1996;11(3):165-75. [pmid: 8923095].
322 Michelson D, Schmidt M, Lee J, et al. Changes in sexual function during acute and six-month fluoxetine therapy: a prospective assessment. J Sex Marital Ther. May-Jun. 2001;27(3):289-302. [pmid: 11354934].
323 Miller SM, Naylor GJ, Murtagh M, et al. A double-blind comparison of paroxetine and placebo in the treatment of depressed patients in a psychiatric outpatient clinic. Acta Psychiatr Scand Suppl. 1989;350:143-4. [pmid: 2530772].
324 Miner CM, Brown EB, Gonzales JS, et al. Switching patients from daily citalopram, paroxetine, or sertraline to once-weekly fluoxetine in the maintenance of response for depression. J Clin Psychiatry. 2002;63(3):232-40. [pmid: 11926723].
325 Mitchell PB, Schweitzer I, Burrows G, et al. Efficacy of venlafaxine and predictors of response in a prospective open-label study of patients with treatment-resistant major depression. J Clin Psychopharmacol. Aug. 2000;20(4):483-7. [pmid: 10917411].
326 Montgomery SA. Safety of mirtazapine: a review. Int Clin Psychopharmacol. Dec. Suppl 4. 1995;10:37-45. [pmid: 8930008].
327 Montgomery SA, Reimitz PE, Zivkov M. Mirtazapine versus amitriptyline in the long-term treatment of depression: a double-blind placebo-controlled study. Int Clin Psychopharmacol. Mar. 1998;13(2):63-73. [pmid: 9669186].
328 Morishita S, Arita S. Differential effects of milnacipran, fluvoxamine and paroxetine for depression, especially in gender. Eur Psychiatry. Dec. 2003;18(8):418-20. [pmid: 14680720].
329 Morishita S, Arita S. Differential period of onset of action of fluvoxamine, paroxetine and milnacipran for depression. Hum Psychopharmacol. Aug. 2003;18(6):479-82. [pmid: 12923828].
330 Mulrow CD, Williams JW Jr, Trivedi M, et al. Treatment of depression--newer pharmacotherapies. Psychopharmacol Bull. 1998;34(4):409-795. [pmid: 10513454].
331 Nelson EC. An open-label study of nefazodone in the treatment of depression with and without comorbid obsessive compulsive disorder. Ann Clin Psychiatry. Dec. 1994;6(4):249-53. [pmid: 7647834].
332 Nelson JC, Wohlreich MM, Mallinckrodt CH, et al. Duloxetine for the treatment of major depressive disorder in older patients. Am J Geriatr Psychiatry. Mar. 2005;13(3):227-35. [pmid: 15728754].
333 Nemeroff CB, Schatzberg AF, Goldstein DJ, et al. Duloxetine for the treatment of major depressive disorder. Psychopharmacol Bull. Autumn. 2002;36(4):106-32. [pmid: 12858150].
334 Nierenberg AA, Adler LA, Peselow E, et al. Trazodone for antidepressant-associated insomnia. Am J Psychiatry. Jul. 1994;151(7):1069-72. [pmid: 8010365].
335 Nierenberg AA, Cole JO, Glass L. Possible trazodone potentiation of fluoxetine: a case series. J Clin Psychiatry. Mar. 1992;53(3):83-5. [pmid: 1548249].
336 Nierenberg AA, Feighner JP, Rudolph R, et al. Venlafaxine for treatment-resistant unipolar depression. J Clin Psychopharmacol. Dec. 1994;14(6):419-23. [pmid: 7884023].
337 Nierenberg AA, Quitkin FM, Kremer C, et al. Placebo-controlled continuation treatment with mirtazapine: acute pattern of response predicts relapse. Neuropsychopharmacology. May. 2004;29(5):1012-8. [pmid: 14997172].
338 Ninan PT, Hassman HA, Glass SJ, et al. Adjunctive modafinil at initiation of treatment with a selective serotonin reuptake inhibitor enhances the degree and onset of therapeutic effects in patients with major depressive disorder and fatigue. J Clin Psychiatry. 2004;65(3):414-20. [pmid: 15096082].
339 Norton KR, Sireling LI, Bhat AV, et al. A double-blind comparison of fluvoxamine, imipramine and placebo in depressed patients. J Affect Disord. Dec. 1984;7(3-4):297-308. [pmid: 6241211].
340 Orengo CA, Kunik ME, Molinari V, et al. The use and tolerability of fluoxetine in geropsychiatric inpatients. J Clin Psychiatry. Jan. 1996;57(1):12-6. [pmid: 8543541].
341 Ottevanger EA. The efficacy of fluvoxamine in patients with severe depression. Prog Neuropsychopharmacol Biol Psychiatry. Jul. 1994;18(4):731-40. [pmid: 7938563].
342 Oxman TE, Barrett JE, Sengupta A, et al. Status of minor depression or dysthymia in primary care following a randomized controlled treatment. Gen Hosp Psychiatry. Nov-Dec. 2001;23(6):301-10. [pmid: 11738460].
343 Pae CU, Kim YJ, Won WY, et al. Paroxetine in the treatment of depressed patients with haematological malignancy: an open-label study. Hum Psychopharmacol. Jan. 2004;19(1):25-9. [pmid: 14716708].
344 Pande AC, Sayler ME. Severity of depression and response to fluoxetine. Int Clin Psychopharmacol. Winter. 1993;8(4):243-5. [pmid: 8277142].
345 Papakostas GI, Petersen T, Denninger JW, et al. Psychosocial functioning during the treatment of major depressive disorder with fluoxetine. J Clin Psychopharmacol. Oct. 2004;24(5):507-11. [pmid: 15349006].
346 Pitts WM, Fann WE, Halaris AE, et al. Bupropion in depression: a tri-center placebo-controlled study. J Clin Psychiatry. May. 1983;44(5 Pt 2):95-100. [pmid: 6406473].
347 Pope HG Jr, McElroy SL, Nixon RA. Possible synergism between fluoxetine and lithium in refractory depression. Am J Psychiatry. Oct. 1988;145(10):1292-4. [pmid: 3262313].
348 Quitkin FM, McGrath PJ, Stewart JW, et al. Remission rates with 3 consecutive antidepressant trials: effectiveness for depressed outpatients. J Clin Psychiatry. Jun. 2005;66(6):670-6. [pmid: 15960558].
349 Quitkin FM, Stewart JW, McGrath PJ, et al. Are there differences between women's and men's antidepressant responses?. Am J Psychiatry. Nov. 2002;159(11):1848-54. [pmid: 12411218].
350 Ravindran AV, Charbonneau Y, Zaharia MD, et al. Efficacy and tolerability of venlafaxine in the treatment of primary dysthymia. J Psychiatry Neurosci. Nov. 1998;23(5):288-92. [pmid: 9846033].
351 Razavi D, Allilaire JF, Smith M, et al. The effect of fluoxetine on anxiety and depression symptoms in cancer patients. Acta Psychiatr Scand. 1996;94(3):205-10. [pmid: 8891089].
352 Robinson DS, Roberts DL, Smith JM, et al. The safety profile of nefazodone. J Clin Psychiatry. Suppl 2. 1996;57:31-8. [pmid: 8626361].
353 Rocca P, Calvarese P, Faggiano F, et al. Citalopram versus sertraline in late-life nonmajor clinically significant depression: a 1-year follow-up clinical trial. J Clin Psychiatry. Mar. 2005;66(3):360-9. [pmid: 15766303].
354 Roose SP, Nelson JC, Salzman C, et al. Open-label study of mirtazapine orally disintegrating tablets in depressed patients in the nursing home. Curr Med Res Opin. 2003;19(8):737-46. [pmid: 14687445].
355 Roose SP, Sackeim HA, Krishnan KR, et al. Antidepressant pharmacotherapy in the treatment of depression in the very old: a randomized, placebo-controlled trial. Am J Psychiatry. Nov. 2004;161(11):2050-9. [pmid: 15514406].
356 Rosenthal J, Hemlock C, Hellerstein DJ, et al. A preliminary study of serotonergic antidepressants in treatment of dysthymia. Prog Neuropsychopharmacol Biol Psychiatry. 1992;16(6):933-41. [pmid: 1513932].
357 Rudolph RL, Entsuah R, Chitra R. A meta-analysis of the effects of venlafaxine on anxiety associated with depression. J Clin Psychopharmacol. Apr. 1998;18(2):136-44. [pmid: 9555599].
358 Rush AJ, Armitage R, Gillin JC, et al. Comparative effects of nefazodone and fluoxetine on sleep in outpatients with major depressive disorder. Biol Psychiatry. Jul. 1. 1998;44(1):3-14. [pmid: 9646878].
359 Rush AJ, Bose A. Escitalopram in clinical practice: results of an open-label trial in a naturalistic setting. Depress Anxiety. 2005;21(1):26-32. [pmid: 15786487].
360 Rush AJ, Bose A, Heydorn WE. Naturalistic study of the early psychiatric use of citalopram in the United States. Depress Anxiety. 2002;16(3):121-7. [pmid: 12415537].
361 Rush AJ, Carmody TJ, Haight BR, et al. Does pretreatment insomnia or anxiety predict acute response to bupropion SR?. Ann Clin Psychiatry. Jan-Mar. 2005;17(1):1-9. [pmid: 15941026].
362 Saiz-Ruiz J, Ibanez A, Diaz-Marsa M, et al. Nefazodone in the treatment of elderly patients with depressive disorders: a prospective, observational study. CNS Drugs. 2002;16(9):635-43. [pmid: 12153334].
363 Saiz-Ruiz J, Ibanez A, Diaz-Marsa M, et al. Efficacy of venlafaxine in major depression resistant to selective serotonin reuptake inhibitors. Prog Neuropsychopharmacol Biol Psychiatry. Oct. 2002;26(6):1129-34. [pmid: 12452535].
364 Saletu-Zyhlarz GM, Abu-Bakr MH, Anderer P, et al. Insomnia related to dysthymia: polysomnographic and psychometric comparison with normal controls and acute therapeutic trials with trazodone. Neuropsychobiology. 2001;44(3):139-49. [pmid: 11586054].
365 Satterlee WG, Faries D. The effects of fluoxetine on symptoms of insomnia in depressed patients. Psychopharmacol Bull. 1995;31(2):227-37. [pmid: 7491373].
366 Schmidt ME, Fava M, Zhang S, et al. Treatment approaches to major depressive disorder relapse. Part 1: dose increase. Psychother Psychosom. Jul-Aug. 2002;71(4):190-4. [pmid: 12097783].
367 Schneider LS, Nelson JC, Clary CM, et al. An 8-week multicenter, parallel-group, double-blind, placebo-controlled study of sertraline in elderly outpatients with major depression. Am J Psychiatry. Jul. 2003;160(7):1277-85. [pmid: 12832242].
368 Schneider LS, Small GW, Clary CM. Estrogen replacement therapy and antidepressant response to sertraline in older depressed women. Am J Geriatr Psychiatry. Fall. 2001;9(4):393-9. [pmid: 11739065].
369 Schweitzer I, Burrows G, Tuckwell V, et al. Sustained response to open-label venlafaxine in drug-resistant major depression. J Clin Psychopharmacol. Apr. 2001;21(2):185-9. [pmid: 11270915].
370 Settle EC, Stahl SM, Batey SR, et al. Safety profile of sustained-release bupropion in depression: results of three clinical trials. Clin Ther. Mar. 1999;21(3):454-63. [pmid: 10321415].
371 Sheehan D, Dunbar GC, Fuell DL. The effect of paroxetine on anxiety and agitation associated with depression. Psychopharmacol Bull. 1992;28(2):139-43. [pmid: 1387484].
372 Shelton C, Entsuah R, Padmanabhan SK, et al. Venlafaxine XR demonstrates higher rates of sustained remission compared to fluoxetine, paroxetine or placebo. Int Clin Psychopharmacol. Jul. 2005;20(4):233-8. [pmid: 15933485].
373 Small GW, Birkett M, Meyers BS, et al. Impact of physical illness on quality of life and antidepressant response in geriatric major depression. Fluoxetine Collaborative Study Group. J Am Geriatr Soc. Oct. 1996;44(10):1220-5. [pmid: 8856002].
374 Spigset O, Adielsson G. Combined serotonin syndrome and hyponatraemia caused by a citalopram-buspirone interaction. Int Clin Psychopharmacol. Jan. 1997;12(1):61-3. [pmid: 9179637].
375 Stahl SM, Entsuah R, Rudolph RL. Comparative efficacy between venlafaxine and SSRIs: a pooled analysis of patients with depression. Biol Psychiatry. Dec. 15. 2002;52(12):1166-74. [pmid: 12488062].
376 Steffens DC, Doraiswamy PM, McQuoid DR. Bupropion SR in the naturalistic treatment of elderly patients with major depression. Int J Geriatr Psychiatry. Sep. 2001;16(9):862-5. [pmid: 11571765].
377 Stern WC, Harto-Truax N, Bauer N. Efficacy of bupropion in tricyclic-resistant or intolerant patients. J Clin Psychiatry. May. 1983;44(5 Pt 2):148-52. [pmid: 6406447].
378 Suri RA, Altshuler LL, Rasgon NL, et al. Efficacy and response time to sertraline versus fluoxetine in the treatment of unipolar major depressive disorder. Journal Of Clinical Psychiatry. 2000;61(12):942-6. [pmid: 11206600].
379 Szegedi A, Muller MJ, Anghelescu I, et al. Early improvement under mirtazapine and paroxetine predicts later stable response and remission with high sensitivity in patients with major depression. J Clin Psychiatry. Apr. 2003;64(4):413-20. [pmid: 12716243].
380 Tam LW, Parry BL. Does estrogen enhance the antidepressant effects of fluoxetine?. Journal Of Affective Disorders. 2003;77(1):87-92. [pmid: 14550939].
381 Taragano F, Lyketsos CG, Paz J, et al. An open-label trial of sertraline for the treatment of major depression in primary care. Ann Clin Psychiatry. Jun. 1999;11(2):67-71. [pmid: 10440523].
382 Taylor FB, Prather MR. The efficacy of nefazodone augmentation for treatment-resistant depression with anxiety symptoms or anxiety disorder. Depress Anxiety. 2003;18(2):83-8. [pmid: 12964175].
383 Teicher MH, Glod C, Cole JO. Emergence of intense suicidal preoccupation during fluoxetine treatment. Am J Psychiatry. Feb. 1990;147(2):207-10. [pmid: 2301661].
384 Thase ME, Blomgren SL, Birkett MA, et al. Fluoxetine treatment of patients with major depressive disorder who failed initial treatment with sertraline. J Clin Psychiatry. Jan. 1997;58(1):16-21. [pmid: 9055832].
385 Thase ME, Entsuah R, Cantillon M, et al. Relative Antidepressant Efficacy of Venlafaxine and SSRIs: Sex-Age Interactions. J Womens Health (Larchmt). Sep. 2005;14(7):609-16. [pmid: 16181017].
386 Thase ME, Feighner JP, Lydiard RB. Citalopram treatment of fluoxetine nonresponders. J Clin Psychiatry. Sep. 2001;62(9):683-7. [pmid: 11681763].
387 Thase ME, Ferguson JM, Lydiard RB, et al. Citalopram treatment of paroxetine-intolerant depressed patients. Depress Anxiety. 2002;16(3):128-33. [pmid: 12415538].
388 Thase ME, Friedman ES, Fasiczka AL, et al. Treatment of men with major depression: a comparison of sequential cohorts treated with either cognitive-behavioral therapy or newer generation antidepressants. J Clin Psychiatry. Jul. 2000;61(7):466-72. [pmid: 10937603].
389 Tollefson GD, Bosomworth JC, Heiligenstein JH, et al. A double-blind, placebo-controlled clinical trial of fluoxetine in geriatric patients with major depression. The Fluoxetine Collaborative Study Group. Int Psychogeriatr. Spring. 1995;7(1):89-104. [pmid: 7579025].
390 Tollefson GD, Holman SL, Sayler ME, et al. Fluoxetine, placebo, and tricyclic antidepressants in major depression with and without anxious features. J Clin Psychiatry. 1994;55(2):50-9. [pmid: 8077155].
391 Tollefson GD, Tollefson SL, Sayler ME, et al. Absence of emergent suicidal ideation during treatment: A comparative, controlled, double-blind analysis employing several distinct antidepressants. Depression. 1994;2(2):73-9.
392 Trappler B, Cohen CI. Use of SSRIs in “very old” depressed nursing home residents. Am J Geriatr Psychiatry. Winter. 1998;6(1):83-9. [pmid: 9469218].
393 Trivedi MH, Rush AJ, Carmody TJ, et al. Do bupropion SR and sertraline differ in their effects on anxiety in depressed patients?. J Clin Psychiatry. Oct. 2001;62(10):776-81. [pmid: 11816866].
394 Tyra JM, Greenawald MH. TCAs or SSRIs as initial therapy for depression?. J Fam Pract. Nov. 1999;48(11):845-6. [pmid: 10907616].
395 Van Houdenhove B, Onghena P, Floris M, et al. An open study of sertraline in acute and continuation treatment of depressed out-patients. J Int Med Res. Nov-Dec. 1997;25(6):340-53. [pmid: 9427167].
396 Van Wyck Fleet J, Manberg PJ, Miller LL, et al. Overview of clinically significant adverse reactions to bupropion. J Clin Psychiatry. May. 1983;44(5 Pt 2):191-6.
397 Verhoeven WM, Veendrik-Meekes MJ, Jacobs GA, et al. Citalopram in mentally retarded patients with depression: a long-term clinical investigation. Eur Psychiatry. Mar. 2001;16(2):104-8. [pmid: 11311174].
398 Wagner W, Plekkenpol B, Gray TE, et al. Review of fluvoxamine safety database. Drugs. Suppl 2. 1992;43:48-53. discussion -4. [pmid: 1378374].
399 Walker PW, Cole JO, Gardner EA, et al. Improvement in fluoxetine-associated sexual dysfunction in patients switched to bupropion. J Clin Psychiatry. Dec. 1993;54(12):459-65. [pmid: 8276736].
400 Weintraub D, Streim JE, Datto CJ, et al. Effect of increasing the dose and duration of sertraline trial in the treatment of depressed nursing home residents. J Geriatr Psychiatry Neurol. Jun. 2003;16(2):109-11. [pmid: 12801161].
401 Wernicke JF, Sayler ME, Koke SC, et al. Fluoxetine and concomitant centrally acting medication use during clinical trials of depression: the absence of an effect related to agitation and suicidal behavior. Depress Anxiety. 1997;6(1):31-9. [pmid: 9394873].
402 White K, Wykoff W, Tynes LL, et al. Fluvoxamine in the treatment of tricyclic-resistant depression. Psychiatr J Univ Ott. Sep. 1990;15(3):156-8. [pmid: 2123039].
403 Whyte EM, Basinski J, Farhi P, et al. Geriatric depression treatment in nonresponders to selective serotonin reuptake inhibitors. J Clin Psychiatry. Dec. 2004;65(12):1634-41. [pmid: 15641868].
404 Wohlreich MM, Mallinckrodt CH, Watkin JG, et al. Duloxetine for the long-term treatment of major depressive disorder in patients aged 65 and older: an open-label study. BMC Geriatr. Dec. 7. 2004;4:11. [pmid: 15585058].
405 Yohannes AM, Connolly MJ, Baldwin RC. A feasibility study of antidepressant drug therapy in depressed elderly patients with chronic obstructive pulmonary disease. Int J Geriatr Psychiatry. May. 2001;16(5):451-4. [pmid: 11376459].
406 Zajecka JM. The effect of nefazodone on comorbid anxiety symptoms associated with depression: experience in family practice and psychiatric outpatient settings. J Clin Psychiatry. Suppl 2. 1996;57:10-4. [pmid: 8626357].
407 Zanardi R, Cusin C, Rossini D, et al. Comparison of response to fluvoxamine in nondemented elderly compared to younger patients affected by major depression. J Clin Psychopharmacol. Dec. 2003;23(6):535-9. [pmid: 14624182].
408 Zarate CA, Kando JC, Tohen M, et al. Does intolerance or lack of response with fluoxetine predict the same will happen with sertraline?. J Clin Psychiatry. Feb. 1996;57(2):67-71. [pmid: 8591971].

## Other(172)

1 Addington D, Addington J, Patten S, et al. Double-blind, placebo-controlled comparison of the efficacy of sertraline as treatment for a major depressive episode in patients with remitted schizophrenia. J Clin Psychopharmacol. Feb. 2002;22(1):20-5. [pmid: 11799338].
2 Agius M, Gardner J, Liu K, et al. An audit to compare discharge rates and suicidality between antidepressant monotherapies prescribed for unipolar depression. Psychiatr Danub. Jun. 2010;22(2):350-3. [pmid: 20562780].
3 Almeida OP, Waterreus A, Hankey GJ. Preventing depression after stroke: Results from a randomized placebo-controlled trial. J Clin Psychiatry. Jul. 2006;67(7):1104-9. [pmid: 16889454].
4 Altintoprak AE, Zorlu N, Coskunol H, et al. Effectiveness and tolerability of mirtazapine and amitriptyline in alcoholic patients with co-morbid depressive disorder: a randomized, double-blind study. Hum Psychopharmacol. 2008;23(4):313-9. [pmid: 18327889].
5 Altman EM, Manos GH. Serotonin syndrome associated with citalopram and meperidine. Psychosomatics. Jul-Aug. 2007;48(4):361-3. [pmid: 17600178].
6 Amsterdam JD, Shults J. Does tachyphylaxis occur after repeated antidepressant exposure in patients with Bipolar II major depressive episode?. J Affect Disord. May. 2009;115(1-2):234-40. [pmid: 18694599].
7 Anderson RJ, Gott BM, Sayuk GS, et al. Antidepressant pharmacotherapy in adults with type 2 diabetes: rates and predictors of initial response. Diabetes Care. Mar. 2010;33(3):485-9. [pmid: 20032276].
8 Arias B, Serretti A, Mandelli L, et al. Dysbindin gene (DTNBP1) in major depression: association with clinical response to selective serotonin reuptake inhibitors. Pharmacogenet Genomics. Feb. 2009;19(2):121-8. [pmid: 19065121].
9 Atlantis E, Browning C, Sims J, et al. Diabetes incidence associated with depression and antidepressants in the Melbourne Longitudinal Studies on Healthy Ageing (MELSHA). Int J Geriatr Psychiatry. 2010;25(7):688-96. [pmid: 19806604].
10 Baldwin DS, Montgomery SA, Nil R, et al. Discontinuation symptoms in depression and anxiety disorders. International Journal of Neuropsychopharmacology. 2007;10(1):73-84. [pmid: 16359583].
11 Barbui C, Andretta M, De Vitis G, et al. Antidepressant drug prescription and risk of abnormal bleeding: A case-control study. J Clin Psychopharmacol. 2009;29(1):33-8. [pmid: 19142104].
12 Barbui C, Furukawa TA, Cipriani A. Effectiveness of paroxetine in the treatment of acute major depression in adults: A systematic re-examination of published and unpublished data from randomized trials. Can Med Assoc J. 2008;178(3):296-305. [pmid: 18227449].
13 Barone P, Scarzella L, Marconi R, et al. Pramipexole versus sertraline in the treatment of depression in Parkinson's disease: a national multicenter parallel-group randomized study. J Neurol. May. 2006;253(5):601-7. [pmid: 16607468].
14 Bech P, Lonn SL, Overo KF. Relapse prevention and residual symptoms: A closer analysis of placebo-controlled continuation studies with escitalopram in major depressive disorder, generalized anxiety disorder, social anxiety disorder, and obsessive-compulsive disorder. J Clin Psychiatry. 2010;71(2):121-9. [pmid: 19961809].
15 Berlanga C, Flores-Ramos M. Different gender response to serotonergic and noradrenergic antidepressants. A comparative study of the efficacy of citalopram and reboxetine. J Affect Disord. Oct. 2006;95(1-3):119-23. [pmid: 16782204].
16 Berman RM, Fava M, Thase ME, et al. Aripiprazole augmentation in major depressive disorder: a double-blind, placebo-controlled study in patients with inadequate response to antidepressants. CNS Spectr. Apr. 2009;14(4):197-206. [pmid: 19407731].
17 Berman RM, Marcus RN, Swanink R, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder: a multicenter, randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Jun. 2007;68(6):843-53. [pmid: 17592907].
18 Binneman B, Feltner D, Kolluri S, et al. A 6-week randomized, placebo-controlled trial of CP-316,311 (a selective CRH1 antagonist) in the treatment of major depression. Am J Psychiatry. May. 2008;165(5):617-20. [pmid: 18413705].
19 Blier P, Ward HE, Tremblay P. Combination of antidepressant from treatment initiation for depression. American Psychiatric Association annual meeting. 2006.
20 Blom MB, Jonker K, Dusseldorp E, et al. Combination treatment for acute depression is superior only when psychotherapy is added to medication. Psychother Psychosom. 2007;76(5):289-97. [pmid: 17700049].
21 Bodnar LM, Sunder KR, Wisner KL. Treatment with selective serotonin reuptake inhibitors during pregnancy: deceleration of weight gain because of depression or drug?. Am J Psychiatry. Jun. 2006;163(6):986-91. [pmid: 16741197].
22 Bose A, Li D, Gandhi C. Escitalopram in the acute treatment of depressed patients aged 60 years or older. Am J Geriatr Psychiatry. 2008;16(1):14-20. [pmid: 18165459].
23 Brown ES, Murray M, Carmody TJ, et al. The Quick Inventory of Depressive Symptomatology-Self-report: a psychometric evaluation in patients with asthma and major depressive disorder. Ann Allergy Asthma Immunol. May. 2008;100(5):433-8. [pmid: 18517074].
24 Brunton S, Wang F, Edwards SB, et al. Profile of adverse events with duloxetine treatment: A pooled analysis of placebo-controlled studies. Drug Saf. 2010;33(5):393-407. [pmid: 20397739].
25 Chen Y, Guo JJ, Li H, et al. Risk of cerebrovascular events associated with antidepressant use in patients with depression: A population-based, nested case-control study. Annals of Pharmacotherapy. 2008;42(2):177-84. [pmid: 18212255].
26 Claghorn J. A double-blind comparison of paroxetine and placebo in the treatment of depressed outpatients. Int Clin Psychopharmacol. Jun. Suppl 4. 1992;6:25-30. [pmid: 1431007].
27 Claghorn JL, Kiev A, Rickels K, et al. Paroxetine versus placebo: a double-blind comparison in depressed patients. J Clin Psychiatry. Dec. 1992;53(12):434-8. [pmid: 1487471].
28 Cravello L, Caltagirone C, Spalletta G. The SNRI venlafaxine improves emotional unawareness in patients with post-stroke depression. Hum Psychopharmacol. Jun. 2009;24(4):331-6. [pmid: 19330795].
29 Dahlberg M, Lundin K. Antidepressants and the Suicide Rate: Is There Really a Connection?. Upsulla University (Sweden) Economics Department. 2005:4.
30 de Abajo FJ, Garcia-Rodriguez LA. Risk of upper gastrointestinal tract bleeding associated with selective serotonin reuptake inhibitors and venlafaxine therapy: interaction with nonsteroidal anti-inflammatory drugs and effect of acid-suppressing agents. Arch Gen Psychiatry. Jul. 2008;65(7):795-803. [pmid: 18606952].
31 De Las Cuevas C, de la Rosa MA, Troyano JM, et al. Are psychotropics drugs used in pregnancy?. Pharmacoepidemiol Drug Saf. Sep. 2007;16(9):1018-23. [pmid: 17455181].
32 Demyttenaere K, Andersen HF, Reines EH. Impact of escitalopram treatment on Quality of Life Enjoyment and Satisfaction Questionnaire scores in major depressive disorder and generalized anxiety disorder. Int Clin Psychopharmacol. Sep. 2008;23(5):276-86. [pmid: 18703937].
33 Deshauer D, Moher D, Fergusson D, et al. Selective serotonin reuptake inhibitors for unipolar depression: A systematic review of classic long-term randomized controlled trials. Can Med Assoc J. 2008;178(10):1293-301. [pmid: 18458261].
34 Desmarais JE, Looper KJ. Interactions between tamoxifen and antidepressants via cytochrome P450 2D6. J Clin Psychiatry. Dec. 2009;70(12):1688-97. [pmid: 20141708].
35 Dichter GS, Tomarken AJ, Freid CM, et al. Do venlafaxine XR and paroxetine equally influence negative and positive affect?. J Affect Disord. Apr. 2005;85(3):333-9. [pmid: 15780704].
36 Djulus J, Koren G, Einarson TR, et al. Exposure to mirtazapine during pregnancy: a prospective, comparative study of birth outcomes. J Clin Psychiatry. Aug. 2006;67(8):1280-4. [pmid: 16965209].
37 Dudley M, Goldney R, Hadzi-Pavlovic D. Are adolescents dying by suicide taking SSRI antidepressants? A review of observational studies. Australasian Psychiatry. 2010;18(3):242-5. [pmid: 20482427].
38 Dunner DL, Wilson M, Fava M, et al. Long-term tolerability and effectiveness of duloxetine in the treatment of major depressive disorder. Depress Anxiety. 2008;25(5):E1-8. [pmid: 17621644].
39 Eckert L, Falissard B. Using meta-regression in performing indirect-comparisons: comparing escitalopram with venlafaxine XR. Curr Med Res Opin. 2006;22(11):2313-21. [pmid: 17076991].
40 Eckert L, Lancon C. Duloxetine compared with fluoxetine and venlafaxine: Use of meta-regression analysis for indirect comparisons. BMC Psychiatry. 2006:6.
41 Einarson TR, Arikian SR, Casciano J, et al. Comparison of extended-release venlafaxine, selective serotonin reuptake inhibitors, and tricyclic antidepressants in the treatment of depression: a meta-analysis of randomized controlled trials. Clin Ther. 1999;21(2):296-308. [pmid: 10211533].
42 Fantino B, Moore N, Verdoux H, et al. Cost-effectiveness of escitalopram vs. citalopram in major depressive disorder. Int Clin Psychopharmacol. Mar. 2007;22(2):107-15. [pmid: 17293711].
43 Fava M, Graves LM, Benazzi F, et al. A cross-sectional study of the prevalence of cognitive and physical symptoms during long-term antidepressant treatment. J Clin Psychiatry. 2006;67(11):1754-9. [pmid: 17196056].
44 Fava M, McCall WV, Krystal A, et al. Eszopiclone co-administered with fluoxetine in patients with insomnia coexisting with major depressive disorder. Biol Psychiatry. 2006;59(11):1052-60. [pmid: 16581036].
45 Feighner JP, Overo K. Multicenter, placebo-controlled, fixed-dose study of citalopram in moderate-to-severe depression. J Clin Psychiatry. Dec. 1999;60(12):824-30. [pmid: 10665628].
46 Feighner JP, Pambakian R, Fowler RC, et al. A comparison of nefazodone, imipramine, and placebo in patients with moderate to severe depression. Psychopharmacol Bull. 1989;25(2):219-21. [pmid: 2690165].
47 Fiedorowicz JG, Takezawa K, Robinson RG. Risk factors for and correlates of poststroke depression following discontinuation of antidepressants. J Neuropsychiatry Clin Neurosci. Fall. 2007;19(4):399-405. [pmid: 18070842].
48 Frank C. Recognition and treatment of serotonin syndrome. Can Fam Physician. Jul. 2008;54(7):988-92. [pmid: 18625822].
49 Garcia-Cebrian A, Bauer M, Montejo AL, et al. Factors influencing depression endpoints research (FINDER): Study design and population characteristics. European Psychiatry. 2008;23(1):57-65. [pmid: 18086518].
50 Gau YT, Liou YJ, Yu YW, et al. Evidence for association between genetic variants of p75 neurotrophin receptor (p75NTR) gene and antidepressant treatment response in Chinese major depressive disorder. Am J Med Genet B Neuropsychiatr Genet. Jul. 5. 2008;147B(5):594-9. [pmid: 18081157].
51 Gentile S. Quetiapine-fluvoxamine combination during pregnancy and while breastfeeding. Arch Womens Ment Health. May. 2006;9(3):158-9. [pmid: 16683078].
52 Gilmer WS, Gollan JK, Wisniewski SR, et al. Does the duration of index episode affect the treatment outcome of major depressive disorder? A STAR*D report. J Clin Psychiatry. Aug. 2008;69(8):1246-56. [pmid: 18681756].
53 Ginsberg DL. Adjunctive ropinirole for treatment-resistant depression. Primary Psychiatry. 2005;12(8):26-7.
54 Hall WD, Lucke J. How have the selective serotonin reuptake inhibitor antidepressants affected suicide mortality?. Aust N Z J Psychiatry. Nov-Dec. 2006;40(11-12):941-50. [pmid: 17054562].
55 Harvey AT, Silkey BS, Kornstein SG, et al. Acute worsening of chronic depression during a double-blind, randomized clinical trial of antidepressant efficacy: differences by sex and menopausal status. J Clin Psychiatry. Jun. 2007;68(6):951-8. [pmid: 17592923].
56 Heiligenstein JH, Ware JE Jr, Beusterien KM, et al. Acute effects of fluoxetine versus placebo on functional health and well-being in late-life depression. Int Psychogeriatr. 1995;7(Suppl):125-37. [pmid: 8580388].
57 Hellerstein DJ, Batchelder ST, Hyler S, et al. Escitalopram versus placebo in the treatment of dysthymic disorder. Int Clin Psychopharmacol. 2010;25(3):143-8. [pmid: 21811192].
58 Henry NL, Stearns V, Flockhart DA, et al. Drug interactions and pharmacogenomics in the treatment of breast cancer and depression. Am J Psychiatry. Oct. 2008;165(10):1251-5. [pmid: 18829880].
59 Herrera-Guzman I, Gudayol-Ferre E, Herrera-Guzman D, et al. Effects of selective serotonin reuptake and dual serotonergic-noradrenergic reuptake treatments on memory and mental processing speed in patients with major depressive disorder. J Psychiatr Res. Jun. 2009;43(9):855-63. [pmid: 19128810].
60 Hewett K, Chrzanowski W, Jokinen R, et al. Double-blind, placebo-controlled evaluation of extended-release bupropion in elderly patients with major depressive disorder. J Psychopharmacol. Apr. 2010;24(4):521-9. [pmid: 19164492].
61 Husain MM, Rush JA, Wisniewski SR, et al. Family history of depression and therapeutic outcome: findings from STAR*D. J Clin Psychiatry. Feb. 2009;70(2):185-95. [pmid: 19192454].
62 Jakob F, Wolf J. EPMS under antidepressive therapy with fluvoxamine and concomitant antibiotic therapy with clindamycin. Pharmacopsychiatry. May. 2007;40(3):129. [pmid: 17541891].
63 Jiang W, O'Connor C, Silva SG, et al. Safety and Efficacy of Sertraline for Depression in Patients with CHF (SADHART-CHF): A randomized, double-blind, placebo-controlled trial of sertraline for major depression with congestive heart failure. Am Heart J. 2008;156(3):437-44. [pmid: 18760123].
64 Jick SS, Li L. Antidepressant drug use and risk of venous thromboembolism. Pharmacotherapy. 2008;28(2):144-50. [pmid: 18225961].
65 Jimenez-Genchi A. Immediate switching from moclobemide to duloxetine may induce serotonin syndrome. J Clin Psychiatry. Nov. 2006;67(11):1821-2. [pmid: 17196070].
66 Kasper S, Spadone C, Verpillat P, et al. Onset of action of escitalopram compared with other antidepressants: Results of a pooled analysis. Int Clin Psychopharmacol. Mar. 2006. 2006;21(2):105-10. [pmid: 16421462].
67 Kato M, Zanardi R, Rossini D, et al. 5-HT2A gene variants influence specific and different aspects of antidepressant response in Japanese and Italian mood disorder patients. Psychiatry Res. May. 15. 2009;167(1-2):97-105. [pmid: 19361869].
68 Katzman MA, Tricco AC, McIntosh D, et al. Paroxetine versus placebo and other agents for depressive disorders: a systematic review and meta-analysis. J Clin Psychiatry. 2007;68(12):1845-59. [pmid: 18162015].
69 Kennedy SH, Andersen HF, Lam RW. Efficacy of escitalopram in the treatment of major depressive disorder compared with conventional selective serotonin reuptake inhibitors and venlafaxine XR: a meta-analysis. J Psychiatry Neurosci. 2006;31(2):122-31. [pmid: 16575428].
70 Kennedy SH, Andersen HF, Thase ME. Escitalopram in the treatment of major depressive disorder: a meta-analysis. Curr Med Res Opin. 2009;25(1):161-75. [pmid: 19210149].
71 Khan A, Fabre LF, Rudolph R. Venlafaxine in depressed outpatients. Psychopharmacol Bull. 1991;27(2):141-4. [pmid: 1924660].
72 Khandker RK, Kruzikas DT, McLaughlin TP. Pharmacy and medical costs associated with switching between venlafaxine and SSRI antidepressant therapy for the treatment of major depressive disorder. J Manag Care Pharm. Jun. 2008;14(5):426-41. [pmid: 18597572].
73 Kluge M, Schussler P, Steiger A. Duloxetine increases stage 3 sleep and suppresses rapid eye movement (REM) sleep in patients with major depression. Eur Neuropsychopharmacol. Jul. 2007;17(8):527-31. [pmid: 17337164].
74 Kocsis JH, Leon AC, Markowitz JC, et al. Patient preference as a moderator of outcome for chronic forms of major depressive disorder treated with nefazodone, cognitive behavioral analysis system of psychotherapy, or their combination. J Clin Psychiatry. Mar. 2009;70(3):354-61. [pmid: 19192474].
75 Kok RM, Nolen WA, Heeren TJ. Venlafaxine versus nortriptyline in the treatment of elderly depressed inpatients: a randomised, double-blind, controlled trial. Int J Geriatr Psychiatry. Dec. 2007;22(12):1247-54. [pmid: 17562523].
76 Kornstein SG, Wohlreich MM, Mallinckrodt CH, et al. Duloxetine efficacy for major depressive disorder in male vs. female patients: data from 7 randomized, double-blind, placebo-controlled trials. J Clin Psychiatry. 2006;67(5):761-70. [pmid: 16841626].
77 Kyomen HH, Whitfield TH. Psychosis in the elderly. Am J Psychiatry. Feb. 2009;166(2):146-50. [pmid: 19188291].
78 Lam RW, Andersen HF. The influence of baseline severity on efficacy of escitalopram and citalopram in the treatment of major depressive disorder: an extended analysis. Pharmacopsychiatry. Sep. 2006;39(5):180-4. [pmid: 16944409].
79 Lam RW, Lonn SL, Despiegel N. Escitalopram versus serotonin noradrenaline reuptake inhibitors as second step treatment for patients with major depressive disorder: A pooled analysis. Int Clin Psychopharmacol. 2010;25(4):199-203. [pmid: 20357664].
80 Langworth S, Bodlund O, Agren H. Efficacy and tolerability of reboxetine compared with citalopram: a double-blind study in patients with major depressive disorder. J Clin Psychopharmacol. Apr. 2006;26(2):121-7. [pmid: 16633139].
81 Lavretsky H, Park S, Siddarth P, et al. Methylphenidate-enhanced antidepressant response to citalopram in the elderly: a double-blind, placebo-controlled pilot trial. Am J Geriatr Psychiatry. Feb. 2006;14(2):181-5. [pmid: 16473984].
82 Leuchter AF, Lesser IM, Trivedi MH, et al. An open pilot study of the combination of escitalopram and bupropion-SR for outpatients with major depressive disorder. J Psychiatr Pract. Sep. 2008;14(5):271-80. [pmid: 18832958].
83 Leykin Y, Amsterdam JD, DeRubeis RJ, et al. Progressive resistance to a selective serotonin reuptake inhibitor but not to cognitive therapy in the treatment of major depression. J Consult Clin Psychol. Apr. 2007;75(2):267-76. [pmid: 17469884].
84 Liberek C, Aubry JM, Baud P. Manic switch and serotonin syndrome with venlafaxine-lithium-valproate association. Therapie. Nov-Dec. 2006;61(6):531-3. [pmid: 17348610].
85 Lineberry CG, Johnston JA, Raymond RN, et al. A fixed-dose (300 mg) efficacy study of bupropion and placebo in depressed outpatients. J Clin Psychiatry. May. 1990;51(5):194-9. [pmid: 2110559].
86 Lustman PJ, Williams MM, Sayuk GS, et al. Factors influencing glycemic control in type 2 diabetes during acute- and maintenance-phase treatment of major depressive disorder with bupropion. Diabetes Care. Mar. 2007;30(3):459-66. [pmid: 17327305].
87 IJ MA, Huijbregts KML, Van Marwijk HWJ, et al. Cost-effectiveness of collaborative care including PST and an antidepressant treatment algorithm for the treatment of major depressive disorder in primary care; A randomised clinical trial. BMC Health Services Research. 2007;7(34).
88 Mallinckrodt CH, Prakash A, Houston JP, et al. Differential antidepressant symptom efficacy: placebo-controlled comparisons of duloxetine and SSRIs (fluoxetine, paroxetine, escitalopram). Neuropsychobiology. 2007;56(2-3):73-85. [pmid: 18037817].
89 Mandelli L, Serretti A, Zanardi R, et al. Antidepressant response in the elderly. Psychiatry Res. Jul. 30. 2007;152(1):37-44. [pmid: 17383015].
90 Marcus RN, McQuade RD, Carson WH, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder: a second multicenter, randomized, double-blind, placebo-controlled study. J Clin Psychopharmacol. Apr. 2008;28(2):156-65. [pmid: 18344725].
91 Markowitz JC, Kocsis JH, Bleiberg KL, et al. A comparative trial of psychotherapy and pharmacotherapy for “pure” dysthymic patients. J Affect Disord. Dec. 2005;89(1-3):167-75. [pmid: 16263177].
92 Matreja PS, Badyal DK, Khosla P, et al. Effectiveness and acceptability of sertraline and citalopram in major depressive disorder: pragmatic randomized open-label comparison. Hum Psychopharmacol. 2007;22(7):477-82. [pmid: 17647298].
93 Mendels J, Johnston R, Mattes J, et al. Efficacy and safety of b.i.d. doses of venlafaxine in a dose-response study. Psychopharmacol Bull. 1993;29(2):169-74. [pmid: 8290661].
94 Mendels J, Reimherr F, Marcus RN, et al. A double-blind, placebo-controlled trial of two dose ranges of nefazodone in the treatment of depressed outpatients. J Clin Psychiatry. Suppl 6. 1995;56:30-6. [pmid: 7649971].
95 Menza M, DeFonzo Dobkin R, Marin H, et al. The impact of treatment of depression on quality of life, disability and relapse in patients with Parkinson's disease. Movement Disorders. 2009;24(9):1325-32. [pmid: 19412944].
96 Montgomery SA, Möller HJ. Is the significant superiority of escitalopram compared with other antidepressants clinically relevant?. Int Clin Psychopharmacol. May. 2009. 2009;24(3):111-8. [pmid: 19357527].
97 Morasco BJ, Rifai MA, Loftis JM, et al. A randomized trial of paroxetine to prevent interferon-alpha-induced depression in patients with hepatitis C. J Affect Disord. Nov. 2007;103(1-3):83-90. [pmid: 17292481].
98 Mottram P, Wilson K, Strobl J. Antidepressants for depressed elderly. Cochrane Database Syst Rev. 2006;(1).
99 Mowla A, Ghanizadeh A, Pani A. A comparison of effects of fluoxetine and nortriptyline on the symptoms of major depressive disorder. J Clin Psychopharmacol. Apr. 2006;26(2):209-11. [pmid: 16633155].
100 Muhonen LH, Lonnqvist J, Juva K, et al. Double-blind, randomized comparison of memantine and escitalopram for the treatment of major depressive disorder comorbid with alcohol dependence. J Clin Psychiatry. Mar. 2008;69(3):392-9. [pmid: 18348597].
101 Muhonen LH, Lonnqvist J, Lahti J, et al. Age at onset of first depressive episode as a predictor for escitalopram treatment of major depression comorbid with alcohol dependence. Psychiatry Res. May. 15. 2009;167(1-2):115-22. [pmid: 19346004].
102 Mulsant BH. Onset of confusion in the context of late-life depression. J Psychiatry Neurosci. Mar. 2007;32(2):152. [pmid: 17353943].
103 Musselman DL, Somerset WI, Guo Y, et al. A double-blind, multicenter, parallel-group study of paroxetine, desipramine, or placebo in breast cancer patients (stages I, II, III, and IV) with major depression. J Clin Psychiatry. Feb. 2006;67(2):288-96. [pmid: 16566626].
104 Mussig K, Morike K, Haring HU. Severe and symptomatic hyponatremia following duloxetine treatment. J Psychopharmacol. May. 2009;23(3):338-9. [pmid: 18562431].
105 Nelson JC. Anxiety does not predict response to duloxetine in major depression: results of a pooled analysis of individual patient data from 11 placebo-controlled trials. Depress Anxiety. 2010;27(1):12-8. [pmid: 20013987].
106 Nemeroff CB, Entsuah R, Benattia I, et al. Comprehensive analysis of remission (COMPARE) with venlafaxine versus SSRIs. Biol Psychiatry. Feb. 15. 2008;63(4):424-34. [pmid: 17888885].
107 Ng J, Sansone RA, McDonald S. Akathisia and abnormal movements of the upper extremities with venlafaxine and methimazole. Gen Hosp Psychiatry. 2009;31(4):388-90. [pmid: 19555803].
108 Nose M, Cipriani A, Furukawa TA, et al. Duloxetine versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2007;(2).
109 Omori I, Watanabe N, Nakagawa A, et al. Fluvoxamine versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews. 2006;(3).
110 Ozdemir S, Yalug I, Aker AT. Serotonin syndrome associated with sertraline monotherapy at therapeutic doses. Prog Neuropsychopharmacol Biol Psychiatry. Apr. 1. 2008;32(3):897-8. [pmid: 18077070].
111 Pani Pier P, Vacca R, Trogu E, et al. Pharmacological treatment for depression during opioid agonist treatment for opioid dependence. Cochrane Database of Systematic Reviews. 2010;(9).
112 Papakostas GI, Clain A, Ameral VE, et al. Fluoxetine-clonazepam cotherapy for anxious depression: an exploratory, post-hoc analysis of a randomized, double blind study. Int Clin Psychopharmacol. 2010;25(1):17-21. [pmid: 19898245].
113 Papakostas GI, Crawford CM, Scalia MJ, et al. Timing of clinical improvement and symptom resolution in the treatment of major depressive disorder. A replication of findings with the use of a double-blind, placebo-controlled trial of Hypericum perforatum versus fluoxetine. Neuropsychobiology. 2007;56(2-3):132-7. [pmid: 18259086].
114 Papakostas GI, Kornstein SG, Clayton AH, et al. Relative antidepressant efficacy of bupropion and the selective serotonin reuptake inhibitors in major depressive disorder: gender-age interactions. Int Clin Psychopharmacol. 2007;22(4):226-9. [pmid: 17519646].
115 Papakostas GI, Montgomery SA, Thase ME, et al. Comparing the rapidity of response during treatment of major depressive disorder with bupropion and the SSRIs: a pooled survival analysis of 7 double-blind, randomized clinical trials. J Clin Psychiatry. Dec. 2007;68(12):1907-12. [pmid: 18162022].
116 Papakostas GI, Thase ME, Fava M, et al. Are Antidepressant Drugs That Combine Serotonergic and Noradrenergic Mechanisms of Action More Effective Than the Selective Serotonin Reuptake Inhibitors in Treating Major Depressive Disorder? A Meta-analysis of Studies of Newer Agents. Biological Psychiatry. 2007;62(11):1217-27. [pmid: 17588546].
117 Papakostas GI, Trivedi MH, Alpert JE, et al. Efficacy of bupropion and the selective serotonin reuptake inhibitors in the treatment of anxiety symptoms in major depressive disorder: a metaanalysis of individual patient data from 10 double-blind, randomized clinical trials. J Psychiatr Res. Jan. 2008;42(2):134-40. [pmid: 17631898].
118 Park YM, Lee HJ, Kang SG, et al. Tardive dyskinesia associated with long-term administration of escitalopram and itopride in major depressive disorder. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 17. 2009;33(2):380-1. [pmid: 19121360].
119 Parker G, Tully L, Olley A, et al. SSRIs as mood stabilizers for Bipolar II Disorder? A proof of concept study. J Affect Disord. Jun. 2006;92(2-3):205-14. [pmid: 16516304].
120 Parry BL. Perimenopausal depression. Am J Psychiatry. Jan. 2008;165(1):23-7. [pmid: 18178752].
121 Perahia DGS, Pritchett YL, Desaiah D, et al. Efficacy of duloxetine in painful symptoms: An analgesic or antidepressant effect?. Int Clin Psychopharmacol. Nov. 2006. 2006;21(6):311-7. [pmid: 17012978].
122 Perry R, Cassagnol M. Desvenlafaxine: A new serotonin-norepinephrine reuptake inhibitor for the treatment of adults with major depressive disorder. Clin Ther. 2009;31(SUPPL. 1):1374-404. [pmid: 19698900].
123 Perugi G, Romano A, Tusini G. Short-term and long-term treatment in depressive syndromes: Focus on antidepressants tolerability. Trattamento farmacologico a breve e lungo termine nelle sindromi depressive: Focus sulla tollerabilità degli antidepressivi. 2007;13(3):378-86.
124 Petersen TJ, Pava JA, Buchin J, et al. The role of cognitive-behavioral therapy and fluoxetine in prevention of recurrence of major depressive disorder. Cognitive Therapy and Research. 2010;34(1):13-23.
125 Pinquart M, Duberstein PR, Lyness JM. Treatments for later-life depressive conditions: A meta-analytic comparison of pharmacotherapy and psychotherapy. Am J Psychiatry. 2006;163(9):1493-501. [pmid: 16946172].
126 Pitchot W, Ansseau M. Shock-like sensations associated with duloxetine discontinuation. Ann Clin Psychiatry. Jul-Sep. 2008;20(3):175. [pmid: 18633745].
127 Post RM, Altshuler LL, Leverich GS, et al. Mood switch in bipolar depression: comparison of adjunctive venlafaxine, bupropion and sertraline. Br J Psychiatry. Aug. 2006;189:124-31. [pmid: 16880481].
128 Posternak MA, Zimmerman M. Dual Reuptake Inhibitors Incur Lower Rates of Tachyphylaxis Than Selective Serotonin Reuptake Inhibitors: A Retrospective Study. J Clin Psychiatry. Jun. 2005. 2005;66(6):705-7. [pmid: 15960562].
129 Prospero-Garcia KA, Torres-Ruiz A, Ramirez-Bermudez J, et al. Fluoxetine-mirtazapine interaction may induce restless legs syndrome: report of 3 cases from a clinical trial. J Clin Psychiatry. Nov. 2006;67(11):1820. [pmid: 17196069].
130 Raja M, Azzoni A. Are antidepressants warranted in the treatment of patients who present suicidal behavior?. Human Psychopharmacology. 2008;23(8):661-8. [pmid: 19016273].
131 Rapaport MH, Lydiard RB, Pitts CD, et al. Low doses of controlled-release paroxetine in the treatment of late-life depression: a randomized, placebo-controlled trial. J Clin Psychiatry. 2009;70(1):46-57. [pmid: 19026248].
132 Reimherr FW, Byerley WF, Ward MF, et al. Sertraline, a selective inhibitor of serotonin uptake, for the treatment of outpatients with major depressive disorder. Psychopharmacol Bull. 1988;24(1):200-5. [pmid: 3290941].
133 Rutherford B, Sneed J, Devanand D, et al. Antidepressant study design affects patient expectancy: a pilot study. Psychol Med. May. 2010;40(5):781-8. [pmid: 19732481].
134 San L, Arranz B. Mirtazapine: Only for depression?. Acta Neuropsychiatrica. Jun-Aug. 2006. 2006;18(3):130-43.
135 Santos PM, Lopez-Garcia P, Navarro JS, et al. False positive phencyclidine results caused by venlafaxine. Am J Psychiatry. Feb. 2007;164(2):349. [pmid: 17267806].
136 Schmitt L, Tonnoir B, Arbus C. Safety and efficacy of oral escitalopram as continuation treatment of intravenous citalopram in patients with major depressive disorder. Neuropsychobiology. 2006;54(4):201-7. [pmid: 17337913].
137 Seemuller F, Riedel M, Obermeier M, et al. Outcomes of 1014 naturalistically treated inpatients with major depressive episode. Eur Neuropsychopharmacol. 2010;20(5):346-55. [pmid: 20097046].
138 Seo HJ, Jung YE, Woo YS, et al. Effect of augmented atypical antipsychotics on weight change in patients with major depressive disorder in a naturalistic setting. Hum Psychopharmacol. Mar. 2009;24(2):135-43. [pmid: 19156709].
139 Serrano-Blanco A, Gabarron E, Garcia-Bayo I, et al. Effectiveness and cost-effectiveness of antidepressant treatment in primary health care: a six-month randomised study comparing fluoxetine to imipramine. J Affect Disord. Apr. 2006;91(2-3):153-63. [pmid: 16458976].
140 Sheffrin M, Driscoll HC, Lenze EJ, et al. Pilot study of augmentation with aripiprazole for incomplete response in late-life depression: getting to remission. J Clin Psychiatry. Feb. 2009;70(2):208-13. [pmid: 19210951].
141 Shelton RC, Andorn AC, Mallinckrodt CH, et al. Evidence for the efficacy of duloxetine in treating mild, moderate, and severe depression. Int Clin Psychopharmacol. Nov. 2007;22(6):348-55. [pmid: 17917553].
142 Shelton RC, Prakash A, Mallinckrodt CH, et al. Patterns of depressive symptom response in duloxetine-treated outpatients with mild, moderate or more severe depression. Int J Clin Pract. Aug. 2007;61(8):1337-48. [pmid: 17627710].
143 Shen J, Moller HJ, Wang X, et al. Mirtazapine, a sedating antidepressant, and improved driving safety in patients with major depressive disorder: a prospective, randomized trial of 28 patients. J Clin Psychiatry. Mar. 2009;70(3):370-7. [pmid: 19192466].
144 Shrivastava RK, Shrivastava SH, Overweg N, et al. A double-blind comparison of paroxetine, imipramine, and placebo in major depression. J Clin Psychiatry. Feb. 1992;53(Suppl):48-51. [pmid: 1531825].
145 Simon JS, Sheehan D, Thase ME, et al. Comparison of efficacy and tolerability of paroxetine vs venlafaxine. 2005.
146 Smith GS, Reynolds CF 3rd, Houck PR, et al. Cerebral glucose metabolic response to combined total sleep deprivation and antidepressant treatment in geriatric depression: a randomized, placebo-controlled study. Psychiatry Res. Jan. 30. 2009;171(1):1-9. [pmid: 19087899].
147 Sneed JR, Culang ME, Keilp JG, et al. Antidepressant medication and executive dysfunction: a deleterious interaction in late-life depression. Am J Geriatr Psychiatry. 2010;18(2):128-35. [pmid: 20104069].
148 Sneed JR, Keilp JG, Brickman AM, et al. The specificity of neuropsychological impairment in predicting antidepressant non-response in the very old depressed. Int J Geriatr Psychiatry. Mar. 2008;23(3):319-23. [pmid: 17726720].
149 Sneed JR, Roose SP, Keilp JG, et al. Response inhibition predicts poor antidepressant treatment response in very old depressed patients. Am J Geriatr Psychiatry. Jul. 2007;15(7):553-63. [pmid: 17586780].
150 Solomon DA, Leon AC, Mueller TI, et al. Tachyphylaxis in unipolar major depressive disorder. J Clin Psychiatry. 2005;66(3):283-90. [pmid: 15766292].
151 Spalletta G, Ripa A, Bria P, et al. Response of emotional unawareness after stroke to antidepressant treatment. Am J Geriatr Psychiatry. Mar. 2006;14(3):220-7. [pmid: 16505126].
152 Sramek JJ, Kashkin K, Jasinsky O, et al. Placebo-controlled study of ABT-200 versus fluoxetine in the treatment of major depressive disorder. Depression. 1995;3(4):199-203.
153 Tadic A, Muller MJ, Rujescu D, et al. The MAOA T941G polymorphism and short-term treatment response to mirtazapine and paroxetine in major depression. Am J Med Genet B Neuropsychiatr Genet. Apr. 5. 2007;144B(3):325-31. [pmid: 17192957].
154 Targownik LE, Bolton JM, Metge CJ, et al. Selective serotonin reuptake inhibitors are associated with a modest increase in the risk of upper gastrointestinal bleeding. Am J Gastroenterol. Jun. 2009;104(6):1475-82. [pmid: 19491861].
155 Taylor MJ, Freemantle N, Geddes JR, et al. Early onset of selective serotonin reuptake inhibitor antidepressant action: Systematic review and meta-analysis. Arch Gen Psychiatry. 2006;63(11):1217-23. [pmid: 17088502].
156 Thase ME, Corya SA, Osuntokun O, et al. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, and fluoxetine in treatment-resistant major depressive disorder. J Clin Psychiatry. Feb. 2007;68(2):224-36. [pmid: 17335320].
157 Thase ME, Haight BR, Richard N, et al. Remission rates following antidepressant therapy with bupropion or selective serotonin reuptake inhibitors: A meta-analysis of original data from 7 randomized controlled trials. Journal of Clinical Psychiatry. 2005;66(8):974-81. [pmid: 16086611].
158 Thase ME, Shelton RC, Khan A. Treatment with venlafaxine extended release after SSRI nonresponse or intolerance: a randomized comparison of standard- and higher-dosing strategies. J Clin Psychopharmacol. Jun. 2006;26(3):250-8. [pmid: 16702889].
159 Trifirò G, Dieleman J, Sen EF, et al. Risk of ischemic stroke associated with antidepressant drug use in elderly persons. J Clin Psychopharmacol. 2010;30(3):252-8. [pmid: 20473059].
160 Trivedi MH, Corey-Lisle PK, Guo Z, et al. Remission, response without remission, and nonresponse in major depressive disorder: impact on functioning. Int Clin Psychopharmacol. May. 2009;24(3):133-8. [pmid: 19318972].
161 Trivedi MH, Pigotti TA, Perera P, et al. Effectiveness of low doses of paroxetine controlled release in the treatment of major depressive disorder. J Clin Psychiatry. Oct. 2004;65(10):1356-64. [pmid: 15491239].
162 Trivedi MH, Rush AJ, Wisniewski SR, et al. Factors associated with health-related quality of life among outpatients with major depressive disorder: A STAR*D report. J Clin Psychiatry. 2006;67(2):185-95. [pmid: 16566612].
163 Trivedi MH, Thase ME, Osuntokun O, et al. An integrated analysis of olanzapine/fluoxetine combination in clinical trials of treatment-resistant depression. J Clin Psychiatry. Mar. 2009;70(3):387-96. [pmid: 19284928].
164 Vazquez MJ, Carretero Quevedo B. Pneumonitis related to venlafaxine. Psychosomatics. Jan-Feb. 2008;49(1):84-5. [pmid: 18212183].
165 Vis PM, van Baardewijk M, Einarson TR. Duloxetine and venlafaxine-XR in the treatment of major depressive disorder: a meta-analysis of randomized clinical trials. Ann Pharmacother. 2005;39(11):1798-807. [pmid: 16189284].
166 Wade A, Despiegel N, Heldbo Reines E. Escitalopram in the long-term treatment of major depressive disorder. Ann Clin Psychiatry. Apr-Jun. 2006;18(2):83-9. [pmid: 16754413].
167 Wade A, Michael Lemming O, Bang Hedegaard K. Escitalopram 10 mg/day is effective and well tolerated in a placebo-controlled study in depression in primary care. Int Clin Psychopharmacol. May. 2002;17(3):95-102. [pmid: 11981349].
168 Walczak DD, Apter JT, Halikas JA, et al. The oral dose-effect relationship for fluvoxamine: a fixed-dose comparison against placebo in depressed outpatients. Ann Clin Psychiatry. Sep. 1996;8(3):139-51. [pmid: 8899132].
169 Watanabe N, Barbui C, Churchill R, et al. Mirtazapine versus other anti-depressive agents for depression (Protocol). Cochrane Database of Systematic Reviews. 2006;(3).
170 Winokur A, Baker RA, Simmons J, et al. Comparative sleep improving effects of mirtazapine vs SSRIs in depressed patients: A meta-analysis of individual patient data. 8th World Congress of the World Federation of Societies of Biological Psychiatry. Vienna, Austria. World J Biol Psychiatry. 2005:S1366-7.
171 Yasui-Furukori N, Kaneko S. Digitalis intoxication induced by paroxetine coadministration. Lancet. Mar. 4. 2006;367(9512):788. [pmid: 16517279].
172 Ziere G, Dieleman JP, Van Der Cammen TJM, et al. Selective serotonin reuptake inhibiting antidepressants are associated with an increased risk of nonvertebral fractures. J Clin Psychopharmacol. 2008;28(4):411-7. [pmid: 18626268].

## Poor Quality(77)

1 Aguglia E, Casacchia M, Cassano GB, et al. Double-blind study of the efficacy and safety of sertraline versus fluoxetine in major depression. Int Clin Psychopharmacol. Fall. 1993;8(3):197-202. [pmid: 8263318].
2 Amini H, Aghayan S, Jalili SA, et al. Comparison of mirtazapine and fluoxetine in the treatment of major depressive disorder: a double-blind, randomized trial. J Clin Pharm Ther. Apr. 2005;30(2):133-8. [pmid: 15811165].
3 Ashman TA, Cantor JB, Gordon WA, et al. A randomized controlled trial of sertraline for the treatment of depression in persons with traumatic brain injury. Arch Phys Med Rehabil. 2009;90(5):733-40. [pmid: 19406291].
4 Beasley CM Jr, Dornseif BE, Bosomworth JC, et al. Fluoxetine and suicide: a meta-analysis of controlled trials of treatment for depression. Bmj. Sep. 21. 1991;303(6804):685-92. [pmid: 1833012].
5 Brown ES, Vigil L, Khan DA, et al. A randomized trial of citalopram versus placebo in outpatients with asthma and major depressive disorder: a proof of concept study. Biol Psychiatry. Dec. 1. 2005;58(11):865-70. [pmid: 15993860].
6 Byerley WF, Reimherr FW, Wood DR, et al. Fluoxetine, a selective serotonin uptake inhibitor, for the treatment of outpatients with major depression. J Clin Psychopharmacol. Apr. 1988;8(2):112-5. [pmid: 3286684].
7 Claghorn JL. The safety and efficacy of paroxetine compared with placebo in a double-blind trial of depressed outpatients. J Clin Psychiatry. Feb. 1992;53(Suppl):33-5. [pmid: 1531821].
8 Claghorn JL, Earl CQ, Walczak DD, et al. Fluvoxamine maleate in the treatment of depression: a single-center, double-blind, placebo-controlled comparison with imipramine in outpatients. J Clin Psychopharmacol. Apr. 1996;16(2):113-20. [pmid: 8690826].
9 Claghorn JL, Lesem MD. A double-blind placebo-controlled study of Org 3770 in depressed outpatients. J Affect Disord. Jun. 8. 1995;34(3):165-71. [pmid: 7560544].
10 Clerc GE, Ruimy P, Verdeau-Palles J. A double-blind comparison of venlafaxine and fluoxetine in patients hospitalized for major depression and melancholia. The Venlafaxine French Inpatient Study Group. Int Clin Psychopharmacol. Sep. 1994;9(3):139-43. [pmid: 7814822].
11 Cohn JB, Crowder JE, Wilcox CS, et al. A placebo- and imipramine-controlled study of paroxetine. Psychopharmacol Bull. 1990;26(2):185-9. [pmid: 2146697].
12 Cohn JB, Wilcox CS. Paroxetine in major depression: a double-blind trial with imipramine and placebo. J Clin Psychiatry. Feb. 1992;53(Suppl):52-6. [pmid: 1531826].
13 Corrigan MH, Denahan AQ, Wright CE, et al. Comparison of pramipexole, fluoxetine, and placebo in patients with major depression. Depress Anxiety. 2000;11(2):58-65. [pmid: 10812530].
14 Croft H, Houser TL, Jamerson BD, et al. Effect on body weight of bupropion sustained-release in patients with major depression treated for 52 weeks. Clin Ther. Apr. 2002;24(4):662-72. [pmid: 12017410].
15 Dube S, Dellva MA, Jones M, et al. A study of the effects of LY2216684, a selective norepinephrine reuptake inhibitor, in the treatment of major depression. J Psychiatr Res. 2010;44(6):356-63. [pmid: 19909980].
16 Dunbar GC, Claghorn JL, Kiev A, et al. A comparison of paroxetine and placebo in depressed outpatients. Acta Psychiatr Scand. May. 1993;87(5):302-5. [pmid: 8517168].
17 Dunbar GC, Cohn JB, Fabre LF, et al. A comparison of paroxetine, imipramine and placebo in depressed out-patients. Br J Psychiatry. Sep. 1991;159:394-8. [pmid: 1835664].
18 Elliott AJ, Uldall KK, Bergam K, et al. Randomized, placebo-controlled trial of paroxetine versus imipramine in depressed HIV-positive outpatients. Am J Psychiatry. Mar. 1998;155(3):367-72. [pmid: 9501747].
19 Evans M, Hammond M, Wilson K, et al. Placebo-controlled treatment trial of depression in elderly physically ill patients. Int J Geriatr Psychiatry. Aug. 1997;12(8):817-24. [pmid: 9283926].
20 Fabre L, Birkhimer LJ, Zaborny BA, et al. Fluvoxamine versus imipramine and placebo: a double-blind comparison in depressed patients. Int Clin Psychopharmacol. Jun. 1996;11(2):119-27. [pmid: 8803649].
21 Fabre LF. A 6-week, double-blind trial of paroxetine, imipramine, and placebo in depressed outpatients. J Clin Psychiatry. Feb. 1992;53(Suppl):40-3. [pmid: 1531823].
22 Fabre LF, Abuzzahab FS, Amin M, et al. Sertraline safety and efficacy in major depression: a double-blind fixed-dose comparison with placebo. Biol Psychiatry. Nov. 1. 1995;38(9):592-602. [pmid: 8573661].
23 Fabre LF, Putman HP 3rd. A fixed-dose clinical trial of fluoxetine in outpatients with major depression. J Clin Psychiatry. Oct. 1987;48(10):406-8. [pmid: 3312176].
24 Falk WE, Rosenbaum JF, Otto MW, et al. Fluoxetine versus trazodone in depressed geriatric patients. J Geriatr Psychiatry Neurol. Oct-Dec. 1989;2(4):208-14. [pmid: 2699556].
25 Fava M, Alpert J, Nierenberg AA, et al. A Double-blind, randomized trial of St John's wort, fluoxetine, and placebo in major depressive disorder. J Clin Psychopharmacol. Oct. 2005;25(5):441-7. [pmid: 16160619].
26 Fava M, Mulroy R, Alpert J, et al. Emergence of adverse events following discontinuation of treatment with extended-release venlafaxine. Am J Psychiatry. Dec. 1997;154(12):1760-2. [pmid: 9396960].
27 Feighner J, Targum SD, Bennett ME, et al. A double-blind, placebo-controlled trial of nefazodone in the treatment of patients hospitalized for major depression. J Clin Psychiatry. May. 1998;59(5):246-53. [pmid: 9632036].
28 Feighner JP. A double-blind comparison of paroxetine, imipramine and placebo in depressed outpatients. Int Clin Psychopharmacol. Jun. Suppl 4. 1992;6:31-5. [pmid: 1431008].
29 Feighner JP, Boyer WF. Paroxetine in the treatment of depression: a comparison with imipramine and placebo. J Clin Psychiatry. Feb. 1992;53(Suppl):44-7. [pmid: 1531824].
30 Feighner JP, Cohn JB, Fabre LF Jr, et al. A study comparing paroxetine placebo and imipramine in depressed patients. J Affect Disord. Jun. 1993;28(2):71-9. [pmid: 8354771].
31 Ferrando SJ, Goldman JD, Charness WE. Selective serotonin reuptake inhibitor treatment of depression in symptomatic HIV infection and AIDS. Improvements in affective and somatic symptoms. Gen Hosp Psychiatry. Mar. 1997;19(2):89-97. [pmid: 9097063].
32 Flament MF, Lane R. Acute antidepressant response to fluoxetine and sertraline in psychiatric outpatients with psychomotor agitation. International Journal of Psychiatry in Clinical Practice. 2001;5(2):103-9.
33 Garakani A, Martinez JM, Marcus S, et al. A randomized, double-blind, and placebo-controlled trial of quetiapine augmentation of fluoxetine in major depressive disorder. Int Clin Psychopharmacol. 2008;23(5):269-75. [pmid: 18703936].
34 Gastpar M, Singer A, Zeller K. Comparative efficacy and safety of a once-daily dosage of hypericum extract STW3-VI and citalopram in patients with moderate depression: a double-blind, randomised, multicentre, placebo-controlled study. Pharmacopsychiatry. 2006;39(2):66-75. [pmid: 16555167].
35 Goldstein DJ, Lu Y, Detke MJ, et al. Duloxetine in the treatment of depression: a double-blind placebo-controlled comparison with paroxetine. J Clin Psychopharmacol. Aug. 2004;24(4):389-99. [pmid: 15232330].
36 Grigoriadis S, Kennedy SH, Bagby RM. A comparison of antidepressant response in younger and older women. J Clin Psychopharmacol. Aug. 2003;23(4):405-7. [pmid: 12920418].
37 Gulseren L, Gulseren S, Hekimsoy Z, et al. Comparison of fluoxetine and paroxetine in type II diabetes mellitus patients. Arch Med Res. Mar-Apr. 2005;36(2):159-65. [pmid: 15847950].
38 Hegerl U, Hautzinger M, Mergl R, et al. Effects of pharmacotherapy and psychotherapy in depressed primary-care patients: A randomized, controlled trial including a patients' choice arm. International Journal of Neuropsychopharmacology. 2010;13(1):31-44. [pmid: 19341510].
39 Kasper S, Montgomery SA, Moller HJ, et al. Longitudinal analysis of the suicidal behaviour risk in short-term placebo-controlled studies of mirtazapine in major depressive disorder. World J Biol Psychiatry. 2010;11(1):36-44. [pmid: 20146649].
40 Lapierre YD, Browne M, Horn E, et al. Treatment of major affective disorder with fluvoxamine. J Clin Psychiatry. Feb. 1987;48(2):65-8. [pmid: 3100510].
41 March JS, Kobak KA, Jefferson JW, et al. A double-blind, placebo-controlled trial of fluvoxamine versus imipramine in outpatients with major depression. J Clin Psychiatry. May. 1990;51(5):200-2. [pmid: 2110560].
42 McGrath PJ, Stewart JW, Janal MN, et al. A placebo-controlled study of fluoxetine versus imipramine in the acute treatment of atypical depression. Am J Psychiatry. Mar. 2000;157(3):344-50. [pmid: 10698808].
43 Mesters P, Cosyns P, Dejaiffe G, et al. Assessment of quality of life in the treatment of major depressive disorder with fluoxetine, 20 mg, in ambulatory patients aged over 60 years. Int Clin Psychopharmacol. Winter. 1993;8(4):337-40. [pmid: 8277160].
44 Montgomery SA, Baldwin DS, Blier P, et al. Which antidepressants have demonstrated superior efficacy? A review of the evidence. International Clinical Psychopharmacology. 2007;22(6):323-9. [pmid: 17917550].
45 Montgomery SA, Baldwin DS, Blier P, et al. Which antidepressants have demonstrated superior efficacy? A review of the evidence: Erratum. International Clinical Psychopharmacology. 2008;23(1):61.
46 Muijen M, Roy D, Silverstone T, et al. A comparative clinical trial of fluoxetine, mianserin and placebo in depressed outpatients. Acta Psychiatr Scand. Sep. 1988;78(3):384-90. [pmid: 3057817].
47 Nyth AL, Gottfries CG, Lyby K, et al. A controlled multicenter clinical study of citalopram and placebo in elderly depressed patients with and without concomitant dementia. Acta Psychiatr Scand. Aug. 1992;86(2):138-45. [pmid: 1529737].
48 Oslin DW, Ten Have TR, Streim JE, et al. Probing the safety of medications in the frail elderly: evidence from a randomized clinical trial of sertraline and venlafaxine in depressed nursing home residents. J Clin Psychiatry. Aug. 2003;64(8):875-82. [pmid: 12927001].
49 Petracca GM, Chemerinski E, Starkstein SE. A double-blind, placebo-controlled study of fluoxetine in depressed patients with Alzheimer's disease. Int Psychogeriatr. Jun. 2001;13(2):233-40. [pmid: 11495397].
50 Pettinati HM, Oslin DW, Kampman KM, et al. A double-blind, placebo-controlled trial combining sertraline and naltrexone for treating co-occurring depression and alcohol dependence. Am J Psychiatry. 2010;167(6):668-75. [pmid: 20231324].
51 Ravindran AV, Teehan MD, Bakish D, et al. The impact of sertraline, desipramine, and placebo on psychomotor functioning in depression. Hum Psychopharmacol. 1995;10(4):273-81.
52 Reimherr FW, Cunningham LA, Batey SR, et al. A multicenter evaluation of the efficacy and safety of 150 and 300 mg/d sustained-release bupropion tablets versus placebo in depressed outpatients. Clin Ther. May-Jun. 1998;20(3):505-16. [pmid: 9663366].
53 Rickels K, Amsterdam J, Clary C, et al. The efficacy and safety of paroxetine compared with placebo in outpatients with major depression. J Clin Psychiatry. Feb. 1992;53(Suppl):30-2. [pmid: 1531820].
54 Rickels K, Case WG. Trazodone in depressed outpatients. Am J Psychiatry. Jun. 1982;139(6):803-6. [pmid: 7044154].
55 Rickels K, Schweizer E, Clary C, et al. Nefazodone and imipramine in major depression: a placebo-controlled trial. Br J Psychiatry. Jun. 1994;164(6):802-5. [pmid: 7952987].
56 Roscoe JA, Morrow GR, Hickok JT, et al. Effect of paroxetine hydrochloride (Paxil) on fatigue and depression in breast cancer patients receiving chemotherapy. Breast Cancer Res Treat. Feb. 2005;89(3):243-9. [pmid: 15754122].
57 Rosenbaum JF, Fava M, Hoog SL, et al. Selective serotonin reuptake inhibitor discontinuation syndrome: a randomized clinical trial. Biol Psychiatry. Jul. 15. 1998;44(2):77-87. [pmid: 9646889].
58 Roth D, Mattes J, Sheehan KH, et al. A double-blind comparison of fluvoxamine, desipramine and placebo in outpatients with depression. Prog Neuropsychopharmacol Biol Psychiatry. 1990;14(6):929-39. [pmid: 2126144].
59 Roy-Byrne PP, Pages KP, Russo JE, et al. Nefazodone treatment of major depression in alcohol-dependent patients: a double-blind, placebo-controlled trial. J Clin Psychopharmacol. Apr. 2000;20(2):129-36. [pmid: 10770449].
60 Rudolph RL, Fabre LF, Feighner JP, et al. A randomized, placebo-controlled, dose-response trial of venlafaxine hydrochloride in the treatment of major depression. J Clin Psychiatry. Mar. 1998;59(3):116-22. [pmid: 9541154].
61 Schmitz JM, Averill P, Stotts AL, et al. Fluoxetine treatment of cocaine-dependent patients with major depressive disorder. Drug Alcohol Depend. Aug. 1. 2001;63(3):207-14. [pmid: 11418225].
62 Schweizer E, Weise C, Clary C, et al. Placebo-controlled trial of venlafaxine for the treatment of major depression. J Clin Psychopharmacol. Aug. 1991;11(4):233-6. [pmid: 1918421].
63 Smith WT, Glaudin V. A placebo-controlled trial of paroxetine in the treatment of major depression. J Clin Psychiatry. Feb. 1992;53(Suppl):36-9. [pmid: 1531822].
64 Smith WT, Glaudin V, Panagides J, et al. Mirtazapine vs. amitriptyline vs. placebo in the treatment of major depressive disorder. Psychopharmacol Bull. 1990;26(2):191-6. [pmid: 2236455].
65 Spielmans GI. Duloxetine does not relieve painful physical symptoms in depression: a meta-analysis. Psychother Psychosom. 2008;77(1):12-6. [pmid: 18087203].
66 Stahl SM. Placebo-controlled comparison of the selective serotonin reuptake inhibitors citalopram and sertraline. Biol Psychiatry. Nov. 1. 2000;48(9):894-901. [pmid: 11074227].
67 Thase ME, Clayton AH, Haight BR, et al. A double-blind comparison between bupropion XL and venlafaxine XR: sexual functioning, antidepressant efficacy, and tolerability. J Clin Psychopharmacol. 2006;26(5):482-8. [pmid: 16974189].
68 Thase ME, Entsuah AR, Rudolph RL. Remission rates during treatment with venlafaxine or selective serotonin reuptake inhibitors. Br J Psychiatry. Mar. 2001;178:234-41. [pmid: 11230034].
69 Tollefson GD, Rampey AH Jr, Beasley CM Jr, et al. Absence of a relationship between adverse events and suicidality during pharmacotherapy for depression. J Clin Psychopharmacol. Jun. 1994;14(3):163-9. [pmid: 8027412].
70 Trkulja V. Is escitalopram really relevantly superior to citalopram in treatment of major depressive disorder? A meta-analysis of head-to-head randomized trials. Croat Med J. 2010;51(1):61-73. [pmid: 20162747].
71 Vartiainen H, Leinonen E. Double-blind study of mirtazapine and placebo in hospitalized patients with major depression. Eur Neuropsychopharmacol. Jun. 1994;4(2):145-50. [pmid: 7919944].
72 Wade A, Crawford GM, Angus M, et al. A randomized, double-blind, 24-week study comparing the efficacy and tolerability of mirtazapine and paroxetine in depressed patients in primary care. Int Clin Psychopharmacol. May. 2003;18(3):133-41. [pmid: 12702891].
73 Wagner GJ, Maguen S, Rabkin JG. Ethnic differences in response to fluoxetine in a controlled trial with depressed HIV-positive patients. Psychiatr Serv. Feb. 1998;49(2):239-40. [pmid: 9575014].
74 Weintraub D, Rosenberg PB, Drye LT, et al. Sertraline for the treatment of depression in alzheimer disease: Week-24 outcomes. American Journal of Geriatric Psychiatry. 2010;18(4):332-40. [pmid: 20220589].
75 Wernicke JF, Dunlop SR, Dornseif BE, et al. Fixed-dose fluoxetine therapy for depression. Psychopharmacol Bull. 1987;23(1):164-8. [pmid: 3496625].
76 Winokur A, DeMartinis NA 3rd, McNally DP, et al. Comparative effects of mirtazapine and fluoxetine on sleep physiology measures in patients with major depression and insomnia. J Clin Psychiatry. Oct. 2003;64(10):1224-9. [pmid: 14658972].
77 Zanardi R, Franchini L, Gasperini M, et al. Double-blind controlled trial of sertraline versus paroxetine in the treatment of delusional depression. Am J Psychiatry. Dec. 1996;153(12):1631-3. [pmid: 8942464].