# Search Strategy

## PubMed Search as Reported in 2007 Report

#16 Search “Antidepressive Agents, Second-Generation”[MeSH] OR “Fluoxetine”[MeSH] OR “Sertraline”[MeSH] OR “Paroxetine”[MeSH] OR “Citalopram”[MeSH] OR “Fluvoxamine”[MeSH] OR “Bupropion”[MeSH] OR “nefazodone”[Substance Name] OR “mirtazapine”[Substance Name] OR “venlafaxine”[Substance Name] OR “escitalopram” [tw] OR “duloxetine”[Substance Name] OR “Trazodone”[MeSH] =13604
#22 Search (“Depressive Disorder”[MeSH] OR “Depressive Disorder, Major”[MeSH]) OR “depression, involutional” [tw] OR “Dysthymic Disorder”[MeSH]OR “subsyndronal depressive disorder” [tw] 47030
#23 Search #16 AND #22 = 4043
#24 Search #16 AND #22 Field: All Fields, Limits: All Adult: 19+ years, English, Humans = 2783
#29 Search (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials”[MeSH]) OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] = 292497
#30 Search #24 AND #29 = 1056
#35 Search #24 NOT #30 Field: All Fields = 1727
#38 Search “Quality of Life”[MeSH] OR “Hospitalization”[MeSH] = 137196
#39 Search #35 AND #38 = 43

### Adverse Events

#42 Search “adverse events” [tw] OR “drug hypersensitivity” [mh] OR “drug toxicity” [mh] OR hyponatremia [mh] OR seizures [mh] OR suicide [mh] OR “weight gain” [mh] OR “gastroesophogeal reflux” [mh] OR libido [mh] OR hepatoxicity [tw] = 124762

### Longitudinal Studies

#44 Search longitudinal studies [mh] OR cohort studies [mh] OR case-control studies [mh] OR comparative study [mh] OR “observational studies” [tw] = 1819544
#45 Search #35 AND #42 = 226
#46 Search #35 AND #44 = 371

### Drug Interactions

#47 Search drug interactions [mh] = 103115
#48 Search #35 AND #47 = 144
#51 Search “Recurrence”[MeSH] OR remission [tw] OR relapse [tw] = 193920
#52 Search #35 AND #51 = 173
  Similar Search Strategy in EMBASE = 133

Total Database = 1922

## PubMed Search (September 4, 2010)

Search | Most Recent Queries | Result
#1 | Search “Antidepressive Agents, Second-Generation”[MeSH] OR “Fluoxetine”[MeSH] OR “Sertraline”[MeSH] OR “Paroxetine”[MeSH] OR “Citalopram”[MeSH] OR “Fluvoxamine”[MeSH] OR “Bupropion”[MeSH] OR “nefazodone”[Substance Name] OR “mirtazapine”[Substance Name] OR “venlafaxine”[Substance Name] OR “escitalopram” [tw] OR “duloxetine”[Substance Name] OR “Trazodone”[MeSH] | 18899
#13 | Search “Antidepressive Agents, Second-Generation”[MeSH] OR “Fluoxetine”[MeSH] OR “Sertraline”[MeSH] OR “Paroxetine”[MeSH] OR “Citalopram”[MeSH] OR “Fluvoxamine”[MeSH] OR “Bupropion”[MeSH] OR “nefazodone”[Substance Name] OR “mirtazapine”[Substance Name] OR “venlafaxine”[Substance Name] OR “escitalopram” [tw] OR “duloxetine”[Substance Name] OR “Trazodone”[MeSH] Limits: Entrez Date from 2005/01/01, Humans, English, All Adult: 19+ years | 2640
#14 | Search “O-desmethylvenlafaxine “[Substance Name] OR desvenlafaxine | 96
#15 | Search “O-desmethylvenlafaxine “[Substance Name] OR desvenlafaxine Limits: Humans, English, All Adult: 19+ years | 37
#16 | Search #15 OR #13 | 2666
#17 | Search (“Depressive Disorder”[MeSH] OR “Depressive Disorder, Major”[MeSH]) OR “depression, involutional” [tw] OR “Dysthymic Disorder”[MeSH]OR “subsyndronal depressive disorder” [tw] | 61592
#18 | Search #16 AND #17 | 1028
#19 | Search (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials”[MeSH]) OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] | 345509
#20 | Search #19 AND #18 | 404
#21 | Search “Quality of Life”[MeSH] OR “Hospitalization”[MeSH] | 191076
#22 | Search #21 AND #18 | 52
#23 | Search “adverse events”[tw] OR “drug hypersensitivity”[MeSH] OR “drug toxicity”[MeSH] OR “hyponatremia”[MeSH] OR “seizures”[MeSH] OR “suicide”[MeSH] OR “weight gain”[MeSH] OR “gastroesophogeal reflux”[MeSH] OR “libido”[MeSH] OR “hepatoxicity”[tw] | 176101
#24 | Search #18 AND #23 | 222
#25 | Search “longitudinal studies”[MeSH] OR “cohort studies”[MeSH] OR “case-control studies”[MeSH] OR “comparative study”[MeSH] OR “observational studies” [tw] | 1055406
#26 | Search “Comparative Study”[Publication Type] | 1433347
#27 | Search #26 OR #25 | 2290232
#28 | Search #18 AND #27 | 398
#29 | Search “drug interactions”[MeSH] | 120577
#30 | Search #18 AND #29 | 46
#31 | Search “Recurrence”[MeSH] OR “remission”[tw] OR “relapse”[tw] | 241942
#32 | Search #31 AND #18 | 274
#33 | Search #32 OR #30 OR #28 OR #24 OR #22 OR #20 | 747

Analogous terms were used to search the Cochrane Library, EMBASE, International Pharmaceutical Abstracts (IPA), and PscyINFO.

## PubMed Immediate-release and Extended-release Search (March 17, 2010)

Search | Most Recent Queries | Result
#13 | Search “Antidepressive Agents, Second-Generation”[MeSH] OR “Fluoxetine”[MeSH] OR “Sertraline”[MeSH] OR “Paroxetine”[MeSH] OR “Citalopram”[MeSH] OR “Fluvoxamine”[MeSH] OR “Bupropion”[MeSH] OR “nefazodone”[Substance Name] OR “mirtazapine”[Substance Name] OR “venlafaxine”[Substance Name] OR “escitalopram” [tw] OR “duloxetine”[Substance Name] OR “Trazodone”[MeSH] OR “O-desmethylvenlafaxine “[Substance Name] OR desvenlafaxine | 19556
#14 | Search (“Depressive Disorder”[MeSH] OR “Depressive Disorder, Major”[MeSH]) OR “involutional depression” OR “Dysthymic Disorder”[MeSH] OR “subsyndromal depression” OR Depressive Disorder, Major/drug therapy* | 63657
#15 | Search #13 AND #14 | 5681
#16 | Search orally disintegrating | 208
#17 | Search controlled release | 25169
#18 | Search extended release | 5473
#19 | Search sustained release | 15592
#20 | Search immediate release | 6982
#21 | Search #16 OR #17 OR #18 OR #19 OR #20 | 46338
#22 | Search SR OR XL OR XR OR CR | 73038
#23 | Search #21 OR #22 | 117320
#24 | Search #23 AND #15 | 269
#25 | Search “Metabolic Clearance Rate”[Mesh] | 19468
#26 | Search “Half-Life”[Mesh] | 32669
#27 | Search #25 OR #26 | 49118
#28 | Search #15 AND #27 | 79
#29 | Search #24 OR #28 | 342
#30 | Search #29 Limits: Humans, English | 324
#44 | Select 4 document(s) | 4
#47 | Search #30 Limits: All Infant: birth-23 months, All Child: 0-18 years, Newborn: birth-1 month, Infant: 1-23 months, Preschool Child: 2-5 years, Child: 6-12 years, Adolescent: 13-18 years | 64
#48 | Search #30 NOT #47 | 260
#49 | Search #48 Limits: Editorial, Letter, Case Reports | 27
#50 | Search #48 NOT #49 Sort by: PublicationDate | 233

## PubMed Search (January 13, 2011)

Search | Most Recent Queries | Result
#1 | Search “Antidepressive Agents, Second-Generation”[MeSH] OR “Fluoxetine”[MeSH] OR “Sertraline”[MeSH] OR “Paroxetine”[Me0SH] OR “Citalopram”[MeSH] OR “Fluvoxamine”[MeSH] OR “Bupropion”[MeSH] OR “nefazodone”[Substance Name] OR “mirtazapine”[Substance Name] OR “venlafaxine”[Substance Name] OR “escitalopram”[tw] OR “duloxetine”[Substance Name] OR “Trazodone”[MeSH] OR “O-desmethylvenlafaxine”[Substance Name] OR desvenlafaxine | 20568
#2 | Search “Depressive Disorder”[MeSH] OR “Depressive Disorder, Major”[MeSH] OR “Dysthymic Disorder”[MeSH] OR (“depression”[tiab] AND “involutional”[tiab]) OR (“subsyndromal”[tiab] AND “depressive disorder”[tiab]) | 66867
#3 | Search #1 AND #2 | 5936
#4 | Search (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[MeSH]) OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR “Randomized Controlled Trial”[tiab] | 439856
#5 | Search #3 AND #4 | 2024
#6 | Search “longitudinal studies”[MeSH] OR “cohort studies”[MeSH] OR “case-control studies”[MeSH] OR “Comparative Study”[Publication Type] OR observational stud* | 2447452
#7 | Search #3 AND #6 | 1955
#8 | Search (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR (“review”[Publication Type] AND “systematic”[tiab]) OR (“systematic review”[All Fields]) | 37806
#9 | Search #3 AND #8 | 46
#10 | Search “Quality of Life”[MeSH] OR “Hospitalization”[MeSH] | 210665
#11 | Search #3 AND #10 | 245
#12 | Search adverse event* OR “drug hypersensitivity”[MeSH] OR “drug toxicity”[MeSH] OR “hyponatremia”[MeSH] OR “seizures”[MeSH] OR “suicide”[MeSH] OR “weight gain”[MeSH] OR “Gastroesophageal Reflux”[Mesh] OR “libido”[MeSH] OR “hepatoxicity”[tw] | 215756
#13 | Search #3 AND #12 | 1040
#14 | Search “drug interactions”[MeSH] | 125761
#15 | Search #3 AND #14 | 348
#16 | Search “Recurrence”[MeSH] OR “remission”[tiab] OR “relapse”[tiab] | 237282
#17 | Search #3 AND #16 | 987
#18 | Search #5 OR #7 OR #9 OR #11 OR #13 OR #15 OR #17 | 3845
#19 | Search #18 Limits: Humans, All Adult: 19+ years | 2917
#20 | Search #19 Limits: Editorial, Letter, Case Reports | 503
#21 | Search #19 NOT #20 | 2414

## Cochrane Search (January 12, 2011)

ID | Search | Hits
#1 | “Antidepressive Agents, Second-Generation”[MeSH] OR “Fluoxetine”[MeSH] OR “Sertraline”[MeSH] OR “Paroxetine”[MeSH] OR “Citalopram”[MeSH] OR “Fluvoxamine”[MeSH] OR “Bupropion”[MeSH] OR “nefazodone” OR “mirtazapine” OR “venlafaxine” OR “escitalopram” OR “du | 8196
#2 | “Depressive Disorder”[MeSH] | 7012
#3 | “Depressive Disorder, Major”[MeSH] | 1717
#4 | “Dysthymic Disorder”[MeSH] | 251
#5 | (depression AND involutional) | 35
#6 | (subsyndromal AND depressive disorder) | 49
#7 | (#2 OR #3 OR #4 OR #5 OR #6) | 7132
#8 | (#1 AND #7) | 2360
#9 | “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[MeSH] | 315860
#10 | “Single-Blind Method”[MeSH] | 10659
#11 | “Double-Blind Method”[MeSH] | 93996
#12 | “Random Allocation”[MeSH] | 24861
#13 | (Randomized Controlled Trial*) | 373183
#14 | (#9 OR #10 OR #11 OR #12 OR #13) | 387219
#15 | (#8 AND #14) | 2008
#16 | “Quality of Life”[MeSH] OR “Hospitalization”[MeSH] | 34854
#17 | (#8 AND #16) | 296
#18 | (adverse event*) | 32596
#19 | “drug hypersensitivity”[MeSH] OR “drug toxicity”[MeSH] | 1762
#20 | “hyponatremia”[MeSH] | 249
#21 | “seizures”[MeSH] OR “suicide”[MeSH] OR “weight gain”[MeSH] OR “Gastroesophageal Reflux”[Mesh] OR “libido”[MeSH] OR “hepatoxicity”[tw] | 9716
#22 | (#18 OR #19 OR #20 OR #21) | 42004
#23 | (#8 AND #22) | 584
#24 | “longitudinal studies”[MeSH] OR “cohort studies”[MeSH] OR “case-control studies”[MeSH] OR “Comparative Study”[Publication Type] OR (observational studies[All Fields] OR observational study[All Fields]) | 147846
#25 | (#8 AND #24) | 939
#26 | “drug interactions”[MeSH] | 4758
#27 | (#8 AND #26) | 33
#28 | “Recurrence”[MeSH] OR “remission”[tiab] OR “relapse”[tiab] | 32620
#29 | (#8 AND #28) | 629
#30 | (#15 OR #17 OR #23 OR #25 OR #27 OR #29) | 2155
#31 | “adult”[MeSH Terms] OR “adult”[All Fields] OR “adults”[All Fields] | 271482
#32 | “humans”[MeSH Terms] OR “humans”[All Fields] OR “human”[All Fields] | 466240
#33 | (#30 AND #31 AND #32) | 1470
#34 | (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] | 25330
#35 | (#8 AND #34) | 199
#36 | (#30 OR #35) | 2161
#37 | (#36 AND #31 AND #32) | 1472
#38 | (#37), from 2005 to 2011 | 542

## IPA & PsycINFO Search (January 12, 2011)

ID# | SEARCH TERMS | RESULTS
1 | DE “Antidepressant Drugs” OR DE “Bupropion” OR DE “Citalopram” OR DE “Fluoxetine” OR DE “Fluvoxamine” OR DE “Nefazodone” OR DE “Paroxetine” OR DE “Serotonin Norepinephrine Reuptake Inhibitors” OR DE “Sertraline” OR DE “Trazodone” OR DE “Tricyclic Antidepressant Drugs” OR DE “Venlafaxine” | 19759
2 | mirtazapine OR escitalopram OR duloxetine OR O-desmethylvenlafaxine OR desvenlafaxine | 2507
3 | S1 or S2 | 21203
4 | MM “Major Depression” OR DE “Dysthymic Disorder” OR DE “Depression (Emotion)” | 77335
5 | depression AND involutional | 243
6 | subsyndromal AND depressive disorder | 101
7 | “Depressive Disorder” | 11625
8 | S4 or S5 or S6 or S7 | 81059
9 | S3 and S8 | 9093
10 | DE “Experimental Design” OR DE “Between Groups Design” OR DE “Clinical Trials” OR DE “Cohort Analysis” OR DE “Followup Studies” OR DE “Longitudinal Studies” OR DE “Prospective Studies” OR DE “Repeated Measures” OR DE “Quantitative Methods” OR DE “Quasi Experimental Methods” OR DE “Sampling (Experimental)” OR DE “Biased Sampling” OR DE “Random Sampling” OR DE “Statistical Analysis” OR DE “Central Tendency Measures” OR DE “Cluster Analysis” OR DE “Confidence Limits (Statistics)” OR DE “Consistency (Measurement)” OR DE “Effect Size (Statistical)” OR DE “Error of Measurement” OR DE “Frequency Distribution” OR DE “Fuzzy Set Theory” OR DE “Goodness of Fit” OR DE “Interaction Analysis (Statistics)” OR DE “Meta Analysis” OR DE “Multivariate Analysis” OR DE “Predictability (Measurement)” OR DE “Statistical Correlation” OR DE “Statistical Data” OR DE “Statistical Estimation” OR DE “Statistical Norms” OR DE “Statistical Probability” OR DE “Statistical Regression” OR DE “Statistical Reliability” OR DE “Statistical Significance” OR DE “Statistical Tests” OR DE “Statistical Validity” OR DE “Statistical Weighting” OR DE “Time Series” OR DE “Variability Measurement” | 88726
11 | “randomized controlled trial” | 6358
12 | S10 or S11 | 94457
13 | S9 and S12 | 468
14 | DE “Quality of Life” OR DE “Quality of Work Life” OR DE “Hospitalization” OR DE “Commitment (Psychiatric)” OR DE “Hospital Admission” OR DE “Hospital Discharge” OR DE “Psychiatric Hospitalization” OR DE “Side Effects (Treatment)” OR DE “Side Effects (Drug)” OR DE “Hyponatremia” OR DE “Seizures” OR DE “Audiogenic Seizures” OR DE “Epileptic Seizures” OR DE “Grand Mal Seizures” OR DE “Petit Mal Seizures” OR DE “Status Epilepticus” OR DE “Suicide” OR DE “Weight Gain” OR “Gastroesophageal Reflux” OR DE “Libido” OR “hepatoxicity” | 76245
15 | S9 and S14 | 1721
16 | DE “Evidence Based Practice” | 6625
17 | S9 and S16 | 29
18 | DE “Drug Interactions” OR DE “Recurrent Depression” OR DE “Relapse (Disorders)” | 10578
19 | S9 and S18 | 452
20 | S13 or S15 or S17 or S19 | 2507
21 | S20 Limiters - Published Date from: 20050101-20110131; Language: English; Articles about Human Studies; Publication Year from: 2005-2011; Publication Type: All Journals; English; Language: English; Age Groups: Adulthood (18 yrs & older); Population Group: Human; Document Type: Journal Article; Exclude Dissertations | 328

After search results across years were combined and duplicates were removed, the EndNote X4 database contained 3,722 references.