# Appendixes

Appendix A Search Strategy

Appendix B Excluded Studies

Appendix C Evidence Tables

Appendix D Poor-Quality Studies

Appendix E Studies Included in Mixed-Treatment Comparisons and Meta-analyses

Appendix F Bibliography of References by Database Searched

Appendix G Strength of Evidence Tables

Appendix H Review and Abstraction Forms