# Acknowledgments

We extend our appreciation to our Technical Expert Panel (TEP): James H. Bray, Ph.D., President of the American Psychological Association; Susan G. Kornstein, M.D., Professor of Psychiatry at the Virginia Commonwealth University; John Santa, M.D. of the American Consumers Union; Gregory Simon, M.D., M.P.H. of Group Health; and John Williams, M.D., primary care physician and former Director of the Duke Evidence-based Practice Center. All provided thoughtful advice and input during our research process.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina. We express our gratitude to Visali Peravali, M.Sc., Tania Wilkins, M.Sc. and Shrikant Bandiwala, Ph.D. for their statistical programming for the indirect comparisons analysis; Tammeka Swinson Evans, Andrea Yuen, Shannon Brode and Audrey Holland, Research Analysts; and Loraine Monroe, our EPC publications specialist.