# Technical Expert Panel

Hayden Bosworth, Ph.D.

Associate Director, Center for Health Services Research in Primary Care

Durham Veterans Affairs Medical Center

Durham, NC

Steven R. Brown, M.D.

Banner Good Samaritan Family Medicine Residency, University of Arizona, Phoenix, AZ

Jonathan P. Curtin, M.D.

Medical Director, Division of Provider Relations and Utilization Management

Office of Health Insurance Programs

New York State Department of Health

Albany, NY

James Figge, M.D., M.B.A.

Medical Director, Division of Provider Relations and Utilization Management

Office of Health Insurance Programs

New York State Department of Health

Albany, NY

Beverly Green, M.D., M.P.H.

Affiliate Investigator, Group Health Research Institute

Family Physician, Group Health Cooperative

Assistant Clinical Professor, University of Washington School of Medicine

Seattle, WA

Lawrence Krakoff, M.D.

Professor of Medicine, Cardiology

Mount Sinai Medical Center

New York, NY

Terry Wall, M.D.

Professor of Pediatrics

University of Alabama at Birmingham School of Medicine

Birmingham, AL

William B. White, M.D.

Professor of Medicine and

Chief, Division of Hypertension and Clinical Pharmacology. Calhoun Cardiology Center

University of Connecticut School of Medicine

Farmington, CT

President-Elect,

American Society of Hypertension

New York, NY