# Summary and Discussion

## Summary

Table 2 summarizes the main findings addressing the five Key Questions of this systematic review. Discussion regarding the report and recommendations for future research follow.

Table 2 Summary of findings of studies addressing Key Questions on self-measured blood pressure monitoring

Key Question | Strength of Evidence | Summary/Conclusions/Comments
Key Question 1: SMBP Alone Versus Usual Care Overall | -- | - Twenty-four studies compared SMBP alone versus usual care (22 RCTs and 2 quasi-RCTs). In total, 5,400 patients with hypertension were included. Four studies were graded quality A; 6, quality B; 13, quality C; and 1 conference abstract was not graded.; - The studies were heterogeneous in terms of the brands and types of SMBP monitors; followup duration (2–36 months); baseline hypertension control (across studies, mean SBP/DBP: 124-167/70-109 mmHg); patient ages (across studies, mean 47–73 years). All patients were adults, most were male, and the most commonly cited comorbid conditions in these studies were type 1 or 2 diabetes, obesity, dyslipidemia, and cardiovascular disease.
Key Question 1: SMBP Alone Versus Usual Care Clinical Outcomes | Insufficient | - No study reported clinical outcomes.; - Conclusion: There is insufficient comparative study evidence regarding clinical outcomes in trials of SMBP versus usual care.
Key Question 1: SMBP Alone Versus Usual Care Blood Pressure | Moderate (favoring SMBP) | - Twenty-three of the 24 studies that compared SMBP alone versus usual care reported BP outcomes (4 quality A, 5 quality B, 13 quality C, and 1 conference abstract that was not graded). See the “Overall” summary above regarding the study heterogeneity.; - Thirteen studies reported categorical changes in BP control, mostly defined as achieving a BP of <130-140/80-90 mmHg (sometimes with lower thresholds for patients with diabetes). Although all but one study found greater rates of achieving BP control with SMBP monitoring, meta-analyses of the subset of trials that examined achieving a BP target found no significant effects at 6- and 12-month followup.; - Twenty-one studies reported continuous BP outcomes. Seventeen studies reported clinic BP outcomes; 5 reported 24-hour ambulatory BP; 6, awake (day) ambulatory BP; and 5, asleep (night) ambulatory BP. In meta-analyses, no significant effect was found at 2 months followup; statistically significant differences for clinic BP favoring SMBP monitoring were found at 6 months (SBP/DBP: -3.1/-2.0 mmHg), but these differences were not statistically significant at 12 months (-1.2/-0.8 mmHg). The meta-analyses were statistically heterogeneous at 6 and 12 months. Only 1 RCT reported followup data beyond 12 months, and it found significant reductions in SBP and DBP at 24 months with SMBP. The studies reporting 24-hour ambulatory BP had inconsistent findings favoring either SMBP or usual care. However, the studies of awake and asleep ambulatory BP fairly consistently favored SMBP, although most did not find a statistically significant difference.; - Subgroup analyses were reported by 4 trials. One study found no differences in the relative effect of SMBP monitoring in patients treated or untreated for hypertension at baseline. Another found no difference by age, sex, or diagnosis with diabetes. A third study found significant reductions in clinic and 24-hour ambulatory DBP in men but not women. A study looking at differences by race did not have consistent findings. Across studies, no clear patterns could be discerned to explain the heterogeneity in results.; - Conclusion: Based primarily on the consistent findings of the quality A and B studies examining the impact of SMBP versus usual care in clinic BP measurements and the corresponding results from meta-analyses, the strength of evidence is moderate for a small improvement in BP using SMBP compared with usual care.
Key Question 1: SMBP Alone Versus Usual Care Surrogate and Intermediate Outcomes (Not Blood Pressure) | Low (failing to support a difference) | - Thirteen of the 24 studies that compared SMBP alone versus usual care reported surrogate and intermediate outcomes that were not BP. See the “Overall” summary above regarding the study heterogeneity.; - Eight studies reported data on categorical and continuous outcomes related to number of medications and dosage (1 quality A, 5 quality B, 2 quality C). Studies variously reported increases or decreases in number of medications, medication dose, added medication classes, number of treatment modifications by physicians, physician assessment of strength of medication regimen, number of antihypertensive medications used, and medication changes. The majority of studies found no difference in medication outcomes, although a minority found significantly greater changes in medication treatment with SMBP monitoring. Weak evidence favors no difference in medication use with SMBP monitoring.; - Three studies reported on quality-of-life outcomes (2 quality B, 1 quality C). Studies used the SF-36 quality-of-life assessment tool. In general, studies found no difference in quality of life between SMBP and usual care.; - Seven studies reported on medication adherence using a variety of different definitions of adherence, including both categorical and continuous outcomes (3 quality B, 4 quality C). A wide variety of definitions were used for medication adherence across studies. Three studies reported some significantly better measures of adherence with SMBP (although not always for all evaluated measures of adherence); the remaining 4 studies found no difference. Overall, there was weak evidence that medication adherence may be better among patients using SMBP monitoring.; - Only a single study each reported on patient satisfaction (quality C) and left ventricular mass index (quality B). No differences were found between SMBP and usual care. There is insufficient evidence for either of these outcomes.; - Conclusion: The evidence is weak or insufficient for these outcomes. Thus, overall the strength of evidence is low and fails to support a difference between SMBP alone versus usual care for surrogate and intermediate outcomes.
Key Question 1: SMBP Alone Versus Usual Care Health Care Encounters | Low (failing to support a difference) | - Six of the 24 studies that compared SMBP alone versus usual care reported number of health care encounters (1 quality A, 3 quality B, and 2 quality C). See the “Overall” summary above regarding the study heterogeneity.; - The majority of studies found no difference in number of physician visits between groups, 2 studies found no difference in number of hypertension-related telephone calls, and 1 study found no difference in number of medical procedures received for hypertension.; - One study found that patients using SMBP had more office visits and 2 studies found that patients using SMBP had fewer visits.; - Conclusion: Based on the lack of agreement in study results, the strength of evidence is low and fails to support a difference between SMBP alone versus usual care for health care encounters.
Key Question 1: SMBP + Additional Support Versus Usual Care Overall | -- | - Twenty-four studies compared SMBP plus additional support versus usual care (19 RCTs, 2 quasi-RCTs, and 3 nonrandomized studies). In total, 6,187 patients with hypertension were included. Six studies were graded quality A; 5, quality B; and 13, quality C. Four of these studies also provided data for SMBP alone versus usual care.; - The studies were heterogeneous in terms of the brands and types of SMBP monitors; followup duration (2-36 months); baseline hypertension control (across studies, mean SBP/DBP: 124-163/70-103 mmHg); patient ages (across studies, mean 47-77 years). All patients were adults, most were male, and the most commonly cited comorbid conditions in these studies were type 1 or 2 diabetes, obesity, dyslipidemia, and cardiovascular disease.; - No form of additional support was examined by more than one trial. The studies were highly heterogeneous in the types of additional support used. They included educational materials, Web resources, telephone monitoring with electronic transmission of BP data, nurse or pharmacist visits, calendar pill packs and/or compliance contracts, and behavioral management and/or medication management. Change in medication management as a result of the monitoring could be initiated by patient, nurse, pharmacist, or primary care physician.
Key Question 1: SMBP + Additional Support Versus Usual Care Clinical Outcomes | Insufficient | - One quality C trial found significantly lower mortality with SMBP plus self-titration versus usual care, and lower composite mortality and end-stage renal disease. End-stage renal disease alone was not significantly different.; - Conclusion: There is insufficient comparative study evidence regarding clinical outcomes in trials of SMBP plus additional support versus usual care.
Key Question 1: SMBP + Additional Support Versus Usual Care Blood Pressure | High (favoring SMBP) | - All 24 studies that compared SMBP plus additional support versus usual care reported BP outcomes. See the “Overall” summary above regarding the study heterogeneity.; - All 6 quality A trials reported a significant mean net reduction in SBP (ranging from -3.4 to -8.9 mmHg) or DBP (ranging from -1.9 to -4.4 mmHg) in the intervention group compared with usual care at up to 12 months followup. Four studies provided results after 12 months. The only quality A trial found no difference between groups at 18 months followup; the other 3 trials reported statistically significant mean net BP reductions for followup periods of 18 to 60 months.; - Conclusion: The strength of evidence is high for an improvement in BP control using SMBP with some form of additional support compared to usual care. By examination across studies, it is not possible to state with certainty whether one form of additional support is superior, as the additional supports examined across studies varied in primary intent, ancillary equipment and educational materials, followup personnel, and algorithms for medication adjustments. The studies were too heterogeneous in numerous ways to allow an explanation of differences in results across studies.
Key Question 1: SMBP + Additional Support Versus Usual Care Surrogate and Intermediate Outcomes (Not Blood Pressure) | Low (failing to support a difference) | - Fourteen of the 24 studies that compared SMBP plus additional support versus usual care reported surrogate and intermediate outcomes that were not BP. See the “Overall” summary above regarding the study heterogeneity.; - Eleven studies reported data on categorical and continuous outcomes related to medication number and dosage (3 quality A, 2 quality B, 6 quality C). Studies variously reported increases or decreases in medication number, medication inertia (no change in regimen), physician assessment of strength of medication regimen, treatment modification by physician, discontinuation of medication, and number of medication classes used or tablets taken. Studies were split between finding no difference in medication outcomes and finding either an increase or decrease in medications with patients using SMBP with additional support. The contradictory findings in the evidence overall favor no difference in medication use with SMBP monitoring plus additional support.; - Three studies (2 quality A and 1 quality C) reported on quality-of-life outcomes. These studies found no difference in SF-12, Consumer Assessment of Healthcare Providers and Systems score, Anxiety score, or Euro QoL 5D score. The studies all found no difference in quality of life.; - Six studies reported on medication adherence using a variety of different definitions of adherence, including both categorical and continuous outcomes (1 quality A, 2 quality B, 3 quality C). The studies had inconsistent findings, with half finding no difference in medication adherence and half finding greater adherence with SMBP plus additional support. Overall, there was weak evidence that medication adherence may be better among patients using SMBP monitoring.; - One study found no difference in adverse drug reactions across three groups with different forms of additional support.; - Conclusion: The evidence is weak or insufficient for these outcomes. Thus, overall the strength of evidence is low and fails to support a difference between SMBP plus additional support versus usual care for surrogate and intermediate outcomes.
Key Question 1: SMBP + Additional Support Versus Usual Care Health Care Encounters | Low (failing to support a difference) | - Eight of the 24 studies that compared SMBP plus additional support versus usual care reported number of health care encounters. All were graded quality C.; - The studies were highly heterogeneous, primarily in the types of additional support used. Additional support included education, alerts, medication monitoring, self-titration, Web training, pharmacist counseling, medication management, and behavioral management. All reported on number of physician (or physician and nurse) visits. One study additionally reported on telephone and Web encounters.; - Six studies found no difference in number of visits, 1 found fewer visits, and 1 found more visits with SMBP plus additional support compared to usual care.; - One study found mixed results with respect to telephone and Web encounters.; - Conclusion: Given the discordant findings as well as the low study quality, the strength of evidence is low and fails to support a difference between groups.
Key Question 2: SMBP + Additional Support Versus SMBP Overall | -- | - Twelve studies compared SMBP plus additional support versus SMBP without additional support or with less intense additional support, of which 11 were RCTs and 1 was quasi-randomized. In total, 3,311 patients with hypertension were included. Two trials were graded quality A; 4, quality B; and 5, quality C; and 1 conference abstract was not graded.; - The studies were highly heterogeneous, primarily in the types of additional support used. Additional support consisted of a mixture of behavioral interventions or disease management by a nurse or pharmacist, medication management, educational interventions, electronic transmission of BP measurements, Web sites/training for patient-provider communication, telemonitoring, BP recording cards or hypertension information leaflets, BP and medication tracking tool, and home visits. Change in medication management as a result of the monitoring could be initiated by patient, nurse, pharmacist, or primary care physician. Other sources of heterogeneity included the brands and types of SMBP monitors; followup duration (3-24 months, although mostly ≤12 months); baseline hypertension control (across studies, mean SBP/DBP: 126-179/70-103 mmHg); patient ages (across studies, mean 50-72 years. All patients were adults, most were male, and the most commonly cited comorbid condition was type 2 diabetes.
Key Question 2: SMBP + Additional Support Versus SMBP Clinical Outcomes | Insufficient | - No study reported clinical outcomes.; - Conclusion: There is insufficient comparative study evidence regarding clinical outcomes in trials of SMBP versus usual care.
Key Question 2: SMBP + Additional Support Versus SMBP Blood Pressure | Low (failing to support a difference) | - All 12 studies that compared SMBP plus an additional support versus SMBP without the additional support or with less intense additional support reported BP outcomes. See the “Overall” summary above regarding the study heterogeneity.; - Eight studies reported categorical changes in BP control, mostly defined as achieving a BP of <120-140/80-90 mmHg (sometimes with lower thresholds for patients with diabetes). Six trials showed no significant difference or were indeterminate for a difference in rates of achieving BP control. One trial of SMBP plus pharmacist counseling plus training in use of a patient Web portal vs. SMBP plus training in use of a patient Web portal found a significant effect favoring, more intensive additional support. Another trial comparing SMBP plus medication monitoring plus educational material versus SMBP plus educational material also found benefit for the more intense additional support; - Ten studies reported continuous BP outcomes. Six trials found no significant difference. Four favored the more intense support in addition to SMBP, comparing pharmacist counseling plus training in use of a patient Web portal versus training in use of a patient Web portal, medication monitoring plus educational material versus educational material, medication monitoring plus educational material versus educational material, and telemonitoring versus SMBP alone. Two studies provided results beyond 12 months. These studies reported findings that were nonsignificant or of uncertain statistical significance.; - Four trials reported subgroup analyses by control of BP at baseline (controlled or not controlled), degree of adherence (lower adherence), or race (white vs. predominantly African American). Two of these studies did not provide analyses for the comparisons of SMBP plus additional support versus SMBP without additional support or with another type of additional support, and two studies did not provide complete subgroup analysis data.; - Conclusion: Overall the strength of evidence is low and fails to support a difference in BP effects between SMBP plus additional support versus SMBP with no additional support or with less intense additional support.
Key Question 2: SMBP + Additional Support Versus SMBP Surrogate and Intermediate Outcomes (Not Blood Pressure) | Low (failing to support a difference) | - Seven of the 12 studies that compared SMBP plus additional support versus SMBP without additional support reported surrogate and intermediate outcomes that were not BP. See the “Overall” summary above regarding the study heterogeneity.; - Two trials reported on quality of life or anxiety (1 quality A, 1 quality B). The studies used SF-36, SF-12, and the State-Trait Anxiety Inventory, a mental health questionnaire. Both found no differences using any quality-of-life measure.; - Five trials reported data on categorical and continuous medication number and dosage (2 quality A, 2 quality B, 1 quality C). Studies reported numbers of patients taking 2 or more classes of medications, medical inertia (defined as no medication change vs. either an increase or decrease in medications), and number of medication drug classes. Four trials using additional support consisting of nurse counseling, home visits for BP measurement, telemonitoring, or education found no difference between SMBP plus additional support and usual care. One trial found a somewhat greater mean number of medication drug classes with SMBP plus Web training plus pharmacist counseling. Weak evidence suggests no difference in medication use.; - Three quality C trials reported on medication adherence. Using different measures in each study, none found a significant difference in medication adherence. One trial also found no difference in a subgroup of individuals with lower baseline adherence.; - Two trials looked at miscellaneous outcomes. One quality C trial found no difference in adverse drug reactions across four groups with different forms of additional support or usual care. One quality A trial found no difference in consumer satisfaction measured with the Consumer Assessment of Healthcare Providers and Systems instrument.; - Conclusion: The evidence is weak due to inconsistency across studies or poor-quality studies, or it is insufficient. Thus, overall the strength of evidence is low and fails to support a difference between SMBP plus additional support versus SMBP without additional support or with less intense additional support for surrogate and intermediate outcomes
Key Question 2: SMBP + Additional Support Versus SMBP Health Care Encounters | Low (failing to support a difference) | - Five of the 12 studies that compared SMBP plus an additional support versus SMBP without the additional support reported number of health care encounters. All were quality C. See the “Overall” summary above regarding the study heterogeneity.; - All reported on outpatient primary care visits, 2 reported on hospital admissions or inpatient or urgent care/emergency use, and 3 reported on cardiac and other specialist visits.; - None found a difference in the numbers of outpatient visits or hospital admissions between patients receiving SMBP with or without additional support.; - One study found more electronic and telephonic communication with SMPB plus pharmacist counseling plus training in use of a patient Web portal compared to SMBP plus training in use of a patient Web portal.; - Conclusion: Despite the consistency across trials, because of their small number and poor quality, overall the strength of evidence is low and fails to support a difference in number of health care encounters when using additional support with SMBP compared to SMBP without additional support or with less intense additional support.
Key Question 3: Different SMBP Devices | Insufficient | - No eligible study provided data to address this question.; - Conclusion: There is insufficient comparative study evidence regarding the comparison of different SMBP devices.
Key Question 4: Blood Pressure Control Relationship With Clinical and Surrogate Outcomes | Insufficient | - No eligible study provided data to address this question.; - Conclusion: There is insufficient comparative study evidence regarding the relationship of BP control with SMBP and clinical and surrogate outcomes.
Key Question 5: Predictors of SMBP Adherence | Insufficient | - One quality B study addressed how adherence to SMBP monitoring varies by patient factors. The study included 377 middle-aged Korean Americans using SMBP with telephonic transmission of BP measurements, hypertension education, and telephone counseling by a nurse. Adherence was defined as transmitting a minimum of 12 readings per week for at least 24 weeks of the 48-week study.; - Age ≥60 years was significantly associated with better adherence with SMBP, and greater depression (measured on a scale specific to Korean Americans) was significantly associated with worse adherence. Other factors explored for their relationship to adherence that did not show significant influences were marital status, education, work status, medication, duration of hypertension, comorbidity, family history of hypertension, body mass index, and knowledge and awareness regarding hypertension.; - Conclusion: There is insufficient evidence regarding predictors of SMBP adherence.

BP = blood pressure; DBP = diastolic blood pressure; Euro QoL 5D = Euro QoL Group 5-Dimension Self Report Questionnaire; RCT = randomized controlled trial; SBP = systolic blood pressure; SF-12/36 = Short Form-12/36 Health Survey; SMBP = self-measured blood pressure (monitoring)

## Discussion

### General Discussion

Self-measured blood pressure (SMBP) has been used in the treatment of hypertension with three major aims: (1) to avoid undertreatment of hypertension by allowing shorter cycles of BP measurement and treatment adjustment than are possible with clinic BP measurements alone; (2) to enhance self-participation in disease management and to enhance patients' adherence with lifestyle interventions and medication treatment; and (3) to avoid overtreatment in those with lower BP out of the clinic compared with in the clinic. This review identified 48 comparative studies that examined the impact of SMBP with or without additional support in the management of hypertension (plus one study on predictors of SMBP adherence). Overall, the benefit of SMBP for BP reduction appears to be modest, but this is not consistent across studies. We examined the role of additional support in combination with SMBP by setting up comparisons as: (1) SMBP alone versus usual care; (2) SMBP with additional support versus usual care; and (3) SMBP plus additional support versus SMBP with no additional support or a less intense additional support (Figure 1). Across studies, however, there was a very large degree of clinical heterogeneity in SMBP monitoring protocols, as well as a lack of consistency in the way SMBP monitoring was implemented and used by patients and in the types of additional support either provided to or expected from the patients. No two studies used the same additional support, and even the studies that used SMBP without additional support varied in their methods. This great heterogeneity limits the conclusions that can be drawn from this systematic review.

### Summary of Findings for Key Questions 1 and 2

Twenty-four trials compared SMBP alone versus usual care. Meta-analysis showed a statistically significant reduction in clinic SBP and DBP (SBP/DBP -3.1/-2.0 mmHg) at 6 months, but not at 12 months. Only one RCT reported followup beyond 12 months; findings indicated significant reductions in SBP and DBP at 24 months in favor of SMBP.

The comparison of SMBP plus additional support versus usual care was examined in 24 studies with 11 of 21 randomized trials and 2 of 3 nonrandomized studies reporting a statistically significant benefit in BP reduction favoring SMBP plus additional support. Four studies provided results after 12 months. The only quality A trial found no difference between groups at 18 months followup; the other three trials reported statistically significant mean net BP reductions for followup periods of 18 to 60 months

We found 12 trials of SMBP plus additional support (or more intensive additional support) versus SMBP without additional (or with less intensive additional support). Only four of these trials reported a significantly greater reduction in BP in the SMBP plus additional (or more intensive) support groups. Two studies provided results beyond 12 months. These studies reported findings that were nonsignificant or of uncertain statistical significance.

To answer the question regarding the role of additional support in combination with SMBP, we attempted to look across the three comparisons of SMBP alone versus usual care, SMBP plus additional support versus usual care, and SMBP plus additional support versus SMBP without additional support or with less intensive additional support. While it should be noted that evidence from indirect comparisons is much inferior to evidence from direct comparisons within trials, the evidence appears to suggest that additional support is synergistic with SMBP to achieve BP control. However, the heterogeneity of additional support with regards to the primary intents, ancillary equipments, educational materials, followup personnel, and algorithms for medication adjustments make it impossible to draw conclusions regarding the potential effects of specific modalities or particular components of additional support or their interactions with SMBP. Further, subgroup analyses in the trials were too few in number for each potential effect modifier, such as sex, race, comorbid disease, socioeconomic status, blood pressure control or compliance at baseline, to allow detection of consistent signals for subgroups that might preferentially benefit.

The observed reduction in BP with SMBP was statistically significant at 6 months but clinically only of small to modest size. Nevertheless, this may reflect a clinically relevant effect on a population level. Observational data suggest that each increase of 20 mmHg SBP or 10 mmHg DBP is associated with a 50 to 100 percent increase in mortality from cardiovascular disease, depending on age.95 In those 60 to 69 years of age, a 10 mmHg lower systolic BP is associated with about one-fifth lower risk of a coronary heart disease event.96 On the other hand, the BP reduction achieved with SMBP is modest compared to the reduction in blood pressure estimated to occur with other lifestyle interventions.1 However, effective lifestyle interventions must be high frequency and intensive and therefore may not feasible in many clinical practice settings. In comparison, SBPM may be a simpler intervention to introduce in the clinical setting.

Results on clinical outcomes for all comparisons were sparse or absent. A small number of studies reported quality of life or mental health outcomes but were inconclusive regarding the effect of SMBP. Other surrogate and intermediate outcomes and outcomes related to health care encounters were also inconsistently studied and reported across studies, further limiting the conclusions that can be drawn. For the comparisons of SMBP versus control and SMBP plus additional support versus control, there was weak evidence that medication adherence may be better among patients using SMBP monitoring. For the comparison of SMBP plus additional support versus SMBP alone or with another type of additional support, the evidence was weak and failed to show a difference

#### Clinical Heterogeneity

Despite the ostensible similarity in research questions across studies, great clinical heterogeneity across the examined publications limits the conclusions that can be drawn. There was a large degree of variability in SMBP monitoring protocols and implementation, use of and response to BP data, and the types of additional support, either provided to or expected from patients. We grouped the additional support interventions into categories based predominantly on education, counseling, Web support, or other support. However, the types of additional support were too heterogeneous and overlapping to be neatly categorized. Further, no two studies used the exact same mode of additional support, and even the studies that used SMBP without additional support varied in their methods.

Studies employed a variety of SMBP monitors, for example. Older studies used manual devices, while more recent studies used semiautomated or automated machines. Protocols for self-measurement varied in frequency and timing of measurements. Further, studies varied regarding how many serial measurements were taken on each occasion, and which measurements were chosen or averaged. The methods of recording and transmitting BP readings were similarly diverse, including ad hoc or structured self-recording into fixed forms; automatic storage of readings; presentation of the readings to the physician, a nurse, or a research coordinator; manual or automatic transmission of readings via telephone or Web site; and other variations. The response to the BP reading also varied with respect to the responder, the timing of treatment regimen changes, and how such changes were implemented. Responders could be the patients' regular providers, study clinicians, nurses, pharmacists, or the patients themselves. Responses in drug management were based either on SMBP results, or clinic BP results, and the actual response could entail counseling on lifestyle modification, general encouragement and support, advice on medication adherence, or changes in medication number, type, and dose. Medication changes could either be prescribed by standardized algorithms, or be deferred to the clinical provider's discretion. Further, even the “usual care” groups varied across studies, ranging from true usual care to study-standardized “usual care” to enhanced care including education or consistent followup.

Given the potential interaction between SMBP, additional support, and the clinical heterogeneity detailed above, it was not possible to confidently sort out which particular feature of SMBP or additional support could provide the greatest impact on reducing BP.

### Summary of Findings for Key Questions 3, 4, and 5

No study comparing different SMBP devices (particularly automated, semiautomated or manual devices) was identified to answer Key Question 3. Automated electronic oscillometric devices are presently the devices most widely used for SMBP monitoring; manual or semi-automated devices were only used in a few older studies.

None of the comparative studies reviewed addressed Key Question 4 by examining the relationship between achieving BP control and clinical or surrogate outcomes.

The data on predictors of adherence with SMBP were scant. One study in a special population of Korean Americans showed older age was independently associated with greater adherence to SMBP monitoring, and that a greater degree of depression was independently associated with lower adherence. Since SMBP is a tool for patient participation, it is likely that its adoption by a patient is affected by a patient's attitudes and preferences for self-participation in disease management. We found no study exploring patients' self-reported attitudes towards participation in disease management and how this would impact SMBP adherence.

## Limitations

As discussed above, the present systematic review is subject to several important limitations. Given the clinical heterogeneity stemming from the variation in the populations, interventions, and outcomes examined, only one or two studies were often available for specific comparisons. Many studies were rated as quality C and likely underpowered, even for BP outcomes. There were no studies in children. Duration of followup was limited and in most instances less than 12 months. Data on clinical event outcomes were lacking.

There are multiple possible reasons possible for why these studies generally found no significant effects and/or relatively small effect sizes. Existing trials did not evaluate patients regarding their pattern of home and clinic BPs prior to inclusion. Each study may have included varying proportions of individuals with uncontrolled hypertension, white coat hypertension, or masked hypertension. Depending on the particular home and clinic BP abnormalities in a specific patient, and whether BP management was guided by home or clinic BP in a trial, SMBP may have resulted in opposing effects on medication management and clinic BP within and across trials. Staessen 2004 and Verberk 2003 have both shown that adjusting BP medication to achieve the same BP target measured either by SMBP or by clinic BP will lead to less medication but higher clinic BP in the groups managed with SMBP.20,32,84 Consequently, SMBP may lead to (1) an intensified drug treatment in the patients with elevated clinic and home BP, thus lowering their clinic and home BP or (2) a reduction in medication in the patients with elevated clinic but normal or low home BP, thus (appropriately) raising their clinic and home BP.

Overall, such opposing medication titrations resulting from inclusion of patients with different clinic and home BP patterns and from different BP management protocols may cancel out effects on BP within and across trials. Thus the actual difference in BP may not fully reflect the potential benefit from SMBP in patients with more homogeneous BP abnormalities, such as in cases of either uncontrolled or refractory hypertension, or in patients with white coat hypertension (patients with typically normal BP whose BP rises to the abnormal range in the clinic, possibly due to anxiety). Further, given the short-term biological variability of BP within a patient and random measurement error, SMBP allows potentially for repeated measurements that provides greater certainty in the assessment of BP level.97

Medication adherence is an important intermediate outcome for primary care providers. It stands to reason that adherence to SMBP is a necessary intermediate outcome in deriving any benefit from SMBP, and that nonadherence to SMBP schedules is a key limitation in the successful application of this intervention in hypertension management. However, adherence itself has not been defined in a consistent fashion, and studies examining predictors of adherence were sparse, precluding any in-depth analysis.

Though it was of interest to this report to address how the particular type of BP device impacted BP control, no study comparing different SMBP devices was identified. Most studies used automated SMBP devices, although a number of these digital BP devices have yet to undergo rigorous independent validation.98 Nevertheless, these devices are not associated with observer bias or terminal digit preference and can be used with minimal training by most patients, even those with physical limitations. Given the widespread adoption of automatic devices, we are unlikely to get more data on manual versus automated devices, despite the difference in cost and the dilemma this presents for policymakers.

## Applicability

Reviewed studies were all conducted in an outpatient setting, mostly in Western Europe and North America. They included only adults with uncontrolled hypertension or on antihypertensive medication, with various eligibility criteria for BP at entry. Patients had to be willing and able to participate in SMBP. In two studies, the home BP monitoring could be conducted by a companion of the patient, usually a family member. Some studies required the patient to have a phone or computer with Web access. The prevalence of comorbid conditions was not consistently reported. Some studies specifically stated exclusion of individuals with active acute illness or recent hospital admissions. Minorities were underrepresented, although a few studies focused on African Americans. These eligibility criteria likely selected groups of patients with lesser severities of illness, better functional and cognitive status, higher socio-economic status, and better family support, thus limiting applicability to the general population of adults under treatment for hypertension.

A few studies reported the effect of various patient characteristics on BP outcomes. These included control of baseline BP, degree of adherence, socioeconomic status, and race. These subgroup analyses were limited by the small number of analyses per subgroup characteristic, and incomplete reporting for all subgroups or statistical analyses. Thus, no overall conclusion could be drawn on the effect of patient characteristics on BP outcomes.

Evidence from studies using manual devices and self-recording of BP on paper may become less and less applicable in the modern era. SMBP in conjunction with modern avenues for provider-patient communication has the potential to impact effectiveness and resource utilization. Telemedicine and Web-based tools have expanded the possibilities for patient-provider interactions to support ‘self-titration’ of BP medication,70 and SMBP plus telemedicine may shift encounters from conventional in-person clinic visits to virtual on-demand encounters that may more flexibly accommodate patient preferences regarding timing of interaction and intensity. SMBP as a component of telemedicine constitutes a major change in delivery of care for individuals with hypertension, and requires rigorous evaluation regarding feasibility, patient and provider preferences, logistical and infrastructural demands, and ethical considerations. The impact of reimbursement structures, in particular fee-for-service versus capitated systems, needs to be evaluated for such a potential shift.99

## Context of Findings

Our findings are consistent with four recently published systematic reviews examining the effect of SMBP identified in our search.100-103 Agarwal 2011 examined 37 trials, Bray 2010 examined 25 trials, Cappuccio 2004 examined 18 trials, and Glynn 2010 examined 14 trials.

In contrast to our review, these reviews did not require a minimum duration of followup of 2 months, and two also included studies in chronic hemodialysis patients; however, all excluded nonrandomized studies, which we allowed. All four reviews also found a modestly significant effect of SMBP on BP reduction, with net differences ranging from -2.5 to -4.2 mmHg for SBP and -1.4 to -2.4 mmHg for DBP. Agarwal 2011 also specifically studied the effect of SMBP on therapeutic inertia, defined as unchanged medication despite elevated BP, and reported less therapeutic inertia (greater number of medication changes) with SMBP compared to control. However, it is unclear how the definition of therapeutic inertia was standardized across studies for the purpose of meta-analysis.

Current clinical practice guidelines recommend the use of SMBP as an adjunct modality in the long-term clinical management of hypertension to supplement the readings obtained in the clinic setting.1 The American Heart Association (AHA) recommends SMBP for the majority of hypertensive patients in order to assess response to treatment and possibly improve adherence, as well as for some patients with prehypertension for the purpose of detecting masked hypertension. Of note, our review did not evaluate SMBP as a diagnostic tool. The AHA also mentions that SMBP may be of increased value in certain populations, such as diabetic patients, who require tight BP control.104

## Ongoing Research

A search in the ClinicalTrials.gov registry yielded 25 active (recently completed or ongoing) studies examining SMBP that are potentially relevant to the Key Questions in our report. No study entry provided results. One study was observational; the remaining 24 were interventional, of which 23 were RCTs. These studies are primarily examining the effects of various types of additional support along with SMBP versus control on BP control. The protocols of these studies are summarized in Table D-44 in Appendix D.

An ongoing trial in Japan, the HOMED-BP study, aims to determine an optimal target BP level on the basis of SMBP at home.105,106 Patients are randomized to either a more intensive BP-lowering group (home SBP <125 mmHg and DBP <80 mmHg) or a less intensive group (home SBP in the range 134-125 and DBP 84-80 mmHg). Patients will be followed until approximately 2013. This trial is expected to inform the choice of the home BP target, although it does not appear that it will provide evidence as to the effect of SMBP monitoring, per se.

## Future Research

On a population level, home BP is lower than clinic BP, but the exact relationship between home and clinic BP levels vary from person to person; thus the strategies to measure and control elevated BP may need to differ based on an individual's discrepancy between home and clinic BP. Individuals with elevated BP at home and in the clinic require more intense BP treatment, while those with elevated BP only in the clinic do not. Therefore, future research on SMBP ought to separate studies according to the primary study goal, either aimed at lowering BP in individuals with uncontrolled hypertension, or avoiding overtreatment in individuals with white coat hypertension. Studies should then evaluate patients according to their pattern of BP abnormality prior to study enrollment. Patients may be characterized as having uncontrolled hypertension, white coat hypertension, or masked hypertension.

In individuals with uncontrolled hypertension, future studies should examine the combined effects of SMBP with frequent cycles of drug titration based on home BP when BP is not yet controlled. Outcomes of interest are control of home and clinic BPs, and medication adherence. Populations of interest include individuals with newly diagnosed hypertension, individuals with hypertension “refractory” to treatment, or individuals with low adherence to medication. Subgroups of interest in studies are older persons and those with important clinical comorbidities, including cardiovascular and cerebrovascular disease, diabetes mellitus, and chronic kidney disease. Other subgroups of interest include racial and ethnic minorities, low SES groups and individuals receiving care in safety-net and non-academic settings. Further, the role of SMBP needs to be examined in children.

In individuals with white coat hypertension, future trials should examine the effects of SMBP and drug treatment based on home BP on the adequacy of home BP control and avoidance of over-treatment. Future studies in individuals with masked hypertension should examine the effect of self-management of home BP on the adequacy of home BP control.

Further there is a need to test SMBP as an adjunct to in-office BP management and use it for validation of clinical impression of BP control in willing patients.

Better standardization is needed regarding how patients use SMBP and the types of additional support that are employed. While we do not suggest that incremental improvements in how SMBP is deployed should cease, we have found that it is of limited value for every study to have a unique SMBP monitoring and additional support protocol. To reduce the heterogeneity of interventions, researchers should consider which already-investigated method of SMBP monitoring and additional support they believe is most promising, and implement that protocol. Similarly, retesting previously examined forms of additional support would be likely to advance the field more than introducing completely new protocols. Furthermore, the interpretability of future studies would be enhanced by the use of “usual care” protocols that most closely resemble the true usual care of the patients being studied as well as by pragmatic trials that would inform real world effectiveness.

Self-measuring BP can be burdensome over time. Future studies of SMBP should, therefore, also compare different monitoring schedules, with the goal of finding the least burdensome protocol. Studies can also evaluate the acceptance and effects of dynamic approaches that tailor measurement frequency to the degree of BP control, e.g., more frequent measurement when not at target and less frequent when in range.

A key question for this report was how different SMBP devices compare against each other, specifically automated, semi-automated, or a manual devices. While we could not identify any RCT with a head-to-head comparison of different devices, most recent studies used automated devices. Automated devices are widely available and require less dexterity on the part of the patient. If the question of cost difference between different types of devices is of interest, then future research on this question may be considered and should evaluate any tradeoffs between cost and user acceptance.

Other important areas for future research include examining the role of various measures for improving the accuracy of and adherence with SMBP, as well as improving the transmission of SMBP information for decisionmaking. Investigations should also be made into further use of telemedicine for patient-provider interaction regarding SMBP results and medication management.

Given the paucity of data for clinical event outcomes in this review, future studies should also examine the effects of SMBP on clinical events in addition to BP control. This will require followup durations greater than 1 year. A 5- to 10-year followup appears more appropriate for a chronic disease like hypertension to obtain more information on vascular outcomes and longer follow up on the effects on BP, adherence with SMBP and medication. In uncomplicated hypertension, it may be challenging to extend trial followup long enough to obtain precise effect estimates for objective clinical outcomes. Echocardiographic changes in left ventricular hypertrophy may be an appropriate vascular surrogate outcome. It should also be possible to nest studies comparing SMBP use versus no SMBP use in other cohort studies or link them to clinical outcome registries. If consistent clinical benefit can be established, the cost-effectiveness of SMBP monitoring should be evaluated by patient group and clinical setting.

Many clinicians consider self-monitoring of BP to be an educational tool to help patients become aware of their disease process, increase their commitment to BP normalization, recognize the importance of antihypertensive therapy, and increase adherence and persistence to BP lowering therapy. Therefore, another outcome of interest to be examined in future comparative studies of SMBP is patients' understanding of disease and how this correlates with adherence to antihypertensive medication and with BP control.

The effectiveness of SMBP may vary by patient characteristics or attitudes. Observational and experimental studies should, therefore, examine characteristics that are associated with adherence with SMBP. Data gathered should encompass demographic, psychosocial, educational, economic, and geographic factors, in addition to clinical variables. Candidate variables of interest include age, sex, race and ethnicity, socioeconomic status, and burden of disease comorbidity. Future research should also explore patient attitudes and values towards self-participation as factors that impact preference for SMBP. It may be possible to glean information on potential candidate variables from other instances of patient self-participation in chronic disease management, for example self-monitoring of blood sugar, self-measurement of anticoagulation, and self-management of asthma. Future studies may assess heterogeneity of treatment effects based on patient attitudes and preferences regarding SMBP.

Of particular importance for future SMBP research is the need to establish targets for home BP based on observational and RCT data. Observational studies should compare risk information from home BP, ambulatory BP measurement, and clinic BP levels. RCTs are needed to compare treatment to different home BP targets and their effect on clinical outcomes.

There is also a need to enhance the transparency of reporting of future research studies of SMBP. At a minimum, studies should consistently report complete information on the SMBP device used (including brand name), type, and accreditation. If necessary, the authors should also comment on how devices used in a study are similar or different to those used in existing validation studies. Further standardization in reporting is needed for how many serial measurements were taken and which ones were used to respond to. Future studies of SMBP should report detail on prescribed and achieved frequency and timing of measurements, how results are recorded or transmitted, and who responds to results and how.

## Conclusion

SMBP may confer a small benefit in blood pressure control, but the BP effect beyond 12 months and the attendant long-term clinical consequences remain unclear. Future research should standardize patient inclusion criteria, BP treatment targets for home BP, and SMBP and additional support protocols to maximize the interpretability and applicability of SMBP trials.