# Results

The literature search yielded 10,331 citations. From these, 334 articles were provisionally accepted for review based on abstracts and titles (Figure 3). After screening their full texts, 46 studies, published in 49 articles, were judged to have met the inclusion criteria. One additional study was found in the reference lists of previous reviews. The grey literature search yielded two conference abstracts but no additional studies from the Food and Drug Administration database. Thus a total of 49 studies (in 52 articles) are reviewed herein. The Summary Tables, with the descriptions and results of each study (except the two abstracts), are in Appendix D.

Figure 3 Literature flow

FDA = Food and Drug Administration Web site; SMBP = self-measured blood pressure; SMBP+AS = self-measured blood pressure with additional support

*The numbers of studies for each Key Question do not sum to the total number of studies as several studies addressed both Key Questions 1 and 2.

†Including two conference abstracts.

This figure is a flow chart that summarizes the study retrieval and selection process of articles on obstructive sleep apnea in adults relevant to the seven key questions. The figure displays the same information as enumerated in the first paragraph of the Results section. In addition, the figure includes the following numbers of studies that were reviewed for each Key Question: Key Question 1, 42 studies; Key Question 2, 15 studies; Key Question 3, no studies; Key Question 4, no studies; and Key Question 5, 1 study. The numbers of studies for each Key Question do not total 49 studies because several studies addressed both Key Questions 1 and 2.

The remaining 285 retrieved articles were rejected for not meeting eligibility criteria; one additional study retrieved from the reference list of a previous review also did not meet eligibility criteria (see Appendix B for the list of rejected articles and the rationale for their rejection). The most common reasons for article rejection were that the analyzed intervention was not self-measured blood pressure (SMBP), the cohort study did not evaluate predictors of adherence with SMBP and/or was too small, SMBP monitoring was used for less than 8 weeks, the article was not a primary study, SMBP monitoring was being performed to diagnose hypertension (or white coat hypertension), and the accuracy or validity of an SMBP device was being measured.

None of the studies were conducted in children. The applicability for each section is thus with reference to adults with hypertension.

Devices used for SMBP monitoring in the 49 studies (including the two conference abstracts) are shown in Table D-1 in Appendix D, along with information that could be retrieved on their validation or accreditation according to the American Association of Medical Instruments, British Hypertension Society, or European Society of Hypertension. In the following we tabulate the information on the device type and accreditation only for the upper arm monitors, although two studies also provided a wrist monitor as a default for individuals with large arm circumference. Regarding devices, 28 studies used automated devices, 2 semi-automated, 4 manual devices, and in 15 the information on the devices was not sufficient to determine the device type.

Regarding accreditation, in 32 studies it appeared that the device was accredited by at least one of the accreditation bodies. However, in 6 of these 30 studies it was not clear if the device for which accreditation information was cited or could be found was identical to the one used in the study, in three studies accreditation was claimed based on other or unpublished data that could not be clearly tracked to formal accreditation criteria, in one study, question remained as to if accreditation criteria were satisfied and one study used a collection of 30 different monitors with incomplete information on device accreditation except for the four main devices. In the remaining 21 studies, there was information on device accreditation.

## Key Question 1 In people with hypertension (adults and children), does self-measured blood pressure (SMBP) monitoring, compared with usual care or other interventions without SMBP, have an effect on clinically important outcomes?

a. How does SMBP monitoring compare with usual care or other interventions without SMBP in its effect on relevant clinical outcomes (cardiovascular events, mortality, patient satisfaction, quality of life, and adverse events related to antihypertensive agents)?
b. How does SMBP monitoring compare with usual care or other interventions without SMBP in its effect on relevant surrogate outcomes (cardiac measures: LVH [left ventricular hypertrophy], LVM [left ventricular mass], LVMI [left ventricular mass index]) and intermediate outcomes (BP control, BP treatment adherence, or health care process measures)?

For Key Question 1, we included only studies of interventions using SMBP monitoring as a principal part of the medical intervention in individuals with hypertension. The first part in this section discusses studies that compared SMBP alone with usual care. The second part discusses studies that compared SMBP with additional support versus usual care. Descriptions of all studies that addressed Key Question 1 (for both parts of the write-up) are summarized in Appendix D Table 2 (descriptions of the interventions) and Table 3 (descriptions of the study characteristics).

### Comparison of SMBP Alone Versus Usual Care

We identified 24 studies (23 reported in 24 articles and 1 study reported as a conference abstract) that contributed data to the comparison of SMBP monitoring alone versus usual care.20,42-44,47,48,51,53,56,58,59,62,64,67,68,71,72,77,79,83,85-88,90 These studies have been published over the past 35 years (1975 to 2010), with seven published before 1990. Of the 24 identified studies, 21 concerned comparisons of SMBP alone versus usual care, and five provided data for the comparison of SMBP plus some additional support (including education, telecounseling, or home visitor measurement in each study) versus the same additional support alone.43,44,53,64,77 The latter comparison was considered to correspond to a “SMBP versus usual care” comparison because the additional support interventions are common in both arms and thus their effects can be considered to cancel out. Thus a total of 26 comparisons were considered.

Of the 24 examined studies, 22 were randomized controlled trials (RCTs) and two were quasi-RCTs (Pierce 1984; Stahl 1984). Of the 22 RCTs, one was of a crossover design (Fitzgerald 1985) and the remaining were parallel group studies. Two of the trials (Dalfo i Baqué 2005 and Godwin 2010) used a cluster randomization scheme, randomizing clinics or physicians, rather than individual patients, to each group.

The examined SMBP interventions utilized a variety of monitor types (11 studies used automated monitors, while the remaining employed manual or semiautomated monitors) (Table D-1 in Appendix D) and applied different followup protocols with respect to frequency of blood pressure (BP) measurements, clinic visits, and types of BP recording and transmission (patient recorded versus centralized automatic transmission) (Table D-2). Usual care typically consisted of the standard-of-care management of hypertension in outpatient and general practice settings, as defined by the current standards of practice in each study.

Nineteen studies included patients with hypertension irrespective of whether these patients were on antihypertensive treatment at study enrollment (Table D-3). Four studies58,59,64,67 included only patients with poorly controlled hypertension despite being on antihypertensive medication, and one study included only patients that had not received antihypertensive treatment for at least one year (Stahl 1984). Thirteen of the 24 studies explicitly defined that the patients included had essential hypertension, whereas the remaining 11 studies20,43,44,47,48,53,58,64,67,72,85,90 did not clarify whether patients with secondary hypertension were included as well. Mean baseline systolic BP (SBP) ranged from 124 to 167 mmHg and diastolic BP (DBP) ranged from 70 to 109 mmHg. The mean age of patients ranged from 47 to 73 years, and men accounted for the majority of participants in 12 of 24 studies. The sample sizes of the intervention groups of interest in the included studies ranged from 12 to 1,325 patients (total = 5400 across studies). The most commonly cited comorbid conditions in these studies were type 1 or 2 diabetes, obesity, dyslipidemia, and cardiovascular disease.

Four studies were rated quality A, six studies were rated quality B, and 13 quality C. The conference abstract (Fuchs 2010) was not graded for quality due to insufficient data. The primary methodological concerns included small sample sizes with multiple testing, lack of power calculations, high dropout rates without adjustments for missing data, and incomplete or inconsistent reporting of data.

#### Clinical Events

None of the studies examined clinical event outcomes.

#### Blood Pressure Outcomes

BP outcomes were reported by 23 studies (25 comparisons in total). Four studies were rated quality A, 5 studies were rated quality B, and 13 quality C. The conference abstract was not graded for quality due to insufficient data. Followup durations ranged from 2 to 36 months, with only two studies (Bosworth 2009; Stahl 1984) having one of more than a year. Reported BP outcomes included both categorical outcomes, where the outcomes were defined as achieving a predefined BP target (e.g., clinic SBP <140 mmHg), and continuous outcomes, where net differences of SBP and DBP between baseline and final measurements (or, in some studies, differences between final values) were calculated. Clinic BP and ambulatory (24-hour, awake, and asleep) BP measurements were reported.

##### Categorical BP Outcomes

(Table D-4, Figure 4)

Figure 4 Forest plot, with meta-analyses, of relative risk of “adequate” BP at followup in RCTs of SMBP with or without additional support versus usual care, by time of outcome measurement

(Note: Estimates favoring SMBP are to the right, in contrast to Figures 5-9 & 11.)

Black circles indicate relative risk for each study. Black diamonds indicate summary estimates of relative risk. Bold numbers in the right columns aligned with the summary estimates are the summary relative risk, their P-values, and the I2 measures of statistical heterogeneity. The letters in brackets to the left of interventions with additional support refer to the categories in Table 1.

ABP = ambulatory blood pressure; Behavior = behavioral; BP = blood pressure (systolic/diastolic); Counsel = counseling; DBP = diastolic blood pressure; DM = coexisting diabetes mellitus; Med = medication; Mgt = management; NA (nd) = not available (no data); n/N Cx = the number of participants with adequate BP control/total in the control (usual care) group; n/N Tx = the number of participants with adequate BP control/total in the intervention (SMBP) group; RR = relative risk; RCT = randomized controlled trial; Rx = prescription; SMBP = self measured blood pressure monitoring; Tele = telemonitoring

*Studies with same name and intervention, with an asterisk, represent the same study arms at different followup times.

†SMBP group (home): <135/85, <125/75 if DM. Usual care group: (clinic) <140/90, <130/80 if DM

Notes:

Bosworth 2009B44 Both groups had behavioral intervention (control group is really behavioral intervention group).

Bosworth 2011^45^ Reported as differences in BP control (from a regression model). RR values derived from figure of estimated proportion in BP control.

DeJesus 2009A53 Both groups had education (control group is really education group).

Earp 1982^55^ Both groups had home visits.

This forest plot displays the relative risk of adequate blood pressure with confidence intervals for individual trials. The trials are categorized by duration of followup, including 2, 3, 4, 6, 12, 18, and 24 months. Trials that reported data at multiple timepoints appear multiple times. Meta-analysis summary estimates are presented for comparisons of SMBP alone versus usual care at 6 and 12 months. Studies of SMBP plus additional support are categorized by the type of additional support as described in Table 1 At 2 months there are 2 comparisons of SMBP alone versus usual care, one of which is reported in an abstract, with a range of relative risks from 1.4 to 2.5. The summary relative risk is 1.63 (95% CI 1.28 to 2.06, I-squared = 0%, favoring SMBP. At 3 months there are five comparisons of SMBP with additional support versus usual care, 2 in category C, 1 in category W, and 3 in category M. The range of relative risks is from 1.2 to 1.6, favoring SMBP for the category C and W comparisons, and from 0.4 to 0.7, favoring usual care, in the 3 category M comparisons all from Marquez Contreras 2009. At 6 months there are 6 comparisons of SMBP alone versus usual care with a scatter of relative risks from 0.9 to 2.0. The summary relative risk is 1.24, 95% CI 0.94 to 1.63, I-squared = 73%, favoring SMBP. At 6 months there are 9 comparisons of SMBP plus additional support versus usual care, 2 in category C, 1 in category E, 1 with both category C and E interventions, 1 in category W, and 4 in category M. The range of relative risks across studies is from 1.1 to 2.7 with wide confidence intervals, favoring SMBP plus additional support. Only the three category M comparisons in Marquez Contreras 2009 are statistically significant. At 12 months there are 3 comparisons of SMBP also versus usual care with relative risks of 1.1 or 1.5. The summary relative risk is 1.18, 95% CI 0.95 to 1.46, I-squared = 86%, favoring SMBP. At 12 months there are 7 comparisons of SMBP plus additional support versus usual care; 4 in category C, 1 in category E, 1 with both category C and E interventions, and 1 in category W. The range of relative risks across these 7 studies is 0.9 to 1.8, mostly favoring SMBP plus additional support. At 24 months there are 2 comparisons from 1 trial of SMBP versus usual care both with a nonsignificant relative risk of 1.1, favoring SMBP. Two comparisons of SMBP plus category C additional support versus usual care also favor SMBP, with relative risks of 1.2 and 1.3.

Figure 5 Forest plot, with meta-analyses, of net change clinic BP in RCTs of SMBP alone versus usual care, by time of outcome measurement

Black and white circles indicate systolic and diastolic blood pressures, respectively. Black and white diamonds indicate summary estimate systolic and diastolic blood pressures, respectively. Bold numbers in the right columns aligned with the summary estimates are the summary net change systolic/diastolic blood pressure, the P-values of the net change, and the I2 measures of statistical heterogeneity. Studies without 95 percent confidence intervals did not report variance data (and were not included in the meta-analyses).

BP = blood pressure (systolic/diastolic); N Cx = the number of participants in the control (usual care) group; N Tx = the number of participants in the intervention (SMBP) group; NA = not available (no data); Net Chg = net change in systolic/diastolic blood pressure; NS = nonsignificant; RCT = randomized controlled trials; SMBP = self measured blood pressure monitoring

*Studies with same name and intervention, with an asterisk, represent the same study arms at different followup times.

Notes:

Binstock 1988^43^ Both groups had education.

Bosworth 2009B44 Both groups had behavioral intervention (control group is really behavioral intervention arm).

Broege 2001^47^ Average during month 2.

DeJesus 2009A53 Both groups had education (control group is really education arm).

This forest plot displays the net changes for SBP and DBP with confidence intervals (when they could be calculated) for individual trials. The trials are categorized by duration of followup, including 2, 3, 6, 12, 18, and 24 months. Trials that reported data at multiple timepoints appear multiple times. Meta-analysis summary estimates are presented for durations of followup at 2, 6, and 12 months. At 2 months there are 3 comparisons with summary SBP 0.1 mmHg, summary DBP 0.1 mmHg, both with wide confidence intervals, nonsignificant, and I-squared = 0. Visually, the comparisons are scattered on both sides of 0 mmHg. At 6 months there are 10 comparisons, 9 of which are included in meta-analysis. Summary SBP -3.1 mmHg, P=0.002, I-squared = 24%; summary DBP -2.0 mmHg, P=0.001, I-squared = 41%. The individual studies mostly found negative net changes favoring SMBP, but with a wide range from -10 to 4 mmHg and wide confidence intervals. At 12 months, there are 7 comparisons, 6 of which are included in meta-analysis. Summary SBP = -2 mmHg, P=0.03, I-squared = 40%; summary DBP = -1.3 mmHg, nonsignificant, I-squared = 78%. The individual studies mostly found negative net changes favoring SMBP, mostly in the range from -4 to 2 mmHg and wide confidence intervals. One trial with 2 comparisons (Bosworth 2009) provided data at 18 and 24 months. Net changes in SBP and DBP were negative, with varying statistical significance, favoring SMBP.

Figure 6 Forest plot of net change 24 hour ambulatory BP in RCTs of SMBP alone versus usual care, by time of outcome measurement

(see notes below Figure 8)

This forest plot displays the net changes for SBP and DBP with confidence intervals for individual trials. The trials are categorized by duration of followup, including 2, 6, and 12 months. Trials that reported data at multiple timepoints appear multiple times. At 6 months 1 comparison with SMBP alone favored SMBP. At 12 months, 2 comparisons of SMBP alone and 1 of SMBP plus category W additional support, 2 of which favored SMBP. Overall, 5 of 7 comparisons favor SMBP for both SBP and DBP, some significantly, some not. Two comparisons (1 at 2 months, 1 at 12 months) favor usual care for both SBP and DBP, mostly statistically significantly. The 2 SMBP plus additional support comparisons are not discernibly different than the SMBP alone comparisons.

Figure 7 Forest plot of net change awake (day) ambulatory BP in RCTs of SMBP alone versus usual care, by time of outcome measurement

(see notes below Figure 8)

This forest plot displays the net changes for SBP and DBP with confidence intervals for individual trials. The trials are categorized by duration of followup, including 2, 3, 6, and 12 months. Trials that reported data at multiple timepoints appear multiple times. No meta-analyses are presented. At 2 months there are 2 comparison, one of which comes from an abstract. At 3 months there is 1 comparison with SMBP alone, at 6 months 2 comparisons with SMBP alone and 1 with SMBP plus category W additional support, and at 12 months, 2 comparisons of SMBP alone and 1 of SMBP plus category W additional support. Overall, 5 of 9 comparisons cluster with nonsignificant net changes favoring SMBP for both SBP and DBP. One comparison at 2 months has a large net change favoring usual care while the abstract reported a large net change favoring SMBP. One of 2 comparisons at 12 months also has significant net changes favoring usual care, but the comparison of SMBP plus additional support shows a significant net change favoring SMBP.

Figure 8 Forest plot of net change asleep (night) ambulatory BP in RCTs of SMBP alone versus usual care, by time of outcome measurement (see notes below)

Figures 6–8:

Black and white circles indicate systolic and diastolic blood pressures, respectively. The letters in brackets to the left of interventions with additional support refer to the categories in Table 1.

BP = blood pressure (systolic/diastolic); N Cx = the number of participants in the control (usual care) group; N Tx = the number of participants in the intervention (SMBP) group; NA = not available (no data); Net Chg = net change in systolic/diastolic blood pressure; RCT = randomized controlled trial; SMBP = self measured blood pressure monitoring

*Studies with same name and intervention (within each figure), with an asterisk, represent the same study arms at different followup times.

†Sensitivity meta-analysis that includes the conference proceeding abstract by Fuchs 2010^58^

Notes (for figures 6–8):

Bailey 1999^42^ Difference of final values (not net change).

Godwin 2010^59^ Difference of final values (not net change).

This forest plot displays the net changes for SBP and DBP with confidence intervals for individual trials. The trials are categorized by duration of followup, including 2, 3, 6, and 12 months. Trials that reported data at multiple timepoints appear multiple times. No meta-analyses are presented. At 2 months there is 1 comparison of SMBP alone reported in an abstract. At 3 months there is 1 comparison with SMBP alone, at 6 months 2 comparisons with SMBP alone, and at 12 months, 2 comparisons of SMBP alone and 1 of SMBP plus category W additional support. Three of 7 comparisons cluster near 0 net change with nonsignificant results for SBP and DBP. The 1 comparison at 2 months had a significant result favoring SMBP. The 1 comparison at 3 months was nonsignificant but had a large net change favoring SMBP. Two of the 3 comparisons at 12 months were divergent. One comparison of SMBP alone had a significant net change in SBP, favoring usual care, but nonsignificant DBP. The one comparison of SMBP plus additional support had significant net changes in BP favoring SMBP.

Figure 9 Forest plot, with meta-analyses, of net change clinic BP in RCTs of SMBP monitoring with additional support versus usual care, by time of outcome measurement

Black and white circles indicate systolic and diastolic blood pressures, respectively. Studies without 95 percent confidence intervals did not report variance data. The letters in brackets to the left of interventions with additional support refer to the categories in Table 1.

BP = blood pressure (systolic/diastolic); N Cx = the number of participants in the control (usual care) group; N Tx = the number of participants in the intervention (SMBP) group; NA = not available (no data); Net Chg = net change in systolic/diastolic blood pressure; RCT = randomized controlled trial; SMBP = self measured blood pressure monitoring

*Studies with same name and intervention, with an asterisk, represent the same study arms at different followup times.

†The same trial with different followup durations (Shea 2006,82 Shea 2009^93^).

Notes:

Binstock 1988^43^ Both groups had education.

Zillich 2005^89^ Both groups had pharmacist.

This forest plot displays the net changes for SBP and DBP with confidence intervals (when they could be calculated) for individual trials. The trials are categorized by duration of followup, including 3, 6, 12, 18, 24, 36, 48, and 60 months. Trials that reported data at multiple timepoints appear multiple times. Meta-analyses are not presented. There are 44 comparisons of SMBP plus additional support versus usual care in the forest plot. In general, most net changes for SBP and DBP range from about -5 to 1 mmHg, with the large majority favoring SMBP. There appears to be a trend that net changes become more negative (progressively favoring SMBP) with longer durations, such that at 12 months and beyond most comparisons found statistically significant negative net changes (favoring SMBP). This trend is most apparent in the single study (Shea 2009) with results beyond 24 months.

Figure 11 Forest plot of net change clinic BP in RCTs of SMBP with additional support versus SMBP monitoring alone, by time of outcome measurement

Black and white circles indicate systolic and diastolic blood pressures, respectively. Studies without 95 percent confidence intervals did not report variance data. The letters in brackets to the left of interventions with additional support refer to the categories in Table 1.

BP = blood pressure (systolic/diastolic); Med = medication; N Add = the number of participants in the SMBP with additional support group; N Cx = the number of participants in the control (SMBP alone) group; NA = not available (no data); Net Chg = net change in systolic/diastolic blood pressure; RCT = randomized controlled trial; Rx = prescription; SMBP = self measured blood pressure monitoring

*Studies with same name and intervention, with an asterisk, represent the same study arms at different followup times.

†Comparator is not SMBP alone; comparison is SMBP+Medication Management versus SMBP+Behavioral management.

Notes:

Bosworth 2011A45 Both groups had behavioral management.

Bosworth 2011B45 Both groups had medication management.

Green 2008^61^ Both groups had Web site.

Marquez Contreras 2009A69 Both groups had leaflet. Intervention is the same as the 2009B analysis.

Marquez Contreras 2009B69 Both groups had card. Intervention is the same as the 2009A analysis.

This forest plot displays the net changes for SBP and DBP with confidence intervals (when they could be calculated) for individual trials. The trials are categorized by duration of followup, including 3, 6, 12, 18, and 24 months. Trials that reported data at multiple timepoints appear multiple times. Meta-analyses are not presented. The additional supports are categorized by the types defined in Table 1. At 3 months there are 2 category M comparisons (from one trial). At 6 months there are 3 category C comparisons, 1 category E comparison, 1 category W comparison, and 2 category M comparisons (from one trial). At 12 months there are 4 category C comparisons, 1 category E comparison, and 1 category M comparison. At 18 months there are 2 category C comparisons and 1 category E comparison. One category C comparison also has results at 24 months. Three of 19 comparisons had significant net changes for either SBP and DBP, which overall ranged from -5.8 to 0.9 mmHg, excluding 1 small study that did not report confidence intervals. Most favored additional support. One study (Bosworth 2011) compared SMBP plus a category E intervention with SMBP plus a category C intervention at 6, 12, and 18 months. The study did not favor either category intervention.

Table 1 Post hoc categorization of types of additional support reported in studies

Category^a^ | Definition of Additional Support | Key Question 1 Studies | Key Question 2 Studies
C | Face to face or telecounseling with regular one-on-one encounters with study personnel (nurse, pharmacist, or others) on a regular basis during the course of the intervention. During these encounters, there may be opportunities for education and disease management, or these encounters could simply be for checking BP alone. | Bosworth, 2009 Bosworth, 2011 b Green, 2008 c Johnson, 1978 Artinian, 2001 Artinian, 2007 Earp, 1982 Haynes, 1976 Rudd, 2004 Zillich, 2005 | Bosworth, 2009 Bosworth, 2011 b Green, 2008 c Johnson, 1978 Brennan, 2010 Cheltsova, 2010
E | Education offered in regular classes on hypertension during the course of the study. No regular one-on-one contact with a professional was reported. The classes covered a variety of topics, such as self-management and nondrug therapies including behavioral and lifestyle modifications to nutrition and weight loss. | Bosworth, 2011 b Pierce, 1984 Gran, 1991 Muhlhauser, 1993 Sawicki, 1995 | Bosworth, 2011 b Pierce, 1984
W | Web-based or telephonic tools with or without counseling support by a professional or preprogrammed computer. The studies offered neither regular one-on-one encounter nor regular educational classes. | Friedman, 1996 Green, 2008 c McManus, 2010 Parati, 2009 Park, 2009 Rinfret, 2009 Shea, 2006 | Carrasco, 2008 Neumann, 2011
M | Miscellaneous types of additional support. A single class offered by a diabetes educator and instruction by a nurse on SMBP monitoring. A leaflet with educational materials on hypertension and/or a card for recording BP and pill counts. A contract on a behavior related to hypertension and calendar pill packs Letter to patients and providers on treatment recommendations | Binstock, 1988 d Márquez Contreras, 2009 DeJesus, 2009 Earle, 2010 | Binstock, 1988 d Márquez Contreras, 2009 Dawes, 2010

BP = blood pressure; C = Counseling; E = Education; M = Miscellaneous additional supports; SMBP = self-measured blood pressure; W = Web-based or telephonic tools

a These are the categories noted in square brackets in the forest plots.

b Bosworth 2011 provides both a category C and a category E comparison for Key Question 2.

c Green 2008 provides both a category C comparison and a category W comparison for Key Question 1.

d All groups in Binstock 1998, including control, also participated in an educational program.

Thirteen studies reported categorical BP outcomes.20,44,51,53,58,62,67,68,71,77,79,85,87 Six RCTs provided data for the outcome of reaching a predefined BP threshold (considered as “adequate” BP control) at 6-month followup. The SBP thresholds used by studies considering the whole population or only nondiabetic patients ranged from 130 to 140 mmHg and DBP thresholds from 80 to 95 mmHg. Three studies specified lower BP thresholds for diabetic patients, however, reporting values which ranged from 125 to 130 mmHg for SBP and 75 to 85 mmHg for DBP.

Meta-analysis of six studies (two quality A, one quality B and three quality C studies) at 6 months followup revealed a nonstatistically significant increase in the probability of achieving adequate BP control with SMBP monitoring (summary relative risk [RR] 1.24; 95 percent confidence interval [CI] 0.94 to 1.63), with statistically significant heterogeneity (I^2^ = 73 percent). All studies reported a point estimate indicating a favorable effect of SMBP monitoring, with the exception of Dalfo i Baqué 2005, which reported a nonsignificant odds ratio (OR) of 0.79 (95 percent CI 0.56 to 1.12) favoring usual care. In a sensitivity meta-analysis that included only the three quality A or B studies, a statistically significant summary RR of 1.53 (95 percent CI 1.22 to 1.93) favoring SMBP was found, with no statistical heterogeneity (I^2^ = 0 percent).

Three RCTs (all rated as quality B studies) reported data for the adequate BP control outcome at 12 months (defined as <140/90 mmHg in one study, and as <140/90 mmHg for nondiabetic and <130/80 mmHg for diabetic patients in the other two studies). Meta-analysis of these results indicated that the summary estimate did not show a statistically significant effect of SMBP monitoring (summary RR 1.18; 95 percent CI 0.95 to 1.46) and that extensive statistical heterogeneity was present (I^2^ = 86 percent). Two comparisons from the same trial (Bosworth 2009) also reported nonsignificant SMBP effects at 24 months followup; however, this study had a more than 20 percent dropout rate at this timepoint.

Four studies reporting categorical BP outcomes were not included in the aforementioned meta-analyses. Pierce 1984 and Stahl 1984 were not included because these were quasi-RCTs; Fuchs 2010 was excluded because the categorical BP outcome was evaluated at 2 months only; and Rogers 2001 was excluded because the reported outcome was the proportion of patients with reductions in SBP and DBP from baseline and not the achievement of a predefined BP target. None of the Pierce 1984, Stahl 1984 and Fuchs 2010 studies found that the use of SMBP was associated with a significant increase in the probability of achieving adequate BP control (for SBP and DBP in Pierce 1984 and Fuchs 2010 and DBP in Stahl 1984). However, Rogers 2001 reported that SMBP use resulted in significantly increased odds of experiencing reductions in SBP (OR 2.52; 95 percent CI 1.13 to 5.64) and DBP (OR 2.32; 95 percent CI 1.05 to 5.15).

##### Continuous BP Outcomes

In total, 21 studies provided data for continuous BP outcomes.20,42-44,47,48,53,56,58,59,62,64,67,68,71, 72,79,83,85,87,88

###### Clinic BP

(Table D-5, Figure 5)

Seventeen studies examined net changes in clinic SBP and DBP between the SMBP and control arms from baseline to final measurements. Three of the studies provided data for BP changes at 2 months. Meta-analysis of these three quality C studies revealed no significant difference in the net change of SBP and DBP between SMBP and usual care: SBP summary net change = 0.1 mmHg (95 percent CI -4.1, 4.3; nonsignificant [NS]); DBP summary net change = 0.1 mmHg (95 percent CI -1.5, 1.7; NS).

For the comparison at 6 months followup, seven RCTs provided data for SBP net changes (one quality A, four quality B and two quality C studies) and nine RCTs for DBP (one quality A, four quality B and four quality C studies). By meta-analysis of these studies, a statistically significant reduction for both SBP and DBP was found favoring SMBP: SBP summary net change = -3.1 mmHg (95 percent CI -5, -1.2; P = 0.002), with low statistical heterogeneity (I^2^ = 24 percent); DBP summary net change = -2.0 mmHg (95 percent CI -3.2, -0.8; P = 0.001), with moderate heterogeneity (I^2^ = 41 percent). All studies had point estimates indicating a favorable effect of SMBP over usual care for both SBP and DBP, with the exception of DeJesus 2009 and Johnson 1978B that showed nonsignificant net changes in DBP favoring usual care over SMBP. In sensitivity meta-analyses that included only quality A and B studies, no material changes in the magnitude and statistical significance of the summary net changes for SBP and DBP were found.

For the 12-month followup data, seven RCTs (one quality A, five quality B and one quality C) were synthesized by meta-analysis (three of them having also contributed data for the 6 month meta-analysis). In the 12-month meta-analysis, no statistically significant net change was evident for SBP or DBP: SBP summary net change = -1.2 mmHg (95 percent CI -3.5, 1.2), with moderate heterogeneity (I^2^ = 66 percent); DBP summary net change = −0.8 (95 percent CI -2.5, 1.0), with high heterogeneity (I^2^ = 81 percent). These summary estimates remained essentially unchanged in sensitivity meta-analyses that included only quality A and B studies.

Beyond 12 months of followup, data were provided only by two comparisons from the same trial (Bosworth 2009). Significant reductions for SBP and DBP with SMBP were found at 24 months only in the comparison of SMBP plus telecounseling versus telecounseling alone.

Stahl 1984, a quasi-RCT not included in the aforementioned meta-analyses, reported a significant reduction in DBP favoring SMBP at 7–12 months followup. The reduction in DBP was no longer statistically significant at subsequent followup times up to 36 months, which were characterized by large proportions of dropouts (>20 percent).

###### 24 Hour Ambulatory BP

(Table D-6, Figure 6)

For the net change in 24 hour ambulatory BP measurement, five studies contributed data; however, the followup durations varied from 2 to 12 months, thus no meta-analysis was feasible for this outcome. At 2 months, three studies (one quality A, one quality C and one conference abstract not rated for quality) reported significant differences in SBP measurements between SMBP monitoring and usual care but different directions of effects were noted. By meta-analysis, no statistically significant net change was found for 2 hour ambulatory SBP or DBP: SBP summary net change = -1.3 mmHg (95 percent CI -8.5, 5.9), with high heterogeneity (I^2^ = 84 percent); DBP summary net change = -2.7 (95 percent CI -5.9, 0.4), with moderate heterogeneity (I^2^ = 63 percent). Of these three studies, Rogers 2001 was rated as quality A and reported significant results favoring SMBP for both 24 hour ambulatory SBP and DBP. Of the two studies reporting 12 month followup data, Goodwin 2010 showed a significant net change in DBP favoring SMBP (-2.0 mmHg), whereas Verberk 2007 reported that the 24 hour ambulatory SBP and DBP were significantly higher in the SMBP group (SBP: +2.1 mmHg; DBP: +1.1 mmHg), thus favoring the usual care arm.

###### Awake (or day) Ambulatory BP

(Table D-7, Figure 7)

Six studies reported awake ambulatory BP. The majority of reported comparisons between the SMBP and usual care arms were nonsignificant in individual studies. Statistically significant results were reported only for SBP by Bailey 1999 (2 months) favoring usual care, for DBP by the conference abstract by Fuchs 2010 (2 months) favoring SMBP, and for both SBP and DBP by Verberk 2007 (12 months) favoring usual care.

###### Asleep (or Night) Ambulatory BP

(Table D-8, Figure 8)

A similar pattern of results was also observed for the net change in asleep ambulatory BP in four studies published in full reports, with all but one comparison for SBP and DBP showing no significant differences between SMBP and usual care arms; a marginally statistically significant result was reported by Verberk 2007 showing a 2.2 mmHg net change in SBP with SMBP at 12 months, favoring usual care. The conference abstract by Fuchs 2010 reported a statistically significant change in both SBP and DBP at 2 months, favoring SMBP.

#### Medication Dosage

(Tables D-9&10)

Eight studies provided data on outcomes relating to the number of medications prescribed and dosage (1 quality A, 5 quality B, and 2 quality C).42,62,72,77,86-88,90 The followup duration in these studies ranged from 2 to 12 months. Reported medication outcomes included both categorical outcomes (Table D-9), where the outcomes were defined as the number of patients with a specified change in medication (e.g., an increase in dosage or ceasing treatment with a particular class of medication), and continuous outcomes (Table D-10), which included number of medications and dosages. Due to the heterogeneity in outcome definitions between studies, no meta-analyses were feasible.

Six out of these eight studies reported categorical medication outcomes.42,72,77,87,88,90 Medication changes were reported in a variety of ways. Three examined an increase in medications, defined variously as either an increase in medication number, medication dose, an added medication class, or physician assessment of strength of medication regimen; none found a significant different between groups.42,67,77 Four looked at medication inertia, defined as no change in medication regimen; none of the four found a difference between groups,67,77,87,88 Two studies reported on a decrease of medication, either as a lower strength of mediation regiment as assessed by a physician or by a cessation of treatment with a particular class of medication.42,77 Neither found a difference between groups. In addition, Midanik 1991 found no difference in the number of patients using medication after study completion at 12 months.

Four of seven studies reported continuous medication outcomes.62,86,88,90 Two compared the number of antihypertensive medications used per patient between SMBP and usual care groups; neither found a significant difference.88,90 Halme 2005 reported no difference between groups in the number of medication changes per patient. van Onzenoort 2010 found the SMBP group to be prescribed 1.9 daily doses of antihypertensive medication compared to 2.4 in the usual care group (P = 0.001).

#### Medication Adherence

(Tables D-11&12)

Seven studies in total provided data on outcomes relating to medication adherence (3 quality B and 4 quality C).42,47,68,71,77,86,88 Followup durations in these studies ranged from 2 to 12 months. Reported medication outcomes included both categorical outcomes (Table D-11), where the outcomes were defined as the number of patients with a specified level of medication adherence, and continuous outcomes (Table D-12), where adherence was measured on a continuous scale (e.g. tablet count).

Five of these seven studies reported categorical medication adherence outcomes.42,47,68,77,86 In Marquez-Contreras 2006, patients with SMBP exhibited significantly different rates of adherence compared to those with usual care (P<0.001). Most notably, patients using SMBP were less likely to have adherences <80 percent as assessed by tablet count (RR 0.31; 95 percent CI 0.15, 0.65). Pierce 1984 found that the SMBP group was less likely to be rated as poor at medication adherence by a visiting nurse (RR 0.54; 95 percent CI 0.21, 1.37). However, neither Bailey 1999 (assessed by tablet count), van Onzenoort 2010 (electronic pill box monitoring), or Broege 2001 found any difference in medication adherence between groups (no specific adherence assessment method described).

Four studies reported continuous medication adherence outcomes.68,71,86,88 Mehos 2000 did not find a difference between groups in adherence as defined by percent of prescribed medications refilled. However, Marquez-Contreras 2006 found the SMBP group to take antihypertensive medication correctly on a greater percentage of study days (difference = 5.7 percent; 95 percent CI 2.87, 8.71; P<0.001), as did van Onzenoort 2010 (difference = 1.4 percent; P = 0.043). Marquez-Contreras 2006 also found that a greater percentage of patients using SMBP took medication at the prescribed time (88.1 versus 79.9 percent; P = 0.006). Zarnke 1997 found no difference between SMBP with self-titration versus usual care in the number of drug doses missed.

#### Quality of Life

(Table D-13)

Three studies provided data on outcomes relating to quality of life (2 quality B and 1 quality C).47,71,90 Followup durations in these studies ranged from 3 to 6 months. Mehos 2000 found no difference between groups in any domain of the Short Form-36 Health Survey (SF-36), while Broege 2001 found no difference between groups in SF-36 total score. Madsen 2008 found the SMBP group to fare better in bodily pain compared to the usual care group, as measured by the SF-36 (Scale 0–100, with higher score indicating better health; net difference = 7.0; P = 0.026), but did not find a significant difference between groups in any other SF-36 domain. Madsen 2008 also found that significantly fewer patients in the SMBP group felt that their health was worse after a year.

#### Health Care Encounters

(Tables D14&15)

Six quality C studies provided data on outcomes relating to health care encounters.42,71,72,83,87,88 Only one of these provided categorical data on health care encounters: Soghikian 1992 found no difference between groups in number of patients with no office visits for hypertension. However, each of the six studies provided continuous data on health care encounters.42,71,72,83,88 Two of these found no difference in the number of visits with a primary care or an otherwise unspecified provider,42,71 while two found no difference in the number of visits specifically related to hypertension.72,83 In Soghikian 1992, the difference remained nonsignificant after adjustment for age, race, sex, baseline DBP, use of baseline antihypertensive meds, and use of outpatient services for hypertension care in the prior year. Zarnke 1997 found that patients in the SMBP with self-titration group had 0.85 more physician visits than the usual care group over a period of eight weeks (95 percent CI 0.30, 1.40; P=0.045). Varis 2010 found that patients in the SMBP group had significantly fewer extra visits than the usual care group (1.4 versus 5.3, P < 0.05). Soghikian 1992 found no difference between groups in the number of medical procedures received for hypertension, but did find the SMBP group to have 1.3 fewer outpatient visits over the one year study period (no statistical comparison performed).

Three studies looked at the number of hypertension-related telephone calls made by study subjects, and found no difference between groups.72,83,87 In Soghikian 1992, the difference remained nonsignificant after adjusting for the aforementioned factors (i.e., age, race, etc.).

#### Miscellaneous Outcomes

(Table D-16)

Two studies reported miscellaneous outcomes.20,51 Dalfó i Baqué 2005, a quality C study, did not find a difference between SMBP and usual care in patient satisfaction (not defined). Verberk 2007, a quality B study, did not find a significant difference in left ventricular mass index change in the SMBP group compared to the usual care group.

#### Subgroups and Heterogeneity

##### BP Outcomes

Four trials reported results from subgroup analyses: Broege 2001 (quality C), Madsen 2008 (quality A), Godwin 2010 (quality B), and Bosworth 2011, an update of Bosworth 2009 (quality B).44,47,59,67,91 However, only the update of Bosworth 2009 performed formal statistical tests, and thus inferences for any differences in effects across subgroups were evaluated qualitatively for the other studies. Broege 2001 reported nonsignificant reductions in SBP and DBP for both the SMBP and usual care (nurse measurement) arms overall. By breaking down their analysis into patients previously treated and untreated, they found that patients previously treated experienced significant increases in BP with both SMBP and usual care, while previously untreated patients exhibited BP reductions in both groups. This discrepancy could be attributed to the fact that a relatively lenient BP target was set for this study (<150/90 mmHg), with previously treated patients meeting this target before study entry and thus possibly being more likely to experience an increase in BP. Nevertheless, the net changes in BP between SMBP and usual care were not statistically significant in either of these two subgroups.

Madsen 2008 examined the effect of SMBP versus usual care on awake and asleep ambulatory BP in subgroups defined by age (< or ≥60 years old), sex, and diagnosis with diabetes. Findings in these subgroups were consistent with the overall analysis. Godwin 2010 examined the effect of the patients' sex on ambulatory and clinic BP measurements. A lack of a statistically significant net change was observed in systolic and diastolic awake ambulatory BP (primary outcome) in both subgroups, which was consistent with the negative finding in the overall trial. However, there was a statistically significant net change in 24-hour ambulatory and clinic DBP favoring SMBP monitoring in men (no significant net changes were observed in women).

A post hoc data analysis of Bosworth 2009 reported a subgroup analysis by whites versus nonwhites, where nonwhites were 95 percent African American. There was no significant difference in SBP or DBP between SMBP and usual care groups at either 12 or 24 months of followup. In contrast, nonwhite patients in the SMBP group had significantly lower SBP and DBP at 12 months, compared with the usual care group. However, at the 24 month followup, these differences were no longer significant.

The summary estimates derived from meta-analyses were characterized by statistically significant heterogeneity in all cases. The small number of studies included in each meta-analysis (ranging from three to nine studies) did not allow a formal exploration of sources of heterogeneity with meta-regression techniques. We aimed to identify potential outliers by examining the pattern of results in the meta-analyses' forest plots. For the categorical outcome of adequate BP control at 6 months, the only study that had a point estimate favoring usual care was Dalfo i Baqué 2005, which was a large, cluster-randomized trial rated quality C due to methodological issues and reporting problems. The clinical characteristics of the patients included in this study were similar to other studies; however, the intervention consisted of SMBP measurements conducted only over two fortnight periods and not throughout the study followup period. Studies synthesized for the continuous BP outcomes displayed a consistent pattern of results favoring SMBP over usual care, although the majority of individual study estimates for SBP and DBP were not statistically significant. For the outcome of net change in clinic SBP and DBP at 12 month followup, Varis 2010 was an outlier showing a statistically significant net change favoring usual care for both SBP and DBP. By excluding this study from the meta-analysis at 12 months, a statistically significant summary net change of -2.0 mmHg (95 percent CI -3.8, -0.2; P = 0.027) for SBP was found favoring SMBP, whereas the summary net change for DBP remained non-significant. The remaining few studies that displayed nonstatistically significant effect estimates favoring usual care over SMBP had generally small sample sizes and their estimates were not precise.

#### Summary

##### Clinical Events

No studies of SMBP versus usual care provide evidence regarding the effect of SMBP monitoring on clinical outcomes. Thus, there is insufficient evidence regarding clinical events.

##### BP Outcomes

Twenty-three studies (four quality A, five quality B, 13 quality C, and conference abstract that was not graded for quality) provided data on BP outcomes. Meta-analysis of a small number of available studies for the outcome of adequate BP control showed that SMBP was not associated with a significantly increased probability of achieving a predefined BP target compared to usual care, at both 6 and 12 months. By restricting these meta-analyses to quality A and B studies only, a statistically significant result for adequate BP control at 6 months was found favoring SMBP. Meta-analyses for the continuous outcomes of net changes in clinic SBP and DBP showed significant effects favoring SMBP. Although there was no significant net change between SMBP and usual care in the meta-analysis at 2 months, SMBP monitoring was associated with statistically significant net changes in both SBP and DBP at 6 months, with summary point estimates that signify small, but clinically relevant reductions on a population level (-3.1 mmHg and -2.0 mmHg for SBP and DBP, respectively). However, these net changes were no longer significant in the meta-analysis of studies at 12 months followup point estimates of -1.2 mmHg and -0.8 for SBP and DBP, respectively). These summary estimates at 6 and 12 months were derived from syntheses of studies that included two quality A studies, six quality B and five quality C studies in total; the summary estimates were essentially unchanged in sensitivity analyses that were restricted to quality A or B studies only. The comparisons of SMBP with usual care for the outcomes of ambulatory BP measurements (24-hour, awake, and asleep) were based on a small number of studies which reported contradictory results. Overall, the studies were too heterogeneous along a variety of criteria (including populations, settings, interventions, control treatment, duration of followup and quality) to allow for a consistent explanation as to the differences in results observed across studies.

Due to the consistency of findings in studies with quality A and B examining the impact of SMBP versus usual care in clinic BP measurements, as well as those of the corresponding meta-analyses, the strength of evidence for an improvement in BP using SMBP compared to usual care is rated as moderate.

##### Surrogate and Intermediate Outcomes (not Blood Pressure)

Eight (one quality A, five quality B, and two quality C) studies reported data related to the number of medications prescribed and dosage.42,62,72,77,86,88,90 Evidence largely indicated no difference in number of medications and dose between SMBP and usual care groups. The majority of studies were rated as B or C quality. However, McManus 2010 did find the SMBP group to be prescribed a greater number of additional medications than the usual care group, and it was the largest trial (with 580 total participants), as well as the only A quality study. Thus there is a weak level of evidence for a lack of difference in medication dose between SMBP and usual care, primarily due to conflicting results and the differing methodologies employed between studies in assessing outcomes.

Seven studies (three quality B, four quality C) reported on medication adherence using a variety of different definitions of adherence.42,47,68,71,77,86,88 Studies were split: four found no difference between groups42,47,71,88 while two reported significantly greater adherence in the SMBP group,68,77 and one found patients in the SMBP group to take medication correctly on a greater percentage of days but did not find a difference in adherence using electronic pill box monitoring86 Given the wide variety of different definitions used and overall low study quality, the level of evidence that medication adherence was better among patients using SMBP monitoring is rated as weak.

Three studies (two quality B, one quality C) reported on quality of life outcomes.47,71,90 A moderate level of evidence points to no difference between SMBP and usual care, as only a single subdomain of one measurement tool in one study found a difference between groups, however, with an important caveat. The quality of life measurement tools were not specifically targeted towards hypertension, and may not capture components of quality of life that are relevant in hypertensive patients who use SMBP devices.

Evidence indicating no difference in patient satisfaction and left ventricular mass index is insufficient, as only one quality C and one quality B study, respectively, were found per outcome.20,51

Due to the inconsistency of findings, as well as heterogeneity of outcome definitions used, the strength of evidence for failing to find a difference between SMBP and usual care is rated as low across surrogate and intermediate outcomes.

##### Health Care Encounters

Six quality C studies reported on health care encounter outcomes.42,71,72,83,87,88 Evidence was mixed, with the majority of outcomes showing evidence of no difference in effect, although one trial found patients using SMBP to have more visits88 and two trials found the SMBP group to have fewer visits.83,87 Given the inconsistency in findings, the strength of evidence that health care encounters were unchanged in patients using SMBP monitoring versus usual care is rated as low.

### Comparison of SMBP Plus Additional Support Versus Usual Care

We identified 24 studies (reported in 25 articles)40,41,43-45,53-55,57,60,61,63,64,69,70,73,75-78,80-82,89,93 that compared SMBP monitoring plus a variety of additional support with usual care (Tables D-2&3). Five studies were published before 1990.^43,55,63,64,77^ Nineteen were RCTs,40,43-45,53,55,57,61,64,69,70,73,75,78,80,82,89,93 two were quasi-RCTs,63,77 and three were nonrandomized comparisons.60,76,81 Additional support included educational materials, letters to patients and providers on treatment recommendations, Web resources, phone monitoring with electronic transmission of BP data, telecounseling, behavioral management, medication management with decision support, nurse or pharmacist visits, calendar pill packs, and/or compliance contracts. Change in medication management as a result of the monitoring could be initiated by study personnel such as a nurse or pharmacist, the patient, or the primary care physician. Concerning SMBP monitoring methods (Table D-1 and D-2 in Appendix D): 14 studies used automated devices; 5 used auscultatory methods;55,60,63,64,77 and 4 did not provide detailed descriptions.43,73,76,81

All the patients enrolled in these studies had uncontrolled hypertension or were on antihypertensive medications at baseline. Mean age of the participants was 37 years in one study that enrolled only patients with type 1 diabetes and kidney disease.81 In the rest of the studies, the mean age ranged from 47 to 77 years. The proportion of male participants varied from 11 to 100 percent. Mean baseline SBP ranged from 124 to 163 mmHg and DBP ranged from 70 to 103 mmHg. The commonly cited comorbidities in these studies were type 1 or 2 diabetes, obesity, dyslipidemia, and cardiovascular disease. The sample size of the studies ranged from 15 to 1406 (total = 6187 across studies). Six studies were rated quality A, five were rated quality B, and 13 studies were rated quality C for the BP outcome. The primary methodological concerns included small sample sizes, the lack of a power calculation, high dropout rates, and incomplete reporting. Overall, the studies are applicable to adults with hypertension in the outpatient setting with the ability to self-monitor BP and with limited comorbid conditions.

#### Clinical Events

Sawicki 1995, in a quality C trial of 91 patients with Type 1 diabetes and diabetic kidney disease, found lower mortality in the SMBP plus self-titration plus education group (4 percent and 28 percent respectively; RR 0.16; 95 percent CI 0.04, 0.66), with the difference remaining significant after adjustment for proteinuria, age, and creatinine clearance (P=0.047).81 The study also found a lower composite of mortality and end-stage renal disease (RR 0.27; 95 percent CI 0.11, 0.66; P=0.006). This result also remained statistically significant after adjustment for DBP and age (P=0.018). However, incidence of end-stage renal disease by itself was not significantly different between groups (RR 0.41; 95 percent CI 0.14, 1.21).

#### Blood Pressure Outcomes

All 24 studies provided data on BP outcomes. The majority of the studies had followup durations of no more than 12 months. Seven studies also reported followup data of more than 12 months.44,45,55,60,73,81,93 Reported BP outcomes included both categorical outcomes, where the outcomes were defined as achieving a predefined BP target (e.g., clinic SBP/DBP ≤140 mmHg), and continuous outcomes, where net differences of SBP and DBP between baseline and final measurements (or, in some instances, differences between final values) were calculated.

Nearly all studies reported clinic BP measurements; in two studies BP measurements were taken at home by research personnel.57,64. Two studies also reported ambulatory (24 hour, awake, or asleep) BP measurements.75,78 Meta-analyses were not performed due to the great heterogeneity of the interventions.

##### Categorical BP Outcomes

(Table D-17, Figure 4)

Eleven studies reported categorical BP outcomes.41,44,45,53,55,61,63,69,73,75,89 Five trials reported that significantly higher proportions of patients achieved controlled BP target at followup in the intervention group compared with usual care.41,45,61,69,75 Márquez Contreras 2009 found that about twice as many patients achieved BP control (<140/90 mmHg or <130/80 mmHg in those with diabetes) using SMBP plus combinations of educational materials and/or medication monitoring compared with usual care (ANOVA P=0.01).69 Green 2008 also found that about twice as many patients achieved BP control (≤140/90 mmHg) using SMBP plus Web training with pharmacist counseling compared with usual care (57 versus 31 percent; P<0.001).61 Parati 2009 also reported a statistically significant difference in the proportion of patients achieving BP control (awake BP <130/80 mmHg) favoring SMBP plus reminder compared to usual care (62 versus 50 percent; P<0.05).75 Artinian 2007 reported that significantly higher proportion of patients achieved diastolic BP control (64 versus 53 percent; P=0.04) but no significant difference for systolic BP control.41 Bosworth 2011 reported that a significantly higher proportion of patients in the behavioral management group and in the medication management with decision support group had improvement in BP control compared to usual care at 12 months (estimated difference 12.8 percent; 95 percent CI 1.6, 24.1, P=0.03 [behavioral]; 12.5 percent; 95 percent CI 1.3, 23.6, P=0.03 [medication]), but there was no significant difference at 18 months.45 There was also no significant difference between combined medication-behavioral management and usual care at any of the time points. The rest of the studies did not report statistically significant differences between usual care and SMBP plus additional support.

##### Continuous BP Outcomes

In total, 24 studies (reported in 25 articles) provided data for continuous BP outcomes.40,41,43-45,53-55,57,60,61,63,64,69,70,73,75-78,80-82,89,93

###### Clinic BP

(Table D-18, Figure 9)

All 24 studies reported clinic-measured BP outcomes or home BP measured by research personnel. Eleven trials reported statistically significant greater reductions in either the clinic SBP or DBP at followup favoring the SMBP intervention with additional support compared to usual care.41,44,45,57,61,70,73,78,80,82,89 The additional support examined in these 11 trials were telecounseling;41,44,57,80 Web training with pharmacist counseling;61 self-titration plus provider alert;70 education;73 medication monitoring with provider alert;78 personalized Web site plus videoconference counseling;82 pharmacist counseling;89 and combined medication-behavioral management (as needed whenever there were inadequate BP control).45

For followup from 3 to 12 months, the mean net change in SBP ranged from -1.6 to -8.5 mmHg, favoring SMBP with additional support; the mean net change in DBP ranged from -1.9 to -4.4 mmHg. Of note, one trial comparing SMBP plus behavioral and medication management against usual care reported statistically a significant reduction of SBP at 12 months (net change -4.3 mmHg; 95 percent CI -8.5, -0.2, P=0.04), but not at 18 months.45 However, in this study, the other interventions (SMBP plus either behavioral management or medication management) did not differ from usual care at any timepoint. Three of four trials reported statistically significant mean net BP reductions for followup periods of 18 to 60 months. With the exception of the single quality A study, Bosworth 2011^45^ at 18 months, net changes in SBP ranged from -2.6 to -5.0 mmHg and in DBP from -1.3 to -4.0 mmHg.44,73,93

Statistical analyses for the between-group differences were not reported in five trials.40,43,53,54,77 Meta-analysis was not undertaken because of the heterogeneity of the interventions across trials. An examination of the forest plot suggests a pattern of reduction in either the SBP or DBP favoring the intervention at longer term followup (12 months and beyond) but not at shorter term followup (3 or 6 months).

Two76,81 of three nonrandomized studies60,76,81 also reported a statistically significant greater reduction in either the SBP or the DBP at followup favoring the intervention (personalized Web site plus nurse counseling76 or self-titration plus education81).

###### Ambulatory BP

(Table D-19, Figures 6–8)

Two trials also provided outcomes on ambulatory continuous BP measurements.75,78 Rinfret 2009 reported a statistically significant greater reduction in 24 hour ambulatory BP (mean net change SBP: -4.8 mmHg; P<0.001; DBP: -2.1 mmHg; P=0.007); awake BP (mean net change SBP: -5.9 mmHg; P<0.001; DBP: -2.5 mmHg; P=0.05); and asleep time BP (mean net change SBP: -3.8 mmHg; P<0.001; DBP: -1.9 mmHg; P=0.05) at 12 months followup favoring those with SMBP plus medication monitoring with provider alert compared to usual care.78 Parati 2009 reported a statistically significant greater reduction of awake SBP in those who had SMBP plus reminder compared to usual care (mean net change: -1.6 mmHg; P<0.05).75 No statistically significant difference was reported for awake DBP.

#### Medication Dosage

(Tables D-20 and 21)

Eleven studies provided data on outcomes relating to the number of medications prescribed and dosage (three quality A, two quality B, and six quality C).41,61,69,70,73,75,77,78,80,81,89 The followup durations in these studies ranged from 2 to 60 months. Reported medication outcomes included both categorical outcomes (Table D-20), where the outcomes were defined as the number of patients with a specified change in medication (e.g. an increase in medication dosage or cessation of a class medication) and continuous outcomes (Table D-21), which reported on quantities of medication or number of medication classes used. Due to the heterogeneity in outcome definitions between studies, no meta-analyses were feasible.

Five of these ten studies reported categorical medication outcomes.73,75,77,80,89 Among these, Pierce 1984 and Zillich 2005 both examined an increase in medications. Pierce 1984 found no difference between SMBP plus education versus usual care in physician assessment of the strength of medication regimen, while Zillich 2005 found that more subjects in the SMBP plus pharmacist counseling group exhibited an increase in the amount of medication used or number of medications compared with the pharmacist BP measurement group (RR 2.26; 95 percent CI 1.42, 3.61; P>0.05). Pierce 1984 reported on medication inertia, defined as no change in medication regimen, and did not find a difference between groups. Rudd 2004 however found more patients having SMBP plus counsel to report no change in drug therapy (RR 0.05; 95 percent CI 0.01, 0.20). With respect to physician assessment of decreased medication, Pierce 1984 found no difference between groups; however, Muhlhauser 1993 found more patients in the SMBP plus education group to show a decrease in the number of medications prescribed than in the usual care group.(RR 0.3; 95 percent CI 0.17, 0.43; P<0.001). Additionally, Zillich 2005 found no difference between groups in the number of patients discontinuing medication after the study. Rudd 2004 found more patients in the SMBP plus counsel group to be taking two or more drugs (RR 1.53; 95 percent CI 1.13, 2.07) or no drugs (RR 1.77; 95 percent CI 1.04, 3.03) at the completion of the 6 month study. Parati 2009 found no difference between groups in percentage of visits at which physicians modified their patient's treatment, but did find that the SMBP group had a significantly smaller percent of visits at which patients were found to have modified their own treatment schedule (P = 0.04).

Seven of 11 reported continuous medication outcomes.41,61,69,70,78,80,81 Four of these reported on the number of hypertension medication classes used.61,70,78,81 Green 2008 found that both the SMBP plus Web training with pharmacist counseling group and the SMBP plus Web training used a greater number of medication classes than the usual care group (SMBP plus Web with pharmacy versus usual care difference: 0.5; 95 percent CI 0.3, 0.6; P<0.05. SMBP plus Web versus usual care difference: 0.3; 95 percent CI 0.1, 0.4; P<0.05). Rinfret 2009 found that the SMBP plus provider alert with medication monitoring group used an average of 1 more medication class than the usual care group (adjusted P = 0.007) and also had 1 more physician-driven medication change (adjusted P=0.03). McManus 2010 found that patients in the SMBP plus alert with self-titration group were prescribed a greater number of additional antihypertensive medications (net difference = 0.46; 95 percent CI 0.34, 0.58; P = 0.001), and Sawicki 1995 found that patients in the SMBP plus education with self-titration group were prescribed a greater number of antihypertensive medications (net difference = 0.46; 95 percent CI 0.34, 0.58; P = 0.001). Marquez-Contreras 2009 found no difference between either SMBP plus educational material, SMBP plus medication monitoring, or SMBP plus educational material with medication monitoring in comparison to usual care with respect to the number of tablets taken per day. Rudd 2004 found a greater number of medication changes in the SMBP plus counsel group (net difference = 2.0; P<0.01). Artinian 2007 found no difference in Treatment Intensity Score, which approximates dosage strength, between SMBP plus telecounseling versus enhanced usual care.

#### Medication Adherence

(Tables D-22 and 23)

Six studies provided data on outcomes relating to medication adherence (one quality A, two quality B, and three quality C).57,63,77,78,80,89 The followup durations in these studies ranged from 2 to 12 months. Reported medication outcomes included both categorical outcomes (Table D-22), where the outcomes were defined as the number of patients with a specified level of medication adherence, and continuous outcomes (Table D-23), where adherence was measured on a continuous scale (e.g., tablet count).

Three of these six studies provided data on categorical medication adherence outcomes.63,77,89 Haynes 1976 found that SMBP plus encouragement resulted in greater medication adherence, defined as a patient having greater adherence at study completion than at baseline, as assessed by a surreptitious pill count conducted by a home visitor (RR 2.06; 95 percent CI 1.11, 3.82; P<0.05). Pierce 1984 found no significant difference in medication adherence between SMBP plus education versus usual care, as assessed by medication count and nurse-administered survey. Zillich 2005 found no difference between SMBP plus pharmacist counseling versus pharmacist BP measurement, as assessed by self-report.

Four of six studies examined continuous medication adherence outcomes.57,63,78,80 Haynes 1976 found that patients in the SMBP plus encouragement group showed a greater increase in percentage of prescribed pills taken than the usual care group (net difference: 23 percent; 95 percent CI 2.9, 43; P=0.025). Friedman 1996 found greater medication adherence in terms of percentage of pills taken in the SMBP plus telecounseling group compared with the usual care group (net difference: 6 percent; 95 percent CI 0.6, 2.8; P=0.03) after adjustment for age, sex, and baseline adherence. Rudd 2004 found the SMBP plus counsel group to take antihypertensive medication correctly on a greater percentage of study days (difference = 11.3 percent; P = 0.03). Rinfret 2009 found no difference between SMBP plus provider alert plus medication monitoring and usual care in “continuous measure of medication acquisition” (cumulative days supply of medication obtained divided by the total days to the next prescription refill, based on pharmacy data) and “continuous measure of medication gaps” (total days of treatment gaps divided by the total days to the next prescription refill, based on pharmacy data). (Outcome definitions are based on the cited reference.94)

#### Quality of Life

(Table D-24)

Three studies provided data on quality of life outcomes (two quality A, one quality C).61,70,75 Followup durations in these studies ranged from 3 to 12 months. Green 2008 found no difference in either the SMBP plus Web training or SMBP plus Web training with pharmacist counseling group compared to usual care with regards to SF-12 score or the Consumer Assessment of Healthcare Providers and Systems score. Parati 2009 found no difference between SMBP plus reminder versus usual care in the Short Form-12 Health Survey (SF-12) score. McManus 2010 found no difference between SMBP plus alert with self-titration in Anxiety score (a six item scale of the State Trait Anxiety Inventory) or Euro Quality of Life Group 5-Dimension Self Report Questionnaire (Euro QoL 5D) score.

#### Health Care Encounters

(Table D-25)

Eight quality C studies provided data on outcomes relating to health care encounters.45,53,61,70,73,78,81,89 DeJesus 2009 found no difference between the SMBP plus one class versus usual care groups in the number of physician and nurse visits. The remaining seven studies provided data on the number of physician visits per study group.45,61,70,73,78,81,89 Five studies found no difference compared to usual care, when looking at SMBP plus education, SMBP plus provider alert with medication monitoring, SMBP plus self-titration with provider alert, and SMBP plus medication management and/or behavioral management.45,61,70,73,78 Zillich 2005 found that patients in the SMBP plus pharmacist counseling group had 0.61 fewer visits than the pharmacist BP measurement group, over a period of 3 months (P=0.007). Sawicki 1995 found that the SMBP group had 2.5 more visits, over a study period of five years (P<0.001). Green 2008 found no difference between either group versus usual care in terms of inpatient and emergency care use.

Green 2008 also found that patients using SMBP plus Web training did not have a different number of message threads or phone encounters compared to the usual care group over a period of 12 months. Patients using SMBP plus Web training with pharmacy counseling had a greater number of message threads (net difference = 19.9, P<0.05) and phone encounters (net difference = 3.5, P<0.001) compared to the usual care group. Patients using SMBP plus Web training had a greater number of patient-initiated message threads compared to the usual care group (net difference = 0.9, P=0.01), as did patients using SMBP plus Web training with pharmacy counseling (net difference = 2.4, P<0.01).

#### Miscellaneous Outcomes

(Table D-26)

One study (quality C), Marquez-Contreras 2009, found no difference between groups with regards to adverse drug reactions, when comparing usual care, SMBP plus medication monitoring, SMBP plus educational material, and SMBP plus medication monitoring with educational material using an ANOVA analysis across the three intervention groups.69

#### Subgroups and Heterogeneity

##### BP Outcomes

(Table 1)

Seven trials reported results from subgroup analyses: Friedman 1996 (quality A), DeJesus 2009 (quality C), McManus 2010 (quality A), Green 2008, (quality A), Bosworth 2011 (quality A), Shea 2006 (quality A), and a second Bosworth 2011, which is an update of Bosworth 2009 (quality B) 44,45,53,61,70,82,91. Friedman 1996 reported that patients who were nonadherent with their antihypertensive medications at baseline were most affected by SMBP with computer-controlled telephone system intervention.57 Mean DBP decreased by 6 mmHg in this group versus an increase of 2.8 mmHg in the usual care group (P=0.01). Quantitative analysis for the adherent group was not reported. DeJesus 2009, using a multivariate logistic model, did not find that body mass index, number of nurse or physician visits, or baseline SBP or DBP predicted the achievement of target BP in a study of patients with diabetes comparing SMBP and nurse education with usual care.53 McManus 2010 reported a greater reduction in SBP in those with higher socioeconomic status who had SMBP plus telemonitoring compared to those with lower socioeconomic status (net difference: -5.7 mmHg at 6 months, P=0.05; -5.4 mmHg at 12 months, P=0.08).70 Green 2008 reported that the subgroup of patients with baseline SBP ≥160 mmHg who had SMBP plus Web-based pharmacist counseling had lower SBP (-13.2 mm, P<0.001) and DBP (-4.6 mm, P<0.001) compared to those with usual care at 12 months followup.61 Quantitative analysis for those with baseline SBP <160 mmHg was not reported. Bosworth 2011 compared 348 patients with adequate BP control (≤140/90 mmHg in patients without diabetes or ≤130/80 mmHg in those with diabetes) to 243 patients with inadequate control in a post hoc analysis.45 The study reported that patients with adequate control at baseline continued to remain in control over the 18 months of the study. For those with inadequate control, comparing SMBP plus behavioral management with usual care, SBP net change was -8.3 mmHg (95 percent CI -15.1, -1.6, P=0.02) at 12 months, but there was no significant difference at 18 months. Comparing SMBP plus medication management with usual care, SBP net change was -7.9 mmHg (95 percent CI -14.5, -1.4, P=0.02) at 12 months and DBP net change was -4.2 mmHg (95 percent CI -8.3, -0.2, P=0.04) at 18 months. Comparing SMBP plus combined medication-behavioral management with usual care, SBP net change was -14.8 mmHg (95 percent CI -21.8, -7.8, P<0.001) at 12 months and 8 mmHg (95 percent CI -15.5, -0.5, P=0.04) at 18 months; DBP was lowered by 5.3 mmHg (95 percent CI -9.5, -1.2, P=0.01) at 12 months and 5.5 mmHg (95 percent CI -9.7, -1.2, P=0.01) at 18 months.

Shea 2006, an RCT of SMBP plus personalized Web site and videoconference counseling versus usual care, also analyzed separately the 12 months outcomes from patients recruited in the Upstate New York area and those from the New York City regions and reported similar magnitude of effects in the two regions for BP outcomes.82 For upstate New York, the adjusted mean net difference for SBP was -3.98 mmHg (ANCOVA P=0.006) versus -2.76 mmHg (ANCOVA P=0.06) for New York City region. For DBP, the adjusted mean net difference in upstate New York was -2.13 mmHg (ANCOVA P=0.003) versus -1.73 mmHg (ANCOVA P=0.02) for New York City region.

As noted in the previous section on SMBP versus usual care, a post hoc data analysis of Bosworth 2009 reported a subgroup analysis by whites versus nonwhites, where nonwhites were 95 percent African American.44,91 In white patients, there was no significant difference in SBP or DBP between the SMBP plus telecounseling group versus the usual care group at either 12 or 24 months of followup. In contrast, nonwhite patients in the SMBP plus telecounseling group had significantly lower (P< 0.05) SBP and DBP at 12 months, compared to the usual care group. These differences remained significant at the 24-month followup.

To try to gain an insight into the heterogeneous nature of the additional supports across studies, we have post hoc classified the various interventions for each group into four categories, which are described in Table 1. This was based on our assessment of the key component, since the categories are not exclusive. Five of the nine studies in category “C” (Counseling with regular one-on-one encounters with study personnel) reported statistically significant reductions in either the SBP or the DBP at followup favoring the additional support with SMBP.41,44,61,80,89 The mean net change in SBP ranged from -3.3 to -8.9 mmHg; the mean net change in DBP ranged from -2.2 to -3.2 mmHg. Green 2008 also reported a significantly higher proportion of patients achieved controlled BP target at followup in the intervention group compared with usual care (57 percent versus. 31 percent; P<0.001).61 Three of five studies in category “E” (Education offered in regular hypertension education classes) reported statistically significant reduction in either the SBP or the DBP at followup favoring those who attended the classes in addition to SMBP.45,73,81 Two studies were conducted by the same group of investigators.73,81 The mean net changes of SBP were -5 mmHg (95 percent CI -10, 0; NS) in the first study73 and -19 mmHg (95 percent CI -33, -5.2; P=0.007) in the second study.81 The mean net changes of DBP were -4 mmHg (95 percent CI -7, -1; P=0.018) in the first study73 and -6.1 mmHg (95 percent CI -13.1, 0.9; NS) in the second study.81 Bosworth 2011 reported an estimated net change in SBP of -4.3 mmHg (95 percent CI -8.5, 0.2; P=0.04) in the combined medication-behavioral management group (versus usual care) at 12 months, but no significant difference at 18 months.45 The estimated net change in DBP was -0.01 mmHg (95 percent CI -2.6, 2.6; P=NS) at 12 months. Six of seven studies in category “W” (Web-based or telephonic tools) reported statistically significant reductions in either the SBP or the DBP at followup favoring those who had additional support.57,61,70,75,76,78,82 The mean net change in SBP ranged from -1.6 to -5.4 mmHg; the mean net change in DBP ranged from -1.9 to -4.4 mmHg. The seventh study reported a significantly higher proportion of patients achieved controlled BP target at followup in the intervention group compared with usual care (62 percent versus. 50 percent; P<0.05).75 Four studies were in category “M” (Miscellaneous).43,53,54,69 The additional support in one study was a single class offered by a diabetes educator and instruction by a nurse on SMBP monitoring.53 The second study used leaflet with educational materials on hypertension and/or a card for recording BP and pill counts.69 Neither study reported a statistically significant difference in continuous BP outcomes. Márquez Contreras 2009 reported a significantly higher proportion of patients achieved controlled BP target at followup in the intervention group compared with usual care (65 percent versus. 35 percent; P=0.01).69 The third study compared SMBP plus contract plus pill pack with control and both groups received education.43 The fourth study compared SMBP via telephone upload with letters for treatment recommendation to patients and providers with usual care.54 Statistical analyses for the between-group differences in the last two studies were not reported.

#### Summary

##### Clinical Events

Only one C quality study reported on clinical events, finding lower mortality and composite of mortality and end-stage renal disease in patients using SMBP, but no difference in end-stage renal disease by itself.81 This study was conducted in individuals with Type 1 diabetes and diabetic kidney disease and therefore has limited applicability. Due to the paucity of evidence, the strength of evidence is insufficient to make a determination as to the clinical event outcomes when comparing SMBP plus additional support to usual care.

##### BP Outcomes

Eleven of 21 trials and two of three nonrandomized studies reported statistically significant reduction in either SBP or DBP at followup favoring the SMBP with additional support intervention. The patients in these studies all had baseline uncontrolled hypertension with or without antihypertensive medications. Two trials enrolled only patients with diabetes.54,82 All six quality A trials reported a significant mean net changes in SBP (ranging from -3.4 to -8.9 mmHg) or DBP (ranging from -1.9 to -4.4 mmHg) in an SMBP plus additional support group compared with usual care at up to 12 months followup. 41,45,57,61,70,82 There were mixed results at 18 months and two studies found significant net reductions in SBP and DBP at 24 to 60 months.45,93 These changes were measured in the clinic45,61,70 and at home.57 The support in addition to SMBP in these six trials were: telemonitoring and counseling on patient adherence to antihypertensive medications;41,57 Web-based pharmacist counseling;61 telemonitoring with self-titration of antihypertensive medications;70 telemonitoring with nurse videoconference,82 and combined medication-behavioral management.45 Three quality B44,80,89 and two quality C trials73,78 also reported significant reductions in SBP or DBP using similarly diverse supports. Overall, the studies were too heterogeneous along a variety of axes to allow for a consistent explanation as to the differences in results observed across studies. It is not possible to state with certainty whether one form of additional support is superior as the additional supports examined across studies varied in the primary intents, ancillary equipments and educational materials, followup personnel, and algorithms for medication adjustments. No form of additional support was examined by more than one trial. Key Question 2 will address trials that performed direct comparisons of SMBP with additional support and SMBP alone.

Overall, in light of the consistent findings in all six quality A trials, the strength of evidence is rated as high in favor of an improvement in BP control using SMBP with some form of additional support compared to usual care.

##### Surrogate and Intermediate Outcomes (no Blood Pressure)

Eleven studies (three quality A, two quality B, and six quality C) reported data related to the number of medications prescribed and dosage.41,61,69,70,73,75,77,78,80,81,89 Evidence was mixed, with some trials finding no difference in number of medications and dose between SMBP and usual care groups, and others finding either an increase or decrease in medications with patients using SMBP with additional support. Half of studies were rated as C quality. Thus there is a weak level of evidence for lack of difference in medication dose between SMBP and usual care, primarily due to conflicting results, low study quality, and the differing methodologies employed between studies in assessing outcomes.

Six studies (one quality A, two quality B, and three quality C) reported on medication adherence using a variety of different definitions of adherence.57,63,77,78,80,89 Studies were split between finding no difference between groups and finding significantly greater adherence in the SMBP group. Given the wide variety of different definitions used and overall low study quality, the level of evidence that medication adherence was better among patients using SMBP monitoring is rated as weak.

Three studies (two quality A, one quality C) reported on quality of life outcomes.61,70,75 A moderate level of evidence points to no difference between SMBP and usual care, as no studies found a difference between groups using a variety of assessment tools, however, with an important caveat. The quality of life measurement tools were not specifically targeted towards hypertension, and may not capture components of quality of life that are relevant in hypertensive patients who use SMBP devices.

Evidence for no difference in adverse drug reactions is limited, as only one C quality study was found for this outcome.69

Due to the inconsistency of findings, as well as heterogeneity of outcome definitions used, the strength of evidence for failing to find a difference between SMBP with some form of additional support versus usual care is rated as low across surrogate and intermediate outcomes.

##### Health Care Encounters

Seven quality C studies reported on health care encounter outcomes.53,61,70,73,78,81,89 Evidence was mixed, with five studies showing no difference in effect, one outcome showing SMBP to have more visits, and one outcome showing SMBP to have fewer health care provider visits. One study looking at electronic or phone communication found more encounters with pharmacist counseling plus Web training compared to usual care, but not with Web training compared to usual care.61 Given the inconsistency in findings, the strength of evidence that health care encounters were not different in patients using SMBP monitoring versus usual care is rated as low.

## Key Question 2 In studies of SMBP monitoring, how do clinical, surrogate, and intermediate outcomes (including SMBP monitoring adherence) vary by the type of additional support provided?

For Key Question 2, we included only studies of interventions using SMBP monitoring as a principal part of the medical intervention in individuals with hypertension. The first portion of this section discusses studies that compared SMBP with additional support versus SMBP without additional support or with different additional support. The second discusses atypical studies that did not clearly fit into the context of Key Question 2 but used SMBP or home BP monitoring in all patients and were sufficiently relevant for inclusion. Descriptions of all studies that addressed Key Question 2 are summarized in Table D-27 (descriptions of the interventions) and Table D-28 (descriptions of the study characteristics).

### Comparison of SMBP With Versus Without Additional Support

Twelve RCTs (11 full reports43-46,49,52,61,64,69,74,77 and one conference abstract50) directly compared SMBP plus additional support versus SMBP alone or with less intensive additional support. Eleven were RCTs and one was a quasi-randomized study. Two studies were rated quality A, four quality B, and five quality C. The conference abstract was not graded for quality due to insufficient data. Three studies were published before 1990.^43,64,77^

The types of additional support varied widely across trials with regards to what, how, and by whom it was delivered. Modalities of additional support consisted of a mixture of educational interventions, behavioral interventions or disease management by a nurse or pharmacist, medication management based on decision support, a hypertension informational leaflet, a BP and medication recording card, electronic transmission of SMBP measurements, Web sites/training for patient provider communication, or home visits. Change in medication management as a result of monitoring could be initiated by study personnel such as a nurse or pharmacist, the patient, or the primary care physician. Seven studies used automated SMBP devices (i.e., devices that automatically inflate the sphygmomanometer and measure BP),44-46,49,52,61,74 while the remainder did not describe the monitor type (Table D-1 in Appendix D).43,50,64,69,77

All studies explicitly qualified that patients had essential hypertension. Studies included patients with hypertension irrespective of whether these patients were on antihypertensive treatment upon study entry. Six included only patients with poorly controlled hypertension despite being on antihypertensive medication.43,45,50,61,69,74

Across relevant trial groups, mean baseline SBP ranged from 126 to 179 mmHg and DBP ranged from 70 to 103 mmHg. The mean age of patients ranged from 50 to 72 years and the proportion of men ranged from 33 to 92 percent. The size of the studies (excluding study groups not relevant for this Key Question) ranged from 34 to 828 (total = 3311 across studies). Six studies did not report the prevalence of comorbid conditions. Five studies reported on the prevalence of diabetes, which ranged from 22 and 43 percent.44-46,49,52 Other comorbid conditions reported included cardiovascular disease in one study (15 percent in Carrasco 2008) and chronic kidney disease in another (7 percent in Brennan 2010).

The primary methodological concerns of the reviewed studies included high dropout rates and incomplete reporting. Overall, the studies are applicable to adults with hypertension in the outpatient setting with the ability to self-monitor BP and with limited comorbid conditions.

#### Clinical Events

No trial examined clinical event outcomes.

#### Blood Pressure Outcomes

All 12 studies provided data on BP outcomes. Followup durations ranged from 3 to 24 months, with only Bosworth 2009 and Bosworth 2011 having followup periods longer than 1 year. The BP outcome was based on clinic BP in nine studies,43-45,49,50,52,61,69,77 home BP in one study,64 both in one study46 and 24 hour ABPM in one study74 . Reported BP outcomes included both categorical outcomes, where the outcomes were defined as achieving a predefined BP target (e.g., clinic SBP <140 mmHg), and continuous outcomes, where net differences of SBP and DBP between baseline and final measurements, or, in one study, differences between final values were given. Meta-analyses were not performed due to the great heterogeneity of interventions across trials.

##### Categorical BP Outcomes

(Table D-29, Figure 10)

Figure 10 Forest plot of relative risk of “adequate” BP at followup in RCTs of SMBP with additional support versus SMBP monitoring alone, by time of outcome measurement

ABP = ambulatory blood pressure; BP = blood pressure (systolic/diastolic); DBP = diastolic blood pressure; DM = coexisting diabetes mellitus; n/N Cx = the number of participants with adequate BP control/total in the control (SMBP alone) group; n/N Tx = the number of participants with adequate BP control/total in the intervention (SMBP with additional support) group; RCT = randomized controlled trial; RR = relative risk; SMBP = self measured blood pressure monitoring

Black circles indicate relative risk for each study. The letters in brackets to the left of interventions with additional support refer to the categories in Table 1.

*Studies with same name and intervention, with an asterisk, represent the same study arms at different followup times.

†Comparator is not SMBP alone; comparison is SMBP+Medication Management versus SMBP+Behavioral management.

Notes:

Estimates favoring additional support (the more intensive intervention) are to the right, in contrast to Figures 5-9 & 11.

Bosworth 2011^45^ Reported as differences in BP control (from a regression model). RR values derived from figure of estimated proportion in BP control.

Bosworth 2011A45 Both groups had behavioral management.

Bosworth 2011B45 Both groups had medication management.

Marquez Contreras 2009A69 Both groups had leaflet.

Marquez Contreras 2009B69 Both groups had card.

Green 2008^61^ Both groups had Web site.

This forest plot displays the relative risk of adequate blood pressure with confidence intervals for individual trials. The trials are categorized by duration of followup, including 3, 6, 12, 18, and 24 months. Trials that reported data at multiple timepoints appear multiple times. No meta-analyses are presented. The additional supports are categorized by the type of additional support as described in Table 1 At 3 months, 1 category W comparison had a nonsignificant relative risk of adequate control favoring additional support and a single study had 2 category M comparisons that both significantly favored usual care alone. At 6 months, there are 2 category M comparisons (from one trial) and 1 comparison each from categories C, E, and W. At 12 months there are 4 category C comparisons and 1 category E comparison. At 18 months, 1 study provided category C and category E comparisons. At 24 months there is 1 category C comparison. The majority of comparisons found no significant difference between SMBP alone and SMBP with additional support, with the range of relative risk for adequate BP control (from 6 to 24 months) ranging from 1.0 and 1.5, generally favoring additional support. There was no clear pattern across followup durations. One study (Bosworth 2011) compared SMBP plus a category E intervention with SMBP plus a category C intervention at 6, 12, and 18 months. The study favored category E intervention at 12 months only.

Eight studies reported findings for categorical BP outcomes, which consisted of seven fully reported RCTs (two quality A study, 4 quality B studies and one quality C study), and one quasi-randomized study graded quality C.44-46,49,61,69,74,77 BP targets varied from <120/80 to <140/90 mmHg across studies, and in one study consisted of discrete reductions in SBP and DBP.77 In three studies, BP targets were lower for individuals with diabetes (clinic BP <130/80 rather than 140/90 mmHg).44,45,69

Green 2008 reported a significantly higher proportion of patients achieving a BP target with the addition of pharmacist counseling to combined SMBP plus Web training (56 versus 36 percent; RR 1.54; 95 percent CI 1.26, 1.88; P<0.001). Marquez Contreras 2009 reported that individuals using SMBP who also received a card for medication monitoring were more likely to achieve BP control at 6 months than those who received the educational material (RR 1.2; 95 percent CI 1.02, 1.38), though the study did not explicitly analyze this comparison. In the same study, comparisons of SMBP plus leaflet with educational material versus SMBP alone or of SMBP plus the card for medication monitoring versus SMBP plus the leaflet with educational material were not statistically significant. Differences in six other studies were not statistically significant or were indeterminate. In these studies, the additional types of support consisted of telecounseling, telemonitoring, educational material, medication monitoring, Web training, physician counseling, nurse counseling, behavior or medication management. One of these studies contained three relevant groups for this Key Question: SMBP plus combined behavior and medication management, SMBP plus behavior management, and SMBP plus medication management.45 The comparisons between these groups were not prespecified, and since the results were reported as adjusted risk differences in percent of patients with BP control, it was not possible to calculate CIs. However, a higher proportion of patients in the SMBP plus behavior and medication management group achieved improvement in BP control compared to SMBP plus medication management at 18 months (estimated difference 8 percent). A higher proportion of patients in the SMBP plus behavior and medication management group achieved BP control compared to SMBP plus behavior management at 18 months (estimated difference 11 percent). And a higher proportion of patients in the SMBP plus medication management group achieved BP control compared to SMBP plus behavior management at 18 months (estimated difference 2.6 percent). Based on relative risk values derived from a figure of estimated proportions in BP control, none of the risk ratios appeared to differ statistically.

##### Continuous BP Outcomes

Ten studies reported continuous clinic BP outcomes. Two studies were rated quality A, three quality B, and four quality C. The conference abstract was not graded for quality due to insufficient data.43-46,49,50,52,61,64,69 One quality B study provided results for continuous 24 hour ABPM.74

###### Clinic BP

(Table D-30, Figure 11)

Ten trials reported changes in clinic BP.43-46,49,50,52,61,64,69 Seven found no evidence or did not provide a measure of statistical difference for a change in BP with the addition of nurse telecounseling, behavioral management, medication management, Web plus physician counseling, telemedicine, home visitor for BP measurement, compliance contracts plus calendar pill packs plus education, or educational material plus BP and medication tracker.43-45,49,50,52,64 One of the studies reporting indeterminate results was Bosworth 2011, which included three intervention groups of SMBP plus medication and behavioral management, SMBP plus medication management, and SMBP plus behavioral management.45 Again, the comparisons of interest for Key Question 2 were not the comparisons for the study's primary analysis, and while the net differences for BP could be calculated, the confidence intervals could not. The largest net difference was for the comparison of SMBP plus combined medication and behavioral management versus SMBP plus behavioral management (-5.8 for SBP and -2.0 for DBP at 18 mos). The remaining three trials showed some benefit for BP reduction from more intense additional support.46,61,69 Brennan 2010 showed statistically lower BP for SMBP plus counseling by a nurse versus SMBP for SBP at 12 months (mean difference -3.0; P=0.03), but no statistically significant difference for DBP. Green 2008 reported statistically significant results favoring the addition of pharmacist counseling to SMBP plus a Web training for SBP and DBP at 12 months. Results were consistently significant before and after adjustment for baseline BP, sex, having a home BP monitor before trial, and clinic (mean difference for adjusted SBP -6.0 mmHg; P<0.001 and for adjusted DBP -2.6 mmHg; P<0.001). Márquez Contreras 2009 reported statistically significant results for DBP (mean net difference -2.2; 95 percent CI -3.9, -0.5) but not SBP at 6 months favoring the addition of a card for recording BP and monitoring of medication pill counts to SMBP plus educational material on a leaflet, though the study did not explicitly analyze this comparison. However, comparisons of the SMBP with and without the educational material or of SMBP plus the card for medication monitoring versus SMBP plus educational material on a leaflet groups were not statistically significant.

Only two studies provided results regarding more intensive versus less intensive additional support in addition to SMBP beyond 12 months. These were nonsignificant or of uncertain statistical significance.44,45 In Bosworth 2009, the loss to followup was 30 percent at 24 months.

###### Ambulatory BP

(Table D-31)

One study evaluated SMBP with telemonitoring versus SMBP and examined 24 hour SMBP and DBP on ABPM.74 The study showed a statistically significant net difference for SBP of -7.2 (95 percent CI -13.8, -0.6, P=0.032) in favor of SMBP with telemonitoring, but not for DBP (-2.0, 95 percent CI -6.2, 2.2, P=0.35).

#### Quality of Life

(Table D-32)

Two studies reported continuous outcomes for quality of life and for mental health.49,61 The quality of life instruments were SF-36 and SF-12 questionnaires, the mental health instrument the State-Trait Anxiety Inventory for Adults with the “state anxiety” and “trait anxiety” components.

Green 2008, a quality A trial, had a followup of 1 year, and compared SMBP plus Web training with pharmacist counseling versus SMBP plus Web training. Carrasco 2008 (quality B) had a followup of 6 months, and compared SMBP plus Web plus physician counseling versus SMBP alone. Both studies found no statistically significant differences in comparative outcomes concerning quality of life or anxiety.

#### Medication Dosage

(Tables D-33 and 34)

Five studies reported outcomes related to medication prescriptions, three of which reported categorical outcomes and two a continuous outcome.46,64,74,77 Two studies were rated quality A, two quality B and one quality C for these outcomes. Followup durations ranged from 3 to 13 months.

Brennan 2010 compared SMBP plus nurse counseling versus SMBP alone and found no statistically significant difference in the proportion of patients taking two or more antihypertensive medication drug-classes as reported by the patient or determined by pharmacy claims after a mean followup of 13 months. Johnson 1978 and Pierce 1984 looked at medical inertia (defined as no medication change versus either an increase or decrease in medication). In addition to SMBP, Johnson 1978 used home visits for BP measurement and Pierce 1984 used education. Neither found any statistically significant difference between groups.

Green 2008 reported that the number of hypertension medication drug-classes used after 1 year followup was greater with the addition of pharmacist counseling to combined SMBP plus Web training (net difference 0.2; 95 percent CI 0.1, 0.4; P<0.01). Neumann 2011 reported “No significant change was observed during the study period” in number of HTN medication classes.

#### Medication Adherence

(Tables D-35 and 36)

Three quality C trials provided data on outcomes related to medication adherence.44,64,77 Duration of followup ranged from 6 to 24 months. Measures for medication adherence were proportion of individuals returning their logs with BP recordings (Bosworth 2009), proportion of prescribed pills that were consumed (Johnson 1978), or undefined (Pierce 1984). None of the three studies found a statistically significant difference between groups in medication adherence.

#### Health Care Encounters

(Table D-37 and 38)

Five studies provided data on health care encounters.44-46,49,61 All five studies were graded quality C for these outcomes. Followup durations ranged from 6 to 24 months. In four studies, the addition of a behavioral intervention had no statistically significant effect on the number of outpatient encounters and the proportion of hospitalized individuals over 2 years; the addition of disease management had no effect the number of primary care visits, cardiac visits, or specialist visits per patient per year; the addition of telemedicine had no effect on the median number of consultations or number of hospital admissions; and the number of primary care and specialty care encounters over 18 months was similar across 4 groups of SMBP plus medication and behavioral management, SMBP plus medication management, SMBP plus behavioral management and usual care without SMBP. In the fifth study, Green 2008, there was also no statistically significant difference for primary care visits, or for inpatient and urgent care/emergency use. The study reported a modest but significant decrease in the percentage of patients with office visits to a specialist in 12 months in the SMBP plus Web training plus pharmacist counseling group relative to baseline and to patients in the other arms but the statistical significance was not clear.

Green 2008 also looked at communication and found a statistically significantly higher number of electronic message thread (P nd), patient initiated electronic message threads (P<0.01) and phone encounters (P<0.001) in the SMBP plus Web training plus pharmacist counseling group than in the SMBP plus Web training group.

#### Miscellaneous Outcomes

(Tables D-26 and 39)

Two trials reported miscellaneous outcomes.61,69 Marquez Contreras 2009 (quality C) provided data on adverse drug reactions after 6 months. These did not differ statistically significantly across all four study groups of SMBP plus use of educational leaflet, SMBP plus use of card for recording of medication, SMBP plus use of leaflet plus card, and usual care.

Green 2008 (quality A) reported consumer satisfaction concerning patient's experiences and satisfaction with health care service measured with the Consumer Assessment of Healthcare Providers and Systems instrument after 1 year. This study found no statistically significant differences when comparing SMBP plus Web training with pharmacist counseling versus SMBP plus Web training.

#### Subgroups and Heterogeneity

Four trials reported results from subgroup analyses: Bosworth 2011 (quality A), Green 2008 (quality A), Johnson 1978 (quality C), and a second Bosworth 2011, which is an update of Bosworth 2009 (quality B).44,45,61,64,91 Bosworth 2011 compared subgroups of 348 patients with adequate BP control (≤140/90 mmHg in patients without diabetes or ≤130/80 mmHg in those with diabetes) to 243 patients with inadequate control in a post hoc analysis.45 The study reported that patients with adequate control at baseline continued to remain in control over the 18 months of the study. For those with inadequate control, SBP net change was -1.4 mmHg at 18 months, and DBP net change was -1.3 mmHg (comparing SMBP plus combined medication and behavioral management with SMBP plus medication management). Comparing SMBP plus combined medication and behavioral management with SMBP plus behavioral management, SBP net change was -8.3 mmHg at 18 months and DBP net change was -6.6 mmHg. Comparing SMBP plus medication management with SMBP plus behavioral management, SBP net change was -6.9 mmHg at 18 months; DBP net change was -5.3 mmHg. For these comparisons, a confidence interval or P value could not be calculated as the study reported adjusted results with usual care being the reference group.

Green 2008 reported categorical and continuous BP outcomes from the subgroup of patients whose SBP at baseline was ≥160 mmHg. In this subgroup, the addition of pharmacist counseling to combined SMBP plus Web training resulted in better BP control at 12 months (RR 2.11; CI 1.22, 3.65; P<0.001) and greater reductions in SBP and DBP. This was consistently found for unadjusted SBP outcomes and after adjustment for baseline BP, sex, having a home BP monitor before trial, and clinic (net difference for adjusted SBP was not provided but P<0.001). For the DBP the unadjusted comparison was not statistically significantly different (P=0.10), although the adjusted analysis was (P<0.03). In the overall group, all 12-month BP outcomes (SBP and DBP, unadjusted and adjusted) were significantly different. However, data for the subgroup with SBP <160 mmHg at baseline were not reported, limiting the interpretability of their subgroup finding.

Johnson 1978 reported changes in adherence among subjects with initial adherence of less than 80 percent. In this subgroup, the percentage of prescribed pills that had been consumed did not differ with the addition of a visitor taking home BP measurement. This was consistent with the results in the entire study. Again, the lack of data on the study subjects with better initial adherence limits the interpretability of these findings.

As noted in the previous section on SMBP versus usual care, a post hoc data analysis of Bosworth 2009 reported a subgroup analysis by whites versus nonwhites, where nonwhites were 95 percent African American.44,91 At both 12 and 24 months of followup, white patients in the SMBP plus telecounseling group had a similar SBP and DBP compared with those in the SMBP group. In non-white patients, SBP and DBP were also similar at 12 months in the two groups. However, at 24 months, SBP was 8.8 mmHg lower and DBP was 2.9 mmHg lower in the SMBP plus telecounseling group compared with the SMBP group. These results were not statistically analyzed.

We attempted to gain an insight into the heterogeneous nature of the additional modalities of support across comparisons using the classification scheme described in Table 1. This scheme was based on our assessment of the key component differing between the two groups, as the categories are not exclusive. Six studies examined the addition of an intervention from category “C” (Counseling with regular one-on-one encounters with study personnel).44-46,50,61,64 Two of these studies showed some benefit for BP control or BP reduction.46,61 As described above, Green 2008 reported a significantly higher proportion of patients achieving a BP target at 12 months and lower SBP and DBP at 12 months with the addition of pharmacist counseling. Brennan 2010 also showed a benefit with the addition of counseling by a nurse at 12 months, albeit only for SBP and not for DBP. Two other studies showed no benefit with addition of telephonic counseling by a nurse44 or home visits.64 The conference abstract by Cheltsova 2010 examined the addition of telephonic counseling by a nurse and also found no difference. The findings from Bosworth 2011 were indeterminate for the comparison of SMBP plus combined medication and behavioral management (C+E) versus SMBP plus behavioral management (E).

Two studies45,77 examined the addition of an intervention from category “E” (Education offered in regular hypertension education classes), the addition of four educational classes. Pierce 1984 found no difference. Bosworth 2011 compared SMBP plus combined medication and behavioral management (C+E) versus SMBP plus medication management (C). The results were indeterminate.

Two studies49,74 examined the addition of an intervention from category “W” (Web-based or telephonic tools). Carrasco 2008 study added a Web site and physician counseling to SMBP, but failed to detect a difference in BP at 6 months. Neumann 2011 with addition of telemonitoring to SMBP showed statistically significant greater net change for SBP on 24 hour ABPM at 3 months but not for DBP.

One study compared SMBP with an intervention from category “C” to and intervention from category “E”. The findings from Bosworth 2011 were indeterminate for the comparison of SMBP plus medication management (C) versus SMBP plus behavioral management (E).

Three studies were placed in category “M” (Miscellaneous).43,69 Binstock 1988 examined the addition of compliance contract plus calendar pill packs to SBMP plus education and found effect estimates in favor of the less intensive treatment group, but did not provide statistical testing. Marquez Contreras 2009 compared addition of a leaflet with educational materials on hypertension in one group, a card for recording BP and pill counts in another group, and a combination of both in a third group. The combination of the card plus leaflet compared to the addition of the leaflet only resulted in significantly lower DBP at 6 months (SBP did not differ significantly between groups). The addition of the card plus leaflet versus just the leaflet also resulted in better BP control. However, as previously mentioned, the study did not explicitly analyze this comparison. Further, comparisons of the SMBP plus the leaflet containing educational material versus SMBP, or of SMBP plus the card for medication monitoring versus SMBP plus the leaflet containing educational material were not statistically significant. Finally, Dawes 2010 found no difference in BP when comparing SMBP plus educational material plus a BP and medication tracking tool with SMBP plus educational material alone.

#### Summary

##### Clinical Events

No studies of SMBP plus additional support versus SMBP without additional support (or plus a less intensive additional support) provide evidence on clinical event outcomes. Thus, there is insufficient evidence regarding clinical events.

##### BP Outcomes

Twelve trials of SMBP plus additional support versus SMBP without additional support (or plus a less intensive additional support) provided BP results across five separate timepoints ranging from 3 to 24 months.43,44,46,49,50,52,61,64,69,77 In total, 3311 patients with hypertension were included. Two trials were graded quality A, four quality B, and five quality C, and one conference abstract was not graded. Additional support consisted of a mixture of behavioral interventions or disease management by a nurse or pharmacist, medication management, educational interventions, electronic transmission of BP measurements, Web sites/training for patient-provider communication, telemonitoring, BP recording cards, BP and medication tracking tool, hypertension information leaflets, or home visits. Change in medication management as a result of the monitoring could be initiated by the patient, nurse, pharmacist, or the primary care physician. The most commonly cited comorbid condition in these studies was type 2 diabetes. Nine studies reported clinic BP outcomes, one study reported only home BP, one study reported both and one reported ABPM.43,44,46,49,50,52,61,64,69,77 I Meta-analysis was not undertaken due to clinical heterogeneity.

Four trials found statistically significant benefits for the more intensive additional support for either SBP, DBP, BP control, or combinations thereof.46,61,69 Green 2008 was the only study rated quality A, and showed consistent benefit for SBP, DBP continuous outcomes and for categorical BP outcome. The additional support examined in this study was pharmacist counseling added to SMBP plus use of Web training. The other eight trials (six full reports and one abstract) were indeterminate for a difference. Across studies, no clear patterns could be discerned to explain the heterogeneity in results. The small number of studies and their distribution across different categories of additional support makes it impossible to draw conclusions regarding the potential effects of specific additional support or its interactions with SMBP. Overall, the strength of evidence is rated as low and fails to support a difference between SMBP plus additional support versus SMBP with no additional support or with less intensive additional support in BP.

Four trials reported subgroup analyses by control of baseline BP at baseline (controlled or not controlled), degree of adherence (lower adherence) or race (white versus predominantly African American). Two of these studies did not provide analyses for the comparisons of SMBP plus additional support versus SMBP without additional support or with another type of additional support and two studies did not provide complete subgroup analyses data.

##### Surrogate and Intermediate Outcomes (not Blood Pressure)

Five trials of SMBP plus additional support versus SMBP without additional support (or plus a less intensive additional support) reported data on categorical and continuous medication number and dosage (two quality A and two quality B, one quality C).46,61,64,77 Studies reported the numbers of patients taking two or more classes of medications, medical inertia (defined as no medication change versus either an increase or decrease in medications), and the number of medication drug-classes. Four trials using additional support consisting of nurse counseling, home visits for BP measurement, telemonitoring or education found no difference between SMBP plus additional support versus SMBP. One trial found a somewhat greater mean number of medication drug-classes with SMBP plus pharmacist care plus Web training. A weak level of evidence suggests no difference in medication use.

Two trials reported quality of life or anxiety outcomes (one quality A and one quality B). The studies used the SF-36 and SF-12 quality of life instruments and the State-Trait Anxiety Inventory, a mental health questionnaire. Both found no differences using these measures. A weak level of evidence fails to support a difference in quality of life or anxiety outcomes.

Three trials (all quality C) reported on medication adherence.44,64,77 Using different measures in each study, none found a significant difference in medication adherence. One trial also found no difference in a subgroup of individuals with lower baseline adherence.64 A weak level of evidence fails to support a difference in medication adherence.

Two trials reported miscellaneous outcomes. One study (quality C) found no difference in adverse drug reactions across four groups with different forms of additional support or usual care.69 One study (quality A) found no difference for consumer satisfaction measured by the Consumer Assessment of Healthcare Providers and Systems instrument.61 The level of evidence is insufficient for miscellaneous outcomes.

Due to the inconsistency of findings, as well as heterogeneity of outcome definitions used, the strength of evidence for failing to find a difference between SMBP with some form of additional support versus usual care is rated as low across surrogate and intermediate outcomes.

##### Health Care Encounters

Five quality C trials compared SMBP plus additional support to SMBP without additional support and reported results for health care encounters. Additional support included counseling by a nurse or pharmacist, behavioral intervention, medication management, Web training or telemedicine. All reported on outpatient primary care visits, two reported on hospital admissions, and three reported on cardiac and other specialist visits. No study found a difference in the numbers of outpatient visits or hospital admissions between patients receiving SMBP with or without additional support. One study found a higher number of any or patient initiated electronic message threads or phone encounters with the addition of pharmacist counseling to SMBP plus Web training. Despite the consistency across trials for visits, due to their small number and general poor quality, overall, the strength of evidence is rated as low and fails to support a difference for health care utilization by the addition of auxiliary support to SMBP compared to SMBP without additional support or with less intensive additional support. One study showed that the addition of pharmacist counseling to training in a patient Web portal increased electronic and telephonic communication.

### Atypical Studies Using SMBP Monitoring in all Groups

Three RCTs did not clearly fit into the context of Key Question 2, but were nonetheless of sufficient interest for inclusion.65,84,85 These studies are discussed individually below, and are summarized in Table D-27 (descriptions of the interventions) and Table D-28 (descriptions of the study characteristics).

#### SMBP With Graphical Display Versus SMBP Without Graphical Display

(Tables D-40 Through 42)

Kabutoya 2009, a quality C RCT, compared SMBP plus a graph-equipped SMBP monitor versus use of the SMBP monitor without the graphic display. The graph-equipped SMBP monitor displayed weekly and monthly averaged BPs, while in the control group the same SMBP monitor displayed only a single BP-value. The study included 65 patients, and was rated quality C because of incomplete and selective reporting.

At 6 months, the percentage of patients with home BP below 135⁄85 mmHg in the graph-equipped SBPM group did not differ from that in the conventional SMBP group (Table D-40). However, the graph-equipped monitor group displayed better BP control at 2 months (41 versus 13 percent, P<0.05), 4 months (40 versus 11 percent, P<0.05), and 5 months (37 versus 16 percent, P<0.05).

At 6 months, continuous home DBP and SBP did not differ between groups (Table D-41). However, at 2 months, home SBP was significantly lower in the group with the graph-equipped SMBP monitor than in the control monitor group (estimated mean difference in home SBP approximately -6.3 mmHg; P<0.05). Clinic BP results were incompletely reported. It was stated only that clinic SBP was significantly lower in the graph-equipped SMBP group at 3 months (net difference -9.7 mmHg; P<0.05), and presumably did not differ at the other time points.

The number of medications was significantly greater in the graph-equipped SMBP group than in the conventional SMBP group at 5 and 6 months (3.74 versus 2.76 at 6 months; P<0.02) (Table D-42). It was not explicitly reported for other timepoints, presumably because it did not differ.

This study provides insufficient evidence for use of a graphical display along with SMBP.

#### SMBP With BP Medication Titration Based on Home BP Versus SMBP With Titration Based on Clinic BP

(Tables D-41 Through 43)

Staessen 2004 randomized a total of 400 patients into two groups. Both groups used SMBP and had their BPs transmitted to study personnel. This was followed by blinded stepwise medication titration to reach the same BP target: a target DBP between 80 and 89 mmHg, but in one group drug treatment was adjusted based on home BP, while in the other group, it was adjusted based on clinic BP. This study was rated quality A for all outcomes except for those related to left ventricular hypertrophy, for which it was rated quality C.

At 12 month followup, BP in the home BP titration group was significantly higher than in the clinic BP titration group (Table D-41). This was consistent for all BP outcomes. For clinic BP, the differences were 6.8 mmHg for SBP (95 percent CI 3.6, 9.9; P<0.001) and 3.5 mmHg for DBP (95 percent CI 1.9, 5.1; P<0.001). For home BP, the differences were 4.9 mmHg for SBP (95 percent CI 2.5, 7.4; P<0.001) and 2.9 mmHg for DBP (1.5, 4.4; P<0.001). For daytime ambulatory BP, the differences were 5.3 mmHg for SBP (95 percent CI 2.6, 7.9; P<0.001) and 3.2 mmHg for DBP (95 percent CI 1.5, 4.8; P<0.001). For nighttime ambulatory BP, the differences were 4.8 mmHg for SBP (95 percent CI 2.1, 7.5; P<0.001) and 3.0 mmHg for DBP (95 percent CI 1.3, 4.7; P<0.001). For 24 hour ABPM, the differences were 4.9 mmHg in SBP (95 percent CI 2.5, 7.4; P<0.001) and 2.9 mmHg in DBP (95 percent CI 1.4, 4.4; P<0.001).

The antihypertensive treatment score, which measured the intensity of equipotent drugs, was significantly lower with home BP titration than with clinic BP titration (P=0.007 at last visit, approximately after 12 months) (Table D-42). Adverse events as assessed by symptom score did not differ significantly between groups.

The number of patients who permanently stopped antihypertensive treatment was significantly greater in the home BP titration group than in the clinic BP titration group (RR 2.34; 95 percent CI 1.48, 3.69; P<0.01) (Table D-43). The proportion of patients proceeding to multiple-drug treatment was not significantly different between the two groups (RR 0.84; 95 percent CI 0.66, 1.06).

Also reported were left ventricular hypertrophy outcomes in a subgroup of patients in both groups. Serial electrocardiograms were available in 355 patients, as well as echocardiographic results in 54 patients. Outcome measures were left ventricular wall thickness, fractional shortening, and the ratio of the peak left ventricular inflow velocities in early diastole and at atrial contraction. After adjustment for baseline values, sex, age, and body mass index, the between-group differences in the changes in most electrocardiographic and echocardiographic measurements were small and statistically nonsignificant. The only statistically significant finding was a marginal clinical benefit for the echocardiographic ratio of the peak left ventricular inflow velocities in early diastole and at atrial contraction (between group difference -0.22; 95 percent CI -0.39, 0.05; P=0.02) in the clinic BP titration versus the home BP titration group.

This study provides insufficient evidence to clarify whether medication titration should be based on SMBP or clinic BP. But it highlights the challenge of selecting a BP target for SMBP since SMBP is generally lower than clinic BP. In a response to a letter to the editor about their study, the study authors suggest that a lower limit for the diastolic blood pressure needs to be chosen for adjusting antihypertensive drug treatment based on SMBP than on clinic BP if the same clinic BP is to be achieved.32 Another study, Verberk 2007, included under KQ1, also adjusted antihypertensive therapy in a blinded fashion based on the same BP target of 120-140/80-90 for either SMBP or clinic BP.20 It also showed a reduction in the number of drugs, with a trend for worse clinic BP control in the SMBP group.

#### Home BP Monitoring by a Family Member Versus SMBP

(Tables D-40 and 41)

Stahl 1984 was a quasi-RCT of 202 patients assigned either to home BP monitoring by a family member or SMBP by the patient. This study was rated quality C due to a lack of randomization, a dropout rate of 67 percent at 36 months, and apparent reporting errors. There was no clear pattern for consistent differences in BP control (Table D-40) or DBP (Table D-41) between groups over time. Although a significantly greater reduction in DBP was observed in the SMBP group versus the family measured group for the 7–12 months interval, this effect reversed at subsequent followup.

There is insufficient evidence to clarify whether the efficacy for BP reduction depends on home BP measurement by a family member versus the patient.

## Key Question 3 How do different devices for SMBP monitoring compare with each other (specifically semiautomatic or automatic versus manual) in their effects on clinical, surrogate, and intermediate outcomes (including SMBP monitoring adherence)?

For Key Question 3, we searched for studies that directly compared SMBP monitoring devices. We found no study comparing devices that were of a priori interest to the reviewers or the Technical Expert Panel. Most devices used in the trials reviewed for Key Question 1 and 2 used automated devices. There is insufficient evidence comparing SMBP monitors.

## Key Question 4 In studies of SMBP monitoring, how does achieving BP control relate to clinical and surrogate outcomes?

In order to address Key Question 4, we searched for studies that reported both BP control outcomes and clinical or surrogate outcomes with sufficient data. Sawicki 1995 was the only eligible study that reported on clinical outcomes (death, kidney, and diabetes-related outcomes).81 However, the study provided no data on how many patients achieved BP control nor other data relevant to this Key Question.

Based on the studies reviewed, the evidence is insufficient regarding how achieving BP control relates to clinical and surrogate outcomes under an SMBP monitoring regime.

## Key Question 5 In people with hypertension how does adherence with SMBP monitoring vary by patient factors?

To address Key Question 5, our literature search was restricted to studies that addressed the outcome of adherence with SMBP monitoring and employed a longitudinal design with at least 100 participants followed for at least 8 weeks. As a prerequisite, studies also had to evaluate adherence rates based on predictors. Only one study met criteria.66

### Adherence With SMBP Monitoring

Kim 2010, a quality B study, investigated predictors for adherence with SMBP monitoring and its relationship to BP control in 377 middle-aged Korean Americans. SMBP was employed as part of an intervention that consisted of education about hypertension and its management, SMBP with telephonic transmission of BP measurements, and telephone counseling by a nurse. Participants were required to measure their BP twice daily. Participants were considered adherent if they had transmitted a minimum of 12 readings per week for at least 24 weeks of the 48-week study. The cohort consisted of equal numbers of men and women, more than half of whom had a college education or higher and more than half of whom were employed either full or part time. Adherence with SMBP was observed in 60 of 377 (16 percent) participants.

Multivariable analysis that adjusted for demographic variables, hypertension characteristics, comorbidity, body mass index, psychosocial variables and ancillary interventions, showed that age >60 years was associated with better adherence with SMBP (OR 5.3; 95 percent CI 1.8, 15.8) compared to younger age groups. The authors noted that older age may have been a surrogate for other factors such as work status or lifestyle patterns. Patients with depression scores of greater severity (>90th percentile) rated on a depression scale specific for Korean Americans were less likely to be adherent (OR 0.2; 95 percent CI 0.04, 0.9). Notably, the study also found that patients with higher depression scores were less likely to have knowledge and awareness regarding hypertension. Other factors explored for their relationship to adherence that did not show significant influences were marital status, education, work status, medication, duration of hypertension, comorbidity, family history (presumably for hypertension, though this was not specified in the paper), body mass index, and knowledge and awareness regarding hypertension.

### Summary

In a single study of Korean Americans, older age was independently associated with greater adherence to SMBP monitoring, and the presence of depression was independently associated with lower adherence. Other tested factors were not associated with adherence. As data are limited to that of a single study, the strength of evidence is insufficient regarding predictors of adherence with SMBP monitoring.