# References

1 Chobanian AV, Bakris GL, Black HR, et al. The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. 2003;289(19):2560-72. [Erratum appears in JAMA. 2003 Jul 9;290(2):197]. [pmid: 12748199].
2 Falkner B. Hypertension in children and adolescents: epidemiology and natural history. Pediatr Nephrol. 2010;25(7):1219-24. [pmid: 19421783].
3 The fourth report on the diagnosis, evaluation, and treatment of high blood pressure in children and adolescents. Pediatrics. 2004;114(2 Suppl 4th Report):555-76. [pmid: 15286277].
4 Kearney PM, Whelton M, Reynolds K, et al. Worldwide prevalence of hypertension: a systematic review. J Hypertens. 2004;22(1):11-19. [pmid: 15106785].
5 The World Health Report 2002 - Reducing Risks, Promoting Healthy Life. http://www.who.int/whr/2002/en/. 2002. 1-31-2011.
6 Whitworth JA. 2003 World Health Organization (WHO)/International Society of Hypertension (ISH) statement on management of hypertension. J Hypertens. 2003;21(11):1983-1992. [pmid: 14597836].
7 Roger VL, Go AS, Lloyd-Jones DM, et al. Heart disease and stroke statistics--2011 update: a report from the American Heart Association. Circulation. 2011;123(4):e18-e209. [pmid: 21160056].
8 Yoon SS, Ostchega Y, Louis T. Recent trends in the prevalence of high blood pressure and its treatment and control, 1999-2008. NCHS Data Brief. 2010;(48):1-8.
9 Vasan RS, Beiser A, Seshadri S, et al. Residual Lifetime Risk for Developing Hypertension in Middle-aged Women and Men: The Framingham Heart Study. JAMA. 2002;287(8):1003-10. [pmid: 11866648].
10 Ezzati M, Oza S, Danaei G, et al. Trends and cardiovascular mortality effects of state-level blood pressure and uncontrolled hypertension in the United States. Circulation. 2008;117(7):905-14. [pmid: 18268146].
11 Law M, Wald N, Morris J. Lowering blood pressure to prevent myocardial infarction and stroke: a new preventive strategy. Health Technol Assess. 2003;7(31):1-94. [pmid: 14604498].
12 Neal B, MacMahon S, Chapman N. Effects of ACE inhibitors, calcium antagonists, and other blood-pressure-lowering drugs: results of prospectively designed overviews of randomised trials. Blood Pressure Lowering Treatment Trialists' Collaboration. Lancet. 2000;356(9246):1955-64. [pmid: 11130523].
13 Gueyffier F, Froment A, Gouton M. New meta-analysis of treatment trials of hypertension: improving the estimate of therapeutic benefit. J Hum Hypertens. 1996;10(1):1-8. [pmid: 8642184].
14 Staessen JA, Gasowski J, Wang JG, et al. Risks of untreated and treated isolated systolic hypertension in the elderly: meta-analysis of outcome trials. Lancet. 2000;355(9207):865-72. [pmid: 10752701].
15 Stamler R. Implications of the INTERSALT study. Hypertension. 1991;17(1 Suppl):I16-20. [pmid: 1986996].
16 Whelton PK, He J, Appel LJ, et al. Primary prevention of hypertension: clinical and public health advisory from The National High Blood Pressure Education Program. JAMA. 2002;288(15):1882-8. [pmid: 12377087].
17 Thavarajah S, White WB, Mansoor GA. Terminal digit bias in a specialty hypertension faculty practice. J Hum Hypertens. 2003;17(12):819-22. [pmid: 14704725].
18 Ghuman N, Campbell P, White WB. Role of ambulatory and home blood pressure recording in clinical practice. Curr Cardiol Rep. 2009;11(6):414-21. [pmid: 19863865].
19 Verberk WJ, Kroon AA, Thien T, et al. Prevalence of the white-coat effect at multiple visits before and during treatment. J Hypertension. 2006;24(12):2357-63.
20 Verberk WJ, Kroon AA, Lenders JW, et al. Self-measurement of blood pressure at home reduces the need for antihypertensive drugs: a randomized, controlled trial. Hypertension. 2007;50(6):1019-25. [pmid: 17938383].
21 Pickering TG, James GD, Boddie C, et al. How common is white coat hypertension?. JAMA. 1988;259(2):225-8. [pmid: 3336140].
22 Niiranen TJ, Jula AM, Kantola IM, et al. Prevalence and determinants of isolated clinic hypertension in the Finnish population: the Finn-HOME study. J Hypertens. 2006;24(3):463-70. [pmid: 16467649].
23 Pickering TG, Davidson K, Gerin W, et al. Masked hypertension. Hypertension. 2002;40(6):795-6. [pmid: 12468559].
24 O'Brien E. Unmasking hypertension. Hypertension. 2005;45(4):481-2. [pmid: 15790959].
25 Appel LJ, Robinson KA, Guallar E, et al. Utility of blood pressure monitoring outside of the clinic setting. Evid Rep Technol Assess (Summ). 2002;(63):1-5. [pmid: 15523745].
26 Celis H, Den HE, Staessen JA. Self-measurement of blood pressure at home in the management of hypertension. Clin Med Res. 2005;3(1):19-26. [pmid: 15962017].
27 O'Brien E, Asmar R, Beilin L, et al. European Society of Hypertension recommendations for conventional, ambulatory and home blood pressure measurement. J Hypertension. 2003;21(5):821-48.
28 Imai Y, Otsuka K, Kawano Y, et al. Japanese society of hypertension (JSH) guidelines for self-monitoring of blood pressure at home. Hypertens Res. 2003;26(10):771-82. [pmid: 14621179].
29 Sphygmomanometers for clinical use. http://www.dableducational.org/sphygmomanometers/devices_1_clinical.html#ClinTable. 2009. 7-19-2011.
30 Verberk WJ, Kroon AA, Kessels AG, et al. Home blood pressure measurement: a systematic review. J Am Coll Cardiol. 2005;46(5):743-51. [pmid: 16139119].
31 Nesbitt SD, Amerena JV, Grant E, et al. Home blood pressure as a predictor of future blood pressure stability in borderline hypertension. The Tecumseh Study. Am J Hypertens. 1997;10(11):1270-80. [pmid: 9397247].
32 Staessen JA, Den Hond E, O'Brien ET. Guidelines for Home- and Office-Based Blood Pressure Monitoring—Reply. JAMA. 2004;291(19):2315-16. [pmid: 15150201].
33 Best blood-pressure monitors. Consumer Reports Health. http://www.consumerreports.org/health/healthy-living/home-medical-supplies/blood-pressure-monitors/blood-pressure-monitor/overview/blood-pressure-monitor-ov.htm. 2010.
34 Whitlock EP, Lopez SA, Chang S, et al. AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol. 2010;63(5):491-501. [pmid: 19540721].
35 Wallace BC, Trikalinos TA, Lau J, et al. Semi-automated screening of biomedical citations for systematic reviews. BMC Bioinformatics. 2010;11:55. [pmid: 20102628].
36 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. Journal of Clinical Epidemiology. 2010;63(5):513-23. [pmid: 19595577].
37 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
38 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
39 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
40 Artinian NT, Washington OG, Templin TN. Effects of home telemonitoring and community-based monitoring on blood pressure control in urban African Americans: a pilot study. Heart Lung. 2001;30(3):191-9. [pmid: 11343005].
41 Artinian NT, Flack JM, Nordstrom CK, et al. Effects of nurse-managed telemonitoring on blood pressure at 12-month follow-up among urban African Americans. Nurs Res. 2007;56(5):312-22. [pmid: 17846552].
42 Bailey B, Carney SL, Gillies AA, et al. Antihypertensive drug treatment: a comparison of usual care with self blood pressure measurement. J Hum Hypertens. 1999;13(2):147-50. [pmid: 10100064].
43 Binstock ML, Franklin KL. A comparison of compliance techniques on the control of high blood pressure. Am J Hypertens. 1988;1(3:Pt 3):t-194S.
44 Bosworth HB, Olsen MK, Grubber JM, et al. Two self-management interventions to improve hypertension control: a randomized trial. Ann Intern Med. 2009;151(10):687-95. [pmid: 19920269].
45 Bosworth HB, Powers BJ, Olsen MK, et al. Home blood pressure management and improved blood pressure control: results from a randomized controlled trial. Archives of Internal Medicine. 2011;171(13):1173-80. [pmid: 21747013].
46 Brennan T, Spettell C, Villagra V, et al. Disease management to promote blood pressure control among African Americans. Popul Health Manag. 2010;13(2):65-72. [pmid: 20415618].
47 Broege PA, James GD, Pickering TG. Management of hypertension in the elderly using home blood pressures. Blood Press Monit. 2001;6(3):139-44. [pmid: 11518836].
48 Carnahan JE, Nugent CA. The effects of self-monitoring by patients on the control of hypertension. Am J Med Sci. 1975;269(1):69-73. [pmid: 1130437].
49 Carrasco MP, Salvador CH, Sagredo PG, et al. Impact of patient-general practitioner short-messages-based interaction on the control of hypertension in a follow-up service for low-to-medium risk hypertensive patients: a randomized controlled trial. IEEE Trans Inf Technol Biomed. 2008;12(6):780-91. [pmid: 19000959].
50 Cheltsova A, Patel S, Young H, et al. A Structured Program for Hypertension Control in an Urban, High Risk Population: A Randomized Trial. Hypertension. 2010;56(5):e109.
51 Dalfó i Baqué A, Capillas Peréz R, Guarch Rocarias M, et al. [Effectiveness of self-measurement of blood pressure in patients with hypertension: the Dioampa study]. [Spanish (English translation available)]. Aten Primaria. 2005;35(5):233-37. [pmid: 15802109].
52 Dawes MG, Kaczorowski J, Swanson G, et al. The effect of a patient education booklet and BP ‘tracker’ on knowledge about hypertension. A randomized controlled trial. Family Practice. 2010;27(5):472-8. [pmid: 20631056].
53 Dejesus RS, Chaudhry R, Leutink DJ, et al. Effects of efforts to intensify management on blood pressure control among patients with type 2 diabetes mellitus and hypertension: a pilot study. Vasc Health Risk Manag. 2009;5:705-11. [pmid: 19756162].
54 Earle KA, Istepanian RS, Zitouni K, et al. Mobile telemonitoring for achieving tighter targets of blood pressure control in patients with complicated diabetes: a pilot study. Diabetes Technol Ther. 2010;12(7):575-9. [pmid: 20597833].
55 Earp JA, Ory MG, Strogatz DS. The effects of family involvement and practitioner home visits on the control of hypertension. Am J Public Health. 1982;72(10):1146-54. [pmid: 7114339].
56 Fitzgerald DJ, O'Callaghan WG, O'Brien E, et al. Home recording of blood pressure in the management of hypertension. Ir Med J. 1985;78(8):216-18. [pmid: 4044205].
57 Friedman RH, Kazis LE, Jette A, et al. A telecommunications system for monitoring and counseling patients with hypertension. Impact on medication adherence and blood pressure control. Am J Hypertens. 1996;9(4:Pt 1):t-92.
58 Fuchs SC, Fuchs FD, Moreira LB, et al. Efficacy of Home Blood Pressure Monitoring on Blood Pressure Control: A Randomized Controlled Trial. Circulation. 2010;122(2):e78.
59 Godwin M, Lam M, Birtwhistle R, et al. A primary care pragmatic cluster randomized trial of the use of home blood pressure monitoring on blood pressure levels in hypertensive patients with above target blood pressure. Fam Pract. 2010;27(2):135-42. [pmid: 20032170].
60 Gran B. Non-pharmacological methods reduce drug use in the treatment of hypertension. A two-year trial in general practice. Scand J Prim Health Care. 1991;9(2):121-8. [pmid: 1891656].
61 Green BB, Cook AJ, Ralston JD, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. [Erratum appears in JAMA. 2009 Nov 11;302(18):1972]. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
62 Halme L, Vesalainen R, Kaaja M, et al. HOme MEasuRement of blood pressure study group. Self-monitoring of blood pressure promotes achievement of blood pressure target in primary health care. Am J Hypertens. 2005;18(11):1415-20. [pmid: 16280273].
63 Haynes RB, Sackett DL, Gibson ES, et al. Improvement of medication compliance in uncontrolled hypertension. Lancet. 1976;1(7972):1265-8. [pmid: 73694].
64 Johnson AL, Taylor DW, Sackett DL, et al. Self-recording of blood pressure in the management of hypertension. Can Med Assoc J. 1978;119(9):1034-9. [pmid: 369673].
65 Kabutoya T, Ishikawa J, Hoshide S, et al. A home blood pressure monitor equipped with a graphic function facilitates faster blood pressure control than the conventional home blood pressure monitor. J Clin Hypertens (Greenwich). 2009;11(8):422-5. [pmid: 19695029].
66 Kim J, Han HR, Song H, et al. Compliance with home blood pressure monitoring among middle-aged Korean Americans with hypertension. Journal of Clinical Hypertension. 2010;12(4):253-60. [pmid: 20433546].
67 Madsen LB, Kirkegaard P, Pedersen EB. Blood pressure control during telemonitoring of home blood pressure. A randomized controlled trial during 6 months. Blood Press. 2008;17(2):78-86. [pmid: 18568696].
68 Márquez-Contreras E, Martell-Claros N, Gil-Guillén V, et al. Efficacy of a home blood pressure monitoring programme on therapeutic compliance in hypertension: the EAPACUM-HTA study. J Hypertens. 2006;24(1):169-75. [pmid: 16331115].
69 Márquez Contreras E, Martel Claros N, Gil Guillén V, et al. [Control of therapeutic inertia in the treatment of arterial hypertension by using different strategies]. [Spanish]. Aten Primaria. 2009;41(6):315-23. [pmid: 19482378].
70 McManus RJ, Mant J, Bray EP, et al. Telemonitoring and self-management in the control of hypertension (TASMINH2): a randomised controlled trial. Lancet. 2010;376(9736):163-72. [pmid: 20619448].
71 Mehos BM, Saseen JJ, MacLaughlin EJ. Effect of pharmacist intervention and initiation of home blood pressure monitoring in patients with uncontrolled hypertension. Pharmacotherapy. 2000;20(11):1384-9. [pmid: 11079287].
72 Midanik LT, Resnick B, Hurley LB, et al. Home blood pressure monitoring for mild hypertensives. Public Health Rep. 1991;106(1):85-9. [pmid: 1899945].
73 Muhlhauser I, Sawicki PT, Didjurgeit U, et al. Evaluation of a structured treatment and teaching programme on hypertension in general practice. Clin Exp Hypertens. 1993;15(1):125-42. [pmid: 8467308].
74 Neumann CL, Menne J. Blood pressure telemonitoring is useful to achieve blood pressure control in inadequately treated patients with arterial hypertension. Journal of Human Hypertension. 2011. 2011:1-7.
75 Parati G, Omboni S, Albini F, et al. Home blood pressure telemonitoring improves hypertension control in general practice. The TeleBPCare study. J Hypertens. 2009;27(1):198-203. [pmid: 19145785].
76 Park MJ, Kim HS, Kim KS. Cellular phone and Internet-based individual intervention on blood pressure and obesity in obese patients with hypertension. Int J Med Inf. 2009;78(10):704-10.
77 Pierce JP, Watson DS, Knights S, et al. A controlled trial of health education in the physician's office. Prev Med. 1984;13(2):185-94. [pmid: 6377291].
78 Rinfret S, Lussier MT, Peirce A, et al. The impact of a multidisciplinary information technology-supported program on blood pressure control in primary care. Circ Cardiovasc Qual Outcomes. Cardiovascular. 2009;(3):170-7. [pmid: 20031834].
79 Rogers MA, Small D, Buchan DA, et al. Home monitoring service improves mean arterial pressure in patients with essential hypertension. A randomized, controlled trial. Ann Intern Med. 2001;134(11):1024-32. [pmid: 11388815].
80 Rudd P, Miller NH, Kaufman J, et al. Nurse management for hypertension. A systems approach. Am J Hypertens. 2004;17(10):921-7. [pmid: 15485755].
81 Sawicki PT, Muhlhauser I, Didjurgeit U, et al. Intensified antihypertensive therapy is associated with improved survival in type 1 diabetic patients with nephropathy. J Hypertens. 1995;13(8):933-8. [pmid: 8557972].
82 Shea S, Weinstock RS, Starren J, et al. A randomized trial comparing telemedicine case management with usual care in older, ethnically diverse, medically underserved patients with diabetes mellitus. J Am Med Inform Assoc. 2006;13(1):40-51. [pmid: 16221935].
83 Soghikian K, Casper SM, Fireman BH, et al. Home blood pressure monitoring. Effect on use of medical services and medical care costs. Med Care. 1992;30(9):855-65. [pmid: 1518317].
84 Staessen JA, Den HE, Celis H, et al. Antihypertensive treatment based on blood pressure measurement at home or in the physician's office: a randomized controlled trial. JAMA. 2004;291(8):955-64. [pmid: 14982911].
85 Stahl SM, Kelley CR, Neill PJ, et al. Effects of home blood pressure measurement on long-term BP control. Am J Public Health. 1984;74(7):704-9. [pmid: 6742256].
86 van Onzenoort HA, Verberk WJ, Kroon AA, et al. Effect of self-measurement of blood pressure on adherence to treatment in patients with mild-to-moderate hypertension. J Hypertens. 2010;28(3):622-7. [pmid: 19952780].
87 Varis J, Kantola I. The choice of home blood pressure result reporting method is essential: Results mailed to physicians did not improve hypertension control compared with ordinary office-based blood pressure treatment. Blood Press. 2010;19(5):319-24. [pmid: 20367560].
88 Zarnke KB, Feagan BG, Mahon JL, et al. A randomized study comparing a patient-directed hypertension management strategy with usual office-based care. Am J Hypertens. 1997;10(1):58-67. [pmid: 9008249].
89 Zillich AJ, Sutherland JM, Kumbera PA, et al. Hypertension outcomes through blood pressure monitoring and evaluation by pharmacists (HOME study). J Gen Intern Med. 2005;20(12):1091-6. [pmid: 16423096].
90 Madsen LB, Kirkegaard P, Pedersen EB. Health-related quality of life (SF-36) during telemonitoring of home blood pressure in hypertensive patients: a randomized, controlled study. Blood Press. 2008;17(4):227-32. [pmid: 18815937].
91 Shea S, IDEATel Consortium. The Informatics for Diabetes and Education Telemedicine (IDEATel) project. Trans Am Clin Climatol Assoc. 2007;118:289-304. [pmid: 18528511].
92 Shea S, Weinstock RS, Teresi JA, et al. A randomized trial comparing telemedicine case management with usual care in older, ethnically diverse, medically underserved patients with diabetes mellitus: 5 year results of the IDEATel study. J Am Med Inform Assoc. 2009;16(4):446-56. [pmid: 19390093].
93 Steiner JF, Prochazka AV. The assessment of refill compliance using pharmacy records: methods, validity, and applications. J Clin Epidemiol. 1997;50:105-16. [pmid: 9048695].
94 Den Hond E, Staessen JA, Celis H, et al. Antihypertensive treatment based on home or office blood pressure--the THOP trial. Blood Press Monit. 2004;9(6):311-4. [pmid: 15564986].
95 Lewington S, Clarke R, Qizilbash N, et al. Age-specific relevance of usual blood pressure to vascular mortality. The Lancet. 2003;361(9366):1391-2.
96 Lawes CM, Bennett DA, Lewington S, et al. Blood pressure and coronary heart disease: a review of the evidence. Seminars in Vascular Medicine. 2002;2(4):355-68. [pmid: 16222626].
97 Powers BJ, Olsen MK, Smith VA, et al. Measuring blood pressure for decision making and quality reporting: where and how many measures?. Ann Intern Med. 2011;154:781-8. [pmid: 21690592].
98 Yarows SA, Julius S, Pickering TG. Home blood pressure monitoring. Archives of Internal Medicine. 2000;160(9):1251-7. [pmid: 10809027].
99 Ogedegbe G. Self-titration for treatment of uncomplicated hypertension. Lancet. 2010;376(9736):144-6. [pmid: 20619449].
100 Agarwal R, Bills JE, Hecht TJ, et al. Role of home blood pressure monitoring in overcoming therapeutic inertia and improving hypertension control: a systematic review and meta-analysis. Hypertension. 2011;57(1):29-38. [pmid: 21115879].
101 Bray EP, Holder R, Mant J, et al. Does self-monitoring reduce blood pressure? Meta-analysis with meta-regression of randomized controlled trials. Ann Med. 2010;42(5):371-86. [pmid: 20504241].
102 Cappuccio FP, Kerry SM, Forbes L, et al. Blood pressure control by home monitoring: meta-analysis of randomised trials. [Erratum appears in BMJ. 2004 Aug 28;329(7464):499]. BMJ. 2004;329(7458):145. [pmid: 15194600].
103 Glynn LG, Murphy AW, Smith SM, et al. Interventions used to improve control of blood pressure in patients with hypertension. Cochrane Database of Systematic Reviews. 2010;(3):CD005182. [doi: 10.1002/14651858.CD005182.pub4]. [pmid: 20238338].
104 Pickering TG, Miller NH, Ogedegbe G, et al. Call to action on use and reimbursement for home blood pressure monitoring: Executive Summary. A joint scientific statement from the American Heart Association, American Society of Hypertension, and Preventive Cardiovascular Nurses Association. J Clin Hypertens (Greenwich ). 2008;10(6):467-76. [pmid: 18550937].
105 Fujiwara T, Nishimura T, Ohkuko T, et al. HOMED-BP Study Group. Rationale and design of HOMED-BP Study: hypertension objective treatment based on measurement by electrical devices of blood pressure study. Blood Pressure Monitoring. 2002;7(1):77-82. [pmid: 12040250].
106 Aoki Y, Asayama K, Ohkubo T, et al. Progress report on the HOMED-BP Study: hypertension objective treatment based on measurement by electrical devices of blood pressure study. Clinical & Experimental Hypertension. 2004;26(2):119-27. [pmid: 15038622].