# Peer Reviewers

Vincent J. Canzanello, M.D.

Associate Professor, Division of Nephrology and Hypertension,

Department of Medicine, Mayo Clinic

Rochester, MN

Susan R. Mendley, M.D.

Associate Professor in Pediatrics and Medicine University of Maryland School of Medicine

Baltimore, MD

Gbenga Ogedegbe, M.D., M.P.H.

Associate Professor, Department of Medicine

Langone Medical Center, New York University

New York, NY

Raymond R. Townsend, M.D.

Director, Hypertension Program

Perelman School of Medicine

Philadelphia, PA

Anthony Viera, M.D., M.P.H.

Assistant Professor, Department of Family Medicine

University of North Carolina at Chapel Hill School of Medicine

Chapel Hill, NC