# Key Informants

Susan Booth

Project Leader, Personal Care & Wellness

Consumer Reports

Yonkers, NY

Hayden Bosworth, Ph.D.

Associate Director, Center for Health Services Research in Primary Care

Durham Veterans Affairs Medical Center

Durham, NC

Steven R. Brown, M.D.

Banner Good Samaritan Family Medicine Residency, University of Arizona

Phoenix, AZ

Jonathan P. Curtin, M.D.

Medical Director, Division of Provider Relations and Utilization Management

Office of Health Insurance Programs

New York State Department of Health

Albany, NY

James Figge, M.D., M.B.A.

Medical Director, Division of Provider Relations and Utilization Management

Office of Health Insurance Programs

New York State Department of Health

Albany, NY

Beverly Green, M.D., M.P.H.

Affiliate Investigator, Group Health Research Institute

Family Physician, Group Health Cooperative

Assistant Clinical Professor, University of Washington School of Medicine

Seattle, WA

Tranice D. Jackson, M.D.

Assistant Professor of Clinical Medicine

Weill Cornell Medical College

New York, NY

Lawrence Krakoff, M.D.

Professor of Medicine, Cardiology

Mount Sinai Medical Center

New York, NY

Karen Rauen, Ph.D.

Director, Health and Consumer Sciences Operation

Consumer Reports

Yonkers, NY

Roger L. Snow, M.D., M.P.H.

Deputy Medical Director, Office of Clinical Affairs

Massachusetts Office of Medicaid (MassHealth)

Quincy, MA

Raymond R. Townsend, M.D.

Director, Hypertension Program

Perelman School of Medicine

Philadelphia, PA

Terry Wall, M.D.

Professor of Pediatrics

University of Alabama at Birmingham School of Medicine

Birmingham, AL

William B. White, M.D.

Professor of Medicine

Chief, Division of Hypertension and Clinical Pharmacology, Calhoun Cardiology Center

University of Connecticut School of Medicine

Farmington, CT

President-Elect

American Society of Hypertension

New York, NY