# Additional Tables

Table D-1 Information on SMBP device accreditation

Table D-2 Description of study interventions: Key Question 1

Table D-3 Study characteristics: Key Question 1

Table D-4 Categorical BP: SMBP alone versus usual care

Table D-5 Clinic BP: SMBP alone versus usual care

Table D-6 Ambulatory BP, 24 hour: SMBP alone versus usual care

Table D-7 Ambulatory BP, awake: SMBP alone versus usual care

Table D-8 Ambulatory BP, asleep: SMBP alone versus usual care

Table D-9 Categorical medication dose and number outcomes: SMBP alone versus usual care

Table D-10 Continuous medication dose and number outcomes: SMBP alone versus usual care

Table D-11 Categorical medication adherence: SMBP alone versus usual care

Table D-12 Continuous medication adherence: SMBP alone versus usual care

Table D-13 Quality of life: SMBP alone versus usual care

Table D-14 Categorical health care resource use: SMBP alone versus usual care

Table D-15 Continuous health care resource use: SMBP alone versus usual care

Table D-16 Continuous miscellaneous outcomes: SMBP alone versus usual care

Table D-17 Categorical BP: SMBP plus additional support versus usual care

Table D-18 Clinic BP: SMBP plus additional support versus usual care

Table D-19 Ambulatory BP: SMBP plus additional support versus usual care

Table D-20 Categorical medication dose and number outcomes: SMBP plus additional support versus usual care

Table D-21 Continuous medication dose and number outcomes: SMBP plus additional support versus usual care

Table D-22 Categorical medication adherence: SMBP plus additional support versus usual care

Table D-23 Continuous medication adherence: SMBP plus additional support versus usual care

Table D-24 Quality of life: SMBP plus additional support versus usual care

Table D-25 Continuous health care resource use: SMBP plus additional support versus usual care

Table D-26 Categorical miscellaneous outcomes: SMBP plus additional support versus usual care

Table D-27 Description of study interventions: Key Question 2

Table D-28 Study characteristics: Key Question 2

Table D-29 Categorical BP: SMBP plus additional support versus SMBP alone (or other additional support)

Table D-30 Clinic BP: SMBP plus additional support versus SMBP alone (or other additional support)

Table D-31 Ambulatory BP: SMBP plus additional support versus SMBP alone (or with other additional support)

Table D-32 Quality of life: SMBP plus additional support versus SMBP alone (or other additional support)

Table D-33 Categorical medication dose and number outcomes: SMBP plus additional support versus SMBP alone (or other additional support)

Table D-34 Continuous medication dose and number outcomes: SMBP plus additional support versus SMBP alone (or other additional support)

Table D-35 Categorical medication adherence: SMBP plus additional support versus SMBP alone (or other additional support)

Table D-36 Continuous medication adherence: SMBP plus additional support versus SMBP alone (or other additional support)

Table D-37 Categorical health care resource use: SMBP plus additional support versus SMBP alone (or other additional support)

Table D-38 Continuous health care resource use: SMBP plus additional support versus SMBP alone (or other additional support)

Table D-39 Continuous miscellaneous outcomes: SMBP plus additional support versus SMBP alone (or other additional support)

Table D-40 Categorical BP: Atypical studies

Table D-41 Continuous BP: Atypical studies

Table D-42 Non-BP continuous outcomes: Atypical studies

Table D-43 Categorical non-BP outcomes: Atypical studies

Table D-44 Ongoing research on SMBP identified through ClinicalTrials.gov