# Data Extraction Forms

SMBP Data Extraction Form: Key Questions 1 &2

SMBP Data Extraction Form: Key Question 5