# Excluded Studies

Studies are listed in alphabetical order by author. The reason for rejection for each study is indicated in italics below the corresponding reference.

Home monitoring aids in blood pressure control. Johns Hopkins Medical Letter, Health After 50. 2006;18:7. Not a study
Abe K, Tsunoda K, Sato T. [Measurement and evaluation of home blood pressure monitoring with particular emphasis on evaluating anti-hypertensive effects using a home blood pressure distribution diagram]. [Japanese]. Nippon Jinzo Gakkai Shi. 2006;48:354-364. [pmid: 16780105]. Cohort without data on predictors of adherence
Aberg H, Tibblin G. Addition of non-pharmacological methods of treatment in patients on antihypertensive drugs: results of previous medication, laboratory tests and life quality. Journal of Internal Medicine. 1989;226:39-46. [pmid: 2666559]. SMBP not analyzed intervention
AbuDagga A, Resnick HE, Alwan M. Impact of blood pressure telemonitoring on hypertension outcomes: a literature review. [Review]. Telemedicine Journal & E-Health. 2010;16:830-838. [pmid: 20815751]. Systematic review (reference list reviewed)
Agarwal R. Home and ambulatory blood pressure monitoring in chronic kidney disease. [Review] [60 refs]. Current Opinion in Nephrology & Hypertension. 2009;18:507-512. [pmid: 19713838]. Not a study
Agarwal R, Andersen MJ. Prognostic importance of clinic and home blood pressure recordings in patients with chronic kidney disease. Kidney International. 2006;69:406-411. [pmid: 16408134]. Cohort without data on predictors of adherence
Alborzi P, Patel N, Agarwal R. Home blood pressures are of greater prognostic value than hemodialysis unit recordings. Clinical Journal of The American Society of Nephrology: CJASN. 2007;2:1228-1234. [pmid: 17942773]. Dialysis patients
Andersen AR, Nielsen PE. Home readings of blood pressure in hypertension. Scandinavian Journal of Primary Health Care. 1985;3:71-77. [pmid: 4059703]. <8 week of SMBP
Anderson CS, Huang Y, Wang JG, et al. Intensive blood pressure reduction in acute cerebral haemorrhage trial (INTERACT): a randomised pilot trial. Lancet Neurology. 2008;7:391-399. [pmid: 18396107]. SMBP not analyzed intervention
Antonicelli R, Partemi M, Spazzafumo L, Amadio L, Paciaroni E. Blood pressure self-measurement in the elderly: differences between automatic and semi-automatic systems. Journal of Human Hypertension. 1995;9:229-231. [pmid: 7595903]. Accuracy/validation study
Antony I, Asmar R, Carette B, Demolis P, Vaisse B. [The REVEIL study: feasibility study of blood pressure self-monitoring. Preliminary results and patient opinions]. [French]. Archives des Maladies du Coeur et des Vaisseaux. 2001;94:897-900. [pmid: 11575227]. <8 week of SMBP
Aoki Y, Asayama K, Ohkubo T, et al. Progress report on the HOMED-BP Study: hypertension objective treatment based on measurement by electrical devices of blood pressure study. Clinical & Experimental Hypertension (New York). 2004;26:119-127. SMBP not analyzed intervention
Appel LJ, Stason WB. Ambulatory blood pressure monitoring and blood pressure self-measurement in the diagnosis and management of hypertension. [Review] [140 refs]. Annals of Internal Medicine. 1993;118:867-882. [pmid: 8093115]. Systematic review (reference list reviewed)
Arnesen E. Comparative study of the blood-pressur-lowering effect of combined therapy with chlorthalidone and metoprolol or alpha-methyldopa, judged by self-monitoring of blood pressure. Current Therapeutic Research Clinical and Experimental. 1978;24:899. SMBP not analyzed intervention
Asayama K, Ohkubo T, Kikuya M, et al. Use of 2003 European Society of Hypertension-European Society of Cardiology guidelines for predicting stroke using self-measured blood pressure at home: the Ohasama study. European Heart Journal. 2005;26:2026-2031. [pmid: 15917279]. Cohort without data on predictors of adherence
Asayama K, Ohkubo T, Kikuya M, et al. Prediction of stroke by home “morning” versus “evening” blood pressure values: the Ohasama study. Hypertension. 2006;48:737-743. [pmid: 16952977]. Cohort without data on predictors of adherence
Asayama K, Ohkubo T, Sato A, et al. Proposal of a risk-stratification system for the Japanese population based on blood pressure levels: the Ohasama study. Hypertension Research - Clinical & Experimental. 2008;31:1315-1322. Diagnosis study
Ashida T. [Improvement in medication compliance by home blood pressure measurement]. [Review] [10 refs] [Japanese]. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2006;64:29-32. Not a study
Ashida T, Sugiyama T, Okuno S, Ebihara A, Fujii J. Relationship between home blood pressure measurement and medication compliance and name recognition of antihypertensive drugs. Hypertension Research - Clinical & Experimental. 2000;23:21-24. Cross-sectional
Ashida T, Yokoyama S, Ebihara A, Sugiyama T, Fujii J. Profiles of patients who control the doses of their antihypertensive drugs by self-monitoring of home blood pressure. Hypertension Research - Clinical & Experimental. 2001;24:203-207. Cross-sectional
Atallah A, Mourad JJ, Inamo J, et al. [Self monitoring of blood pressure in Guadeloupe in 2005 results of the PRETRAHGUAD enquiry]. [French]. Archives des Maladies du Coeur et des Vaisseaux. 2006;99:1225-1229. [pmid: 18942525]. Cross-sectional
Aylett M, Marples G, Jones K. Home blood pressure monitoring: its effect on the management of hypertension in general practice. British Journal of General Practice. 1999;49:725-728. [pmid: 10756615]. Cohort without data on predictors of adherence
Bachmann LM, Steurer J, Holm D, Vetter W. To what extent can we trust home blood pressure measurement? A randomized, controlled trial. Journal of Clinical Hypertension. 2002;4:405-407. [pmid: 12461302]. <8 week of SMBP
Badskjaer J, Nielsen PE. Clinical experience using home readings in hypertensive subjects (indirect technique). Acta Medica Scandinavica - Supplementum. 1982;670:89-95. [pmid: 6964492]. Accuracy/validation study
Bayo LlibreJ, Roca SC, Dalfo BA, et al. [Effectiveness of self-monitoring of blood pressure in white coat hypertension diagnosis. Rationale and design]. [Spanish]. Atencion Primaria. 2005;35:208-212. [pmid: 15766497]. Diagnosis study
Bayo Llibre J, Roca SC, Dalfo BA, Verdu Rotellar JM, Martin-Baranera MM. [White-coat hypertension indicators diagnosed through self-measurement of blood pressure at home]. [Spanish]. Atencion Primaria. 2007;39:507-509. Diagnosis study
Beitelshees AL, Gong Y, Bailey KR, et al. Comparison of office, ambulatory, and home blood pressure antihypertensive response to atenolol and hydrochlorthiazide. Journal of Clinical Hypertension. 2010;12:14-21. [pmid: 20047624]. SMBP not analyzed intervention
Bobrie G, Chatellier G, Genes N, et al. Cardiovascular prognosis of “masked hypertension” detected by blood pressure self-measurement in elderly treated hypertensive patients. JAMA. 2004;291:1342-1349. [pmid: 15026401]. Diagnosis study
Bobrie G, Postel-Vinay N, Delonca J, Corvol P, SETHI I. Self-measurement and self-titration in hypertension: a pilot telemedicine study. American Journal of Hypertension. 2007;20:1314-1320. [pmid: 18047923]. Cohort without data on predictors of adherence
Boreu QF, de Tuero GC, Rodriguez-Poncelas A, et al. Proportion of isolated clinical hypertension in primary care settings. Comparison of target organ damage in patients with isolated clinical hypertension and patients with sustained arterial hypertension. Blood Pressure. 2007;16:354-361. [pmid: 17852096]. <8 week of SMBP
Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. American Heart Journal. 2009;157:450-456. [pmid: 19249414]. SMBP not analyzed intervention
Bosworth HB, Olsen MK, Dudley T, et al. The Take Control of Your Blood pressure (TCYB) study: study design and methodology. Contemporary Clinical Trials. 2007;28:33-47. [pmid: 16996808]. Study protocol
Bosworth HB, Olsen MK, McCant F, et al. Hypertension Intervention Nurse Telemedicine Study (HINTS): testing a multifactorial tailored behavioral/educational and a medication management intervention for blood pressure control. American Heart Journal. 2007;153:918-924. [pmid: 17540191]. Study protocol
Bray EP, Holder R, Mant J, McManus RJ. Does self-monitoring reduce blood pressure? Meta-analysis with meta-regression of randomized controlled trials. Annals of Medicine. 2010;42:371-386. [pmid: 20504241]. Systematic review (reference list reviewed)
Brueren MM, Schouten HJ, de Leeuw PW, van Montfrans GA, van Ree JW. A series of self-measurements by the patient is a reliable alternative to ambulatory blood pressure measurement. British Journal of General Practice. 1998;48:1585-1589. [pmid: 9830184]. <8 week of SMBP
Campbell NR, Abbott D, Bass M, et al. Self-measurement of blood pressure: recommendations of the Canadian Coalition for High Blood Pressure Prevention and Control. Canadian Journal of Cardiology. Suppl. 1995;11:17H. Not a study
Canzanello VJ, Jensen PL, Hunder I. Rapid adjustment of antihypertensive drugs produces a durable improvement in blood pressure. American Journal of Hypertension. 2001;14:345-350. [pmid: 11336180]. Cohort without data on predictors of adherence
Canzanello VJ, Jensen PL, Schwartz LL, Worra JB, Klein LK. Improved blood pressure control with a physician-nurse team and home blood pressure measurement. Mayo Clinic Proceedings. 2005;80:31-36. [pmid: 15667026]. Cohort without data on predictors of adherence
Cappuccio FP, Kerry SM, Forbes L, Donald A. Blood pressure control by home monitoring: meta-analysis of randomised trials. [Erratum appears in BMJ. 2004 Aug 28;329(7464):499]. BMJ. 2004;329:145. [pmid: 15194600]. Systematic review (reference list reviewed)
Cardozo L, Steinberg J. Telemedicine for recently discharged older patients. Telemedicine Journal & E-Health. 2010;16:49-55. [pmid: 20064067]. SMBP not analyzed intervention
Celis H, Den HE, Staessen JA. Self-measurement of blood pressure at home in the management of hypertension. [Review] [47 refs]. Clinical Medicine & Research. 2005;3:19-26. [pmid: 15962017]. Not a study
Chapman RH, Kowal SL, Cherry SB, Ferrufino CP, Roberts CS, Chen L. The modeled lifetime cost-effectiveness of published adherence-improving interventions for antihypertensive and lipid-lowering medications. [Review]. Value in Health. 2010;13:685-694. [pmid: 20825627]. Does not address SMBP
Chatellier G, Dutrey-Dupagne C, Vaur L, et al. Home self blood pressure measurement in general practice. The SMART study. Self-measurement for the Assessment of the Response to Trandolapril. American Journal of Hypertension. 1996;9:644-652. [pmid: 8806976]. SMBP not analyzed intervention
Chodosh J, Morton SC, Mojica W, et al. Meta-analysis: chronic disease self-management programs for older adults. Annals of Internal Medicine. 2005;143:427-438. [pmid: 16172441]. Accuracy/validation study
Christensen A, Christrup LL, Fabricius PE, et al. The impact of an electronic monitoring and reminder device on patient compliance with antihypertensive therapy: a randomized controlled trial. Journal of Hypertension. 2010;28:194-200. [pmid: 19770778]. SMBP not analyzed intervention
Christofaro DG, Fernandes RA, Gerage AM, Alves MJ, Polito MD, Oliveira AR. Validation of the Omron HEM 742 blood pressure monitoring device in adolescents. Arquivos Brasileiros de Cardiologia. 2009;92:10-15. [pmid: 19219259]. Accuracy/validation study
Chiu CW, Wong FK. Effects of 8 weeks sustained follow-up after a nurse consultation on hypertension: a randomised trial. International Journal of Nursing Studies. 2010;47:1374-1382. [pmid: 20413121]. Intervention is not SMBP
Chrubasik S, Droste C, Glimm E, Black A. Comparison of different methods of blood pressure measurements. Blood Pressure Monitoring. 2007;12:157-166. [pmid: 17496465]. Diagnosis study
Clement DL. Home versus office monitoring of blood pressure: a European multicentre study of high blood pressure. Journal of Hypertension - Supplement. 1989;7:S49-S51. SMBP not analyzed intervention
Coll-de-Tuero G, Foguet-Boreu Q, Rodriguez-Poncelas A, et al. [Normal values in self-blood pressure measurement in relation to the presence of target organ disease. Data from the VAMPAHICA study]. [Spanish]. Medicina Clinica. 2008;130:321-326. [pmid: 18373907]. Cohort without data on predictors of adherence
Cordoba Garcia R, Cuello Olivan MJ. [Self-measurement of blood pressure in primary care]. [Spanish]. Atencion Primaria. 2000;26:261-266. [pmid: 11100588]. Not a study
Costa FV, Ambrosioni E, Piovaccari G, Magnani B. [Usefulness of self-measurement of arterial pressure in the control of anti-hypertensive therapy]. [Italian]. Giornale di Clinica Medica. 1979;60:490-499. [pmid: 467881]. Cohort without data on predictors of adherence
Cuspidi C, Meani S, Fusi V, et al. Home blood pressure measurement and its relationship with blood pressure control in a large selected hypertensive population. Journal of Human Hypertension. 2004;18:725-731. [pmid: 15103315]. Cross-sectional
Cuspidi C, Meani S, Lonati L, et al. Prevalence of home blood pressure measurement among selected hypertensive patients: results of a multicenter survey from six hospital outpatient hypertension clinics in Italy. Blood Pressure. 2005;14:251-256. [pmid: 16126560]. Cross-sectional
Cuspidi C, Meani S, Valerio C, et al. Body mass index, nocturnal fall in blood pressure and organ damage in untreated essential hypertensive patients. Blood Pressure Monitoring. 2008;13:318-324. [pmid: 19020422]. SMBP not analyzed intervention
Datta SK, Oddone EZ, Olsen MK, et al. Economic analysis of a tailored behavioral intervention to improve blood pressure control for primary care patients. American Heart Journal. 2010;160:257-263. [pmid: 20691830]. SMBP not analyzed intervention
De Marco A, Feitosa AM, Gomes MM, Parente GB, Victor EG. Pulse pressure measured by home blood pressure monitoring and its correlation to left ventricular mass index. Arquivos Brasileiros de Cardiologia. 2007;88:91-95. [pmid: 17364125]. Cohort without data on predictors of adherence
Denolle T, Eon Y, Le NH, Seignard H, Battini J. [District program to improve the cardiovascular risk of resistant hypertensive patients in general medicine]. [French]. Archives des Maladies du Coeur et des Vaisseaux. 2005;98:761-766. [pmid: 16220744]. Cohort without data on predictors of adherence
Divison JA, Puras A, Aguilera M, et al. [Home self-measurements of blood pressure and relationship with diagnosis of hypertension and target organ damage: comparative study with ambulatory monitoring]. [Spanish]. Medicina Clinica. 2000;115:730-735. [pmid: 11141439]. Diagnosis study
Divison JA, Sanchis DC, Carrion VL, et al. [Different uses of home blood pressure measurement in the diagnosis and monitoring of hypertension]. [Spanish]. Atencion Primaria. 2006;38:399-404. [pmid: 17173815]. Accuracy/validation study
Dupuy O, Chanudet X, Mayaudon H, Bordier L, Damiano J, Bauduceau B. Home blood pressure monitoring in diabetic population. Diabetes & Metabolism. 2003;29:440-444. [pmid: 14526275]. Not a study
Edmonds D, Foerster E, Groth H, Greminger P, Siegenthaler W, Vetter W. Does self-measurement of blood pressure improve patient compliance in hypertension?. Journal of Hypertension - Supplement. 1985;3:S31-S34. Not comparative, N<100
Egan BM, Zhao Y, Axon RN. US trends in prevalence, awareness, treatment, and control of hypertension, 1988-2008. JAMA. 2010;303:2043-2050. [pmid: 20501926]. SMBP not analyzed intervention
Eguchi K, Matsui Y, Shibasaki S, et al. Age-specific impact of self-monitored pulse pressure on hypertensive target organ damage in treated hypertensive patients. Journal of Clinical Hypertension. 2007;9:522-529. [pmid: 17617762]. Cohort without data on predictors of adherence
Elliot WJ, Izzo JL Jr, White WB, et al. Graded blood pressure reduction in hypertensive outpatients associated with use of a device to assist with slow breathing. Journal of Clinical Hypertension. 2004;6:553-559. [pmid: 15470284]. SMBP not analyzed intervention
Eto K, Tsuchihashi T, Ohta Y, Onaka U, Ueno M. Home blood pressure measurement may lead to less strict control of office blood pressure. Clinical & Experimental Hypertension (New York). 2008;30:225-231. Cohort without data on predictors of adherence
Ewald S, vor dem EJ, Uen S, Neikes F, Vetter H, Mengden T. Relationship between the frequency of blood pressure self-measurement and blood pressure reduction with antihypertensive therapy : results of the OLMETEL (OLMEsartan TELemonitoring blood pressure) study. Clinical Drug Investigation. 2006;26:439-446. [pmid: 17163276]. Not comparative, N<100
Fagard RH, Van Den BC, De CP. Prognostic significance of blood pressure measured in the office, at home and during ambulatory monitoring in older patients in general practice. Journal of Human Hypertension. 2005;19:801-807. [pmid: 15959536]. SMBP not analyzed intervention
Fahey T, Schroeder K, Ebrahim S. Educational and organisational interventions used to improve the management of hypertension in primary care: a systematic review. [Review] [96 refs]. British Journal of General Practice. 2005;55:875-882. [pmid: 16282005]. Not a study
Fahey T, Schroeder K, Ebrahim S. Interventions used to improve control of blood pressure in patients with hypertension. [Review] [161 refs][Update of Cochrane Database Syst Rev. 2006;(2):CD005182; PMID: 16625627]. Cochrane Database of Systematic Reviews. 2006;(4):CD005182. Systematic review (reference list reviewed)
Feldman PH, McDonald MV, Mongoven JM, Peng TR, Gerber LM, Pezzin LE. Home-based blood pressure interventions for blacks. Circulation. 2009;2:241-248. [pmid: 20031844]. Study protocol
Felix-Redondo FJ, Fernandez-Berges D, Rios-Rivera J, Perez-Castan JF, Valiente-Rubio JI, Molina-Martinez LM. [Blood pressure control in a hypertensive population when measurements are performed in the clinic or self-monitoring by the patient]. [Spanish]. Atencion Primaria. 2009;41:120-122. [pmid: 19231710]. Cohort without data on predictors of adherence
Fernandez RS, Davidson P, Griffiths R, Juergens C, Stafford B, Salamonson Y. A pilot randomised controlled trial comparing a health-related lifestyle self-management intervention with standard cardiac rehabilitation following an acute cardiac event: Implications for a larger clinical trial. Australian Critical Care. 2009;22:17-27. [pmid: 19081265]. SMBP not analyzed intervention
Figar S, Galarza C, Petrlik E, et al. Effect of education on blood pressure control in elderly persons: a randomized controlled trial. American Journal of Hypertension. 2006;19:737-743. [pmid: 16814130]. SMBP not analyzed intervention
Flynn JT. Impact of ambulatory blood pressure monitoring on the management of hypertension in children. Blood Pressure Monitoring. 2000;5:211-216. [pmid: 11035862]. SMBP not analyzed intervention
Foerster EC, Achermann R, Groth H, Edmonds D, Siegenthaler W, Vetter W. [Does self-measurement of blood pressure improve compliance in hypertensive patients?]. [German]. Schweizerische Medizinische Wochenschrift. Journal. 1985:163-165. Cohort without data on predictors of adherence
Fonseca-Reyes S, Cervantes-Munguia R, de AlbaGarcia JG, Parra-Carrillo JZ, Lopez-Maldonado F, Montes-Casillas M. Evaluation and effects of the Omron 725 CIC device for measuring blood pressure in a hypertension clinic. Blood Pressure Monitoring. 2007;12:321-327. [pmid: 17890971]. Accuracy/validation study
Fravel MA, Ernst ME, Weber CA, Dawson JD, Carter BL, Bergus GR. Influence of patient characteristics on success of ambulatory blood pressure monitoring. Pharmacotherapy. 2008;28:1341-1347. [pmid: 18956994]. SMBP not analyzed intervention
Fujiwara T, Nishimura T, Ohkuko T, Imai Y, HOMED-BP Study Group. Rationale and design of HOMED-BP Study: hypertension objective treatment based on measurement by electrical devices of blood pressure study. Blood Pressure Monitoring. 2002;7:77-82. [pmid: 12040250]. Study protocol
Fukunaga H, Ohkubo T, Kobayashi M, et al. Cost-effectiveness of the introduction of home blood pressure measurement in patients with office hypertension. Journal of Hypertension. 2008;26:685-690. [pmid: 18327077]. Cost-effectiveness analysis
Gillum RF, Etemadi N, Boen JR, Kebede J. Cost effectiveness of home vs clinic blood pressure measurements. American Heart Journal. 1981;101:689-690. [pmid: 6784563]. Cohort without data on predictors of adherence
Girerd X, Denolle T, Yau C, et al. Automated office and home phone-transmitted blood pressure recordings in uncontrolled hypertension treated with valsartan and hydrochlorothiazide. Blood Pressure Supplement. 2004;2:18-24. [pmid: 15631279]. Cohort without data on predictors of adherence
Glynn LG, Murphy AW, Smith SM, Schroeder K, Fahey T. Interventions used to improve control of blood pressure in patients with hypertension. [Review] [200 refs][Update of Cochrane Database Syst Rev. 2006;(4):CD005182; PMID: 17054244]. Cochrane Database of Systematic Reviews. 2010;(3):CD005182. [pmid: 20238338]. Not a study
Gomes MA, Pierin AM, Segre CA, Mion JD. [Home blood pressure measurement and ambulatory blood pressure measurement versus office blood pressure measurement]. [Portuguese]. Arquivos Brasileiros de Cardiologia. 1998;71:581-585. [pmid: 10347933]. Accuracy/validation study
Gonzalez Portillo L. [Patients' adherence to therapy and their understanding of hypertension at health centers]. [Spanish]. Atencion Primaria. 1993;12:469-473. [pmid: 8257752]. SMBP not analyzed intervention
Goulis DG, Giaglis GD, Boren SA, et al. Effectiveness of home-centered care through telemedicine applications for overweight and obese patients: a randomized controlled trial. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 2004;28:1391-1398. [pmid: 15356664]. Population not hypertensive
Hackett GI, Moore S, Harrison PW, Davies M. Computerised self-measurement of blood pressure. Practitioner. 1984;228:591-593. [pmid: 6377289]. Accuracy/validation study
Hanon O, Mourad JJ, Mounier-Vehier C, et al. [Blood pressure self-monitoring contributes to improved patient education among hypertensive subjects]. [French]. Archives des Maladies du Coeur et des Vaisseaux. 2001;94:879-883. [pmid: 11575223]. Cross-sectional
Hara A, Ohkubo T, Kondo T, et al. Detection of silent cerebrovascular lesions in individuals with ‘masked’ and ‘white-coat’ hypertension by home blood pressure measurement: the Ohasama study. Journal of Hypertension. 2009;27:1049-1055. [pmid: 19402227]. Diagnosis study
Harno K, Kauppinen-Makelin R, Syrjalainen J. Managing diabetes care using an integrated regional e-health approach. Journal of Telemedicine & Telecare. Suppl 1. 2006;12:13-15. [pmid: 16884565]. SMBP not analyzed intervention
Hautefeuille A, Jeffredo P, Cadier S, Dessolle L, Le Reste JY. [Home blood pressure measurement: source of anxiety? Prospective observational study]. [French]. Revue du Praticien. Suppl 10. 2009;59:3-6. [pmid: 20085214]. Not comparative, N<100
Hedner T, Narkiewicz K, Kjeldsen SE. Cost-effectiveness of blood pressure measurement and hypertension follow-up. Blood Pressure. 2006;15:4-5. [pmid: 16492609]. Not a study
Hemmelgarn BR, Zarnke KB, Campbell NR, et al. The 2004 Canadian Hypertension Education Program recommendations for the management of hypertension: Part I--Blood pressure measurement, diagnosis and assessment of risk. Canadian Journal of Cardiology. 2004;20:31-40. [pmid: 14968141]. Not a study
Hermida RC, Chayan L, Ayala DE, et al. Association of metabolic syndrome and blood pressure nondipping profile in untreated hypertension. American Journal of Hypertension. 2009;22:307-313. [pmid: 19131935]. SMBP not analyzed intervention
Horikawa T, Obara T, Ohkubo T, et al. Difference between home and office blood pressures among treated hypertensive patients from the Japan Home versus Office Blood Pressure Measurement Evaluation (J-HOME) study. Hypertension Research - Clinical & Experimental. 2008;31:1115-1123. <8 week of SMBP
Horoz OO, Yuksel B, Bayazit AK, et al. Ambulatory blood pressure monitoring and serum nitric oxide concentration in type 1 diabetic children. Endocrine Journal. 2009;56:477-485. [pmid: 19225212]. SMBP not analyzed intervention
Hoshide S, Ishikawa J, Eguchi K, Ojima T, Shimada K, Kario K. Masked nocturnal hypertension and target organ damage in hypertensives with well-controlled self-measured home blood pressure. Hypertension Research - Clinical & Experimental. 2007;30:143-149. Cohort without data on predictors of adherence
Hozawa A, Ohkubo T, Nagai K, et al. Prognosis of isolated systolic and isolated diastolic hypertension as assessed by self-measurement of blood pressure at home: the Ohasama study. Archives of Internal Medicine. 2000;160:3301-3306. [pmid: 11088093]. Cohort without data on predictors of adherence
Hozawa A, Shimazu T, Kuriyama S, Tsuji I. Benefit of home blood pressure measurement after a finding of high blood pressure at a community screening. Journal of Hypertension. 2006;24:1265-1271. [pmid: 16794474]. <8 week of SMBP
Hunt JS, Siemienczuk J, Pape G, et al. A randomized controlled trial of team-based care: impact of physician-pharmacist collaboration on uncontrolled hypertension. Journal of General Internal Medicine. 2008;23:1966-1972. [pmid: 18815843]. SMBP not analyzed intervention
Imai Y, Abe K, Hisamichi S, Tsuji I, Satoh H, Nagai K. [Evaluation of the effects of antihypertensive medication with home blood pressure measurements in a cohort of northern Japan]. [Japanese]. Japanese Circulation Journal. Suppl 4. 1994;58:1324-1327. [pmid: 7699786]. SMBP not analyzed intervention
Imai Y, Ohkubo T, Tsuji I, et al. Relationships among blood pressures obtained using different measurement methods in the general population of Ohasama, Japan. Hypertension Research - Clinical & Experimental. 1999;22:261-272. Accuracy/validation study
Ishikawa J, Carroll DJ, Kuruvilla S, Schwartz JE, Pickering TG. Changes in home versus clinic blood pressure with antihypertensive treatments: a meta-analysis. Hypertension. 2008;52:856-864. [pmid: 18809791]. Systematic review (reference list reviewed)
Ishikawa J, Kario K, Hoshide S, et al. Determinants of exaggerated difference in morning and evening blood pressure measured by self-measured blood pressure monitoring in medicated hypertensive patients: Jichi Morning Hypertension Research (J-MORE) Study. American Journal of Hypertension. 2005;18:958-965. [pmid: 16053993]. Cohort without data on predictors of adherence
Ito K, Obara T, Ohkubo T, et al. Influence of home blood pressure measuring conditions in the evening on the morning-evening home blood pressure difference in treated hypertensive patients: the J-HOME study. Blood Pressure Monitoring. 2009;14:160-165. [pmid: 19550298]. Cohort without data on predictors of adherence
Izquierdo R, Lagua CT, Meyer S, et al. Telemedicine intervention effects on waist circumference and body mass index in the IDEATel project. Diabetes Technology & Therapeutics. 2010;12:213-220. [pmid: 20151772]. SMBP not analyzed intervention
Jehn ML, Patt MR, Appel LJ, Miller ER III. One year follow-up of overweight and obese hypertensive adults following intensive lifestyle therapy. Journal of Human Nutrition & Dietetics. 2006;19:349-354. [pmid: 16961681]. SMBP not analyzed intervention
Johnson KA, Partsch DJ, Rippole LL, McVey DM. Reliability of self-reported blood pressure measurements. Archives of Internal Medicine. 1999;159:2689-2693. [pmid: 10597759]. <8 week of SMBP
Jula A, Puukka P, Karanko H. Multiple clinic and home blood pressure measurements versus ambulatory blood pressure monitoring. Hypertension. 1999;34:261-266. [pmid: 10454451]. Accuracy/validation study
Kamoi K, Ito T, Miyakoshi M, Minagawa S. Usefulness of home blood pressure measurement in the morning in patients with type 2 diabetes: long-term results of a prospective longitudinal study. Clinical & Experimental Hypertension (New York). 2010;32:184-192. Not a trial of SMBP
Karatzi K, Protogerou A, Rarra V, Stergiou GS. Home and office blood pressure in children and adolescents: the role of obesity. The Arsakeion School Study. Journal of Human Hypertension. 2009;23:512-520. [pmid: 19129855]. Cohort without data on predictors of adherence
Kario K. [Perfect 24-hr blood pressure control using self-measured blood pressure and ambulatory blood pressure monitoring in chronic kidney disease]. [Review] [20 refs] [Japanese]. Nippon Jinzo Gakkai Shi. 2009;51:465-470. [pmid: 19601555]. SMBP not analyzed intervention
Kario K, Matsui Y, Shibasaki S, et al. An alpha-adrenergic blocker titrated by self-measured blood pressure recordings lowered blood pressure and microalbuminuria in patients with morning hypertension: the Japan Morning Surge-1 Study. Journal of Hypertension. 2008;26:1257-1265. [pmid: 18475166]. SMBP not analyzed intervention
Karotsis AK, Symeonidis A, Mastorantonakis SE, Stergiou GS, Home-Di-Plus Study Group. Additional antihypertensive effect of drugs in hypertensive subjects uncontrolled on diltiazem monotherapy: a randomized controlled trial using office and home blood pressure monitoring. Clinical & Experimental Hypertension (New York). 2006;28:655-662. SMBP not analyzed intervention
Karpettas N, Kollias A, Vazeou A, Stergiou GS. Office, ambulatory and home blood pressure measurement in children and adolescents. [Review]. Expert Review of Cardiovascular Therapy. 2010;8:1567-1578. [pmid: 21090932]. Review of SMBP measurement accuracy
Kawabe H, Saito I. Does short sleep duration in daily life affect morning home blood pressure? Evaluation in Japanese people. Clinical & Experimental Hypertension (New York). 2008;30:183-190. SMBP not analyzed intervention
Kawabe H, Saito I. Influence of age and sex on prevalence of masked hypertension determined from home blood pressure measurements. Journal of Human Hypertension. 2007;21:94-95. [pmid: 17082798]. Cohort without data on predictors of adherence
Kawabe H, Saito I, Saruta T. Effects of nighttime alcohol intake on evening and next morning home blood pressure in Japanese normotensives. Clinical & Experimental Hypertension (New York). 2007;29:43-49. <8 week of SMBP
Kawano Y, Pontes CS, Abe H, Takishita S, Omae T. Effects of alcohol consumption and restriction on home blood pressure in hypertensive patients: serial changes in the morning and evening records. Clinical & Experimental Hypertension (New York). 2002;24:33-39. <8 week of SMBP
Kelly JT. Evaluating employee health risks due to hypertension and obesity: self-testing workplace health stations. Postgraduate Medicine. 2009;121:152-158. [pmid: 19179824]. Cohort without data on predictors of adherence
Khan IA, Gajaria M, Stephens D, Balfe JW. Ambulatory blood pressure monitoring in children: a large center's experience. Pediatric Nephrology. 2000;14:802-805. [pmid: 10955931]. SMBP not analyzed intervention
Kim MT, Han HR, Park HJ, Lee H, Kim KB. Constructing and testing a self-help intervention program for high blood pressure control in Korean American seniors--a pilot study. Journal of Cardiovascular Nursing. 2006;21:77-84. [pmid: 16601523]. Not comparative, N<100
Kjeldsen SE, Moan A, Petrin J, Weder AB, Zweifler AJ, Julius S. Evaluation of self-measured home vs. clinic intra-arterial blood pressure. Blood Pressure. 1993;2:28-34. [pmid: 8193727]. <8 week of SMBP
Konstantopoulou AS, Konstantopoulou PS, Papargyriou IK, Liatis ST, Stergiou GS, Papadogiannis DE. Masked, white coat and sustained hypertension: comparison of target organ damage and psychometric parameters. Journal of Human Hypertension. 2010;24:151-157. [pmid: 19571827]. Cohort without data on predictors of adherence
Kuriyama S, Otsuka Y, Iida R, Matsumoto K, Tokudome G, Hosoya T. Morning blood pressure predicts hypertensive organ damage in patients with renal diseases: effect of intensive antihypertensive therapy in patients with diabetic nephropathy. Internal Medicine. 2005;44:1239-1246. [pmid: 16415543]. Not comparative, N<100
Landert M, Holm D, Steurer J, Bachmann L, Vetter W. [Manipulation of blood pressure self-monitoring protocol values: a randomized controlled study]. [German]. Praxis. 2003;92:1075-1080. [pmid: 12830671]. SMBP not analyzed intervention
Larkin KT, Schauss SL, Elnicki DM, Goodie JL. Detecting white coat and reverse white coat effects in clinic settings using measures of blood pressure habituation in the clinic and patient self-monitoring of blood pressure. Journal of Human Hypertension. 2007;21:516-524. [pmid: 17361194]. <8 week of SMBP
Laughlin KD, Sherrard DJ, Fisher L. Comparison of clinic and home blood pressure levels in essential hypertension and variables associated with clinic-home differences. Journal of Chronic Diseases. 1980;33:197-206. [pmid: 7358822]. <8 week of SMBP
Leeman MJ, Lins RL, Sternon JE, Huberlant BC, Fassotte CE. Effect of antihypertensive treatment on office and self-measured blood pressure: the Autodil study. Journal of Human Hypertension. 2000;14:525-529. [pmid: 10962521]. <8 week of SMBP
Li Y, Thijs L, Hansen TW, et al. Prognostic value of the morning blood pressure surge in 5645 subjects from 8 populations. Hypertension. 2010;55:1040-1048. [pmid: 20212273]. SMBP not analyzed intervention
Lickvers K, Kottmair S, Rose I, Muller M, Middeke M. [Results of the “Health Program Hypertension” of the German Health Insurance (DKV)]. [German]. Deutsche Medizinische Wochenschrift. 2005;130:2628-2630. [pmid: 16281157]. Cohort without data on predictors of adherence
Llisterri JL, Alonso FJ, Gorostidi M, et al. [Differences between office and ambulatory control of hypertension in very elderly patients. The CARDIORISC - MAPAPRES project]. [Spanish]. Medicina Clinica. 2009;133:769-776. [pmid: 19819490]. Cohort without data on predictors of adherence
Logan AG, McIsaac WJ, Tisler A, et al. Mobile phone-based remote patient monitoring system for management of hypertension in diabetic patients. American Journal of Hypertension. 2007;20:942-948. [pmid: 17765133]. Not comparative, N<100
Lou LM, Gimeno JA, Gomez SR, et al. [Comparison of clinical arterial pressure, home-arterial pressure measurement, and ambulatory arterial pressure monitoring in patients with type II diabetes mellitus and diabetic nephropathy]. [Spanish]. Nefrologia. 2002;22:179-189. [pmid: 12085419]. Diagnosis study
Magadza C, Radloff SE, Srinivas SC. The effect of an educational intervention on patients' knowledge about hypertension, beliefs about medicines, and adherence. Research In Social & Administrative Pharmacy. 2009;5:363-375. [pmid: 19962679]. SMBP not analyzed intervention
Magometschnigg D, Havelec L, Schnogl H, et al. [Comparison of results of daily blood pressure self-monitoring and general practice monitoring within the scope of a study assessing treatment of hypertension with quinapril]. [German]. Wiener Medizinische Wochenschrift. 1992;142:501-512. [pmid: 1290245]. SMBP not analyzed intervention
Maldonado J, Pereira T, Estudo AMPA. Self-measurement of blood pressure in arterial hypertension--preliminary results from the AMPA study. Revista Portuguesa de Cardiologia. 2009;28:7-21. [pmid: 19388489]. Cohort without data on predictors of adherence
Mallion JM, Genes N, Vaur L, et al. Blood pressure levels, risk factors and antihypertensive treatments: lessons from the SHEAF study. Journal of Human Hypertension. 2001;15:841-848. [pmid: 11773986]. <8 week of SMBP
Mancia G, Bombelli M, Corrao G, et al. Metabolic syndrome in the Pressioni Arteriose Monitorate E Loro Associazioni (PAMELA) study: daily life blood pressure, cardiac damage, and prognosis. Hypertension. 2007;49:40-47. [pmid: 17130308]. SMBP not analyzed intervention
Mancia G, Bombelli M, Facchetti R, et al. Long-term risk of sustained hypertension in white-coat or masked hypertension. Hypertension. 2009;54:226-232. [pmid: 19564548]. Cohort without data on predictors of adherence
Mancia G, Bombelli M, Lanzarotti A, et al. Systolic vs diastolic blood pressure control in the hypertensive patients of the PAMELA population. Pressioni Arteriose Monitorate E Loro Associazioni. Archives of Internal Medicine. 2002;162:582-586. [pmid: 11871927]. Cohort without data on predictors of adherence
Mancia G, Facchetti R, Bombelli M, Grassi G, Sega R. Long-term risk of mortality associated with selective and combined elevation in office, home, and ambulatory blood pressure. Hypertension. 2006;47:846-853. [pmid: 16567588]. Diagnosis study
Mancia G, Pessina AC, Trimarco B, Grassi G, SILVIA (Studio Italiano Longitudinale sulla Valutazione della Ipertensione Arteriosa nel. Blood pressure control according to new guidelines targets in low-to high-risk hypertensives managed in specialist practice. Journal of Hypertension. 2004;22:2387-2396. [pmid: 15614034]. Cohort without data on predictors of adherence
Mancia G, Sega R, Milesi C, Cesana G, Zanchetti A. Blood-pressure control in the hypertensive population. Lancet. 1997;349:454-457. [pmid: 9040574]. Cohort without data on predictors of adherence
Manus JM. [Self monitoring and management of hypertension]. [French]. Revue de L'Infirmiere. 2003;95:36. Not a study
Mario B, Massimiliano M, Chiara M, Alessandro S, Antonella C, Gianfranco F. White-coat effect among older patients with suspected cognitive impairment: prevalence and clinical implications. International Journal of Geriatric Psychiatry. 2009;24:509-517. [pmid: 18937278]. Cohort without data on predictors of adherence
Martinez MA, Sancho T, Garcia P, et al. Home blood pressure in poorly controlled hypertension: relationship with ambulatory blood pressure and organ damage. Blood Pressure Monitoring. 2006;11:207-213. [pmid: 16810031]. Cross-sectional
McCant F, McKoy G, Grubber J, et al. Feasibility of blood pressure telemonitoring in patients with poor blood pressure control. Journal of Telemedicine & Telecare. 2009;15:281-285. [pmid: 19720764]. No outcomes or analyses of interest
McManus RJ, Mant J, Roalfe A, et al. Targets and self monitoring in hypertension: randomised controlled trial and cost effectiveness analysis. BMJ. 2005;331:493. [pmid: 16115830]. BP measured in office setting
Menard J, Serrurier D, Bautier P, Plouin PF, Corvol P. Crossover design to test antihypertensive drugs with self-recorded blood pressure. Hypertension. 1988;11:153-159. [pmid: 3277912]. Not comparative, N<100
Mengden T. Long term control of blood pressure guided by self-messurement is superior to usual office based care. Deutsche Medizinische Wochenschrift. Suppl 3. 1999;124:S92. Abstract
Mengden T, Binswanger B, Spuhler T, Weisser B, Vetter W. The use of self-measured blood pressure determinations in assessing dynamics of drug compliance in a study with amlodipine once a day, morning versus evening. Journal of Hypertension. 1993;11:1403-1411. [pmid: 8133022]. SMBP not analyzed intervention
Mengden T, Binswanger B, Weisser B, Vetter W. An evaluation of self-measured blood pressure in a study with a calcium-channel antagonist versus a beta-blocker. American Journal of Hypertension. 1992;5:154-160. [pmid: 1349485]. SMBP not analyzed intervention
Metoki H, Ohkubo T, Kikuya M, et al. Prognostic significance for stroke of a morning pressor surge and a nocturnal blood pressure decline: the Ohasama study. Hypertension. 2006;47:149-154. [pmid: 16380533]. Cohort without data on predictors of adherence
Mooney LA, Franks AM. Evaluation of community health screening participants' knowledge of cardiovascular risk factors. Journal of the American Pharmacists Association: JAPhA. 2004;49:529-537. [pmid: 19589765]. SMBP not analyzed intervention
Morgan PJ, Lubans DR, Collins CE, Warren JM, Callister R. The SHED-IT randomized controlled trial: evaluation of an Internet-based weight-loss program for men. Obesity. 2009;17:2025-2032. [pmid: 19343018]. SMBP not analyzed intervention
Msanobu T, HACARARE Study Group. [Evaluation of antihypertensive effect of angiotensin II receptor blockers in patients with essential hypertension by self-measured home blood pressure--HACARARE 300 study]. [Japanese]. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2009;67:2013-2020. SMBP not analyzed intervention
Muhlhauser I, Sawicki P, Didjurgeit U, Jorgens V, Berger M. Uncontrolled hypertension in type 1 diabetes: assessment of patients' desires about treatment and improvement of blood pressure control by a structured treatment and teaching programme. Diabetic Medicine. 1988;5:693-698. [pmid: 2975558]. Not a comparative study
Mule G, Caimi G, Cottone S, et al. Value of home blood pressures as predictor of target organ damage in mild arterial hypertension. Journal of Cardiovascular Risk. 2002;9:123-129. [pmid: 12006920]. Cohort without data on predictors of adherence
Nagashio M, Suzuki Y, Onishi Y, et al. [Post-operative cardiac rehabilitation programs for early returning to daily life activities: self-measurement of heart rate and blood pressure during staying at home trial]. [Japanese]. Journal of Cardiology. 2003;41:91-95. [pmid: 12649927]. Not comparative, N<100
Narkiewicz K. Comparison of home and office blood pressure in hypertensive patients treated with zofenopril or losartan. Blood Pressure Supplement. 2007;2:7-12. [pmid: 18046973]. SMBP not analyzed intervention
Neeser K, Weber C. Cost impact of self-measurement of blood glucose on complications of type 2 diabetes: the Spanish perspective. Diabetes Technology & Therapeutics. 2009;11:509-516. [pmid: 19698064]. SMBP not analyzed intervention
Nielsen PE, Myschetzky P, Andersen AR, Andersen GS. Home readings of blood pressure in assessment of hypertensive subjects. Acta Medica Scandinavica - Supplementum. 1986;714:147-151. [pmid: 3472436]. <8 week of SMBP
Niiranen TJ, Hanninen MR, Johansson J, Reunanen A, Jula AM. Home-measured blood pressure is a stronger predictor of cardiovascular risk than office blood pressure: the Finn-Home study. Hypertension. 2010;55:1346-1351. [pmid: 20385970]. Cohort without data on predictors of adherence
Niiranen TJ, Jula AM, Kantola IM, Karanko H, Reunanen A. Home-measured blood pressure is more strongly associated with electrocardiographic left ventricular hypertrophy than is clinic blood pressure: the Finn-HOME study. Journal of Human Hypertension. 2007;21:788-794. [pmid: 17637793]. Diagnosis study
Niiranen TJ, Kantola IM, Vesalainen R, Johansson J, Ruuska MJ. A comparison of home measurement and ambulatory monitoring of blood pressure in the adjustment of antihypertensive treatment. American Journal of Hypertension. 2006;19:468-474. [pmid: 16647616]. SMBP not analyzed intervention
Nilsson M, Rasmark U, Nordgren H, et al. The physician at a distance: the use of videoconferencing in the treatment of patients with hypertension. Journal of Telemedicine & Telecare. 2009;15:397-403. [pmid: 19948706]. SMBP not analyzed intervention
Nishinaga M, Takata J, Okumiya K, Matsubayashi K, Ozawa T, Doi Y. High morning home blood pressure is associated with a loss of functional independence in the community-dwelling elderly aged 75 years or older. Hypertension Research - Clinical & Experimental. 2005;28:657-663. Cohort without data on predictors of adherence
Nordmann A, Frach B, Walker T, Martina B, Battegay E. Reliability of patients measuring blood pressure at home: prospective observational study. BMJ. 1999;319:1172. [pmid: 10541509]. <8 week of SMBP
Obara T, Ito K, Ohkubo T, et al. Uncontrolled hypertension based on morning and evening home blood pressure measurements from the J-HOME study. Hypertension Research - Clinical & Experimental. 2009;32:1072-1078. Cohort without data on predictors of adherence
Obara T, Ohkubo T, Asayama K, et al. Prevalence of Masked Hypertension in Subjects Treated with Antihypertensive Drugs as Assessed by Morning versus Evening Home Blood Pressure Measurements: the J-HOME study. Clinical & Experimental Hypertension (New York). 2008;30:277-287. Diagnosis study
Obara T, Ohkubo T, Asayama K, et al. Home blood pressure measurements associated with better blood pressure control: the J-HOME study. Journal of Human Hypertension. 2008;22:197-204. [pmid: 18172452]. <8 week of SMBP
Obara T, Ohkubo T, Kikuya M, et al. The current status of home and office blood pressure control among hypertensive patients with diabetes mellitus: the Japan Home Versus Office Blood Pressure Measurement Evaluation (J-HOME) study. Diabetes Research & Clinical Practice. 2006;73:276-283. [pmid: 16595157]. Cross-sectional
Ogedegbe G, Schoenthaler A. A systematic review of the effects of home blood pressure monitoring on medication adherence. [Review] [27 refs]. Journal of Clinical Hypertension. 2006;8:174-180. [pmid: 16522994]. Systematic review (reference list reviewed)
Ogedegbe G, Tobin JN, Fernandez S, et al. Counseling African Americans to Control Hypertension (CAATCH) trial: a multi-level intervention to improve blood pressure control in hypertensive blacks. Circulation. 2009;2:249-256. [pmid: 20031845]. Study protocol
Ohkubo T, Asayama K, Imai Y. The value of self-measured home blood pressure in predicting stroke. [Review] [29 refs]. Expert Review of Neurotherapeutics. 2006;6:163-173. [pmid: 16466296]. Diagnosis study
Ohkubo T, Asayama K, Kikuya M, et al. How many times should blood pressure be measured at home for better prediction of stroke risk? Ten-year follow-up results from the Ohasama study. Journal of Hypertension. 2004;22:1099-1104. [pmid: 15167443]. <8 week of SMBP
Ohkubo T, Asayama K, Kikuya M, et al. Prediction of ischaemic and haemorrhagic stroke by self-measured blood pressure at home: the Ohasama study. [Review] [21 refs]. Blood Pressure Monitoring. 2004;9:315-320. [pmid: 15564987]. Diagnosis study
Ohkubo T, Imai Y, Tsuji I, et al. Home blood pressure measurement has a stronger predictive power for mortality than does screening blood pressure measurement: a population-based observation in Ohasama, Japan. Journal of Hypertension. 1998;16:971-975. [pmid: 9794737]. Diagnosis study
Oikawa T, Obara T, Ohkubo T, et al. Characteristics of resistant hypertension determined by self-measured blood pressure at home and office blood pressure measurements: the J-HOME study. Journal of Hypertension. 2006;24:1737-1743. [pmid: 16915022]. Diagnosis study
Palmas W, Pickering TG, Teresi J, et al. Telemedicine home blood pressure measurements and progression of albuminuria in elderly people with diabetes. Hypertension. 2008;51:1282-1288. [pmid: 18378859]. Cohort without data on predictors of adherence
Parati G, Omboni S. Role of home blood pressure telemonitoring in hypertension management: an update. [Review]. Blood Pressure Monitoring. 2010;15:285-295. [pmid: 21084882]. Review article (reference list reviewed)
Pavlik VN, Greisinger AJ, Pool J, Haidet P, Hyman DJ. Does reducing physician uncertainty improve hypertension control?: rationale and methods. Circulation. Cardiovascular. 2009:257-263. SMBP not analyzed intervention
Perry HM Jr, Camel GH. Survival of treated hypertensive patients as a function of compliance and control. Journal of Hypertension - Supplement. 1984;2:S197-S199. Cohort without data on predictors of adherence
Phillips RA, Weinberg JM. Hypertension 2005: an evidence-based approach to diagnosis and treatment - an American perspective. [Review] [63 refs]. Expert Review of Cardiovascular Therapy. 2005;3:691-704. [pmid: 16076279]. Not a study
Pickering TG, Gerin W, Holland JK. Home blood pressure teletransmission for better diagnosis and treatment. Current Hypertension Reports. 1999;1:489-494. [pmid: 10981111]. Not a study
Pickering TG, Miller NH, Ogedegbe G, Krakoff LR, Artinian NT, Goff D. Call to action on use and reimbursement for home blood pressure monitoring: Executive Summary. A joint scientific statement from the American Heart Association, American Society of Hypertension, and Preventive Cardiovascular Nurses Association. Journal of Clinical Hypertension. 2008;10:467-476. [pmid: 18550937]. Not a study
Pinna GD, Maestri R, Andrews D, et al. Home telemonitoring of vital signs and cardiorespiratory signals in heart failure patients: system architecture and feasibility of the HHH model. International Journal of Cardiology. 2007;120:371-379. [pmid: 17189654]. No outcomes or analyses of interest
Poncelet P, Clerson P, Ribstein J, Bassous M, Scart GC. [Is masked hypertension an artefact due to the blood pressure measurement method and threshold effects?]. [French]. Archives des Maladies du Coeur et des Vaisseaux. 2005;98:751-756. [pmid: 16220742]. Diagnosis study
Port K, Palm K, Viigimaa M. Daily usage and efficiency of remote home monitoring in hypertensive patients over a one-year period. Journal of Telemedicine & Telecare. Suppl 1. 2005;11:34-36. [pmid: 16035987]. Not comparative, N<100
Powers BJ, Olsen MK, Oddone EZ, Bosworth HB. The effect of a hypertension self-management intervention on diabetes and cholesterol control. American Journal of Medicine. 2009;122:639-646. [pmid: 19559166]. SMBP not analyzed intervention
Queiroz AC, Gagliardi JF, Forjaz CL, Rezk CC. Clinic and ambulatory blood pressure responses after resistance exercise. Journal of Strength & Conditioning Research. 2009;23:571-578. [pmid: 19209079]. SMBP not analyzed intervention
Qureshi G, Salciccioli L, Clark LT, Lazar J. Home blood pressure monitoring in an ethnically diverse inner-city cardiology practice. Ethnicity & Disease. 2008;18:37-41. [pmid: 18447097]. Not comparative, N<100
Ragot S, Ezzaher A, Meunier A, Poterre M, Bourkaib R, Herpin D. Comparison of trough effect of telmisartan vs perindopril using self blood pressure measurement: EVERESTE study. Journal of Human Hypertension. 2002;16:865-873. [pmid: 12522468]. SMBP not analyzed intervention
Ragot S, Genes N, Vaur L, Herpin D. Comparison of three blood pressure measurement methods for the evaluation of two antihypertensive drugs: feasibility, agreement, and reproducibility of blood pressure response. American Journal of Hypertension. 2000;13:632-639. [pmid: 10912746]. SMBP not analyzed intervention
Rajzer M. [Effect of telemonitoring of blood pressure in patients with hypertension]. Nadcisnienie Tetnicze. 2007;11:318-327. <8 week of SMBP
Reed SD, Li Y, Oddone EZ, et al. Economic evaluation of home blood pressure monitoring with or without telephonic behavioral self-management in patients with hypertension. American Journal of Hypertension. 2010;23:142-148. [pmid: 19927132]. SMBP not analyzed intervention
Reims HM, Kjeldsen SE, Mancia G. Home blood pressure monitoring. Journal of Hypertension. 2005;23:1437-1439. [pmid: 15942472]. Not a study
Russo GE, Torre MC, Tosco U, Caramiello MS, Russo R, Scarpellini MG. [Monitored and random arterial blood pressure as prediction of biological risk. Comparison with domiciliary self-measurement]. [Italian]. Annali Italiani di Medicina Interna. 1990;5:106-111. [pmid: 2248857]. Accuracy/validation study
Sabater-Hernandez D, Azpilicueta I, Sanchez-Villegas P, Amariles P, Baena MI, Faus MJ. Clinical value of blood pressure measurement in the community pharmacy. [Review]. Pharmacy World & Science. 2010;32:552-558. [pmid: 20652831]. Review of pharmacy BP measurement
Saito S, Asayama K, Ohkubo T, et al. The second progress report on the Hypertension Objective treatment based on Measurement by Electrical Devices of Blood Pressure (HOMED-BP) study. Blood Pressure Monitoring. 2004;9:243-247. [pmid: 15472496]. SMBP not analyzed intervention
Sakaguchi K, Horimatsu T, Kishi M, et al. Isolated home hypertension in the morning is associated with target organ damage in patients with type 2 diabetes. Journal of Atherosclerosis & Thrombosis. 2005;12:225-231. [pmid: 16141627]. Cohort without data on predictors of adherence
Santamore WP, Homko CJ, Kashem A, McConnell TR, Bove AA. Using a telemedicine system to decrease cardiovascular disease risk in an underserved population: design, use, and interim results. Conf Proc IEEE Eng Med Biol Soc. 2007;2007:3701-3704. [pmid: 18002801]. No outcomes or analyses of interest
Sato A, Asayama K, Ohkubo T, et al. Optimal cutoff point of waist circumference and use of home blood pressure as a definition of metabolic syndrome: the Ohasama study. American Journal of Hypertension. 2008;21:514-520. [pmid: 18437142]. Cohort without data on predictors of adherence
Scherr D, Kastner P, Kollmann A, et al. Effect of home-based telemonitoring using mobile phone technology on the outcome of heart failure patients after an episode of acute decompensation: randomized controlled trial. Journal of Medical Internet Research. 2009;11:e34. [pmid: 19687005]. Heart failure. SMBP used as part of telemonitoring
Schroeder K. Making rational therapeutic decisions in hypertension: How useful are electronic monitors in improving blood pressure control?. American Journal of Hypertension. 2007;20:126. [pmid: 17261455]. Not a study
Sega R, Facchetti R, Bombelli M, et al. Prognostic value of ambulatory and home blood pressures compared with office blood pressure in the general population: follow-up results from the Pressioni Arteriose Monitorate e Loro Associazioni (PAMELA) study. Circulation. 2005;111:1777-1783. [pmid: 15809377]. Cohort without data on predictors of adherence
Sega R, Trocino G, Lanzarotti A, et al. Alterations of cardiac structure in patients with isolated office, ambulatory, or home hypertension: Data from the general population (Pressione Arteriose Monitorate E Loro Associazioni [PAMELA] Study). Circulation. 2001;104:1385-1392. [pmid: 11560854]. Diagnosis study
Sheps SG, Canzanello VJ. Current role of automated ambulatory blood pressure and self-measured blood pressure determinations in clinical practice. Mayo Clinic Proceedings. 1994;69:1000-1005. [pmid: 7934181]. Not a study
Shibuya Y, Ikeda T, Gomi T. Morning rise of blood pressure assessed by home blood pressure monitoring is associated with left ventricular hypertrophy in hypertensive patients receiving long-term antihypertensive medication. Hypertension Research - Clinical & Experimental. 2007;30:903-911. Diagnosis study
Shim H, Kim HM, Song SH, et al. Personalized healthcare note service for hypertension patients using mobile device. Conf Proc IEEE Eng Med Biol Soc. 2008;2008:1521-1524. [pmid: 19162961]. Not a study
Shimada K, Fujita T, Ito S, et al. The importance of home blood pressure measurement for preventing stroke and cardiovascular disease in hypertensive patients: a sub-analysis of the Japan Hypertension Evaluation with Angiotensin II Antagonist Losartan Therapy (J-HEALTH) study, a prospective nationwide observational study. Hypertension Research - Clinical & Experimental. 2008;31:1903-1911. Diagnosis study
Smith MA. Home blood pressure monitoring. American Pharmacy. 1985;NS25:46-48. [pmid: 3984852]. Not a study
Staessen JA, Thijs L, Ohkubo T, et al. Thirty years of research on diagnostic and therapeutic thresholds for the self-measured blood pressure at home. Blood Pressure Monitoring. 2008;13:352-365. [pmid: 19020427]. Not a study
Stepien M, Stepien A, Matusewicz W. Comparative analysis of ambulatory self-measurement of blood pressure and automatic ambulatory blood pressure monitoring. Acta Cardiologica. 2002;57:74-75. [pmid: 11918165]. Accuracy/validation study
Stepien M, Stepien A, Matusewicz W. [Evaluation of self-measurement of blood pressure im ambulatory monitoring of hypertension therapy]. [Polish]. Przeglad Lekarski. 2002;59:756-758. [pmid: 12632904]. Accuracy/validation study
Stergiou GS. Which is the correct term for blood pressure measurements taken at home?. [Review] [19 refs]. Blood Pressure Monitoring. 2003;8:165-167. [pmid: 14517480]. Not a study
Stergiou GS. Ambulatory or home blood pressure monitoring for treatment adjustment?. [Review] [5 refs]. American Journal of Hypertension. 2006;19:475-476. [pmid: 16647617]. Not a study
Stergiou GS, Efstathiou SP, Alamara CV, Mastorantonakis SE, Roussias LG. Home or self blood pressure measurement? What is the correct term?. Journal of Hypertension. 2003;21:2259-2264. [pmid: 14654745]. <8 week of SMBP
Stergiou GS, Nasothimiou E, Giovas P, Kapoyiannis A, Vazeou A. Diagnosis of hypertension in children and adolescents based on home versus ambulatory blood pressure monitoring. Journal of Hypertension. 2008;26:1556-1562. [pmid: 18622232]. Diagnosis study
Stergiou GS, Salgami EV, Tzamouranis DG, Roussias LG. Masked hypertension assessed by ambulatory blood pressure versus home blood pressure monitoring: is it the same phenomenon?. American Journal of Hypertension. 2005;18:772-778. [pmid: 15925734]. Diagnosis study
Stergiou GS, Skeva II, Baibas NM, Kalkana CB, Roussias LG, Mountokalakis TD. Diagnosis of hypertension using home or ambulatory blood pressure monitoring: comparison with the conventional strategy based on repeated clinic blood pressure measurements. Journal of Hypertension. 2000;18:1745-1751. [pmid: 11132597]. <8 week of SMBP
Stergiou GS, Voutsa AV, Achimastos AD, Mountokalakis TD. Home self-monitoring of blood pressure: is fully automated oscillometric technique as good as conventional stethoscopic technique?. American Journal of Hypertension. 1997;10:428-433. [pmid: 9128209]. <8 week of SMBP
Stergiou GS, Yiannes NG, Rarra VC, Panagiotakos DB. Home blood pressure normalcy in children and adolescents: the Arsakeion School study. Journal of Hypertension. 2007;25:1375-1379. [pmid: 17563558]. Diagnosis study
Steurer-Stey C, Zoller M, Moshinsky CC, Senn O, Rosemann T. Does a colour-coded blood pressure diary improve blood pressure control for patients in general practice: the CoCo trial. Trials [Electronic Resource]. 2010;11:38. Study protocol
Sulakova T, Janda J, Cerna J, et al. Arterial HTN in children with T1DM--frequent and not easy to diagnose. Pediatric Diabetes. 2009;10:441-448. [pmid: 19500279]. SMBP not analyzed intervention
Svetkey LP, Pollak KI, Yancy WS Jr, et al. Hypertension improvement project: randomized trial of quality improvement for physicians and lifestyle modification for patients. Hypertension. 2009;54:1226-1233. [pmid: 19920081]. SMBP not analyzed intervention
Szirmai LA, Arnold C, Farsang C. Improving control of hypertension by an integrated approach -- results of the ‘Manage it well!’ programme. Journal of Hypertension. 2005;23:203-211. [pmid: 15643143]. <8 week of SMBP
Tachibana R, Tabara Y, Kondo I, Miki T, Kohara K. Home blood pressure is a better predictor of carotid atherosclerosis than office blood pressure in community-dwelling subjects. Hypertension Research - Clinical & Experimental. 2004;27:633-639. Cohort without data on predictors of adherence
Tamaki S, Nakamura Y, Teramura M, et al. The factors contributing to whether or not hypertensive patients bring their home blood pressure record to the outpatient clinic. Internal Medicine. 2008;47:1561-1565. [pmid: 18797113]. No outcomes or analyses of interest
Tan NC, Khin LW, Pagi R. Home blood-pressure monitoring among hypertensive patients in an Asian population. Journal of Human Hypertension. 2005;19:559-564. [pmid: 15944723]. Cross-sectional
Terawaki H. Home blood pressure monitoring, even by the elderly, may save a kidney. Hypertension Research - Clinical & Experimental. 2009;32:1055. Not a study
Thiboutot J, Stuckey H, Binette A, et al. A web-based patient activation intervention to improve hypertension care: study design and baseline characteristics in the web hypertension study. Contemporary Clinical Trials. 2010;31:634-646. [pmid: 20837163]. No SMBP in intervention
Thijs L, Staessen JA, Celis H, et al. The international database of self-recorded blood pressures in normotensive and untreated hypertensive subjects. Blood Pressure Monitoring. 1999;4:77-86. [pmid: 10450117]. Accuracy/validation study
Thorpe CT, Oddone EZ, Bosworth HB. Patient and social environment factors associated with self blood pressure monitoring by male veterans with hypertension. Journal of Clinical Hypertension. 2008;10:692-699. [pmid: 18844764]. Cross-sectional
Tobe SW, Hunter K, Geerts R, Raymond N, Pylypchuk G, Canadian Hypertension Society. IMPPACT: Investigation of Medical Professionals and Patients Achieving Control Together. Canadian Journal of Cardiology. 2008;24:205-208. [pmid: 18340390]. <8 week of SMBP
Torrisi G, Di MS, Spallina G, Campisi M, Leotta C, Malaguarnera M. A diary model for monitoring blood pressure in the elderly. European Review for Medical & Pharmacological Sciences. 1997;1:119-124. [pmid: 9558777]. SMBP not analyzed intervention
Trief PM, Teresi JA, Eimicke JP, Shea S, Weinstock RS. Improvement in diabetes self-efficacy and glycaemic control using telemedicine in a sample of older, ethnically diverse individuals who have diabetes: the IDEATel project. Age & Ageing. 2009;38:219-225. [pmid: 19171951]. SMBP not analyzed intervention
Tyson MJ, McElduff P. Self-blood-pressure monitoring--a questionnaire study: response, requirement, training, support-group popularity and recommendations. Journal of Human Hypertension. 2003;17:51-61. [pmid: 12571617]. Cross-sectional
Uchida H, Nakamura Y, Kaihara M, Norii H, Hanayama Y, Makino H. The MUSCAT study: a Multicenter PROBE Study Comparing the Effects of Angiotensin II Type-1 Receptor Blockers on Self-Monitored Home Blood Pressure in Patients with Morning Hypertension: study design and background characteristics. Hypertension Research - Clinical & Experimental. 2008;31:51-58. Study protocol
Vaisse B, Genes N, Vaur L, et al. [The feasibility of at-home self-monitoring blood pressure in elderly hypertensive patients]. [French]. Archives des Maladies du Coeur et des Vaisseaux. 2000;93:963-967. [pmid: 10989738]. <8 week of SMBP
Verberk WJ, Kroon AA, Kessels AG, de Leeuw PW. Home blood pressure measurement: a systematic review. [Review] [83 refs]. Journal of the American College of Cardiology. 2005;46:743-751. [pmid: 16139119]. Systematic review (reference list reviewed)
Verberk WJ, Thien T, Kroon AA, et al. Prevalence and persistence of masked hypertension in treated hypertensive patients. American Journal of Hypertension. 2007;20:1258-1265. [pmid: 18047914]. Diagnosis study
Vetter W, Hess L, Brignoli R. Influence of self-measurement of blood pressure on the responder rate in hypertensive patients treated with losartan: results of the SVATCH Study. Standard vs Automatic Treatment Control of COSAAR in Hypertension. Journal of Human Hypertension. 2000;14:235-241. [pmid: 10805048]. Wrist SMBP measurement
Viera AJ, Cohen LW, Mitchell CM, Sloane PD. Use of home blood pressure monitoring by hypertensive patients in primary care: survey of a practice-based research network cohort. Journal of Clinical Hypertension. 2008;10:280-286. [pmid: 18401225]. Cohort without data on predictors of adherence
Warren RE, Marshall T, Padfield PL, Chrubasik S. Variability of office, 24-hour ambulatory, and self-monitored blood pressure measurements. British Journal of General Practice. 2010;60:675-680. [pmid: 20849695]. Cohort study without adherence data
Waugh J, Halligan A, Shennan A. Antenatal home blood pressure monitoring: a pilot randomised controlled trial. BJOG: An International Journal of Obstetrics & Gynaecology. 2000;107:1180-1181. [pmid: 11002971]. Not a study
Weintraub A, Gregory D, Patel AR, et al. A multicenter randomized controlled evaluation of automated home monitoring and telephonic disease management in patients recently hospitalized for congestive heart failure: the SPAN-CHF II trial. Journal of Cardiac Failure. 2010;16:285-292. [pmid: 20350694]. Heart failure. SMBP used as part of telemonitoring
Weiss JJ, Osorio G, Ryan E, Marcus SM, Fishbein DA. Prevalence and patient awareness of medical comorbidities in an urban AIDS clinic. AIDS Patient Care & Stds. 2010;24:39-48. [pmid: 20095901]. SMBP not analyzed intervention
Welin L, Svardsudd K, Tibblin G. Home blood pressure measurements--feasibility and results compared to office measurements. The study of men born in 1913. Acta Medica Scandinavica. 1982;211:275-279. [pmid: 7102366]. Accuracy/validation study
Wetzels GE, Nelemans PJ, Schouten JS, et al. Electronic monitoring of adherence as a tool to improve blood pressure control. A randomized controlled trial. American Journal of Hypertension. 2007;20:119-125. [pmid: 17261454]. SMBP not analyzed intervention
White WB, Asmar R, Imai Y, et al. Task force VI: Self-monitoring of the blood pressure. [Review] [67 refs]. Blood Pressure Monitoring. 1999;4:343-351. [pmid: 10602538]. Not a study
Xue F, Yao W, Lewin RJ. A randomised trial of a 5 week, manual based, self-management programme for hypertension delivered in a cardiac patient club in Shanghai. BMC Cardiovascular Disorders. 2008;8:10. [pmid: 18460201]. <8 week of SMBP
Yamasue K, Tochikubo O, Kono E, Maeda H. Self-monitoring of home blood pressure with estimation of daily salt intake using a new electrical device. Journal of Human Hypertension. 2006;20:593-598. [pmid: 16710288]. Cohort without data on predictors of adherence
Yan IR, Poon CC, Zhang YT. A protocol design for evaluation of wearable cuff-less blood pressure measuring devices. Conf Proc IEEE Eng Med Biol Soc. 2009;2009:7045-7047. [pmid: 19964197]. Accuracy/validation study
Yasui D, Asayama K, Ohkubo T, et al. Stroke risk in treated hypertension based on home blood pressure: the Ohasama study. American Journal of Hypertension. 2010;23:508-514. [pmid: 20186131]. Cohort without data on predictors of adherence
Yavuz BB, Yavuz B, Tayfur O, et al. White coat effect and its clinical implications in the elderly. Clinical & Experimental Hypertension (New York). 2009;31:306-315. SMBP not analyzed intervention
Yen LL, Patrick WK, Chie WC. Comparison of relaxation techniques, routine blood pressure measurements, and self-learning packages in hypertension control. Preventive Medicine. 1996;25:339-345. [pmid: 8781012]. SMBP not analyzed intervention
Yin TT, Williams N, Burton C, et al. Hypertension, fetal growth restriction and obstructive sleep apnoea in pregnancy. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 2008;141:35-38. SMBP not analyzed intervention
Yoshitomi Y, Nagakura C, Miyauchi A. Significance of mean blood pressure for blood pressure control. International Heart Journal. 2005;46:691-699. [pmid: 16157960]. Cohort without data on predictors of adherence
Zhuo S, Wen W, Li-Yuan M, Shu-Yu W, Yi-Xin W. Home blood pressure measurement in prehypertension and untreated hypertension: comparison with ambulatory blood pressure monitoring and office blood pressure. Blood Pressure Monitoring. 2009;14:245-250. [pmid: 19918171]. Accuracy/validation study
Zutz A, Ignaszewski A, Bates J, Lear SA. Utilization of the internet to deliver cardiac rehabilitation at a distance: a pilot study. Telemedicine Journal & E-Health. 2007;13:323-330. [pmid: 17603835]. SMBP not analyzed intervention