# Literature Search Strategy

Databases: Ovid MEDLINE, MEDLINE(R) In-Process, Cochrane Controlled Trials Register (CCTR) Last run 2/17/2010

# | Searches
1 | exp Blood Pressure Monitoring, Ambulatory/ | SMBP
2 | exp Blood Pressure Monitors/ | SMBP
3 | exp Blood Pressure/ | SMBP
4 | exp hypertension/ | SMBP
5 | exp Self Care/ | SMBP
6 | (3 or 4) and 5 | SMBP
7 | ((blood pressure or hypertens$) and self and (measure$ or monitor$ or care or manage$)).mp. | SMBP
8 | 1 or 2 or 6 or 7 | SMBP
9 | randomized controlled trial.pt. | Comparative Studies (KQ 1-3)
10 | controlled clinical trial.pt. | Comparative Studies (KQ 1-3)
11 | randomized controlled trials/ | Comparative Studies (KQ 1-3)
12 | Random Allocation/ | Comparative Studies (KQ 1-3)
13 | Double-blind Method/ | Comparative Studies (KQ 1-3)
14 | Single-Blind Method/ | Comparative Studies (KQ 1-3)
15 | clinical trial.pt. | Comparative Studies (KQ 1-3)
16 | Clinical Trials.mp. or exp Clinical Trials/ | Comparative Studies (KQ 1-3)
17 | (clinic$ adj25 trial$).tw. | Comparative Studies (KQ 1-3)
18 | ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. | Comparative Studies (KQ 1-3)
19 | Placebos/ | Comparative Studies (KQ 1-3)
20 | placebo$.tw. | Comparative Studies (KQ 1-3)
21 | random$.tw. | Comparative Studies (KQ 1-3)
22 | trial$.tw. | Comparative Studies (KQ 1-3)
23 | (randomized control trial or clinical control trial).sd. | Comparative Studies (KQ 1-3)
24 | (latin adj square).tw. | Comparative Studies (KQ 1-3)
25 | Comparative Study.tw. or Comparative Study.pt. | Comparative Studies (KQ 1-3)
26 | exp Evaluation studies/ | Comparative Studies (KQ 1-3)
27 | Follow-Up Studies/ | Comparative Studies (KQ 1-3)
28 | Prospective Studies/ | Comparative Studies (KQ 1-3)
29 | (control$ or prospectiv$ or volunteer$).tw. | Comparative Studies (KQ 1-3)
30 | Cross-Over Studies/ | Comparative Studies (KQ 1-3)
31 | or/9-30 | Comparative Studies (KQ 1-3)
32 | exp cohort studies/ or exp prospective studies/ or exp retrospective studies/ or exp epidemiologic studies/ or exp case-control studies/ | Cohorts (KQ 4)
33 | (cohort or retrospective or prospective or longitudinal or observational or follow-up or followup or registry).af. | Cohorts (KQ 4)
34 | case-control.af. or (case adj10 control).tw. | Cohorts (KQ 4)
35 | ep.fs. | Cohorts (KQ 4)
36 | 32 or 33 or 34 or 35 | Cohorts (KQ 4)
37 | 8 and (31 or 36) | Limits
38 | limit 37 to humans [Limit not valid in CDSR,CCTR; records were retained] | Limits
39 | limit 38 to yr=“1888 - 2000” | Limits
40 | remove duplicates from 39 | Limits
41 | limit 37 to yr=“2001-2008” | Limits
42 | remove duplicates from 41 | Limits
43 | limit 37 to yr=“2009-current” | Limits
44 | remove duplicates from 43 | Limits
45 | or/40, 42, 44 | Final
46 | (home adj20 blood pressure).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | Added Terms
47 | or/9-45 | Added Terms
48 | 46 and 47 | Added Terms
49 | (exp telemedicine/ or exp self-examination/) and (exp Blood pressure/ or exp Hypertension/) | Added Terms
50 | 47 and 49 | Added Terms
51 | 45 or 48 or 50 | Added Terms