# Appendixes

Appendix A Literature Search Strategy

Appendix B Excluded Studies

Appendix C Data Extraction Forms

Appendix D Additional Tables