# Acronyms and Abbreviations

AHA: American Heart Association
AHRQ: Agency for Healthcare Research and Quality
BP: blood pressure
CER: comparative effectiveness review
CI: confidence interval
DBP: diastolic blood pressure
EPC: Evidence-based Practice Center
Euro QoL 5D: Euro Quality of Life Group 5-Dimension Self Report Questionnaire
FDA: Food and Drug Administration
JNC-7: Seventh Joint National Committee (guideline on hypertension)
NHANES: National Health and Nutrition Examination Surveys
OR: odds ratio
PICOD: populations, interventions, comparators, outcomes, and study designs
RCT: randomized controlled trial
RR: relative risk
SBP: systolic blood pressure
SE: standard error
SF-36 (or 12): Short Form-36 (or 12) Health Survey
SMBP: self-measured blood pressure (monitoring)
TEP: Technical Expert Panel
TOO: Task Order Officer