# Technical Expert Panel

Lilly Hechtman, M.D., F.R.C.P.

Montreal Children’s Hospital

Montreal, Quebec, Canada

Margaret Weiss, M.D., Ph.D., F.R.C.P.(C)

University of British Columbia Children’s and Women’s Health

Vancouver, British Columbia, Canada

Stephen Faraone, M.D., Ph.D.

SUNY Upstate Medical University

Syracuse, NY

William E. Pelham, Jr., Ph.D.

State University of New York at Stony Brook

Buffalo, NY

L. Eugene Arnold, M.D., Med.

Ohio State University, Nisonger Center

Columbus OH

Laurence L. Greenhill, Ph.D., M.D.

Columbia University

New York, NY

Julie Zito, Ph.D.

University of Maryland

Baltimore, MD