# References

1 Still GF. Some abnormal psychical conditions in children: the Goulstonian lectures. Lancet. 1902;1:1008-12.
2 Mayes R, Rafalovich A. Suffer the restless children: the evolution of ADHD and paediatric stimulant use, 1900–80. Hist Psychiatry. 2007;18(72:Pt 4):435-57. [pmid: 18590022].
3 Eisenberg L. Commentary with a historical perspective by a child psychiatrist: when “ADHD” was the “brain-damaged child.”. J Child Adolesc Psychopharmacol. 2007;17(3):279-83. [pmid: 17630858].
4 Centers for Disease Control and Prevention (CDC). Mental health in the United States. Prevalence of diagnosis and medication treatment for attention-deficit/hyperactivity disorder--United States, 2003. MMWR Morb Mortal Wkly Rep. 2005;54(34):842-7. [pmid: 16138075].
5 Kessler RC, Adler L, Barkley R, et al. The prevalence and correlates of adult ADHD in the United States: results from the National Comorbidity Survey Replication. Am J Psychiatry. 2006;163(4):716-23. [pmid: 16585449].
6 Report of the International Narcotics Contol Board for 2009, Comments on the Reported Statistics on Psychotropic Substances. 2010:35-59. http://www.incb.org/pdf/technical-reports/psychotropics/2009/Publication_Parts_09_english/Part_Two_Tables_EFS_2009.pdf.
7 Greenhill L, Kollins S, Abikoff H, et al. Efficacy and safety of immediate-release methylphenidate treatment for preschoolers with ADHD. J Am Acad Child Adolesc Psychiatry. 2006;45(11):1284-93. [pmid: 17023867].
8 Fayyad J, de Graaf R, Kessler R, et al. Cross-national prevalence and correlates of adult attention-deficit hyperactivity disorder. Br J Psychiatry. 2007;190:402-9. [pmid: 17470954].
9 Simon V, Czobor P, Balint S, et al. Prevalence and correlates of adult attention-deficit hyperactivity disorder: meta-analysis. Br J Psychiatry. 2009;194(3):204-11. [pmid: 19252145].
10 Jadad AR, Boyle M, Cunningham C, et al. Treatment of Attention-Deficit/Hyperactivity Disorder, Evidence Report/Technology Assessment No.11. AHRQ Publication No. 00-E005. Rockville, MD. Agency for Healthcare Research and Quality. 11. 1999. [pmid: 10790990].
11 Cohen J. Statistical Power Analysis for the Behavioral Sciences. Hillsdale, NJ. Lawrence Erlbaum Associates. 1998.
12 Higgins J, Green S. Cochrane Handbook for Systematic Reviews of Interventions version 5.1.0. 03. 2011.
13 Armstrong R, Waters E, Doyle J. 21, Reviews in health promotion and public health, Cochrane Handbook for Systematic Reviews of Interventions. The Cochrane Collaboration. 2008.
14 Grade Working Group. Grading the Quality of Evidence and the Strength of Recommendations. www.gradeworkinggroup.org.
15 Owens DK, Lohr KN, Atkins D, et al. AHRQ Series Paper 5: Grading the strength of a body of evidence when comparing medical interventions - Agency for Healthcare Research and Quality and the Effective Health-care Program. J Clin Epidemiol. 2010;63:513-23. [pmid: 19595577].
16 Markie-Dadds C, Sanders MR. A controlled evaluation of an enhanced self-directed behavioural family intervention for parents of children with conduct problems in rural and remote areas. Behav Change. 2006;23(1):55-72.
17 Connell S, Sanders MR, Markie-Dadds C. Self-directed behavioral family intervention for parents of oppositional children in rural and remote areas. Behav Modif. 1997;21(4):379-408. [pmid: 9337598].
18 Markie-Dadds C, Sanders MR. Self-directed Triple P (Positive Parenting Program) for mothers with children at-risk of developing conduct problems. Behav Cogn Psychother. 2006;34(3):259-75.
19 Bor W, Sanders MR, Markie-Dadds C. The effects of the Triple P-Positive Parenting Program on preschool children with co-occurring disruptive behavior and attentional/hyperactive difficulties. J Abnorm Child Psychol. 2002;30(6):571-87. [pmid: 12481972].
20 Sanders MR, Christensen AP. A comparison of the effects of child management and planned activities training in five parenting environments. J Abnorm Child Psychol. 1985;13(1):101-17. [pmid: 3973246].
21 Sanders MR, Bor W, Morawska A. Maintenance of treatment gains: a comparison of enhanced, standard, and self-directed Triple P-Positive Parenting Program. J Abnorm Child Psychol. 2007;35(6):983-98. [pmid: 17610061].
22 Dadds MR, McHugh TA. Social support and treatment outcome in behavioral family therapy for child conduct problems. J Consult Clin Psychol. 1992;60(2):252-9. [pmid: 1592955].
23 Lavigne JV, Lebailly SA, Gouze KR, et al. Treating oppositional defiant disorder in primary care: a comparison of three models. J Pediatr Psychol. 2008;33(5):449-61. [pmid: 17956932].
24 Jones K, Daley D, Hutchings J, et al. Efficacy of the Incredible Years Basic Parent Training Programme as an early intervention for children with conduct problems and ADHD. Child Care Health Dev. 2007;33(6):749-56. [pmid: 17944785].
25 Hutchings J, Gardner F, Bywater T, et al. Parenting intervention in Sure Start services for children at risk of developing conduct disorder: pragmatic randomised controlled trial. BMJ. 2007;334(7595):678. [pmid: 17350966].
26 Bywater T, Hutchings J, Daley D, et al. Long-term effectiveness of a parenting intervention for children at risk of developing conduct disorder. Br J Psychiatry. 2009;195(4):318-24. [pmid: 19794200].
27 Williford AP, Shelton TL. Using mental health consultation to decrease disruptive behaviors in preschoolers: adapting an empirically-supported intervention. J Child Psychol Psychiatry. 2008;49(2):191-200. [pmid: 18211278].
28 Bagner DM, Eyberg SM. Parent-child interaction therapy for disruptive behavior in children with mental retardation: a randomized controlled trial. J Clin Child Adolesc Psychol. 2007;36(3):418-29. [pmid: 17658985].
29 Hood KK, Eyberg SM. Outcomes of parent-child interaction therapy: mothers’ reports of maintenance three to six years after treatment. J Clin Child Adolesc Psychol. 2003;32(3):419-29. [pmid: 12881030].
30 Matos M, Bauermeister JJ, Bernal G. Parent-child interaction therapy for Puerto Rican preschool children with ADHD and behavior problems: a pilot efficacy study. Fam Process. 2009;48(2):232-52. [pmid: 19579907].
31 Nixon RDV. Changes in hyperactivity and temperament in behaviourally disturbed preschoolers after parent-child interaction therapy (PCIT). Behav Change. 2001;18(3):168-76.
32 Nixon RD, Sweeney L, Erickson DB, et al. Parent-child interaction therapy: a comparison of standard and abbreviated treatments for oppositional defiant preschoolers. J Consult Clin Psychol. 2003;71(2):251-60. [pmid: 12699020].
33 Funderburk BW, Eyberg SM, Newcomb K, et al. Parent-child interaction therapy with behavior problem children: maintenance of treatment effects in the school setting. Child Fam Behav Ther. 1998;20(2):17-38.
34 Eyberg SM, Boggs SR, Algina J. Parent-child interaction therapy: a psychosocial model for the treatment of young children with conduct problem behavior and their families. Psychopharmacol Bull. 1995;31(1):83-91. [pmid: 7675994].
35 Schuhmann EM, Foote RC, Eyberg SM, et al. Efficacy of parent-child interaction therapy: interim report of a randomized trial with short-term maintenance. J Clin Child Psychol. 1998;27(1):34-45. [pmid: 9561935].
36 Sonuga-Barke EJ, Daley D, Thompson M, et al. Parent-based therapies for preschool attention-deficit/hyperactivity disorder: a randomized, controlled trial with a community sample. J Am Acad Child Adolesc Psychiatry. 2001;40(4):402-8. [pmid: 11314565].
37 Sonuga-Barke EJ, Thompson M, Daley D, et al. Parent training for Attention Deficit/Hyperactivity Disorder: is it as effective when delivered as routine rather than as specialist care?. Br J Clin Psychol. 2004;43(Pt:4):4-57.
38 Sonuga-Barke EJ, Daley D, Thompson M. Does maternal ADHD reduce the effectiveness of parent training for preschool children’s ADHD?. J Am Acad Child Adolesc Psychiatry. 2002;41(6):696-702. [pmid: 12049444].
39 Thompson MJJ, Laver-Bradbury C, Ayres M, et al. A small-scale randomized controlled trial of the revised New Forest Parenting Programme for preschoolers with attention deficit hyperactivity disorder. Eur Child Adolesc Psychiatry. 2009;18(10):605-16. [pmid: 19404717].
40 Hanisch C, Freund-Braier I, Hautmann C, et al. Detecting effects of the indicated prevention Programme for Externalizing Problem behaviour (PEP) on child symptoms, parenting, and parental quality of life in a randomized controlled trial. Behav Cogn Psychother. 2010;38(1):95-112. [pmid: 19995467].
41 Feusner JD, Moody T, Hembacher E, et al. Abnormalities of visual processing and frontostriatal systems in body dysmorphic disorder. Arch Gen Psychiatry. 2010;67(2):197-205. [pmid: 20124119].
42 Reid MJ, Webster-Stratton C, Hammond M. Follow-up of children who received the Incredible Years intervention for oppositional-defiant disorder: maintenance and prediction of 2-year outcome. Behav Ther. 2003;(4):471-91.
43 Heriot SA, Evans IM, Foster TM. Critical influences affecting response to various treatments in young children with ADHD: a case series. Child Care Health Dev. 2008;34(1):121-33. [pmid: 18171453].
44 Barkley RA. The effects of methylphenidate on the interactions of preschool ADHD children with their mothers. J Am Acad Child Adolesc Psychiatry. 1988;27(3):336-41. [pmid: 3379016].
45 Barkley RA, Karlsson J, Pollard S, et al. Developmental changes in the mother-child interactions of hyperactive boys: Effects of two dose levels of Ritalin. J Child Psychol Psychiatry. 1985;26(5):705-15. [pmid: 3900116].
46 Handen BL, Feldman HM, Lurier A, et al. Efficacy of methylphenidate among preschool children with developmental disabilities and ADHD. J Am Acad Child Adolesc Psychiatry. 1999;38(7):805-12. [pmid: 10405497].
47 Musten LM, Firestone P, Pisterman S, et al. Effects of methylphenidate on preschool children with ADHD: cognitive and behavioral functions. J Am Acad Child Adolesc Psychiatry. 1997;36(10):1407-15. [pmid: 9334554].
48 Ghuman JK, Aman MG, Lecavalier L, et al. Randomized, placebo-controlled, crossover study of methylphenidate for attention-deficit/hyperactivity disorder symptoms in preschoolers with developmental disorders. J Child Adolesc Psychopharmacol. 2009;19(4):329-39. [pmid: 19702485].
49 Short EJ, Manos MJ, Findling RL, et al. A prospective study of stimulant response in preschool children: insights from ROC analyses. J Am Acad Child Adolesc Psychiatry. 2004;43(3):251-9. [pmid: 15076257].
50 Schleifer M, Weiss G, Cohen N, et al. Hyperactivity in preschoolers and the effect of methylphenidate. Am J Orthopsychiatry. 1975;45(1):38-50. [pmid: 1089359].
51 Abikoff HB, Vitiello B, Riddle MA, et al. Methylphenidate effects on functional outcomes in the Preschoolers with Attention-Deficit/Hyperactivity Disorder Treatment Study (PATS). J Child Adolesc Psychopharmacol. 2007;17(5):581-92. [pmid: 17979579].
52 Ghuman JK, Riddle MA, Vitiello B, et al. Comorbidity moderates response to methylphenidate in the Preschoolers with Attention-Deficit/Hyperactivity Disorder Treatment Study (PATS). J Child Adolesc Psychopharmacol. 2007;17(5):563-80. [pmid: 17979578].
53 Swanson J, Greenhill L, Wigal T, et al. Stimulant-related reductions of growth rates in the PATS. J Am Acad Child Adolesc Psychiatry. 2006;45(11):1304-13. [pmid: 17023868].
54 Wigal T, Greenhill L, Chuang S, et al. Safety and tolerability of methylphenidate in preschool children with ADHD. J Am Acad Child Adolesc Psychiatry. 2006;45(11):1294-303. [pmid: 17028508].
55 Firestone P, Musten LM, Pisterman S, et al. Short-term side effects of stimulant medication are increased in preschool children with attention-deficit/hyperactivity disorder: a double-blind placebo-controlled study. J Child Adolesc Psychopharmacol. 1998;8(1):13-25. [pmid: 9639076].
56 Cohen NJ. Evaluation of the relative effectiveness of methylphenidate and cognitive behavior modification in the treatment of kindergarten-aged hyperactive children. J Abnorm Child Psychol. 1981;9(1):43-54. [pmid: 7217537].
57 Charach A, Ickowicz A, Schachar R. Stimulant treatment over five years: adherence, effectiveness, and adverse effects. J Am Acad Child Adolesc Psychiatry. 2004;43(5):559-67. [pmid: 15100562].
58 Law SF, Schachar RJ. Do typical clinical doses of methylphenidate cause tics in children treated for attention-deficit hyperactivity disorder?. J Am Acad Child Adolesc Psychiatry. 1999;38(8):944-51. [pmid: 10434485].
59 Barbaresi WJ, Katusic SK, Colligan RC, et al. Long-term stimulant medication treatment of attention-deficit/hyperactivity disorder: results from a population-based study. J Dev Behav Pediatr. 2006;27(1):1-10. [pmid: 16511362].
60 Hoare P, Remschmidt H, Medori R, et al. 12-month efficacy and safety of OROS MPH in children and adolescents with attention-deficit/hyperactivity disorder switched from MPH. Eur Child Adolesc Psychiatry. 2005;14(6):305-9. [pmid: 16220214].
61 Gillberg C, Melander H, von Knorring AL, et al. Long-term stimulant treatment of children with attention-deficit hyperactivity disorder symptoms. A randomized, double-blind, placebo-controlled trial. Arch Gen Psychiatry. 1997;54(9):857-64. [pmid: 9294377].
62 Gadow KD, Sverd J, Sprafkin J, et al. Long-term methylphenidate therapy in children with comorbid attention-deficit hyperactivity disorder and chronic multiple tic disorder. Arch Gen Psychiatry. 1999;56(4):330-6. [pmid: 10197827].
63 McGough JJ, Biederman J, Wigal SB, et al. Long-term tolerability and effectiveness of once-daily mixed amphetamine salts (Adderall XR) in children with ADHD. J Am Acad Child Adolesc Psychiatry. 2005;44(6):530-8. [pmid: 15908835].
64 Findling RL, Biederman J, Wilens TE, et al. Short- and long-term cardiovascular effects of mixed amphetamine salts extended release in children. J Pediatr. 2005;147(3):348-54. [pmid: 16182674].
65 Weisler RH, Biederman J, Spencer TJ, et al. Long-term cardiovascular effects of mixed amphetamine salts extended release in adults with ADHD. CNS Spectrums. 2005;10(12 Suppl 20):35-43. [pmid: 16344839].
66 Michelson D, Buitelaar JK, Danckaerts M, et al. Relapse prevention in pediatric patients with ADHD treated with atomoxetine: a randomized, double-blind, placebo-controlled study. J Am Acad Child Adolesc Psychiatry. 2004;43(7):896-904. [pmid: 15213591].
67 Buitelaar JK, Michelson D, Danckaerts M, et al. A randomized, double-blind study of continuation treatment for attention-deficit/hyperactivity disorder after 1 year. Biol Psychiatry. 2007;61(5):694-9. [pmid: 16893523].
68 Adler LA, Spencer TJ, Milton DR, et al. Long-term, open-label study of the safety and efficacy of atomoxetine in adults with attention-deficit/hyperactivity disorder: an interim analysis. J Clin Psychiatry. 2005;66(3):294-9. [pmid: 15766294].
69 Wernicke JF, Faries D, Girod D, et al. Cardiovascular effects of atomoxetine in children, adolescents, and adults. Drug Safety. 2003;26(10):729-40. [pmid: 12862507].
70 Biederman J, Melmed RD, Patel A, et al. Long-term, open-label extension study of guanfacine extended release in children and adolescents with ADHD. CNS Spectrums. 2008;13(12):1047-55. [pmid: 19179940].
71 Sallee FR, Lyne A, Wigal T, et al. Long-term safety and efficacy of guanfacine extended release in children and adolescents with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(3):215-26. [pmid: 19519256].
72 Conners CK, Epstein JN, March JS, et al. Multimodal treatment of ADHD in the MTA: an alternative outcome analysis. J Am Acad Child Adolesc Psychiatry. 2001;40(2):159-67. [pmid: 11211364].
73 MTA Cooperative Group. National Institute of Mental Health Multimodal Treatment Study of ADHD follow-up: 24-month outcomes of treatment strategies for attention-deficit/hyperactivity disorder. Pediatrics. 2004;113(4):754-61. [pmid: 15060224].
74 MTA Cooperative Group. A 14-month randomized clinical trial of treatment strategies for attention-deficit/hyperactivity disorder. The MTA Cooperative Group. Multimodal Treatment Study of Children with ADHD. Arch Gen Psychiatry. 1999;56(12):1073-86. [pmid: 10591283].
75 Abikoff H, Hechtman L, Klein RG, et al. Symptomatic improvement in children with ADHD treated with long-term methylphenidate and multimodal psychosocial treatment. J Am Acad Child Adolesc Psychiatry. 2004;43(7):802-11. [pmid: 15213581].
76 Abikoff H, Hechtman L, Klein RG, et al. Social functioning in children with ADHD treated with long-term methylphenidate and multimodal psychosocial treatment. J Am Acad Child Adolesc Psychiatry. 2004;43(7):820-9. [pmid: 15213583].
77 So CY, Leung PW, Hung SF. Treatment effectiveness of combined medication/behavioural treatment with Chinese ADHD children in routine practice. Behav Res Ther. 2008;46(9):983-92. [pmid: 18692170].
78 Swanson JM, Elliott GR, Greenhill LL, et al. Effects of stimulant medication on growth rates across 3 years in the MTA follow-up. J Am Acad Child Adolesc Psychiatry. 2007;46(8):1015-27. [pmid: 17667480].
79 Newcorn JH, Kratochvil CJ, Allen AJ, et al. Atomoxetine and osmotically released methylphenidate for the treatment of attention deficit hyperactivity disorder: acute comparison and differential response. Am J Psychiatry. 2008;165(6):721-30. [pmid: 18281409].
80 Jensen PS, Hinshaw SP, Kraemer HC, et al. ADHD comorbidity findings from the MTA study: comparing comorbid subgroups. J Am Acad Child Adolesc Psychiatry. 2001;40(2):147-58. [pmid: 11211363].
81 Jensen PS, Arnold LE, Swanson JM, et al. 3-year follow-up of the NIMH MTA study. J Am Acad Child Adolesc Psychiatry. 2007;46(8):989-1002. [pmid: 17667478].
82 Molina BS, Hinshaw SP, Swanson JM, et al. The MTA at 8 years: prospective follow-up of children treated for combined-type ADHD in a multisite study. J Am Acad Child Adolesc Psychiatry. 2009;48(5):484-500. [pmid: 19318991].
83 Molina BS, Flory K, Hinshaw SP, et al. Delinquent behavior and emerging substance use in the MTA at 36 months: prevalence, course, and treatment effects. J Am Acad Child Adolesc Psychiatry. 2007;46(8):1028-40. [pmid: 17667481].
84 Swanson JM, Hinshaw SP, Arnold LE, et al. Secondary evaluations of MTA 36-month outcomes: propensity score and growth mixture model analyses. J Am Acad Child Adolesc Psychiatry. 2007;46(8):1003-14. [pmid: 17667479].
85 Barbaresi WJ, Katusic SK, Colligan RC, et al. Modifiers of long-term school outcomes for children with attention-deficit/hyperactivity disorder: does treatment with stimulant medication make a difference? Results from a population-based study. J Dev Behav Pediatr. 2007;28(4):274-87. [pmid: 17700079].
86 Biederman J, Monuteaux MC, Spencer T, et al. Do stimulants protect against psychiatric disorders in youth with ADHD? A 10-year follow-up study. Pediatrics. 2009;124(1):71-8. [pmid: 19564285].
87 Katusic SK, Barbaresi WJ, Colligan RC, et al. Psychostimulant treatment and risk for substance abuse among young adults with a history of attention-deficit/hyperactivity disorder: a population-based, birth cohort study. J Child Adolesc Psychopharmacol. 2005;15(5):764-76. [pmid: 16262593].
88 Mannuzza S, Klein RG, Truong NL, et al. Age of methylphenidate treatment initiation in children with ADHD and later substance abuse: prospective follow-up into adulthood. Am J Psychiatry. 2008;165(5):604-9. [pmid: 18381904].
89 Hechtman L, Abikoff H, Klein RG, et al. Academic achievement and emotional status of children with ADHD treated with long-term methylphenidate and multimodal psychosocial treatment. J Am Acad Child Adolesc Psychiatry. 2004;43(7):812-9. [pmid: 15213582].
90 Langberg JM, Arnold LE, Flowers AM, et al. Parent-reported homework problems in the MTA study: evidence for sustained improvement with behavioral treatment. J Clin Child Adolesc Psychol. 2010;39(2):220-33. [pmid: 20390813].
91 Jitendra AK, DuPaul GJ, Volpe RJ, et al. Consultation-based academic intervention for children with attention deficit hyperactivity disorder: school functioning outcomes. School Psych Rev. 2007;36(2):217-36.
92 Volpe RJ, DuPaul GJ, Jitendra AK, et al. Consultation-based academic interventions for children with attention deficit hyperactivity disorder: effects on reading and mathematics outcomes at 1-year follow-up. School Psych Rev. 2009;38(1):5-13.
93 Polanczyk G, de Lima MS, Horta BL, et al. The worldwide prevalence of ADHD: a systematic review and metaregression analysis. Am J Psychiatry. 2007;164(6):942-8. [pmid: 17541055].
94 Safer DJ, Zito JM, Fine EM. Increased methylphenidate usage for attention deficit disorder in the 1990s. Pediatrics. 1996;98(6):1084-8. [pmid: 8951257].
95 Robison LM, Sclar DA, Skaer TL, et al. National trends in the prevalence of attention-deficit/hyperactivity disorder and the prescribing of methylphenidate among school-age children: 1990–1995. Clin Pediatr (Phila). 1999;38(4):209-17. [pmid: 10326176].
96 Zuvekas SH, Vitiello B, Norquist GS. Recent trends in stimulant medication use among U.S. children. Am J Psychiatry. 2006;163(4):579-85. [pmid: 16585430].
97 Zito JM, Safer DJ, Valluri S, et al. Psychotherapeutic medication prevalence in Medicaid-insured preschoolers. J Child Adolesc Psychopharmacol. 2007;17(2):195-203. [pmid: 17489714].
98 Scheffler RM, Hinshaw SP, Modrek S, et al. The global market for ADHD medications. Health Aff (Millwood). 2007;26(2):450-7. [pmid: 17339673].
99 Bokhari F, Mayes R, Scheffler RM. An analysis of the significant variation in psychostimulant use across the U.S. Pharmacoepidemiol Drug Saf. 2005;14(4):267-75. [pmid: 15386704].
100 Bloom B, Cohen RA, Freeman G. Summary health statistics for U.S. children: National Health Interview Survey, 2007. Vital Health Stat. 2009;(239):1-80.
101 Miller TW, Nigg JT, Miller RL. Attention deficit hyperactivity disorder in African American children: what can be concluded from the past ten years?. Clin Psychol Rev. 2009;29(1):77-86. [pmid: 19008029].
102 Leslie LK, Wolraich ML. ADHD service use patterns in youth. J Pediatr Psychol. 2007;32(6):695-710. [pmid: 17556401].
103 Zito JM, Safer DJ, de Jongvan den Berg L, et al. A three-country comparison of psychotropic medication prevalence in youth. Child Adolesc Psychiatry Ment Health. 2008;2(1):26. [pmid: 18817536].
104 Froehlich TE, Lanphear BP, Epstein JN, et al. Prevalence, recognition, and treatment of attention-deficit/hyperactivity disorder in a national sample of US children. Arch Pediatr Adolesc Med. 2007;161(9):857-64. [pmid: 17768285].
105 Perwien A, Hall J, Swensen A, et al. Stimulant treatment patterns and compliance in children and adults with newly treated attention-deficit/hyperactivity disorder. J Manag Care Pharm. 2004;10(2):122-9. [pmid: 15032561].
106 Marcus SC, Wan GJ, Kemner JE, et al. Continuity of methylphenidate treatment for attention-deficit/hyperactivity disorder. Arch Pediatr Adolesc Med. 2005;159(6):572-8. [pmid: 15939858].
107 Eyestone LL, Howell RJ. An epidemiological study of attention-deficit hyperactivity disorder and major depression in a male prison population. J Am Acad Psychiatry Law. 1994;22(2):181-93.
108 Williams J, Taylor E. The evolution of hyperactivity, impulsivity and cognitive diversity. J R Soc Interface. 2006;3(8):399-413. [pmid: 16849269].
109 Lahey BB, Pelham WE, Chronis A, et al. Predictive validity of ICD-10 hyperkinetic disorder relative to DSM-IV attention-deficit/hyperactivity disorder among younger children. Journal of Child Psychology & Psychiatry & Allied Disciplines. 2006;47(5):472-9.
110 Dopfner M, Breuer D, Wille N, et al. How often do children meet ICD-10/DSM-IV criteria of attention deficit-/hyperactivity disorder and hyperkinetic disorder? Parent-based prevalence rates in a national sample--results of the BELLA study. Eur Child Adolesc Psychiatry. 2008;17(Suppl 1):59-70. [pmid: 19132305].
111 DeSantis AD, Webb EM, Noar SM. Illicit use of prescription ADHD medications on a college campus: a multimethodological approach. J Am Coll Health. 2008;57(3):315-24. [pmid: 18980888].
112 Rabiner DL, Anastopoulos AD, Costello EJ, et al. The misuse and diversion of prescribed ADHD medications by college students. J Atten Disord. 2009;13(2):144-53. [pmid: 19448150].
113 Angold A, Erkanli A, Egger HL, et al. Stimulant treatment for children: a community perspective. J Am Acad Child Adolesc Psychiatry. 1984;39(8):975-84. [pmid: 10939226].
114 Costello EJ, Mustillo S, Erkanli A, et al. Prevalence and development of psychiatric disorders in childhood and adolescence. Arch Gen Psychiatry. 2003;60(8):837-44. [pmid: 12912767].
115 Goldman LS, Genel M, Bezman RJ, et al. Diagnosis and treatment of attention-deficit/hyperactivity disorder in children and adolescents. JAMA. 1998;279(14):1100-7. [pmid: 9546570].
116 Schachar R, Chen S, Crosbie J, et al. Comparison of the predictive validity of hyperkinetic disorder and attention deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2007;16(2):90-100.
117 Child Medication Safety Act of 2005 Bill (H.R.1790). Congressional Record - House. 2005;151(19):26003.
118 Pliszka S. AACAP Work Group on Quality Issues. Practice parameter for the assessment and treatment of children and adolescents with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2007;46(7):894-921. [pmid: 17581453].
119 Greenhill LL, Posner K, Vaughan BS, et al. Attention deficit hyperactivity disorder in preschool children. Child Adolesc Psychiatr Clin N Am. 2008;17(2):347-66. [pmid: 18295150].
120 Chavez B, Sopko MA Jr, Ehret MJ, et al. An update on central nervous system stimulant formulations in children and adolescents with attention-deficit/hyperactivity disorder. Ann Pharmacother. 2009;43(6):1084-95. [pmid: 19470858].
121 Ipser J, Stein DJ. Systematic review of pharmacotherapy of disruptive behavior disorders in children and adolescents. Psychopharmacology (Berl). 2007;191(1):127-40. [pmid: 16983542].
122 Kern L, Dupaul GJ, Volpe RJ, et al. Multisetting assessment-based intervention for young children at risk for attention deficit hyperactivity disorder: initial effects on academic and behavioral functioning. School Psych Rev. 2007;36(2):237-55.
123 FDA/Center for Drug Evaluation and Research. ADDERALL. 2011;2011.
124 Ghuman JK, Arnold LE, Anthony BJ. Psychopharmacological and other treatments in preschool children with attention-deficit/hyperactivity disorder: Current evidence and practice. J Child Adolesc Psychopharmacol. 2008;18(5):413-47. [pmid: 18844482].
125 Kollins S, Greenhill L, Swanson J, et al. Rationale, design, and methods of the Preschool ADHD Treatment Study (PATS). J Am Acad Child Adolesc Psychiatry. 2006;45(11):1275-83. [pmid: 17023869].
126 Cunningham CE, Boyle MH. Preschoolers at risk for attention-deficit hyperactivity disorder and oppositional defiant disorder: family, parenting, and behavioral correlates. J Abnorm Child Psychol. 2002;30(6):555-69. [pmid: 12481971].
127 Miller AR, Lalonde CE, McGrail KM, et al. Prescription of methylphenidate to children and youth, 1990–1996. CMAJ. 2001;165(11):1489-94. [pmid: 11762572].
128 Brownell MD, Yogendran MS. Attention-deficit hyperactivity disorder in Manitoba children: medical diagnosis and psychostimulant treatment rates. Can J Psychiatry. 2001;46(3):264-72. [pmid: 11320681].
129 Rappley MD, Gardiner JC, Jetton JR, et al. The use of methylphenidate in Michigan. Arch Pediatr Adolesc Med. 1995;149(6):675-9. [pmid: 7767425].
130 Achenbach TM, Dumenci L, Rescorla LA. Are American children’s problems still getting worse? A 23-year comparison. J Abnorm Child Psychol. 2003;31(1):1-11. [pmid: 12597695].
131 Charach A, Cao H, Schachar R, et al. Correlates of methylphenidate use in Canadian children: a cross-sectional study. Can J Psychiatry. 2006;51(1):17-26. [pmid: 16491980].
132 Cummings JG, Wittenberg J-V. Supportive expressive therapy - parent child version: An exploratory study. Psychother. 2008;45(2):148-64.
133 Cunningham CE, Bremner R, Boyle M. Large group community-based parenting programs for families of preschoolers at risk for disruptive behaviour disorders: utilization, cost effectiveness, and outcome. J Child Psychol Psychiatry. 1995;36(7):1141-59. [pmid: 8847377].
134 Landy S, Menna R. An evaluation of a group intervention for parents with aggressive young children: Improvements in child functioning, maternal confidence, parenting knowledge and attitudes. Early Child Dev Care. 2006;176(6):605-20.
135 Pisterman S, McGrath P, Firestone P, et al. Outcome of parent-mediated treatment of preschoolers with attention deficit disorder with hyperactivity. J Consult Clin Psychol. 1989;57(5):628-35. [pmid: 2794183].
136 Pisterman S, Firestone P, McGrath P, et al. The effects of parent training on parenting stress and sense of competence. Can J Behav Sci. 1992;24(1):41-58.
137 Pisterman S, Firestone P, McGrath P, et al. The role of parent training in treatment of preschoolers with ADDH. Am J Orthopsychiatry. 1992;62(3):397-408. [pmid: 1497105].
138 Weeks A, Laver-Bradbury C. Behaviour modification in hyperactive children. Nurs Times. 1997;93(47):56-8. [pmid: 9418516].
139 Jones K, Daley D, Hutchings J, et al. Efficacy of the Incredible Years Programme as an early intervention for children with conduct problems and ADHD: long-term follow-up. Child Care Health Dev. 2008;34(3):380-90. [pmid: 18410644].
140 Nixon RD, Sweeney L, Erickson DB, et al. Parent-child interaction therapy: one- and two-year follow-up of standard and abbreviated treatments for oppositional preschoolers. J Abnorm Child Psychol. 2004;32(3):263-71. [pmid: 15228175].
141 Shelton TL, Barkley RA, Crosswait C, et al. Multimethod psychoeducational intervention for preschool children with disruptive behavior: two-year post-treatment follow-up. J Abnorm Child Psychol. 2000;28(3):253-66. [pmid: 10885683].
142 Barkley RA, Shelton TL, Crosswait C, et al. Multi-method psycho-educational intervention for preschool children with disruptive behavior: preliminary results at post-treatment. J Child Psychol Psychiatry. 2000;41(3):319-32. [pmid: 10784079].
143 McGoey KE, DuPaul GJ, Eckert TL, et al. Outcomes of a Multi-Component Intervention for Preschool Children At-Risk for Attention-Deficit/Hyperactivity Disorder Child. Fam Behav Ther. 2005;27(1):33-56.
144 Smith BH, Pelham WE, Gnagy E, et al. Equivalent effects of stimulant treatment for attention-deficit hyperactivity disorder during childhood and adolescence. J Am Acad Child Adolesc Psychiatry. 1998;37(3):314-21. [pmid: 9519637].
145 Andriola MR. Efficacy and safety of methylphenidate and pemoline in children with attention deficit hyperactivity disorder. Curr Ther Res Clin. 2000;61(4):208-15.
146 Nolan EE, Gadow KD, Sprafkin J. Stimulant medication withdrawal during long-term therapy in children with comorbid attention-deficit hyperactivity disorder and chronic multiple tic disorder. Pediatrics. 1999;103(4:Pt 1):730-7. [pmid: 10103294].
147 Lexchin J, Bero LA, Djulbegovic B, et al. Pharmaceutical industry sponsorship and research outcome and quality: systematic review. BMJ. 2003;326(7400):1167. [pmid: 12775614].
148 Winterstein AG, Gerhard T, Shuster J, et al. Cardiac safety of central nervous system stimulants in children and adolescents with attention-deficit/hyperactivity disorder. Pediatrics. 2007;120(6):e1494-e1501. [pmid: 18055666].
149 Winterstein AG, Gerhard T, Shuster J, et al. Cardiac safety of methylphenidate versus amphetamine salts in the treatment of ADHD. Pediatrics. 2009;124(1):e75-e80. [pmid: 19564272].
150 Holick CN, Turnbull BR, Jones ME, et al. Atomoxetine and cerebrovascular outcomes in adults. Journal of Clinical Psychopharmacology. 2009;29(5):453-60. [pmid: 19745645].
151 Leibson CL, Barbaresi WJ, Ransom J, et al. Emergency department use and costs for youth with attention-deficit/hyperactivity disorder: associations with stimulant treatment. Ambulatory Pediatrics. 2006;6(1):45-53. [pmid: 16443183].
152 Charach A, Figueroa M, Chen S, et al. Stimulant treatment over 5 years: Effects on growth. J Am Acad Child Adolesc Psychiatry. 2006;45(4):415-21. [pmid: 16601646].
153 Faraone SV, Giefer EE. Long-term effects of methylphenidate transdermal delivery system treatment of ADHD on growth. J Am Acad Child Adolesc Psychiatry. 2007;46(9):1138-47. [pmid: 17712237].
154 Poulton A, Cowell CT. Slowing of growth in height and weight on stimulants: a characteristic pattern. J Paediatr Child Health. 2003;39(3):180-5. [pmid: 12654140].
155 Sund AM, Zeiner P. Does extended medication with amphetamine or methylphenidate reduce growth in hyperactive children?. Nord J Psychiatry. 2002;56(1):53-7. [pmid: 11869467].
156 Zachor DA, Roberts AW, Hodgens JB, et al. Effects of long-term psychostimulant medication on growth of children with ADHD. Res Dev Disabil. 2006;27(2):162-74. [pmid: 15955659].
157 Pliszka SR, Matthews TL, Braslow KJ, et al. Comparative effects of methylphenidate and mixed salts amphetamine on height and weight in children with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2006;45(5):520-6. [pmid: 16670648].
158 Kramer JR, Loney J, Ponto LB, et al. Predictors of adult height and weight in boys treated with methylphenidate for childhood behavior problems. J Am Acad Child Adolesc Psychiatry. 2000;39(4):517-24. [pmid: 10761355].
159 Spencer TJ, Kratochvil CJ, Sangal RB, et al. Effects of atomoxetine on growth in children with attention-deficit/hyperactivity disorder following up to five years of treatment. J Child Adolesc Psychopharmacol. 2007;17(5):689-700. [pmid: 17979588].
160 MTA Cooperative Group. National Institute of Mental Health Multimodal Treatment Study of ADHD follow-up: changes in effectiveness and growth after the end of treatment. Pediatrics. 2004;113(4):762-9. [pmid: 15060225].
161 Wells KC, Epstein JN, Hinshaw SP, et al. Parenting and family stress treatment outcomes in attention deficit hyperactivity disorder (ADHD): an empirical analysis in the MTA study. J Abnorm Child Psychol. 2000;28(6):543-53. [pmid: 11104316].
162 Wells KC, Chi TC, Hinshaw SP, et al. Treatment-related changes in objectively measured parenting behaviors in the multimodal treatment study of children with attention-deficit/hyperactivity disorder. J Consult Clin Psychol. 2006;74(4):649-57. [pmid: 16881772].
163 Hinshaw SP, Owens EB, Wells KC, et al. Family processes and treatment outcome in the MTA: negative/ineffective parenting practices in relation to multimodal treatment. J Abnorm Child Psychol. 2000;28(6):555-68. [pmid: 11104317].
164 Jensen PS, Hinshaw SP, Swanson JM, et al. Findings from the NIMH Multimodal Treatment Study of ADHD (MTA): implications and applications for primary care providers. J Dev Behav Pediatr. 2001;22(1):60-73. [pmid: 11265923].
165 Swanson JM, Kraemer HC, Hinshaw SP, et al. Clinical relevance of the primary findings of the MTA: success rates based on severity of ADHD and ODD symptoms at the end of treatment. J Am Acad Child Adolesc Psychiatry. 2001;40(2):168-79. [pmid: 11211365].
166 Vitiello B, Severe JB, Greenhill LL, et al. Methylphenidate dosage for children with ADHD over time under controlled conditions: lessons from the MTA. J Am Acad Child Adolesc Psychiatry. 2001;40(2):188-96. [pmid: 11211367].
167 Arnold LE, Elliot M, Sachs L, et al. Effects of ethnicity on treatment attendance, stimulant response/dose, and 14-month outcome in ADHD. Journal of Consulting & Clinical Psychology. 2003;71(4):713-27. [pmid: 12924677].
168 Hechtman L, Etcovitch J, Platt R, et al. Does multimodal treatment of ADHD decrease other diagnoses?. Clinical Neuroscience Research. 2005;5(5–6):273-82.
169 Hoza B, Gerdes AC, Mrug S, et al. Peer-assessed outcomes in the multimodal treatment study of children with attention deficit hyperactivity disorder. J Clin Child Adolesc Psychol. 2005;34(1):74-86. [pmid: 15677282].
170 Hechtman L, Abikoff H, Klein RG, et al. Children with ADHD treated with long-term methylphenidate and multimodal psychosocial treatment: impact on parental practices. J Am Acad Child Adolesc Psychiatry. 2004;43(7):830-8. [pmid: 15213584].
171 Klein RG, Abikoff H, Hechtman L, et al. Design and rationale of controlled study of long-term methylphenidate and multimodal psychosocial treatment in children with ADHD. J Am Acad Child Adolesc Psychiatry. 2004;43(7):792-801. [pmid: 15213580].
172 Monastra VJ, Monastra DM, George S. The effects of stimulant therapy, EEG biofeedback, and parenting style on the primary symptoms of attention-deficit/hyperactivity disorder. Appl Psychophysiol Biofeedback. 2002;27(4):231-49. [pmid: 12557451].
173 Treacy L, Tripp G, Baird A. Parent stress management training for attention-deficit/hyperactivity disorder. Behav Ther. 2005;36(3):223-33.
174 Powers RL, Marks DJ, Miller CJ, et al. Stimulant treatment in children with attention-deficit/hyperactivity disorder moderates adolescent academic outcome. J Child Adolesc Psychopharmacol. 2008;18(5):449-59. [pmid: 18928410].
175 Evans SW, Serpell ZN, Schultz BK, et al. Cumulative benefits of secondary school-based treatment of students with attention deficit hyperactivity disorder. School Psych Rev. 2007;36(2):256-73.
176 Monuteaux MC, Spencer TJ, Faraone SV, et al. A randomized, placebo-controlled clinical trial of bupropion for the prevention of smoking in children and adolescents with attention-deficit/hyperactivity disorder. J Clin Psychiatry. 2007;68(7):1094-101. [pmid: 17685748].
177 Lambert N. The contribution of childhood ADHD, conduct problems, and stimulant treatment to adolescent and adult tobacco and psychoactive substance abuse. Ethical Hum Psychol Psychiatry. 2005;7(3):197-221.
178 Satterfield JH, Faller KJ, Crinella FM, et al. A 30-year prospective follow-up study of hyperactive boys with conduct problems: adult criminality. J Am Acad Child Adolesc Psychiatry. 2007;46(5):601-10. [pmid: 17450051].
179 Biederman J, Monuteaux MC, Spencer T, et al. Stimulant therapy and risk for subsequent substance use disorders in male adults with ADHD: a naturalistic controlled 10-year follow-up study. Am J Psychiatry. 2008;165(5):597-603. [pmid: 18316421].
180 Huss M, Poustka F, Lehmkuhl G, et al. No increase in long-term risk for nicotine use disorders after treatment with methylphenidate in children with attention-deficit/hyperactivity disorder (ADHD): evidence from a non-randomised retrospective study. J Neural Transm. 2008;115(2):335-9. [pmid: 18253808].
181 Wilens TE, Adamson J, Monuteaux MC, et al. Effect of prior stimulant treatment for attention-deficit/hyperactivity disorder on subsequent risk for cigarette smoking and alcohol and drug use disorders in adolescents. Arch Pediatr Adolesc Med. 2008;162(10):916-21. [pmid: 18838643].
182 Biederman J, Wilens T, Mick E, et al. Pharmacotherapy of attention-deficit/hyperactivity disorder reduces risk for substance use disorder. Pediatrics. 1999;104(2):e20. [pmid: 10429138].
183 Goksoyr PK, Nottestad JA. The burden of untreated ADHD among adults: the role of stimulant medication. Addict Behav. 2008;33(2):342-6. [pmid: 17920777].
184 Daviss WB, Birmaher B, Diler RS, et al. Does pharmacotherapy for attention-deficit/hyperactivity disorder predict risk of later major depression?. J Child Adolesc Psychopharmacol. 2008;18(3):257-64. [pmid: 18582180].
185 Biederman J, Monuteaux MC, Mick E, et al. Psychopathology in females with attention-deficit/hyperactivity disorder: a controlled, five-year prospective study. Biol Psychiatry. 2006;60(10):1098-105. [pmid: 16712802].
186 Parens E, Johnston J. Facts, values, and attention-deficit hyperactivity disorder (ADHD): An update on the controversies. Child Adolesc Psychiatry Ment Health. 2009;3(1):1. [pmid: 19152690].
187 Barkley RA. Issues in the diagnosis of attention-deficit/hyperactivity disorder in children. Brain Dev-Jpn. 2003;25(2):77-83.
188 Wolraich ML, Hannah JN, Pinnock TY, et al. Comparison of diagnostic criteria for attention-deficit hyperactivity disorder in a county-wide sample. J Am Acad Child Adolesc Psychiatry. 1996;35(3):319-24. [pmid: 8714320].
189 Hill P. Attention deficit hyperactivity disorder. Arch Dis Child. 1998;79(5):381-4. [pmid: 10193247].
190 Kessler RC, Adler LA, Barkley R, et al. Patterns and predictors of attention-deficit/hyperactivity disorder persistence into adulthood: results from the national comorbidity survey replication. Biol Psychiatry. 2005;57(11):1442-51. [pmid: 15950019].
191 Lara C, Fayyad J, de Graaf R, et al. Childhood predictors of adult attention-deficit/hyperactivity disorder: results from the World Health Organization World Mental Health Survey Initiative. Biol Psychiatry. 2009;65(1):46-54. [pmid: 19006789].
192 Pieroth EM. Diagnosing attention-deficit/hyperactivity disorder in adults. Prof Case Manag. 2008;13(3):179-81. [pmid: 18562915].
193 McGough JJ, Barkley RA. Diagnostic controversies in adult attention deficit hyperactivity disorder. Am J Psychiatry. 2004;161(11):1948-56. [pmid: 15514392].
194 Schlander M, Schwarz O, Trott GE, et al. Who cares for patients with attention-deficit/hyperactivity disorder (ADHD)? Insights from Nordbaden (Germany) on administrative prevalence and physician involvement in health care provision. Eur Child Adolesc Psychiatry. 2007;16(7):430-8. [pmid: 17468967].
195 Santosh PJ, Taylor E, Swanson J, et al. Refining the diagnoses of inattention and overactivity syndromes: A reanalysis of the Multimodal Treatment study of attention deficit hyperactivity disorder (ADHD) based on ICD-10 criteria for hyperkinetic disorder. Clinical Neuroscience Research. 2005;(5–6):307-14.
196 Ustun TB. Using the International Classification of Functioning, Disease and Health in Attention-Deficit/Hyperactivity Disorder: Separating the Disease From Its Epiphenomena. Ambulatory Pediatrics. 2007;(1 Suppl):132-9. [pmid: 17261492].
197 Foreman DM, Ford T. Assessing the diagnostic accuracy of the identification of hyperkinetic disorders following the introduction of government guidelines in England. Child Adolesc Psychiatry Ment Health. 2008.
198 Dopfner M, Steinhausen HC, Coghill D, et al. Cross-cultural reliability and validity of ADHD assessed by the ADHD Rating Scale in a pan-European study. Eur Child Adolesc Psychiatry. 2006;15:Suppl-55.
199 Boyle MH, Offord DR, Racine Y, et al. Identifying thresholds for clasifying childhood psychiatric disorder: Issues and prospects. J Am Acad Child Adolesc Psychiatry. 1996;35(11):1440-8. [pmid: 8936910].
200 Harkness S, Super C, Sutherland MA, et al. Culture and the Construction of Habits in Daily Life: Implications for the Successful Development of Children with Disabilities. OTJR. 2007;27(Fall, Suppl):33S-40S. 2007.
201 Gidwani PP, Opitz GM, Perrin JM. Mothers’ views on hyperactivity: A cross-cultural perspective. J Dev Behav Pediatr. 2006;27(2):121-6. [pmid: 16682875].
202 Stevens J, Harman JS, Kelleher KJ. Ethnic and regional differences in primary care visits for attention-deficit hyperactivity disorder. J Dev Behav Pediatr. 2004;25(5):318-25. [pmid: 15502548].
203 Mattox R, Harder J. Attention deficit hyperactivity disorder (ADHD) and diverse populations. Child & Adolescent Social Work Journal. 2007;24(2):195-207.
204 Breton J-J, Bergeron L, Valla J-P, et al. Quebec child mental health survey: Prevalence of DSM-III-R mental health disorders. J Child Psychol Psychiatry. 1999;40(3):375-84. [pmid: 10190339].
205 Sciutto MJ, Eisenberg M. Evaluating the evidence for and against the overdiagnosis of ADHD. J Atten Disord. 2007;11(2):106-13. [pmid: 17709814].
206 Elder TE. The importance of relative standards in ADHD diagnoses: Evidence based on exact birth dates. J Health Econ. 2010. [doi: 10.1016/j.jhealeco.2010.06.003.2010].
207 Evans WN, Morrill MS, Parente ST. Measuring Inappropriate Medical Diagnosis and Treatment in Survey Data:The Case of ADHD among School-Age Children. J Health Econ. 2010. [doi: 10.106/jhealeco.2010.07.005.2010].
208 Costello EJ, Keeler G, Angold A. Poverty, Race/Ethnicity, and Psychiatric Disorder. A Study of Rural Children. Am J Public Health. 2001;91(9):1494-8. [pmid: 11527787].
209 Costello EJ, Erkanli A, Fairbank JA, et al. The Prevalence of Potentially Traumatic Events in Childhood and Adolescence. J Trauma Stress. 2010;15(2):99-112. [pmid: 12013070].
210 Stevens J, Harman JS, Kelleher KJ. Race/ethnicity and insurance status as factors associated with ADHD treatment patterns. J Child Adolesc Psychopharmacol. 2005;15(1):88-96. [pmid: 15741790].
211 Visser SN, Lesesne CA, Perou R. National estimates and factors associated with medication treatment for childhood attention-deficit/hyperactivity disorder. Pediatrics. 2007;119:Suppl–106.
212 Lykens KA, Fulda KA, Bae SE, et al. Differences in risk factors for children with special health care needs (CSHCN) receiving needed specialty care by socioeconomic status. BMC Pediatr. 03. 9. 2010;(48). [doi: 10.1186/1471-2431-9-48]. 2010. 03.
213 Cox ER, Motheral BR, Henderson RR, et al. Geographic variation in the prevalence of stimulant medication use among children 5 to 14 years old: results from a commercially insured US sample. Pediatrics. 2003;111(2):237-43. [pmid: 12563045].
214 Huang YS, Guilleminault C, Li HY, et al. Attention-deficit/hyperactivity disorder with obstructive sleep apnea: a treatment outcome study. Sleep Medicine. 2007;8(1):18-30. [pmid: 17157069].
215 Whitaker RC, Phillips SM, Orzol SM. Food insecurity and the risks of depression and anxiety in mothers and behavior problems in their preschool-aged children. Pediatrics. 2006;118(3):e859-e868. [pmid: 16950971].
216 Singh I. A Framework for Understanding Trends in ADHD Diagnoses and Stimulant Drug Treatment: Schools and Schooling as a Case Study. BioSocieties. 2006;1:439-52.
217 Rafalovich A. Relational Troubles and Semiofficial Suspicion: Educators and the Medicalization of “Unruly” Children. Symbolic Interaction. 2005;28(1):25-46.
218 Johnson CF, Prinz R. Hyperactivity is in the eyes of the beholder. An evaluation of how teachers view the hyperactive child. Clin Pediatr (Phila). 1976;15(3):222-8. [pmid: 1253507].
219 Schneider H, Eisenberg D. Who receives a diagnosis of attention-deficit/ hyperactivity disorder in the United States elementary school population?. Pediatrics. 2006;117(4):e601-e609. [pmid: 16585277].
220 Sax L, Kautz KJ. Who first suggests the diagnosis of attention-deficit/hyperactivity disorder?. Ann Fam Med. 2003;1(3):171-4. [pmid: 15043379].
221 Hartung CM, Lefler EK, Tempel AB, et al. Halo effects in ratings of ADHD and ODD: Identification of susceptible symptoms. J Psychopathol Behav Assess. 2010;32(1):128-37.
222 Dong HL, Oakland T, Jackson G, et al. Estimated prevalence of attention-deficit/ hyperactivity disorder symptoms among college freshmen: gender, race, and rater effects. J Learn Disabil. 2008;41(4):371-84. [pmid: 18560023].
223 Costello EJ, Loeber R, Stouthamer-Loeber M. Pervasive and situational hyperactivity--confounding effect of informant: A research note. J Child Psychol Psychiatry. 1991;32(2):367-76. [pmid: 2033114].
224 Rowland AS, Skipper B, Rabiner DL, et al. The shifting subtypes of ADHD: classification depends on how symptom reports are combined. J Abnorm Child Psychol. 2008;36(5):731-43. [pmid: 18347973].
225 Soma Y, Nakamura K, Oyama M, et al. Prevalence of attention-deficit/hyperactivity disorder (ADHD) symptoms in preschool children: Discrepancy between parent and teacher evaluations. Environ Health Prev Med. 2009;14(2):150-4. [pmid: 19568859].
226 Pastor PN, Reuben CA. Diagnosed attention deficit hyperactivity disorder and learning disability: United States, 2004–2006. Vital Health Stat. 2008;(237):1-14.
227 Fulton BD, Scheffler RM, Hinshaw SP, et al. National variation of ADHD diagnostic prevalence and medication use: health care providers and education policies. Psychiatr Serv. 2009;60(8):1075-83. [pmid: 19648195].
228 Barbaresi WJ, Katusic SK, Colligan RC, et al. How common is attention-deficit/hyperactivity disorder? Incidence in a population-based birth cohort in Rochester, Minn. Arch Pediatr Adolesc Med. 2002;156(3):217-24. [pmid: 11876664].
229 Rafalovich A. Exploring clinician uncertainty in the diagnosis and treatment of attention deficit hyperactivity disorder. Sociol Health Illn. 2005;27(3):305-23. [pmid: 15953210].
230 Health Canada. Survey of Attention Deficit Hyperactivity Disorder (ADHD) Diagnosis and Treatment with Methylphenidate Among Canadian Physicians. 1999. http://www.hc-sc.gc.ca/dhp-mps/alt_formats/hpfb-dgpsa/pdf/medeff/methylphenidate_adhd-thada_fs-if-eng.pdf.
231 Arria AM, Caldeira KM, O’Grady KE, et al. Nonmedical use of prescription stimulants among college students: associations with attention-deficit-hyperactivity disorder and polydrug use. Pharmacotherapy. 2008;28(2):156-69. [pmid: 18225963].
232 Sollman MJ, Ranseen JD, Berry DTR. Detection of Feigned ADHD in College Students. Psychological Assessment. 2010;22(2):325-35. 2010. [pmid: 20528060].
233 Tucha L, Sontag TA, Walitza S, et al. Detection of malingered attention deficit hyperactivity disorder. ADHD. 2011:47-53.
234 Huss M, Holling H, Kurth B-M, et al. How often are German children and adolescents diagnosed with ADHD? Prevalence based on the judgment of health care professionals: Results of the german health and examination survey. Eur Child Adolesc Psychiatry. 2008;17(Suppl 1):52-8. [pmid: 19132304].
235 Bauermeister JJ, Shrout PE, Ramirez R, et al. ADHD correlates, comorbidity, and impairment in community and treated samples of children and adolescents. J Abnorm Child Psychol. 2007;35(6):883-98. [pmid: 17505876].
236 Montiel C, Pena JA, Montiel-Barbero I, et al. Prevalence rates of attention deficit/hyperactivity disorder in a school sample of Venezuelan children. Child Psychiatry Hum Dev. 2008;39(3):311-22. [pmid: 18157741].
237 Michanie C, Kunst G, Margulies DS, et al. Symptom prevalence of ADHD and ODD in a pediatric population in Argentina. J Atten Disord. 2007;11(3):363-7. [pmid: 17932387].
238 Ponde MP, Freire AC. Prevalence of attention deficit hyperactivity disorder in schoolchildren in the city of Salvador, Bahia, Brazil. Arq Neuropsiquiatr. 2007;65(2A):240-4. [pmid: 17607421].
239 Suvarna BS, Kamath A. Prevalence of attention deficit disorder among preschool age children. NMCJ. 2009;11(1):1-4. [pmid: 19769227].
240 Hebrani P, Abdolahian E, Behdani F, et al. The prevalence of attention deficit hyperactivity disorder in preschool-age children in Mashhad, north-East of Iran. Arch Iran Med. 2007;10(2):147-51. [pmid: 17367214].
241 Ghanizadeh A. Distribution of symptoms of attention deficit-hyperactivity disorder in schoolchildren of Shiraz, south of Iran. Arch Iran Med. 2008;11(6):618-24. [pmid: 18976032].
242 Adewuya AO, Famuyiwa OO. Attention deficit hyperactivity disorder among Nigerian primary school children: prevalence and co-morbid conditions. Eur Child Adolesc Psychiatry. 2007;16(1):10-5. [pmid: 17136303].
243 Alyahri A, Goodman R. The prevalence of DSM-IV psychiatric disorders among 7–10 year old Yemeni schoolchildren. Soc Psych Epid. 2008;43(3):224-30.
244 Sarwat A, Ali SMI, Ejaz MS. Mental health morbidity in children: A hospital based study in child psychiatry clinic. Pak J Med Sci Q. 2009;25(6):982-5.
245 Gau SS, Chong MY, Chen TH, et al. A 3-year panel study of mental disorders among adolescents in Taiwan. Am J Psychiatry. 2005;162(7):1344-50. [pmid: 15994718].
246 Farah LG, Fayyad JA, Eapen V, et al. ADHD in the Arab world: a review of epidemiologic studies. J Atten Disord. 2009;13(3):211-22. [pmid: 19372498].
247 Roberts RE, Roberts CR, Xing Y. Rates of DSM-IV psychiatric disorders among adolescents in a large metropolitan area. J Psychiatr Res. 2007;41(11):959-67. [pmid: 17107689].
248 Ruchkin V, Lorberg B, Koposov R, et al. ADHD symptoms and associated psychopathology in a community sample of adolescents from the European north of Russia. J Atten Disord. 2008;12(1):54-63. [pmid: 17712166].
249 Leung PWL, Hung S-F, Ho T-P, et al. Prevalence of DSM-IV disorders in Chinese adolescents and the effects of an impairment criterion: A pilot community study in Hong Kong. Eur Child Adolesc Psychiatry. 2008;17(7):452-61. [pmid: 18427862].
250 Skounti M, Philalithis A, Galanakis E. Variations in prevalence of attention deficit hyperactivity disorder worldwide. Eur J Pediatr. 2007;166(2):117-23. [pmid: 17033803].
251 Faraone SV, Biederman J. What is the prevalence of adult ADHD? Results of a population screen of 966 adults. J Atten Disord. 2005;9(2):384-91. [pmid: 16371661].
252 Hudson JL, Miller GE, Kirby JB. Explaining racial and ethnic differences in children’s use of stimulant medications. Med Care. 2007;45(11):1068-75. [pmid: 18049347].
253 Merikangas KR, He J-P, Brody D, et al. Prevalence and treatment of mental disorders among US children in the 2001–2004 NHANES. Pediatrics. 2010;125(1):75-81. [pmid: 20008426].
254 Zima B, Bussing R, Tang L. Quality of care for childhood attention-deficit/hyperactivity disorder in a managed care Medicaid program. J Am Acad Child Adolesc Psychiatry. 2010;49(12):1225-37. [pmid: 21093772].
255 Zarin DA, Tanielian TL, Suarez AP, et al. Treatment of attention-deficit hyperactivity disorder by different physician specialties. Psychiatr Serv. 1998;49(2):171. [pmid: 9574998].
256 Habel LA, Schaefer CA, Levine P, et al. Treatment with stimulants among youths in a large California health plan. J Child Adolesc Psychopharmacol. 2005;15(1):62-7. [pmid: 15741787].
257 Winterstein AG, Gerhard T, Shuster J, et al. Utilization of pharmacologic treatment in youths with attention deficit/hyperactivity disorder in Medicaid database. Ann Pharmacother. 2008;42(1):24-31. [pmid: 18042808].
258 Castle L, Aubert RE, Verbrugge RR, et al. Trends in medication treatment for ADHD. J Atten Disord. 2007;10(4):335-42. [pmid: 17449832].
259 Bhatara VS, Feil M, Hoagwood K, et al. Datapoints: trends in combined pharmacotherapy with stimulants for children. Psychiatr Serv. 2002;53(3):244. [pmid: 11875215].
260 DosReis S, Zito JM, Safer DJ, et al. Multiple psychotropic medication use for youths: a two-state comparison. J Child Adolesc Psychopharmacol. 2005;15(1):68-77. [pmid: 15741788].
261 Bhatara VS, Aparasu RR. Pharmacotherapy with atomoxetine for US children and adolescents. Ann Clin Psychiatry. 2007;19(3):175-80. [pmid: 17729019].
262 Comer JS, Olfson M, Mojtabai R. National trends in child and adolescent psychotropic polypharmacy in office-based practice, 1996–2007. J Am Acad Child Adolesc Psychiatry. 2010;42(10):1001-10. [pmid: 20855045].
263 Stallworth LE, Fick DM, Ownby DR, et al. Antibiotic use in children who have asthma: results of retrospective database analysis. J Manag Care Pharm. 2005;11(8):657-62. [pmid: 16194129].
264 Brinker A, Mosholder A, Schech SD, et al. Indication and use of drug products used to treat attention-deficit/hyperactivity disorder: a cross-sectional study with inference on the likelihood of treatment in adulthood. J Child Adolesc Psychopharmacol. 2007;17(3):328-33. [pmid: 17630866].
265 Chen CY, Gerhard T, Winterstein AG. Determinants of initial pharmacological treatment for youths with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(2):187-95. [pmid: 19364296].
266 Olfson M, Marcus S, Wan G. Stimulant dosing for children with ADHD: a medical claims analysis. J Am Acad Child Adolesc Psychiatry. 2009;48(1):51-9. [pmid: 19218896].
267 Safer DJ, Krager JM. Prevalence of medication treatment for hyperactive adolescents. Psychopharmacol Bull. 1985;21(2):212-5. [pmid: 4001287].
268 Safer DJ, Malever M. Stimulant treatment in Maryland public schools. Pediatrics. 2000;106(3):533-9. [pmid: 10969099].
269 Swanson JM, Volkow ND. Psychopharmacology: Concepts and opinions about the use of stimulant medications. Journal of Child Psychology and Psychiatry. 2009;50(1–2):180-93. [pmid: 19220601].
270 Varley CK, Vincent J, Varley P, et al. Emergence of tics in children with attention deficit hyperactivity disorder treated with stimulant medications. Compr Psychiatry. 2001;42(3):228-33. [pmid: 11349243].
271 Visser SN, Lesesne CA, Perou R. National estimates and factors associated with medication treatment for childhood attention-deficit/hyperactivity disorder. Pediatrics. 2007;119:Suppl-106.
272 Romano E, Baillargeon RH, Wu HX, et al. Prevalence of methylphenidate use and change over a two-year period: a nationwide study of 2- to 11-year-old Canadian children. J Pediatr. 2002;141(1):71-5. [pmid: 12091854].
273 Mitchell B, Carleton B, Smith A, et al. Trends in psychostimulant and antidepressant use by children in 2 Canadian provinces. Can J Psychiatry. 2008;53(3):152-9. [pmid: 18441661].
274 Hsia Y, Maclennan K. Rise in psychotropic drug prescribing in children and adolescents during 1992–2001: a population-based study in the UK. Eur J Epidemiol. 2009;24(4):211-6. [pmid: 19266290].
275 Wong IC, Asherson P, Bilbow A, et al. Cessation of attention deficit hyperactivity disorder drugs in the young (CADDY) a pharmacoepidemiological and qualitative study. Health Technology Assessment (Winchester, England). 2009;13(50):iii-iiv.
276 Trip A-M, Visser ST, Kalverdijk LJ, et al. Large increase of the use of psycho-stimulants among youth in the Netherlands between 1996 and 2006. Br J Clin Pharmacol. 2009;67(4):466-8. [pmid: 19371321].
277 Valentine J, Zubrick S, Sly P. National trends in the use of stimulant medication for attention deficit hyperactivity disorder. J Paediatr Child Health. 1996;32(3):223-7. [pmid: 8827539].
278 Reid R, Hakendorf P, Prosser B. Use of psychostimulant medication for ADHD in South Australia. J Am Acad Child Adolesc Psychiatry. 2002;41(8):906-13. [pmid: 12162626].
279 Salmelainen P. Trends in the prescribing of stimulant medication for the treatment of attention deficit hyperactivity disorder in children and adolescents in New South Wales. N S W Public Health Bull. 2002;13(Suppl 1):1-65. [pmid: 12189396].
280 Preen DB, Calver J, Sanfilippo FM, et al. Patterns of psychostimulant prescribing to children with ADHD in Western Australia: variations in age, gender, medication type and dose prescribed. Aust N Z J Public Health. 2007;31(2):120-6. [pmid: 17461001].
281 Vinker S, Vinker R, Elhayany A. Prevalence of methylphenidate use among Israeli children: 1998–2004. Clin Drug Invest. 2006;26(3):161-7.
282 Landgren M, Pettersson R, Kjellman B, et al. ADHD, DAMP and other neurodevelopmental/psychiatric disorders in 6-year-old children: epidemiology and co-morbidity. Dev Med Child Neurol. 1996;38(10):891-906. [pmid: 8870611].
283 Szatmari P, Offord DR, Boyle MH. Ontario Child Health Study: prevalence of attention deficit disorder with hyperactivity. J Child Psychol Psychiatry. 1989;30(2):219-30. [pmid: 2708462].
284 Almeida Montes LG, Hernandez Garcia AO, Ricardo-Garcell J. ADHD prevalence in adult outpatients with nonpsychotic psychiatric illnesses. J Atten Disord. 2007;11(2):150-6. [pmid: 17709815].
285 Graetz BW, Sawyer MG, Hazell PL, et al. Validity of DSM-IV ADHD subtypes in a nationally representative sample of Australian children and adolescents. J Am Acad Child Adolesc Psychiatry. 2001;40(12):1410-7. [pmid: 11765286].
286 Gomez R, Harvey J, Quick C, et al. DSM-IV AD/HD: confirmatory factor models, prevalence, and gender and age differences based on parent and teacher ratings of Australian primary school children. J Child Psychol Psychiatry. 1999;40(2):265-74. [pmid: 10188709].
287 Fergusson DM, Horwood LJ, Lynskey MT. Prevalence and comorbidity of DSM-III-R diagnoses in a birth cohort of 15 year olds. J Am Acad Child Adolesc Psychiatry. 1993;32(6):1127-34. [pmid: 8282656].
288 Gruber R, Grizenko N, Schwartz G, et al. Performance on the continuous performance test in children with ADHD is associated with sleep efficiency. Sleep. 2007;30(8):1003-9. [pmid: 17702270].
289 Polanczyk G, Jensen P. Epidemiologic considerations in attention deficit hyperactivity disorder: a review and update. Child Adolesc Psychiatr Clin N Am. 2008;17(2):245-60. [pmid: 18295145].