# Peer Reviewers

L. Eugene Arnold, M.D., Med.

Ohio State University, Nisonger Center

Columbus, OH

Lisa Clements, Ph.D.

Missouri Department of Social Services

Jefferson City, MO

Jaswinder Ghuman, M.D.

University of Arizona

Tucson, AZ

Laurence L. Greenhill, Ph.D., M.D.

Columbia University

New York, NY

John Ratey, M.D.

Massachusetts Mental Health Center

Harvard University

Cambridge, MA

Maggie Toplak, Ph.D.

York University

Toronto, Ontario. Canada

Julie Zito, Ph.D.

University of Maryland

Baltimore, MD