# Key Informants

Lisa Clements, Ph.D.

Missouri Department of Social Services

Jefferson City, MO

Jaswinder Ghuman, M.D.

University of Arizona

Tucson, AZ

George DuPaul, Ph.D.

Lehigh University

Bethlehem, PA