# Introduction

## Historical Background

Children with Attention Deficit Hyperactivity Disorder (ADHD), a condition characterized by inattention, overactivity, and impulsivity, are most frequently identified and treated in primary school. Population studies indicate that five percent of children worldwide show impaired levels of attention, as well as hyperactivity. Boys are classified with ADHD approximately twice as frequently as girls and primary school age children approximately twice as frequently as adolescents. ADHD symptoms exist on a continuum in the general population, and are considered as a ‘disorder’ to a greater or lesser degree depending on the source of identification, (e.g., parent or teacher), perception of extent of functional impairment, diagnostic criteria, and the threshold chosen for defining a ‘case.’ The developmentally excessive levels of inattention, overactivity, and impulsivity characteristic of ADHD are present from an early age. However, preschoolers with early signs of ADHD may also have co-occurring oppositional noncompliant behaviors, temper tantrums, and aggression that overshadow symptoms of inattention and overactivity and confound the diagnosis. These behaviors may be given the more general label of a Disruptive Behavior Disorder (DBD), which include Oppositional Defiant Disorder (ODD) and Conduct Disorder (CD) as well as ADHD. If not already identified by an early age, preschool youngsters with ODD frequently meet criteria for ADHD by grade school.

Key Question 3 will address issues which influence our understanding of prevalence; at this point we include a brief, necessarily truncated, history, with a somewhat expanded timeline of relevant events in Table 14.

Although anecdotally and in stories characters with ADHD-like behaviors are described much earlier, the first clinical description of the syndrome was presented by Sir George Frederick Still in 1902.^1^ In a series of lectures subsequently published in The Lancet, he describes children, more often boys than girls, who display ‘an abnormal capacity for sustained attention causing school failure, even in the absence of intellectual retardation’. He provides virtually a textbook description of ADHD children: his assessment and interpretations perhaps influenced and obscured slightly with other conditions now categorized separately and, in keeping with the understanding of the times, attributed to “defects of moral control.” He presents his observations of these children under different social conditions and environments, and enlarges on the limitations and impairments they experience as a result.

Since, discoveries usually occur in a larger social context, however, it cannot be coincidence that this constellation of behaviors was thrown into sharp relief within a generation of the passing of The Educational Act (1876), which mandated elementary education for all children. It is in the context of this structured environment that even today, for many children, attentional difficulties are defined.2

Observing that the sequelae in some survivors of the Spanish influenza epidemic included agitation, in 1922, Tredgold postulated the source of what we now term ADHD as neurologically based and called it ‘minimal brain damage,’ although in fact only a few children displayed this post-influenza reaction. However, this theory set the stage for interpreting ADHD as a neurological condition for the next half century, until subsequent scientific discoveries, classification models, and social events nudged theoretical constructs toward some combination of genetic, biological, social, and evolutionary explanations. 2,108

Helping these young patients was another matter, and it was not until Charles Bradley identified d,l-amphetamine in 1932 and discovered it worked ‘paradoxically’ for some among the inpatient children under his care, did doctors have an effective treatment strategy. The impact of this development has been such that once an apparently effective pharmacological solution appeared, widespread dependence on it as a model for treatment has persisted, even though 50 years later, in 1980, Rapoport observed that the calming and focusing effects of stimulants were apparent in both normal and ADHD children and that age, rather than susceptibility, was likely the defining feature of the drug effect.3 Parallel to these pharmacological developments, creation of diagnostic categories, psychometric instruments, and definitions were proceeding, both deriving from and shaping our understanding of this heterogenous disorder.109,110 The controversy around accurate diagnosis is particularly heightened with documented increases in diagnosis of younger children and associated increases in treatment with psychoactive medications.

From an estimated 150,000 to 200,000 children in the United States treated with stimulants at the end of the 1960s, as of 2005, current estimates stand at 4.4 million children diagnosed with ADHD, of whom 56 percent or 2.5 million receive medication.4 Prescription sales data have been available for psychostimulant drugs since 1971, when they were recategorized as Schedule II controlled substances with mandatory reporting requirements. Despite its status as a controlled substance, there is still cause for concern since methylphenidate (MPH) appears so widely available beyond the normal range of medical access points (e.g., through internet sources, as well as with increased use as a ‘study aid’ on campuses111,112) and the evidence of mismatch between who gets diagnosed and who gets prescribed. Eisenberg3 cites the Great Smoky Mountain studies by Angold113 and Costello,114 which find a definite diagnosis prevalence of ADHD as 0.9 percent in the population (as measured by interviews with parents), and rates of psychostimulant treatment more than double that, with many of those using medication meeting partial but not full diagnostic criteria. Other studies do not find such strong evidence of a mismatch, as reported by Goldman115 and Schachar et al. 116

We close this synopsis of the history of ADHD with reference to another influential school related legislation, the 2005 introduction and passage of the Child Medication Safety Act (House of Representatives (H.R.) 1790) which was ‘enacted to protect children and parents from being coerced into administering a controlled substance or psychotropic drug in order to attend school, and for other purposes, …’117 The introduction of this legislation may introduce limits on the role of institutions in decisions about children with ADHD, so that parents maintain authority over decisions in regard to medication for their child. However, the controversy also points to the need for further development of a range of alternative strategies for families who prefer no medication.

## Clinical Context

Children with ADHD, characterized by inattention, overactivity, and impulsivity, are most frequently identified and treated in primary school. Population studies identify that approximately 5 percent of children worldwide show impaired levels of attention, as well as hyperactivity.93 Boys are classified with ADHD approximately twice as frequently as girls, and younger children approximately twice as frequently as adolescents. ADHD symptoms exist on a continuum in the general population, and are considered as a ‘disorder’ to a greater or lesser degree depending on the source of identification (e.g., parent or teacher), including extent of functional impairment, diagnostic criteria, and the threshold chosen for defining a ‘case.’93 As alluded to in the preceding section, the cultural and situational context are also influential in case identification, largely through the responses of parents and teachers who answer the questions about symptoms and impaired functioning. Therefore, formal diagnostic criteria such as the DSM-IV include presence of impairment across settings, for example both at home and at school. There is increasing interest in identifying and treating very young children, those in preschool, in order to ameliorate the burden on child and family as early as possible and thereby diminish the later development of social and academic repercussions.

### The Social Burden Associated With Attention Deficit Hyperactivity Disorder (ADHD)

Clinically significant ADHD is often associated with concurrent oppositional and aggressive behaviors, anxiety, low self-esteem, and learning disabilities. Symptoms generally interfere with academic and behavioral functioning at school, and may also disrupt family and peer relationships. ADHD begins before children enter school although it is most commonly identified and treated in primary school, at age 7 to 9 years.118 In the preschool age group, ADHD is characterized not only by impairment in attention span, excessive impulsivity, and overactivity, but also is frequently accompanied by additional disruptive behavior symptoms, including severe temper tantrums, demanding, uncooperative behavior, and aggressiveness.119 While levels of symptoms decrease with age, the majority of children with ADHD continue to show impairment relative to same-age peers throughout adolescence and into adulthood. Estimates of prevalence of ADHD among adults worldwide is 2.5 percent.9

### Interventions for ADHD

Interventions for ADHD include a range of medication and nonmedication options. Many children, teens, and families receive nonspecific psychosocial support, counseling, and advice, as well as academic tutoring and coaching, both in school and out. Complementary and alternative medicine options, including dietary supplements, are also available. Few of these interventions have been systematically evaluated, and fewer still have been examined for their long-term effectiveness. One area of careful study has been the efficacy of pharmacological agents on the core symptoms of ADHD and more recently on several aspects of overall functional impairment. This research has often, but not always, been supported by industry.

Nonpharmacological interventions, especially behavior training with parents and teachers, have been studied most extensively for treatment of DBD, primarily ODD and CD. These conditions often co-occur with ADHD, especially hyperactive impulsive subtype, and in community practice can be hard to distinguish from one another. The well known Multimodal Treatment Study of ADHD (MTA Study) funded by the U.S. National Institutes of Mental Health (NIMH) remains the best source of information regarding the comparative effectiveness of pharmacological versus non pharmacological interventions for ADHD over an extended period of time. The MTA study is discussed at length later in this report (pp. 74–76). Following the initial results, published in 1999,^74^ behavioral interventions for children age 6 and up generally targeted ODD and CD symptoms with MPH and other psychostimulants used for core symptoms of ADHD, inattention, impulsivity, distractibility, and overactivity.

### Pharmacological Interventions

Multiple short-term studies document that psychostimulant medications, either MPH, dextroamphetamine (DEX), or mixed amphetamine salts (MAS), effectively decrease the core symptoms of ADHD and associated impairment.10 A review of the mechanisms of action of pharmacological interventions for ADHD is beyond the scope of this report. Some preparations last only a few hours, with symptoms returning as the medication wears off. Many families choose to use medication primarily on school days, and these medications have primarily been studied in school-aged children and youth aged 6 years and older. Psychostimulants, most commonly MPH and DEX, are generally safe and well tolerated. Common side effects include poor appetite, insomnia, headaches, stomachaches, and increased blood pressure and heart rate. Prolonged use may result in a decreased rate of growth, generally considered clinically insignificant.118 Concerns have been raised from postmarketing surveillance suggesting a rare incidence of sudden death, perhaps associated with pre-existing cardiac defects, however, the rate does not appear to exceed that of the base rate of sudden death in the population.118 As noted earlier, approximately 2.5 million children in the United States, ages 4 to 17 years with a diagnosis of Attention Deficit Disorder (ADD) or ADHD, currently take medication.4

Several extended release preparations of psychostimulants have been developed in recent years aimed at improved adherence and symptom control throughout the day as well as decreased abuse potential.120 Non-stimulants (e.g., alpha adrenergic agents and atomoxetine (ATX)) have also been developed and found to be helpful in controlling symptoms with few adverse events.121 However, in general, the benefits of medications wear off when they are discontinued. Since ADHD is a chronic disorder, many children, teens, and adults stay on medications for years at a time. Given the possibility of cumulative effects over time, a review of evidence regarding benefits and risks of prolonged medication use for ADHD is indicated.

### Nonpharmacological Interventions

In the area of nonpharmacologic interventions, behavior training has been found to be helpful, primarily for disruptive behaviors that frequently coincide with ADHD.122 Since ADHD may begin before school age, using the precedent of older children, increasing numbers of preschoolers are being identified and treated, sometimes with medications. However, the most commonly used psychostimulant, MPH, does not yet have government regulatory approval for use in children less than 6 years of age, while MAS has been granted approval by the FDA in the United States for children under 6 years, but older than 3 years of age.123 Recent reviews of treatments for preschoolers with ADHD emphasize the use of parenting interventions prior to medication based on general clinical consensus.124 Indeed, the Preschool ADHD Treatment Study (PATS), funded by the U.S. National Institute for Mental Health (NIMH), included parent behavior training (PBT) as the first phase for all children recruited into the study prior to randomization for the purpose of evaluating efficacy and safety of psychostimulant medication.125 While the few studies available suggest stimulant medications are effective for the core symptoms of inattention, hyperactivity, and impulsiveness in very young children, psychostimulants also appear to cause more adverse events in preschool children than in older children.54 Beyond the PATS, little information exists to document effectiveness of either medication or non-medication interventions specifically for ADHD in this age group. Part of the difficulty has been lack of clarity regarding reliability and validity of diagnostic criteria and therefore lack of widespread application of the ADHD diagnosis for children under 6 years.119 To address this information gap we will examine interventions for preschoolers with DBD, which include ADHD behaviors. Research has accumulated regarding PBT for preschoolers with disruptive behavior in the past decade, but many of the studies do not recruit based on an ADHD diagnosis, but rather based on clinically significant disruptive behavior. However, ADHD in preschoolers is commonly identified in the context of comorbid oppositional and aggressive behavior.126 A review of these studies will provide useful information about parenting interventions in preschoolers at very high risk of ADHD, especially those with defiant and aggressive behaviors. Other interventions and combinations of interventions for preschoolers with DBD including ADHD will also be reviewed.

### Long-Term Outcomes

Children with ADHD are at risk for poor adolescent outcomes including decreased high school completion, early substance use, increased driving infractions, early parenthood, increased contact with the law, and the onset of concurrent psychiatric disorders. Both retrospective studies and prospective longitudinal studies over long time periods face challenges in documenting outcomes and controlling for recall bias. Comparisons of treated versus untreated individuals can be hard to interpret as both known and unknown factors play a role over the developmental spectrum from preschool to young adulthood. The natural history of those with ADHD, in comparison to those not meeting the diagnostic criteria for ADHD, remains poorly documented as standardized diagnostic criteria and methods of investigation have been in existence a relatively short time. Not knowing the natural history of the disorder complicates interpretation of treatment extension studies. Despite these limitations, it is timely to examine the current literature to see what has been accomplished and to consider directions for future research. Outcomes of interest for these studies include: persistence of ADHD, new onset psychiatric and substance use disorders, as well as educational, occupational, and social functioning outcomes.

### Prevalence and Variations in Management

Over the past several decades, rates of identification and treatment for people with ADHD have increased as documented by population-based studies using health administrative databases.94,95,127 In some cases, small-area variation in prescriptions has been linked to specific physicians, suggesting that increases in identification may be linked with changes in practice patterns rather than an increase in the underlying endemic prevalence of the disorder.128,129 In fact, the underlying prevalence of the disorder in children appears to have been relatively stable since the 1980s, to the extent that it has been measured using identical research methods.130 In the past 10 years, increases in identification and treatment have occurred primarily among girls and older children consistent with changes in clinical guidelines.95,131 Increases in off-label prescription of psychotropic medications for very young children have also been noted, presumably for preschoolers identified at high risk for ADHD because of disruptive behavior.97

## Scope and Purpose of the Systematic Review

The purpose of this review is to: (i) critically examine the effectiveness and adverse events of interventions in preschool children with clinically significant disruptive behavior (that is, meeting clinical thresholds on standardized symptom scales and/or clinically diagnosed with disruptive behavior disorders or ADHD), and therefore at high risk for ADHD; (ii) critically examine the comparative long-term effectiveness and adverse events of interventions for ADHD (pharmacological, psychosocial, or behavioral, and the combination of pharmacological and psychosocial or behavioral interventions); and (iii) summarize what is known about patterns of identification and treatment for the condition. Factors to be examined include geography, sociodemographics, temporal aspects, and provider background. This systematic appraisal will also identify gaps in the existing literature that will inform directions for future research.

This review follows the 1999 publication of a systematic review of ADHD sponsored by the AHRQ.10 That review examined subjects of any age and all lengths of treatment and followup. The current review is focusing attention on both the treatment of preschoolers, which has become of greater interest to parents and physicians since 1999, and on the long-term outcomes of treatment of any type for ADHD for any age. The previous report looked at only RCTs, while this review will include other study designs in order to capture more long-term outcomes and more adverse events.

The key questions are as follows:

- Key Question 1. Among children less than 6 years of age with Attention Deficit Hyperactivity Disorder or Disruptive Behavior Disorder, what are the effectiveness and adverse event outcomes following treatment?
- Key Question 2. Among people 6 years of age or older with Attention Deficit Hyperactivity Disorder, what are the effectiveness and adverse event outcomes following 12 months or more of any combination of followup or treatment, including, but not limited to, 12 months or more of continuous treatment?
- Key Question 3. How do: (a) underlying prevalence of ADHD, and (b) rates of diagnosis (clinical identification) and treatment for ADHD vary by geography, time period, provider type, and sociodemographic characteristics?