# Discussion

## Summary of the Evidence

This systematic review examined three questions regarding the effectiveness and safety of interventions for persons with Attention Deficit Hyperactivity Disorder (ADHD). We investigated safety and efficacy of interventions for preschool children with Disruptive Behavior Disorders (DBD) (which includes Oppositional Defiant Disorder (ODD) and Conduct Disorder (CD), as well as ADHD), including those at high risk for ADHD. The SOE for effectiveness of interventions to improve disruptive behavior, including ADHD, in preschoolers is summarized in Table 21. We investigated long-term effectiveness of interventions, with a special focus on the safety of pharmacologic interventions for persons of all ages with ADHD. The SOE for longer term effectiveness for interventions to improve ADHD symptoms is summarized in Table 22. Finally, we report on variability in prevalence, clinical identification, and treatment for ADHD in the United States and elsewhere.

Table 21 KQ1. Effectiveness of interventions for ADHD and DBD in children <6 years old

Intervention | Level of Evidence | Conclusion
a. Parent behavior training | SOE: High SMD: −0.68 (95% CI, −0.88 to −0.47) | Parent behavioral interventions are an efficacious treatment option for preschoolers with DBD, and show benefit for ADHD symptoms. These studies support the long-term effectiveness of parent interventions for preschoolers with DBD, including ADHD symptoms, with evidence that benefits are maintained for up to 2 years. There also appears to be a dose response effect.
b. Multicomponent home and school or daycare-based interventions | SOE: Insufficient | Evidence is drawn from few reports Where there is no socioeconomic burden, multicomponent interventions work as well as a structured parent education program in several domains. Where there is socioeconomic burden, the treatment classroom appears to be the primary beneficial intervention and appears related to lack of parent engagement and attendance at PBT sessions. Relative benefits of the school-based intervention diminished over 2 years.
c. Medication (MPH only) | SOE: Low SMD: −0.83 (95% CI, −1.21 to −0.44) | With evidence drawn primarily from the PATS study, MPH (e.g., short-acting, immediate release MPH) is both efficacious and generally safe for treatment of ADHD symptoms, but there has been no long-term followup in preschoolers

Abbreviations: ADHD = Attention Deficit Hyperactivity Disorder; DBD = Disruptive Behavior Disorder; MPH = methylphenidate; PATS = The Preschool ADHD Treatment Study; PBT = parent behavior training; SMD = Standardized Mean Difference; SOE = strength of evidence

Table 22 KQ2. Long-term (>1 year) effectiveness of interventions for ADHD in people 6 years and older

Intervention | Level of Evidence | Conclusion
a. Medication treatment | SOE: Low MPH: SMD: −0.54 (95% CI, −0.79 to −0.29) ATX: SMD = −0.40 (95% CI, −0.61 to −0.18) | Very few studies include untreated controls. Studies largely funded by industry. Psychostimulants continue to provide control of ADHD symptoms and are generally well tolerated for months to years at a time. The evidence for MPH use in the context of careful medication monitoring shows good evidence for benefits for symptoms for 14 months. ATX is effective for ADHD symptoms and well tolerated over 12 months.
a. Medication treatment | SOE: Insufficient | Only one study of GXR monotherapy is available which reports reduced ADHD symptoms and global improvement, although less than a fifth of participants completed 12 months. Monitoring of cardiac status may be indicated since approximately one percent of participants showed ECG changes judged clinically significant.
b. Combined psychostimulant medication and behavioral treatment | SOE: Low SMD = −0.70 (95% CI, −0.95 to −0.46) | The results from 2 cohorts indicate both medication (MPH) and combined medication and behavioral treatment are effective in treating ADHD plus ODD symptoms in children, primarily boys aged 7–9 years of normal intelligence with combined type of ADHD, especially during the first 2 years of treatment. Several reports from one “good” quality study suggest that combined medication and behavioral treatment improves outcomes more than medication alone for some subgroups of children with ADHD Combined type, and for some outcomes.
c. Behavioral/psychosocial | SOE: Insufficient | Not enough evidence to draw conclusions for persons 6 years and older and with a diagnosis of ADHD.
d. Parent behavior training | SOE: Insufficient | Not enough evidence to draw conclusions for persons 6 years and older and with a diagnosis of ADHD.
e. Academic interventions | SOE: Insufficient | One “good” study and its extension showed that classroom-based programs to enhance academic skills are effective in improving achievement scores in multiple domains, but following discontinuation, the benefits for sustained growth in academic skills is limited to the domain of reading fluency. All other domains show skill maintenance but not continued growth.

Abbreviations: ADHD = Attention Deficit Hyperactivity Disorder; ATX = atomoxetine; DBD = Disruptive Behavior Disorder; ECG = electrocardiogram; GXR = guanfacine extended release; MPH = methylphenidate; ODD = Oppositional Defiant Disorder; SES = socioeconomic status; SMD = Standardized Mean Difference; SOE = strength of evidence

Overall, we found that the most information about long-term outcomes applies to boys ages 7 to 9 years at intervention. Preschoolers with diagnosed ADHD, girls, teenagers, and adults have rarely been the focus of intervention research. In general, safe and effective interventions have been identified. Parent behavior training for preschoolers is efficacious and benefits appear to last, although many parents drop out of treatment. Medications can be efficacious in preschoolers, but are not as well tolerated as in children over 6 years of age, or in adults. In addition, parents show decreasing adherence to medication use for their children over 12 months despite effectiveness. For children over 6 years of age, teenagers, and adults, medications remain the most thoroughly researched interventions, with most studies sponsored by industry. In addition to psychostimulant medications, two additional pharmacologic agents, atomoxetine (ATX) and guanfacine extended release (GXR), have been studied and appear effective and safe for one or more years at a time, with differing adverse event profiles. Classroom teacher-based interventions can improve academic and classroom behavior outcomes for both preschoolers and primary school children, but difficulties re-emerge 1 to 2 years following discontinuation of the intervention. For some subgroups of children, additional benefit may derive from combined medication and behavioral interventions, but not for all. There remains a lack of clarity about how long treatment may be required, of what type, and for whom. For some, incremental improvement accrues with continued intervention over years; for others, medication interventions can be discontinued without symptom relapse. However, these observations are difficult to evaluate due to the absence of information regarding specific subgroups receiving treatment and details regarding co-interventions.

A survey of the research in community samples suggests that clinical identification and treatment of ADHD has increased, especially since the early 1990s, and varies widely geographically. Prevalence estimates for the underlying or background rate of ADHD in school age children vary primarily due to method of measurement, definition of disorder, and informant. Fewer prevalence studies are available addressing older adolescents and adults.. Information regarding clinical identification and treatment for large-scale populations has been gathered through epidemiologic surveys with parents, through studies using administrative claims databases where providers document diagnoses and treatments recommended for insurance claims, and through prescription databases examining the use of medications. Alternative or additional educational or psychosocial interventions are not represented. The data sources shape what research questions can be answered.

## Rating the Body of Evidence

We assessed the overall strength of the body of evidence using the context of the GRADE approach, modified as the Grading System as defined by AHRQ.14,15 Although we included papers that were not randomized controlled trials (RCTs), there are several factors suggested by the GRADE approach that may decrease the overall strength of the evidence (SOE):

1. Study limitations (predominately risk of bias)
2. Type of study design (experimental versus observational)
3. Consistency of results (degree to which study results for an outcome are similar between studies; variability that is easily explained)
4. Directness of the evidence (assesses whether interventions can be linked directly to the health outcomes)
5. Precision (degree of certainty surrounding an effect estimate for a specific outcome)

The ratings were arrived at through discussion among two or more of the investigators. Only papers rated as “good” were included in these analyses since they represent the best available data at this point in time. See Appendix D.

## Key Question 1 Among children less than 6 years of age with Attention Deficit Hyperactivity Disorder or Disruptive Behavior Disorder, what are the effectiveness and adverse event outcomes following treatment?

Twenty-eight “good” or “fair” quality RCTs investigating the effect of parent behavior training (PBT) on a variety of outcomes in preschool children with DBD are available, most comparing interventions to wait list controls (see Tables 2 and 3 for study details). We performed meta-analyses examining effectiveness of PBT for reducing child disruptive behavior, including symptoms of ADHD. The descriptive review of the studies showed that parent behavioral interventions are an efficacious treatment option for preschoolers with DBD and also improve parents’ sense of competence. The meta-analyses indicated that parent-rated child disruptive behaviors improve to a clinically significant degree. Among these RCTs, eight examined measures of ADHD symptoms.36–39,133,135–137 Seven of the eight studies documented improvements in these symptoms as well. Some studies utilized blinded observations of child and parent interactions and identified improved child compliance and improved parenting strategies. Self-directed, group, and individual variants of parenting interventions are generally equally effective, though group therapy may be more cost-effective when compared to individual therapy. The primary barrier to effectiveness is that parents do not attend or do not complete the recommended numbers of sessions, and this interferes with optimal benefit.

Extension studies suggest that the benefits shown postintervention are maintained.19,21,26,27,29,33,139–141 However, these studies lack a control group, since most RCTs used wait list controls and the comparison families received the intervention following the prescribed period of waiting. In addition, the extension studies show high levels of attrition. Therefore, the possibility exists that natural maturation or child development would also lead to improvement over extended periods of time.

Seven studies examined interventions combining home- and school- or daycare-based interventions designed specifically for preschoolers or kindergarten children with ADHD or those at high risk for ADHD and DBD.27,40,42,122,141–143 Two studies examined comprehensive home and school behavior training in comparison to community care or a structured parent education program in a population of children with little socio-economic burden.122,143 In this population, behavior and school readiness improved following both the multicomponent intervention and the comparison interventions. Few children received medication. In contrast, a combination PBT and teacher consultation program showed definite benefit in comparison to treatment as usual for a low socioeconomic Head Start community.27 Another study examined a kindergarten treatment classroom intervention in comparison to PBT, combined PBT and treatment classroom, and a no-treatment control. This population included both families on public assistance and those not on public assistance. The treatment classroom appeared to be the primary beneficial intervention, with little additional improvement noted for those in PBT, although parent attendance was poor. Pragmatic issues interfered with randomization potentially biasing outcomes.141,142 Studies of combined parent and teacher or school-based intervention in less well educated, or low socioeconomic status (SES) families find that parent participation can be modest even when groups occur at convenient times, with transportation and babysitting provided.27 A dose effect of attendance at sessions has been noted where children of those who attend more sessions show improved child behavior and parents report greater improvement in skills.40

There are only a few short-term studies examining psychostimulant use in preschoolers, most with small sample sizes. Of these, only one small study compares medication directly with PBT and the combination of medication and PBT.43 The medication dose it examines is low compared with doses suggested by other studies. The sample size was very small, perhaps due to attrition (16 of 26 children completing interventions), precluding the usual statistical analysis for controlled trials examining efficacy. There is one RCT with a more robust sample size (N= 165) that offers the best evidence of both efficacy and safety, the preschool ADHD Treatment Study (PATS). Following clinical consensus, all 303 families with children eligible for the study initially participated in a 10-session PBT program. The next phase was an open-label safety lead-in phase followed by a 5-week multiple dose randomized crossover titration trial to examine dose effects, including adverse events. After identifying the child’s best dose, a 4-week parallel RCT compared best dose to placebo. One hundred and forty children entered a 10-month open label extension study. The research program offered excellent evidence that methylphenidate (MPH) is both efficacious and generally safe for treatment of ADHD symptoms.7 However, additional analyses identify that children do not improve in all domains, as parents report increases in mood and anxiety symptoms, while clinicians identify global improvement and teachers note improved social skills.51 Children experience more adverse events than older groups, and many families do not maintain adherence.54 The most common adverse event resulting in withdrawal from the study was irritability. Growth rates are slowed over 1 year’s time,53 and children with multiple comorbidities do more poorly on medication than those who have a less complicated presentation.52

## Key Question 2 Among people 6 years of age or older with Attention Deficit Hyperactivity Disorder, what are the effectiveness and adverse event outcomes following 12 months or more of any combination of followup or treatment, including, but not limited to, 12 months or more of continuous treatment?

Among the studies available examining extended outcomes following treatment, many examined pharmacologic agents, and these were primarily industry sponsored. Three studies were placebo-controlled discontinuation studies or relapse-prevention studies.61,66,67 In general pharmacologic agents continue to control the symptoms of ADHD after 12 months of use, with benefits maintained, although studies did not address the possibility of improved symptoms due to maturation. The different agents demonstrate different safety profiles, such that adverse events may be a primary reason for choosing one agent over another (switching to another formulation of psychostimulant, for example) or to another class of agent. Few serious adverse events are noted, although GXR appears to be less well tolerated than other agents examined. With two-thirds of the studies funded by industry, there may be enhanced representations of effectiveness and safety.147 The following discussion offers details about effectiveness and safety by specific agent.

### Psychostimulants

Psychostimulants continue to provide control of ADHD symptoms and are generally well tolerated for months to years at a time. Concerns about exacerbation of tics with stimulants appear to be unfounded, although sample size in studies of tics remain small and this may result in a type II error. Some of the long-term research summarizes information based on short-acting formulations of psychostimulants, requiring multiple doses daily. The Barbaresi59 study, for instance, reports that MPH is better tolerated than dextroamphetamine (DEX). However, direct comparison of once-daily agents, for example, OROS MPH and MAS XR is can be difficult. For example, the Hoare, et al.60 study of OROS MPH included adolescents and those with ADHD inattentive type (ADHD-I), whereas the McGough, et al.63 study of a MAS XR sample had more than 90 percent of participants with ADHD Combined type (ADHD-C). Comparison could be read as suggestive that OROS MPH is better tolerated than MAS XR, but both studies had 15 percent of participants withdraw because of adverse events. Also the methods for collecting adverse events may have been more sensitive in McGough, et al., as they were collected by both spontaneous reports and by investigator inquiry.63 It is also possible that the Hoare, et al., study offered participants relatively less effective dose, thereby diminishing the likelihood of adverse events.60 The agents have not been compared in the same long-term (over 12 months) trial and therefore, it is not possible to make direct comparisons of effectiveness and safety or tolerability.

### Atomoxetine

Long-term extension trials show that ATX is both safe and effective for ADHD symptoms in children and teens over 12 to 18 months. The research examining its use considers global functional assessments as well as ADHD symptom change. In contrast to studies of other agents, the research offers direct comparison with placebo for examination of relapse prevention, offering evidence that benefits are maintained following discontinuation.66,67,69 An important caveat to these statements appears in Newcorn, et. al.,79 a study not meeting criteria for this review as the total length of treatment and followup was less than 12 months. This study compared effect sizes for ATX with OROS MPH and documented the psychostimulant as more efficacious than ATX for ADHD symptom control. Adler, et al.,68 offer the only study of a pharmacologic intervention over an extended time period in adults with ADHD.

### Guanfacine Extended Release

Open-label extension trials of GXR show it to be effective and generally safe.70,71 Parents report benefit in reduced ADHD symptoms and global improvement for a substantial number of children and teens with ADHD. Somnolence, headache, and fatigue appear to interfere with its use, but these adverse events appear to diminish following several months of treatment, although this may be due to discontinuation by those who do not tolerate the agent.70 Substantially fewer children completed the 12-month extension trial on GXR monotherapy than completed the psychostimulant trials and the ATX trials reviewed, suggesting less overall effectiveness and tolerability. Fewer adverse events are reported and adherence improved with concurrent administration of psychostimulants.71 These observations may also reflect improved symptom control.

### Adverse Events

We examined studies regarding three areas of adverse events that required the use of articles that were not clinical trials comparing two or more interventions. The studies examined growth rates in comparison to standardized norms and rates of hospital and emergency department use for cardiac events and cerebrovascular events, such as cerebrovascular accidents (CVAs) and Transient Ischemic attacks (TIAs). In this review, the safety, tolerability, and adverse events of pharmacological agents is reported within the context of clinical trials, the information appears where the clinical trials of the specific agent are described.

#### Growth

Medications used for ADHD appear to have a small but distinct dose–related impact on rates of growth for children with ADHD. Limitations in the studies include small sample size, comparison with population norms, and the relatively short duration of studies, which interfere with clarification regarding final adult height following years of medication use. Two well designed clinical trials of psychostimulants, the PATS and the MTA study, both examined the question of growth in children with ADHD who received and those who did not receive psychostimulants. The PATS study53 is described in the MPH section of KQ1, and the MTA study78 in the combined interventions section of KQ2. Both studies document decreased growth rates for children receiving MPH over 12 months to 3 years.53,78

#### Cardiac Events

Rates of hospital admission for cardiac reasons are similar between those with ADHD who use psychostimulants and rates in the general population. Rates of emergency department use were 20 percent higher for those with ADHD who use stimulant medication compared ADHD patients who do not.148 Rates were comparable among those using MPH and amphetamines. Use of concurrent bronchodilators, antidepressants, or antipsychotics, age 15 to 20 years, and a history of cardiac problems were associated with increased use of emergency departments.149 ECG changes that were judged to be clinically significant, including reports of significant bradycardia, junctional escape complexes, and intraventricular delay occurred in one percent of participants treated with GXR.

#### Cerebrovascular Events

Groups prescribed ATX and psychostimulants had similar rates of incidents of CVAs or TIAs. However, the combined ADHD medication cohort exhibited a higher hazard ratio (HR) (3.44, 95% CI, 1.13 to 10.60 ) for TIAs compared with the general population after adjusting for baseline risk factors. A similar pattern was not observed for CVAs. These results do not support an increased risk of cerebrovascular events for users of ATX over psychostimulants. However, users of ADHD medications may be at higher risk of TIAs than the general population.150

### Psychostimulant Medication Compared With Combination of Psychostimulant Medication and Psychosocial and/or Behavioral Treatment

The studies examining combined PBT and school or daycare interventions for children with ADHD suggest that adding classroom teacher consultation may be of greater importance for children in low SES communities, rather than for families with educated parents who live in communities with resources.27,122,143 As a group, these studies offered some information about the benefits of PBT over a full school year, but also documented that many disadvantaged families do not attend PBT sessions even when transportation and babysitting are available.27 When parents attend, children benefit.40 One recent German study offered quality evidence about combining teacher behavior training and direct child training with and without PBT.40 Synergies among some, but not all, aspects of the program were noted, and some benefits lasted a year beyond discontinuation of the intervention program. Additional studies of this type will confirm the best means of offering interventions, as well as which children to target.

Three cohorts were identified that examined stimulant medication and/or combined medication and psychosocial or behavioral treatment. One of these was a study in China,77 and two were in North America,73,74,160,171 including the followup cohort extension study of the Multimodal treatment (MTA) study of ADHD, the largest RCT to date examining combinations of interventions.73 The results from these three cohorts indicate that both psychostimulants and combined psychostimulants and behavioral treatment are effective in treating ADHD plus ODD symptoms in children, and also anxiety, primarily boys ages 7 to 9 years of normal intelligence with combined type of ADHD, especially during the first 2 years of treatment. Overall, the MTA study suggests that combined therapy may have a slight advantage over medication management during the first 14 months, and a clear advantage over behavior treatment,72,165 especially for children with multiple comorbidities.80 However, combined treatment is equivalent to medication alone in controlling ADHD and ODD symptoms for up to 2 years if the child shows an early favorable response to medication.76 The MTA study also suggests that these two strategies may be superior to psychosocial/behavioral treatment alone or community care during the first 2 years,73,74,169 although psychosocial/behavioral treatment is equally effective as treatments with psychostimulants for ADHD children with comorbid anxiety disorder during the first 14 months.80 Combination therapy and medication management are effective in reducing ODD during the first 2 years of treatment,75 and superior to psychosocial/behavioral treatment and Community Care.73,74 It appears that psychosocial/behavioral treatment reduces the risk of substance use for 10 months following the intervention, but the effect appears to disappear by 22 months.83 However a re-analysis of the data adjusting outcome for age, suggested that the reduced risk for substance use following behavioral intervention was maintained at 3 years. These results were formally presented, but not published (Molina, October 2010). No treatment strategy is clearly superior in reducing other comorbid psychiatric disorders at 14 months or 3 years.81,168

Combining medication with psychosocial/behavioral treatment may reduce the dose of medication required, improve retention of patients in treatment, and improve positive parenting. So, et al., in a study involving Chinese children, set the mean daily dose of stimulant medication to less than half that used in the MTA study, and many fewer families who were offered medication alone continued in care.77 However, there may be genetic and cultural differences between samples studied that make direct comparison with children in North America complex. Abikoff ‘s 2004 study suggests that it may be cost-effective to treat stimulant-responsive children free of learning and conduct problems with medication alone, although families in both groups had frequent contact with clinicians.76 Treatment with psychostimulants, intensive behavioral treatment or combination of the two can reduce negative parenting, but combined treatment may be the most effective in improving positive parenting.89,161–163 Too few long-term studies examining combinations of medication management and psychosocial/behavioral interventions are available to clarify what subgroups of children do best with which interventions. For some subgroups, multiple interventions are synergistic, but perhaps not for all. Synergies may result in improved effectiveness due to increased treatment adherence, continuity of care, and proactive approaches to new onset of mental health concerns over extended periods of time.

Using intention to treat analyses, the MTA study suggests a loss of superiority of any individual intervention 2 years after treatment has ended.160 However, secondary analyses such as mixed effects models, propensity score analysis, and growth mixture model analysis have provided additional findings. These secondary studies document that most children with ADHD receiving any of the interventions generally maintained improvement for up to 8 years, while a small proportion began to worsen after the interventions discontinued. On the other hand, while most of the children experienced improved symptoms and functioning, they did not reach levels of functioning comparable to their nonclinical community peers.82

We also examined longitudinal cohort studies that followed children for multiple years following initial treatment. The outcomes and time frames varied extensively across studies. Biederman, et al.,86 and Wilens, et al.,181 studied an exclusively female cohort, and all others studied an exclusively or predominantly male sample. Although any conclusions can only be seen as preliminary, it appears that stimulant medication might protect against psychiatric disorders (e.g., ODD, CD, depression, anxiety disorder) at 10 years. Some studies suggest that stimulant medication reduces substance use disorders in late adolescence or adulthood,87,88,181 while one paper reported no benefit.179 Two studies suggested that stimulant medication may protect against nicotine use.176,181 Treatment with stimulant medication, especially at an early age, may delay the onset of smoking and reduce substance use disorder.88,177,180 Given the challenges inherent in pursuing long-term outcomes studies, with lack of ability to control for co-interventions and significant life events, such information can only be seen as hypothesis generating.

We found three reports on two cohorts that examined academic achievement as the primary outcome following classroom-based interventions. Other studies reported on academic outcome as one of multiple secondary outcome measures. The review of the academic outcomes with long-term followup of treatment interventions revealed benefits, albeit limited, with medication interventions in some aspects of reading and arithmetical skills.86,174,288 Combining psychobehavioral and academic skills interventions with medication offers no additional gains than medication alone, at least for children with ADHD without comorbid learning disabilities. Interventions for academic skills in classroom-based programs result in academic enhancement, but the findings support the need for sustained intervention to improve academic functioning over time.91,92,175

## Key Question 3 How do (a) underlying prevalence of ADHD, and (b) rates of diagnosis (clinical identification) and treatment for ADHD vary by geography, time period, provider type, and sociodemographic characteristics?

According to a recent comprehensive systematic review and metaregression analysis that encompassed studies from all areas of the world, the worldwide pooled prevalence estimate of ADHD among those 18 years of age or younger is 5.29 percent (95% CI, 5.01 to 5.56).93 A significant amount of variability was noted in the comparison of prevalence estimates across world regions and results seemed to indicate that once methodological differences of studies were controlled for, geographic location explained very little of the variability.93 In fact, after this step, only significant differences were detected between studies carried out in North America, Africa, and the Middle East.93 The requirement of impairment for the diagnosis, diagnostic criteria, and source of information were the main sources of variability in the pooled prevalence estimate of ADHD.93

Most studies show that more boys than girls have ADHD, and children in the age group 5 to 10 years show the highest prevalence. In addition, some studies suggest that children from lower socioeconomic status (SES) demonstrate higher levels of symptoms. Research detailing prevalence in other age groups worldwide is generally lacking, with few studies examining prevalence among preschoolers, adolescents, or adults. These are age groups where diagnostic consensus is less clear, making the task of identifying cases difficult. There is a general lack of uniform protocol for eliciting information about prevalence, including research choices about informants, measurement instruments, and definition of cases across geographic areas.

Despite the inherent difficulties with case identification on a community-wide basis, information about clinical identification and treatment available through epidemiological surveys, administrative claims, and prescription data converge to document that the pharmacological use of psychostimulants for ADHD increased throughout the early to mid 1990s, and use of medications for ADHD continues to increase through the 2000s in the United States.94–96 Changing patterns of ADHD medication use suggest increases among girls and adolescents. While at a much lower rate of use, medication use has also increased among preschoolers and adults. Agents prescribed have changed from short-acting preparations of stimulants to long-acting formulations.98 Similarly, in Canada and in Europe psychostimulant use for children with ADHD increased throughout the 1990s and early 2000s; however, levels of ADHD medication use are three to four times higher in the United States than in the Netherlands or in Germany.98,103 In general, more boys than girls are treated and in the United States, more Caucasians than Hispanic or African-Americans have medication dispensed once they are diagnosed.101,102 There are geographic disparities among service use in the United States as well, with more children in the midwest and south receiving psychostimulants relative to the west, and more children in urban rather than rural centers.213 In addition, children living in more affluent communities are more likely to receive psychostimulants.99 Both characteristics of service providers and access to health insurance influence clinical identification and subsequent treatment. Patterns of medication use suggest poor adherence and inconsistent use.105 Fewer teens than younger children, and fewer Caucasians than persons from minority groups, used medication over an extended period of time.106

## Limitations

Since the AHRQ review of long-term intervention studies for ADHD, published in 1997, researchers have sought opportunities to discover what has happened to the participants of earlier studies, and begun to tackle the challenges of prospective cohort studies. The primary weaknesses reflected in the literature relate to these challenges. Overall, data were difficult to compare due to lack of clarity with regard to uniformity of assessment and reporting, as well as inconsistencies in study design and the development of objective outcomes.

### Preschool Interventions

While the overall evidence for preschool interventions is strongest for PBT for disruptive behavior including ADHD, very few RCTs offer information about PBT interventions designed specifically for preschoolers with ADHD. Despite this, seven of the eight PBT intervention studies documented improvement in ADHD symptoms. We chose to emphasize similarities among manualized PBT programs, although differences are also noted. Further research will be required to document whether the programs as currently running are successful in addressing aspects of functional impairment due to ADHD symptoms. Although short-term trials show the efficacy of PBT, evidence for lasting benefits are less robust. While it appears that PBT benefits may last several years, no extension study included untreated comparison groups, and attrition over the followup period ranged from 24 percent at 18 months26 to 54 percent at 3 to 6 years,21,29 limiting interpretation of the results.

Investigations of psychostimulant medication use in preschoolers are generally short-term trials with very small samples. The PATS study addresses a number of important methodological and clinical concerns, examining the potential additional benefit of medication following a series of 10 PBT sessions. Careful attention to details regarding adverse events and the impact of these on medication adherence offers clear information about long-term effectiveness and safety. Interestingly, clinicians documented improved global functioning concurrently with parents noting increased mood problems.51 While parent and teacher ADHD symptom scales measuring dysfunction noted improvement, those measuring strengths as well as weaknesses in behavior showed no overall behavioral benefit from the addition of stimulant medication. The PATS study offers information about both the potential benefits and limitations of stimulant medication use in young children. Limitations are: 1) younger children experience more dose related adverse events than older children, 2) stimulants interfere with rates of growth, and 3) not all parents agree with ongoing use following medication titration.7,53,54 Also, the presence of three or more comorbid conditions interfered with the effectiveness of psychostimulant medication following PBT.52 Only 54 percent of those initially enrolled in the study opted to enter the medication titration component following PBT, suggesting that parent preferences play an important role in providing optimum care for young children with ADHD.

Future work should examine the appropriate place of PBT as a specific intervention for ADHD in preschoolers. A focus of such studies should include different SES and ethnocultural groups, as well as the presence of comorbid conditions in the children. Adverse events are not discussed in reports of PBT trials or teacher training/classroom intervention trials. Outcomes examined should include global functioning and school readiness as well as behavior symptom counts. Specific attention to the circumstances surrounding parental reluctance to engage in treatment or parent attrition from PBT is warranted as that appears to be a primary barrier to success. Additional awareness and understanding of parent preferences may be especially important in this age group.

### Extended Studies

Studies conducted over long periods of time face challenges in controlling for many confounders which may affect the outcomes studied. Several of these longer-term studies either did not enroll representatives from lower SES at risk for psychosocial adversity or those who were less able to be contacted for followup. Some studies did not systematically collect or report important confounders, such as socioeconomic demographics, family psychiatric history, childhood abuse, adherence to treatment, or co-interventions. The retrospective studies face problems with recall and documentation bias, both of which prospective longitudinal studies face as well if the time intervals between data collection are lengthy. An important challenge is the documentation of treatment adherence and co-interventions, both formal and informal, which affect treatment outcomes.

A considerable limitation to evaluating academic outcomes following interventions is that classroom-based or teacher consultation-based interventions are by nature difficult to investigate, as it can be challenging to coordinate cross-sector research and to develop informative comparison interventions that are ethically acceptable. In addition, few of the studies reviewed controlled for learning disabilities and IQ, important confounding factors for academic outcomes in an ADHD population. Additional aspects to consider in future studies will be the challenges inherent in coordinating and tracking the co-interventions offered in school settings along with those offered in health care settings.

The most commonly studied population in the extended interventions studies were children, primarily boys, ages 7 to -9 years, with ADHD-C at the time of documented treatment. It is not clear whether the same intervention outcomes apply to community samples across different geographical regions, cultures, and to both genders, other ADHD subtypes, and different age groups. In addition, for the most rigorous studies, there was no comparison group of children with untreated ADHD, as this would be an ethical challenge. It is therefore difficult to be fully confident that the improvements seen over time were due to treatment effects rather than subsequent co-interventions, maturation or other unmeasured effects.

A major gap in the available literature is the lack of clinical trials and extensions of clinical trials examining non-pharmacological interventions targeting the functional impairment associated with ADHD symptoms in a variety of sample populations.

### Prevalence and Health Services Studies

Determining prevalence of ADHD across all age categories in the population is necessary to understand the burden that the condition poses. From this, we can identify gaps in service and develop responses which will help patients and their families in the shorter-term and allow patients to meet their potential in all areas of their lives, such as maintaining fulfilling relationships and finding success in school and workplace environments. There are several methodological factors that influence the calculation of prevalence estimates – namely, the diagnostic criteria employed, along with the informant type, and the data source.289 As described by a recent systematic review/meta regression of the worldwide prevalence of ADHD,93 key methodological differences between studies accounted for much of the variability in the pooled prevalence estimate, highlighting the need for a standardized, methodological approach in order to improve comparability of estimates and epidemiological trends reported over time and in different geographical areas.

To date, the prevalence of ADHD among both adolescents and adults is not well delineated in the literature. Adolescents tend to be subsumed under children, though the burden in this age group may well be different and/or incorrectly approximated by current diagnostic methods. It is also unclear whether the diagnostic criteria are appropriate for use with adults. University-aged individuals with ADHD may be worth examining further, as a special group. Other special populations that warrant further interest include diverse cultural groups and/or ethnic minorities, and other vulnerable groups such as immigrants and families of low SES.

To develop an understanding of who is identified and treated for ADHD in community practice, the types of data used most frequently were epidemiologic surveys and administrative claims and prescription databases. The first type of data is limited to relatively smaller numbers of volunteers, although specific research questions about risk and protective factors can be asked.

The administrative claims database is limited in the sense that it represents only services reimbursed whereas the prescription database takes into account only those who use prescription medication. Nevertheless, each provides a depiction of what happens in community practice, identifying enrollee characteristics as well as clinician diagnosis and treatment plans, or in the case of prescription databases, dispensed medication. Similar to epidemiology studies for prevalence, issues of case identification, informant, quality of interventions, and outcome measures limit interpretations of the results. For the purposes of understanding who is receiving what kind of treatment, a significant shortcoming of the current literature is the lack of information on other forms of treatment for ADHD besides the use of psychostimulants or other medications. This renders the task of capturing all aspects of treatment use difficult. In addition to addressing this gap, more attention should be paid to uncovering whether or not certain groups (e.g., those of lower SES, ethnic minorities, children in foster care, or those living in more isolated or rural areas) are being under-recognized and/or under treated for ADHD.

Some of the potential vulnerable groups appear to be identified and prescribed medication, if not actually treated, to a greater degree than the norm. Overall, the rates of identification and treatment with ADHD medications is high in the United States relative to other areas globally, and higher in some regions of the United States than others, raising issues about the possibility that some practitioners are identifying too many children and youth, while others may be identifying too few. Evidence suggests that it is not only characteristics of the patients but also characteristics of the providers that influences rates of diagnosis and medication treatment. Patterns suggest that cultural biases exist suggesting that increased information about patient preferences could improve the match between what interventions are offered and what treatments are accepted. As it currently stands, many sufferers may be identified, but a large proportion of those in need do not utilize the treatments offered, even if they can be accessed.