# Conclusions and Recommendations for Future Research

## Key Question 1 Treatment in Children <6 Years of Age

The evidence available for interventions in preschoolers with Disruptive Behavior Disorders (DBD) is difficult to interpret given the difficulty in diagnosing children this young, since normal maturational processes moderate behavioral responses; however it supports the use of parent behavior training (PBT) as an effective intervention both for oppositional behaviors and for Attention Deficit Hyperactivity Disorder (ADHD) symptoms where measured, with no adverse events reported. The largest barrier to successful completion of the intervention is parent attrition. Preliminary efforts to examine modes of service delivery to accommodate parent preferences suggest such adjustments do not interfere with its effectiveness as long as the program is delivered as designed. For preschoolers, psychostimulant medications are also generally safe and efficacious for improving behavior and can provide benefits in addition to PBT, although essentially nothing is known about possible long-term effects of treatment of preschool children with these or other psychoactive medications. As well, adverse events, especially irritability and moodiness, can lead to discontinuation over extended periods of time, and the use of these medications for several months to a year impacts growth rate to a small degree. The addition of school-based interventions to PBT appears to be more useful for disadvantaged populations, although benefits diminish following discontinuation of the intervention.

Areas for future research:

- Investigations of parent preferences regarding behavior training are needed to determine if parent completion rates for training can be improved.
- Some studies adjusted the PBT to address ADHD specifically, but other interventions also showed improvement in measured ADHD symptoms without adjustment. Evaluation is required regarding the need for specific adjustments to assist children with ADHD.
- Further investigation is required of the role of psychoeducation interventions in the continuum of ADHD care, as this may be a cost-effective intervention option. One study found that a structured parent education program offered the same benefits as combined PBT and school consultation for middle income families.
- The role of teacher consultation or classroom interventions deserves additional evaluation in the context of across-sector research combining health care and education interventions for preschool children at high risk of ADHD.
- The development of methods to investigate long-term outcomes of preschool interventions including appropriate comparison groups is required.
- The optimal circumstances for adding medication in the treatment for preschool children with ADHD, including which subgroups, for how long, and in conjunction with what additional interventions.
- More research on the effects and effectiveness of medication is needed in the younger age groups who are now receiving treatment in increasing numbers.
- This review did not examine alternative interventions such as dietary manipulations, however, the examination of elimination diets, addition of supplements, and awareness of micronutrients for neurological and behavioral functioning in young children is an important area of potential research that is garnering attention in Europe. The implications for the use of appetite suppressing medications merits serious study

## Key Question 2 Long-Term (>1 Year) Outcomes

The long-term effectiveness and safety of several psychostimulants, atomoxetine (ATX) and guanfacine XR (GXR) have been examined prospectively in children and adolescents over the age of 6 years. All of these agents appear efficacious in properly identified populations for the control of core symptoms of ADHD, such as inattention and overactivity for up to 12 months. Fewer individuals discontinue psychostimulants and ATX than GXR due to adverse events. Placebo-controlled discontinuation trials are few, with one in children receiving an amphetamine, and two others after 1 year and again after 2 years of use in children receiving ATX. These trials suggest that some individuals continue to benefit, and others no longer benefit, following 12, 15 or 24 months of continuous treatment with medication. Longer followup of cohorts would be useful, as they offer information about how likely it is that individuals will continue to derive benefit from the ongoing use of medication.

Ongoing examination of adverse events for persons using medications for ADHD throughout the lifespan is certainly still warranted. Evidence now suggests that some children experience mild growth decrements while on psychostimulants for long periods of time. While these are considered of little clinical significance, it is not clear if these changes may represent potential nutritional or developmental concerns that are not yet recognized. Examination of adverse event profiles in the extension of pharmacology studies suggests that while cardiovascular concerns remain rare, use of GXR may require greater monitoring than psychostimulants or ATX. On a broader scale, health administrative data suggest that neither cardiac events among those 20 years of age and younger, nor cerebrovascular accidents in adults are more frequent among those using medications for ADHD than for persons in the general population. Further examination in appropriate data sources is warranted, however, as adult users of psychostimulants or ATX may be at increased risk of transient ischemic attacks.

Evaluation of long-term outcomes following interventions for ADHD is complex due to the multiple patterns of services used. The best data are available through the 8-year followup of the MTA study.73,74,81,82 By 3 years after initiation, no single intervention group showed superior benefit, likely due to individuals obtaining a complex range of interventions in the community. The majority of children who received an intervention were maintaining improvements in functioning, although they were not improved enough to match nonclinical comparison groups. A small proportion returned to previous levels of poor functioning over time. There was no clear relationship identified between duration of medication use and outcomes. Other cohort studies suggest that long-term use of medication improves grade retention and academic achievement,85,86 and may lessen onset of Oppositional Defiant Disorder (ODD), Conduct Disorder (CD), as well as substance use, anxiety, and depressive disorders.

Areas for future research:

- Extension studies of pharmacological agents that include placebo-controlled relapse prevention trials are needed, as these offer information about whether or which individuals may gradually discontinue use of medication.
- Direct head-to-head comparison of psychostimulants and ATX or alpha agonists over extended periods of time are not yet available.
- Pharmacy data show that combinations of stimulants and ATX or alpha agonists occur with some regularity. Examination of the relative safety and effectiveness of combined agents requires systematic study in clinical populations.
- Interventions in subgroups not commonly investigated to this point in time are needed, specifically individuals with primarily inattentive subtype of ADHD, girls, teenagers, university students, and adults. Other groups of interest are those with psychiatric comorbidities, and different racial or ethnic groups, or low socioeconomic circumstances.
- Little specific information is available regarding outcomes for those with comorbid learning disabilities, language impairments, reading, mathematics disorders, or other comorbidities.
- The definition of interventions as “psychosocial and/or behavioral” is highly inclusive and based on the intensive intervention used in the MTA study that included PBT, a summer behavior treatment program for the child, and consultation with the school teacher following the summer intervention. The individual aspects of this program require “unpacking” and matching to the subgroups of ADHD and comorbid conditions, as well as sociodemographic groups that the data suggested would most likely benefit. Evaluation of the separate components of the interventions will optimize the match between what the child needs and what intervention he/she receives.
- Understanding the role of academic interventions or combined medication and academic interventions with an emphasis on long-term academic outcomes is important, as maximizing educational success is often an important long-term treatment goal. Examining the impact of educational interventions in subgroups of ADHD children and teens with identified learning disorders is important.
- The use of standardized outcome measures such as global impairment scales or quality of life scales would be useful to compare study outcomes from different cohorts.
- The use of more objective outcomes, such as reduced criminal or court-related events, fewer days of psychiatric hospitalizations or number of hospitalizations, and improved academic performance would be helpful.
- The challenges of lengthy studies are many, and effective studies must include systematic data collection, retention of participants, and identification of appropriate comparison groups.
- Rigorous observational (cohort) research methods, including registries, require further development through efficient data collection (e.g., from Electronic Medical Records enhanced by collection of reliable information of satisfaction, persistence, and proximal and distal outcomes).
- Properly designed case-control studies may be a feasible approach for identifying rarer and/or longer term outcomes.

## Key Question 3 Prevalence and Variations in Diagnosis and Treatment

A systematic review and meta-regression placed the worldwide pooled prevalence estimate of ADHD among those 18 years of age or younger at 5.29 percent,93 with more boys than girls identified and the highest rates of disorder occurring in the 5 to 10 year age group. Primary sources of variability were identified as methodological rather than geographic, and included differences in the requirements for impairment, diagnostic criteria, and sources of information. Fewer studies are available that document prevalence in adult, adolescent, or preschool age groups, which likely reflects a lack of clarity regarding current diagnostic criteria in these groups. Information about clinical identification and treatment available through administrative and prescription data and health surveys documents that psychostimulant use for ADHD increased throughout the 1980s and early to mid 1990s in the United States. Nonpharmacologic interventions are not documented in these sources. Disparities are noted, with more boys than girls treated, and more Caucasians than Hispanic or African-Americans receiving medication treatment once diagnosed. Rates of identification and treatment also vary geographically. For direct geographic or time period comparisons to be informative, data sources and methods of identifying cases and documenting interventions should be comparable.

In pursuing this question describing rates of clinical identification and of treatment, we identified that no standardized methods are readily available to compare the quality of the research studies with each other. Existing tools designed for other categories of studies (e.g., clinical trials) are not appropriate for evaluating studies using existing administrative data as some of the underlying assumptions behind the research differ. Population-based data were relatively scarce and lacked uniform methods and settings, which interfered with interpretation. The evidence available suggests that underlying prevalence of ADHD varies less than rates of diagnosis and treatment. Patterns of diagnosis and treatment appeared to be associated with such factors as locale, time period, and patient or provider characteristics.

Areas for future research:

- Prevalence data regarding ADHD in subpopulations of adolescents, and adults should be included. In some areas of the world, information about ADHD prevalence among university students is needed. Other special populations to consider are those with developmental disorders, in foster care, or those who have been incarcerated.
- Standardized methods of data collection, case identification and outcomes measurement in epidemiologic surveys and administrative databases is required.
- There is a need for more research on patterns of service use in order to improve our understanding of health system, educational system, health insurance, provider, family and child factors that influence the distribution, access, and receipt of treatment for ADHD.
- Cross-sector coordination of health services, mental health services, and education databases is especially required in the area of ADHD.
- Development of a method for evaluating and comparing the internal validity of studies using administrative data is an important goal that will improve the methods of research in this area.
- More comprehensive ongoing surveillance and population-based surveys will improve the pertinence and quality of available data.

## Implications for Clinical Practice and Policy

The three questions addressed in this review target distinctly different aspects of identification and treatment of ADHD. The specific questions about the clinical effectiveness and safety of preschool interventions, extended interventions, and longer-term outcomes across the lifespan, and variations in diagnosis and treatment all inform the broad picture of evolving management practices concerning ADHD. Increasing reliance on medications to treat large numbers of young children, youth, and adults, with a limited body of rigorous evidence as to efficacy or effectiveness, highlights the need for understanding the implications for individual patients across their lifespan. The United States leads globally in rates of diagnosis and medication treatment of ADHD, which also shapes this discourse. Sociocultural factors, parent and youth beliefs about ADHD, and attitudes about its treatment, as well as individual experiences with the interventions have a strong impact on patterns of treatment adherence in clinical practice.

There is one primary implication from the review of interventions for preschoolers at risk of ADHD: the first line intervention for young children is evidence-based PBT. Other interventions may also be effective, but further research is required before definitive recommendations can be made. Combinations of teacher and child behavioral training and classroom-based programs are promising, in some subgroups more than others. Stimulant medication for ADHD symptoms also plays a role. Awareness of physiologic adverse effects is important, especially as children show decrements in growth when using the medications. Adverse effects of behavior training have not been identified, although lack of parental engagement appears to be the most important barrier to receiving care.

A review of long-term outcomes of interventions primarily identifies the ongoing need for more information that will inform practice. The majority of detailed information reflects clinical trials for pharmacological agents. The large picture remains that receipt of quality interventions confers benefit for many children with ADHD, but that functional impairment continues, albeit to a lesser degree. Psychostimulant medications as a single intervention that is carefully monitored are helpful, primarily for boys ages 7 to 9 at diagnosis of ADHD Combined type (ADHD-C), with or without ODD, who do not have additional comorbid conditions, including learning disorders. This statement leaves out a wide range of other children, teens, and adults with ADHD. Combinations of psychosocial/behavioral interventions with stimulant medications appear to confer benefits for a wider array of children, enhancing acceptance and adherence to treatment, improving parent-child relationships, and potentially decreasing the rate of early adolescent substance use. Some, but not all, studies suggest that following the discontinuation of interventions, a small portion of the children may return to previous levels of functional impairment, eliminating the gains made. Therefore, acknowledging the chronic nature of the condition and the need for ongoing monitoring, resources, and supports of various kinds is important for clinical care.

The broad review of health services information largely reflects information from the United States. The overall picture in the United States is one where diagnoses of ADHD may be offered too frequently, since the rate is higher than the estimates based on epidemiological studies that include both symptoms and impairment. Intertwined with this observation is that ADHD medications are increasingly prescribed, but many individuals discontinue them following a brief trial. Increasing rates of prescription may be due in part to the possibility that children and youth are identified in order to justify a trial of medication, even while there is increasing recognition that populations such as girls, teens and adults not previously identified and treated appears to be an important trend.

It is also important that a better understanding of patients’ and families’ decisions not to use medication once prescribed be reached. It is possible that other types of interventions should be considered before medication, depending on patient preferences, and pattern of comorbidities. The increasing use of off-label prescriptions for very young children is concerning, especially as PBT is effective for the disruptive behavior which is often the primary impairment when ADHD occurs in preschoolers. However, access to evidence-based PBT programs may be limited in some regions leading to increased reliance on medications. Certainly, the use of PBT is not identified in the administrative data sources used to examine community care for ADHD.

Over the past two decades, the pharmaceutical industry has responded to the initial evidence that psychostimulants are helpful for children and youth with ADHD and developed improved preparations with sustained effectiveness and improved adverse effect profiles. Many who accept medication have benefited from these agents. However, evidence is slowly accruing that some subgroups require and many patients prefer a range of approaches which are appropriate to the patient’s age and level of development, as well as culturally sensitive to the family, including educational and nonpharmacological interventions, often in combination with medications. The evidence for other interventions requires further development before substantive recommendations can be offered.