# Strength of Evidence/Grading Tables

Table SOE1 Strength of evidence: ADHD interventions for children younger than 6 years of age: behavioral change after intervention

Number of Studies (Subjects) | Domains Pertaining to Strength of Evidence | | | | Strength of Evidence (SOE)
| Risk of Bias; Design/Quality | Consistency | Directness | Precision | Strength of Evidence (SOE) | Harms
Parent behavior training – immediately post-intervention – data from strongest studies only | | | | | Strong SOE
8(421) | RCT/Low risk | Consistent | Direct | Precise | SMD = −0.86 [−1.07, −0.65] | Not reported
Bagner 2007; Bor 2002; Hutchings 2007; Markie-Dadds 2006; Nixon 2001; Pisterman 1992, Sonuga-Barke 2001; Thompson 2008
Parent behavior training - extension | | | | | Insufficient SOE
Insufficient data
Pharmacological | | | | | Low SOE
1 (114) | RCT/Low risk | Consistent | Direct | Precise | SMD = −0.83 [−1.21, −0.44] | Reviewed separately
PATS 2007
Multi-component – non-pharmacological | | | | | Insufficient SOE
Insufficient data
Multi-component including pharmacological | | | | | Insufficient SOE
Insufficient data
Pharmacological ADVERSE EVENTS – Growth, G/I, Behavioral | | | | | Insufficient SOE
Insufficient data

Table SOE2 Strength of evidence: Long-term ADHD interventions for people 6 years of age or older

Number of Studies (Subjects) | Domains Pertaining to Strength of Evidence | | | | Strength of Evidence (SOE)
| Risk of Bias; Design/Quality | Consistency | Directness | Precision | Strength of Evidence (SOE)
Parent behavior training | | | | | Insufficient SOE
Insufficient data
Behavioral/Psychosocial | | | | | Insufficient SOE
Insufficient data
Academic Interventions (non-Pharmacological) | | | | | Insufficient SOE
Combined | | | | | Low SOE
1(263) | RCT/Low risk | Consistent | Direct | Precise | SMD = −.070 [−0.95, −0.46]
MTA 1999
Pharmacological - Effectiveness | | | | | Low SOE
1(251) | RCT/Low risk | Consistent | Direct | Precise | MPH: SMD = −0.54 [−0.79, −0.29] ATX: SMD = −0.40 [−0.61, −0.18]
MTA 1999
Pharmacological extension studies. Risk of withdrawing before end of study period (1.5 to 3 yrs) | | | | | Insufficient SOE
Insufficient data
Long Term Use of Psychostimulants – Adverse Events - Specific
Growth | | | | | Insufficient SOE
Insufficient data
Cardiac | | | | | Insufficient SOE
Insufficient data
Cerebrovascular | | | | | Insufficient SOE
Insufficient data
Tic | | | | | Insufficient SOE
Insufficient data
Long Term Use of Psychostimulants – Potential benefits
Academic | | | | | Insufficient SOE
Insufficient data
Smoking | | | | | Insufficient SOE
Insufficient data
Substance Use Disorder | | | | | Insufficient SOE
Insufficient data
Criminality | | | | | Insufficient SOE
Insufficient data
Psychiatric | | | | | Insufficient SOE
Insufficient data
Emergency Room Usage | | | | | Insufficient SOE
Insufficient data