# Excluded Studies

Evaluation of the first 3 years of the Fast Track prevention trial with children at high risk for adolescent conduct problems. J Abnorm Child Psychol. 2002;30(1):19-35. [pmid: 11930969]. Exclude: No included comparisons of outcomes, OVID-Medline.
Alternative treatments for attention deficit hyperactivity disorder. Paediatr Child Health. 2003;(4):243-6. Exclude: Not an included population, OVID-EMBASE. [pmid: 20020005].
The effects of the Fast Track Program on serious problem outcomes at the end of elementary school. J Clin Child Adolesc Psychol. 2004;33(4):650-61. Exclude: Not an included population, OVID-PsycINFO. [pmid: 15498733].
Aarskog D, Fevang FO, Klove H, et al. The effect of the stimulant drugs, dextroamphetamine and methylphenidate, on secretion of growth hormone in hyperactive children. J Pediatr. 1977;90(1):136-9. Exclude: No included comparisons of outcomes,. [pmid: 318680].
Abikoff H, Gittelman R. Does behavior therapy normalize the classroom behavior of hyperactive children. Arch Gen Psychiatry. 1984;(5):449-54. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6721670].
Abikoff H, Gittelman R. The normalizing effects of methylphenidate on the classroom behavior of ADDH children. J Abnorm Child Psychol. 1985;(1):33-44. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3973251].
Abramson PR, Abramson SD. A fractorial study of a multidimensional approach to aggressive behavior in black preschool age children. J Genet Psychol. 1974;125(1st Half):31-6. [pmid: 4457611]. Exclude: Not an included population, OVID-Medline.
Ackerman PT, Dykman RA, Holcomb PJ, et al. Methylphenidate effects on cognitive style and reaction time in four groups of children. Psychiatry Res. 1982;7(2):199-213. Exclude: No included comparisons of outcomes,. [pmid: 6959170].
Ackerman PT, Dykman RA, Holcomb PJ, et al. Effects of high and low dosages of methylphenidate in children with strong and sensitive nervous systems. Pavlovian J Biol Sci. 1983;(1):36-48. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Ackerman PT, Holcomb PJ, Dykman RA. Effects of reward and methylphenidate on heart rate response morphology of augmenting and reducing children. Int J Psychophysiol. 1984;1(4):301-16. Exclude: No included comparisons of outcomes,. [pmid: 6542082].
Ad-Dab’bagh Y, Greenfield B, Milne-Smith J, et al. Inpatient treatment of severe disruptive behavior disorders with risperidone and milieu therapy. Can J Psychiatr. 2000;45(4):376-82. [pmid: 10813072]. Exclude: No included comparisons of outcomes, OVID-Medline.
Adams D, Allen D. Assessing the need for reactive behavior management strategies in children with intellectual disability and severe challenging behavior. J Intell Disabil Res. 2001;(4):335-43. Exclude: No included intervention compared, OVID-EMBASE.
Adler L, Dietrich A, Reimherr FW, et al. Safety and tolerability of once versus twice daily atomoxetine in adults with ADHD. Ann Clin Psychiatry. 2006;18(2):107-13. [pmid: 16754416]. Exclude: No included comparisons of outcomes, OVID-Medline.
Adler L, Wilens T, Zhang S, et al. Retrospective safety analysis of atomoxetine in adult ADHD patients with or without comorbid alcohol abuse and dependence. Am J Addict. 2009;18(5):393-401. [pmid: 19874159]. Exclude: No included comparisons of outcomes, OVID-Medline.
Agarwala S. Behavior modification in nursery school children. Dayalbagh Educ Inst Res J Educ. 1985;3(1):30-3. Exclude: Not able to retrieve full report, OVID-PsycINFO.
Ahmann PA, Waltonen SJ, Olson KA, et al. Placebo-controlled evaluation of Ritalin side effects. Pediatrics. 1993;91(6):1101-6. [pmid: 8502509]. Exclude: No included comparisons of outcomes, OVID-Medline.
Ahmann PA, Theye FW, Berg R, et al. Placebo-controlled evaluation of amphetamine mixture-dextroamphetamine salts and amphetamine salts (Adderall): efficacy rate and side effects. Pediatrics. 2001;107(1):E10. [pmid: 11134474]. Exclude: No included comparisons of outcomes, OVID-Medline.
Aird RB, Yamamoto T. Behavior disorders of childhood. Electroencephalogr Clin Neurophysiol. 1966;21(2):148-56. [pmid: 4162007]. Exclude: Not an included population, OVID-Medline.
Akhondzadeh S, Tavakolian R, Davari-Ashtiani R, et al. Selegiline in the treatment of attention deficit hyperactivity disorder in children: a double blind and randomized trial. Prog Neuropsychopharmacol Biol Psychiatr. 2003;27(5):841-5. [pmid: 12921918]. Exclude: No included comparisons of outcomes, OVID-Medline.
Akhondzadeh S, Mohammadi MR, Khademi M. Zinc sulfate as an adjunct to methylphenidate for the treatment of attention deficit hyperactivity disorder in children: a double blind and randomized trial. BMC Psychiatr. 2004;4:9. [pmid: 15070418]. Exclude: No included comparisons of outcomes, OVID-Medline.
Alderton HR, Hoddinott BA. A controlled study of the use of thioridazine in the treatment of hyperactive and aggressive children in a children’s psychiatric hospital. Can Psychiatr Assoc J. 1964;9(3):239-47. Exclude: No included comparisons of outcomes,. [pmid: 14154307].
Alexandris A, Lundell FW. Effect of thioridazine, amphetamine and placebo on the hyperkinetic syndrome and cognitive area in mentally deficient children. Can Med Assoc J. 1968;98(2):92-6. Exclude: No included comparisons of outcomes,. [pmid: 4864657].
Alger I. Attention-deficit hyperactivity disorder; AIDS in children and adolescents. Hosp Community Psychiatr. 1989;(12):1222-3. Exclude: Not an included population, OVID-EMBASE.
Alhambra MA, Fowler TP, Alhambra AA. EEG biofeedback: A new treatment option for ADD/ADHD. J Neurother. 1995;1(2):39-43. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Allakhverdiev AR, Horunzheva Y, Kadyrova KG. Influence of functional biocontrol on brain non-specific systems in children with neurotic hyperkinesis. Hum Physiol. 1995;21(4):341-3. Exclude: Not an included population, OVID-PsycINFO.
Allen KE, Henke LB, Harris FR, et al. Control of hyperactivity by social reinforcement of attending behavior. J Educ Psychol. 1967;58(4):231-7. [pmid: 6062455]. Exclude: Not an included population, OVID-Medline.
Aman MG, Sprague RL. The state-dependent effects of methylphenidate and dextroamphetamine. J Nerv Ment Dis. 1974;158(4):268-79. [pmid: 4819605]. Exclude: No included comparisons of outcomes, OVID-Medline.
Aman MG, Werry JS. Methylphenidate in children: Effects upon cardiorespiratory function on exertion. Int J Ment Health. 1975;4(1–2):119-31. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Aman MG, Mitchell EA, Turbott SH. The effects of essential fatty acid supplementation by Efamol in hyperactive children. J Abnorm Child Psychol. 1987;(1):75-90. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3553274].
Aman MG, Marks RE, Turbott SH, et al. Clinical effects of methylphenidate and thioridazine in intellectually subaverage children. J Am Acad Child Adolesc Psychiatry. 1991;30(2):246-56. [pmid: 2016229]. Exclude: No included comparisons of outcomes, OVID-Medline.
Aman MG, Kern RA, McGhee DE, et al. Fenfluramine and methylphenidate in children with mental retardation and attention deficit hyperactivity disorder: laboratory effects. J Autism Dev Disord. 1993;23(3):491-506. Exclude: No included comparisons of outcomes,. [pmid: 8226583].
Aman MG, Kern RA, McGhee DE, et al. Fenfluramine and methylphenidate in children with mental retardation and ADHD: clinical and side effects. J Am Acad Child Adolesc Psychiatry. 1993;32(4):851-9. [pmid: 8340309]. Exclude: No included comparisons of outcomes, OVID-Medline.
Aman MG, Armstrong S, Buican B, et al. Four-year follow-up of children with low intelligence and ADHD: a replication. Res Dev Disabil. 2002;23(2):119-34. [pmid: 12061750]. Exclude: No included intervention compared, OVID-Medline.
Aman MG, De Smedt G, Derivan A, et al. Double-blind, placebo-controlled study of risperidone for the treatment of disruptive behaviors in children with subaverage intelligence. Am J Psychiatry. 2002;159(8):1337-46. [pmid: 12153826]. Exclude: No included comparisons of outcomes, OVID-Medline.
Aman MG, Hollway JA, Leone S, et al. Effects of risperidone on cognitive-motor performance and motor movements in chronically medicated children. Res Dev Disabil. 2009;30(2):386-96. [pmid: 18768293]. Exclude: No included comparisons of outcomes, OVID-Medline.
Aman MG, Marks RE, Turbott SH, et al. Methylphenidate and thioridazine in the treatment of intellectually subaverage children: Effects on cognitive-motor performance. J Am Acad Child Adolesc Psychiatry. 1991;30(5):816-24. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 1938800].
Ambrosino SV, De Fonte TM. A psychoeducational study of the hyperkinetic syndrome. Psychosomatics. 1973;14(4):207-13. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 4794850].
Amery B, Minichiello MD, Brown GL. Aggression in hyperactive boys: Response to d-amphetamine. J Am Acad Child Psychiatry. 1984;(3):291-4. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6736494].
Amon KL, Campbell A. Can children with AD/HD learn relaxation and breathing techniques through biofeedback video games. Aust J Educ Dev Psychol. 2008;8:72-84. Exclude: No included comparisons of outcomes, ERIC Database.
Anastopoulos AD, Shelton TL, Dupaul GJ, et al. Parent behavior training for attention-deficit hyperactivity disorder: Its impact on parent functioning. J Abnorm Child Psychol. 1993;(5):581-96. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 8294653].
Anderson K, Barabasz M, Barabasz A, et al. Efficacy of Barabasz’s instant alert hypnosis in the treatment of ADHD with neurotherapy. Child Stud J. 2000;30(1):51-62. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Anderson RP, Halcomb CG, Gordon W, et al. Measurement of attention distractibility in LD children. Acad Ther. 1974;9(5):261-6. Exclude: Not an included population, OVID-PsycINFO.
Angold A, Erkanli A, Egger HL, et al. Stimulant treatment for children: a community perspective. J Am Acad Child Adolesc Psychiatry. 984;39(8):975-84. [pmid: 10939226]. Exclude: No included comparisons of outcomes, OVID-Medline.
Arbuthnot J, Gordon DA. Behavioral and cognitive effects of a moral reasoning development intervention for high-risk behavior-disordered adolescents. J Consult Clin Psychol. 1986;54(2):208-16. Exclude: Not an included population. [pmid: 3700808].
Ardoin SP, Martens BK. Testing the ability of children with attention deficit hyperactivity disorder to accurately report the effects of medication on their behavior. J Appl Behav Anal. 2000;33(4):593-610. [pmid: 11214033]. Exclude: No included comparisons of outcomes, OVID-Medline.
Arnett PA, Fischer M, Newby RF. The effect of Ritalin on response to reward and punishment in children with ADHD. Child Stud J. 1996;26(1):51-70. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Arnett PA, Fischer M, Newby RF. “The effect of Ritalin on response to reward and punishment in children with ADHD”: Addendum. Child Stud J. 1996;26(2):161. Exclude: Not an included population, OVID-PsycINFO.
Arnold LE, Wender PH, McCloskey K, et al. Levoamphetamine and dextroamphetamine: comparative efficacy in the hyperkinetic syndrome. Assessment by target symptoms. Arch Gen Psychiatry. 1972;27(6):816-22. Exclude: No included comparisons of outcomes,. [pmid: 4564954].
Arnold LE, Kirilcuk V, Corson SA, et al. Levoamphetamine and dextroamphetamine: differential effect on aggression and hyperkinesis in children and dogs. Am J Psychiatry. 1973;130(2):165-70. Exclude: Not an included population. [pmid: 4568123].
Arnold LE, Abikoff HB, Cantwell DP, et al. National Institute of Mental Health collaborative multimodal treatment study of children with ADHD (the MTA). Design challenges and choices. Arch Gen Psychiatry. 1997;54(9):865-70. [pmid: 9294378]. Exclude: No included comparisons of outcomes, OVID-Medline.
Arnold LE, Pinkham SM, Votolato N. Does zinc moderate essential fatty acid and amphetamine treatment of attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2000;10(2):111-7. [pmid: 10933121]. Exclude: Not an included population, OVID-Medline.
Arnold LE, Lindsay RL, Conners CK, et al. A double-blind, placebo-controlled withdrawal trial of dexmethylphenidate hydrochloride in children with attention deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 2004;14(4):542-54. [pmid: 15662146]. Exclude: No included comparisons of outcomes, OVID-Medline.
Arnold LE, Chuang S, Davies M, et al. Nine months of multicomponent behavioral treatment for ADHD and effectiveness of MTA fading procedures. J Abnorm Child Psychol. 2004;32(1):39-51. [pmid: 14998110]. Exclude: No included comparisons of outcomes, OVID-Medline.
Arnold LE, Aman MG, Cook AM, et al. Atomoxetine for hyperactivity in autism spectrum disorders: placebo-controlled crossover pilot trial. J Am Acad Child Adolesc Psychiatry. 2006;45(10):1196-205. [pmid: 17003665]. Exclude: No included comparisons of outcomes, OVID-Medline.
Arnold LE, Amato A, Bozzolo H, et al. Acetyl-L-carnitine (ALC) in attention-deficit/hyperactivity disorder: a multi-site, placebo-controlled pilot trial. J Child Adolesc Psychopharmacol. 2007;17(6):791-802. [pmid: 18315451]. Exclude: No included comparisons of outcomes, OVID-Medline.
Arnold LE. Vestibular and visual rotational stimulation as treatment for attention deficit and hyperactivity. Am J Occup Ther. 1985;39(2):84-91. Exclude: No included intervention compared, OVID-PsycINFO. [pmid: 3872075].
Arnold LE, Huestis RD, Wemmer D, et al. Differential effect of amphetamine optical isomers on Bender Gestalt performance of the minimally brain dysfunctioned. J Learn Disabil. 1978;11(3):127-32. Exclude: Not an included population, OVID-PsycINFO. [pmid: 353207].
Arnold LE, Amato A, Bozzolo H, et al. Acetyl-L-carnitine in attention-deficit/hyperactivity disorder: A multi-site, placebo-controlled pilot trial. J Child Adolesc Psychopharmacol. 2007;17(6):791-801. Exclude: No included comparisons of outcomes,. [pmid: 18315451].
Arnold SC, Forehand R. A comparison of cognitive training and response cost procedures in modifying cognitive styles of impulsive children. Cognit Ther Res. 1979;(2):183-7. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Atkins MS, Frazier SL, Birman D, et al. School-based mental health services for children living in high poverty urban communities. Admin Pol Ment Health. 2006;33(2):146-59. [pmid: 16502132]. Exclude: Not an included population, OVID-Medline.
Augenbraun B, Reid HL, Friedman DB. Brief intervention as a preventive force in disorders of early childhood. Am J Orthopsychiatry. 1967;37(4):697-702. [pmid: 6033424]. Exclude: Not an included population, OVID-Medline.
Augimeri LK, Farrington DP, Koegl CJ, et al. The SNAPTM Under 12 Outreach Project: Effects of a community based program for children with conduct problems. J Child Fam Studies. 2007;16(6):799-807. Exclude: Not an included population,.
August GJ, Hektner JM, Egan EA, et al. The early risers longitudinal prevention trial: examination of 3-year outcomes in aggressive children with intent-to-treat and as-intended analyses. Psychol Addict Behav. 2002;16(4 Suppl):S27-39. [pmid: 12502275]. Exclude: No included comparisons of outcomes, OVID-Medline.
August GJ, Lee SS, Bloomquist ML, et al. Dissemination of an evidence-based prevention innovation for aggressive children living in culturally diverse, urban neighborhoods: the Early Risers effectiveness study. Prev Sci. 2003;4(4):271-86. [pmid: 14598999]. Exclude: No included comparisons of outcomes, OVID-Medline.
August GJ, Egan EA, Realmuto GM, et al. Four years of the early risers early-age-targeted preventive intervention: Effects on aggressive children’s peer relations. Behav Ther. 2003;(4):453-70. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Bailey V. Cognitive-behavioral therapies for children and adolescents. Adv Psychiatr Treat. 2001;(3):224-32. Exclude: Not an included population, OVID-EMBASE.
Baker-Henningham H, Walker S, Powell C, et al. A pilot study of the Incredible Years Teacher Training programme and a curriculum unit on social and emotional skills in community pre-schools in Jamaica. Child Care Health Dev. 2009;35(5):624-31. [pmid: 19320645]. Exclude: No included comparisons of outcomes, OVID-Medline.
Baker-Henningham H, Walker S. A qualitative study of teacher’s perceptions of an intervention to prevent conduct problems in Jamaican pre-schools. Child Care Health Dev. 2009;35(5):632-42. [pmid: 19689568]. Exclude: No included comparisons of outcomes, OVID-Medline.
Bakermans-Kranenburg MJ, van IJzendoorn MH, Mesman J, et al. Effects of an attachment-based intervention on daily cortisol moderated by dopamine receptor D4: a randomized control trial on 1- to 3-year-olds screened for externalizing behavior. Dev Psychopathol. 2008;20(3):805-20. [pmid: 18606032]. Exclude: No included comparisons of outcomes, OVID-Medline.
Bakken RJ, Paczkowski M, Kramer HP, et al. Effects of atomoxetine on attention-deficit/hyperactivity disorder in clinical pediatric treatment settings: a naturalistic study. Curr Med Res Opin. 2008;24(2):449-60. [pmid: 18179733]. Exclude: No included comparisons of outcomes, OVID-Medline.
Baldwin RW, Kenny TJ. Thioridazine in the management of organic behavior disturbances in children. Curr Ther Res Clin Exp. 1966;8(8):373-7. [pmid: 4958152]. Exclude: Not an included population, OVID-Medline.
Ballard JE, Boileau RA, Sleator EK, et al. Cardiovascular responses of hyperactive children to methylphenidate. JAMA. 1976;236(25):2870-4. Exclude: No included comparisons of outcomes,. [pmid: 792490].
Ballinger CT, Varley CK, Nolen PA. Effects of methylphenidate on reading in children with attention deficit disorder. Am J Psychiatry. 1984;(12):1590-3. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6507665].
Balthazor MJ, Wagner RK, Pelham WE. The specificity of the effects of stimulant medication on classroom learning-related measures of cognitive processing for attention deficit disorder children. J Abnorm Child Psychol. 1991;19(1):35-52. Exclude: No included comparisons of outcomes,. [pmid: 2030246].
Bambery M, Porcerelli JH. Psychodynamic therapy for oppositional defiant disorder: changes in personality, object relations, and adaptive function after six months of treatment. J Am Psychoanal Assoc. 2006;54(4):1334-9. [pmid: 17354508]. Exclude: No included comparisons of outcomes, OVID-Medline.
Banaschewski T, Besmens F, Zieger H, et al. Evaluation of sensorimotor training in children with ADHD. Percept Mot Skills. 2001;92(1):137-49. [pmid: 11322578]. Exclude: No included comparisons of outcomes, OVID-Medline.
Banerjee S, Ayyash HF. Does atomoxetine increase the risk of aggression and hostility in children with attention deficit hyperactivity disorder. Arch Dis Child Educ Pract. 2008;93(4):131-2. [pmid: 18644903]. Exclude: No included comparisons of outcomes, OVID-Medline.
Banerjee S. Use of atomoxetine in children and adolescents with ADHD. Prog Neuro Psychiatr. 2009;(2):18-20. Exclude: No included comparisons of outcomes, EMBASE.
Barcai A. The emergence of neurotic conflict in some children after successful administration of dextroamphetamine. J Child Psychol Psychitr Allied Disc. 1969;10(4):269-76. [pmid: 5376593]. Exclude: Not an included population, OVID-Medline.
Barkley RA. The effects of methylphenidate on various types of activity level and attention in hyperkinetic children. J Abnorm Child Psychol. 1977;5(4):351-69. [pmid: 604377]. Exclude: No included comparisons of outcomes, OVID-Medline.
Barkley RA, Cunningham CE. Stimulant drugs and activity level in hyperactive children. Am J Orthopsychiatry. 1979;49(3):491-9. [pmid: 474732]. Exclude: No included comparisons of outcomes, OVID-Medline.
Barkley RA, Cunningham CE. The effects of methylphenidate on the mother-child interactions of hyperactive children. Arch Gen Psychiatry. 1979;36(2):201-8. [pmid: 369470]. Exclude: No included comparisons of outcomes, OVID-Medline.
Barkley RA, Strzelecki E, Karlsson J, et al. Effects of age and ritalin do sage on the mother-child interactions of hyperactive children. J Consult Clin Psychol. 1984;52(5):750-8. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6501660].
Barkley RA. Hyperactive girls and boys: Stimulant drug effects on mother-child interactions. J Child Psychol Psychitr Allied Disc. 1989;30(3):379-90. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Barkley RA, McMurray MB, Edelbrock CS, et al. The response of aggressive and nonaggressive ADHD children to two doses of methylphenidate. J Am Acad Child Adolesc Psychiatry. 1989;28(6):873-81. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 2808257].
Barkley RA, McMurray MB, Edelbrock CS, et al. Side effects of methylphenidate in children with attention deficit hyperactivity disorder: a systemic, placebo-controlled evaluation. Pediatrics. 1990;86(2):184-92. [pmid: 2196520]. Exclude: No included comparisons of outcomes, OVID-Medline.
Barkley RA, Dupaul GJ, McMurray MB. Attention deficit disorder with and without hyperactivity: clinical response to three dose levels of methylphenidate. Pediatrics. 1991;87(4):519-31. Exclude: No included comparisons of outcomes,. [pmid: 2011430].
Barkley RA, Fischer M, Newby RF, et al. Development of a multimethod clinical protocol for assessing stimulant drug response in children with attention deficit disorder. J Clin Child Psychol. 1988;17(1):14-24. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Barling J, Bullen G. Dietary factors and hyperactivity: A failure to replicate. J Genet Psychol. 1985;146(1):117-23. Exclude: No included intervention compared, OVID-PsycINFO. [pmid: 3900286].
Barnett R, Maruff P, Vance A, et al. Abnormal executive function in attention deficit hyperactivity disorder: the effect of stimulant medication and age on spatial working memory. Psychol Med. 2001;31(6):1107-15. [pmid: 11513378]. Exclude: No included comparisons of outcomes, OVID-Medline.
Barratt ES, Kent TA, Bryant SG, et al. A controlled trial of phenytoin in impulsive aggression. J Clin Psychopharmacol. 1991;11(6):388-9. Exclude: Not an included population,. [pmid: 1770157].
Barrera M Jr, Biglan A, Taylor TK, et al. Early elementary school intervention to reduce conduct problems: a randomized trial with Hispanic and non-Hispanic children. Prev Sci. 2002;3(2):83-94. [pmid: 12088139]. Exclude: Not an included population, OVID-Medline.
Barry RJ, Clarke AR, Hajos M, et al. Acute atomoxetine effects on the EEG of children with Attention-Deficit/Hyperactivity Disorder. Neuropharmacology. 2009;57(7–8):702-7. Exclude: No included comparisons of outcomes, EMBASE. [pmid: 19698723].
Barton J, Mooney P, Prasad S. Atomoxetine hydrochloride and executive function in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2005;15(2):147-9. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 15910196].
Bastiaens L. Both atomoxetine and stimulants improve quality of life in an ADHD population treated in a community clinic. Psychiatr Q. 2008;79(2):133-7. [pmid: 18327640]. Exclude: No included comparisons of outcomes, OVID-Medline.
Bastiaens L. Effectiveness and tolerability of atomoxetine in a real-world ADHD population: Nonrandomized comparison with stimulants. Psychiatry. 2007;4(12):44-8. Exclude: No included comparisons of outcomes,. [pmid: 20436763].
Beal D, Gillis JS. Methylphenidate hydrochloride and judgmental behavior in hyperkinetic children. Curr Ther Res Clin Exp. 1979;26(6):931-9. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Beal D, Gillis JS. The effect of methylphenidate hydrochloride on interpersonal learning in hyperkinetic children. Res Comm Psychol Psychiatr Behav. 1988;13(4):285-300. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Beauchaine TP, Gartner J, Hagen B. Comorbid depression and heart rate variability as predictors of aggressive and hyperactive symptom responsiveness during inpatient treatment of conduct-disordered, ADHD boys. Aggressive Behavior. 2000;26(6):425-41. Exclude: Not an included population, OVID-PsycINFO.
Beauchaine TP, Gartner J. A linear growth curve analysis of inpatient treatment response by conduct-disordered, ADHD, and comorbid preadolescents. Aggressive Behavior. 2003;29(5):440-56. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Beauregard M, Levesque J. Functional magnetic resonance imaging investigation of the effects of neurofeedback training on the neural bases of selective attention and response inhibition in children with attention-deficit/hyperactivity disorder. Appl Psychophysiol Biofeedback. 2006;31(1):3-20. [pmid: 16552626]. Exclude: No included comparisons of outcomes, OVID-Medline.
Bedard AC, Ickowicz A, Logan GD, et al. Selective inhibition in children with attention-deficit hyperactivity disorder off and on stimulant medication. J Abnorm Child Psychol. 2003;31(3):315-27. [pmid: 12774864]. Exclude: No included comparisons of outcomes, OVID-Medline.
Bedard AC, Martinussen R, Ickowicz A, et al. Methylphenidate improves visual-spatial memory in children with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2004;43(3):260-8. [pmid: 15076258]. Exclude: No included comparisons of outcomes, OVID-Medline.
Behan J, Fitzpatrick C, Sharry J, et al. Evaluation of the Parenting Plus Programme. Ir J Psychol. 2001;22(3–4):238-56. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Belanger SA, Vanasse M, Spahis S, et al. Omega-3 fatty acid treatment of children with attention-deficit hyperactivity disorder: A randomized, double-blind, placebo-controlled study. Paediatr Child Health. 2009;14(2):89-98. Exclude: No included comparisons of outcomes, EMBASE. [pmid: 19436468].
Belden H. ADHD therapy to be applied transdermally. Drug Top. 2006;150(10). Exclude: No included comparisons of outcomes, OVID-Embase.
Bellgrove MA, Hawi Z, Kirley A, et al. Association between dopamine transporter (DAT1) genotype, left-sided inattention, and an enhanced response to methylphenidate in attention-deficit hyperactivity disorder. Neuropsychopharmacology. 2005;30(12):2290-7. [pmid: 16123773]. Exclude: No included comparisons of outcomes, OVID-Medline.
Bemporad JR. Psychotherapy for adults with attention deficit disorder. Harv Ment Health Lett. 1998;14(12):4-5. [pmid: 9613257]. Exclude: No included intervention compared, OVID-Medline.
Bender NN. Self-verbalization versus tutor verbalization in modifying impulsivity. J Educ Psychol. 1976;68(3):347-54. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Bennett DE, Zentall SS, French BF, et al. The effects of computer-administered choice on students with and without characteristics of Attention-Deficit/Hyperactivity Disorder. Behav Dis. 2006;31(2):189-203. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Bennett KS, Hay DA, Piek J, et al. The Australian Twin ADHD Project: current status and future directions. Twin Res Hum Genet. 2006;9(6):718-26. [pmid: 17254397]. Exclude: Not an included population, OVID-Medline.
Berman T, Douglas VI, Barr RG. Effects of methylphenidate on complex cognitive processing in attention-deficit hyperactivity disorder. J Abnorm Psychol. 1999;108(1):90-105. [pmid: 10066996]. Exclude: No included comparisons of outcomes, OVID-Medline.
Bernal ME. Behavioral feedback in the modification of brat behaviors. J Nerv Ment Dis. 1969;148(4):375-85. [pmid: 5768915]. Exclude: Not an included population, OVID-Medline.
Bernal ME, Klinnert MD, Schultz LA. Outcome evaluation of behavioral parent behavior training and client-centered parent counseling for children with conduct problems. J Appl Behav Anal. 1980;13(4):677-91. Exclude: No included comparisons of outcomes,. [pmid: 7204284].
Bernat DH, August GJ, Hektner JM, et al. The Early Risers preventive intervention: testing for six-year outcomes and mediational processes. J Abnorm Child Psychol. 2007;35(4):605-17. [pmid: 17333359]. Exclude: Not an included population, OVID-Medline.
Békés M, Polák G, Istvánffy M, et al. Effect of long-term administration of Pindolol (LB-46, Visken) in essential circulatory hyperkinesis. A double-blind, cross-over study. Int J Clin Pharmacol. 1974;9(2):87-92. Exclude: Not an included population,. [pmid: 4208032].
Bhagavan HN, Coleman M, Coursin DB. Distribution of pyridoxal-5-phosphate in human blood between the cells and the plasma: effect of oral administration of pyridoxine on the ratio in Down’s and hyperactive patients. Biochem Med. 1975;14(2):201-8. [pmid: 130903]. Exclude: No included comparisons of outcomes, OVID-Medline.
Bhagavan HN, Coleman M, Coursin DB. The effect of pyridoxine hydrochloride on blood serotonin and pyridoxal phosphate contents in hyperactive children. Pediatrics. 1975;55(3):437-41. [pmid: 1143984]. Exclude: No included comparisons of outcomes, OVID-Medline.
Bhatara VS, Feil M, Hoagwood K, et al. Datapoints: trends in combined pharmacotherapy with stimulants for children. Psychiatr Serv. 2002;53(3):244. [pmid: 11875215]. Exclude: Not an included population, OVID-Medline.
Bhatara VS, Aparasu RR. Pharmacotherapy with atomoxetine for US children and adolescents. Ann Clin Psychiatry. 2007;19(3):175-80. [pmid: 17729019]. Exclude: No included comparisons of outcomes, OVID-Medline.
Bidder RT, Gray OP, Newcombe R. Behavioral treatment of hyperactive children. Arch Dis Child. 1978;53(7):574-9. [pmid: 686794]. Exclude: Not an included population, OVID-Medline.
Biederman J, Baldessarini RJ, Wright V, et al. A double-blind placebo controlled study of desipramine in the treatment of ADD: II. Serum drug levels and cardiovascular findings. J Am Acad Child Adolesc Psychiatry. 1989;28(6):903-11. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 2808261].
Biederman J, Baldessarini RJ, Wright V, et al. A double-blind placebo controlled study of desipramine in the treatment of ADD: I. Efficacy. J Am Acad Child Adolesc Psychiatry. 1989;28(5):777-84. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 2676967].
Biederman J, Baldessarini RJ, Wright V, et al. A double-blind placebo controlled study of desipramine in the treatment of ADD: III. Lack of impact of comorbidity and family history factors on clinical response. J Am Acad Child Adolesc Psychiatry. 1993;32(1):199-204. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 8428872].
Biederman J, Mick E, Prince J, et al. Systematic chart review of the pharmacologic treatment of comorbid attention deficit hyperactivity disorder in youth with bipolar disorder. J Child Adolesc Psychopharmacol. 1999;9(4):247-56. [pmid: 10630454]. Exclude: No included intervention compared, OVID-Medline.
Biederman J, Swanson JM, Wigal SB, et al. Efficacy and safety of modafinil film-coated tablets in children and adolescents with attention-deficit/hyperactivity disorder: results of a randomized, double-blind, placebo-controlled, flexible-dose study. Pediatrics. 2005;116(6):e777-e784. [pmid: 16322134]. Exclude: No included comparisons of outcomes, OVID-Medline.
Biederman J, Spencer TJ, Wilens TE, et al. Long-term safety and effectiveness of mixed amphetamine salts extended release in adults with ADHD. Cns Spectrums. 2005;10(12 Suppl 20):16-25. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 16344837].
Biederman J, Arnsten AF, Faraone SV, et al. New developments in the treatment of ADHD. J Clin Psychiatry. 2006;67(1):148-59. [pmid: 16426101]. Exclude: Not an included population, OVID-Medline.
Biederman J, Boellner SW, Childress A, et al. Lisdexamfetamine dimesylate and mixed amphetamine salts extended-release in children with ADHD: a double-blind, placebo-controlled, crossover analog classroom study. Biol Psychiatry. 2007;62(9):970-6. [pmid: 17631866]. Exclude: No included comparisons of outcomes, OVID-Medline.
Biederman J, Boellner SW, Childress A, et al. “Lisdexamfetamine dimesylate and mixed amphetamine salts extended-release in children with ADHD: A double-blind, placebo-controlled, crossover analog classroom study”: Erratum. Biol Psychiatry. 2007;62(11):1334. Exclude: Not an included population, OVID-PsycInfo.
Bierman KL, Coie JD, Dodge KA, et al. Using the Fast Track randomized prevention trial to test the early-starter model of the development of serious conduct problems. Dev Psychopathol. 2002;14(4):925-43. [pmid: 12549710]. Exclude: Not an included population, OVID-Medline.
Bilici M, Yildirim F, Kandil S, et al. Double-blind, placebo-controlled study of zinc sulfate in the treatment of attention deficit hyperactivity disorder. Prog Neuropsychopharmacol Biol Psychiatr. 2004;28(1):181-90. [pmid: 14687872]. Exclude: No included comparisons of outcomes, OVID-Medline.
Blader JC. Pharmacotherapy and postdischarge outcomes of child inpatients admitted for aggressive behavior. J Clin Psychopharmacol. 2006;26(4):419-25. [pmid: 16855463]. Exclude: Not an included population, OVID-Medline.
Blakemore B, Shindler S, Conte R. A problem solving training program for parents of children with attention deficit hyperactivity disorder. Can J Sch Psychol. 1993;9(1):66-85. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Bledsoe J, Semrud-Clikeman M, Pliszka SR. A magnetic resonance imaging study of the cerebellar vermis in chronically treated and treatment-naive children with attention-deficit/hyperactivity disorder combined type. Biol Psychiatry. 2009;65(7):620-4. [pmid: 19150052]. Exclude: No included comparisons of outcomes, OVID-Medline.
Block SL, Kelsey D, Coury D, et al. Once. -daily atomoxetine for treating pediatric attention-deficit/hyperactivity disorder: comparison of morning and evening dosing. Clin Pediatr. 2009;48(7):723-33. [pmid: 19420182]. Exclude: No included comparisons of outcomes, OVID-Medline.
Boggs SR, Eyberg SM, Edwards DL, et al. Outcomes of parent-child interaction therapy: A comparison of treatment completers and study dropouts one to three years later. Child Fam Behav Ther. 2004;26(4):1-22. Exclude: No included intervention compared, OVID-PsycINFO.
Boisjoli R, Vitaro F, Lacourse E, et al. Impact and clinical significance of a preventive intervention for disruptive boys: 15-year follow-up. Br J Psychiatry. 2007;191:415-9. [pmid: 17978321]. Exclude: Not an included population, OVID-Medline.
Bokhari FAS, Heiland F, Levine P, et al. Risk factors for discontinuing drug therapy among children with ADHD. Health Serv Outcome Res Meth. 2008;8(3):134-58. Exclude: No included comparisons of outcomes, EMBASE.
Borcherding BG, Keysor CS, Cooper TB, et al. Differential effects of methylphenidate and dextroamphetamine on the motor activity level of hyperactive children. Neuropsychopharmacology. 1989;2(4):255-63. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 2692588].
Borcherding BG, Keysor CS, Rapoport JL, et al. Motor/vocal tics and compulsive behaviors on stimulant drugs: Is there a common vulnerability. Psychiatry Res. 1990;33(1):83-94. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 2217661].
Borden KA, Brown RT. Attributional outcomes: The subtle messages of treatments for attention deficit disorder. Cognit Ther Res. 1989;13(2):147-60. Exclude: No included comparisons of outcomes,.
Boris M, Mandel FS. Foods and additives are common causes of the attention deficit hyperactive disorder in children. Ann Allergy. 1994;(5):462-8. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 8179235].
Bradley SJ, Kolers N, Cohen N. Behavioral and developmental gains made in a therapeutic preschool and an integrated day care program: a pilot study. Can J Psychiatr. 1988;33(6):482-7. [pmid: 2461795]. Exclude: Not an included population, OVID-Medline.
Bradley SJ, Jadaa DA, Brody J, et al. Brief psychoeducational parenting program: an evaluation and 1-year follow-up. J Am Acad Child Adolesc Psychiatry. 2003;42(10):1171-8. [pmid: 14560166]. Exclude: Not an included population, OVID-Medline.
Bramble DJ, Cosgrove PVF. Parental assessments of the efficacy of risperidone in attention deficit hyperactivity disorder. Clin Child Psychol Psychiatr. 2002;(2):225-33. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Bramham J, Young S, Bickerdike A, et al. Evaluation of group cognitive behavioral therapy for adults with ADHD. J Attention Disord. 2009;12(5):434-41. [pmid: 18310557]. Exclude: No included comparisons of outcomes, OVID-Medline.
Braswell L, August GJ, Bloomquist ML, et al. School-based secondary prevention for children with disruptive behavior: initial outcomes. J Abnorm Child Psychol. 1997;25(3):197-208. Exclude: Not an included population,. [pmid: 9212372].
Braud LW. The effects of frontal EMG biofeedback and progressive relaxation upon hyperactivity and its behavioral concomitants. Biofeedback Self Regul. 1978;3(1):69-89. Exclude: No included comparisons of outcomes,. [pmid: 667193].
Brestan EV, Eyberg SM, Boggs SR, et al. Parent-child interaction therapy: Parents’ perceptions of untreated siblings. Child Fam Behav Ther. 1997;19(3):13-28. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Bright GM. Abuse of medications employed for the treatment of ADHD: results from a large-scale community survey. Medscape J Med. 2008;10(5):111. [pmid: 18596945]. Exclude: No included comparisons of outcomes, OVID-Medline.
Brinker A, Mosholder A, Schech SD, et al. Indication and use of drug products used to treat attention-deficit/hyperactivity disorder: a cross-sectional study with inference on the likelihood of treatment in adulthood. J Child Adolesc Psychopharmacol. 2007;17(3):328-33. [pmid: 17630866]. Exclude: Not an included population, OVID-Medline.
Brotman LM, Klein RG, Kamboukos D, et al. Preventive intervention for urban, low-income preschoolers at familial risk for conduct problems: a randomized pilot study. J Clin Child Adolesc Psychol. 2003;32(2):246-57. [pmid: 12679283]. Exclude: Not an included population, OVID-Medline.
Brotman LM, Gouley KK, Chesir-Teran D, et al. Prevention for preschoolers at high risk for conduct problems: immediate outcomes on parenting practices and child social competence. J Clin Child Adolesc Psychol. 2005;34(4):724-34. [pmid: 16232069]. Exclude: Not an included population, OVID-Medline.
Brotman LM, O’Neal CR, Huang KY, et al. An experimental test of parenting practices as a mediator of early childhood physical aggression. J Child Psychol Psychitr Allied Disc. 2009;50(3):235-45. [pmid: 19220626]. Exclude: Not an included population, OVID-Medline.
Brown CS, Wells BG, Cold JA, et al. Possible influence of carbamazepine on plasma imipramine concentrations in children with attention deficit hyperactivity disorder. J Clin Psychopharmacol. 1990;(5):359-62. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 2258453].
Brown D, Winsberg BG, Bialer I, et al. Imipramine therapy and seizures: three children treated for hyperactive behavior disorders. Am J Psychiatry. 1973;130(2):210-2. [pmid: 4685246]. Exclude: No included comparisons of outcomes, OVID-Medline.
Brown GL, Ebert MH, Mikkelsen EJ, et al. Behavior and motor activity response in hyperactive children and plasma amphetamine levels following a sustained release preparation. J Am Acad Child Psychiatry. 1980;19(2):225-39. [pmid: 7391429]. Exclude: No included comparisons of outcomes, OVID-Medline.
Brown RT, Borden KA, Clingerman SR. Adherence to methylphenidate therapy in a pediatric population: a preliminary investigation. Psychopharmacol Bull. 1985;21(1):28-36. Exclude: No included comparisons of outcomes,. [pmid: 3983335].
Brown RT, Wynne ME, Borden KA, et al. Methylphenidate and cognitive therapy in children with attention deficit disorder: a double-blind trial. J Dev Behav Pediatr. 1986;7(3):163-74. Exclude: No included comparisons of outcomes,. [pmid: 3522630].
Brown RT, Borden KA, Wynne ME, et al. Methylphenidate and cognitive therapy with ADD children: a methodological reconsideration. J Abnorm Child Psychol. 1986;14(4):481-97. Exclude: No included comparisons of outcomes,. [pmid: 3782621].
Brown RT, Borden KA, Wynne ME, et al. Compliance with pharmacological and cognitive treatments for attention deficit disorder. J Am Acad Child Adolesc Psychiatry. 1987;26(4):521-6. Exclude: No included comparisons of outcomes,. [pmid: 3654504].
Brown RT, Sexson SB. A controlled trial of methylphenidate in black adolescents. Attentional, behavioral, and physiological effects. Clin Pediatr. 1988;27(2):74-81. [pmid: 3338232]. Exclude: No included comparisons of outcomes, OVID-Medline.
Brown RT, Sleator EK. Methylphenidate in hyperkinetic children: Differences in dose effects on impulsive behavior. Pediatrics. 1979;64(4):408-11. Exclude: No included comparisons of outcomes, ERIC Database. [pmid: 492804].
Brown RT, Conrad KJ. Impulse control or selective attention: Remedial programs for hyperactivity. Psychol Schools. 1982;19(1):92-7. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Broyd SJ, Johnstone SJ, Barry RJ, et al. The effect of methylphenidate on response inhibition and the event-related potential of children with attention deficit/hyperactivity disorder. Int J Psychophysiol. 2005;58(1):47-58. [pmid: 15925419]. Exclude: No included comparisons of outcomes, OVID-Medline.
Brue AW, Oakland TD, Evans RA. The use of a dietary supplement combination and an essential fatty acid as an alternative and complementary treatment for children with attention-deficit/hyperactivity disorder. Sci Rev Alternative Med. 2001;(4):187-94. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Brulotte J, Bukutu C, Vohra S. Complementary, holistic, and integrative medicine: fish oils and neurodevelopmental disorders. Pediatr Rev. 2009;30(4):e29-e33. [pmid: 19339384]. Exclude: Did not compare two included treatments, OVID-Medline.
Buckley RE. Neurophysiologic proposal for the amphetamine response in hyperkinetic children. Psychosomatics. 1972;13(2):93-9. [pmid: 4671944]. Exclude: Not an included population, OVID-Medline.
Budd KS. Home-based treatment of severe disruptive behaviors: A reinforcement package for preschool and kindergarten children. Behav Modif. 1981;5(2):273-98. Exclude: Not an included population, OVID-PsycINFO.
Budman C, Coffey BJ, Shechter R, et al. Aripiprazole in children and adolescents with Tourette disorder with and without explosive outbursts. J Child Adolesc Psychopharmacol. 2008;(5):509-15. Exclude: Not an included population, EMBASE. [pmid: 18928415].
Bugental DB, Collins S, Collins L, et al. Attributional and behavioral changes following two behavior management interventions with hyperactive boys: A follow-up study. Child Dev. 1978;49(1):247-50. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 657894].
Buitelaar JK, Danckaerts M, Gillberg C, et al. A prospective, multicenter, open-label assessment of atomoxetine in non-North American children and adolescents with ADHD. Eur Child Adolesc Psychiatr. 2004;13(4):249-57. [pmid: 15365896]. Exclude: Not an included population, OVID-Medline.
Burd L, Kerbeshian J, Fisher W. Does the use of phenobarbital as an anticonvulsant permanently exacerbate hyperactivity. Can J Psychiatr. 1987;(1):10-3. Exclude: Not an included population, OVID-EMBASE.
Bussing R, Zima BT, Mason D, et al. Use and persistence of pharmacotherapy for elementary school students with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2005;15(1):78-87. [pmid: 15741789]. Exclude: No included comparisons of outcomes, OVID-Medline.
Butter HJ, Lapierre YD. The effect of methylphenidate on sensory perception and integration in hyperactive children. Int Pharmacopsychiatry. 1974;9(4):235-44. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 4616915].
Butter HJ, Lapierre YD. The effect of methylphenidate on sensory perception in varying degrees of hyperkinetic behavior. Dis Nerv Syst. 1975;36(6):286-8. Exclude: No included intervention compared, OVID-PsycINFO. [pmid: 1097220].
Butter HJ, Lapierre Y, Firestone P, et al. A comparative study of the efficacy of ACTH analog, methylphenidate, and placebo on attention deficit disorder with hyperkinesis. J Clin Psychopharmacol. 1983;(4):226-30. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6309918].
Butter HJ, Lapierre Y, Firestone P, et al. Efficacy of ACTH 4–9 analog, methylphenidate, and placebo on attention deficit disorder with hyperkinesis. Prog Neuropsychopharmacol Biol Psychiatr. 1984;(4–6):661-4. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Byrne JM, Bawden HN, DeWolfe NA, et al. Clinical assessment of psychopharmacological treatment of preschoolers with ADHD. J Clin Experiment Neuropsychol. 1998;20(5):613-27. [pmid: 10079039]. Exclude: Not an included population, OVID-Medline.
Cabiya JJ, Padilla-Cotto L, Gonzalez K, et al. Effectiveness of a cognitive-behavioral intervention for Puerto Rican children. Revista Interamericana de Psicologia. 2008;42(2):195-202. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Cala S, Crismon ML, Baumgartner J. A survey of herbal use in children with attention-deficit-hyperactivity disorder or depression. Pharmacother. 2003;23(2):222-30. [pmid: 12587812]. Exclude: Not an included population, OVID-Medline.
Calhoun G Jr, Fees CK, Bolton JA. Attention-deficit hyperactivity disorder: alternatives for psychotherapy. Percept Mot Skills. 1994;79(1:Pt 2):657-8. [pmid: 7808906]. Exclude: Not an included population, OVID-Medline.
Campbell M, Fish B, Korein J, et al. Lithium and chlorpromazine: a controlled crossover study of hyperactive severely disturbed young children. J Autism Child Schizophr. 1972;2(3):234-63. [pmid: 4567547]. Exclude: No included comparisons of outcomes, OVID-Medline.
Campbell M, Small AM, Green WH. Lithium and haloperidol in hospitalized aggressive children. Psychopharmacol Bull. 1982;(3):126-30. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Campbell M, Adams PB, Small AM, et al. Lithium in hospitalized aggressive children with conduct disorder: a double-blind and placebo-controlled study. [erratum appears in J Am Acad Child Adolesc Psychiatry 1995 May;34(5):694]. J Am Acad Child Adolesc Psychiatry. 1995;34(4):445-53. [pmid: 7751258]. Exclude: No included comparisons of outcomes, OVID-Medline.
Campbell SB, Schleifer M, Weiss G, et al. A two-year follow-up of hyperactive preschoolers. Am J Orthopsychiatry. 1977;47(1):149-62. [pmid: 831523]. Exclude: Not an included population, OVID-Medline.
Campbell SB, Breaux AM, Ewing LJ, et al. A one-year follow-up study of parent-referred hyperactive preschool children. J Am Acad Child Psychiatry. 1984;(3):243-9. Exclude: No included intervention compared, OVID-EMBASE. [pmid: 6736488].
Carlson CL, Pelham J, Milich R, et al. ADHD boys’ performance and attributions following success and failure: Drug effects and individual differences. Cognit Ther Res. 1993;(3):269-87. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Carlson CL, Mann M, Alexander DK. Effects of reward and response cost on the performance and motivation of children with ADHD. Cognit Ther Res. 2000;(1):87-98. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Carlson CL, Tamm L. Responsiveness of children with attention deficit-hyperactivity disorder to reward and response cost: Differential impact on performance and motivation. J Consult Clin Psychol. 2000;68(1):73-83. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 10710842].
Carlson GA, Loney J, Salisbury H, et al. Stimulant treatment in young boys with symptoms suggesting childhood mania: a report from a longitudinal study. J Child Adolesc Psychopharmacol. 2000;10(3):175-84. [pmid: 11052407]. Exclude: No included comparisons of outcomes, OVID-Medline.
Carlson GA, Dunn D, Kelsey D, et al. A pilot study for augmenting atomoxetine with methylphenidate: Safety of concomitant therapy in children with attention-deficit/hyperactivity disorder. Child Adolesc Psychiatr Ment Health. 2007. Exclude: No included comparisons of outcomes, EMBASE.
Carlson GA, Rapport MD, Kelly KL, et al. The effects of methylphenidate and lithium on attention and activity level. J Am Acad Child Adolesc Psychiatry. 1992;31(2):262-70. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 1564028].
Carter CM, Urbanowicz M, Hemsley R, et al. Effects of a few food diet in attention deficit disorder. Arch Dis Child. 1993;(5):564-8. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 8257176].
Casat CD, Pleasants DZ, Van Wyck FJ. A double-blind trial of bupropion in children with attention deficit disorder. Psychopharmacol Bull. 1987;(1):120-2. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3110853].
Casat CD, Pleasants DZ, Schroeder DH, et al. Bupropion in children with attention deficit disorder. Psychopharmacol Bull. 1989;25(2):198-201. Exclude: No included comparisons of outcomes,. [pmid: 2513592].
Castaneda R, Sussman N, Levy R, et al. A treatment algorithm for attention deficit hyperactivity disorder in cocaine-dependent adults: A one-year private practice study with long-acting stimulants, fluoxetine, and bupropion. Subst Abuse. 1999;(1):59-71. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Castellanos FX, Elia J, Kruesi MJP, et al. Cerebrospinal fluid homovanillic acid predicts behavioral response to stimulants in 45 boys with attention deficit/hyperactivity disorder. Neuropsychopharmacology. 1996;(2):125-37. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 8822535].
Castellanos FX, Giedd JN, Elia J, et al. Controlled stimulant treatment of ADHD and comorbid Tourette’s syndrome: effects of stimulant and dose. J Am Acad Child Adolesc Psychiatry. 1997;36(5):589-96. [pmid: 9136492]. Exclude: No included comparisons of outcomes, OVID-Medline.
Castellanos FX. Toward the dimensionome: Parsing reward-related processing in attention-deficit/hyperactivity disorder. Biol Psychiatry. 2009;(1):5-6. Exclude: No included intervention compared, EMBASE. [pmid: 19064036].
Cermak SA, Stein F, Abelson C. Hyperactive children and an activity group therapy model. Am J Occup Ther. 1973;27(6):311-5. [pmid: 4723724]. Exclude: Not an included population, OVID-Medline.
Chacko A, Pelham WE, Gnagy EM, et al. Stimulant medication effects in a summer treatment program among young children with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2005;44(3):249-57. [pmid: 15725969]. Exclude: Not an included population, OVID-Medline.
Chacko A, Wymbs BT, Wymbs FA, et al. Enhancing traditional behavioral parent behavior training for single mothers of children with ADHD. J Clin Child Adolesc Psychol. 2009;38(2):206-18. [pmid: 19283599]. Exclude: No included comparisons of outcomes, OVID-Medline.
Chan E, Rappaport LA, Kemper KJ. Complementary and alternative therapies in childhood attention and hyperactivity problems. J Dev Behav Pediatr. 2003;24(1):4-8. [pmid: 12584479]. Exclude: No included intervention compared, OVID-Medline.
Chang HL, Ko NC, Liang HY. No correlation between continuous performance test and optimal methylphenidate dosage in ADHD children. Psychiatr Clin Neurosci. 2009;63(5):702-3. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Charlebois P, LeBlanc M, Tremblay RE, et al. Teacher, mother, and peer support in the elementary school as protective factors against juvenile delinquency. Int J Behav Dev. 1995;18(1):1-22. Exclude: No included intervention compared, OVID-PsycINFO.
Charles L, And O. Long-term use and discontinuation of methylphenidate with hyperactive children. Dev Med Child Neurol. 1979;21(6):758-64. Exclude: No included comparisons of outcomes, ERIC Database. [pmid: 520713].
Charles L, Schain RJ. A four-year follow-up study of the effects of methylphenidate on the behavior and academic achievement of hyperactive children. J Abnorm Child Psychol. 1981;9(4):495-505. Exclude: Not an included population, OVID-PsycInfo. [pmid: 7328229].
Chase RM, Eyberg SM. Clinical presentation and treatment outcome for children with comorbid externalizing and internalizing symptoms. J Anxiety Disord. 2008;22(2):273-82. [pmid: 17467229]. Exclude: No included comparisons of outcomes, OVID-Medline.
Chase SN, Clement PW. Effects of self-reinforcement and stimulants on academic performance in children with Attention Deficit Disorder. J Clin Child Psychol. 1985;14(4):323-33. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Chatoor I, Wells KC, Conners CK. The effects of nocturnally administered stimulant medication on EEG sleep and behavior in hyperactive children. J Am Acad Child Psychiatry. 1983;(4):337-42. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6875127].
Cherland E, Fitzpatrick R. Psychotic side effects of psychostimulants: a 5-year review. Can J Psychiatr. 1999;44(8):811-3. [pmid: 10566114]. Exclude: No included intervention compared, OVID-Medline.
Chertin B, Koulikov D, Abu-Arafeh W, et al. Treatment of nocturnal enuresis in children with attention deficit hyperactivity disorder. J Urol. 2007;178(4:Pt 2):t-7. [pmid: 17707010]. Exclude: No included comparisons of outcomes, OVID-Medline.
Chevalier N, Poissant H, Bergeron H, et al. The effect of visual-motor imagery training on CPT performance in children with Attention Deficit Hyperactivity Disorder. J Cognit Educ Psychol. 2003;3(2):120-36. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Childress AC, Spencer T, Lopez F, et al. Efficacy and safety of dexmethylphenidate extended-release capsules administered once daily to children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;(4):351-61. Exclude: No included comparisons of outcomes, EMBASE. [pmid: 19702487].
Chong TM. The significance of parent-child relationship in behavioral disturbances and psychosomatic conditions in children and their management by hypnotherapy. J Singapore Paediatr Soc. 1967;9(2):113-6. [pmid: 5588734]. Exclude: Not an included population, OVID-Medline.
Chou WJ, Chou MC, Tzang RF, et al. Better efficacy for the osmotic release oral system methylphenidate among poor adherents to immediate-release methylphenidate in the three ADHD subtypes. Psychiatr Clin Neurosci. 2009;63(2):167-75. [pmid: 19335386]. Exclude: No included comparisons of outcomes, OVID-Medline.
Chovanova Z, Muchova J, Sivonova M, et al. Effect of polyphenolic extract, Pycnogenol, on the level of 8-oxoguanine in children suffering from attention deficit/hyperactivity disorder. Free Radic Res. 2006;40(9):1003-10. [pmid: 17015282]. Exclude: No included comparisons of outcomes, OVID-Medline.
Christensen DE, Sprague RL. Reduction of hyperactive behavior by conditioning procedures alone and combined with methylphenidate (Ritalin). Behav Res Ther. 1973;11(3):331-4. Exclude: No included comparisons of outcomes,. [pmid: 4727296].
Chronis AM, Pelham WE Jr, Gnagy EM, et al. The impact of late-afternoon stimulant dosing for children with ADHD on parent and parent-child domains. J Clin Child Adolesc Psychol. 2003;32(1):118-26. [pmid: 12573937]. Exclude: No included comparisons of outcomes, OVID-Medline.
Chronis AM, Fabiano GA, Gnagy EM, et al. An evaluation of the summer treatment program for children with attention deficit/hyperactivity disorder using a treatment withdrawal design. Behav Ther. 2004;35(3):561-85. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Cihak DF, Kirk ER, Boon RT. Effects of classwide positive peer “Tootling” to reduce the disruptive classroom behaviors of elementary students with and without disabilities. J Behav Educ. 2009;18(4):267-78. Exclude: Not an included population, ERIC Database.
Clarke AR, Barry RJ, McCarthy R, et al. EEG differences between good and poor responders to methylphenidate and dexamphetamine in children with attention-deficit/hyperactivity disorder. Clin Neurophysiol. 2002;113(2):194-205. [pmid: 11856625]. Exclude: No included comparisons of outcomes, OVID-Medline.
Clarke AR, Barry RJ, Bond D, et al. Effects of stimulant medications on the EEG of children with attention-deficit/hyperactivity disorder. Psychopharmacol. 2002;164(3):277-84. [pmid: 12424551]. Exclude: No included comparisons of outcomes, OVID-Medline.
Clarke AR, Barry RJ, McCarthy R, et al. Effects of stimulant medications on children with attention-deficit/hyperactivity disorder and excessive beta activity in their EEG. Clin Neurophysiol. 2003;114(9):1729-37. [pmid: 12948803]. Exclude: No included comparisons of outcomes, OVID-Medline.
Clarke AR, Barry RJ, McCarthy R, et al. Effects of stimulant medications on the EEG of children with attention-deficit/hyperactivity disorder predominantly inattentive type. Int J Psychophysiol. 2003;47(2):129-37. [pmid: 12568943]. Exclude: No included comparisons of outcomes, OVID-Medline.
Clarke AR, Barry RJ, McCarthy R, et al. Effects of imipramine hydrochloride on the EEG of children with attention-deficit/hyperactivity disorder who are non-responsive to stimulants. Int J Psychophysiol. 2008;68(3):186-92. [pmid: 18304665]. Exclude: No included comparisons of outcomes, OVID-Medline.
Clay TH, Gualtieri CT, Evans RW, et al. Clinical and neuropsychological effects of the novel antidepressant bupropion. Psychopharmacol Bull. 1988;24(1):143-8. [pmid: 3133717]. Exclude: No included comparisons of outcomes, OVID-Medline.
Cluett Redden S, Forness SR, Ramey CT, et al. Head start children with a putative diagnosis of ADHD: A four-year follow-up of special education placement. Educ Treat Child. 2003;26(3):208-23. Exclude: Not an included population, OVID-PsycINFO.
Coats KI. Cognitive self-instructional training approach for reducing disruptive behavior of young children. Psychol Rep. 1979;44(1):127-34. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 461602].
Cocciarella A, Wood R, Low KG. Brief behavioral treatment for attention-deficit hyperactivity disorder. Percept Mot Skills. 1995;81(1):225-6. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 8532460].
Cockcroft K, Ashwal J, Bentley A. Sleep and daytime sleepiness in methylphenidate medicated and un-medicated children with attention-deficit/hyperactivity disorder (ADHD). Afr J Psychiatr. 2009;12(4):275-9. [pmid: 20033109]. Exclude: No included comparisons of outcomes, OVID-Medline.
Cohen M, Freedman N, Engelhardt DM, et al. Family interaction patterns, drug treatment, and change in social aggression. Arch Gen Psychiatry. 1968;19(1):50-6. Exclude: Not an included population,. [pmid: 5661009].
Cohen NJ, Douglas VI. Characteristics of the orienting response in hyperactive and normal children. Psychophysiology. 1972;9(2):238-45. [pmid: 5024166]. Exclude: No included intervention compared, OVID-Medline.
Cohen NJ, Bradley S, Kolerse N. Building competence in delayed and disturbed preschoolers: outcome evaluation of an intensive day treatment program. Rev Canad Sante Publique. 1986;77(Suppl 1):65-71. [pmid: 2427178]. Exclude: Not an included population, OVID-Medline.
Cohen NJ, Bradley S, Kolers N. Outcome evaluation of a therapeutic day treatment program for delayed and disturbed preschoolers. J Am Acad Child Adolesc Psychiatry. 1987;26(5):687-93. [pmid: 2444576]. Exclude: No included intervention compared, OVID-Medline.
Combs-Ronto LA, Olson SL, Lunkenheimer ES, et al. Interactions between maternal parenting and children’s early disruptive behavior: bidirectional associations across the transition from preschool to school entry. J Abnorm Child Psychol. 2009;37(8):1151-63. [pmid: 19533326]. Exclude: No included intervention compared, OVID-Medline.
Conduct Problems Prevention Research Group. Fast track randomized controlled trial to prevent externalizing psychiatric disorders: findings from grades 3 to 9. J Am Acad Child Adolesc Psychiatry. 2007;46(10):1250-62. [pmid: 17885566]. Exclude: Not an included population, OVID-Medline.
Conlon KE, Strassle CG, Vinh D, et al. Family management styles and ADHD: utility and treatment implications. J Fam Nurs. 2008;14(2):181-200. [pmid: 18391181]. Exclude: No included intervention compared, OVID-Medline.
Connell A, Bullock BM, Dishion TJ, et al. Family intervention effects on co-occurring early childhood behavioral and emotional problems: a latent transition analysis approach. J Abnorm Child Psychol. 2008;36(8):1211-25. [pmid: 18473160]. Exclude: Not an included population, OVID-Medline.
Conners CK, Eisenberg L, Barcai A. Effect of dextroamphetamine on children. Studies on subjects with learning disabilities and school behavior problems. Arch Gen Psychiatry. 1967;17(4):478-85. Exclude: No included comparisons of outcomes,. [pmid: 4861380].
Conners CK, Rothschild G, Eisenberg L, et al. Dextroamphetamine sulfate in children with learning disorders. Effects on perception, learning, and achievement. Arch Gen Psychiatry. 1969;21(2):182-90. Exclude: Not an included population,. [pmid: 4896164].
Conners CK, Goyette CH, Southwick DA, et al. Food additives and hyperkinesis: a controlled double-blind experiment. Pediatrics. 1976;58(2):154-66. Exclude: No included comparisons of outcomes,. [pmid: 781610].
Conners CK, Casat CD, Gualtieri CT, et al. Bupropion hydrochloride in attention deficit disorder with hyperactivity. J Am Acad Child Adolesc Psychiatry. 1996;35(10):1314-21. [pmid: 8885585]. Exclude: No included comparisons of outcomes, OVID-Medline.
Conte R, et al. A mediational training program for parents of children with attention deficit hyperactivity disorder. Can J Spec Educ. 1994;9(3):33-68. Exclude: No included comparisons of outcomes, ERIC Database.
Cook JR, Mausbach T, Burd L, et al. A preliminary study of the relationship between central auditory processing disorder and attention deficit disorder. J Psychiatr Neurosci. 1993;18(3):130-7. Exclude: No included comparisons of outcomes,.
Corkum PV, McKinnon MM, Mullane JC. The effect of involving classroom teachers in a parent behavior training program for families of children with ADHD. Child Fam Behav Ther. 2005;27(4):29-49. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Correia Filho AG, Bodanese R, Silva TL, et al. Comparison of risperidone and methylphenidate for reducing ADHD symptoms in children and adolescents with moderate mental retardation. J Am Acad Child Adolesc Psychiatry. 2005;44(8):748-55. [pmid: 16034276]. Exclude: No included comparisons of outcomes, OVID-Medline.
Costin J, Vance A, Barnett R, et al. Attention deficit hyperactivity disorder and comorbid anxiety: Practitioner problems in treatment planning. Child Adolesc Ment Health. 2002;7(1):16-24. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Costin J, Lichte C, Hill-Smith A, et al. Parent group treatments for children with oppositional defiant disorder. AeJAMH. 2004;3:36-43. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Cotton MF, Rothberg AD. Methylphenidate v. placebo--a randomised double-blind crossover study in children with the attention deficit disorder. S Afr Med J. 1988;74(6):268-71. Exclude: No included comparisons of outcomes,. [pmid: 3047886].
Cottrell S, Tilden D, Robinson P, et al. A modeled economic evaluation comparing atomoxetine with stimulant therapy in the treatment of children with attention-deficit/hyperactivity disorder in the United Kingdom. Value in Health. 2008;11(3):376-88. [pmid: 18489664]. Exclude: No included comparisons of outcomes, OVID-Medline.
Cowen EL, Zax M, Izzo LD, et al. Prevention of emotional disorders in the school setting: a further investigation. J Consult Psychol. 1966;30(5):381-7. [pmid: 5916870]. Exclude: Not an included population, OVID-Medline.
Cox DJ, Mikami AY, Cox BS, et al. Effect of long-acting OROS methylphenidate on routine driving in young adults with attention-deficit/hyperactivity disorder. Arch Pediatr Adolesc Med. 2008;162(8):793-4. [pmid: 18678816]. Exclude: No included comparisons of outcomes, OVID-Medline.
Cox ER, Halloran DR, Homan SM, et al. Trends in the prevalence of chronic medication use in children: 2002–2005. Pediatrics. 2008;122(5):e1053-e1061. [pmid: 18977954]. Exclude: Not an included population, OVID-Medline.
Cueva JE, Overall JE, Small AM, et al. Carbamazepine in aggressive children with conduct disorder: A double-blind and placebo-controlled study. J Am Acad Child Adolesc Psychiatry. 1996;35(4):480-90. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 8919710].
Cullen KJ, Boundy CA. The prevalence of behavior disorders in the children of 1,000 Western Australian families. Med J Aust. 1966;2(17):805-8. [pmid: 5921846]. Exclude: No included intervention compared, OVID-Medline.
Cullen KJ, Cullen AM. Long-term follow-up of the Busselton six-year controlled trial of prevention of children’s behavior disorders. J Pediatr. 1996;129(1):136-9. Exclude: Not an included population,. [pmid: 8757573].
Cunningham CE, Barkley RA. The effects of methylphenidate on the mother-child interactions of hyperactive identical twins. Dev Med Child Neurol. 1978;20(5):634-42. [pmid: 729911]. Exclude: No included intervention compared, OVID-Medline.
Cunningham CE, Siegel LS, Offord DR. A developmental dose response analysis of the effects of methylphenidate on the peer interactions of attention deficit disordered boys. J Child Psychol Psychiatr. 1985;26(6):955-71. Exclude: No included comparisons of outcomes,.
Cunningham CE, Siegel LS, Offord DR. A dose-response analysis of the effects of methylphenidate on the peer interactions and simulated classroom performance of ADD children with and without conduct problems. J Child Psychol Psychiatr. 1991;32(3):439-52. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Cunningham CE, Bremner R, Secord-Gilbert M. Increasing the availability, accessibility, and cost efficacy of services for families of ADHD children: A school-based systems-oriented parenting course. Can J Sch Psychol. 1993;9(1):1-15. Exclude: Not an included population, OVID-PsycINFO.
Cunningham MA, Pillai V, Rogers WJ. Haloperidol in the treatment of children with severe behavior disorders. Br J Psychiatry. 1968;114(512):845-54. Exclude: No included comparisons of outcomes,. [pmid: 4874166].
Curtis NM, Ronan KR, Heiblum N, et al. Dissemination and effectiveness of multisystemic treatment in New Zealand: a benchmarking study. J Fam Psychol. 2009;23(2):119-29. [pmid: 19364207]. Exclude: No included comparisons of outcomes, OVID-Medline.
Cutuli JJ, Chaplin TM, Gillham JE, et al. Preventing co-occurring depression symptoms in adolescents with conduct problems: the Penn Resiliency Program. Ann N Y Acad Sci. 2006;1094:282-6. [pmid: 17347362]. Exclude: No included comparisons of outcomes, OVID-Medline.
da Silva TL, Pianca TG, Roman T, et al. Adrenergic alpha2A receptor gene and response to methylphenidate in attention-deficit/hyperactivity disorder-predominantly inattentive type. J Neural Transm. 2008;115(2):341-5. [pmid: 18200436]. Exclude: No included comparisons of outcomes, OVID-Medline.
Dalby JT, Kinsbourne M, Swanson JM, et al. Hyperactive children’s underuse of learning time: Correction by stimulant treatment. Child Dev. 1977;48(4):1448-53. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 608366].
Daviss WB, Patel NC, Robb AS, et al. Clonidine for attention-deficit/hyperactivity disorder: II. ECG changes and adverse events analysis. J Am Acad Child Adolesc Psychiatry. 2008;47(2):189-98. [pmid: 18182964]. Exclude: No included comparisons of outcomes, OVID-Medline.
Day DM, Pal A, Goldberg K. Assessing the post-residential functioning of latency-aged conduct disordered children. Residential Treatment for Children & Youth. 1994;11(3):45-61. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Day HD, Abmayr SB. Parent reports of sleep disturbances in stimulant-medicated children with attention-deficit hyperactivity disorder. J Clin Psychol. 1998;54(5):701-16. [pmid: 9696120]. Exclude: No included comparisons of outcomes, OVID-Medline.
de Sousa A, de Sousa DA, Agarwal MR. Diphenylhydantoin in hyperkinesis. Child Psychiatr Q. 1989;22(2–3):57-61. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
DeBar LL, Lynch F, Powell J, et al. Use of psychotropic agents in preschool children: associated symptoms, diagnoses, and health care services in a health maintenance organization. Arch Pediatr Adolesc Med. 2003;157(2):150-7. [pmid: 12580684]. Exclude: No included comparisons of outcomes, OVID-Medline.
Dell’agnello G, Maschietto D, Bravaccio C, et al. Atomoxetine hydrochloride in the treatment of children and adolescents with attention-deficit/hyperactivity disorder and comorbid oppositional defiant disorder: A placebo-controlled Italian study. Eur Neuropsychopharmacol. 2009;(11):822-34. Exclude: No included comparisons of outcomes, EMBASE. [pmid: 19716683].
DeLong GR. Lithium carbonate treatment of select behavior disorders in children suggesting manic-depressive illness. J Pediatr. 1978;93(4):689-94. [pmid: 359772]. Exclude: Not an included population, OVID-Medline.
Denhoff E. Effects of dextroamphetamine on hyperkinetic children: A controlled double blind study. J Learn Disabil. 1971;4(9):491-8. Exclude: No included comparisons of outcomes,.
Denkowski KM, Denkowski GC. Is group progressive relaxation training as effective with hyperactive children as individual EMG biofeedback treatment. Biofeedback Self Regul. 1984;(3):353-64. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6395905].
Denkowski KM, Denkowski GC, Omizo MM. Predictors of success in the EMG biofeedback training of hyperactive male children. Biofeedback Self Regul. 1984;(2):253-64. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6509114].
Denney CB, Rapport MD. Predicting methylphenidate response in children with ADHD: theoretical, empirical, and conceptual models. J Am Acad Child Adolesc Psychiatry. 1999;38(4):393-401. [pmid: 10199110]. Exclude: No included comparisons of outcomes, OVID-Medline.
Deputy SR. Treatment of ADHD in children with tics: a randomized controlled trial. Clin Pediatr. 2002;41(9):736. [pmid: 12462329]. Exclude: No included comparisons of outcomes, OVID-Medline.
DeVeaugh-Geiss J, Conners CK, Sarkis EH, et al. GW320659 for the treatment of attention-deficit/hyperactivity disorder in children. J Am Acad Child Adolesc Psychiatry. 2002;41(8):914-20. [pmid: 12162627]. Exclude: No included comparisons of outcomes, OVID-Medline.
Diamond IR, Tannock R, Schachar RJ. Response to methylphenidate in children with ADHD and comorbid anxiety. J Am Acad Child Adolesc Psychiatry. 1999;38(4):402-9. [pmid: 10199111]. Exclude: No included comparisons of outcomes, OVID-Medline.
Dishion TJ, Shaw D, Connell A, et al. The family check-up with high-risk indigent families: preventing problem behavior by increasing parents’ positive behavior support in early childhood. Child Dev. 2008;79(5):1395-414. [pmid: 18826532]. Exclude: Not an included population, OVID-Medline.
Dixit SP, Pandey MN, Dubey GP. Management of attention deficit/hyperactivity disorder--use of an effective paradigm. Indian J Med Sci. 2002;56(8):376-80. [pmid: 12645162]. Exclude: No included comparisons of outcomes, OVID-Medline.
Doherty SL, Frankenberger W, Fuhrer R, et al. Children’s self-reported effects of stimulant medication. Int J Disabil Dev Educ. 2000;47(1):39-54. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Donnelly C, Faries D, Swensen A, et al. The effect of atomoxetine on the social and family functioning of children and adolescents with attention-deficit/hyperactivity disorder (ADHD). Eur Neuropsychopharmacol. 2002;12(Suppl 3):S437. Exclude: No included comparisons of outcomes,.
Donnelly M, Rapoport JL, Ismond DR. Fenfluramine treatment of childhood attention deficit disorder with hyperactivity: A preliminary report. Psychopharmacol Bull. 1986;(1):152-4. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3523573].
Donnelly M, Zametkin AJ, Rapoport JL, et al. Treatment of childhood hyperactivity with desipramine: plasma drug concentration, cardiovascular effects, plasma and urinary catecholamine levels, and clinical response. Clin Pharmacol Ther. 1986;39(1):72-81. [pmid: 3510796]. Exclude: No included comparisons of outcomes, OVID-Medline.
Donnelly M, Rapoport JL, Potter WZ, et al. Fenfluramine and dextroamphetamine treatment of childhood hyperactivity. Clinical and biochemical findings. Arch Gen Psychiatry. 1989;46(3):205-12. Exclude: No included comparisons of outcomes,. [pmid: 2645848].
Donner R, Michaels MA, Ambrosini PJ. Cardiovascular effects of mixed amphetamine salts extended release in the treatment of school-aged children with attention-deficit/hyperactivity disorder. Biol Psychiatry. 2007;61(5):706-12. [pmid: 16899230]. Exclude: No included comparisons of outcomes, OVID-Medline.
DosReis S, Owens PL, Puccia KB, et al. Multimodal treatment for ADHD among youths in three Medicaid subgroups: disabled, foster care, and low income. Psychiatr Serv. 2004;55(9):1041-8. [pmid: 15345765]. Exclude: Not an included population, OVID-Medline.
DosReis S, Mychailyszyn MP, Evans-Lacko SE, et al. The meaning of attention-deficit/hyperactivity disorder medication and parents’ initiation and continuity of treatment for their child. J Child Adolesc Psychopharmacol. 2009;(4):377-83. Exclude: Not an included population, EMBASE. [pmid: 19702489].
Douglas VI, Barr RG, O’Neill ME, et al. Short term effects of methylphenidate on the cognitive, learning and academic performance of children with attention deficit disorder in the laboratory and the classroom. J Child Psychol Psychitr Allied Disc. 1986;(2):191-211. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Douglas VI, Parry PA. Effects of reward and nonreward on frustration and attention in attention deficit disorder. J Abnorm Child Psychol. 1994;(3):281-302. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 8064034].
Douglas VI, Barr RG, Desilets J, et al. Do high doses of stimulants impair flexible thinking in attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1995;34(7):877-85. [pmid: 7649958]. Exclude: No included comparisons of outcomes, OVID-Medline.
Döpfner M, Breuer D, Schürmann S, et al. Effectiveness of an adaptive multimodal treatment in children with attention-deficit hyperactivity disorder -- global outcome. Eur Child Adolesc Psychiatr. 2004;13(Suppl 1):I117-129. Exclude: No included comparisons of outcomes,.
Drechsler R, Straub M, Doehnert M, et al. Controlled evaluation of a neurofeedback training of slow cortical potentials in children with attention deficit/hyperactivity disorder (ADHD). Behav Brain Funct. 2007;3(1):35. Exclude: No included comparisons of outcomes,. [pmid: 17655749].
Drtilkova I. Correlation between the therapeutic success in the hyperkinetic syndrome and EEG or MBD symptoms. Act Nerv Super. 1984;26(1):26-7. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Drtilkova I, Misurec J, Balastikova B, et al. EEG changes after mesocarb in respondent and nonrespondent hyperkinetic children. Act Nerv Super. 1989;(1):50. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Drtílková I, Náhunek K, Machácková V, et al. Controlled comparison of the effect of dosulepin and diazepam in hyperkinetic children with phenylketonuria. Act Nerv Super. 1978;20(4):247-8. Exclude: No included comparisons of outcomes,.
Drugli MB, Larsson B. Children aged 4–8 years treated with parent behavior training and child therapy because of conduct problems: generalisation effects to day-care and school settings. Eur Child Adolesc Psychiatr. 2006;15(7):392-9. [pmid: 16614786]. Exclude: Not an included population, OVID-Medline.
Drugli MB, Larsson B, Clifford G. Changes in social competence in young children treated because of conduct problems as viewed by multiple informants. Eur Child Adolesc Psychiatr. 2007;16(6):370-8. [pmid: 17401611]. Exclude: Not an included population, OVID-Medline.
Drugli MB, Larsson B, Fossum S, et al. Five- to six-year outcome and its prediction for children with ODD/CD treated with parent behavior training. J Child Psychol Psychiatr. 2010;51(5):559-66. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Ducharme JM, Spencer T, Davidson A, et al. Errorless compliance training: building a cooperative relationship between parents with brain injury and their oppositional children. Am J Orthopsychiatry. 2002;72(4):585-95. [pmid: 15792043]. Exclude: Not an included population, OVID-Medline.
Duggan CM, Mitchell G, Nikles CJ, et al. Managing ADHD in general practice. N of 1 trials can help!. Aust Fam Physician. 2000;29(12):1205-9. [pmid: 11140235]. Exclude: No included comparisons of outcomes, OVID-Medline.
Dumas JE. Interactional correlates of treatment outcome in behavioral parent behavior training. J Consult Clin Psychol. 1984;52(6):946-54. [pmid: 6520287]. Exclude: Not an included population, OVID-Medline.
Dumas JE, Wahler RG. Indiscriminate mothering as a contextual factor in aggressive-oppositional child behavior: “damned if you do and damned if you don’t”. J Abnorm Child Psychol. 1985;13(1):1-17. [pmid: 3973245]. Exclude: No included comparisons of outcomes, OVID-Medline.
Dumas JE, Albin JB. Parent behavior training outcome: does active parental involvement matter. Behav Res Ther. 1986;24(2):227-30. [pmid: 3964188]. Exclude: Not an included population, OVID-Medline.
Dupaul GJ, Rapport MD. Does methylphenidate normalize the classroom performance of children with attention deficit disorder. J Am Acad Child Adolesc Psychiatry. 1993;32(1):190-8. Exclude: No included comparisons of outcomes,. [pmid: 8428871].
Dupaul GJ, Barkley RA, McMurray MB. Response of children with ADHD to methylphenidate: interaction with internalizing symptoms. J Am Acad Child Adolesc Psychiatr y. 1994;33(6):894-903. [pmid: 8083147]. Exclude: No included comparisons of outcomes, OVID-Medline.
Dupaul GJ, Ervin RA, Hook CL, et al. Peer tutoring for children with attention deficit hyperactivity disorder: effects on classroom behavior and academic performance. J Appl Behav Anal. 1998;31(4):579-92. [pmid: 9891395]. Exclude: No included comparisons of outcomes, OVID-Medline.
DuPaul GJ, Jitendra AK, Volpe RJ, et al. Consultation-based academic interventions for children with ADHD: Effects on reading and mathematics achievement. J Abnorm Child Psychol. 2006;34(5):633-46. Exclude: No included comparisons of outcomes, ERIC Database.
Durell TM, Pumariega AJ, Rothe EM, et al. Effects of open-label atomoxetine on African-American and Caucasian pediatric outpatients with attention-deficit/hyperactivity disorder. Ann Clin Psychiatry. 2009;21(1):26-37. [pmid: 19239830]. Exclude: No included comparisons of outcomes, OVID-Medline.
Dvorakova M, Jezova D, Blazicek P, et al. Urinary catecholamines in children with attention deficit hyperactivity disorder (ADHD): modulation by a polyphenolic extract from pine bark (pycnogenol). Nutr Neurosci. 2007;10(3–4):151-7. [pmid: 18019397]. Exclude: Not an included population, OVID-Medline.
Dykman RA, Ackerman PT, McCray DS. Effects of methylphenidate on selective and sustained attention in hyperactive, reading-disabled, and presumably attention-disordered boys. J Nerv Ment Dis. 1980;168(12):745-52. Exclude: No included comparisons of outcomes,. [pmid: 7452214].
Dykman RA, Holcomb PJ, Ackerman PT, et al. Auditory ERP augmentation-reducion and methylphenidate dosage needs in attention and reading disordered children. Psychiatry Res. 1983;(3):255-69. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6578535].
Dyme IZ, Sahakian BJ, Golinko BE, et al. Perseveration induced by methylphenidate in children: preliminary findings. Prog Neuropsychopharmacol Biol Psychiatr. 1982;6(3):269-73. [pmid: 6890702]. Exclude: No included comparisons of outcomes, OVID-Medline.
Eapen V, Gururaj AK. Risperidone treatment in 12 children with developmental disorders and attention-deficit/hyeractivity disorder. Prim Care Comp J Clin Psychiatr. 2005;(5):221-4. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Eckenrode J, Zielinski D, Smith E, et al. Child maltreatment and the early onset of problem behaviors: can a program of nurse home visitation break the link. Dev Psychopathol. 2001;13(4):873-90. [pmid: 11771912]. Exclude: Not an included population, OVID-Medline.
Eddy JM, Reid JB, Stoolmiller M, et al. Outcomes during middle school for an elementary school-based preventive intervention for conduct problems: Follow-up results from a randomized trial. Behav Ther. 2003;34(4):535-52. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Edwards L. Effectiveness of self-management on attentional behavior and reading comprehension for children with attention deficit disorder. Child Fam Behav Ther. 1995;17(2):1-17. Exclude: Not an included population, ERIC Database.
Efron D, Jarman F, Barker M. Methylphenidate versus dexamphetamine in children with attention deficit hyperactivity disorder: A double-blind, crossover trial. Pediatrics. 1997;100(6):E6. [pmid: 9382907]. Exclude: No included comparisons of outcomes, OVID-Medline.
Efron D, Jarman FC, Barker MJ. Medium-term outcomes are comparable with short-term outcomes in children with ADHD treated with stimulants. J Paediatr Child Health. 1999;35(5):10. Exclude: No included comparisons of outcomes,.
Efron D, Jarman FC, Barker MJ. Medium-term outcomes are comparable with short-term outcomes in children with attention deficit hyperactivity disorder treated with stimulant medication. J Paediatr Child Health. 2000;36(5):457-61. [pmid: 11036801]. Exclude: No included comparisons of outcomes, OVID-Medline.
Efron DJ. Methylphenidate vs dexamphetamine in children with attention deficit hyperactivity disorder: a double-blind cross-over trial. J Paediatr Child Health. 1997;33(4):A21. Exclude: No included comparisons of outcomes,.
Egeland B. Training impulsive children in the use of more efficient scanning techniques. Proceed Ann Convention APA. 1973:677-8. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Egger J, Stolla A, McEwen LM. Controlled trial of hyposensitisation in children with food-induced hyperkinetic syndrome. Lancet. 1992;(8802):1150-3. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 1349376].
Eisenberg J, Asnis GM, Van Praag HM, et al. Effect of tyrosine on attention deficit disorder with hyperactivity. J Clin Psychiatry. 1988;(5):193-5. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3284877].
Elia J, Borcherding BG, Potter WZ, et al. Stimulant drug treatment of hyperactivity: Biochemical correlates. Clin Pharmacol Ther. 1990;(1):57-66. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 2196146].
Elia J, Borcherding BG, Rapoport JL, et al. Methylphenidate and dextroamphetamine treatments of hyperactivity: are there true nonresponders. Psychiatry Res. 1991;36(2):141-55. [pmid: 2017529]. Exclude: No included comparisons of outcomes, OVID-Medline.
Elia J, Welsh PA, Gullotta CS, et al. Classroom academic performance: improvement with both methylphenidate and dextroamphetamine in ADHD boys. J Child Psychol Psychitr Allied Disc. 1993;34(5):785-804. [pmid: 8340445]. Exclude: No included comparisons of outcomes, OVID-Medline.
Ellis MJ, Witt PA, Reynolds R, et al. Methylphenidate and the activity of hyperactives in the informal setting. Child Dev. 1974;45(1):217-20. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 4820278].
Epperson J, Valum JL. The effects of stimulant medications on the art products of ADHD children. Art Ther J Am Art Ther Assoc. 1992;9(1):36-41. Exclude: No included comparisons of outcomes, ERIC Database.
Epstein JN, Rabiner D, Johnson DE, et al. Improving attention-deficit/hyperactivity disorder treatment outcomes through use of a collaborative consultation treatment service by community-based pediatricians: a cluster randomized trial. Arch Pediatr Adolesc Med. 2007;161(9):835-40. [pmid: 17768282]. Exclude: No included intervention compared, OVID-Medline.
Epstein JN, Casey BJ, Tonev ST, et al. ADHD- and medication-related brain activation effects in concordantly affected parent-child dyads with ADHD. J Child Psychol Psychitr Allied Disc. 2007;48(9):899-913. [pmid: 17714375]. Exclude: No included comparisons of outcomes, OVID-Medline.
Ercan ES, Varan A, Deniz U. Effects of combined treatment on Turkish children diagnosed with attention-deficit/hyperactivity disorder: a preliminary report. J Child Adolesc Psychopharmacol. 2005;15(2):203-19. [pmid: 15910205]. Exclude: No included comparisons of outcomes, OVID-Medline.
Escobar R, Montoya A, Polavieja P, et al. Evaluation of patients’ and parents’ quality of life in a randomized placebo-controlled atomoxetine study in attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(3):253-63. [pmid: 19519260]. Exclude: No included comparisons of outcomes, OVID-Medline.
Etscheidt S. Reducing aggressive behavior and improving self-control: A cognitive-behavioral training program for behaviorally disordered adolescents. Behav Dis. 1991;16(2):107-15. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Evans RW, Gualtieri CT, Hicks RE. A neuropathic substrate for stimulant drug effects in hyperactive children. Clin Neuropharmacol. 1986;(3):264-81. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3719572].
Evans RW, Gualtieri CT, Amara I. Methylphenidate and memory: Dissociated effects in hyperactive children. Psychopharmacol. 1986;(2):211-6. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Everett J, Thomas J, Cote F, et al. Cognitive effects of psychostimulant medication in hyperactive children. Child Psychiatry Hum Dev. 1991;22(2):79-87. Exclude: Not an included population, OVID-PsycINFO. [pmid: 1686856].
Eyberg SM, Funderburk BW, Hembree-Kigin TL, et al. Parent-child interaction therapy with behavior problem children: One and two year maintenance of treatment effects in the family. Child Fam Behav Ther. 2001;23(4):1-20. Exclude: Not an included population, OVID-PsycINFO.
Fabiano GA, Chacko A, Pelham WE Jr, et al. A comparison of behavioral parent behavior training programs for fathers of children with attention-deficit/hyperactivity disorder. Behav Ther. 2009;40(2):190-204. [pmid: 19433150]. Exclude: No included comparisons of outcomes, OVID-Medline.
Fabiano GA, Pelham WEJr, Manos MJ, et al. An evaluation of three time-out procedures for children with attention deficit/hyperactivity disorder. Behav Ther. 2004;35(3):449-69. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Fabiano GA, Pelham WE Jr, Gnagy EM, et al. The single and combined effects of multiple intensities of behavior modification and methylphenidate for children with attention deficit hyperactivity disorder in a classroom setting. Sch Psychol Rev. 2007;36(2):195-216. Exclude: No included comparisons of outcomes, ERIC Database.
Fabienne B. Effects of mother’s mediating strategies on cognitive modifiability and behavioral outcomes of the child with ADHD: Links with parental, contextual, and child characteristics. J Cognit Educ Psychol. 2008;7(2):300-1. Exclude: Not an included population, OVID-PsycInfo.
Falcomata TS, Northup JA, Dutt A, et al. A preliminary analysis of instructional control in the maintenance of appropriate behavior. J Appl Behav Anal. 2008;41(3):429-34. [pmid: 18816982]. Exclude: No included comparisons of outcomes, OVID-Medline.
Faraone SV, Pliszka SR, Olvera RL, et al. Efficacy of Adderall and methylphenidate in attention deficit hyperactivity disorder: a reanalysis using drug-placebo and drug-drug response curve methodology. J Child Adolesc Psychopharmacol. 2001;11(2):171-80. [pmid: 11436957]. Exclude: No included comparisons of outcomes, OVID-Medline.
Faraone SV, Short EJ, Biederman J, et al. Efficacy of Adderall and methylphenidate in attention deficit hyperactivity disorder: a drug-placebo and drug-drug response curve analysis of a naturalistic study. Int J Neuropsychopharmacol. 2002;5(2):121-9. [pmid: 12135536]. Exclude: No included comparisons of outcomes, OVID-Medline.
Faraone SV, Biederman J, Zimmerman B. An analysis of patient adherence to treatment during a 1-year, open-label study of OROS methylphenidate in children with ADHD. J Attention Disord. 2007;11(2):157-66. [pmid: 17494833]. Exclude: No included comparisons of outcomes, OVID-Medline.
Faraone SV, Glatt SJ, Bukstein OG, et al. Effects of once-daily oral and transdermal methylphenidate on sleep behavior of children with ADHD. J Attention Disord. 2009;12(4):308-15. [pmid: 18400982]. Exclude: No included comparisons of outcomes, OVID-Medline.
Faraone SV, Spencer TJ, Kollins SH, et al. Effects of lisdexamfetamine dimesylate treatment for ADHD on growth. J Am Acad Child Adolesc Psychiatry. 2010;49(1):24-32. Exclude: No included comparisons of outcomes, OVID-Embase. [pmid: 20215923].
Faraone SV, Glatt SJ. Effects of extended-release guanfacine on ADHD symptoms and sedation-related adverse events in children with ADHD. J Attention Disord. 2010;13(5):532-8. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Fehlings DL, Roberts W, Humphries T, et al. Attention deficit hyperactivity disorder: Does cognitive behavioral therapy improve home behavior. J Dev Behav Pediatr. 1991;12(4):223-8. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 1939676].
Feigin A, Kurlan R, McDermott M, et al. A double blind placebo controlled cross over study of deprenyl in children with Tourette’s syndrome (TS) and attention-deficit hyperactivity disoder (ADHD). Neurology. 1995;45:254. Exclude: No included comparisons of outcomes,.
Feldman H, Crumrine P, Handen BL, et al. Methylphenidate in children with seizures and attention-deficit disorder. Am J Dis Child. 1989;143(9):1081-6. Exclude: No included comparisons of outcomes,. [pmid: 2672786].
Feldman MA, Condillac RA, Tough S, et al. Effectiveness of community positive behavioral intervention for persons with developmental disabilities and severe behavior disorders. Behav Ther. 2002;(3):377-98. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Ferguson HB, Simeon JG. Evaluating drug effects on children’s cognitive functioning. Prog Neuropsychopharmacol Biol Psychiatr. 1984;8(4–6):683-6. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Ferguson LR, Partyka LB, Lester BM. Patterns of parent perception differentiating clinic from nonclinic children. J Abnorm Child Psychol. 1974;2(3):169-81. [pmid: 4443497]. Exclude: Not an included population, OVID-Medline.
Fernandez MA, Eyberg SM. Predicting treatment and follow-up attrition in parent-child interaction therapy. J Abnorm Child Psychol. 2009;37(3):431-41. [pmid: 19096926]. Exclude: Not an included population, OVID-Medline.
Fiedler NL, Ullman DG. The effects of stimulant drugs on curiosity behaviors of hyperactive boys. J Abnorm Child Psychol. 1983;(2):193-206. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6619433].
Findling RL, McNamara NK, Branicky LA, et al. A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry. 2000;39(4):509-16. [pmid: 10761354]. Exclude: No included comparisons of outcomes, OVID-Medline.
Findling RL, Short EJ, Manos MJ. Developmental aspects of psychostimulant treatment in children and adolescents with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2001;40(12):1441-7. [pmid: 11765290]. Exclude: No included comparisons of outcomes, OVID-Medline.
Findling RL, McNamara NK, Stansbrey RJ, et al. A pilot evaluation of the safety, tolerability, pharmacokinetics, and effectiveness of memantine in pediatric patients with attention-deficit/hyperactivity disorder combined type. J Child Adolesc Psychopharmacol. 2007;17(1):19-33. [pmid: 17343551]. Exclude: No included comparisons of outcomes, OVID-Medline.
Findling RL, Short EJ, McNamara NK, et al. Methylphenidate in the treatment of children and adolescents with bipolar disorder and attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2007;46(11):1445-53. [pmid: 18049294]. Exclude: No included comparisons of outcomes, OVID-Medline.
Findling RL, Bukstein OG, Melmed RD, et al. “A randomized, double-blind, placebo-controlled, parallel-group study of methylphenidate transdermal system in pediatric patients with attention-deficit/hyperactivity disorder”: Correction. J Clin Psychiatry. 2008;69(2):329. Exclude: No included comparisons of outcomes, OVID-PsycInfo.
Findling RL, Bukstein OG, Melmed RD, et al. A randomized, double-blind, placebo-controlled, parallel-group study of methylphenidate transdermal system in pediatric patients with attention-deficit/hyperactivity disorder. J Clin Psychiatry. 2008;69(1):149-59. Exclude: No included comparisons of outcomes, OVID-PsycInfo. [pmid: 18312050].
Fine S, Jewesson B. Active drug placebo trial of methylphenidate--a clinical service for children with an attention deficit disorder. Canadian Journal of Psychiatry. 1989;34(5):447-9. Exclude: No included comparisons of outcomes,.
Fine S, Johnston C. Drug and placebo side effects in methylphenidate-placebo trial for attention deficit hyperactivity disorder. Child Psychiatry Hum Dev. 1993;24(1):25-30. [pmid: 8404241]. Exclude: No included comparisons of outcomes, OVID-Medline.
Finnerty RJ, Soltys JJ, Cole JO. The use of D-amphetamine with hyperkinetic children. Psychopharmacologia. 1971;21(3):302-8. Exclude: No included comparisons of outcomes,. [pmid: 5095419].
Firestone P, Kelly MJ, Goodman JT, et al. Differential effects of parent behavior training and stimulant medication with hyperactives. A progress report. J Am Acad Child Psychiatry. 1981;20(1):135-47. Exclude: No included comparisons of outcomes,. [pmid: 7217546].
Firestone P, Crowe D, Goodman JT, et al. Vicissitudes of follow-up studies: Differential effects of parent behavior training and stimulant medication with hyperactives. Am J Orthopsychiatry. 1986;(2):184-94. Exclude: Longterm outcomes from pre 1997 publication, OVID-EMBASE. [pmid: 3706498].
Firestone P. Factors associated with children’s adherence to stimulant medication. Am J Orthopsychiatry. 1982;52(3):447-57. Exclude: Not an included population, OVID-PsycINFO. [pmid: 7114173].
Fischer M, Newby RF. Assessment of stimulant response in ADHD children using a refined multimethod clinical protocol. J Clin Child Psychol. 1991;20(3):232-44. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Fitzpatrick PA, Klorman R, Brumaghim JT, et al. Effects of sustained-release and standard preparations of methylphenidate on attention deficit disorder. J Am Acad Child Adolesc Psychiatry. 1992;31(2):226-34. [pmid: 1564023]. Exclude: No included comparisons of outcomes, OVID-Medline.
Fleischman MJ. A replication of Patterson’s “Intervention for boys with conduct problems”. J Consult Clin Psychol. 1981;49(3):342-51. [pmid: 7276323]. Exclude: Not an included population, OVID-Medline.
Flintoff MM. Methylphenidate increases selectivity of visual scanning in children referred for hyperactivity. J Abnorm Child Psychol. 1982;10(2):145-61. Exclude: No included comparisons of outcomes, OVID-PsycInfo. [pmid: 7108059].
Flisher AJ, Sorsdahl K, Hatherill S, et al. Packages of care for attention-deficit hyperactivity disorder in low- and middle-income countries. PLoS Med. 2010;7(2):e1000235. [pmid: 20186271]. Exclude: Not an included population, OVID-Medline.
Flood WA, Wilder DA, Flood AL, et al. Peer-mediated reinforcement plus prompting as treatment for off-task behavior in children with attention deficit hyperactivity disorder. J Appl Behav Anal. 2002;35(2):199-204. [pmid: 12102141]. Exclude: No included comparisons of outcomes, OVID-Medline.
Flory JD, Newcorn JH, Miller C, et al. Serotonergic function in children with attention-deficit hyperactivity disorder: relationship to later antisocial personality disorder. Br J Psychiatry. 2007;190:410-4. [pmid: 17470955]. Exclude: No included intervention compared, OVID-Medline.
Fonagy P, Target M. The efficacy of psychoanalysis for children with disruptive disorders. J Am Acad Child Adolesc Psychiatry. 1994;33(1):45-55. [pmid: 8138520]. Exclude: Not an included population, OVID-Medline.
Forness SR, Cantwell DP, Swanson JM, et al. Differential effects of stimulant medication on reading performance of boys with hyperactivity with and without conduct disorder. J Learn Disabil. 1991;24(5):304-10. Exclude: No included comparisons of outcomes,. [pmid: 2045727].
Fossum S, Morch WT, Handegard BH, et al. Parent behavior training for young Norwegian children with ODD and CD problems: predictors and mediators of treatment outcome. Scand J Psychol. 2009;50(2):173-81. [pmid: 19170971]. Exclude: No included comparisons of outcomes, OVID-Medline.
Foster EM, Olchowski AE, Webster-Stratton CH. Is stacking intervention components cost-effective? An analysis of the Incredible Years program. J Am Acad Child Adolesc Psychiatry. 2007;46(11):1414-24. [pmid: 18049291]. Exclude: Not an included population, OVID-Medline.
Fowler I. The relationship of certain perinatal factors to behavior, speech, or learning problems in children. South Med J. 1965;58(10):1245-8. [pmid: 5841449]. Exclude: Not an included population, OVID-Medline.
Frame K. Empowering preadolescents With ADHD: demons or delights. Adv Nurse Sci. 2003;26(2):131-9. [pmid: 12795541]. Exclude: No included comparisons of outcomes, OVID-Medline.
Frank Y. Visual event related potentials after methylphenidate and sodium valproate in children with attention deficit hyperactivity disorder. Clin Electroencephalogr. 1993;24(1):19-24. [pmid: 8420693]. Exclude: No included comparisons of outcomes, OVID-Medline.
Frankel F, Myatt R, Cantwell DP, et al. Parent-assisted transfer of children’s social skills training: effects on children with and without attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1997;36(8):1056-64. [pmid: 9256585]. Exclude: No included comparisons of outcomes, OVID-Medline.
Frankenberger W, Cannon C. Effects of Ritalin on academic achievement from first to fifth grade. Int J Disabil Dev Educ. 1999;46(2):199-221. Exclude: No included intervention compared, OVID-PsycINFO.
Frei H, Thurneysen A. Treatment for hyperactive children: homeopathy and methylphenidate compared in a family setting. Br Homeopath J. 2001;90(4):183-8. [pmid: 11680802]. Exclude: No included intervention compared, OVID-Medline.
Freibergs V, Douglas VI, Weiss G. The effect of chlorpromazine on concept learning in hyperactive children under two conditions of reinforcement. Psychopharmacologia. 1968;13(4):299-310. Exclude: No included comparisons of outcomes,. [pmid: 4881014].
French BF, Zentall SS, Bennett D. Short-term memory of children with and without characteristics of attention deficit hyperactivity disorder. Learn Indiv Differ. 2001;13(3):205-25. Exclude: Not an included population, OVID-PsycINFO.
Friedmann N, Thomas J, Carr R, et al. Effect on growth in pemoline-treated children with attention deficit disorder. Am J Dis Child. 1981;135(4):329-32. [pmid: 7211792]. Exclude: No included comparisons of outcomes, OVID-Medline.
Frijling-Schreuder EC. The vicissitudes of aggression in normal development, in childhood neurosis and in childhood psychosis. Int J Psychoanal. 1972;53(2):185-90. [pmid: 5057062]. Exclude: Not an included population, OVID-Medline.
Frobel Smithee JA, Klorman R, Brumaghim JT, et al. Methylphenidate does not modify the impact of response frequency or stimulus sequence on performance and event-related potentials of children with attention deficit hyperactivity disorder. J Abnorm Child Psychol. 1998;(4):233-45. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 9700516].
Froehlich TE, Lanphear BP, Epstein JN, et al. Prevalence, recognition, and treatment of attention-deficit/hyperactivity disorder in a national sample of US children. Arch Pediatr Adolesc Med. 2007;161(9):857-64. [pmid: 17768285]. Exclude: No included intervention compared, OVID-Medline.
Froelich J, Doepfner M, Lehmkuhl G. Effects of combined cognitive behavioral treatment with parent management training in ADHD. Behav Cognit Psychother. 2002;(1):111-5. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Fung ALC. A qualitative evaluation of social-cognitive changes in children with reactively aggressive behaviors. J Sch Violence. 2007;6(1):45-64. Exclude: No included comparisons of outcomes,.
Gadow KD, Nolan EE, Sverd J, et al. Methylphenidate in aggressive-hyperactive boys: I. Effects on peer aggression in public school settings. J Am Acad Child Adolesc Psychiatry. 1990;29(5):710-8. [pmid: 2228923]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gadow KD, Nolan EE, Sverd J. Methylphenidate in hyperactive boys with comorbid tic disorder: II. Short-term behavioral effects in school settings. J Am Acad Child Adolesc Psychiatry. 1992;(3):462-71. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 1592778].
Gadow KD, Nolan E, Sprafkin J, et al. School observations of children with attention-deficit hyperactivity disorder and comorbid tic disorder: effects of methylphenidate treatment. J Dev Behav Pediatr. 1995;16(3):167-76. [pmid: 7560119]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gadow KD, Nolan EE, Sverd J, et al. Anxiety and depression symptoms and response to methylphenidate in children with attention-deficit hyperactivity disorder and tic disorder. J Clin Psychopharmacol. 2002;22(3):267-74. [pmid: 12006897]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gadow KD, Paolicelli LM, Nolan EE, et al. Methylphenidate in aggressive hyperactive boys: II. Indirect effects of medication treatment on peer behavior. J Child Adolesc Psychopharmacol. 1992;2(1):49-61. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 19630622].
Gan J, Cantwell DP. Dosage effects of methylphenidate on paired associate learning: Positive/negative placebo responders. J Am Acad Child Psychiatry. 1982;21(3):237-42. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 7096841].
Gardner F, Burton J, Klimes I. Randomised controlled trial of a parenting intervention in the voluntary sector for reducing child conduct problems: outcomes and mechanisms of change. J Child Psychol Psychitr Allied Disc. 2006;47(11):1123-32. [pmid: 17076751]. Exclude: Not an included population, OVID-Medline.
Gardner F, Connell A, Trentacosta CJ, et al. Moderators of outcome in a brief family-centered intervention for preventing early problem behavior. J Consult Clin Psychol. 2009;77(3):543-53. [pmid: 19485594]. Exclude: Not an included population, OVID-Medline.
Garfinkel BD, Wender PH, Sloman L, et al. Tricyclic antidepressant and methylphenidate treatment of attention deficit disorder in children. J Am Acad Child Psychiatry. 1983;22(4):343-8. Exclude: No included comparisons of outcomes,. [pmid: 6875128].
Garfinkel BD, Webster CD, Sloman L. Responses to methylphenidate and varied doses of caffeine in children with attention deficit disorder. Can J Psychiatr. 1981;26(6):395-401. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Gau SS, Chen SJ, Chou WJ, et al. National survey of adherence, efficacy, and side effects of methylphenidate in children with attention-deficit/hyperactivity disorder in Taiwan. J Clin Psychiatry. 2008;69(1):131-40. [pmid: 18312048]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gaylin W. Behavior control: from the brain to the mind. Hastings Cent Rep. 2009;39(3):13-6. [pmid: 19537615]. Exclude: Not an included population, OVID-Medline.
Germano M, Meleleo D, Montorfano G, et al. Plasma, red blood cells phospholipids and clinical evaluation after long chain omega-3 supplementation in children with attention deficit hyperactivity disorder (ADHD). Nutr Neurosci. 2007;10(1–2):1-9. [pmid: 17539477]. Exclude: No included comparisons of outcomes, OVID-Medline.
Ghuman JK, Ginsburg GS, Subramaniam G, et al. Psychostimulants in preschool children with attention-deficit/hyperactivity disorder: clinical evidence from a developmental disorders institution. J Am Acad Child Adolesc Psychiatry. 2001;40(5):516-24. [pmid: 11349695]. Exclude: No included intervention compared, OVID-Medline.
Gibbs A, Moor S, Frampton C, et al. Impact of psychosocial interventions on children with disruptive and emotional disorders treated in a health camp. Aust N Z J Psychiatry. 2008;42(9):789-99. [pmid: 18696283]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gimpel GA, Collett BR, Veeder MA, et al. Effects of stimulant medication on cognitive performance of children with ADHD. Clin Pediatr. 2005;44(5):405-11. [pmid: 15965546]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gittelman-Klein R, Klein DF, Abikoff H, et al. Relative efficacy of methylphenidate and behavior modification in hyperkinetic children: an interim report. J Abnorm Child Psychol. 1976;4(4):361-79. Exclude: No included comparisons of outcomes,. [pmid: 1002948].
Gittelman KR, Mannuzza S. Hyperactive boys almost grown up. III. Methylphenidate effects on ultimate height. Arch Gen Psychiatry. 1988;(12):1131-4. Exclude: No included intervention compared, OVID-EMBASE. [pmid: 3058089].
Gittelman KR, Landa B, Mattes JA, et al. Methylphenidate and growth in hyperactive children. A controlled withdrawal study. Arch Gen Psychiatry. 1988;(12):1127-1130. Exclude: Longterm outcomes from pre 1997 publication, OVID-EMBASE. [pmid: 3058088].
Glueck ET, Glueck S. Identification of potential delinquents at 2–3 years of age. Int J Soc Psychiatry. 1966;12(1):5-16. [pmid: 5906144]. Exclude: Not an included population, OVID-Medline.
Goez H, Back-Bennet O, Zelnik N. Differential stimulant response on attention in children with comorbid anxiety and oppositional defiant disorder. J Child Neurol. 2007;22(5):538-42. [pmid: 17690058]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gol D, Jarus T. Effect of a social skills training group on everyday activities of children with attention-deficit-hyperactivity disorder. Dev Med Child Neurol. 2005;47(8):539-45. [pmid: 16108454]. Exclude: No included comparisons of outcomes, OVID-Medline.
Goldhaber SB. Summer day treatment for children with attention-deficit hyperactivity disorder. Hosp Community Psychiatr. 1991;(4):422-4. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Goldman W, Seltzer R, Reuman P. Association between treatment with central nervous system stimulants and Raynaud’s syndrome in children: a retrospective case-control study of rheumatology patients. Arthritis Rheum. 2008;58(2):563-6. [pmid: 18240233]. Exclude: No included comparisons of outcomes, OVID-Medline.
Golinko BE, Rennick PM, Lewis RF. Predicting stimulant effectiveness in hyperactive children with a repeatable neuropsychological battery: a preliminary study. Prog Neuropsychopharmacol Biol Psychiatr. 1981;5(1):65-8. Exclude: No included comparisons of outcomes,.
Golinko BE. Side effects of dexedrine in hyperactive children: Operationalization and quantification in a short-term trial. Prog Neuropsychopharmacol Biol Psychiatr. 1982;6(2):175-83. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Goodman D, Faraone SV, Adler LA, et al. Interpreting ADHD rating scale scores: Linking ADHD rating scale scores and CGI levels in two randomized controlled trials of lisdexamfetamine dimesylate in ADHD. Prim Psychiatr. 2010;17(3):44-52. Exclude: No included comparisons of outcomes, OVID-Embase.
Gordon DA, Forehand R, Picklesimer DK. The effects of dextroamphetamine on hyperactive children using multiple outcome measures. J Clin Child Psychol. 1978;7(2):125-8. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Gordon SB, Lerner LL, Keefe FJ. Responsive parenting: an approach to training parents of problem children. Am J Community Psychol. 1979;7(1):45-56. [pmid: 453123]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gorski PA. Racing cain. J Dev Behav Pediatr. 2002;23(2):95. [pmid: 11943971]. Exclude: No included intervention compared, OVID-Medline.
Grcevich S, Rowane WA, Marcellino B, et al. Retrospective comparison of Adderall and methylphenidate in the treatment of attention deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 2001;11(1):35-41. [pmid: 11322743]. Exclude: No included comparisons of outcomes, OVID-Medline.
Greenberg LM, Yellin AM, Spring C, et al. Clinical effects of imipramine and methylphenidate in hyperactive children. Int J Ment Health. 1975;4(1–2):144-56. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Greenfield BJ, Senecal J. Recreational multifamily therapy for troubled children. Am J Orthopsychiatry. 1995;65(3):434-9. [pmid: 7485429]. Exclude: No included comparisons of outcomes, OVID-Medline.
Greenhill LL, Puig-Antich J, Novacenko H. Prolactin, growth hormone and growth responses in boys with attention deficit disorder and hyperactivity treated with methylphenidate. J Am Acad Child Psychiatry. 1984;(1):58-67. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6693678].
Greenhill LL, Swanson JM, Vitiello B, et al. Impairment and deportment responses to different methylphenidate doses in children with ADHD: the MTA titration trial. J Am Acad Child Adolesc Psychiatry. 2001;40(2):180-7. [pmid: 11211366]. Exclude: No included comparisons of outcomes, OVID-Medline.
Greenhill LL, Swanson JM, Steinhoff K, et al. A pharmacokinetic/pharmacodynamic study comparing a single morning dose of adderall to twice-daily dosing in children with ADHD. J Am Acad Child Adolesc Psychiatry. 2003;42(10):1234-41. [pmid: 14560174]. Exclude: No included comparisons of outcomes, OVID-Medline.
Greenhill L, Kollins S, Abikoff H, et al. Erratum: “Efficacy and Safety of Immediate-Release MPH Treatment for Preschoolers With ADHD”. J Am Acad Child Adolesc Psychiatry. 2007;46(1):141. Exclude: Not an included population, OVID-PsycInfo.
Greenhill LL. Lithium carbonate in the treatment of hyperactive children. Arch Gen Psychiatry. 1973;28(5):636-40. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 4573417].
Grin’-Yatsenko VA, Kropotov Y, Ponomarev VA, et al. Effect of biofeedback training of sensorimotor and beta 1EEG rhythms on attention parameters. Hum Physiol. 2001;27(3):259-66. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Grizenko N, Papineau C, Sayegh L. Effectiveness of a multimodal day treatment program for children with disruptive behavior problems. J Am Acad Child Adolesc Psychiatry. 1993;(1):127-34. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 8428865].
Grizenko N. Outcome of multimodal day treatment for children with severe behavior problems: a five-year follow-up. J Am Acad Child Adolesc Psychiatry. 1997;36(7):989-97. [pmid: 9204678]. Exclude: No included comparisons of outcomes, OVID-Medline.
Grizenko N, Papineau D, Sayegh L. A comparison of day treatment and outpatient treatment for children with disruptive behavior problems. Can J Psychiatr. 1993;38(6):432-5. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Groen Y, Mulder LJ, Wijers AA, et al. Methylphenidate improves diminished error and feedback sensitivity in ADHD: An evoked heart rate analysis. Biol Psychol. 2009;82(1):45-53. [pmid: 19464338]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gronlund MA, Aring E, Landgren M, et al. Visual function and ocular features in children and adolescents with attention deficit hyperactivity disorder, with and without treatment with stimulants. Eye. 2007;21(4):494-502. [pmid: 16518370]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gross-Tsur V, Shalev RS, Badihi N, et al. Efficacy of methylphenidate in patients with cerebral palsy and attention-deficit hyperactivity disorder (ADHD). J Child Neurol. 2002;17(12):863-6. [pmid: 12593456]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gross MD. Caffeine in the treatment of children with minimal brain dysfunction or hyperkinetic syndrome. Psychosomatics. 1975;16(1):26-7. [pmid: 1101283]. Exclude: Not an included population, OVID-Medline.
Gross MD. A comparison of dextro-amphetamine and racemic-amphetamine in the treatment of the hyperkinetic syndrome or minimal brain dysfunction. Dis Nerv Syst. 1976;37(1):14-6. [pmid: 1106966]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gross MD. Growth of hyperkinetic children taking methylphenidate, dextroamphetamine, or imipramine/desipramine. Pediatrics. 1976;58(3):423-31. [pmid: 958770]. Exclude: Not an included population, OVID-Medline.
Gross MD, Tofanelli RA, Butzirus SM, et al. The effect of diets rich in and free from additives on the behavior of children with hyperkinetic and learning disorders. J Am Acad Child Adolesc Psychiatry. 1987;(1):53-5. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3584001].
Gruber R, Joober R, Grizenko N, et al. Dopamine transporter genotype and stimulant side effect factors in youth diagnosed with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(3):233-9. [pmid: 19519258]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gualtieri CT, Hicks RE, Mayo JP, et al. The persistence of stimulant effects in chronically treated children: Further evidence of an inverse relationship between drug effects and placebo levels of response. Psychopharmacol. 1984;(1):44-7. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Gualtieri CT, Evans RW. Motor performance in hyperactive children treated with imipramine. Percept Mot Skills. 1988;(3):763-9. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3043370].
Gualtieri CT. Growth hormone and prolactin secretion in adults and hyperactive children: Relation to methylphenidate serum levels. Psychoneuroendocrinology. 1981;6(4):331-9. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 7323251].
Gucuyener K, Erdemoglu AK, Senol S, et al. Use of methylphenidate for attention-deficit hyperactivity disorder in patients with epilepsy or electroencephalographic abnormalities. J Child Neurol. 2003;18(2):109-12. [pmid: 12693777]. Exclude: No included intervention compared, OVID-Medline.
Guimaraes AP, Zeni C, Polanczyk G, et al. MAOA is associated with methylphenidate improvement of oppositional symptoms in boys with attention deficit hyperactivity disorder. Int J Neuropsychopharmacol. 2009;12(5):709-14. [pmid: 19309535]. Exclude: No included comparisons of outcomes, OVID-Medline.
Gumpel TP. Are social competence difficulties caused by performance or acquisition deficits? The importance of self-regulatory mechanisms. Psychol Schools. 2007;44(4):351-72. Exclude: No included comparisons of outcomes, ERIC Database.
Gundersen K, Svartdal F. Aggression replacement training in Norway: Outcome evaluation of 11 Norwegian student projects. Scand J Educ Res. 2006;50(1):63-81. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Haas M, Karcher K, Pandina GJ. Treating disruptive behavior disorders with risperidone: a 1-year, open-label safety study in children and adolescents. J Child Adolesc Psychopharmacol. 2008;18(4):337-45. [pmid: 18759643]. Exclude: Not an included population, OVID-Medline.
Hagen H, Moore K, Wickham G, et al. Effect of the EYEPORTReg. system on visual function in ADHD children: A pilot study. J Behav Optometry. 2008;19(2):37-41. Exclude: No included comparisons of outcomes, OVID-PsycInfo.
Hagerman RJ, Murphy MA, Wittenberger MD. A controlled trial of stimulant medication in children with the fragile X syndrome. Am J Med Genet. 1988;30(1–2):377-92. Exclude: No included comparisons of outcomes,. [pmid: 3052064].
Hagino OR, Weller EB, Weller RA, et al. Untoward effects of lithium treatment in children aged four through six years. J Am Acad Child Adolesc Psychiatry. 1995;34(12):1584-90. [pmid: 8543529]. Exclude: No included comparisons of outcomes, OVID-Medline.
Hakkaart-van Roijen L, Zwirs BW, Bouwmans C, et al. Societal costs and quality of life of children suffering from attention deficient hyperactivity disorder (ADHD). Eur Child Adolesc Psychiatr. 2007;16(5):316-26. [pmid: 17483870]. Exclude: No included intervention compared, OVID-Medline.
Halliday R, Callaway E, Lynch M. Age, stimulant drug, and practice effects on P3 latency and concurrent reaction time. Ann N Y Acad Sci. 1984;425:357-61. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6588853].
Halliday R, Callaway E, Rosenthal JH. The visual ERP predicts clinical response to methylphenidate in hyperactive children. Psychophysiology. 1984;(1):114-21. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6366860].
Halliday R, Rosenthal JH, Naylor H, et al. Averaged evoked potential predictors of clinical improvement in hyperactive children treated with methylphenidate: An initial study and replication. Psychophysiology. 1976;13(5):429-40. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 972966].
Halmoy A, Fasmer OB, Gillberg C, et al. Occupational outcome in adult ADHD: impact of symptom profile, comorbid psychiatric problems, and treatment: a cross-sectional study of 414 clinically diagnosed adult ADHD patients. J Attention Disord. 2009;13(2):175-87. [pmid: 19372500]. Exclude: No included intervention compared, OVID-Medline.
Halperin JM, Gittelman R, Katz S, et al. Relationship between stimulant effect, electroencephalogram, and clinical neurological findings in hyperactive children. J Am Acad Child Psychiatry. 1986;(6):820-5. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3540074].
Hamarman S, Fossella J, Ulger C, et al. Dopamine receptor 4 (DRD4) 7-repeat allele predicts methylphenidate dose response in children with attention deficit hyperactivity disorder: a pharmacogenetic study. J Child Adolesc Psychopharmacol. 2004;14(4):564-74. [pmid: 15662148]. Exclude: No included comparisons of outcomes, OVID-Medline.
Hamazaki T, Hirayama S. The effect of docosahexaenoic acid-containing food administration on symptoms of attention-deficit/hyperactivity disorder - a placebo-controlled double-blind study. Eur J Clin Nutr. 2004;58(5):838. Exclude: No included intervention compared,. [pmid: 15116088].
Hamburger-Bar R, Eisenberg J, Belmaker RH. Animal and clinical studies of vasopressin effects on learning and memory. Isr J Med Sci. 1987;23(1–2):12-8. Exclude: No included comparisons of outcomes,. [pmid: 2952619].
Hampstead WJ. The effects of EMG-assisted relaxation training with hyperkinetic children: A behavioral alternative. Biofeedback Self Regul. 1979;4(2):113-25. Exclude: Not an included population, OVID-PsycINFO. [pmid: 476187].
Handen BL, Feldman H, Gosling A, et al. Adverse side effects of methylphenidate among mentally retarded children with ADHD. J Am Acad Child Adolesc Psychiatry. 1991;30(2):241-5. [pmid: 2016228]. Exclude: No included comparisons of outcomes, OVID-Medline.
Handen BL, Breaux AM, Janosky J, et al. Effects and noneffects of methylphenidate in children with mental retardation and ADHD. J Am Acad Child Adolesc Psychiatry. 1992;(3):455-61. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 1592777].
Handen BL, Janosky J, McAuliffe S, et al. Prediction of response to methylphenidate among children with ADHD and mental retardation. J Am Acad Child Adolesc Psychiatry. 1994;33(8):1185-93. [pmid: 7982869]. Exclude: No included comparisons of outcomes, OVID-Medline.
Handen BL, Janosky J, McAuliffe S. Long-term follow-up of children with mental retardation/borderline intellectual functioning and ADHD. J Abnorm Child Psychol. 1997;25(4):287-95. [pmid: 9304445]. Exclude: Not an included population, OVID-Medline.
Handen BL, Johnson CR, Lubetsky M. Efficacy of methylphenidate among children with autism and symptoms of attention-deficit hyperactivity disorder. J Autism Dev Disord. 2000;30(3):245-55. [pmid: 11055460]. Exclude: No included comparisons of outcomes, OVID-Medline.
Handen BL, Sahl R, Hardan AY. Guanfacine in children with autism and/or intellectual disabilities. J Dev Behav Pediatr. 2008;29(4):303-8. [pmid: 18552703]. Exclude: No included comparisons of outcomes, OVID-Medline.
Handen BL, Sagady AE, McAuliffe-Bellin S. Methylphenidate and play skills in children with intellectual disability and ADHD. J Ment Health Res Intell Disabil. 2009;2(1):1-10. Exclude: No included comparisons of outcomes, OVID-PsycInfo.
Hanisch C, Konrad K, Gunther T, et al. Age-dependent neuropsychological deficits and effects of methylphenidate in children with attention-deficit/hyperactivity disorder: a comparison of pre- and grade-school children. J Neural Transm. 2004;111(7):865-81. [pmid: 15206003]. Exclude: No included comparisons of outcomes, OVID-Medline.
Hansson K, Olsson M, Cederblad M. A salutogenic investigation and treatment of conduct disorder (CD). Nord J Psychiatr. 2004;58(1):5-16. [pmid: 14985149]. Exclude: No included comparisons of outcomes, OVID-Medline.
Harding KL, Judah RD, Gant C. Outcome-based comparison of Ritalin versus food-supplement treated children with AD/HD. Alternative Med Rev. 2003;8(3):319-30. [pmid: 12946241]. Exclude: No included comparisons of outcomes, OVID-Medline.
Harrison-Woolrych M, Garcia-Quiroga J, Ashton J, et al. Safety and usage of atypical antipsychotic medicines in children: a nationwide prospective cohort study. Drug Saf. 2007;30(7):569-79. [pmid: 17604408]. Exclude: No included comparisons of outcomes, OVID-Medline.
Hartley L. Hyperactivity, drugs and attention to features in a story. Br J Clin Psychol. 1986;(3):233-4. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3768581].
Hartman RR, Stage SA, Webster-Stratton C. A growth curve analysis of parent behavior training outcomes: examining the influence of child risk factors (inattention, impulsivity, and hyperactivity problems), parental and family risk factors. J Child Psychol Psychitr Allied Disc. 2003;44(3):388-98. [pmid: 12635968]. Exclude: Not an included population, OVID-Medline.
Harvey WJ, Reid G, Grizenko N, et al. Fundamental movement skills and children with attention-deficit hyperactivity disorder: peer comparisons and stimulant effects. J Abnorm Child Psychol. 2007;35(5):871-82. [pmid: 17503174]. Exclude: No included comparisons of outcomes, OVID-Medline.
Harwood MD, Eyberg SM. Therapist verbal behavior early in treatment: relation to successful completion of parent-child interaction therapy. J Clin Child Adolesc Psychol. 2004;33(3):601-12. [pmid: 15271617]. Exclude: Not an included population, OVID-Medline.
Haslam RH, Dalby JT, Rademaker AW. Effects of megavitamin therapy on children with attention deficit disorders. Pediatrics. 1984;74(1):103-11. Exclude: No included comparisons of outcomes,. [pmid: 6234505].
Haslam RH. Is there a role for megavitamin therapy in the treatment of attention deficit hyperactivity disorder. Adv Neurol. 1992;58:303-10. Exclude: No included comparisons of outcomes,. [pmid: 1414636].
Hautmann C, Hanisch C, Mayer I, et al. Effectiveness of the prevention program for externalizing problem behavior (PEP) in children with symptoms of attention-deficit/hyperactivity disorder and oppositional defiant disorder--generalization to the real world. J Neural Transm. 2008;115(2):363-70. [pmid: 18253810]. Exclude: No included comparisons of outcomes, OVID-Medline.
Hautmann C, Hoijtink H, Eichelberger I, et al. One-year follow-up of a parent management training for children with externalizing behavior problems in the real world. Behav Cognit Psychother. 2009;(4):379-96. Exclude: No included comparisons of outcomes, EMBASE. [pmid: 19619384].
Hautmann C, Hoijtink H, Eichelberger I, et al. One-year follow-up of a parent management training for children with externalizing behavior problems in the real world. Behav Cognit Psychother. 2009;37(4):379-96. Exclude: Not an included population, OVID-PsycINFO. [pmid: 19619384].
Hava FA. Lithium, the hyperactive child and manic depressive illness. J Ark Med Soc. 1973;69(10):299-300. [pmid: 4265814]. Exclude: Not an included population, OVID-Medline.
Hawk LW Jr, Yartz AR, Pelham WE Jr, et al. The effects of methylphenidate on prepulse inhibition during attended and ignored prestimuli among boys with attention-deficit hyperactivity disorder. Psychopharmacol. 2003;165(2):118-27. [pmid: 12417963]. Exclude: No included comparisons of outcomes, OVID-Medline.
Hawkins RP, Peterson RF, Schweid E, et al. Behavior therapy in the home: amelioration of problem parent-child relations with the parent in a therapeutic role. J Exp Child Psychol. 1966;4(1):99-107. [pmid: 5971021]. Exclude: No included comparisons of outcomes, OVID-Medline.
Hazel-Fernandez LA, Klorman R, Wallace JM, et al. Methylphenidate improves aspects of executive function in African American children with ADHD. J Attention Disord. 2006;9(4):582-9. [pmid: 16648225]. Exclude: No included comparisons of outcomes, OVID-Medline.
Hazell P, Zhang S, Wolanczyk T, et al. Comorbid oppositional defiant disorder and the risk of relapse during 9 months of atomoxetine treatment for attention-deficit/hyperactivity disorder. Eur Child Adolesc Psychiatr. 2006;15(2):105-10. [pmid: 16523251]. Exclude: No included comparisons of outcomes, OVID-Medline.
Hechtman L, Weiss G, Perlman T. Young adult outcome of hyperactive children who received long-term stimulant treatment. J Am Acad Child Psychiatry. 1984;23(3):261-9. Exclude: Longterm outcomes from pre 1997 publication, OVID-PsycINFO. [pmid: 6736490].
Heinicke CH. Frequency of psychotherapeutic session as a factor affecting the child’s developmental status. Psychoanal Study Child. 1965;20:42-98. [pmid: 5835553]. Exclude: Not an included population, OVID-Medline.
Henggeler SW, Letourneau EJ, Chapman JE, et al. Mediators of change for multisystemic therapy with juvenile sexual offenders. J Consult Clin Psychol. 2009;77(3):451-62. [pmid: 19485587]. Exclude: Not an included population, OVID-Medline.
Henker B, Astor-Dubin L, Varni JW. Psychostimulant medication and perceived intensity in hyperactive children. J Abnorm Child Psychol. 1986;(1):105-14. Exclude: Not an included population, OVID-EMBASE. [pmid: 2869076].
Hervey-Jumper H, Douyon K, Franco KN. Deficits in diagnosis, treatment and continuity of care in African-American children and adolescents with ADHD. J Natl Med Assoc. 2006;98(2):233-8. [pmid: 16708509]. Exclude: No included comparisons of outcomes, OVID-Medline.
Hetherington EM, Frankie G. Effects of parental dominance, warmth, and conflict on imitation in children. J Pers Soc Psychol. 1967;6(2):119-25. [pmid: 6035302]. Exclude: Not an included population, OVID-Medline.
Heywood C, Beale I. EEG biofeedback vs. placebo treatment for attention-deficit/hyperactivity disorder: a pilot study. J Attention Disord. 2003;7(1):43-55. [pmid: 14738180]. Exclude: No included comparisons of outcomes, OVID-Medline.
Hindle RC, Priest J. The management of hyperkinetic children: a trial of dietary therapy. N Z Med J. 1978;88(616):43-5. [pmid: 279852]. Exclude: No included intervention compared, OVID-Medline.
Hinshaw SP, Henker B, Whalen CK. Cognitive-behavioral and pharmacologic interventions for hyperactive boys: Comparative and combined effects. J Consult Clin Psychol. 1984;(5):739-49. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6501659].
Hinshaw SP, Henker B, Whalen CK. Self-control in hyperactive boys in anger-inducing situations: Effects of cognitive-behavioral training and of methylphenidate. J Abnorm Child Psychol. 1984;(1):55-77. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6715694].
Hinshaw SP, Buhrmester D, Heller T. Anger control in response to verbal provocation: effects of stimulant medication for boys with ADHD. J Abnorm Child Psychol. 1989;17(4):393-407. Exclude: No included comparisons of outcomes,. [pmid: 2677081].
Hinshaw SP, Heller T, McHale JP. Covert antisocial behavior in boys with attention-deficit hyperactivity disorder: External validation and effects of methylphenidate. J Consult Clin Psychol. 1992;60(2):274-81. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 1592958].
Ho LY. Child development programme in Singapore 1988 to 2007. Ann Acad Med Singapore. 2007;36(11):898-910. [pmid: 18071596]. Exclude: Not an included population, OVID-Medline.
Hoath FE, Sanders MR. A feasibility study of Enhanced Group Triple P - Positive parenting program for parents of children with attention-deficit/hyperactivity disorder. Behav Change. 2002;(4):191-206. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Hoffman SP, Engelhardt DM, Margolis RA, et al. Response to methylphenidate in low socioeconomic hyperactive children. Arch Gen Psychiatry. 1974;30(3):354-9. [pmid: 4813138]. Exclude: No included comparisons of outcomes, OVID-Medline.
Horn WF, Ialongo NS, Pascoe JM, et al. Additive effects of psychostimulants, parent behavior training, and self-control therapy with ADHD children. J Am Acad Child Adolesc Psychiatry. 1991;(2):233-40. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 2016227].
Horn WF, Ialongo N, Popovich S, et al. Behavioral parent behavior training and cognitive-behavioral self-control therapy with ADD-H children: Comparative and combined effects. J Clin Child Psychol. 1987;16(1):57-68. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Houck GM, King MC, Tomlinson B, et al. Small group intervention for children with attention disorders. J Sch Nurs. 2002;18(4):196-200. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 12201656].
Huang HL, Chao CC, Tu CC, et al. Behavioral parent behavior training for Taiwanese parents of children with attention-deficit/hyperactivity disorder. Psychiatr Clin Neurosci. 2003;57(3):275-81. [pmid: 12753567]. Exclude: No included intervention compared, OVID-Medline.
Huang YS, Guilleminault C, Li HY, et al. Attention-deficit/hyperactivity disorder with obstructive sleep apnea: a treatment outcome study. Sleep Medicine. 2007;8(1):18-30. [pmid: 17157069]. Exclude: No included comparisons of outcomes, OVID-Medline.
Huessy HR, Wright AL. The use of imipramine in children’s behavior disorders. Acta Paedopsychiatr. 1970;37(7):194-9. [pmid: 4927115]. Exclude: No included comparisons of outcomes, OVID-Medline.
Huessy HR, Metoyer M, Townsend M. 8–10 year follow-up of 84 children treated for behavioral disorder in rural Vermont. Acta Paedopsychiatr. 1974;40(6):230-5. [pmid: 4617481]. Exclude: No included comparisons of outcomes, OVID-Medline.
Hughes JN, Cavell TA, Meehan BT, et al. Adverse school context moderates the outcomes of selective interventions for aggressive children. J Consult Clin Psychol. 2005;73(4):731-6. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 16173861].
Huisjes HJ, Hadders-Algra M, Touwen BCL. Is clonidine a behavioral teratogen in the human. Early Hum Dev. 1986;(1):43-8. Exclude: Not an included population, OVID-EMBASE. [pmid: 3732118].
Huizink AC, van Lier PA, Crijnen AA. Attention deficit hyperactivity disorder symptoms mediate early-onset smoking. Eur Addict Res. 2009;15(1):1-9. [pmid: 19052457]. Exclude: No included comparisons of outcomes, OVID-Medline.
Humphries T, Swanson J, Kinsbourne M, et al. Stimulant effects on persistence of motor performance of hyperactive children. J Pediatr Psychol. 1979;(1):55-66. Exclude: Not an included population, OVID-EMBASE.
Humphries T, Kinsbourne M, Swanson J. Stimulant effects on cooperation and social interaction between hyperactive children and their mothers. J Child Psychol Psychiatr. 1978;19(1):13-22. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Hunt RD, Minderaa RB, Cohen DJ. The therapeutic effect of clonidine in attention deficit disorder with hyperactivity: A comparison with placebo and methylphenidate. Psychopharmacol Bull. 1986;(1):229-36. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3523578].
Hutchings J, Lane E, Kelly J. Comparison of two treatments for children with severely disruptive behaviors: A four-year follow-up. Behav Cognit Psychother. 2004;(1):15-30. Exclude: Not an included population, OVID-EMBASE.
Iaboni F, Douglas VI, Baker AG. Effects of reward and response costs on inhibition in ADHD children. J Abnorm Psychol. 1995;104(1):232-40. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 7897047].
Ialongo NS, Horn WF, Pascoe JM, et al. The effects of a multimodal intervention with attention-deficit hyperactivity disorder children: A 9-month follow-up. J Am Acad Child Adolesc Psychiatry. 1993;(1):182-9. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 8428870].
Ibay AD, Bascelli LM, Graves RS. Does increasing methylphenidate dose aid symptom control in ADHD?. J Fam Pract. 2003;52(5):400-403. Exclude: Not an included population, OVID-PsycINFO. [pmid: 12737774].
Iseri E, Kilic BG, Senol S, et al. Effects of methylphenidate on leptin and appetite in children with attention-deficit hyperactivity disorder: an open label trial. Meth Find Exp Clin Pharmacol. 2007;29(1):47-52. [pmid: 17344944]. Exclude: No included comparisons of outcomes, OVID-Medline.
Ison MS. Training in social skills: an alternative technique for handling disruptive child behavior. Psychol Rep. 2001;88(3:Pt 1):903-11. [pmid: 11508042]. Exclude: No included comparisons of outcomes, OVID-Medline.
Ivanov I, Klein M, Green WH, et al. The challenges of psychopharmacological management of children with severe developmental disabilities. J Child Adolesc Psychopharmacol. 2006;16(6):793-9. [pmid: 17201623]. Exclude: Not an included population, OVID-Medline.
Izard CE, King KA, Trentacosta CJ, et al. Accelerating the development of emotion competence in Head Start children: effects on adaptive and maladaptive behavior. Dev Psychopathol. 2008;20(1):369-97. [pmid: 18211742]. Exclude: Not an included population, OVID-Medline.
Jacobi-Polishook T, Shorer Z, Melzer I. The effect of methylphenidate on postural stability under single and dual task conditions in children with attention deficit hyperactivity disorder - a double blind randomized control trial. J Neurol Sci. 2009;280(1–2):15-21. [pmid: 19217632]. Exclude: No included comparisons of outcomes, OVID-Medline.
Jaffe C, Bush KR, Straits-Troster K, et al. A comparison of methamphetamine-dependent inpatients childhood attention deficit hyperactivity disorder symptomatology. J Addict Dis. 2005;24(3):133-52. [pmid: 16186089]. Exclude: Not an included population, OVID-Medline.
Jahromi LB, Kasari CL, McCracken JT, et al. Positive effects of methylphenidate on social communication and self-regulation in children with pervasive developmental disorders and hyperactivity. J Autism Dev Disord. 2009;39(3):395-404. [pmid: 18752063]. Exclude: No included comparisons of outcomes, OVID-Medline.
James RS, Sharp WS, Bastain TM, et al. Double-blind, placebo-controlled study of single-dose amphetamine formulations in ADHD. J Am Acad Child Adolesc Psychiatry. 2001;40(11):1268-76. [pmid: 11699800]. Exclude: No included comparisons of outcomes, OVID-Medline.
Jaselskis CA, Cook EH Jr, Fletcher KE, et al. Clonidine treatment of hyperactive and impulsive children with autistic disorder. J Clin Psychopharmacol. 1992;12(5):322-7. [pmid: 1479049]. Exclude: Not an included population, OVID-Medline.
Jason LA, Gesten E, Yock T. Relational and behavioral interventions with economically disadvantaged toddlers. Am J Orthopsychiatry. 1976;46(2):270-8. [pmid: 1266950]. Exclude: Not an included population, OVID-Medline.
Jensen JB, Garfinkel BD. Neuroendocrine aspects of attention deficit hyperactivity disorder. Neurologic Clinics. 1988;(1):111-29. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3380074].
Jensen PS. Fact versus fancy concerning the multimodal treatment study for attention-deficit hyperactivity disorder. Can J Psychiatr. 1999;44(10):975-80. Exclude: Not an included population, OVID-PsycINFO.
Jerrott S, Clark SE, Fearon I. Day treatment for disruptive behavior disorders: Can a short-term program be effective. J Can Acad Child Adolesc Psychiatr. 2010;19(2):88-93. Exclude: No included comparisons of outcomes, OVID-Embase.
Joachim S, Sanders MR, Turner KM. Reducing preschoolers’ disruptive behavior in public with a brief parent discussion group. Child Psychiatry Hum Dev. 2010;41(1):47-60. [pmid: 19633952]. Exclude: Not an included population, OVID-Medline.
Johnson CR, Handen BL, Lubetsky MJ, et al. Efficacy of methylphenidate and behavioral intervention on classroom behavior in children with ADHD and mental retardation. Behav Modif. 1994;18(4):470-87. Exclude: No included comparisons of outcomes,. [pmid: 7980374].
Johnson DL. Parent-child development center follow-up project: child behavior problem results. J Prim Prev. 2006;27(4):391-407. [pmid: 16802073]. Exclude: Not an included population, OVID-Medline.
Johnston C, Pelham WE, Hoza J, et al. Psychostimulant rebound in attention deficit disordered boys. J Am Acad Child Adolesc Psychiatry. 1988;27(6):806-10. [pmid: 3198571]. Exclude: No included comparisons of outcomes, OVID-Medline.
Johnston C, Seipp C, Hommersen P, et al. Treatment choices and experiences in attention deficit and hyperactivity disorder: relations to parents’ beliefs and attributions. Child Care Health Dev. 2005;31(6):669-77. [pmid: 16207224]. Exclude: No included intervention compared, OVID-Medline.
Johnston JA, Ye W, Van Brunt DL, et al. Decreased use of clonidine following treatment with atomoxetine in children with ADHD. J Clin Psychopharmacol. 2006;26(4):389-95. [pmid: 16855457]. Exclude: Not an included population, OVID-Medline.
Jones D, Godwin J, Dodge KA, et al. Impact of the fast track prevention program on health services use by conduct-problem youth. Pediatrics. 2010;125(1):e130-e136. [pmid: 20008428]. Exclude: Not an included population, OVID-Medline.
Jonkman LM, Kemner C, Verbaten MN, et al. Perceptual and response interference in children with attention-deficit hyperactivity disorder, and the effects of methylphenidate. Psychophysiology. 1999;36(4):419-29. [pmid: 10432791]. Exclude: No included comparisons of outcomes, OVID-Medline.
Jonkman LM, Kemner C, Verbaten MN, et al. Attentional capacity, a probe ERP study: differences between children with attention-deficit hyperactivity disorder and normal control children and effects of methylphenidate. Psychophysiology. 2000;37(3):334-46. [pmid: 10860411]. Exclude: No included comparisons of outcomes, OVID-Medline.
Jouriles EN, McDonald R, Spiller L, et al. Reducing conduct problems among children of battered women. J Consult Clin Psychol. 2001;69(5):774-85. [pmid: 11680554]. Exclude: Not an included population, OVID-Medline.
Kantavong P, Sivabaedya S. A professional learning program for enhancing the competency of students with special needs. Int J Whole School. 2010;6(1):53-62. Exclude: Not an included population, ERIC.
Kapalka GM. Managing students with ADHD in out-of-class settings. Emotional & Behavioral Difficulties. 2008;13(1):21-30. Exclude: No included comparisons of outcomes, OVID-PsycInfo.
Kaplan BJ, McNicol J, Conte RA, et al. Dietary replacement in preschool-aged hyperactive boys. Pediatrics. 1989;(1):7-17. Exclude: No included intervention compared, OVID-EMBASE. [pmid: 2909977].
Kaplan S, Heiligenstein J, West S, et al. Efficacy and safety of atomoxetine in childhood attention-deficit/hyperactivity disorder with comorbid oppositional defiant disorder. J Attention Disord. 2004;8(2):45-52. [pmid: 15801334]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kaplan SL, Busner J, Kupietz S, et al. Effects of methylphenidate on adolescents with aggressive conduct disorder and ADDH: a preliminary report. J Am Acad Child Adolesc Psychiatry. 1990;29(5):719-23. Exclude: No included comparisons of outcomes,. [pmid: 2228924].
Karabekiroglu K, Yazgan YM, Dedeoglu C. Can we predict short-term side effects of methylphenidate immediate-release. Int J Psychiatr Clin Pract. 2008;(1):48-54. Exclude: No included comparisons of outcomes, EMBASE.
Karpouzis F, Pollard H, Bonello R. A randomised controlled trial of the Neuro Emotional Technique (NET) for childhood Attention Deficit Hyperactivity Disorder (ADHD): a protocol. Trials. 2009;10:6. [pmid: 19173743]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kazdin AE, French NH, Sherick RB. Acceptability of alternative treatments for children: evaluations by inpatient children, parents, and staff. J Consult Clin Psychol. 1981;49(6):900-7. Exclude: No included comparisons of outcomes,. [pmid: 7309957].
Kazdin AE, Mazurick JL, Siegel TC. Treatment outcome among children with externalizing disorder who terminate prematurely versus those who complete psychotherapy. J Am Acad Child Adolesc Psychiatry. 1994;33(4):549-57. [pmid: 8005908]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kazdin AE, Wassell G. Therapeutic changes in children, parents, and families resulting from treatment of children with conduct problems. J Am Acad Child Adolesc Psychiatry. 2000;39(4):414-20. [pmid: 10761342]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kazdin AE, Marciano PL, Whitley MK. The therapeutic alliance in cognitive-behavioral treatment of children referred for oppositional, aggressive, and antisocial behavior. J Consult Clin Psychol. 2005;73(4):726-30. [pmid: 16173860]. Exclude: Not an included population, OVID-Medline.
Kazdin AE, Whitley MK. Comorbidity, case complexity, and effects of evidence-based treatment for children referred for disruptive behavior. J Consult Clin Psychol. 2006;74(3):455-67. [pmid: 16822103]. Exclude: No included comparisons of outcomes, OVID-Medline.
Keage HA, Clark CR, Hermens DF, et al. ERP indices of working memory updating in AD/HD: differential aspects of development, subtype, and medication. J Clin Neurophysiol. 2008;25(1):32-41. [pmid: 18303558]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kelley ME, Fisher WW, Lomas JE, et al. Some effects of stimulant medication on response allocation: a double-blind analysis. J Appl Behav Anal. 2006;39(2):243-7. [pmid: 16813046]. Exclude: No included intervention compared, OVID-Medline.
Kelly KL, Rapport MD, Dupaul GJ. Attention deficit disorder and methylphenidate: a multi-step analysis of dose-response effects on children’s cardiovascular functioning. Int Clin Psychopharmacol. 1988;3(2):167-81. [pmid: 3294285]. Exclude: No included comparisons of outcomes, OVID-Medline.
Keltikangas-Jarvinen L, Kangas P. Problem-solving strategies in aggressive and nonaggressive children. Aggressive Behavior. 1988;(4):255-64. Exclude: Not an included population, OVID-EMBASE.
Kemner JE, Lage MJ. Impact of methylphenidate formulation on treatment patterns and hospitalizations: A retrospective analysis. Ann Gen Psychiatr. 2006. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Kemner JE, Lage MJ. Effect of methylphenidate formulation on treatment patterns and use of emergency room services. Am J Health Syst Pharm. 2006;63(4):317-22. [pmid: 16452517]. Exclude: Not an included population, OVID-Medline.
Kempton S, Vance A, Maruff P, et al. Executive function and attention deficit hyperactivity disorder: stimulant medication and better executive function performance in children. Psychol Med. 1999;29(3):527-38. [pmid: 10405075]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kendall PC, Reber M, McLeer S, et al. Cognitive-behavioral treatment of conduct-disordered children. Cognit Ther Res. 1990;14(3):279-97. Exclude: No included comparisons of outcomes,.
Kendall PC, Finch AJ. Analyses of changes in verbal behavior following a cognitive-behavioral treatment for impulsivity. J Abnorm Child Psychol. 1979;7(4):455-63. Exclude: No included comparisons of outcomes, OVID-PsycInfo. [pmid: 521568].
Kent JD, Blader JC, Koplewicz HS, et al. Effects of late-afternoon methylphenidate administration on behavior and sleep in attention-deficit hyperactivity disorder. Pediatrics. 1995;96(2:Pt 1):320-5. [pmid: 7630692]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kent MA, Camfield CS, Camfield PR. Double-blind methylphenidate trials: practical, useful, and highly endorsed by families. Arch Pediatr Adolesc Med. 1999;153(12):1292-6. [pmid: 10591309]. Exclude: No included intervention compared, OVID-Medline.
Kessler S. Drug therapy in attention-deficit hyperactivity disorder. South Med J. 1996;89(1):33-8. [pmid: 8545689]. Exclude: No included comparisons of outcomes, OVID-Medline.
Keulers EH, Hendriksen JG, Feron FJ, et al. Methylphenidate improves reading performance in children with attention deficit hyperactivity disorder and comorbid dyslexia: an unblinded clinical trial. Eur J Paediatr Neurol. 2007;11(1):21-8. [pmid: 17169593]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kim Y, Shin MS, Kim JW, et al. Neurocognitive effects of switching from methylphenidate-IR to OROS-methylphenidate in children with ADHD. Hum Psychopharmacol. 2009;24(2):95-102. [pmid: 19226534]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kindlon D, Sollee N, Yando R. Specificity of behavior problems among children with neurological dysfunctions. J Pediatr Psychol. 1988;13(1):39-47. [pmid: 2455032]. Exclude: Not an included population, OVID-Medline.
King B, Zwi K, Nunn K, et al. Use of risperidone in a paediatric population: an observational study. J Paediatr Child Health. 2003;39(7):523-7. [pmid: 12969207]. Exclude: Not an included population, OVID-Medline.
King S, Waschbusch DA, Pelham WE Jr, et al. Social information processing in elementary-school aged children with ADHD: medication effects and comparisons with typical children. J Abnorm Child Psychol. 2009;37(4):579-89. [pmid: 19107591]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kirley A, Lowe N, Hawi Z, et al. Association of the 480 bp DAT1 allele with methylphenidate response in a sample of Irish children with ADHD. Am J Med Genet. 2003;Part 1:50-4. [pmid: 12898575]. Exclude: No included intervention compared, OVID-Medline.
Klinkerfuss GH, Lange PH, Weinberg WA, et al. Electroencephalographic abnormalities of children with hyperkinetic behavior. Neurology. 1965;15(10):883-91. [pmid: 5890881]. Exclude: No included intervention compared, OVID-Medline.
Klorman R, Salzman LF, Bauer LO. Effects of two doses of methylphenidate on cross-situational and borderline hyperactive children’s evoked potentials. Electroencephalogr Clin Neurophysiol. 1983;(2):169-85. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6191948].
Klorman R, Brumaghim JT, Salzman LF, et al. Effects of methylphenidate on attention-deficit hyperactivity disorder with and without aggressive/noncompliant features. J Abnorm Psychol. 1988;(4):413-22. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3060506].
Klorman R, Brumaghim JT, Salzman LF, et al. Comparative effects of methylphenidate on attention-deficit hyperactivity disorder with and without aggressive/noncompliant features. Psychopharmacol Bull. 1989;(1):109-13. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 2772109].
Klorman R, Brumaghim JT, Salzman LF, et al. Effects of methylphenidate on processing negativities in patients with attention-deficit hyperactivity disorder. Psychophysiology. 1990;(3):328-37. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 2236435].
Klorman R, Brumaghim JT, Fitzpatrick PA, et al. Clinical and cognitive effects of methylphenidate on children with attention deficit disorder as a function of aggression/oppositionality and age. J Abnorm Psychol. 1994;103(2):206-21. [pmid: 8040490]. Exclude: No included comparisons of outcomes, OVID-Medline.
Klorman R, Brumaghim JT, Fitzpatrick PA, et al. Methylphenidate reduces abnormalities of stimulus classification in adolescents with attention deficit disorder. J Abnorm Psychol. 1992;101(1):130-8. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 1537959].
Knopp W, Arnold LE, Andras RL, et al. Predicting amphetamine response in hyperkinetic children by electronic pupillography. Pharmakopsychiatr Neuropsychopharmakol. 1973;6(3):158-66. [pmid: 4795017]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kobel M, Bechtel N, Weber P, et al. Effects of methylphenidate on working memory functioning in children with attention deficit/hyperactivity disorder. Eur J Paediatr Neurol. 2009;13(6):516-23. [pmid: 19056305]. Exclude: No included comparisons of outcomes, OVID-Medline.
Koegel RL, Koegel LK, Surratt A. Language intervention and disruptive behavior in preschool children with autism. J Autism Dev Disord. 1992;22(2):141-53. [pmid: 1378049]. Exclude: No included comparisons of outcomes, OVID-Medline.
Koegl CJ, Farrington DP, Augimeri LK, et al. Evaluation of a targeted cognitive-behavioral program for children with conduct problems--the SNAP Under 12 Outreach Project: service intensity, age and gender effects on short- and long-term outcomes. Clin Child Psychol Psychiatr. 2008;13(3):419-34. [pmid: 18783124]. Exclude: No included intervention compared, OVID-Medline.
Kolko DJ, Loar LL, Sturnick D. Inpatient social-cognitive skills training groups with conduct disordered and attention deficit disordered children. J Child Psychol Psychitr Allied Disc. 1990;(5):737-48. Exclude: No included intervention compared, OVID-EMBASE.
Kolko DJ, Dorn LD, Bukstein OG, et al. Community vs. clinic-based modular treatment of children with early-onset ODD or CD: a clinical trial with 3-year follow-up. J Abnorm Child Psychol. 2009;37(5):591-609. [pmid: 19221871]. Exclude: Not an included population, OVID-Medline.
Kollins S, Greenhill L, Swanson J, et al. Rationale, design, and methods of the Preschool ADHD Treatment Study (PATS). J Am Acad Child Adolesc Psychiatry. 2006;(11):1275-83. Exclude: No included comparisons of outcomes, OVID-Embase. [pmid: 17023869].
Kollins SH, Shapiro SK, Newland MC, et al. Discriminative and participant-rated effects of methylphenidate in children diagnosed with attention deficit hyperactivity disorder (ADHD). Exp Clin Psychopharmacol. 1998;6(4):375-89. [pmid: 9861552]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kollins SH, English J, Robinson R, et al. Reinforcing and subjective effects of methylphenidate in adults with and without attention deficit hyperactivity disorder (ADHD). Psychopharmacol. 2009;204(1):73-83. [pmid: 19104775]. Exclude: No included comparisons of outcomes, OVID-Medline.
Konofal E, Lecendreux M, Deron J, et al. Effects of iron supplementation on attention deficit hyperactivity disorder in children. Pediatr Neurol. 2008;38(1):20-6. [pmid: 18054688]. Exclude: No included comparisons of outcomes, OVID-Medline.
Konrad K, Neufang S, Fink GR, et al. Long-term effects of methylphenidate on neural networks associated with executive attention in children with ADHD: results from a longitudinal functional MRI study. J Am Acad Child Adolesc Psychiatry. 2007;46(12):1633-41. [pmid: 18030085]. Exclude: No included comparisons of outcomes, OVID-Medline.
Konstantareas MM, Homatidis S. Effectiveness of cognitive mediation and behavior modification with hospitalized hyperactives. Can J Psychiatr. 1983;(6):462-70. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Kooij JS, Boonstra AM, Vermeulen SH, et al. Response to methylphenidate in adults with ADHD is associated with a polymorphism in SLC6A3 (DAT1). Am J Med Genet. 2008;(2):201-8. [pmid: 17955457]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kopecky H, Chang HT, Klorman R, et al. Performance and private speech of children with attention-deficit/hyperactivity disorder while taking the Tower of Hanoi test: effects of depth of search, diagnostic subtype, and methylphenidate. J Abnorm Child Psychol. 2005;33(5):625-38. [pmid: 16195955]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kraft IA, Ardali C, Duffy JH, et al. A clinical study of chloridazepoxide used in psychiatric disorders of children. Int J Neuropsychiatry. 1965;1(5):433-7. [pmid: 5858883]. Exclude: Not an included population, OVID-Medline.
Krakowski AJ. Amitriptyline in treatment of hyperkinetic children. A double-blind study. Psychosomatics. 1965;6(5):355-60. [pmid: 5319250]. Exclude: No included comparisons of outcomes, OVID-Medline.
Krakowski AJ. Outpatient treatment of the emotionally ill child: a comparison of two psychotropic agents. Psychosomatics. 1965;6(6):402-9. [pmid: 5845949]. Exclude: Not an included population, OVID-Medline.
Kramer AF, Cepeda NJ, Cepeda ML. Methylphenidate effects on task-switching performance in attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2001;40(11):1277-84. [pmid: 11699801]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kratochvil CJ, Heiligenstein JH, Dittmann R, et al. Atomoxetine and methylphenidate treatment in children with ADHD: a prospective, randomized, open-label trial. J Am Acad Child Adolesc Psychiatry. 2002;41(7):776-84. [pmid: 12108801]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kratochvil CJ, Newcorn JH, Arnold LE, et al. Atomoxetine alone or combined with fluoxetine for treating ADHD with comorbid depressive or anxiety symptoms. J Am Acad Child Adolesc Psychiatry. 2005;44(9):915-24. [pmid: 16113620]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kratochvil CJ, Egger H, Greenhill LL, et al. Pharmacological management of preschool ADHD. J Am Acad Child Adolesc Psychiatry. 2006;45(1):115-8. [pmid: 16327589]. Exclude: Not an included population, OVID-Medline.
Kratochvil CJ, Vaughan BS, Mayfield-Jorgensen ML, et al. A pilot study of atomoxetine in young children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2007;17(2):175-85. [pmid: 17489712]. Exclude: No included intervention compared, OVID-Medline.
Kratochvil CJ, Faries D, Vaughan B, et al. Emotional expression during attention-deficit/hyperactivity disorders treatment: initial assessment of treatment effects. J Child Adolesc Psychopharmacol. 2007;17(1):51-62. [pmid: 17343553]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kratochvil CJ, Michelson D, Newcorn JH, et al. High-dose atomoxetine treatment of ADHD in youths with limited response to standard doses. J Am Acad Child Adolesc Psychiatry. 2007;46(9):1128-37. [pmid: 17712236]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kratochvil CJ, May DE, Silva SG, et al. Treatment response in depressed adolescents with and without co-morbid attention-deficit/hyperactivity disorder in the treatment for adolescents with depression study. J Child Adolesc Psychopharmacol. 2009;19(5):519-27. [pmid: 19877976]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kratochwill TR, McDonald L, Levin JR, et al. Families and Schools Together: an experimental study of multi-family support groups for children at risk. J Sch Psychol. 2009;47(4):245-65. [pmid: 19480887]. Exclude: No included intervention compared, OVID-Medline.
Krusch DA, Klorman R, Brumaghim JT, et al. Methylphenidate slows reactions of children with attention deficit disorder during and after an error. J Abnorm Child Psychol. 1996;24(5):633-50. Exclude: No included comparisons of outcomes,. [pmid: 8956088].
Kuperman S, Stewart MA. Use of propranolol to decrease aggressive outbursts in younger patients. Open study reveals potentially favorable outcome. Psychosomatics. 1987;28(6):315-9. [pmid: 3432546]. Exclude: No included comparisons of outcomes, OVID-Medline.
Kupietz SS, Balka EB. Alterations in the vigilance performance of children receiving amitriptyline and methylphenidate pharmacotherapy. Psychopharmacol. 1976;50(1):29-33. Exclude: No included comparisons of outcomes,.
Kupietz SS, Winsberg BG, Richardson E, et al. Effects of methylphenidate dosage in hyperactive reading-disabled children: I. Behavior and cognitive performance effects. J Am Acad Child Adolesc Psychiatry. 1988;(1):70-7. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3343209].
Kurlan R, Goldberg J. Clonidine and methylphenidate were effective for attention deficit hyperactivity disorder in children with comorbid tics. Evid Base Med. 2002;(5):157. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Kurtz SM. Treating ADHD in school settings. Sch Nurs News. 2002;19(2):28-33. [pmid: 11979657]. Exclude: No included intervention compared, OVID-Medline.
Kusaga A, Yamashita Y, Koeda T, et al. Increased urine phenylethylamine after methylphenidate treatment in children with ADHD. Ann Neurol. 2002;52(3):372-4. [pmid: 12205654]. Exclude: No included intervention compared, OVID-Medline.
Lacourse E, Cote S, Nagin DS, et al. A longitudinal-experimental approach to testing theories of antisocial behavior development. Dev Psychopathol. 2002;14(4):909-24. Exclude: Not an included population, OVID-PsycINFO. [pmid: 12549709].
Lage M, Hwang P. Effect of methylphenidate formulation for attention deficit hyperactivity disorder on patterns and outcomes of treatment. J Child Adolesc Psychopharmacol. 2004;14(4):575-81. [pmid: 15662149]. Exclude: Not an included population, OVID-Medline.
Lahat E, Weiss M, Ben Shlomo A, et al. Bone mineral density and turnover in children with attention-deficit hyperactivity disorder receiving methylphenidate. J Child Neurol. 2000;15(7):436-9. [pmid: 10921512]. Exclude: No included comparisons of outcomes, OVID-Medline.
Lai KYC, Pang AHT, Wong CK, et al. Characteristics of dropouts from a child psychiatry clinic in Hong Kong. Soc Psychiatr Psychiatr Epidemiol. 1998;(1):45-8. Exclude: Not an included population, OVID-EMBASE.
Lajoie G, Anderson V, Anderson P, et al. Effects of methylphenidate on attention skills in children with attention deficit/hyperactivity disorder. Brain Impair. 2005;6(1):21-32. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Lamont J. Homoeopathic treatment of attention deficit hyperactivity disorder: a controlled study. Br Homeopath J. 1997;10(86):196-200. Exclude: No included comparisons of outcomes,.
Lamont J. Homeopathic treatment of attention deficit hyperactivity disorder: a controlled study. Biomed Ther. 1998;3(16):219-22. Exclude: No included comparisons of outcomes,.
Landman GB, McCrindle B. Pediatric management of nonpervasively ‘hyperactive’ children. Clin Pediatr. 1986;(12):600-4. Exclude: No included intervention compared, OVID-EMBASE.
Lang R, O’Reilly M, Lancioni G, et al. Discrepancy in functional analysis results across two settings: implications for intervention design. J Appl Behav Anal. 2009;42(2):393-7. [pmid: 19949530]. Exclude: Not an included population, OVID-Medline.
Langberg JM, Arnold LE, Flowers AM, et al. Parent-reported homework problems in the MTA study: Evidence for sustained improvement with behavioral treatment. J Clin Child Adolesc Psychol. 2010;39(2):220-33. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 20390813].
Langley K, Fowler T, Ford T, et al. Adolescent clinical outcomes for young people with attention-deficit hyperactivity disorder. Br J Psychiatry. 2010;196:235-40. [pmid: 20194547]. Exclude: No included intervention compared, OVID-Medline.
Larsson B, Fossum S, Clifford G, et al. Treatment of oppositional defiant and conduct problems in young Norwegian children : results of a randomized controlled trial. Eur Child Adolesc Psychiatr. 2009;18(1):42-52. [pmid: 18563473]. Exclude: Not an included population, OVID-Medline.
Larue RH Jr, Northup J, Baumeister AA, et al. An evaluation of stimulant medication on the reinforcing effects of play. J Appl Behav Anal. 2008;41(1):143-7. [pmid: 18468289]. Exclude: No included intervention compared, OVID-Medline.
Lasich A. Attention deficit hyperactivity disorder and co-morbidity: A clinic study. South Afr J Child Adolesc Psychiatr. 1992;4(1):8-12. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Lavigne JV, Lebailly SA, Gouze KR, et al. Predictor and moderator effects in the treatment of oppositional defiant disorder in pediatric primary care. J Pediatr Psychol. 2008;33(5):462-72. [pmid: 17956931]. Exclude: No included comparisons of outcomes, OVID-Medline.
Lavigne JV, LeBailly SA, Gouze KR, et al. Predictors and correlates of completing behavioral parent behavior training for the treatment of oppositional defiant disorder in pediatric primary care. Behav Ther. 2010;41(2):198-211. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 20412885].
Lawrence CA, Barry RJ, Clarke AR, et al. Methylphenidate effects in attention deficit/hyperactivity disorder: electrodermal and ERP measures during a continuous performance task. Psychopharmacol. 2005;183(1):81-91. [pmid: 16160877]. Exclude: No included comparisons of outcomes, OVID-Medline.
LeBlanc JC, Binder CE, Armenteros JL, et al. Risperidone reduces aggression in boys with a disruptive behavior disorder and below average intelligence quotient: analysis of two placebo-controlled randomized trials. Int Clin Psychopharmacol. 2005;20(5):275-83. [pmid: 16096518]. Exclude: No included comparisons of outcomes, OVID-Medline.
Lee JS, Kim BN, Kang E, et al. Regional cerebral blood flow in children with attention deficit hyperactivity disorder: comparison before and after methylphenidate treatment. Hum Brain Mapp. 2005;24(3):157-64. [pmid: 15486990]. Exclude: No included comparisons of outcomes, OVID-Medline.
Lee SI, Hong SD, Kim SY, et al. Efficacy and tolerability of OROS methylphenidate in Korean children with attention-deficit/hyperactivity disorder. Prog Neuropsychopharmacol Biol Psychiatr. 2007;31(1):210-6. [pmid: 17046131]. Exclude: No included comparisons of outcomes, OVID-Medline.
Leitner Y, Barak R, Giladi N, et al. Gait in attention deficit hyperactivity disorder: effects of methylphenidate and dual tasking. J Neurol. 2007;254(10):1330-8. [pmid: 17401735]. Exclude: No included comparisons of outcomes, OVID-Medline.
Lerer RJ, Lerer MP. The effects of methylphenidate on the soft neurological signs of hyperactive children. Pediatrics. 1976;57(4):521-5. Exclude: No included comparisons of outcomes,. [pmid: 772581].
Lerer RJ, Artner J, Lerer MP. Handwriting deficits in children with minimal brain dysfunction: Effects of methylphenidate (Ritalin) and placebo. J Learn Disabil. 1979;12(7):450-5. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 521686].
Leslie LK, Plemmons D, Monn AR, et al. Investigating ADHD treatment trajectories: listening to families’ stories about medication use. J Dev Behav Pediatr. 2007;28(3):179-88. [pmid: 17565284]. Exclude: No included intervention compared, OVID-Medline.
Levin ED, Conners CK, Silva D, et al. Effects of chronic nicotine and methylphenidate in adults with attention deficit/hyperactivity disorder. Exp Clin Psychopharmacol. 2001;9(1):83-90. [pmid: 11519638]. Exclude: No included comparisons of outcomes, OVID-Medline.
Levine J, Ring A, Barak Y, et al. Inositol may worsen attention deficit disorder with hyperactivity. Hum Psychopharmacol Clin Exp. 1995;10(6):481-4. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Levinson BM. Pet psychotherapy: use of household pets in the treatment of behavior disorder in childhood. Psychol Rep. 1965;17(3):695-8. [pmid: 5892572]. Exclude: Not an included population, OVID-Medline.
Levy F, Hobbes G. Hyperkinesis and diet: a replication study. Am J Psychiatry. 1978;135(12):1559-60. [pmid: 717580]. Exclude: No included intervention compared, OVID-Medline.
Levy F, Dumbrell S, Hobbes G, et al. Hyperkinesis and diet: a double-blind crossover trial with a tartrazine challenge. Med J Aust. 1978;1(2):61-4. [pmid: 349320]. Exclude: No included comparisons of outcomes, OVID-Medline.
Levy F, Hobbes G. The action of stimulant medication in attention deficit disorder with hyperactivity: Dopaminergic, noradrenergic, or both. J Am Acad Child Adolesc Psychiatry. 1988;(6):802-5. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 2848797].
Levy F, Hobbes G. Does haloperidol block methylphenidate. Psychopharmacol. 1996;126(1):70-4. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Levy K, Hunt C, Heriot S. Treating comorbid anxiety and aggression in children. J Am Acad Child Adolesc Psychiatry. 2007;46(9):1111-8. [pmid: 17712234]. Exclude: Not an included population, OVID-Medline.
Levy LD, Fleming JP, Klar D. Treatment of refractory obesity in severely obese adults following management of newly diagnosed attention deficit hyperactivity disorder. Int J Obes. 2009;(3):326-34. Exclude: Not an included population, EMBASE.
Levy S. The hyperkinetic child--a forgotten entity, its diagnosis and treatment. Int J Neuropsychiatry. 1966;2(4):330-6. [pmid: 5966762]. Exclude: No included comparisons of outcomes, OVID-Medline.
Lewis JA, Young R. Deanol and methylphenidate in minimal brain dysfunction. Clin Pharmacol Ther. 1975;17(5):534-40. Exclude: No included comparisons of outcomes,. [pmid: 1092513].
Lewis WM. Group training for parents of children with behavior problems. J Specialists Group Work. 1986;11(4):194-9. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Li S, Yu B, Zhou D, et al. Acupuncture for attention-deficit hyperactivity disorder (ADHD) in children and adolescents. Cochrane Database of Systematic Reviews. 2009;(2). Exclude: No included intervention compared, EMBASE.
Lijffijt M, Kenemans JL, ter Wal A, et al. Dose-related effect of methylphenidate on stopping and changing in children with attention-deficit/hyperactivity disorder. Eur Psychiatr. 2006;21(8):544-7. [pmid: 15994064]. Exclude: No included comparisons of outcomes, OVID-Medline.
Lim CG, Ooi YP, Fung DS, et al. Sleep disturbances in Singaporean children with attention deficit hyperactivity disorder. Ann Acad Med Singapore. 2008;37(8):655-61. [pmid: 18797558]. Exclude: No included intervention compared, OVID-Medline.
Lin SJ, Crawford SY, Lurvey PL. Trend and area variation in amphetamine prescription usage among children and adolescents in Michigan. Soc Sci Med. 2005;60(3):617-26. [pmid: 15550309]. Exclude: Not an included population, OVID-Medline.
Linares LO, Stovall-McClough KC, Li M, et al. Salivary cortisol in foster children: a pilot study. Child Abuse Negl. 2008;32(6):665-70. [pmid: 18582935]. Exclude: Not an included population, OVID-Medline.
Linden M, Habib T, Radojevic V. A controlled study of the effects of EEG biofeedback on cognition and behavior of children with attention deficit disorder and learning disabilities. Biofeedback Self Regul. 1996;21(1):35-49. [pmid: 8833315]. Exclude: No included comparisons of outcomes, OVID-Medline.
Linnoila M, Gualtieri CT, Jobson K, et al. Characteristics of the therapeutic response to imipramine in hyperactive children. Am J Psychiatry. 1979;136(9):1201-3. [pmid: 474813]. Exclude: No included comparisons of outcomes, OVID-Medline.
Lisska MC, Rivkees SA. Daily methylphenidate use slows the growth of children: a community based study. J Pediatr Endocrinol. 2003;16(5):711-8. [pmid: 12880120]. Exclude: No included intervention compared, OVID-Medline.
Llorens LA, Rubin EZ, Braun JS, et al. The effects of a cognitive-perceptual-motor training approach on children with behavior maladjustment. Am J Occup Ther. 1969;23(6):502-12. Exclude: No included comparisons of outcomes,. [pmid: 5344929].
Lobitz GK, Johnson SM. Normal versus deviant children. A multimethod comparison. J Abnorm Child Psychol. 1975;3(4):353-74. [pmid: 1223204]. Exclude: Not an included population, OVID-Medline.
Locher PJ. Use of haptic training to modify impulse and attention control deficits of learning disabled children. J Learn Disabil. 1985;18(2):89-93. [pmid: 3973506]. Exclude: Not an included population, OVID-Medline.
Lochman JE. Cognitive-behavioral intervention with aggressive boys: Three-year follow-up and preventive effects. J Consult Clin Psychol. 1992;(3):426-32. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 1619096].
Lochman JE. Effects of different treatment lengths in cognitive behavioral interventions with aggressive boys. Child Psychiatry Hum Dev. 1985;16(1):45-56. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 4064791].
Lochman JE, Wells KC. The coping power program for preadolescent aggressive boys and their parents: Outcome effects at the 1-year follow-up. J Consult Clin Psychol. 2004;72(4):571-8. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 15301641].
Loffredo DA, Omizo M, Hammett VL. Group relaxation training and parental involvement with hyperactive boys. J Learn Disabil. 1984;17(4):210-3. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 6371172].
Loney J, Prinz RJ, Mishalow J, et al. Hyperkinetic/aggressive boys in treatment: predictors of clinical response to methylphenidate. Am J Psychiatry. 1978;135(12):1487-91. [pmid: 717562]. Exclude: No included comparisons of outcomes, OVID-Medline.
Long N, Rickert VI, Ashcraft EW. Bibliotherapy as an adjunct to stimulant medication in the treatment of attention-deficit hyperactivity disorder. J Pediatr Health Care. 1993;7(2):82-8. Exclude: No included comparisons of outcomes,. [pmid: 8492283].
Long P, Forehand R, Wierson M, et al. Does parent behavior training with young noncompliant children have long-term effects. Behav Res Ther. 1994;32(1):101-7. [pmid: 8135705]. Exclude: No included comparisons of outcomes, OVID-Medline.
Loo SK, Specter E, Smolen A, et al. Functional effects of the DAT1 polymorphism on EEG measures in ADHD. J Am Acad Child Adolesc Psychiatry. 2003;42(8):986-93. [pmid: 12874502]. Exclude: No included comparisons of outcomes, OVID-Medline.
Lopez FA, Ginsberg LD, Arnold V. Effect of lisdexamfetamine dimesylate on parent-rated measures in children aged 6 to 12 years with attention-deficit/hyperactivity disorder: a secondary analysis. Postgrad Med. 2008;120(3):89-102. [pmid: 18824828]. Exclude: No included comparisons of outcomes, OVID-Medline.
Lubar JF. EEG Biofeedback and Learning Disabilities. Theory Into Practice. 1985;24(2):106-11. Exclude: Not an included population, ERIC Database.
Luby JL, Stalets MM, Belden AC. Psychotropic prescriptions in a sample including both healthy and mood and disruptive disordered preschoolers: relationships to diagnosis, impairment, prescriber type, and assessment methods. J Child Adolesc Psychopharmacol. 2007;17(2):205-15. [pmid: 17489715]. Exclude: No included comparisons of outcomes, OVID-Medline.
Ludolph AG, Kassubek J, Schmeck K, et al. Dopaminergic dysfunction in attention deficit hyperactivity disorder (ADHD), differences between pharmacologically treated and never treated young adults: a 3,4-dihdroxy-6-[18F]fluorophenyl-l-alanine PET study. Neuroimage. 2008;41(3):718-27. [pmid: 18424180]. Exclude: No included comparisons of outcomes, OVID-Medline.
Ludwig HT, Matte B, Katz B, et al. Do sluggish cognitive tempo symptoms predict response to methylphenidate in patients with attention-deficit/hyperactivity disorder-inattentive type. J Child Adolesc Psychopharmacol. 2009;(4):461-5. Exclude: No included comparisons of outcomes, EMBASE. [pmid: 19702499].
Lufi D, Parish-Plass J, Gai E. The effect of methylphenidate on the cognitive and personality functioning of ADHD children. Isr J Psychiatr Relat Sci. 1997;34(3):200-9. [pmid: 9334525]. Exclude: No included comparisons of outcomes, OVID-Medline.
Lufi D, Gai E. The effect of methylphenidate and placebo on eye-hand coordination functioning and handwriting of children with attention deficit hyperactivity disorder. Neurocase. 2007;13(5):334-41. [pmid: 18781432]. Exclude: No included comparisons of outcomes, OVID-Medline.
Luk ESL, Staiger PK, Mathai J, et al. Children with persistent conduct problems who dropout of treatment. Eur Child Adolesc Psychiatr. 2001;(1):28-36. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Lunkenheimer ES, Dishion TJ, Shaw DS, et al. Collateral benefits of the Family Check-Up on early childhood school readiness: indirect effects of parents’ positive behavior support. Dev Psychol. 2008;44(6):1737-52. [pmid: 18999335]. Exclude: Not an included population, OVID-Medline.
Lynk SM, Amidon E. Chemotherapy with delinquents. Mich Med. 1965;64(10):762-6. [pmid: 5831077]. Exclude: Not an included population, OVID-Medline.
Maffla AG. Double-blind assessment of the activity of minaprine (30038-CB) in child psychiatry. Pharmatherapeutica. 1981;2(9):601-6. Exclude: No included comparisons of outcomes,. [pmid: 7267677].
Mahalick DM, Carmel PW, Greenberg JP, et al. Psychopharmacologic treatment of acquired attention disorders in children with brain injury. Pediatr Neurosurg. 1998;29(3):121-6. [pmid: 9838263]. Exclude: Not an included population, OVID-Medline.
Maiano C, Ninot G, Morin AJ, et al. Effects of sport participation on the basketball skills and physical self of adolescents with conduct disorders. Adapted Physical Activity Quarterly. 2007;24(2):178-96. [pmid: 17916916]. Exclude: Not an included population, OVID-Medline.
Malhotra S, Santosh PJ. An open clinical trial of buspirone in children with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1998;37(4):364-71. [pmid: 9549956]. Exclude: No included comparisons of outcomes, OVID-Medline.
Malone MA, Kershner JR, Siegel L. The effects of methylphenidate on levels of processing and laterality in children with attention deficit disorder. J Abnorm Child Psychol. 1988;16(4):379-95. Exclude: No included comparisons of outcomes,. [pmid: 3221029].
Malone MA, Swanson JM. Effects of methylphenidate on impulsive responding in children with attention-deficit hyperactivity disorder. J Child Neurol. 1993;(2):157-63. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 8505479].
Manassis K, Monga S. A therapeutic approach to children and adolescents with anxiety disorders and associated comorbid conditions. J Am Acad Child Adolesc Psychiatry. 2001;40(1):115-7. [pmid: 11195553]. Exclude: Not an included population, OVID-Medline.
Manchanda SS, Kishore B, Jain CK, et al. Hydroxyzine hydrochloride in the management of children with behavior problems. Indian Pediatr. 1969;6(8):538-49. [pmid: 4902197]. Exclude: Not an included population, OVID-Medline.
Manos MJ, Short EJ, Findling RL. Differential effectiveness of methylphenidate and Adderall in school-age youths with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1999;38(7):813-9. [pmid: 10405498]. Exclude: No included comparisons of outcomes, OVID-Medline.
Mansheim P. Short-term psychiatric inpatient treatment of preschool children. Hosp Community Psychiatr. 1990;41(6):670-2. [pmid: 2361674]. Exclude: No included comparisons of outcomes, OVID-Medline.
Marcason W. Can dietary intervention play a part in the treatment of attention deficit and hyperactivity disorder. J Am Diet Assoc. 2005;105(7):1161-2. [pmid: 15983541]. Exclude: No included intervention compared, OVID-Medline.
Marcus SC, Wan GJ, Kemner JE, et al. Continuity of methylphenidate treatment for attention-deficit/hyperactivity disorder. Arch Pediatr Adolesc Med. 2005;159(6):572-8. [pmid: 15939858]. Exclude: No included comparisons of outcomes, OVID-Medline.
Martenyi F, Treuer T, Gau SSF, et al. Attention-deficit/hyperactivity disorder diagnosis, co-morbidities, treatment patterns, and quality of life in a pediatric population in central and eastern Europe and Asia. J Child Adolesc Psychopharmacol. 2009;(4):363-76. Exclude: No included comparisons of outcomes, EMBASE. [pmid: 19702488].
Martin DM. Hyperkinetic behavior disorders in children: clinical results with methylphenidate hydrochloride (Ritalin). West Med Med J West. 1967;8(1):23-7. [pmid: 6072016]. Exclude: No included comparisons of outcomes, OVID-Medline.
Masi G, Milone A, Canepa G, et al. Olanzapine treatment in adolescents with severe conduct disorder. Eur Psychiatr. 2006;21(1):51-7. [pmid: 16487906]. Exclude: Not an included population, OVID-Medline.
Masi G, Milone A, Manfredi A, et al. Effectiveness of lithium in children and adolescents with conduct disorder: a retrospective naturalistic study. CNS Drugs. 2009;23(1):59-69. [pmid: 19062775]. Exclude: No included comparisons of outcomes, OVID-Medline.
Matier K, Halperin JM, Sharma V, et al. Methylphenidate response in aggressive and nonaggressive ADHD children: Distinctions on laboratory measures of symptoms. J Am Acad Child Adolesc Psychiatry. 1992;31(2):219-25. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 1564022].
Matsumoto K, Tsujimoto T, Morishita H, et al. A variation of acupuncture used in the sedation of hyperactive children. Am J Acupuncture. 1990;(4):359-61. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Mattes JA, Gittelman R. Growth of hyperactive children on maintenance regimen of methylphenidate. Arch Gen Psychiatry. 1983;(3):317-21. Exclude: Longterm outcomes from pre 1997 publication, OVID-EMBASE. [pmid: 6830410].
Mattes JA. Comparative effectiveness of carbamazepine and propranolol for rage outbursts. J Neuropsych Clin Neurosci. 1990;2(2):159-64. Exclude: No included comparisons of outcomes,.
Mattes JA, Gittelman R. Effects of artificial food colorings in children with hyperactive symptoms: A critical review and results of a controlled study. Arch Gen Psychiatry. 1981;38(6):714-8. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 7247635].
Mattiasson A, Ekstrom B, Andersson KE. Effects of intravesical instillation of verapamil in patients with detrusor hyperactivity. Neurourol Urodyn. 1987;6(3):253-4. Exclude: Not an included population,.
Mattson RH, Calverley JR. Dextroamphetamine-sulfate-induced dyskinesias. JAMA. 1968;204(5):400-2. [pmid: 5694457]. Exclude: Not an included population, OVID-Medline.
Mautner VF, Kluwe L, Thakker SD, et al. Treatment of ADHD in neurofibromatosis type 1. Dev Med Child Neurol. 2002;44(3):164-70. [pmid: 12005317]. Exclude: No included comparisons of outcomes, OVID-Medline.
Mayes SD, Crites DL, Bixler EO, et al. Methylphenidate and ADHD: influence of age, IQ and neurodevelopmental status. Dev Med Child Neurol. 1994;36(12):1099-107. [pmid: 7525394]. Exclude: No included comparisons of outcomes, OVID-Medline.
McAuley R. Training parents to modify conduct problems in their children. J Child Psychol Psychitr Allied Disc. 1982;23(3):335-42. [pmid: 7107748]. Exclude: No included intervention compared, OVID-Medline.
McBride MC. An individual double-blind crossover trial for assessing methylphenidate response in children with attention deficit disorder. J Pediatr. 1988;113(1:Pt 1):137-45. [pmid: 3290413]. Exclude: No included comparisons of outcomes, OVID-Medline.
McCarthy S, Cranswick N, Potts L, et al. Mortality associated with attention-deficit hyperactivity disorder (ADHD) drug treatment: A retrospective cohort study of children, adolescents and young adults using the general practice research database. Drug Saf. 2009;(11):1089-96. Exclude: No included intervention compared, EMBASE. [pmid: 19810780].
McCracken JT, Biederman J, Greenhill LL, et al. Analog classroom assessment of a once-daily mixed amphetamine formulation, SLI381 (Adderall XR), in children with ADHD. J Am Acad Child Adolesc Psychiatry. 2003;42(6):673-83. [pmid: 12921475]. Exclude: No included comparisons of outcomes, OVID-Medline.
McDonald M. The psychiatric evaluation of children. J Am Acad Child Psychiatry. 1965;4(4):569-612. [pmid: 5835673]. Exclude: Not an included population, OVID-Medline.
McDonald R, Jouriles EN, Skopp NA. Reducing conduct problems among children brought to women’s shelters: intervention effects 24 months following termination of services. J Fam Psychol. 2006;20(1):127-36. Exclude: Not an included population,. [pmid: 16569097].
McDonald S, Bennett KM, Chambers H, et al. Covert orienting and focusing of attention in children with attention deficit hyperactivity disorder. Neuropsychologia. 1999;37(3):345-56. [pmid: 10199647]. Exclude: No included intervention compared, OVID-Medline.
McDonnell KA, Mathews LL. Promoting enhanced parenting: A group for caregivers of children diagnosed with AD/HD. J Specialists Group Work. 2001;26(3):276-88. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
McGillivray JA, Cummins RA, Prior MR. Cognitive behavior modification of impulsive responding by hyperaggressive children in interpersonal problem situations. Aust N Z J Dev Dis. 1988;(1):55-70. Exclude: No included comparisons of outcomes, OVID-EMBASE.
McGough J, Mccracken J, Swanson J, et al. Pharmacogenetics of methylphenidate response in preschoolers with ADHD. J Am Acad Child Adolesc Psychiatry. 2006;(11):1314-22. Exclude: No included comparisons of outcomes, OVID-Embase. [pmid: 17023870].
McGough JJ, Wigal SB, Abikoff H, et al. A randomized, double-blind, placebo-controlled, laboratory classroom assessment of methylphenidate transdermal system in children with ADHD. J Attention Disord. 2006;9(3):476-85. [pmid: 16481664]. Exclude: No included comparisons of outcomes, OVID-Medline.
McGuffin PW. The effect of timeout duration on frequency of aggression in hospitalized children with conduct disorders. Behav Residential Treat. 1991;(4):279-88. Exclude: No included comparisons of outcomes, OVID-EMBASE.
McInnes A, Bedard AC, Hogg-Johnson S, et al. Preliminary evidence of beneficial effects of methylphenidate on listening comprehension in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2007;17(1):35-49. [pmid: 17343552]. Exclude: No included comparisons of outcomes, OVID-Medline.
McIntyre HB, Firemark HM, Cho AK, et al. Computer analyzed EEG in amphetamine-responsive hyperactive children. Psychiatry Res. 1981;4(2):189-97. Exclude: No included comparisons of outcomes,. [pmid: 6939009].
McIntyre LL. Parent behavior training for young children with developmental disabilities: randomized controlled trial. Am J Ment Retard. 2008;113(5):356-68. [pmid: 18702556]. Exclude: Not an included population, OVID-Medline.
McKay MM, Harrison ME, Gonzales J, et al. Multiple-family groups for urban children with conduct difficulties and their families. Psychiatr Serv. 2002;53(11):1467-8. [pmid: 12407277]. Exclude: No included comparisons of outcomes, OVID-Medline.
McKeage K, Scott LJ. SLI-381 (Adderall XR). CNS Drugs. 676;17(9):669-75. [pmid: 12828502]. Exclude: No included comparisons of outcomes, OVID-Medline.
McLeod M, Laubscher T, Regier L, et al. Taking the stress out of individualizing ADHD drug therapy. Can Fam Physician. 2009;(9):895-8. Exclude: No included intervention compared, EMBASE. [pmid: 19752258].
Meyer K, Kelley ML. Improving homework in adolescents with attention-deficit/hyperactivity disorder: Self vs. parent monitoring of homework behavior and study skills. Child Fam Behav Ther. 2007;29(4):25-42. Exclude: No included comparisons of outcomes,.
Mikami AY, Cox DJ, Davis MT, et al. Sex differences in effectiveness of extended-release stimulant medication among adolescents with attention-deficit/hyperactivity disorder. J Clin Psychol Med Sett. 2009;16(3):233-42. [pmid: 19418208]. Exclude: No included comparisons of outcomes, OVID-Medline.
Mikkelsen E, Lake CR, Brown GL, et al. The hyperactive child syndrome: peripheral sympathetic nervous system function and the effect of d-amphetamine. Psychiatry Res. 1981;4(2):157-69. Exclude: No included comparisons of outcomes,. [pmid: 6939007].
Milich Richards, Pelham William E. Effects of sugar ingestion on the classroom and playgroup behavior of attention deficit disordered boys. J Consult Clin Psychol. 1986;54(5):714-8. Exclude: No included intervention compared,. [pmid: 3771891].
Milich R, Carlson CL, Pelham WE Jr, et al. Effects of methylphenidate on the persistence of ADHD boys following failure experiences. J Abnorm Child Psychol. 1991;19(5):519-36. [pmid: 1770183]. Exclude: No included comparisons of outcomes, OVID-Medline.
Milich R, Licht BG, Murphy DA, et al. Attention-deficit hyperactivity disordered boys’ evaluations of and attributions for task performance on medication versus placebo. J Abnorm Psychol. 1989;98(3):280-4. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 2671083].
Miller AR, Lalonde CE, McGrail KM. Children’s persistence with methylphenidate therapy: a population-based study. Can J Psychiatr. 2004;49(11):761-8. [pmid: 15633854]. Exclude: Not an included population, OVID-Medline.
Miller GE, Prinz RJ. Engagement of families in treatment for childhood conduct problems. Behav Ther. 2003;(4):517-34. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Millichap JG, Aymat F, Sturgis LH, et al. Hyperkinetic behavior and learning disorders. 3. Battery of neuropsychological tests in controlled trial of methylphenidate. Am J Dis Child. 1968;116(3):235-44. [pmid: 5676645]. Exclude: No included comparisons of outcomes, OVID-Medline.
Millichap JG. Growth of hyperactive children treated with methylphenidate. J Learn Disabil. 1978;11(9):567-70. [pmid: 731121]. Exclude: No included comparisons of outcomes, OVID-Medline.
Minde K, Weiss G, Mendelson N. A 5-year follow-up study of 91 hyperactive school children. J Am Acad Child Psychiatry. 1972;11(3):595-610. Exclude: Not an included population, OVID-PsycINFO. [pmid: 5044734].
Mino Y, Ohara H. Methylphenidate and interpersonal relationships of children with attention deficit hyperactivity disorder. Jpn J Psychiatr Neurol. 1991;45(1):45-51. [pmid: 1753489]. Exclude: No included comparisons of outcomes, OVID-Medline.
Miranda A, Presentacion MJ, Soriano M. Effectiveness of a school-based multicomponent program for the treatment of children with ADHD. J Learn Disabil. 2002;35(6):546-62. [pmid: 15493252]. Exclude: No included comparisons of outcomes, OVID-Medline.
Miranda A, Jarque S, Rosel J. Treatment of children with ADHD: psychopedagogical program at school versus psychostimulant medication. Psicothema. 2006;18(3):335-41. [pmid: 17296053]. Exclude: No included comparisons of outcomes, OVID-Medline.
Mitchell WS, Rothwell B, Burtenshaw W. Mothers and their disturbed preschool children: an intervention study. Child Care Health Dev. 1975;1(6):389-96. [pmid: 1222499]. Exclude: Not an included population, OVID-Medline.
Modi NB, Wang B, Noveck RJ, et al. Dose-proportional and stereospecific pharmacokinetics of methylphenidate delivered using an osmotic, controlled-release oral delivery system. J Clin Pharmacol. 2000;40(10):1141-9. [pmid: 11028253]. Exclude: Not an included population, OVID-Medline.
Moll GH, Heinrich H, Trott G, et al. Deficient intracortical inhibition in drug-naive children with attention-deficit hyperactivity disorder is enhanced by methylphenidate. Neurosci Lett. 2000;284(1–2):121-5. [pmid: 10771177]. Exclude: No included comparisons of outcomes, OVID-Medline.
Molloy GN. Chemicals, exercise and hyperactivity: A short report. Int J Disabil Dev Educ. 1989;36(1):57-61. Exclude: No included intervention compared, OVID-PsycINFO.
Mooij T. Promoting prosocial pupil behavior: 2-secondary school intervention and pupil effects. Br J Educ Psychol. 1999;69(Pt 4):479-504. [pmid: 10665165]. Exclude: Not an included population, OVID-Medline.
Moore KJ, Shannon KK. The development of superstitious beliefs in the effectiveness of treatment of anger: Evidence for the importance of experimental program evaluation in applied settings. Behav Residential Treat. 1993;8(2):147-61. Exclude: Not an included population, OVID-PsycINFO.
Moore SF, Cole SO. Cognitive self-mediation training with hyperkinetic children. BPS. 1978;12(1):18-20. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Moretti MM, Holland R, Peterson S. Long term outcome of an attachment-based program for conduct disorder. Can J Psychiatr. 1994;39(6):360-70. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Morris DP, Dozier E. Subtler organic factors in behavior disorders of childhood: follow-up studies. South Med J. 1965;58(10):1213-6. [pmid: 5841443]. Exclude: Not an included population, OVID-Medline.
Muniz R, Brams M, Mao A, et al. Efficacy and safety of extended-release dexmethylphenidate compared with d,l-methylphenidate and placebo in the treatment of children with attention-deficit/hyperactivity disorder: a 12-hour laboratory classroom study. J Child Adolesc Psychopharmacol. 2008;18(3):248-56. [pmid: 18582179]. Exclude: No included comparisons of outcomes, OVID-Medline.
Murphy DA, Pelham WE, Lang AR. Aggression in boys with attention deficit-hyperactivity disorder: Methylphenidate effects on naturalistically observed aggression, response to provocation, and social information processing. J Abnorm Child Psychol. 1992;20(5):451-66. Exclude: No included comparisons of outcomes, OVID-PsycInfo. [pmid: 1487590].
Murray LK, Kollins SH. Effects of methylphenidate on sensitivity to reinforcement in children diagnosed with attention deficit hyperactivity disorder: an application of the matching law. J Appl Behav Anal. 2000;33(4):573-91. [pmid: 11214032]. Exclude: No included comparisons of outcomes, OVID-Medline.
Myers WC, Burton PR, Sanders PD, et al. Project back-on-track at 1 year: a delinquency treatment program for early-career juvenile offenders. J Am Acad Child Adolesc Psychiatry. 2000;39(9):1127-34. [pmid: 10986809]. Exclude: Not an included population, OVID-Medline.
Myren KJ, Thernlund G, Nylen A, et al. Atomoxetine’s effect on societal costs in Sweden. J Attention Disord. 2010;13(6):618-28. Exclude: No included comparisons of outcomes, ERIC.
Nahata MC, Ng L, Coury DL. Treatment of attention deficit hyperactivity disorder in pediatric patients. J Appl Ther Res. 2000;(1):1-5. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Nair V, Mahadevan S. Randomised controlled study-efficacy of clonidine versus carbamazepine in children with ADHD. J Trop Pediatr. 2009;55(2):116-21. [pmid: 19203986]. Exclude: No included comparisons of outcomes, OVID-Medline.
Najdowski AC, Wallace MD, Penrod B, et al. Caregiver-conducted experimental functional analyses of inappropriate mealtime behavior. J Appl Behav Anal. 2008;41(3):459-65. [pmid: 18816987]. Exclude: Not an included population, OVID-Medline.
Naka S, Abe K. Behavior problems in Japanese 3-year-old children. Acta Paedopsychiatr. 1966;33(1):6-11. [pmid: 5322890]. Exclude: Not an included population, OVID-Medline.
Nakken H. Research on the changes of behavior in children with physical and mental handicaps influenced by psychomotor training. Int J Rehabil Res. 1979;2(1):102-3. [pmid: 157984]. Exclude: Not an included population, OVID-Medline.
Nall A. Alpha training and the hyperkinetic child: Is it effective. Acad Ther. 1973;9(1):5-19. Exclude: Not an included population, OVID-PsycINFO.
Naruse H, Nagahata M, Nakane Y, et al. A multi-center double-blind trial of pimozide (Orap), haloperidol and placebo in children with behavioral disorders, using crossover design. Acta Paedopsychiatr. 1982;48(4):173-84. [pmid: 6756027]. Exclude: No included comparisons of outcomes, OVID-Medline.
Nash JK. Treatment of attention deficit hyperactivity disorder with neurotherapy. Clin Electroencephalogr. 2000;(1):30-7. Exclude: No included intervention compared, OVID-EMBASE. [pmid: 10638350].
National Academy for the Advancement of ADHD Care. Determining and achieving therapeutic targets in attention-deficit/hyperactivity disorder. J Clin Psychiatry. 2003;64(3):265-76. [pmid: 12716267]. Exclude: No included intervention compared, OVID-Medline.
Nemoda Z, Angyal N, Tarnok Z, et al. Carboxylesterase 1 gene polymorphism and methylphenidate response in ADHD. Neuropharmacology. 2009;57(7–8):731-3. [pmid: 19733552]. Exclude: No included comparisons of outcomes, OVID-Medline.
Newbern D, Dansereau DF, Czuchry M, et al. Node-link mapping in individual counseling: treatment impact on clients with ADHD-related behaviors. J Psychoactive Drugs. 2005;37(1):93-103. [pmid: 15916255]. Exclude: Not an included population, OVID-Medline.
Newcorn JH. Amphetamine salt compound treatment for adults with attention deficit hyperactivity disorder. Curr Psychiatr Rep. 2002;4(2):85-6. [pmid: 11914167]. Exclude: No included comparisons of outcomes, OVID-Medline.
Newcorn JH, Ivanov I. Psychopharmacologic treatment of attention-deficit/hyperactivity disorder and disruptive behavior disorders. Pediatr Ann. 2007;36(9):564-74. [pmid: 17910204]. Exclude: No included intervention compared, OVID-Medline.
Newcorn JH, Donnelly C. Cardiovascular safety of medication treatments for attention-deficit/hyperactivity disorder. Mt Sinai J Med. 2009;76(2):198-203. [pmid: 19306385]. Exclude: No included intervention compared, OVID-Medline.
Newcorn JH, Sutton VK, Zhang S, et al. Characteristics of placebo responders in pediatric clinical trials of attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2009;48(12):1165-72. Exclude: No included comparisons of outcomes, OVID-Embase. [pmid: 19858759].
Newmark SC. Nutritional intervention in ADHD. Explore. 2009;5(3):171-4. [pmid: 19409364]. Exclude: No included intervention compared, OVID-Medline.
Niccols A. Immediate and short-term outcomes of the ‘COPEing with Toddler Behavior’ parent group. J Child Psychol Psychitr Allied Disc. 2009;50(5):617-26. [pmid: 19076262]. Exclude: Not an included population, OVID-Medline.
Niederhofer H. St. John’s wort may improve some symptoms of attention-deficit hyperactivity disorder. Nat Prod Res. 2010;24(3):203-5. [pmid: 20140799]. Exclude: No included comparisons of outcomes, OVID-Medline.
Niklasson M, Niklasson I, Norlander T. Sensorimotor therapy: using stereotypic movements and vestibular stimulation to increase sensorimotor proficiency of children with attentional and motor difficulties. Percept Mot Skills. 2009;108(3):643-69. [pmid: 19725302]. Exclude: Not an included population, OVID-Medline.
Nikles CJ, Mitchell GK, Del Mar CB, et al. An n-of-1 trial service in clinical practice: testing the effectiveness of stimulants for attention-deficit/hyperactivity disorder. Pediatrics. 2006;117(6):2040-6. [pmid: 16740846]. Exclude: No included comparisons of outcomes, OVID-Medline.
Nikles CJ, Mitchell GK, Del Mar CB, et al. Long-term changes in management following n-of-1 trials of stimulants in attention-deficit/hyperactivity disorder. Eur J Clin Pharmacol. 2007;63(11):985-9. [pmid: 17701403]. Exclude: No included intervention compared, OVID-Medline.
Nilsen W. Fostering futures: a preventive intervention program for school-age children in foster care. Clin Child Psychol Psychiatr. 2007;12(1):45-63. [pmid: 17378079]. Exclude: Not an included population, OVID-Medline.
Nissen SE. ADHD drugs and cardiovascular risk. N Engl J Med. 2006;354(14):1445-8. [pmid: 16549404]. Exclude: No included comparisons of outcomes, OVID-Medline.
Nitkowski D, Petermann F, Buttner P, et al. Behavior modification of aggressive children in child welfare: evaluation of a combined intervention program. Behav Modif. 2009;33(4):474-92. [pmid: 19571325]. Exclude: No included comparisons of outcomes, OVID-Medline.
No ai. ADHD drugs may slow growth: 2-year study finds children who took various stimulant medications grew less, gained less weight than children who did not take stimulants. Psychiatr Ann. 2004;34(6):431. Exclude: Not an included population, OVID-PsycINFO.
Nolan EE, Gadow KD. Children with ADHD and tic disorder and their classmates: behavioral normalization with methylphenidate. J Am Acad Child Adolesc Psychiatry. 1997;36(5):597-604. [pmid: 9136493]. Exclude: No included comparisons of outcomes, OVID-Medline.
Nolan EE, Gadow KD. Relation between ratings and observations of stimulant drug response in hyperactive children. J Clin Child Psychol. 1994;23(1):78-90. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Northup J, Reitman D, de Back J. The STAR Program: A description and analysis of a multifaceted early intervention for young children with a diagnosis of attention deficit hyperactivity disorder. Child Fam Behav Ther. 2009;31(2):75-93. Exclude: No included comparisons of outcomes, ERIC Database.
Nye CL, Zucker RA, Fitzgerald HE. Early intervention in the path to alcohol problems through conduct problems: treatment involvement and child behavior change. J Consult Clin Psychol. 1995;63(5):831-40. [pmid: 7593877]. Exclude: Not an included population, OVID-Medline.
O’Connell RG, Bellgrove MA, Dockree PM, et al. Cognitive remediation in ADHD: effects of periodic non-contingent alerts on sustained attention to response. Neuropsychol Rehab. 2006;16(6):653-65. [pmid: 17127571]. Exclude: No included comparisons of outcomes, OVID-Medline.
O’Toole K, Abramowitz A, Morris R, et al. Effects of methylphenidate on attention and nonverbal learning in children with attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1997;36(4):531-8. [pmid: 9100428]. Exclude: No included comparisons of outcomes, OVID-Medline.
Odom SE. Effects of an educational intervention on mothers of male children with attention deficit hyperactivity disorder. J Community Health Nurs. 1996;13(4):207-20. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 8973026].
Ogden T, Hagen KA. Treatment effectiveness of Parent Management Training in Norway: a randomized controlled trial of children with conduct problems. J Consult Clin Psychol. 2008;76(4):607-21. [pmid: 18665689]. Exclude: Not an included population, OVID-Medline.
Oleinick MS, Bahn AK, Eisenberg L, et al. Early socialization experiences and intrafamilial environment. A study of psychiatric outpatient and control group children. Arch Gen Psychiatry. 1966;15(4):344-53. [pmid: 5954712]. Exclude: Not an included population, OVID-Medline.
Olson RL, Roberts MW. Alternative treatments for sibling aggression. Behav Ther. 1987;(3):243-50. Exclude: Not an included population, OVID-EMBASE.
Overtoom CC, Verbaten MN, Kemner C, et al. Effects of methylphenidate, desipramine, and L-dopa on attention and inhibition in children with Attention Deficit Hyperactivity Disorder. Behav Brain Res. 2003;145(1–2):7-15. [pmid: 14529800]. Exclude: No included comparisons of outcomes, OVID-Medline.
Overtoom CC, Bekker EM, van der Molen MW, et al. Methylphenidate restores link between stop-signal sensory impact and successful stopping in adults with attention-deficit/hyperactivity disorder. Biol Psychiatry. 2009;65(7):614-9. [pmid: 19103443]. Exclude: No included comparisons of outcomes, OVID-Medline.
Owens EB, Hinshaw SP, Kraemer HC, et al. Which treatment for whom for ADHD? Moderators of treatment response in the MTA. J Consult Clin Psychol. 2003;71(3):540-52. [pmid: 12795577]. Exclude: No included comparisons of outcomes, OVID-Medline.
Owens JS, Richerson L, Beilstein EA, et al. School-based mental health programming for children with inattentive and disruptive behavior problems: first-year treatment outcome. J Attention Disord. 2005;9(1):261-74. [pmid: 16371673]. Exclude: No included comparisons of outcomes, OVID-Medline.
Ozolins DA, Anderson RP. Effects of feedback on the vigilance task performance of hyperactive and hypoactive children. Percept Mot Skills. 1980;50(2):415-24. Exclude: No included intervention compared, OVID-PsycINFO. [pmid: 7375290].
Page JG. Pemoline (Cylert) in the treatment of childhood hyperkinesis. J Learn Disabil. 1974;7(8):498-503. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Palcic JL, Jurbergs N, Kelley ML. A comparison of teacher and parent delivered consequences: Improving classroom behavior in low-income children with ADHD. Child Fam Behav Ther. 2009;31(2):117-33. Exclude: No included comparisons of outcomes, ERIC Database.
Palkes H, Stewart M, Freedman J. Improvement in maze performance of hyperactive boys as a function of verbal-training procedures. J Spec Educ. 1971;5(4):337-42. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Pandina GJ, Bossie CA, Zhu Y, et al. Evaluating movement disorders in pediatric patients receiving risperidone: A comparison of spontaneous reports and research criteria for TD. Child Adolesc Psychiatr Ment Health. 2007. Exclude: Not an included population, EMBASE.
Pandina GJ, Bilder R, Harvey PD, et al. Risperidone and cognitive function in children with disruptive behavior disorders. Biol Psychiatry. 2007;62(3):226-34. [pmid: 17210137]. Exclude: Not an included population, OVID-Medline.
Pandina GJ, Zhu Y, Cornblatt B. Cognitive function with long-term risperidone in children and adolescents with disruptive behavior disorder. J Child Adolesc Psychopharmacol. 2009;19(6):749-56. [pmid: 20035593]. Exclude: No included comparisons of outcomes, OVID-Medline.
Parker DR, Boutelle K. Executive function coaching for college students with learning disabilities and ADHD: A new approach for fostering self-determination. Learn Disabil Res Pract. 2009;24(4):204-15. Exclude: No included comparisons of outcomes, ERIC Database.
Pataki CS, Carlson GA, Kelly KL, et al. Side effects of methylphenidate and desipramine alone and in combination in children. J Am Acad Child Adolesc Psychiatry. 1993;32(5):1065-72. [pmid: 8407753]. Exclude: No included comparisons of outcomes, OVID-Medline.
Paternite CE, Loney J, Salisbury H, et al. Childhood inattention-overactivity, aggression, and stimulant medication history as predictors of young adult outcomes. J Child Adolesc Psychopharmacol. 1999;9(3):169-84. [pmid: 10521010]. Exclude: No included intervention compared, OVID-Medline.
Patterson GR, Jones R, Whittier J, et al. A behavior modification technique for the hyperactive child. Behav Res Ther. 1964;2:217-26. Exclude: Not an included population,.
Patterson GR, Reid JB. Intervention for families of aggressive boys: a replication study. Behav Res Ther. 1973;11(4):383-94. [pmid: 4777636]. Exclude: No included comparisons of outcomes, OVID-Medline.
Patterson J, Barlow J, Mockford C, et al. Improving mental health through parenting programmes: block randomised controlled trial. Arch Dis Child. 2002;87(6):472-7. [pmid: 12456542]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pearson DA, Santos CW, Roache JD, et al. Treatment effects of methylphenidate on behavioral adjustment in children with mental retardation and ADHD. J Am Acad Child Adolesc Psychiatry. 2003;42(2):209-16. [pmid: 12544181]. Exclude: No included comparisons of outcomes, OVID-Medline.
Peck HL, Kehle TJ, Bray MA, et al. Yoga as an intervention for children with attention problems. Sch Psychol Rev. 2005;34(3):415-24. Exclude: No included comparisons of outcomes, ERIC Database.
Peeke S, Halliday R, Callaway E. Effects of two doses of methylphenidate on verbal information processing in hyperactive children. J Clin Psychopharmacol. 1984;(2):82-8. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6707244].
Pelham WE, Bender ME, Caddell J, et al. Methylphenidate and children with attention deficit disorder. Dose effects on classroom academic and social behavior. Arch Gen Psychiatry. 1985;42(10):948-52. Exclude: No included comparisons of outcomes,. [pmid: 3899046].
Pelham WE, Walker JL, Sturges J, et al. Comparative effects of methylphenidate on ADD girls and ADD boys. J Am Acad Child Adolesc Psychiatry. 1989;28(5):773-6. Exclude: No included comparisons of outcomes,. [pmid: 2676966].
Pelham WE, Murphy DA, Vannatta K, et al. Methylphenidate and attributions in boys with attention-deficit hyperactivity disorder. J Consult Clin Psychol. 1992;60(2):282-92. Exclude: No included comparisons of outcomes,. [pmid: 1592959].
Pelham WE, Hoza B, Kipp HL, et al. Effects of methylphenidate and expectancy of ADHD children’s performance, self-evaluations, persistence, and attributions on a cognitive task. Exp Clin Psychopharmacol. 1997;5(1):3-13. [pmid: 9234034]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pelham WE, Aronoff HR, Midlam JK, et al. A comparison of ritalin and adderall: efficacy and time-course in children with attention-deficit/hyperactivity disorder. Pediatrics. 1999;103(4):e43. [pmid: 10103335]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pelham WE, Gnagy EM, Greiner AR, et al. Behavioral versus behavioral and pharmacological treatment in ADHD children attending a summer treatment program. J Abnorm Child Psychol. 2000;28(6):507-25. [pmid: 11104314]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pelham WE, Gnagy EM, Burrows-MacLean L, et al. Once-a-day Concerta methylphenidate versus three-times-daily methylphenidate in laboratory and natural settings. Pediatrics. 2001;107(6):E105. [pmid: 11389303]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pelham WE, Hoza B, Pillow DR, et al. Effects of methylphenidate and expectancy on children with ADHD: behavior, academic performance, and attributions in a summer treatment program and regular classroom settings. J Consult Clin Psychol. 2002;70(2):320-35. [pmid: 11952190]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pelham WE Jr, Sturges J, Hoza J, et al. Sustained release and standard methylphenidate effects on cognitive and social behavior in children with attention deficit disorder. Pediatrics. 1987;80(4):491-501. [pmid: 3658567]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pelham WE Jr, Greenslade KE, Vodde-Hamilton M, et al. Relative efficacy of long-acting stimulants on children with attention deficit-hyperactivity disorder: a comparison of standard methylphenidate, sustained-release methylphenidate, sustained-release dextroamphetamine, and pemoline. Pediatrics. 1990;86(2):226-37. [pmid: 2196522]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pelham WE Jr, Waschbusch DA, Hoza B, et al. Effects of methylphenidate and expectancy on performance, self-evaluations, persistence, and attributions on a social task in boys with ADHD. Exp Clin Psychopharmacol. 2001;9(4):425-37. [pmid: 11764019]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pelham WEJr, Swanson JM, Furman MB, et al. Pemoline effects on children with ADHD: A time-response by dose-response analysis on classroom measures. Annu Progr Child Psychiatr Child Dev. 1996:473-93. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Pelham WE, Milich R, Walker JL. Effects of continuous and partial reinforcement and methylphenidate on learning in children with attention deficit disorder. J Abnorm Psychol. 1986;95(4):319-25. Exclude: No included comparisons of outcomes, OVID-PsycInfo. [pmid: 3805493].
Pelham WE, Carlson C, Sams SE, et al. Separate and combined effects of methylphenidate and behavior modification on boys with attention deficit-hyperactivity disorder in the classroom. J Consult Clin Psychol. 1993;61(3):506-15. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 8326053].
Pelham WE, Hoza B, Pillow DR, et al. Effects of methyphenidate and expectancy on children with ADHD: Behavior, academic performance, and attributions in a summer treatment program and regular classroom settings. J Consult Clin Psychol. 2002;70(2):320-35. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 11952190].
Pelham WE Jr, And O. Methylphenidate and baseball playing in ADHD Children: Who’s on first. J Consult Clin Psychol. 1990;58(1):130-3. Exclude: No included comparisons of outcomes, ERIC Database. [pmid: 2319047].
Penzner JB, Dudas M, Saito E, et al. Lack of effect of stimulant combination with second-generation antipsychotics on weight gain, metabolic changes, prolactin levels, and sedation in youth with clinically relevant aggression or oppositionality. J Child Adolesc Psychopharmacol. 2009;19(5):563-73. [pmid: 19877981]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pepler D, King G, Craig W, et al. The development and evaluation of a multisystem social skills group training program for aggressive children. Child Youth Care Forum. 1995;24(5):297-313. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Perez-Alvarez F, Serra-Amaya C, Timoneda-Gallart CA. Cognitive versus behavioral ADHD phenotype: what is it all about. Neuropediatrics. 2009;40(1):32-8. [pmid: 19639526]. Exclude: No included comparisons of outcomes, OVID-Medline.
Perrin JM, Friedman RA, Knilans TK, et al. Cardiovascular monitoring and stimulant drugs for attention-deficit/hyperactivity disorder. Pediatrics. 2008;122(2):451-3. [pmid: 18676566]. Exclude: No included intervention compared, OVID-Medline.
Perwien AR, Faries DE, Kratochvil CJ, et al. Improvement in health-related quality of life in children with ADHD: an analysis of placebo controlled studies of atomoxetine. J Dev Behav Pediatr. 2004;25(4):264-71. [pmid: 15308927]. Exclude: No included comparisons of outcomes, OVID-Medline.
Perwien AR, Kratochvil CJ, Faries DE, et al. Atomoxetine treatment in children and adolescents with attention-deficit hyperactivity disorder: what are the long-term health-related quality-of-life outcomes. J Child Adolesc Psychopharmacol. 2006;16(6):713-24. [pmid: 17201615]. Exclude: No included intervention compared, OVID-Medline.
Pfiffner LJ, McBurnett K. Social skills training with parent generalization: treatment effects for children with attention deficit disorder. J Consult Clin Psychol. 1997;65(5):749-57. [pmid: 9337494]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pierce D, Dixon CM, Wigal SB, et al. Pharmacokinetics of methylphenidate transdermal system (MTS): results from a laboratory classroom study. J Child Adolesc Psychopharmacol. 2008;18(4):355-64. [pmid: 18759645]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pieroth EM. Diagnosing attention-deficit/hyperactivity disorder in adults. Prof Case Manag. 2008;13(3):179-81. [pmid: 18562915]. Exclude: No included intervention compared, OVID-Medline.
Piscalkiene V. Experimental training of children with attention deficit/hyperactivity disorder. Online Submission. 2009;6(8):17-30. Exclude: No included comparisons of outcomes, ERIC Database.
Place M, Rajah S, Crake T. Combining day patient treatment with family work in a child psychiatry clinic. Eur Arch Psychiatr Neurol Sci. 1990;239(6):373-8. [pmid: 2144238]. Exclude: Not an included population, OVID-Medline.
Platt JE, Campbell M, Green WH, et al. Cognitive effects of lithium carbonate and haloperidol in treatment-resistant aggressive children. Arch Gen Psychiatry. 1984;(7):657-62. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6428372].
Platt JE, Campbell M, Grega DM, et al. Cognitive effects of haloperidol and lithium in aggressive conduct-disorder children. Psychopharmacol Bull. 1984;20(1):93-7. Exclude: No included comparisons of outcomes,. [pmid: 6718655].
Pliszka SR, Lancaster J, Liotti M, et al. Volumetric MRI differences in treatment-naive vs chronically treated children with ADHD. Neurology. 2006;(6):1023-7. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 17000972].
Pliszka SR, Liotti M, Bailey BY, et al. Electrophysiological effects of stimulant treatment on inhibitory control in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2007;17(3):356-66. [pmid: 17630869]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pliszka SR. Effect of anxiety on cognition, behavior, and stimulant response in ADHD. Annu Progr Child Psychiatr Child Dev. 1990:454-66. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Plumer PJ, Stoner G. The relative effects of classwide peer tutoring and peer coaching on the positive social behaviors of children with ADHD. J Attention Disord. 2005;9(1):290-300. [pmid: 16371675]. Exclude: No included comparisons of outcomes, OVID-Medline.
Pohl GM, Van Brunt DL, Ye W, et al. A retrospective claims analysis of combination therapy in the treatment of adult attention-deficit/hyperactivity disorder (ADHD). BMC Health Serv Res. 2009;9:95. [pmid: 19505334]. Exclude: Not an included population, OVID-Medline.
Polak L, Molcan J. Clonidine in hyperkinetic children. Act Nerv Super. 1990;32(1):66-7. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Porrino LJ, Rapoport JL, Behar D. A naturalistic assessment of the motor activity of hyperactive boys: II. Stimulant drug effects. Arch Gen Psychiatry. 1983;(6):688-93. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6847336].
Porter SS, Omizo MM. The effects of group relaxation training/large muscle exercise, and parental involvement on attention to task, impulsivity, and locus of control among hyperactive boys. Except Child. 1984;31(1):54-64. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Posey DJ, Aman MG, McCracken JT, et al. Positive effects of methylphenidate on inattention and hyperactivity in pervasive developmental disorders: an analysis of secondary measures. Biol Psychiatry. 2007;61(4):538-44. [pmid: 17276750]. Exclude: No included comparisons of outcomes, OVID-Medline.
Powell L, Gilchrist M, Stapley J. A journey of self-discovery: An intervention involving massage, yoga and relaxation for children with emotional and behavioral difficulties attending primary schools. Emotional & Behavioral Difficulties. 2008;13(3):193-9. Exclude: No included comparisons of outcomes, ERIC Database.
Prasad S, Harpin V, Poole L, et al. A multi-centre, randomised, open-label study of atomoxetine compared with standard current therapy in UK children and adolescents with attention-deficit/hyperactivity disorder (ADHD). Curr Med Res Opin. 2007;23(2):379-94. [pmid: 17288692]. Exclude: No included comparisons of outcomes, OVID-Medline.
Preen DB, Calver J, Sanfilippo FM, et al. Patterns of psychostimulant prescribing to children with ADHD in Western Australia: variations in age, gender, medication type and dose prescribed. Aust N Z J Pub Health. 2007;31(2):120-6. [pmid: 17461001]. Exclude: No included comparisons of outcomes, OVID-Medline.
Preuss U, Ralston SJ, Baldursson G, et al. Study design, baseline patient characteristics and intervention in a cross-cultural framework: results from the ADORE study. Eur Child Adolesc Psychiatr. 2006;15(Suppl 1):14. [pmid: 17177015]. Exclude: No included intervention compared, OVID-Medline.
Prince JB, Wilens TE, Biederman J, et al. A controlled study of nortriptyline in children and adolescents with attention deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 2000;10(3):193-204. [pmid: 11052409]. Exclude: No included comparisons of outcomes, OVID-Medline.
Prinz RJ, Miller GE. Family-based treatment for childhood antisocial behavior: Experimental influences on dropout and engagement. J Consult Clin Psychol. 1994;(3):645-50. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 8063993].
Pritchard M, Graham P. An investigation of a group of patients who have attended both the child and adult departments of the same psychiatric hospital. Br J Psychiatry. 1966;112(487):603-12. [pmid: 5964702]. Exclude: Not an included population, OVID-Medline.
Ptacek R, Kuzelova H, Paclt I, et al. ADHD and growth: anthropometric changes in medicated and non-medicated ADHD boys. Med Sci Monitor. 2009;15(12):CR595-599. [pmid: 19946228]. Exclude: No included comparisons of outcomes, OVID-Medline.
Quinn D, Wigal S, Swanson J, et al. Comparative pharmacodynamics and plasma concentrations of d-threo-methylphenidate hydrochloride after single doses of d-threo-methylphenidate hydrochloride and d,l-threo-methylphenidate hydrochloride in a double-blind, placebo-controlled, crossover laboratory school study in children with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2004;43(11):1422-9. [pmid: 15502602]. Exclude: No included comparisons of outcomes, OVID-Medline.
Quinn PO, Rapoport JL. One-year follow-up of hyperactive boys treated with imipramine or methylphenidate. Am J Psychiatry. 1975;132(3):241-5. Exclude: Not an included population,. [pmid: 1090193].
Quintanilla J. A half-day treatment program. Hosp Community Psychiatr. 1966;17(6):161. [pmid: 5931319]. Exclude: Not an included population, OVID-Medline.
Rabiner DL, Murray DW, Skinner AT, et al. A randomized trial of two promising computer-based interventions for students with attention difficulties. J Abnorm Child Psychol. 2010;38(1):131-42. [pmid: 19697119]. Exclude: No included comparisons of outcomes, OVID-Medline.
Radigan M, Lannon P, Roohan P, et al. Medication patterns for attention-deficit/hyperactivity disorder and comorbid psychiatric conditions in a low-income population. J Child Adolesc Psychopharmacol. 2005;15(1):44-56. [pmid: 15741785]. Exclude: No included intervention compared, OVID-Medline.
Rains A, Scahill L. New long-acting stimulants in children with ADHD. J Child Adolesc Psychiatr Nurs. 2004;17(4):177-9. [pmid: 15742799]. Exclude: No included intervention compared, OVID-Medline.
Rajesh AS, Bates G, Wright JG. Atomoxetine-induced electrocardiogram changes. Arch Dis Child. 2006;91(12):1023-4. [pmid: 17119076]. Exclude: No included comparisons of outcomes, OVID-Medline.
Ramer JC, Tinker DE, Domoto M. Short-term admission for behavior modification. Am J Dis Child. 1986;140(3):242-4. [pmid: 3946353]. Exclude: No included comparisons of outcomes, OVID-Medline.
Randolph DL, Wallin KR. A comparison of behavioral consultation and behavioral consultation with model-reinforcement group counseling for children who are consistently off-task. J Educ Res. 1973;67(3):103-7. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Rao JK, Julius JR, Breen TJ, et al. Response to growth hormone in attention deficit hyperactivity disorder: effects of methylphenidate and pemoline therapy. Pediatrics. 1998;102(2:Pt 3):497-500. [pmid: 9685452]. Exclude: Not an included population, OVID-Medline.
Rapoport J. Childhood behavior and learning problems treated with imipramine. Int J Neuropsychiatry. 1965;1(6):635-42. [pmid: 5886540]. Exclude: No included comparisons of outcomes, OVID-Medline.
Rapoport J, Quinn P, Scribanu N, et al. Platelet serotonin of hyperactive school age boys. Br J Psychiatry. 1974;125:138-40. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 4606916].
Rapoport JL, Quinn PO, Bradbard G, et al. Imipramine and methylphenidate treatments of hyperactive boys. A double-blind comparison. Arch Gen Psychiatry. 1974;30(6):789-93. [pmid: 4598851]. Exclude: No included comparisons of outcomes, OVID-Medline.
Rapoport JL, Quinn PO, Copeland AP, et al. ACTH 4–10 cognitive and behavioral effects in hyperactive, learning-disabled children. Neuropsychobiology. 1977;2(5–6):291-6. Exclude: No included comparisons of outcomes,. [pmid: 197444].
Rapoport JL, Tepsic PN, Grice J, et al. Decreased motor activity of hyperactive children on dextroamphetamine during active gym program. Psychiatry Res. 1980;2(3):225-9. Exclude: No included comparisons of outcomes,. [pmid: 6932064].
Rapp DJ. Does diet affect hyperactivity. J Learn Disabil. 1978;11(6):383-9. [pmid: 670829]. Exclude: No included intervention compared, OVID-Medline.
Rapp DJ. Food allergy treatment for hyperkinesis. J Learn Disabil. 1979;12(9):608-16. Exclude: No included intervention compared, OVID-PsycINFO. [pmid: 541570].
Rappley MD, Eneli IU, Mullan PB, et al. Patterns of psychotropic medication use in very young children with attention-deficit hyperactivity disorder. J Dev Behav Pediatr. 2002;23(1):23-30. [pmid: 11889348]. Exclude: No included intervention compared, OVID-Medline.
Rapport MD, Dupaul GJ, Stoner G, et al. Comparing classroom and clinic measures of attention deficit disorder: differential, idiosyncratic, and dose-response effects of methylphenidate. J Consult Clin Psychol. 1986;54(3):334-41. Exclude: No included comparisons of outcomes,. [pmid: 3522683].
Rapport MD, Carlson GA, Kelly KL, et al. Methylphenidate and desipramine in hospitalized children: I. Separate and combined effects on cognitive function. J Am Acad Child Adolesc Psychiatry. 1993;32(2):333-42. [pmid: 8444762]. Exclude: No included comparisons of outcomes, OVID-Medline.
Rapport MD, Denney C. Titrating methylphenidate in children with attention-deficit/hyperactivity disorder: is body mass predictive of clinical response. J Am Acad Child Adolesc Psychiatry. 1997;36(4):523-30. [pmid: 9100427]. Exclude: No included comparisons of outcomes, OVID-Medline.
Rapport MD, Randall R, Moffitt C. Attention-Deficit/Hyperactivity Disorder and methylphenidate: a dose-response analysis and parent-child comparison of somatic complaints. J Attention Disord. 2002;6(1):15-24. [pmid: 12045757]. Exclude: No included comparisons of outcomes, OVID-Medline.
Rapport MD, Kofler MJ, Coiro MM, et al. Unexpected effects of methylphenidate in attention-deficit/hyperactivity disorder reflect decreases in core/secondary symptoms and physical complaints common to all children. J Child Adolesc Psychopharmacol. 2008;18(3):237-47. [pmid: 18582178]. Exclude: No included comparisons of outcomes, OVID-Medline.
Rapport MD, Quinn SO, DuPaul GJ, et al. Attention deficit disorder with hyperactivity and methylphenidate: The effects of dose and mastery level on children’s learning performance. J Abnorm Child Psychol. 1989;17(6):669-89. Exclude: No included comparisons of outcomes, OVID-PsycInfo. [pmid: 2607058].
Raver CC, Jones SM, Li-Grining C, et al. Targeting children’s behavior problems in preschool classrooms: a cluster-randomized controlled trial. J Consult Clin Psychol. 2009;77(2):302-16. [pmid: 19309189]. Exclude: Not an included population, OVID-Medline.
Ravich RA, Dunton HD. “Say you’re sorry”--a ten-year follow-up. Am J Psychother. 1966;20(4):615-26. [pmid: 5972568]. Exclude: Not an included population, OVID-Medline.
Ray DC, Schottelkorb A, Tsai MH. Play therapy with children exhibiting symptoms of attention deficit hyperactivity disorder. Int J Play Ther. 2007;16(2):95-111. Exclude: No included comparisons of outcomes,.
Reid MJ, Webster-Stratton C, Hammond M. Enhancing a classroom social competence and problem-solving curriculum by offering parent behavior training to families of moderate-to high-risk elementary school children. J Clin Child Adolesc Psychol. 2007;36(4):605-20. [pmid: 18088218]. Exclude: No included intervention compared, OVID-Medline.
Reid MK, Borkowski JG. Effects of methylphenidate (Ritalin) on information processing in hyperactive children. J Abnorm Child Psychol. 1984;(1):169-86. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6715692].
Reimherr FW, Wender PH, Ebert MH, et al. Cerebrospinal fluid homovanillic acid and 5-hydroxyindoleacetic acid in adults with attention deficit disorder, residual type. Psychiatry Res. 1984;11(1):71-8. Exclude: No included comparisons of outcomes,. [pmid: 6200893].
Reinhardt MC, Benetti L, Victor MM, et al. Is age-at-onset criterion relevant for the response to methylphenidate in attention-deficit/hyperactivity disorder. J Clin Psychiatry. 2007;68(7):1109-16. [pmid: 17685750]. Exclude: No included comparisons of outcomes, OVID-Medline.
Reitman D, Hupp SD, O’Callaghan PM, et al. The influence of a token economy and methylphenidate on attentive and disruptive behavior during sports with ADHD-diagnosed children. Behav Modif. 2001;25(2):305-23. [pmid: 11317639]. Exclude: No included comparisons of outcomes, OVID-Medline.
Research Units on Pediatric Psychopharmacology Autism Network. Randomized, controlled, crossover trial of methylphenidate in pervasive developmental disorders with hyperactivity. Arch Gen Psychiatry. 2005;62(11):1266-74. [pmid: 16275814]. Exclude: Not an included population, OVID-Medline.
Reyes M, Buitelaar J, Toren P, et al. A randomized, double-blind, placebo-controlled study of risperidone maintenance treatment in children and adolescents with disruptive behavior disorders. Am J Psychiatry. 2006;163(3):402-10. [pmid: 16513860]. Exclude: No included comparisons of outcomes, OVID-Medline.
Reyes M, Olah R, Csaba K, et al. Long-term safety and efficacy of risperidone in children with disruptive behavior disorders. Results of a 2-year extension study. Eur Child Adolesc Psychiatr. 2006;15(2):97-104. [pmid: 16523250]. Exclude: Not an included population, OVID-Medline.
Rhodes SM, Coghill DR, Matthews K. Methylphenidate restores visual memory, but not working memory function in attention deficit-hyperkinetic disorder. Psychopharmacol. 2004;175(3):319-30. [pmid: 15138760]. Exclude: No included comparisons of outcomes, OVID-Medline.
Richardson AJ, Montgomery P. The. Oxford. -Durham study: a randomized, controlled trial of dietary supplementation with fatty acids in children with developmental coordination disorder. Pediatrics. 2005;115(5):1360-6. [pmid: 15867048]. Exclude: Not an included population, OVID-Medline.
Richardson E, Kupietz S, Maitinsky S. What is the role of academic intervention in the treatment of hyperactive children with reading disorders. J Child Contemp Soc. 1986;19(1–2):153-67. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Rickel AU, Smith RL, Sharp KC. Description and evaluation of a preventive mental health program for preschoolers. J Abnorm Child Psychol. 1979;7(1):101-12. [pmid: 438427]. Exclude: Not an included population, OVID-Medline.
Rickel AU, Smith RL. Maladapting preschool children: identification, diagnosis, and remediation. Am J Community Psychol. 1979;7(2):197-208. [pmid: 474536]. Exclude: Not an included population, OVID-Medline.
Rickson DJ, Watkins WG. Music therapy to promote prosocial behaviors in aggressive adolescent boys--a pilot study. J Music Ther. 2003;40(4):283-301. [pmid: 15015908]. Exclude: No included comparisons of outcomes, OVID-Medline.
Rickson DJ. Instructional and improvisational models of music therapy with adolescents who have attention deficit hyperactivity disorder (ADHD): a comparison of the effects on motor impulsivity. J Music Ther. 2006;43(1):39-62. [pmid: 16671837]. Exclude: Not an included population, OVID-Medline.
Riddle KD, Rapoport JL. A 2-year follow-up of 72 hyperactive boys. Classroom behavior and peer acceptance. J Nerv Ment Dis. 1976;162(2):126-34. Exclude: Not an included population,. [pmid: 1249566].
Riordan HJ, Flashman LA, Saykin AJ, et al. Neuropsychological correlates of methylphenidate treatment in adult ADHD with and without depression. Arch Clin Neuropsychol. 1999;(2):217-33. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 14590604].
Risser MG, Bowers TG. Cognitive and neuropsychological characteristics of attention deficit hyperactivity disorder children receiving stimulant medications. Percept Mot Skills. 1993;77(3, Pt 1):1023-31. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 8284137].
Robison LM, Sclar DA, Skaer TL, et al. Treatment modalities among US children diagnosed with attention-deficit hyperactivity disorder: 1995–99. Int Clin Psychopharmacol. 2004;19(1):17-22. [pmid: 15101565]. Exclude: No included comparisons of outcomes, OVID-Medline.
Rogevich ME, Perin D. Effects on science summarization of a reading comprehension intervention for adolescents with behavior and attention disorders. Except Child. 2008;74(2):135-54. Exclude: No included comparisons of outcomes, ERIC Database.
Rohde LA. ADHD in Brazil: the DSM-IV criteria in a culturally different population. J Am Acad Child Adolesc Psychiatry. 2002;41(9):1131-3. [pmid: 12218435]. Exclude: No included intervention compared, OVID-Medline.
Rohde P, Clarke GN, Mace DE, et al. An efficacy/effectiveness study of cognitive-behavioral treatment for adolescents with comorbid major depression and conduct disorder. J Am Acad Child Adolesc Psychiatry. 2004;43(6):660-8. [pmid: 15167082]. Exclude: Not an included population, OVID-Medline.
Rooney KJ. Independent strategies for efficient study: A core approach. Acad Ther. 1989;24(4):383-90. Exclude: Not an included population, ERIC Database.
Rosekrans MA, Hartup WW. Imitative influences of consistent and inconsistent response consequences to a model on aggressive behavior in children. J Pers Soc Psychol. 1967;7(4):429-34. [pmid: 6065873]. Exclude: Not an included population, OVID-Medline.
Rosenblatt A, Attkisson CC. Integrating systems of care in California for youth with severe emotional disburbance: I. A descriptive overview of the California AB377 Evaluation Project. J Child Fam Studies. 1992;1(1):93-113. Exclude: Not an included population, OVID-PsycINFO.
Ross RG. Psychotic and manic-like symptoms during stimulant treatment of attention deficit hyperactivity disorder. Am J Psychiatry. 2006;163(7):1149-52. [pmid: 16816217]. Exclude: No included intervention compared, OVID-Medline.
Rossiter T. The effectiveness of neurofeedback and stimulant drugs in treating AD/HD: part II. Replication Appl Psychophysiol Biofeedback. 2004;29(4):233-43. [pmid: 15707253]. Exclude: No included comparisons of outcomes, OVID-Medline.
Rostain AL. Guanfacine extended release in the treatment of attention-deficit/hyperactivity disorder. Curr Psychiatr Rep. 2009;(5):339-40. Exclude: No included comparisons of outcomes, EMBASE.
Rostain AL. Lisdexamfetamine in the treatment of attention-deficit/hyperactivity disorder in adults. Curr Psychiatr Rep. 2009;(5):341-2. Exclude: No included comparisons of outcomes, EMBASE.
Rothenberger A, Banaschewski T. Control examinations in methylphenidate therapy. Padiatrische Praxis. 2002;(1):157-60. Exclude: Not an included population, OVID-EMBASE.
Rothschild CJ, Nicol H. Allergic reaction to methylphenidate. Can Med Assoc J. 1972;106(10):1064. [pmid: 5032136]. Exclude: No included intervention compared, OVID-Medline.
Rowe KS. Synthetic food colourings and ‘hyperactivity’: a double-blind crossover study. Aust Paediatr J. 1988;24(2):143-7. [pmid: 3395307]. Exclude: No included comparisons of outcomes, OVID-Medline.
Rowlandson PH, Smith C. An interagency service delivery model for autistic spectrum disorders and attention deficit hyperactivity disorder. Child Care Health Dev. 2009;(5):681-90. Exclude: No included intervention compared, EMBASE. [pmid: 19320646].
Rubia K, Noorloos J, Smith A, et al. Motor timing deficits in community and clinical boys with hyperactive behavior: the effect of methylphenidate on motor timing. J Abnorm Child Psychol. 2003;31(3):301-13. [pmid: 12774863]. Exclude: No included comparisons of outcomes, OVID-Medline.
Rubia K, Halari R, Christakou A, et al. Impulsiveness as a timing disturbance: neurocognitive abnormalities in attention-deficit hyperactivity disorder during temporal processes and normalization with methylphenidate. Phil Trans Roy Soc Lond B Biol Sci. 2009;364(1525):1919-31. [pmid: 19487194]. Exclude: No included comparisons of outcomes, OVID-Medline.
Rubin R, Balow B. Learning and behavior disorders: a longitudinal study. Except Child. 1971;38(4):293-9. [pmid: 4256278]. Exclude: No included intervention compared, OVID-Medline.
Rugino TA, Copley TC. Effects of modafinil in children with attention-deficit/hyperactivity disorder: an open-label study. J Am Acad Child Adolesc Psychiatry. 2001;40(2):230-5. [pmid: 11211372]. Exclude: No included comparisons of outcomes, OVID-Medline.
Ryle A, Pond DA, Hamilton M. The prevalence and patterns of psychological disturbance in children of primary age. J Child Psychol Psychitr Allied Disc. 1965;6(2):101-13. [pmid: 5851097]. Exclude: Not an included population, OVID-Medline.
Sadiq AJ. Attention-deficit/hyperactivity disorder and integrative approaches. Pediatr Ann. 2007;36(8):508-15. [pmid: 17824277]. Exclude: Not an included population, OVID-Medline.
Sadiq AJ. Attention-deficit/Hyperactivity disorder and integrative approaches. Psychiatr Ann. 2007;37(9):630-8. Exclude: Not an included population,.
Safer D, Allen R, Barr E. Depression of growth in hyperactive children on stimulant drugs. New Eng J Med. 1972;287(5):217-20. Exclude: No included comparisons of outcomes,. [pmid: 4556640].
Safer DJ, Allen RP. Drug comparison in hyperactive children. Am J Psychiatry. 1973;130(8):939-40. Exclude: Not an included population,. [pmid: 4577472].
Safer D, Krager JM. Hyperactivity and inattentiveness: School assessment of stimulant treatment. Clin Pediatr. 1989;28(5):216-21. Exclude: Not an included population, OVID-PsycINFO.
Safer DJ, Allen RP. Stimulant drug treatment of hyperactive adolescents. Dis Nerv Syst. 1975;36(8):454-7. Exclude: Not an included population, OVID-PsycINFO. [pmid: 1164867].
Safren SA, Otto MW, Sprich S, et al. Cognitive-behavioral therapy for ADHD in medication-treated adults with continued symptoms. Behav Res Ther. 2005;43(7):831-42. [pmid: 15896281]. Exclude: No included comparisons of outcomes, OVID-Medline.
Saklofske DH, Schwean VL. Standardized procedures for measuring the correlates of ADHD in children: A research program. Can J Sch Psychol. 1993;9(1):28-36. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Saletu B, Saletu M, Simeon J, et al. Comparative symptomatological and evoked potential studies with d-amphetamine, thioridazine, and placebo in hyperkinetic children. Biol Psychiatry. 1975;10(3):253-75. Exclude: No included comparisons of outcomes,. [pmid: 1095081].
Sallee F, Stiller R, Perel J, et al. Oral pemoline kinetics in hyperactive children. Clin Pharmacol Ther. 1985;(6):606-9. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 4006361].
Samuels JA, Franco K, Wan F, et al. Effect of stimulants on 24-h ambulatory blood pressure in children with ADHD: a double-blind, randomized, cross-over trial. Pediatr Nephrol. 2006;21(1):92-5. [pmid: 16254730]. Exclude: No included comparisons of outcomes, OVID-Medline.
Sanders M, Calam R, Durand M, et al. Does self-directed and web-based support for parents enhance the effects of viewing a reality television series based on the Triple P - Positive Parenting Programme. J Child Psychol Psychitr Allied Disc. 2008;(9):924-32. Exclude: Not an included population, EMBASE.
Sanders MR, Markie-Dadds C, Tully LA, et al. The triple P-positive parenting program: a comparison of enhanced, standard, and self-directed behavioral family intervention for parents of children with early onset conduct problems. J Consult Clin Psychol. 2000;68(4):624-40. Exclude: Not an included population,. [pmid: 10965638].
Sanders MR, Ralph A, Sofronoff K, et al. Every family: a population approach to reducing behavioral and emotional problems in children making the transition to school. J Prim Prev. 2008;29(3):197-222. [pmid: 18461457]. Exclude: Not an included population, OVID-Medline.
Sandler A, Glesne C, Geller G. Children’s and parents’ perspectives on open-label use of placebos in the treatment of ADHD. Child Care Health Dev. 2008;34(1):111-20. [pmid: 18171452]. Exclude: No included comparisons of outcomes, OVID-Medline.
Sangal RB, Sangal JM. Attention-deficit/hyperactivity disorder: cognitive evoked potential (P300) amplitude predicts treatment response to atomoxetine. Clin Neurophysiol. 2005;116(3):640-7. [pmid: 15721078]. Exclude: No included intervention compared, OVID-Medline.
Sangal RB, Owens J, Allen AJ, et al. Effects of atomoxetine and methylphenidate on sleep in children with ADHD. Sleep. 2006;29(12):1573-85. [pmid: 17252888]. Exclude: No included comparisons of outcomes, OVID-Medline.
Satterfield JH, Cantwell DP, Saul RE, et al. Response to stimulant drug treatment in hyperactive children: prediction from EEG and neurological findings. J Autism Child Schizophr. 1973;3(1):36-48. [pmid: 4740584]. Exclude: No included comparisons of outcomes, OVID-Medline.
Satterfield JH, Cantwell DP, Satterfield BT. Multimodality treatment: A one-year follow-up of 84 hyperactive boys. Arch Gen Psychiatry. 1979;36(9):965-74. Exclude: No included intervention compared, OVID-PsycINFO. [pmid: 464746].
Saxena K, Mora L, Torres E, et al. Divalproex sodium-ER in outpatients with disruptive behavior disorders: A three month open label study. Child Psychiatry Hum Dev. 2010;41(3):274-84. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 20043204].
Saxon SA, Magee JT, Siegel DS. Activity level patterns in the hyperactive Ritalin responder and non-responder. J Clin Child Psychol. 1977;6(3):27-9. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Sayger TV, Horne AM, Walker JM, et al. Social learning family therapy with aggressive children: Treatment outcome and maintenance. J Fam Psychol. 1988;1(3):261-85. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Sayger TV, Horne AM, Glaser BA. Marital satisfaction and social learning family therapy for child conduct problems: Generalization of treatment effects. J Marital Fam Ther. 1993;19(4):393-402. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 21118477].
Scahill L, Chappell PB, Kim YS, et al. A placebo-controlled study of guanfacine in the treatment of children with tic disorders and attention deficit hyperactivity disorder. Am J Psychiatry. 2001;158(7):1067-74. [pmid: 11431228]. Exclude: No included comparisons of outcomes, OVID-Medline.
Scarboro ME, Forehand R. Effects of two types of response-contingent time-out on compliance and oppositional behavior of children. J Exp Child Psychol. 1975;19(2):252-64. [pmid: 1151283]. Exclude: Not an included population, OVID-Medline.
Schachar R, Taylor E, Wieselberg M, et al. Changes in family function and relationships in children who respond to methylphenidate. J Am Acad Child Adolesc Psychiatry. 1987;26(5):728-32. Exclude: No included comparisons of outcomes,. [pmid: 3667503].
Schaefer JW, Palkes HS, Stewart MA. Group counseling for parents of hyperactive children. Child Psychiatry Hum Dev. 1974;5(2):89-94. [pmid: 4442295]. Exclude: No included comparisons of outcomes, OVID-Medline.
Schechter MD, Timmons GD. Objectively measured hyperactivity - II. Caffeine and amphetamine effects. J Clin Pharmacol. 1985;(4):276-80. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 4008672].
Scheffler RM, Brown TT, Fulton BD, et al. Positive association between attention-deficit/ hyperactivity disorder medication use and academic achievement during elementary school. Pediatrics. 2009;123(5):1273-9. [pmid: 19403491]. Exclude: Not an included population, OVID-Medline.
Scheres A, Oosterlaan J, Sergeant JA. Response inhibition in children with DSM-IV subtypes of AD/HD and related disruptive disorders: the role of reward. Child Neuropsychol. 2001;7(3):172-89. [pmid: 12187474]. Exclude: No included comparisons of outcomes, OVID-Medline.
Scheres A, Oosterlaan J, Swanson J, et al. The effect of methylphenidate on three forms of response inhibition in boys with AD/HD. J Abnorm Child Psychol. 2003;31(1):105-20. [pmid: 12597703]. Exclude: No included comparisons of outcomes, OVID-Medline.
Scheres A, Oosterlaan J, Sergeant JA. Speed of inhibition predicts teacher-rated medication response in boys with attention deficit hyperactivity disorder. Int J Disabil Dev Educ. 2006;53(1):93-109. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Schertz M, Adesman AR, Alfieri NE, et al. Predictors of weight loss in children with attention deficit hyperactivity disorder treated with stimulant medication. Pediatrics. 1996;(4):763-9. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 8885958].
Schleser R, Meyers AW, Cohen R, et al. Self-instruction interventions with non-self-controlled children: effects of discovery versus faded rehearsal. J Consult Clin Psychol. 1983;51(6):954-5. Exclude: No included comparisons of outcomes,. [pmid: 6655112].
Schmidt MH, Mocks P, Lay B, et al. Does oligoantigenic diet influence hyperactive/conduct-disordered children--a controlled trial. Eur Child Adolesc Psychiatr. 1997;6(2):88-95. [pmid: 9257090]. Exclude: No included comparisons of outcomes, OVID-Medline.
Schmidt ME, Kruesi MJP, Elia J, et al. Effect of dextroamphetamine and methylphenidate on calcium and magnesium concentration in hyperactive boys. Psychiatry Res. 1994;54(2):199-210. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 7761553].
Schoenwald SK, Carter RE, Chapman JE, et al. Therapist adherence and organizational effects on change in youth behavior problems one year after multisystemic therapy. Admin Pol Ment Health. 2008;35(5):379-94. [pmid: 18561019]. Exclude: No included comparisons of outcomes, OVID-Medline.
Scholer SJ, Hudnut-Beumler J, Dietrich MS. A brief primary care intervention helps parents develop plans to discipline. Pediatrics. 2010;125(2):e242-e249. Exclude: Not an included population, OVID-Embase. [pmid: 20083523].
Schweitzer JB, Sulzer-Azaroff B. Self-control in boys with Attention Deficit Hyperactivity Disorder: Effects of added stimulation and time. J Child Psychol Psychitr Allied Disc. 1995;(4):671-86. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Scott S, Spender Q, Doolan M, et al. Multicentre controlled trial of parenting groups for childhood antisocial behavior in clinical practice. BMJ. 2001;323(7306):194-8. [pmid: 11473908]. Exclude: No included comparisons of outcomes, OVID-Medline.
Sebrechts MM, Shaywitz SE, Shaywitz BA. Components of attention, methylphenidate dosage, and blood levels in children with attention deficit disorder. Pediatrics. 1986;(2):222-8. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3945535].
Seeger G, Schloss P, Schmidt MH. Marker gene polymorphisms in hyperkinetic disorder--predictors of clinical response to treatment with methylphenidate. Neurosci Lett. 2001;313(1–2):45-8. [pmid: 11684336]. Exclude: No included comparisons of outcomes, OVID-Medline.
Seifert J, Scheuerpflug P, Zillessen KE, et al. Electrophysiological investigation of the effectiveness of methylphenidate in children with and without ADHD. J NeuralTransm. 2003;110(7):821-9. [pmid: 12811642]. Exclude: No included comparisons of outcomes, OVID-Medline.
Semrud-Clikeman M, Nielsen KH, Clinton A, et al. An intervention approach for children with teacher- and parent-identified attentional difficulties. J Learn Disabil. 1999;32(6):581-90. [pmid: 15510444]. Exclude: No included comparisons of outcomes, OVID-Medline.
Semrud-Clikeman M, Pliszka SR, Lancaster J, et al. Volumetric MRI differences in treatment-naive vs chronically treated children with ADHD. Neurology. 2006;67(6):1023-7. [pmid: 17000972]. Exclude: No included comparisons of outcomes, OVID-Medline.
Semrud-Clikeman M, Pliszka S, Liotti M. Executive functioning in children with attention-deficit/hyperactivity disorder: combined type with and without a stimulant medication history. Neuropsychology. 2008;22(3):329-40. [pmid: 18444711]. Exclude: No included comparisons of outcomes, OVID-Medline.
Shader RI, Harmatz JS, Oesterheld JR, et al. Population pharmacokinetics of methylphenidate in children with attention-deficit hyperactivity disorder. J Clin Pharmacol. 1999;39(8):775-85. [pmid: 10434228]. Exclude: No included comparisons of outcomes, OVID-Medline.
Shaffer RJ, Jacokes LE, Cassily JF, et al. Effect of interactive metronome training on children with ADHD. Am J Occup Ther. 2001;55(2):155-62. [pmid: 11761130]. Exclude: No included comparisons of outcomes, OVID-Medline.
Shaw DS, Dishion TJ, Supplee L, et al. Randomized trial of a family-centered approach to the prevention of early conduct problems: 2-year effects of the family check-up in early childhood. J Consult Clin Psychol. 2006;74(1):1-9. [pmid: 16551138]. Exclude: Not an included population, OVID-Medline.
Shaw DS, Connell A, Dishion TJ, et al. Improvements in maternal depression as a mediator of intervention effects on early childhood problem behavior. Dev Psychopathol. 2009;21(2):417-39. [pmid: 19338691]. Exclude: Not an included population, OVID-Medline.
Shaw P, Sharp WS, Morrison M, et al. Psychostimulant treatment and the developing cortex in attention deficit hyperactivity disorder. Am J Psychiatry. 2009;166(1):58-63. [pmid: 18794206]. Exclude: No included comparisons of outcomes, OVID-Medline.
Shechtman Z. Client behavior and therapist helping skills in individual and group treatment of aggressive boys. J Counsel Psychol. 2004;51(4):463-72. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Shekim WO, Sinclair E, Glaser R. Norepinephrine and dopamine metabolites and educational variables in boys with attention deficit disorder and hyperactivity. J Child Neurol. 1987;(1):50-6. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3624828].
Sherburne S, Utley B, McConnell S, et al. Decreasing violent or aggressive theme play among preschool children with behavior disorders. Except Child. 1988;55(2):166-72. [pmid: 2980300]. Exclude: Not an included population, OVID-Medline.
Sherwin AC, Schoelly ML, Klein BL, et al. Determination of psychiatric impairment in children. J Nerv Ment Dis. 1965;141(3):333-41. [pmid: 5891973]. Exclude: Not an included population, OVID-Medline.
Shin WC, Song DH, Ha EH, et al. Six-week open-label trial of topiramate to treat disruptive behaviors in children and adolescents with or without mental retardation. Psychiatr Investig. 2006;(2):73-80. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Shivram R, Bankart J, Meltzer H, et al. Service utilization by children with conduct disorders: findings from the 2004 Great Britain child mental health survey. Eur Child Adolesc Psychiatr. 2009;18(9):555-63. [pmid: 19353233]. Exclude: Not an included population, OVID-Medline.
Silva RR, Campbell M, Golden RR, et al. Side effects associated with lithium and placebo administration in aggressive children. Psychopharmacol Bull. 1992;28(3):319-26. [pmid: 1480737]. Exclude: No included comparisons of outcomes, OVID-Medline.
Simeon J, Milin R, Walker S. A retrospective chart review of risperidone use in treatment-resistant children and adolescents with psychiatric disorders. Prog Neuropsychopharmacol Biol Psychiatr. 2002;(2):267-75. Exclude: Not an included population, OVID-EMBASE.
Sirois PA, Montepiedra G, Kapetanovic S, et al. Impact of medications prescribed for treatment of attention-deficit hyperactivity disorder on physical growth in children and adolescents with HIV. J Dev Behav Pediatr. 2009;30(5):403-12. [pmid: 19827220]. Exclude: No included comparisons of outcomes, OVID-Medline.
Sleator EK, Von Neumann AW. Methylphenidate in the treatment of hyperkinetic children. Clin Pediatr. 1974;13(1):19-24. Exclude: No included comparisons of outcomes,.
Sleator EK, von Neumann A, Sprague RL. Hyperactive children: A continuous long-term placebo-controlled follow-up. JAMA. 1974;229(3):316-7. Exclude: Not an included population, OVID-PsycINFO. [pmid: 4600587].
Smith SW. Trifluoperazine in children and adolescents with marked behavior problems. Am J Psychiatry. 1965;122(6):702-3. [pmid: 5843663]. Exclude: Not an included population, OVID-Medline.
Smolkowski K, Biglan A, Barrera M, et al. Schools and homes in partnership (SHIP): long-term effects of a preventive intervention focused on social behavior and reading skill in early elementary school. Prev Sci. 2005;6(2):113-25. [pmid: 15889626]. Exclude: No included comparisons of outcomes, OVID-Medline.
Smyrnios KX, Kirkby RJ. Long-term comparison of brief versus unlimited psychodynamic treatments with children and their parents. J Consult Clin Psychol. 1993;61(6):1020-7. [pmid: 8113479]. Exclude: Not an included population, OVID-Medline.
Snyder AM, Maruff P, Pietrzak RH, et al. Effect of treatment with stimulant medication on nonverbal executive function and visuomotor speed in children with attention deficit/hyperactivity disorder (ADHD). Child Neuropsychol. 2008;14(3):211-26. [pmid: 17852127]. Exclude: No included comparisons of outcomes, OVID-Medline.
Snyder R, Turgay A, Aman M, et al. Effects of risperidone on conduct and disruptive behavior disorders in children with subaverage IQs. J Am Acad Child Adolesc Psychiatry. 2002;41(9):1026-36. [pmid: 12218423]. Exclude: No included comparisons of outcomes, OVID-Medline.
Solanto M, Newcorn J, Vail L, et al. Stimulant drug response in the predominantly inattentive and combined subtypes of attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(6):663-71. [pmid: 20035584]. Exclude: No included comparisons of outcomes, OVID-Medline.
Solanto MV, Conners CK. A dose-response and time-action analysis of autonomic and behavioral effects on methylphenidate in attention deficit disorder with hyperactivity. Psychophysiology. 1982;(6):658-67. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 7178383].
Solanto MV, Wender EH. Does methylphenidate constrict cognitive functioning. J Am Acad Child Adolesc Psychiatry. 1989;(6):897-902. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 2808260].
Solanto MV. The effects of reinforcement and response-cost on a delayed response task in children with attention deficit hyperactivity disorder: A research note. J Child Psychol Psychitr Allied Disc. 1990;(5):803-8. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Solanto MV. Behavioral effects of low-dose methylphenidate in childhood Attention Deficit Disorder: Implications for a mechanism of stimulant drug action. J Am Acad Child Psychiatry. 1986;25(1):96-101. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 3950273].
Solanto MV, Wender EH. “Does methylphenidate constrict cognitive functioning?”: Erratum. J Am Acad Child Adolesc Psychiatry. 1990;29(1):156. Exclude: Not an included population, OVID-PsycINFO.
Solomons G. The hyperactive child. J Iowa Med Soc. 1965;55(8):464-9. [pmid: 5837903]. Exclude: Not an included population, OVID-Medline.
Sonuga-Barke EJ, Coghill D, Markowitz JS, et al. Sex differences in the response of children with ADHD to once-daily formulations of methylphenidate. J Am Acad Child Adolesc Psychiatry. 2007;46(6):701-10. [pmid: 17513982]. Exclude: No included comparisons of outcomes, OVID-Medline.
Sonuga-Barke EJ, Van Lier P, Swanson JM, et al. Heterogeneity in the pharmacodynamics of two long-acting methylphenidate formulations for children with attention deficit/hyperactivity disorder. A growth mixture modelling analysis. Eur Child Adolesc Psychiatr. 2008;17(4):245-54. [pmid: 18071840]. Exclude: No included comparisons of outcomes, OVID-Medline.
Sonuga-Barke EJ, Coghill D, Wigal T, et al. Adverse reactions to methylphenidate treatment for attention-deficit/hyperactivity disorder: structure and associations with clinical characteristics and symptom control. J Child Adolesc Psychopharmacol. 2009;19(6):683-90. [pmid: 20035586]. Exclude: No included comparisons of outcomes, OVID-Medline.
Sonuga-Barke EJ, Coghill D, DeBacker M, et al. Measuring methylphenidate response in attention-deficit/hyperactvity disorder: how are laboratory classroom-based measures related to parent ratings. J Child Adolesc Psychopharmacol. 2009;19(6):691-8. [pmid: 20035587]. Exclude: No included comparisons of outcomes, OVID-Medline.
Spencer T, Biederman J, Kerman K, et al. Desipramine treatment of children with attention-deficit hyperactivity disorder and tic disorder or Tourette’s syndrome. J Am Acad Child Adolesc Psychiatry. 1993;32(2):354-60. [pmid: 8444765]. Exclude: No included intervention compared, OVID-Medline.
Spencer T, Biederman J, Wilens T, et al. Nortriptyline treatment of children with attention-deficit hyperactivity disorder and tic disorder or Tourette’s syndrome. J Am Acad Child Adolesc Psychiatry. 1993;32(1):205-10. [pmid: 8428873]. Exclude: No included intervention compared, OVID-Medline.
Spencer T, Biederman J, Coffey B, et al. A double-blind comparison of desipramine and placebo in children and adolescents with chronic tic disorder and comorbid attention-deficit/hyperactivity disorder. Arch Gen Psychiatry. 2002;59(7):649-56. [pmid: 12090818]. Exclude: No included comparisons of outcomes, OVID-Medline.
Spencer T, Heiligenstein JH, Biederman J, et al. Results from 2 proof-of-concept, placebo-controlled studies of atomoxetine in children with attention-deficit/hyperactivity disorder. J Clin Psychiatry. 2002;63(12):1140-7. [pmid: 12523874]. Exclude: No included comparisons of outcomes, OVID-Medline.
Spencer TJ, Biederman J, Harding M, et al. Growth deficits in ADHD children revisited: evidence for disorder-associated growth delays. J Am Acad Child Adolesc Psychiatry. 1996;35(11):1460-9. [pmid: 8936912]. Exclude: Longterm outcomes from pre 1997 publication, OVID-Medline.
Spencer TJ, Abikoff HB, Connor DF, et al. Efficacy and safety of mixed amphetamine salts extended release (adderall XR) in the management of oppositional defiant disorder with or without comorbid attention-deficit/hyperactivity disorder in school-aged children and adolescents: A 4-week, multicenter, randomized, double-blind, parallel-group, placebo-controlled, forced-dose-escalation study. Clin Ther. 2006;28(3):402-18. [pmid: 16750455]. Exclude: No included comparisons of outcomes, OVID-Medline.
Spencer TJ. Pharmacology of adult ADHD with stimulants. Cns Spectrums. 2007;12(4:Suppl 6):8-11. [pmid: 17715564]. Exclude: No included intervention compared, OVID-Medline.
Spencer TJ. Treatment of adult ADHD and comorbid depression. Cns Spectrums. 2008;13(5:Suppl 8):14-6. [pmid: 18567134]. Exclude: Not an included population, OVID-Medline.
Spencer TJ, Greenbaum M, Ginsberg LD, et al. Safety and effectiveness of coadministration of guanfacine extended release and psychostimulants in children and adolescents with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(5):501-10. [pmid: 19877974]. Exclude: No included comparisons of outcomes, OVID-Medline.
Spiga R, Pearson DA, Broitman M, et al. Effects of methylphenidate on cooperative responding in children with attention deficit-hyperactivity disorder. Exp Clin Psychopharmacol. 1996;4(4):451-8. Exclude: No included comparisons of outcomes, OVID-PsycInfo.
Spivak B, Vered Y, Yoran-Hegesh R, et al. The influence of three months of methylphenidate treatment on platelet-poor plasma biogenic amine levels in boys with attention deficit hyperactivity disorder. Hum Psychopharmacol Clin Exp. 2001;16(4):333-7. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Sprafkin J, Gadow KD. Double-blind versus open evaluations of stimulant drug response in children with attention-deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 1996;(4):215-28. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 9231315].
Sprague RL, Sleator EK. Methylphenidate in hyperkinetic children: differences in dose effects on learning and social behavior. Science. 1977;198(4323):1274-6. Exclude: No included comparisons of outcomes,. [pmid: 337493].
Srinivas NR, Hubbard JW, Quinn D, et al. Enantioselective pharmacokinetics and pharmacodynamics of dl-threo-methylphenidate in children with attention deficit hyperactivity disorder. Clin Pharmacol Ther. 1992;(5):561-8. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 1424430].
Staller JA. Psychopharmacologic treatment of aggressive preschoolers: a chart review. Prog Neuropsychopharmacol Biol Psychiatr. 2007;31(1):131-5. [pmid: 17007977]. Exclude: No included comparisons of outcomes, OVID-Medline.
Starr HL, Kemner J. Multicenter, randomized, open-label study of OROS methylphenidate versus atomoxetine: treatment outcomes in African-American children with ADHD. J Natl Med Assoc. 2005;97(10:Suppl):11S-6S. [pmid: 16350601]. Exclude: No included comparisons of outcomes, OVID-Medline.
Stein MA, Blondis TA, Schnitzler ER, et al. Methylphenidate dosing: twice daily versus three times daily. Pediatrics. 1996;98(4:Pt 1):748-56. [pmid: 8885956]. Exclude: No included comparisons of outcomes, OVID-Medline.
Stein MA, Waldman ID, Sarampote CS, et al. Dopamine transporter genotype and methylphenidate dose response in children with ADHD. Neuropsychopharmacology. 2005;30(7):1374-82. [pmid: 15827573]. Exclude: No included comparisons of outcomes, OVID-Medline.
Steingard R, Biederman J, Spencer T, et al. Comparison of clonidine response in the treatment of attention-deficit hyperactivity disorder with and without comorbid tic disorders. J Am Acad Child Adolesc Psychiatry. 1993;32(2):350-3. Exclude: Longterm outcomes from pre 1997 publication, OVID-EMBASE. [pmid: 8444764].
Steinhausen-ChHRomahn G, Gobel D. Computer analyzed EEG in methylphenidate-responsive hyperactive children. Neuropediatrics. 1984;(1):28-32. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Stemmler M, Beelmann A, Jaursch S, et al. Improving parenting practices in order to prevent child behavior problems: a study on parent behavior training as part of the EFFEKT program. Int J Hyg Environ Health. 2007;210(5):563-70. [pmid: 17869582]. Exclude: Not an included population, OVID-Medline.
Stephens RS, Pelham WE, Skinner R. State-dependent and main effects of methylphenidate and pemoline on paired-associate learning and spelling in hyperactive children. J Consult Clin Psychol. 1984;(1):104-13. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6699239].
Stern PR. Therapeutic education: a multidisciplinary approach to the needs of the disturbed child. Ment Hyg. 1965;49(4):608-12. [pmid: 5834809]. Exclude: Not an included population, OVID-Medline.
Stevens DA, Stover CE, Backus JT. The hyperkinetic child: effect of incentives on the speed of rapid tapping. J Consult Clin Psychol. 1970;34(1):56-9. Exclude: Not an included population,. [pmid: 5436466].
Stevens J, Harman JS, Kelleher KJ. Sociodemographic and economic comparisons of children prescribed longer-acting versus short-acting stimulant medications for attention deficit hyperactivity disorder. J Behav Health Serv Res. 2005;32(4):430-7. [pmid: 16215451]. Exclude: No included comparisons of outcomes, OVID-Medline.
Stewart M, Kelso J. A two-year-follow-up of boys with aggressive conduct disorder. Psychopathology. 1987;(5–6):296-304. Exclude: Not an included population, OVID-EMBASE. [pmid: 3454454].
Stewart MA, Pitts FN Jr, Craig AG, et al. The hyperactive child syndrome. Am J Orthopsychiatry. 1966;36(5):861-7. [pmid: 5971494]. Exclude: No included intervention compared, OVID-Medline.
Stewart MA, Adams CC, Meardon JK. Unsocialized aggressive boys: a follow-up study. J Clin Psychiatry. 1978;39(11):797-9. [pmid: 721783]. Exclude: No included comparisons of outcomes, OVID-Medline.
Stojanovski SD, Robinson RF, Baker SD, et al. Children and adolescent exposures to atomoxetine hydrochloride reported to a poison control center. Clin Toxicol. 2006;44(3):243-7. [pmid: 16749540]. Exclude: No included comparisons of outcomes, OVID-Medline.
Strauss LC. The efficacy of a homeopathic preparation in the management of attention deficit hyperactivity disorder. Biomed Ther. 2000;18(2):197-201. Exclude: Not an included population,.
Strayhorn JM, Weidman CS. Reduction of attention deficit and internalizing symptoms in preschoolers through parent-child interaction training. J Am Acad Child Adolesc Psychiatry. 1989;(6):888-96. Exclude: Not an included population, OVID-EMBASE. [pmid: 2808259].
Strayhorn JM, Weidman CS. Follow-up one year after parent-child interaction training: effects on behavior of preschool children. J Am Acad Child Adolesc Psychiatry. 1991;30(1):138-43. [pmid: 2005049]. Exclude: Not an included population, OVID-Medline.
Strous RD, Maayan R, Kaminsky M, et al. DHEA and DHEA-S levels in hospitalized adolescents with first-episode schizophrenia and conduct disorder: a comparison study. Eur Neuropsychopharmacol. 2009;19(7):499-503. [pmid: 19351578]. Exclude: No included intervention compared, OVID-Medline.
Sudarmadji SS, Meliala L, Aziz A. Improvement of cognitive function in attention deficit hyperactivity disorder (ADHD) treatment by methylphenidate (MPH) of elementary school students at Bantul District, Yogyakarta Special Regency. J Neurol Sci. 2009;285(Suppl 1):S236. Abstract-0. Exclude: No included comparisons of outcomes, OVID-CCTR.
Sullivan MA, O’Leary SG. Maintenance following reward and cost token programs. Behav Ther. 1990;(1):139-49. Exclude: Not an included population, OVID-EMBASE.
Sundell K, Hansson K, Lofholm CA, et al. The transportability of multisystemic therapy to Sweden: short-term results from a randomized trial of conduct-disordered youths. J Fam Psychol. 2008;22(4):550-60. [pmid: 18729669]. Exclude: No included comparisons of outcomes, OVID-Medline.
Sunohara GA, Voros JG, Malone MA, et al. Effects of methylphnidate in children with attention deficit hyperactivity disorder: A comparison of event-related potentials between medication responders and non-responders. Int J Psychophysiol. 1997;27(1):9-14. Exclude: No included comparisons of outcomes,. [pmid: 9161888].
Sunohara GA, Malone MA, Rovet J, et al. Effect of methylphenidate on attention in children with attention deficit hyperactivity disorder (ADHD): ERP evidence. Neuropsychopharmacology. 1999;21(2):218-28. [pmid: 10432470]. Exclude: No included comparisons of outcomes, OVID-Medline.
Surwillo WW. Changes in the electroencephalogram accompanying the use of stimulant drugs (methylphenidate and dextroamphetamine) in hyperactive children. Biol Psychiatry. 1977;12(6):787-99. [pmid: 597528]. Exclude: No included comparisons of outcomes, OVID-Medline.
Sutcliffe PA, Bishop DV, Houghton S, et al. Effect of attentional state on frequency discrimination: a comparison of children with ADHD on and off medication. J Speech Lang Hear Res. 2006;49(5):1072-84. [pmid: 17077215]. Exclude: No included comparisons of outcomes, OVID-Medline.
Sutcliffe PA, Bishop DVM, Houghton S. Sensitivity of four subtests of the Test of Everyday Attention for Children (TEA-Ch) to stimulant medication in children with ADHD. Educ Psychol. 2006;26(3):325-37. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Svanborg P, Thernlund G, Gustafsson PA, et al. Efficacy and safety of atomoxetine as add-on to psychoeducation in the treatment of attention deficit/hyperactivity disorder: a randomized, double-blind, placebo-controlled study in stimulant-naive Swedish children and adolescents. Eur Child Adolesc Psychiatr. 2009;18(4):240-9. [pmid: 19156355]. Exclude: No included comparisons of outcomes, OVID-Medline.
Sverd J, Gadow KD, Paolicelli LM. Methylphenidate treatment of attention-deficit hyperactivity disorder in boys with Tourette’s syndrome. J Am Acad Child Adolesc Psychiatry. 574. 28(4):580-9. [pmid: 2768152]. Exclude: No included comparisons of outcomes, OVID-Medline.
Swanson J, Gupta S, Guinta D, et al. Acute tolerance to methylphenidate in the treatment of attention deficit hyperactivity disorder in children. Clin Pharmacol Ther. 1999;66(3):295-305. [pmid: 10511066]. Exclude: No included comparisons of outcomes, OVID-Medline.
Swanson J, Gupta S, Lam A, et al. Development of a new once-a-day formulation of methylphenidate for the treatment of attention-deficit/hyperactivity disorder: proof-of-concept and proof-of-product studies. Arch Gen Psychiatry. 2003;60(2):204-11. [pmid: 12578439]. Exclude: No included comparisons of outcomes, OVID-Medline.
Swanson JM, Sandman CA, Deutsch C, et al. Methylphenidate hydrochloride given with or before breakfast: I. Behavioral, cognitive, and electrophysiologic effects. Pediatrics. 1983;72(1):49-55. [pmid: 6866591]. Exclude: No included comparisons of outcomes, OVID-Medline.
Swanson JM, Wigal S, Greenhill LL, et al. Analog classroom assessment of Adderall in children with ADHD. J Am Acad Child Adolesc Psychiatry. 1998;37(5):519-26. [pmid: 9585654]. Exclude: No included comparisons of outcomes, OVID-Medline.
Swanson JM, Gupta S, Williams L, et al. Efficacy of a new pattern of delivery of methylphenidate for the treatment of ADHD: effects on activity level in the classroom and on the playground. J Am Acad Child Adolesc Psychiatry. 2002;41(11):1306-14. [pmid: 12410072]. Exclude: No included comparisons of outcomes, OVID-Medline.
Swanson JM, Wigal SB, Wigal T, et al. A comparison of once-daily extended-release methylphenidate formulations in children with attention-deficit/hyperactivity disorder in the laboratory school (the Comacs Study). Pediatrics. 2004;113(3:Pt 1):t-16. [pmid: 14993578]. Exclude: No included comparisons of outcomes, OVID-Medline.
Swanson JM, Kinsbourne M. Stimulant-related state-dependent learning in hyperactive children. Science. 1976;192(4246):1354-7. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 1273596].
Swartwood MO, Swartwood JN, Farrell J. Stimulant treatment of ADHD: Effects on creativity and flexibility in problem solving. Creativ Res J. 2003;15(4):417-9. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Sykes DH, Douglas VI, Weiss G, et al. Attention in hyperactive children and the effect of methylphenidate (ritalin). J Child Psychol Psychitr Allied Disc. 1971;12(2):129-39. [pmid: 4935554]. Exclude: No included comparisons of outcomes, OVID-Medline.
Sykes DH, Douglas VI, Morgenstern G. The effect of methylphenidate (ritalin) on sustained attention in hyperactive children. Psychopharmacologia. 1972;25(3):262-74. Exclude: No included comparisons of outcomes,. [pmid: 4557941].
Szobot CM, Ketzer C, Cunha RD, et al. The acute effect of methylphenidate on cerebral blood flow in boys with attention-deficit/hyperactivity disorder. Eur J Nucl Med Mol Imag. 2003;30(3):423-6. [pmid: 12634972]. Exclude: No included comparisons of outcomes, OVID-Medline.
Szobot CM, Rohde LA, Katz B, et al. A randomized crossover clinical study showing that methylphenidate-SODAS improves attention-deficit/hyperactivity disorder symptoms in adolescents with substance use disorder. Braz J Med Biol Res. 2008;41(3):250-7. [pmid: 18327433]. Exclude: No included comparisons of outcomes, OVID-Medline.
Szyrynski V. Psychotherapy with parents of maladjusted children. Can Psychiatr Assoc J. 1965;10(5):350-8. [pmid: 5829415]. Exclude: Not an included population, OVID-Medline.
Tamm L, Carlson CL. Task demands interact with the single and combined effects of medication and contingencies on children with ADHD. J Attention Disord. 2007;10(4):372-80. [pmid: 17449836]. Exclude: No included comparisons of outcomes, OVID-Medline.
Tannock R, Schachar RJ, Carr RP, et al. Dose-response effects of methylphenidate on academic performance and overt behavior in hyperactive children. Pediatrics. 1989;(4):648-57. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 2780127].
Tannock R, Schachar R. Methylphenidate and cognitive perseveration in hyperactive children. J Child Psychol Psychitr Allied Disc. 1992;33(7):1217-28. [pmid: 1400703]. Exclude: No included comparisons of outcomes, OVID-Medline.
Tannock R, Ickowicz A, Schachar R. Differential effects of methylphenidate on working memory in ADHD children with and without comorbid anxiety. J Am Acad Child Adolesc Psychiatry. 1995;34(7):886-96. [pmid: 7649959]. Exclude: No included comparisons of outcomes, OVID-Medline.
Tannock R, Martinussen R, Frijters J. Naming speed performance and stimulant effects indicate effortful, semantic processing deficits in attention-deficit/hyperactivity disorder. J Abnorm Child Psychol. 2000;28(3):237-52. [pmid: 10885682]. Exclude: No included comparisons of outcomes, OVID-Medline.
Taylor E, Schachar R, Thorley G. Which boys respond to stimulant medication? A controlled trial of methylphenidate in boys with disruptive behavior. Psychol Med. 1987;(1):121-43. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3554290].
Teicher MH, Polcari A, Anderson CM, et al. Rate dependency revisited: understanding the effects of methylphenidate in children with attention deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 2003;13(1):41-51. [pmid: 12804125]. Exclude: No included comparisons of outcomes, OVID-Medline.
Teicher MH, Polcari A, Foley M, et al. Methylphenidate blood levels and therapeutic response in children with attention-deficit hyperactivity disorder: I. Effects of different dosing regimens. J Child Adolesc Psychopharmacol. 2006;16(4):416-31. [pmid: 16958567]. Exclude: No included comparisons of outcomes, OVID-Medline.
Tellechea N, Guardiola A, Barros HT, et al. Efficacy of imipramine in children with attention deficit hyperactivity disorder. Int Pediatr. 1991;6(4):343-6. Exclude: No included comparisons of outcomes,.
Thiruchelvam D, Charach A, Schachar RJ. Moderators and mediators of long-term adherence to stimulant treatment in children with ADHD. J Am Acad Child Adolesc Psychiatry. 2001;40(8):922-8. [pmid: 11501692]. Exclude: No included comparisons of outcomes, OVID-Medline.
Thompson AE, Nazir SA, Abbas MJ, et al. Switching from immediate- to sustained-release psychostimulants in routine treatment of children with attention-deficit hyperactivity disorder. Psychiatr Bull. 2006;(7):247-50. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Thompson JN, Varley CK, McClellan J, et al. Second opinions improve ADHD prescribing in a medicaid-insured community population. J Am Acad Child Adolesc Psychiatry. 2009;48(7):740-8. [pmid: 19465882]. Exclude: No included comparisons of outcomes, OVID-Medline.
Thompson MJJ, Laver-Bradbury C, Ayres M, et al. A small-scale randomized controlled trial of the revised new forest parenting programme for preschoolers with attention deficit hyperactivity disorder. Eur Child Adolesc Psychiatr. 2009;18(10):605-16. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Thomson JB, Varley CK. Prediction of stimulant response in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 1998;8(2):125-32. [pmid: 9730078]. Exclude: No included comparisons of outcomes, OVID-Medline.
Thorell LB. The Community Parent Education Program (COPE): treatment effects in a clinical and a community-based sample. Clin Child Psychol Psychiatr. 2009;14(3):373-87. [pmid: 19515754]. Exclude: No included comparisons of outcomes, OVID-Medline.
Thurston CM, Sobol MP, Swanson J, et al. Effects of methylphenidate (Ritalin) on selective attention in hyperactive children. J Abnorm Child Psychol. 1979;7(4):471-81. Exclude: No included comparisons of outcomes,. [pmid: 521570].
Tillery KL, Katz J, Keller WD. Effects of methylphenidate (Ritalin) on auditory performance in children with attention and auditory processing disorders. J Speech Lang Hear Res. 2000;43(4):893-901. [pmid: 11386476]. Exclude: No included comparisons of outcomes, OVID-Medline.
Timmons-Mitchell J. Containing aggressive acting out in abused children. Child Welfare. 1986;65(5):459-68. [pmid: 3757592]. Exclude: Not an included population, OVID-Medline.
Tirosh E, Sadeh A, Munvez R, et al. Effects of methylphenidate on sleep in children with attention-deficient hyperactivity disorder. An activity monitor study. Am J Dis Child. 1993;147(12):1313-5. Exclude: No included comparisons of outcomes,. [pmid: 8249952].
Tirosh E, Elhasid R, Kamah SC, et al. Predictive value of placebo methylphenidate. Pediatr Neurol. 1993;9(2):131-3. Exclude: No included comparisons of outcomes,. [pmid: 8499043].
Tjon Pian, Gi CV, Broeren JPA, Starreveld JS, et al. Melatonin for treatment of sleeping disorders in children with attention deficit/hyperactivity disorder: A preliminary open label study. Eur J Pediatr. 2003;(7–8):554-5. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 12783318].
Toren P, Silbergeld A, Eldar S, et al. Lack of effect of methylphenidate on serum growth hormone (GH), GH-binding protein, and insulin-like growth factor I. Clin Neuropharmacol. 1997;20(3):264-9. [pmid: 9197950]. Exclude: No included comparisons of outcomes, OVID-Medline.
Torrioli MG, Vernacotola S, Peruzzi L, et al. A double-blind, parallel, multicenter comparison of L-acetylcarnitine with placebo on the attention deficit hyperactivity disorder in fragile X syndrome boys. Am J Med Genet. 2008;(7):803-12. [pmid: 18286595]. Exclude: No included intervention compared, OVID-Medline.
Tourette’s Syndrome Study Group. Treatment of ADHD in children with tics: a randomized controlled trial. Neurology. 2002;58(4):527-36. [pmid: 11865128]. Exclude: No included comparisons of outcomes, OVID-Medline.
Tramontina S, Zeni CP, Ketzer CR, et al. Aripiprazole in children and adolescents with bipolar disorder comorbid with attention-deficit/hyperactivity disorder: a pilot randomized clinical trial. J Clin Psychiatry. 2009;70(5):756-64. [pmid: 19389329]. Exclude: Not an included population, OVID-Medline.
Tran KD, Nguyen CD, Weedon J, et al. Child behavior and quality of life in pediatric obstructive sleep apnea. Arch Otolaryngol Head Neck Surg. 2005;131(1):52-7. [pmid: 15655186]. Exclude: Not an included population, OVID-Medline.
Trebaticka J, Kopasova S, Hradecna Z, et al. Treatment of ADHD with French maritime pine bark extract, Pycnogenol. Eur Child Adolesc Psychiatr. 2006;15(6):329-35. [pmid: 16699814]. Exclude: No included comparisons of outcomes, OVID-Medline.
Tremblay RE, McCord J, Boileau H, et al. Can disruptive boys be helped to become competent. Psychiatry. 1991;54(2):148-61. Exclude: No included comparisons of outcomes,. [pmid: 1852848].
Tremblay RE, Pagani-Kurtz L, Masse LC, et al. A bimodal preventive intervention for disruptive kindergarten boys: its impact through mid-adolescence. J Consult Clin Psychol. 1995;63(4):560-8. [pmid: 7673533]. Exclude: Not an included population, OVID-Medline.
Tucha O, Prell S, Mecklinger L, et al. Effects of methylphenidate on multiple components of attention in children with attention deficit hyperactivity disorder. Psychopharmacol. 2006;185(3):315-26. [pmid: 16521033]. Exclude: No included comparisons of outcomes, OVID-Medline.
Tucha O, Mecklinger L, Laufkotter R, et al. Methylphenidate-induced improvements of various measures of attention in adults with attention deficit hyperactivity disorder. J Neural Transm. 2006;113(10):1575-92. [pmid: 16897610]. Exclude: No included comparisons of outcomes, OVID-Medline.
Tucker JD, Suter W, Petibone DM, et al. Cytogenetic assessment of methylphenidate treatment in pediatric patients treated for attention deficit hyperactivity disorder. Mutat Res. 2009;677(1–2):53-8. [pmid: 19465145]. Exclude: No included comparisons of outcomes, OVID-Medline.
Turgay A, Binder C, Snyder R, et al. Long-term safety and efficacy of risperidone for the treatment of disruptive behavior disorders in children with subaverage IQs. Pediatrics. 2002;110(3):e34. [pmid: 12205284]. Exclude: No included intervention compared, OVID-Medline.
Tutty S, Gephart H, Wurzbacher K. Enhancing behavioral and social skill functioning in children newly diagnosed with attention-deficit hyperactivity disorder in a pediatric setting. J Dev Behav Pediatr. 2003;24(1):51-7. [pmid: 12584485]. Exclude: No included comparisons of outcomes, OVID-Medline.
Tymms P, Merrell C. The impact of screening and advice on inattentive, hyperactive and impulsive children. Eur J Spec Needs Educ. 2006;(3):321-37. Exclude: No included intervention compared, OVID-EMBASE.
Ullmann RK, Sleator EK. Responders, nonresponders, and placebo responders among chilren with attention deficit disorder. Importance of a blinded placebo evaluation. Clin Pediatr. 1986;(12):594-9. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Van Brunt DL, Johnston JA, Ye W, et al. Predictors of selecting atomoxetine therapy for children with attention-deficit-hyperactivity disorder. Pharmacother. 2005;25(11):1541-9. [pmid: 16232017]. Exclude: Not an included population, OVID-Medline.
van de Wiel NM, Matthys W, Cohen-Kettenis PT, et al. The effectiveness of an experimental treatment when compared to care as usual depends on the type of care as usual. Behav Modif. 2007;31(3):298-312. [pmid: 17438344]. Exclude: No included comparisons of outcomes, OVID-Medline.
van den Hoofdakker BJ, van dV, Sytema S, et al. Effectiveness of behavioral parent behavior training for children with ADHD in routine clinical practice: a randomized controlled study. J Am Acad Child Adolesc Psychiatry. 2007;46(10):1263-71. [pmid: 17885567]. Exclude: No included comparisons of outcomes, OVID-Medline.
van den Hoofdakker BJ, Nauta MH, van der Veen-Mulders L, et al. Behavioral parent behavior training as an adjunct to routine care in children with attention-deficit/hyperactivity disorder: Moderators of treatment response. J Pediatr Psychol. 2010;35(3):317-29. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 19633060].
van der Meere JJ, Shalev RS, Borger N, et al. Methylphenidate, interstimulus interval, and reaction time performance of children with attention deficit/hyperactivity disorder: A pilot study. Child Neuropsychol. 2009;15(6):554-66. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 19296298].
van der Meere J, Shalev R, Borger N, et al. Sustained attention, activation and MPH in ADHD: A research note. J Child Psychol Psychiatr. 1995;36(4):697-703. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
van der Meulen EM, Bakker SC, Pauls DL, et al. High sibling correlation on methylphenidate response but no association with DAT1-10R homozygosity in Dutch sibpairs with ADHD. J Child Psychol Psychitr Allied Disc. 2005;46(10):1074-80. [pmid: 16178931]. Exclude: Not an included population, OVID-Medline.
Van Oudheusden LJ, Scholte HR. Efficacy of carnitine in the treatment of children with attention-deficit hyperactivity disorder. Prostaglandins Leukotrienes & Essential Fatty Acids. 2002;67(1):33-8. [pmid: 12213433]. Exclude: No included comparisons of outcomes, OVID-Medline.
van Zeijl J, Mesman J, van IJzendoorn MH, et al. Attachment-based intervention for enhancing sensitive discipline in mothers of 1- to 3-year-old children at risk for externalizing behavior problems: a randomized controlled trial. J Consult Clin Psychol. 2006;74(6):994-1005. [pmid: 17154730]. Exclude: Not an included population, OVID-Medline.
Vance AL, Luk ES, Costin J, et al. Attention deficit hyperactivity disorder: anxiety phenomena in children treated with psychostimulant medication for 6 months or more. Aust N Z J Psychiatry. 1999;33(3):399-406. [pmid: 10442797]. Exclude: No included comparisons of outcomes, OVID-Medline.
Varley CK, Trupin EW. Double-blind assessment of stimulant medication for attention deficit disorder: A model for clinical application. Am J Orthopsychiatry. 1983;(3):542-7. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6349375].
Varley CK, Trupin EW. Double-blind administration of methylphenidate to mentally retarded children with attention deficit disorder: A preliminary study. Am J Ment Defic. 1982;86(6):560-6. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 7102728].
Verbaten MN, Overtoom CC, Koelega HS, et al. Methylphenidate influences on both early and late ERP waves of ADHD children in a continuous performance test. J Abnorm Child Psychol. 1994;22(5):561-78. [pmid: 7822629]. Exclude: No included comparisons of outcomes, OVID-Medline.
Verduyn C, Barrowclough C, Roberts J, et al. Maternal depression and child behavior problems. Randomised placebo-controlled trial of a cognitive-behavioral group intervention. Br J Psychiatry. 2003;183:342-8. [pmid: 14519613]. Exclude: Not an included population, OVID-Medline.
Vetro A, Szentistvanyi I, Pallag L, et al. Therapeutic experience with lithium in childhood aggressivity. Neuropsychobiology. 1985;14(3):121-7. [pmid: 3938528]. Exclude: Not an included population, OVID-Medline.
Visser M, Kunnen SE, van Geert PLC. The impact of context on the development of aggressive behavior in special elementary school children. Mind Brain Educ. 2010;4(1):34-43. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Vitiello B, Hill JL, Elia J, et al. P.r.n. medications in child psychiatric patients: a pilot placebo-controlled study. J Clin Psychiatry. 1991;52(12):499-501. [pmid: 1752851]. Exclude: No included comparisons of outcomes, OVID-Medline.
Vollmer TR, Marcus BA, Ringdahl JE, et al. Progressing from brief assessments to extended experimental analyses in the evaluation of aberrant behavior. J Appl Behav Anal. 1995;28(4):561-76. Exclude: Not an included population, OVID-PsycINFO. [pmid: 16795882].
von Knorring AL, Soderberg A, Austin L, et al. Massage decreases aggression in preschool children: a long-term study. Acta Paediatr. 2008;97(9):1265-9. [pmid: 18782279]. Exclude: No included intervention compared, OVID-Medline.
Vostanis P, Anderson L, Window S. Evaluation of a family support service: short-term outcome. Clin Child Psychol Psychiatr. 2006;11(4):513-28. [pmid: 17163221]. Exclude: No included comparisons of outcomes, OVID-Medline.
Vuijk P, van Lier PA, Huizink AC, et al. Prenatal smoking predicts non-responsiveness to an intervention targeting attention-deficit/hyperactivity symptoms in elementary schoolchildren. J Child Psychol Psychitr Allied Disc. 2006;47(9):891-901. [pmid: 16930383]. Exclude: No included comparisons of outcomes, OVID-Medline.
Vyborova L, Nahunek K, Drtilkova I, et al. A controlled study of lisurid in hyperactive children. Act Nerv Super. 1978;20(1):86-7. [pmid: 345719]. Exclude: No included comparisons of outcomes, OVID-Medline.
Vyborova L, Balastikova B, Drtilkova I, et al. Clonazepam and dithiaden in hyperkinetic children. Act Nerv Super. 1979;21(3):155-6. [pmid: 574703]. Exclude: No included comparisons of outcomes, OVID-Medline.
Vyborova L, Nahunek K, Drtilkova J. Amphetaminil and methylphenidate in hyperkinetic children: Analysis of therapeutic results and EEG changes. Act Nerv Super. 1985;(4):304-6. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Vyborova L, Nahunek K, Balastikova B, et al. Comparison of the short-term effect of eleven psychotropic drugs on the hyperkinetic syndrome in children. Act Nerv Super. 1986;(4):308-9. Exclude: Not an included population, OVID-EMBASE.
Vyborova L, Nahunek K, Balastikova B, et al. Changes in the pathology of the hyperkinetic syndrome in children following treatment with amphetaminil, methylphenidate and clorotepin. Act Nerv Super. 1987;29(3):245-6. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Vyborova L, Nahunek K, Drtilkova I, et al. Oxyprothepin and clorotepin compared in the hyperkinetic syndrome. Act Nerv Super. 1989;(1):45-6. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Wahler RG, Winkel GH, Peterson RF, et al. Mothers as behavior therapists for their own children. Behav Res Ther. 1965;3(2):113-24. [pmid: 5828566]. Exclude: No included comparisons of outcomes, OVID-Medline.
Wahler RG, Cartor PG, Fleischman J, et al. The impact of synthesis teaching and parent behavior training with mothers of conduct-disordered children. J Abnorm Child Psychol. 1993;21(4):425-40. Exclude: No included comparisons of outcomes, OVID-PsycInfo. [pmid: 8408988].
Waizer J, Hoffman SP, Polizos P, et al. Outpatient treatment of hyperactive school children with imipramine. Am J Psychiatry. 1974;131(5):587-91. Exclude: No included comparisons of outcomes,. [pmid: 4594559].
Walitza S, Werner B, Romanos M, et al. Does methylphenidate cause a cytogenetic effect in children with attention deficit hyperactivity disorder. Environ Health Perspect. 2007;115(6):936-40. [pmid: 17589603]. Exclude: No included comparisons of outcomes, OVID-Medline.
Walitza S, Kampf K, Artamonov N, et al. No elevated genomic damage in children and adolescents with attention deficit/hyperactivity disorder after methylphenidate therapy. Toxicol Lett. 2009;184(1):38-43. [pmid: 19015014]. Exclude: No included comparisons of outcomes, OVID-Medline.
Walker CJ, Clement PW. Treating inattentive, impulsive, hyperactive children with self-modeling and stress inoculation training. Child Fam Behav Ther. 1992;14(2):75-85. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Walker MK, Sprague RL, Sleator EK, et al. Effects of methylphenidate hydrochloride on the subjective reporting of mood in children with attention deficit disorder. Issues Ment Health Nurs. 1988;4(9):373-85. Exclude: No included comparisons of outcomes,. [pmid: 3229984].
Warakomska-Grzycka S. Studies of reactions of in- and outpatient treatment of children aged 1–5 years. Pol Med Sci Hist Bull. 1967;10(1):36-42. [pmid: 6038763]. Exclude: Not an included population, OVID-Medline.
Ward J. New radiopharmaceutical may settle ADHD treatment debate. Adv Nurse Pract. 2001;9(2):59. [pmid: 12416055]. Exclude: Not an included population, OVID-Medline.
Waring ME, Lapane KL. Overweight in children and adolescents in relation to attention-deficit/hyperactivity disorder: results from a national sample. Pediatrics. 2008;122(1):e1-e6. [pmid: 18595954]. Exclude: No included comparisons of outcomes, OVID-Medline.
Waschbusch DA, Pelham WE Jr, Massetti G. The Behavior Education Support and Treatment (BEST) school intervention program: pilot project data examining schoolwide, targeted-school, and targeted-home approaches. J Attention Disord. 2005;9(1):313-22. [pmid: 16371677]. Exclude: No included comparisons of outcomes, OVID-Medline.
Watter N, Dreifuss FE. Modification of hyperkinetic behavior by nortriptyline. Va Med Mon. 1973;100(2):123-6. [pmid: 4683948]. Exclude: No included comparisons of outcomes, OVID-Medline.
Waxmonsky J, Pelham WE, Gnagy E, et al. The efficacy and tolerability of methylphenidate and behavior modification in children with attention-deficit/hyperactivity disorder and severe mood dysregulation. J Child Adolesc Psychopharmacol. 2008;18(6):573-88. [pmid: 19108662]. Exclude: No included comparisons of outcomes, OVID-Medline.
Weaver CM, Shaw DS, Dishion TJ, et al. Parenting self-efficacy and problem behavior in children at high risk for early conduct problems: the mediating role of maternal depression. Infant Behav Dev. 2008;31(4):594-605. [pmid: 18789537]. Exclude: No included comparisons of outcomes, OVID-Medline.
Weber K. Methylphenidate: Rate-dependent drug effects in hyperactive boys. Psychopharmacol. 1985;85(2):231-5. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Weber KS, Frankenberger W, Heilman K. The effects of Ritalin on the academic achievement of children diagnosed with attention-deficit hyperactivity disorder. Dev Disabil Bull. 1992;20(2):49-68. Exclude: Not an included population, OVID-PsycINFO.
Webster-Stratton C. Randomized trial of two parent-training programs for families with conduct-disordered children. J Consult Clin Psychol. 1984;52(4):666-78. [pmid: 6470293]. Exclude: Not an included population, OVID-Medline.
Webster-Stratton C, Hollinsworth T, Kolpacoff M. The long-term effectiveness and clinical significance of three cost-effective training programs for families with conduct-problem children. J Consult Clin Psychol. 1989;57(4):550-3. Exclude: No included comparisons of outcomes,. [pmid: 2504794].
Webster-Stratton C. Enhancing the effectiveness of self-administered videotape parent behavior training for families with conduct-problem children. J Abnorm Child Psychol. 1990;18(5):479-92. [pmid: 2266221]. Exclude: No included comparisons of outcomes, OVID-Medline.
Webster-Stratton C, Hammond M. Treating children with early-onset conduct problems: a comparison of child and parent behavior training interventions. J Consult Clin Psychol. 1997;65(1):93-109. [pmid: 9103739]. Exclude: Not an included population, OVID-Medline.
Webster-Stratton C, Reid MJ, Hammond M. Preventing conduct problems, promoting social competence: a parent and teacher training partnership in head start. J Clin Child Psychol. 2001;30(3):283-302. [pmid: 11501247]. Exclude: Not an included population, OVID-Medline.
Webster-Stratton C, Reid J, Hammond M. Social skills and problem-solving training for children with early-onset conduct problems: who benefits. J Child Psychol Psychitr Allied Disc. 2001;42(7):943-52. [pmid: 11693589]. Exclude: Not an included population, OVID-Medline.
Webster-Stratton C, Reid MJ, Hammond M. Treating children with early-onset conduct problems: intervention outcomes for parent, child, and teacher training. J Clin Child Adolesc Psychol. 2004;33(1):105-24. [pmid: 15028546]. Exclude: No included comparisons of outcomes, OVID-Medline.
Weinblatt U, Omer H. Nonviolent resistance: a treatment for parents of children with acute behavior problems. J Marital Fam Ther. 2008;34(1):75-92. [pmid: 18199182]. Exclude: No included comparisons of outcomes, OVID-Medline.
Weingartner H, Rapoport JL, Buchsbaum MS. Cognitive processes in normal and hyperactive children and their response to amphetamine treatment. J Abnorm Psychol. 1980;(1):25-37. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 7365116].
Weiss G, Werry J, Minde K, et al. Studies on the hyperactive child. V. The effects of dextroamphetamine and chlorpromazine on behavior and intellectual functioning. J Child Psychol Psychiatr. 1968;9(3):145-56. Exclude: No included comparisons of outcomes,.
Weiss G, Minde K, Douglas V, et al. Comparison of the effects of chlorpromazine, dextroamphetamine and methylphenidate on the behavior and intellectual functioning of hyperactive children. Can Med Assoc J. 1971;104(1):20-5. Exclude: No included comparisons of outcomes,. [pmid: 5540117].
Weiss M, Wasdell M, Patin J. A post hoc analysis of d-threo-methylphenidate hydrochloride (focalin) versus d,l-threo-methylphenidate hydrochloride (ritalin). J Am Acad Child Adolesc Psychiatry. 2004;43(11):1415-21. [pmid: 15502601]. Exclude: No included comparisons of outcomes, OVID-Medline.
Weiss RE, Stein MA, Refetoff S. Behavioral effects of liothyronine (L-T3) in children with attention deficit hyperactivity disorder in the presence and absence of resistance to thyroid hormone. Thyroid. 1997;7(3):389-93. [pmid: 9226208]. Exclude: No included comparisons of outcomes, OVID-Medline.
Weithorn CJ, Kagen E. Training first graders of high-activity level to improve performance through verbal self-direction. J Learn Disabil. 1979;12(2):82-8. [pmid: 438641]. Exclude: No included comparisons of outcomes, OVID-Medline.
Weizman A, Weitz R, Szekely GA. Combination of neuroleptic and stimulant treatment in attention deficit disorder with hyperactivity. J Am Acad Child Psychiatry. 1984;(3):295-8. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 6145738].
Wells KC, Egan J. Social learning and systems family therapy for childhood oppositional disorder: comparative treatment outcome. Compr Psychiatry. 1988;29(2):138-46. [pmid: 3370964]. Exclude: No included comparisons of outcomes, OVID-Medline.
Wells P, Faragher B. In-patient treatment of 165 adolescents with emotional and conduct disorders: A study of outcome. Br J Psychiatry. 1993;162:345-52. Exclude: Not an included population, OVID-PsycINFO. [pmid: 8453429].
Wender PH, Reimherr FW, Wood D, et al. A controlled study of methylphenidate in the treatment of attention deficit disorder, residual type, in adults. Am J Psychiatry. 1985;142(5):547-52. Exclude: No included comparisons of outcomes,. [pmid: 3885760].
Werba BE, Eyberg SM, Boggs SR, et al. Predicting outcome in parent-child interaction therapy: success and attrition. Behav Modif. 2006;30(5):618-46. [pmid: 16894233]. Exclude: No included comparisons of outcomes, OVID-Medline.
Wernicke JF, Adler L, Spencer T, et al. Changes in symptoms and adverse events after discontinuation of atomoxetine in children and adults with attention deficit/hyperactivity disorder: a prospective, placebo-controlled assessment. J Clin Psychopharmacol. 2004;24(1):30-5. [pmid: 14709944]. Exclude: No included comparisons of outcomes, OVID-Medline.
Werry JS, Weiss G, Douglas V, et al. Studies on the hyperactive child. 3. The effect of chlorpromazine upon behavior and learning ability. J Am Acad Child Psychiatry. 1966;5(2):292-312. Exclude: No included comparisons of outcomes,. [pmid: 5324670].
Werry JS, Aman MG. Methylphenidate and haloperidol in children. Effects on attention, memory, and activity. Arch Gen Psychiatry. 1975;32(6):790-5. [pmid: 1093506]. Exclude: No included comparisons of outcomes, OVID-Medline.
Werry JS, Aman MG, Lampen E. Haloperidol and methylphenidate in hyperactive children. Acta Paedopsychiatr. 1976;42(1):26-40. [pmid: 775883]. Exclude: No included comparisons of outcomes, OVID-Medline.
Werry JS, Aman MG, Diamond E. Imipramine and methylphenidate in hyperactive children. J Child Psychol Psychitr Allied Disc. 1980;21(1):27-35. [pmid: 7358801]. Exclude: No included comparisons of outcomes, OVID-Medline.
Werry JS, Sprague RL. Methylphenidate in children: Effect of dosage. Aust N Z J Psychiatry. 1974;8(1):9-19. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 4606809].
Whalen CK, Henker B, Finck D. Medication effects in the classroom: three naturalistic indicators. J Abnorm Child Psychol. 1981;9(4):419-33. Exclude: No included comparisons of outcomes,. [pmid: 7328224].
Whalen CK, Henker B, Swanson JM, et al. Natural social behaviors in hyperactive children: Dose effects of methylphenidate. J Consult Clin Psychol. 1987;(2):187-93. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3571671].
Whalen CK, Henker B, Granger DA. Ratings of medication effects in hyperactive children: Viable or vulnerable. Behav Assess. 1989;(2):179-99. Exclude: Not able to retrieve full report, OVID-EMBASE.
Whalen CK, Henker B, Buhrmester D, et al. Does stimulant medication improve the peer status of hyperactive children. J Consult Clin Psychol. 1989;(4):545-9. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 2768616].
Whalen CK, Henker B, Granger DA. Social judgment processes in hyperactive boys: Effects of methylphenidate and comparisons with normal peers. J Abnorm Child Psychol. 1990;(3):297-316. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 2198308].
Whalen CK. Behavior observations of hyperactive children and methylphenidate (Ritalin) effects in systematically structured classroom environments: Now you see them, now you don’t. J Pediatr Psychol. 1978;3(4):177-87. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Whalen CK. Peer interaction in a structured communication task: Comparisons of normal and hyperactive boys and of methylphenidate (Ritalin) and placebo effects. Child Dev. 1979;50(2):388-401. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 487880].
Whalen CK, Henker B. Social impact of stimulant treatment for hyperactive children. J Learn Disabil. 1991;24(4):231-41. Exclude: No included comparisons of outcomes, OVID-PsycINFO. [pmid: 1875158].
White SR, Yadao CM. Characterization of methylphenidate exposures reported to a regional poison control center. Arch Pediatr Adolesc Med. 2000;154(12):1199-203. [pmid: 11115302]. Exclude: No included comparisons of outcomes, OVID-Medline.
Whitehead PL, Clark LD. Effect of lithium carbonate, placebo, and thioridazine on hyperactive children. Am J Psychiatry. 1970;127(6):824-5. [pmid: 5482878]. Exclude: No included comparisons of outcomes, OVID-Medline.
Whitehouse D, Shah U, Palmer FB. Comparison of sustained-release and standard methylphenidate in the treatment of minimal brain dysfunction. J Clin Psychiatry. 1980;(8):282-5. Exclude: Not an included population, OVID-EMBASE. [pmid: 7400107].
Whitmore EA, Mikulich SK, Ehlers KM, et al. One-year outcome of adolescent females referred for conduct disorder and substance abuse/dependence. Drug Alcohol Depend. 2000;59(2):131-41. [pmid: 10891626]. Exclude: Not an included population, OVID-Medline.
Whyte J, Hart T, Schuster K, et al. Effects of methylphenidate on attentional function after traumatic brain injury: A randomized, placebo-controlled trial. Am J P M R. 1997;(6):440-50. Exclude: Not an included population, OVID-EMBASE.
Wigal S, Swanson JM, Feifel D, et al. A double-blind, placebo-controlled trial of dexmethylphenidate hydrochloride and d,l-threo-methylphenidate hydrochloride in children with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2004;43(11):1406-14. [pmid: 15502600]. Exclude: No included comparisons of outcomes, OVID-Medline.
Wigal SB, Biederman J, Swanson JM, et al. Efficacy and safety of modafinil film-coated tablets in children and adolescents with or without prior stimulant treatment for attention-deficit/ hyperactivity disorder: Pooled analysis of 3 randomized, double-blind, placebo-controlled studies. Prim Care Comp J Clin Psychiatr. 2006;(6):352-60. Exclude: No included comparisons of outcomes, OVID-Embase.
Wigal SB, Wilens TE, Wolraich M, et al. Hematologic and blood biochemistry monitoring during methylphenidate treatment in children with attention-deficit/hyperactivity disorder: 2-year, open-label study results. Pediatrics. 2007;120(1):e120-e128. [pmid: 17548486]. Exclude: No included comparisons of outcomes, OVID-Medline.
Wilens TE, McDermott SP, Biederman J, et al. Cognitive therapy in the treatment of adults with ADHD: A systematic chart review of 26 cases. J Cognit Psychother. 1999;(3):215-26. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Wilens TE, Spencer TJ, Swanson JM, et al. Combining methylphenidate and clonidine: a clinically sound medication option. J Am Acad Child Adolesc Psychiatry. 1999;38(5):614-9. [pmid: 10230195]. Exclude: Not an included population, OVID-Medline.
Wilens TE, Gignac M, Swezey A, et al. Characteristics of adolescents and young adults with ADHD who divert or misuse their prescribed medications. J Am Acad Child Adolesc Psychiatry. 2006;45(4):408-14. [pmid: 16601645]. Exclude: No included intervention compared, OVID-Medline.
Williams JI, Cram DM, Tausig FT, et al. Relative effects of drugs and diet on hyperactive behaviors: an experimental study. Pediatrics. 1978;61(6):811-7. [pmid: 353680]. Exclude: No included comparisons of outcomes, OVID-Medline.
Williams PD, Elder JH, Griggs C. The effects of family training and support on child behavior and parent satisfaction. Arch Psychiatr Nurs. 1987;1(2):89-97. [pmid: 3646041]. Exclude: Not an included population, OVID-Medline.
Williams RA, And O. Evaluation of access to care and medical and behavioral outcomes in a school-based intervention program for attention-deficit hyperactivity disorder. J Sch Health. 1993;63(7):294-7. Exclude: No included comparisons of outcomes, ERIC Database. [pmid: 8246460].
Wilmshurst LA. Treatment programs for youth with emotional and behavioral disorders: an outcome study of two alternate approaches. Ment Health Serv Res. 2002;4(2):85-96. [pmid: 12090310]. Exclude: No included comparisons of outcomes, OVID-Medline.
Winsberg BG, Bialer I, Kupietz S, et al. Effects of imipramine and dextroamphetamine on behavior of neuropsychiatrically impaired children. Am J Psychiatry. 1972;128(11):1425-31. Exclude: No included comparisons of outcomes,. [pmid: 4553490].
Winsberg BG, Press M, Bialer I, et al. Dextroamphetamine and methylphenidate in the treatment of hyperactive-aggressive children. Pediatrics. 1974;53(2):236-41. [pmid: 4590730]. Exclude: No included comparisons of outcomes, OVID-Medline.
Winsberg BG, Kupietz SS, Sverg J, et al. Methylphenidate oral dose plasma concentrations and behavioral response in children. Psychopharmacol. 1982;76(4):329-32. [pmid: 6812106]. Exclude: No included comparisons of outcomes, OVID-Medline.
Winsberg BG, Maitinsky S, Richardson E, et al. Effects of methylphenidate on achievement in hyperactive children with reading disorders. Psychopharmacol Bull. 1988;(2):238-41. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3212155].
Winterstein AG, Gerhard T, Shuster J, et al. Utilization of pharmacologic treatment in youths with attention deficit/hyperactivity disorder in Medicaid database. Ann Pharmacother. 2008;42(1):24-31. [pmid: 18042808]. Exclude: No included comparisons of outcomes, OVID-Medline.
Witcher JW, Long A, Smith B, et al. Atomoxetine pharmacokinetics in children and adolescents with attention deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 2003;13(1):53-63. [pmid: 12804126]. Exclude: No included comparisons of outcomes, OVID-Medline.
Wodarski JS, Pedi SJ. The empirical evaluation of the effects of different group treatment strategies against a controlled treatment strategy on behavior exhibited by antisocial children, behaviors of the therapist, and two self-rating scales that measure antisocial behavior. J Clin Psychol. 1978;34(2):471-81. Exclude: Not an included population,. [pmid: 681526].
Wolpert A, Quintos A, White L, et al. Thiothixene and chlorprothixene in behavior disorders. Curr Ther Res Clin Exp. 1968;10(11):566-9. Exclude: No included comparisons of outcomes,. [pmid: 4973973].
Wolraich M, Milich R, Stumbo P, et al. Effects of sucrose ingestion on the behavior of hyperactive boys. J Pediatr. 1985;106(4):675-82. Exclude: No included intervention compared,. [pmid: 3981325].
Wolraich ML, Greenhill LL, Pelham W, et al. Randomized, controlled trial of oros methylphenidate once a day in children with attention-deficit/hyperactivity disorder. Pediatrics. 2001;108(4):883-92. [pmid: 11581440]. Exclude: No included comparisons of outcomes, OVID-Medline.
Wood DR, Reimherr FW, Wender PH, et al. Diagnosis and treatment of minimal brain dysfunction in adults: a preliminary report. Arch Gen Psychiatry. 1976;33(12):1453-60. Exclude: No included comparisons of outcomes,. [pmid: 793563].
Wood DR, Reimherr FW, Wender PH. Treatment of attention deficit disorder with DL-phenylalanine. Psychiatry Res. 1985;16(1):21-6. Exclude: No included comparisons of outcomes,. [pmid: 3903813].
Wooltorton E. Medications for attention deficit hyperactivity disorder: cardiovascular concerns. Can Med Assoc J. 2006;175(1):29. [pmid: 16772535]. Exclude: No included intervention compared, OVID-Medline.
Wright LS, McKenzie CD. A talking group therapy for hyperactive 11 year old boys. Devereux School Forum. 1973;8(1):1-24. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Wright NA. Social skills training for conduct-disordered boys in residential treatment: A promising approach. Residential Treatment for Children & Youth. 1995;12(4):15-28. Exclude: Not an included population, OVID-PsycINFO.
Yaman A, Mesman J, van IJzendoorn MH, et al. Parenting and toddler aggression in second-generation immigrant families: The moderating role of child temperament. J Fam Psychol. 2010;24(2):208-11. Exclude: Not an included population, OVID-PsycINFO. [pmid: 20438196].
Yamashita Y, Mukasa A, Honda Y, et al. Short-term effect of American summer treatment program for Japanese children with attention deficit hyperactivity disorder. Brain Dev. 2010;32(2):115-22. [pmid: 19150587]. Exclude: No included comparisons of outcomes, OVID-Medline.
Yang P, Hsu HY, Chiou SS, et al. Health-related quality of life in methylphenidate-treated children with attention-deficit-hyperactivity disorder: results from a Taiwanese sample. Aust N Z J Psychiatry. 2007;41(12):998-1004. [pmid: 17999272]. Exclude: No included comparisons of outcomes, OVID-Medline.
Yates A, Gray F, Beutler LE, et al. Effect of negative air ionization on hyperactive and autistic children. Am J Phys Med. 1987;66(5):264-8. Exclude: No included comparisons of outcomes,. [pmid: 3434628].
Yepes LE, Balka EB, Winsberg BG, et al. Amitriptyline and methylphenidate treatment of behaviorally disordered children. J Child Psychol Psychiatr. 1977;18(1):39-52. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Zaghlawan HY, Ostrosky MM, Al Khateeb JM. Decreasing the inattentive behavior of Jordanian children: A group experiment. Educ Treat Child. 2007;30(3):49-64. Exclude: No included comparisons of outcomes,.
Zahn TP, Rapoport JL, Thompson CL. Autonomic and behavioral effects of dextroamphetamine and placebo in normal and hyperactive prepubertal boys. J Abnorm Child Psychol. 1980;8(2):145-60. Exclude: No included comparisons of outcomes,. [pmid: 6995513].
Zametkin AJ, Brown GL, Karoum F. Urinary phenethylamine response to d-amphetamine in 12 boys with attention deficit disorder. Am J Psychiatry. 1984;141(9):1055-8. Exclude: No included comparisons of outcomes,. [pmid: 6380319].
Zametkin AJ, Reeves JC, Webster L, et al. Promethazine treatment of children with Attention Deficit Disorder with Hyperactivity--ineffective and unpleasant. J Am Acad Child Psychiatry. 1986;25(6):854-6. [pmid: 3540075]. Exclude: No included comparisons of outcomes, OVID-Medline.
Zametkin AJ, Karoum F, Rapoport JL. Treatment of hyperactive children with D-phenylalanine. Am J Psychiatry. 1987;(6):792-4. Exclude: No included comparisons of outcomes, OVID-EMBASE. [pmid: 3296793].
Zeiner P. Do the beneficial effects of extended methylphenidate treatment in boys with attention-deficit hyperactivity disorder dissipate rapidly during placebo treatment. Nord J Psychiatr. 1999;(1):55-60. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Zeiner P, Bryhn G, Bjercke C, et al. Response to methylphenidate in boys with attention-deficit hyperactivity disorder. Acta Paediatr. 1999;88(3):298-303. [pmid: 10229041]. Exclude: No included comparisons of outcomes, OVID-Medline.
Zeiner P. Body growth and cardiovascular function after extended treatment (1.75 years) with methylphenidate in boys with attention-deficit hyperactivity disorder. J Child Adolesc Psychopharmacol. 1995;5(2):129-38. Exclude: Longterm outcomes from pre 1997 publication, OVID-PsycINFO.
Zelniker T, Oppenheimer L. Modification of information processing of impulsive children. Child Dev. 1973;44(3):445-50. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Zentall SS, Meyer MJ. Self-regulation of stimulation for ADD-H children during reading and vigilance task performance. J Abnorm Child Psychol. 1988;(4):519-36. Exclude: No included comparisons of outcomes, OVID-EMBASE.
Zentall SS. Effects of color stimulation on performance and activity of hyperactive and nonhyperactive children. J Educ Psychol. 1986;78(2):159-65. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Zepf FD, Holtmann M, Stadler C, et al. Diminished central nervous 5-HT neurotransmission and mood self-ratings in children and adolescents with ADHD: no clear effect of rapid tryptophan depletion. Hum Psychopharmacol. 2009;24(2):87-94. [pmid: 19226535]. Exclude: No included comparisons of outcomes, OVID-Medline.
Zepf FD, Holtmann M, Stadler C, et al. Reduced serotonergic functioning changes heart rate in ADHD. J Neural Transm. 2009;116(1):105-8. [pmid: 19018449]. Exclude: No included comparisons of outcomes, OVID-Medline.
Zuvekas SH, Vitiello B, Norquist GS. Recent trends in stimulant medication use among U.S. children. Am J Psychiatry. 2006;163(4):579-85. [pmid: 16585430]. Exclude: No included intervention compared, OVID-Medline.
Zwaanswijk M, Verhaak PF, van der EJ, et al. Change in children’s emotional and behavioral problems over a one-year period: Associations with parental problem recognition and service use. Eur Child Adolesc Psychiatr. 2006;15(3):127-31. [pmid: 16416243]. Exclude: No included intervention compared, OVID-Medline.
Zwaigenbaum L, Dick P, Handley-Derry M, et al. “N of 1” trials of methylphenidate in two children with Williams syndrome and attention deficit hyperactivity disorder. J Dev Phys Disabil. 2006;18(1):45-58. Exclude: No included comparisons of outcomes, OVID-PsycINFO.
Zwart LM, Kallemeyn LM. Peer-based coaching for college students with ADHD and learning disabilities. J Postsecondary Educ Disabil. 2001;15(1):1-15. Exclude: No included comparisons of outcomes, ERIC Database.