# Forms

Level 1 Title and Abstract Screening Form

Level 2 Title and Abstract Screening Form

Level 3 Full Text Screening Form

Full Text Sorting Level

Quality Assessment Tool for Quantitative Studies

KQ3. ADHD Prevalence. Level 1 Title and Abstract Screening Form

KQ3. ADHD Prevalence. Level 2 Diagnostic or Treatment Prevalence?

KQ3. ADHD Prevalence. Level 3 Full Text

KQ3. ADHD Prevalence. Level 4 Citations Used in Report

Template Used To Determine Strength of Evidence