# Search Strategies

## ADHD Treatment Search Strategies

OVID-Medline

May 31 2010

1. “attention deficit and Disruptive Behavior Disorders”/ or attention deficit disorder with hyperactivity/ or Conduct Disorder/
2. minimal brain d?sfunction*.tw,sh.
3. (attention deficit* or adhd).ti.
4. addh.tw.
5. or/1–4
6. Hyperkinesis/
7. Impulsive Behavior/
8. Child Behavior Disorders/
9. aggression/ or agonistic behavior/
10. inattent*.tw.
11. Impulse Control Disorders/
12. (disruptive adj4 disorder?).tw.
13. or/6–12
14. limit 13 to (“newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)”)
15. exp *Mental Disorders/
16. (attention deficit* or adhd).tw.
17. hyperactiv*.tw.
18. inattent*.tw.
19. Impulsive Behavior/
20. or/16–19
21. 15 and 20
22. 5 or 21
23. limit 22 to yr = “1997-Current”
24. 14 or 23
25. Drug Therapy/ae, co, ct, mo [Adverse Effects, Complications, Contraindications, Mortality]
26. (side effect? or adverse or harm?).tw.
27. atomoxetine.tw.
28. guanfacine.tw.
29. Lisdexamfetamine.tw.
30. Vyvanse.tw.
31. exp Central Nervous System Stimulants/ae, ct, po, to [Adverse Effects, Contraindications, Poisoning, Toxicity]
32. ritalin.tw.
33. or/25–32
34. (attention deficit* or adhd).tw.
35. 33 and 34
36. 24 or 35
37. (comment or editorial or letter).pt.
38. 36 not 37
39. review.pt,sh.
40. 38 and 39
41. meta-analysis.pt,ti,ab,sh.
42. (meta anal$ or metaanal$).ti,ab,sh.
43. ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ti.
44. ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ab.
45. ((pool$ or combined or combining) adj (data or trials or studies or results)).ti,ab.
46. (medline or embase or cochrane).ti,ab.
47. or/44–46
48. review.pt,sh.
49. 47 and 48
50. 41 or 49 or 43 or 42
51. 38 and 50
52. 40 not 51
53. 38 not 52
54. limit 53 to humans
55. limit 54 to english language

OVID-Embase

May 31 2010

1. attention deficit disorder/
2. minimal brain d?sfunction*.tw,sh.
3. (attention deficit* or adhd).ti.
4. addh.tw.
5. or/1–4
6. hyperactivity/
7. disruptive behavior/
8. Conduct Disorder/
9. oppositional defiant disorder/
10. hyperkinesia/
11. aggression/ or aggressiveness/ or anger/ or bullying/ or hostility/
12. impulsiveness/
13. inattention.tw.
14. (disruptive adj4 disorder?).tw.
15. or/6–14
16. limit 15 to (infant or child or preschool child <1 to 6 years>)
17. exp *behavior disorder/
18. hyperactiv*.tw.
19. hyperactivity/
20. inattent*.tw.
21. (attention deficit* or adhd).tw.
22. hyperkine*.tw.
23. hyperkinesia/
24. impulsiveness/
25. or/18–24
26. 17 and 25
27. 5 or 26
28. limit 27 to yr = “1997-Current”
29. 16 or 28
30. limit 29 to human
31. limit 30 to (book or book series or conference paper or editorial or letter or note)
32. 30 not 31
33. review.pt,sh.
34. 32 and 33
35. meta analysis/
36. meta-analysis.ti,ab.
37. (meta anal$ or metaanal$).ti,ab.
38. ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ti.
39. ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ab.
40. ((pool$ or combined or combining) adj (data or trials or studies or results)).ti,ab.
41. (medline or embase or cochrane).ti,ab.
42. or/39–41
43. review.pt,sh.
44. 42 and 43
45. or/35–38
46. 45 or 44
47. 32 and 46
48. 34 not 47
49. 32 not 48
50. limit 49 to english language

OVID-PsycINFO

May 31 2010

1. attention deficit disorder/ or attention deficit disorder with hyperactivity/
2. minimal brain d?sfunction*.tw,sh.
3. (attention deficit* or adhd).ti.
4. addh.tw.
5. or/1–4
6. Conduct Disorder/
7. aggressive behavior/
8. impulsiveness/
9. exp impulse control disorders/
10. oppositional defiant disorder/
11. distractability/
12. attention span/
13. hyperkinesis/
14. inattent*.tw.
15. (disruptive adj4 disorder?).tw.
16. or/6–15
17. limit 16 to childhood
18. exp *behavior problems/ or *behavior disorders/
19. (attention deficit* or adhd).tw.
20. 18 and 19
21. exp “side effects (treatment)”/
22. (side effect? or adverse or harm?).tw.
23. or/21–22
24. 19 and 23
25. 5 or 20
26. limit 25 to yr = “1997-Current”
27. 17 or 24 or 26
28. limit 27 to human
29. limit 28 to english language
30. limit 29 to (chapter or “column/opinion” or “comment/reply” or editorial or letter or review-book)
31. 29 not 30

OVID-Cochrane Central

May 31, 2010

1. “attention deficit and Disruptive Behavior Disorders”/ or attention deficit disorder with hyperactivity/ or Conduct Disorder/
2. minimal brain d?sfunction*.tw,sh.
3. (attention deficit* or adhd).ti.
4. addh.tw.
5. or/1–4
6. Hyperkinesis/
7. Impulsive Behavior/
8. Child Behavior Disorders/
9. aggression/ or agonistic behavior/
10. inattent*.tw.
11. Impulse Control Disorders/
12. (disruptive adj4 disorder?).tw.
13. or/6–12
14. limit 13 to (“newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)”) [Limit not valid; records were retained]
15. exp *Mental Disorders/
16. (attention deficit* or adhd).tw.
17. hyperactiv*.tw.
18. inattent*.tw.
19. Impulsive Behavior/
20. or/16–19
21. 15 and 20
22. 5 or 21 (1799)
23. limit 22 to yr= “1997-Current”
24. 14 or 23
25. Drug Therapy/ae, co, ct, mo [Adverse Effects, Complications, Contraindications, Mortality]
26. (side effect? or adverse or harm?).tw.
27. atomoxetine.tw.
28. guanfacine.tw.
29. Lisdexamfetamine.tw.
30. Vyvanse.tw.
31. exp Central Nervous System Stimulants/ae, ct, po, to [Adverse Effects, Contraindications, Poisoning, Toxicity]
32. ritalin.tw.
33. or/25–32
34. (attention deficit* or adhd).tw.
35. 33 and 34
36. 24 or 35

ERIC ADHD Search – May 31, 2009

((Thesaurus Descriptors: ”Attention Deficit Disorders”) or (Thesaurus Descriptors: ”Attention Deficit Hyperactivity Disorder”) or (Thesaurus Descriptors: ”Hyperactivity”) or (Keywords: ”attention deficit”) or (Keywords: ADHD) or (Keywords: inattention) and (Thesaurus Descriptors: ”Self Control”)) and (Publication Type: ”Journal Articles” OR Publication Type: ”ERIC Publications” OR Publication Type: ”Information Analyses” OR Publication Type: ”Numerical Quantitative Data” OR Publication Type: ”Reference Materials General” OR Publication Type: ”Reports Evaluative” OR Publication Type: ”Reports General” OR Publication Type: ”Reports Research” OR Publication Type: ”Translations”)

## ADHD Prevalence Search Strategies

OVID-Medline

March 25 2010

1. ((prescription or administrative or insurance or claims) adj3 (data or database? or claims)).tw.
2. “Databases, Factual”/
3. *Physician’s Practice Patterns/
4. Physician’s Practice Patterns/sn, td [Statistics & Numerical Data, Trends]
5. insurance claim reporting/ or “insurance claim review”/
6. Epidemiology/
7. Drug Utilization/sn, td [Statistics & Numerical Data, Trends]
8. off-label.tw.
9. “Off-Label Use”/st, sn [Standards, Statistics & Numerical Data]
10. *”Pharmacoepidemiology”/
11. Pharmacoepidemiology/st, sn, td [Standards, Statistics & Numerical Data, Trends]
12. “Drug Utilization Review”/
13. utilization.tw.
14. health surveys/ or population surveillance/ or health care surveys/
15. (trend? or pattern? or rate? or prevalence).ti.
16. ((national or regional or prescribing or prescripton or diagnos*) adj3 (trend? or rate? or pattern? or variation? or prevalence)).tw.
17. Drug Prescriptions/sn, td [Statistics & Numerical Data, Trends]
18. or/1–17
19. *Methylphenidate/tu [Therapeutic Use]
20. exp *Amphetamines/tu [Therapeutic Use]
21. exp *Central Nervous System Stimulants/tu [Therapeutic Use]
22. exp *Psychotropic Drugs/tu [Therapeutic Use]
23. *Attention Deficit Disorder with Hyperactivity/ep [Epidemiology]
24. exp *Antipsychotic Agents/tu [Therapeutic Use]
25. off-label.tw.
26. “Off-Label Use”/
27. *”Pharmacoepidemiology”/
28. Pharmacoepidemiology/st, sn, td [Standards, Statistics & Numerical Data, Trends]
29. *Drug Utilization/sn, td [Statistics & Numerical Data, Trends]
30. “Drug Utilization Review”/
31. or/19–30
32. limit 31 to (“all infant (birth to 23 months)” or “preschool child (2 to 5 years)”)
33. “attention deficit and Disruptive Behavior Disorders”/ or attention deficit disorder with hyperactivity/ or Conduct Disorder/
34. minimal brain d?sfunction*.tw,sh.
35. (attention deficit* or adhd).ti.
36. addh.tw.
37. or/33–36
38. Hyperkinesis/
39. Impulsive Behavior/
40. Child Behavior Disorders/
41. aggression/ or agonistic behavior/
42. inattent*.tw.
43. Impulse Control Disorders/
44. (disruptive adj4 disorder?).tw.
45. or/38–44
46. limit 45 to (“newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)”)
47. 37 or 46
48. 18 and 47
49. 32 or 48
50. exp *Attention Deficit Disorder with Hyperactivity/di, ep [Diagnosis, Epidemiology]
51. 49 or 50
52. limit 51 to english language
53. limit 52 to yr = “1980-Current”
54. limit 53 to (comment or congresses or editorial or letter or news)
55. 53 not 54

OVID-Embase

March 25 2010

1. *clinical practice/
2. ((prescription or administrative or insurance or claims) adj3 (data or database? or claims)).tw.
3. factual database/
4. health insurance/
5. pharmacoepidemiology/
6. exp *epidemiology/
7. *”drug use”/ or *drug preference/ or *”off label drug use”/ or *prescription/
8. off-label.tw.
9. health survey/
10. (trend? or pattern? or rate? or prevalence).ti.
11. ((national or regional or prescribing or prescripton or diagnos*) adj3 (trend? or rate? or pattern? or variation? or prevalence)).tw.
12. utilization.tw.
13. “billing and claims”/
14. *geographic distribution/
15. *drug utilization/
16. “utilization review”/
17. trend study/
18. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17
19. *methylphenidate/
20. methylphenidate/dt
21. exp *central nervous system agents/dt [Drug Therapy]
22. *attention deficit disorder/ep [Epidemiology]
23. *”drug use”/ or *drug preference/ or “off label drug use”/ or *prescription/
24. pharmacoepidemiology/
25. “utilization review”/
26. trend study/
27. or/19–26
28. limit 27 to preschool child <1 to 6 years>
29. attention deficit disorder/
30. minimal brain d?sfunction*.tw,sh.
31. (attention deficit* or adhd).ti.
32. addh.tw.
33. or/29–32
34. hyperactivity/
35. disruptive behavior/
36. Conduct Disorder/
37. oppositional defiant disorder/
38. hyperkinesia/
39. aggression/ or aggressiveness/ or anger/ or bullying/ or hostility/
40. impulsiveness/
41. inattention.tw.
42. (disruptive adj4 disorder?).tw.
43. or/34–42
44. limit 43 to (infant or child or preschool child <1 to 6 years>)
45. 33 or 44
46. 18 and 45
47. 28 or 46
48. *attention deficit disorder/ep, pe
49. 47 or 48
50. limit 49 to (human and english language)
51. limit 50 to yr = “1980-Current”
52. limit 51 to (book or book series or conference paper or editorial or letter or note or proceeding)
53. 51 not 52

OVID-PsycINFO

March 26 2010

1. *clinical practice/
2. ((prescription or administrative or insurance or claims) adj3 (data or database? or claims)).tw.
3. exp databases/
4. exp health insurance/
5. epidemiology/
6. “prescribing (drugs)”/
7. *drug therapy/
8. *drug usage/
9. off-label.tw.
10. exp questionnaires/ or exp surveys/
11. ((national or regional or prescribing or prescripton or diagnos*) adj3 (trend? or rate? or pattern? or variation? or prevalence)).tw.
12. utilization.tw.
13. utilization reviews/
14. *human sex differences/
15. *age differences/
16. *demographic characteristics/
17. (trend? or pattern? or rate? or prevalence).ti.
18. *health care utilization/
19. or/1–18
20. psychotropic.tw.
21. *methylphenidate/
22. exp *cns stimulating drugs/
23. exp *neuroleptic drugs/
24. “prescribing (drugs)”/
25. *drug therapy/
26. *drug usage/
27. off-label.tw.
28. or/20–27
29. limit 28 to (140 infancy or 160 preschool age )
30. attention deficit disorder/ or attention deficit disorder with hyperactivity/
31. minimal brain d?sfunction*.tw,sh.
32. (attention deficit* or adhd).ti.
33. addh.tw.
34. or/30–33
35. Conduct Disorder/
36. aggressive behavior/
37. impulsiveness/
38. exp impulse control disorders/
39. oppositional defiant disorder/
40. distractability/
41. attention span/
42. hyperkinesis/
43. inattent*.tw.
44. (disruptive adj4 disorder?).tw.
45. or/35–44
46. limit 45 to (140 infancy or 160 preschool age )
47. 34 or 46
48. 19 and 47
49. 29 or 48
50. limit 49 to english language
51. limit 50 to human
52. limit 51 to yr = “1980-Current”
53. limit 52 to (“0200 book” or “0240 authored book” or “0280 edited book” or “0300 encyclopedia” or “0400 dissertation abstract” or (chapter or “column/opinion” or “comment/reply” or dissertation or editorial or encyclopedia entry or letter or obituary or review-book or review-software & other))
54. 52 not 53