# Appendixes

Appendix A Search Strategies

Appendix B Forms

Appendix C Excluded Studies

Appendix D Strength of Evidence/Grading Tables