# Acknowledgments

The researchers at the Evidence-based Practice Center would like to acknowledge the following people for their contributions.

We are grateful to our Task Order Officer, Steven Fox, for his support and guidance. Members of the Technical Expert Panel were instrumental in the formation of the parameters and goals of this review.

We would also like to thank those who worked so conscientiously retrieving and screening citations, abstracting data, preparing figures, and editing the report: Julianna Beckett, Bryan Cheeseman, Roxanne Cheeseman, Alicia Freeborn, Connie Freeborn, Jeffrey Freeborn, Mary Gauld, Suzanne Johansen, Sara Kaffashian, Dorothy Kendry, Jinhui Ma, Leah Macdonald, Sandra McIsaac, Rachael Morris, Galatea Papageorgiou, Maureen Rice, Robert Stevens, and Ian White. Our thanks to Drs. Michael Boyle and Harry Shannon and Ms. Nancy Santesso for providing assistance along the way.