# Abbreviations

Abbreviation: Definition
%ile: percentile
ADD: Attention Deficit Disorder
ADHD: Attention Deficit Hyperactivity Disorder
ADHD-C: Attention Deficit Hyperactivity Disorder Combined type
ADHD-HI: Attention Deficit Hyperactivity Disorder-Hyperactive Impulsive
ADHD-I: Attention Deficit Hyperactivity Disorder-Inattentive
AE: Adverse Events
AHRQ: Agency for Healthcare Research and Quality
amph: amphetamine
ARCOS: Automation of Reports and Consolidated Orders System
ATX: atomoxetine
B.C.: British Columbia
BELLA: Mental Health Module (German)
BP: Blood Pressure
bpm: Beats per minute
C p/t: Conners parent/teacher
CBCL: Child Behavior Checklist
CBM: Curriculum-based measurement
CC: Community Care
CD: Conduct Disorder
CER: Comparative Effectiveness Review
CGI-IS: Clinical Global Impressions-Impairment scale
CHP-C: Challenging Horizon Program and Consultation
CHQ: child health questionnaire
CI: Confidence interval
cm: centimeter
CP: classroom performance
CT: clinical trial
CVAs: Cerebrovascular Accidents
d/c’d: discontinued
DAWBA: Development and Well-Being Assessment
DBD: Disruptive Behavior Disorder
DEX: dextroamphetamine
diff: difference
DISC-IV: Diagnostic Interview Schedule for Children Version IV
DISC-IV-P: Diagnostic Interview Schedule for Children Version IV – Prevalence
DR: dose related
DSM: Diagnostic and Statistical Manual of Mental Disorders
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders 4^th^ edition
DSM-III-R: Diagnostic and Statistical Manual of Mental Disorders 3^rd^ edition - revision
DSM-IV-TR: Diagnostic and Statistical Manual of Mental Disorders 4^th^ edition – text revision
ECBI: Early Child Behavior Inventory
ECG: Electrocardiograph
ED: Emergency Department
EMBASE: Excerpta Medical Database
EPC: Evidence-based Practice Center
ERIC: Education Resources Information Center
f/u: followup
FBB-HKS/ADHS: German ADHD Rating Scale
FDA: Food & Drug Administration
freq: frequency
GP: General Practitioner
GPA: Grade Point Average
GPRD: General Practice Research Database
GRADE: The Grading of Recommendations Assessment, Development and Evaluation
GXR: Guanfacine extended release
H.R.: House of Representatives
ICD: International Classification of Diseases
IDAI: Intensive Data-based Academic Intervention
IQ: Intelligence Quotient
IR: immediate release
IYPP: Incredible Years Parenting Program
kg: kilogram
KiGGS: The German Health Interview and Examination Survey for Children and Adolescents
KQ: Key Question
K-SADS-E: Kiddie - Schedule for Affective Disorders and Schizophrenia - Expressive
levo: levoamphetamine
LT: long-term
MAS: Mixed Amphetamine Salts
MAS XR: mixed amphetamine salts extended release
MCI: Multi-component Intervention
MEPS: Medical Expenditure Panel Survey
mg: milligram
mmHg: Millimeters of Mercury
MPH: methylphenidate
MTA: Multimodal Treatment Study of Children with ADHD
NAMCS: National Ambulatory Medical Care Survey
NC: non-compliance
NCHS: National Survey of Child Health
NFPP: New Forest Parenting Program
NHANES: National Health and Nutrition Examination Survey
NHIS: National Health Interview Survey
NIMH: National Institute for Mental Health
NLSCY: National Longitudinal Study of Children and Youth
ODD: Oppositional Defiant Disorder
OLE: Open Label Extension
OROS MPH: Osmotic-controlled Release Oral delivery System methylphenidate
PATS: Preschool ADHD Treatment Study
PCIT: Parent-Child Interaction Therapy
PE: Parent Education
PICOT: population, intervention, comparison, treatment
PSOC: Parent Sense of Competency
PBT: Parent behavior training
Q: Question
QTc: Q T Interval
RCR: retrospective chart review
RCT: Randomized Controlled Trial
RR: Relative Risk
RS IV: Rating Scale version IV
SADS: The Schedule for Affective Disorders and Schizophrenia
SD: Standard Deviations
SDQ: Strengths and Difficulties Questionnaires
SE: Side Effect
SES: Socio-economic status
SET-PC: Supportive Expressive Therapy – Parent Child
SMD: Standardized Mean Difference
SNAP-IV: Swanson, Nolan and Pelham
SRS: Systematic Review Software
stim: stimulant
STP: summer treatment program
t.i.d.: ter in die (three times per day)
TDAI: Traditional Data-based Academic Intervention
TEP: Technical Expert Panel
TIAs: Transient Ischemic Attacks
TOO: Task Order Officer
Triple P: Positive Parenting of Preschoolers
U.K.: United Kingdom
U.S.A.: United States of American
VADPRS: Vanderbilt ADHD Diagnostic Parent Rating Scale
VARTRS: Vanderbilt ADHD Teacher Rating Scale
vs: versus
WA: Western Australia
yr: year