# Technical Expert Panel

Evelyn Attia, M.D.

Columbia University Medical Center

New York, NY

Tami Eide, Pharm.D., B.C.P.S., FASHP

Idaho Dept of Health & Welfare

Boise, ID

Carol Eisen, M.D.

County of Los Angeles Department of Mental Health

Los Angeles, CA

David Sultzer, M.D.

Greater Los Angeles Healthcare System

Los Angeles, CA

Bruce Kagan, M.D., Ph.D.

UCLA Psychiatry and Biobehavioral Sciences

Los Angeles, CA

Syed Naqvi, M.D.

Cedars-Sinai Medical Center

Los Angeles, CA

Cheryl A. Sadowski, B.Sc., Pharm.D.

University of Alberta

Edmonton, Alberta, Canada

Charles Schultz, M.D.

University of Minnesota

Minneapolis, MN