# Summary and Discussion

We conducted an extensive literature search, data abstraction, and meta-analyses, whenever possible, to assess the efficacy, comparative effectiveness, and safety of atypical antipsychotics for off-label indications. Since the submission of our original comparative effectiveness review (CER)in 2006, many new high-quality controlled trials have been published; we were able to add many to our prior quantitative analyses and conduct additional analyses on new conditions and adverse events. In this chapter, we describe the limitations of our review and meta-analyses and then present our conclusions. We also discuss the implications of our findings for future research.

Limitations. Our literature search procedures were extensive and included canvassing experts from academia and industry regarding studies we may have missed. However, the possibility of publication bias still exists. For the most part, our assessment did not yield any evidence of unexplained heterogeneity. Two exceptions include one outcome for depression and the Y-BOCS “percent of participants responded” outcome used in our obsessive-compulsive disorder (OCD) meta-analysis. In our analysis of atypicals as augmentation in treatment of major depressive disorder (MDD), possible publication bias appeared in studies reporting the percent of participants remitted according to the Montgomery-Asberg Depression Rating Scale (MADRS). We conducted additional efficacy meta-analyses using Hamilton Depression Rating Scale (HAM-D) outcomes; efficacy results were similar, but no heterogeneity was detected. Thus, our confidence that some atypicals are efficacious as augmentation of selective serotonin reuptake inhibitors (SSRIs) or serotonin-norepineprhine reuptake inhibitors (SNRIs) for depression remains despite evidence of possible publication bias. Heterogeneity was also evident in studies assessing the efficacy of atypicals for OCD. This heterogeneity was likely due to patient enrollment criteria; studies used different definitions of “refractory” and “treatment resistant.” Another published meta-analysis of atypicals for OCD192 found similar efficacy results but no heterogeneity according to statistical tests.

Furthermore, when we reviewed the recent meta-analysis assessing death and the use of these drugs in persons with dementia, we learned of the existence of some manufacturer-supported trials, the published results of which we searched for and were not able to find, despite extensive computerized searches and requests to the manufacturers (we have since learned the results were not published). It is possible that other such unpublished trial results exist for the other conditions included in our report. In addition, we excluded non-English language studies. Thus, we assume that publication bias may occur for all conditions, resulting in an overestimation of efficacy of these drugs and conditions.

An important limitation common to systematic reviews is the quality of the original studies included. In order to measure the quality of clinical trials we used the Jadad scale.17 As empirical evidence regarding other study characteristics and their relationship to bias is lacking, we did not attempt to use other criteria. However, other aspects of the design and execution of a trial may be related to bias, but we do not yet have good measures of these elements. In our 2006 CER on off-label use of atypicals, we conducted a sensitivity analysis on the relationship between trial quality and effect size; the better quality trials reported an effect size 25 percent smaller than did lower quality trials. This finding increases the likelihood that a synthesis of results of all studies—whether narrative or quantitative—may produce inflated estimates of efficacy. As stated above, the higher general quality of the dementia and depression augmentation studies led to a greater strength of evidence rating for those uses. Another factor contributing to our conclusions is the degree to which the available evidence comes from manufacturer-supported studies. In studies of other drugs and in studies of atypical antipsychotic drugs in particular, there is evidence that sponsorship by the manufacturer is more likely to yield results favorable to the manufacturer's product. In some cases this has been related to design or reporting methods that intentionally favor the manufacturer's product. Thus, to the extent that all or almost all of the available evidence supporting drug/indication came from the manufacturer, we downgraded our confidence in the conclusion. The existence of Clinical Antipsychotic Trials of Intervention Effectiveness-Alzheimer's Disease (CATIE-AD), which was federally sponsored and reported results consistent with the manufacturer supported studies, substantially increases our confidence regarding the studied atypical antipsychotics for elderly patients with dementia.

We could come to very few conclusions regarding dosage. Most trials used flexible dosing, so patients were on a wide range of doses.

Applicability of research to the larger treatment population is important in interpreting the results of the included studies. The participation rate, the intended target population, representativeness of the setting, and representativeness of the individuals must be known to assess applicability. Such data were reported unevenly in the studies we reviewed. The dementia trials were most often conducted in nursing homes, hospitals, or assisted living facilities. According to our review on utilization patterns, these settings represent where atypicals are most often used in the elderly. Studies for other conditions were not particularly representative. For example, three of the four trials for Attention-Deficit Hyperactivity Disorder (ADHD) were conducted in children with severe co-occurring conditions, such as bipolar disorder or mental retardation.

In the studies of atypicals as augmentation for SSRI or SNRI patients with MDD, it was often unclear whether patients were simultaneously undergoing psychotherapy. One trial165 specifically stated that subjects were prohibited from initiating such therapy during the trial, but other reports were unclear on the issue. Thus, it is unclear whether treatment over and above the medication influenced the study results. As many depression patients are treated in primary care, it is important to note that subjects in the depression trials were recruited from both primary care and mental health centers.

We found only one controlled trial of atypicals for treatment of insomnia. Among observational studies only one small one188 included patients with insomnia as primary diagnosis. Others included patients with Parkinson's disease, MDD, polysubstance abuse withdrawal symptoms, and tamoxifen induced insomnia. Thus, the results of these studies should not be applied to the general population.

Conclusions. Tables 30 and 31 present the most clinically relevant findings. It is important to note that we found no trials, large observational studies, or utilization studies of the three newest atypicals (asenapine, iloperidone, and paliperidone) for off-label uses. Table 30 is organized as follows: First, all conditions dealt with in our original CER, in alphabetical order; second, all the new off-label indications in alphabetical order.

Table 30 Summary update: efficacy of atypical antipsychotics for off-label use

Usage | Strength of Evidence | 2006 Findings | 2011 Findings | 2011 Conclusions
Dementia | High | A published meta-analysis of 15 placebo-controlled trials (PCTs) found small but statistically significant effects favoring treatment with risperidone and aripiprazole. There were effects that favored treatment with olanzapine for the BPRS and the NPI, but these differences were not statistically significant. Three studies of quetiapine were considered too clinically dissimilar to pool and results for the individual studies showed, with one exception, trends favoring treatment with quetiapine that did not reach conventional levels of statistical significance. | Overall – In our meta-analysis of PCTs, aripiprazole, olanzapine, and risperidone were superior to placebo as treatment of behavioral symptoms measured by total scores on BEHAVE-AD, BPRS, and NPI. Effect sizes were generally considered to be “small” in magnitude. Psychosis – In our meta-analysis risperidone was superior to placebo, as measured by the psychosis subscales of the BEHAVE-AD, BPRS, and NPI. Results for aripiprazole did not meet conventional levels of statistical significance. Agitation – In our meta-analysis, aripiprazole, olanzapine and risperidone were superior to placebo, as measured by the agitation subscales of the BEHAVE-AD, BPRS, NPI, and CMAI. Three head to head trials compared atypicals; none was found superior. | Aripiprazole, olanzapine, and risperidone have efficacy as treatment for behavioral symptoms of dementia.
Depression – MDD: augmentation of SSRI / SNRI | Moderate - risperidone, aripiprazole, quetiapine Low – olanzapine, ziprasidone | Three trials assessed the combination of olanzapine and fluoxetine , one trial each assessed augmentation of various SRIs with risperidone, ziprasidone, and quetiapine, and one study assessed adding risperidone versus olanzapine to SSRI. The combination of olanzapine and fluoxetine was no better than fluoxetine alone in improvement of depressive symptoms at 8 weeks, but three trials reported more rapid improvement in depressive symptoms (at 2-4 weeks) with combination therapy using olanzapine or quetiapine. The one trial that directly compared augmentation therapy between olanzapine and risperidone reported no differences in outcome. | We conducted a meta-analysis using “response” to treatment and remission as outcome. Pooling trials that reported the HAM-D as outcome, the relative risk of responding for participants taking quetiapine or risperidone was significantly higher than for placebo. Olanzapine had only two trials, so pooling was not performed; the trials reported olanzapine superior to placebo. Other trials reported MADRS scores; the relative risk of responding for participants taking aripiprazole was significantly higher than those taking placebo. Risperidone and ziprasidone were included in two trials and one trial, respectively, these reported the drug superior to placebo. One trial compared ziprasidone at differing levels augmenting sertraline to sertraline alone. This trial found a greater improvement in CGI-S and MADRS scores augmenting with ziprasidone at 160mg than either augmentation with ziprasidone at 80mg or sertraline alone. However, there was no significant difference in HAMD-17, CGI-I or HAM-A scores. | Aripiprazole, quetiapine, and risperidone have efficacy as augmentation to SSRIs/SNRIs for major depressive disorder. Olanzapine and ziprasidone may also have efficacy.
Depression – MDD: Monotherapy | Moderate | The three olanzapine studies (above) also assessed its efficacy as monotherapy. Olanzapine alone was no better than placebo in improving symptoms at 6 or 12 weeks. Outcomes were too heterogeneous to allow pooling. | In our meta-analysis of five placebo controlled trials, quetiapine was superior according to relative risk of both responding and remitted as measured by MADRS. | Olanzapine does not have efficacy as monotherapy for major depressive disorder. Quetiapine has efficacy as monotherapy for major depressive disorder.
Obsessive compulsive disorder – augmentation of SSRI | Moderate – quetiapine, risperidone Low - olanzapine | 12 trials used risperidone, olanzapine, or quetiapine as augmentation therapy in patients who were resistant to treatment with SSRI. Nine trials were sufficiently similar clinically to pool. Atypical antipsychotics had a clinically important benefit (measured by the Yale-Brown Obsessive-Compulsive Scale) when used as augmentation therapy. Relative risk of “responding” significant for augmentation with quetiapine and risperidone. There were too few studies of olanzapine augmentation to permit separate pooling of this drug. | Our updated meta-analysis found risperidone superior to placebo, as measured by changed in the Yale Brown Obsessive Compulsive Scale (Y-BOCS). There were too few studies (two) to permit separate pooling for olanzapine; both trials reported olanzapine superior to placebo. One new head to head trial found no difference in effect between olanzapine and risperidone as SSRI augmentation. One new head to head trial found quetiapine more effective than ziprasidone as SSRI augmentation. One new trial compared quetiapine to clomipramine as SSRI augmentation. Quetiapine produced a significant reduction in Y-BOCS score, while clomipramine did not. | Risperidone has efficacy in improving OCD symptoms when used as an adjunct to SSRI in treatment refractory patients. Olanzapine may also have efficacy. Quetiapine is more efficacious than ziprasidone and clomipramine for this purpose.
Obsessive compulsive disorder – augmentation of citalopram | Low-quetiapine Very low - risperidone | One trial of risperidone reported no differences between groups in achieving a response to therapy, but patients maintained on risperidone had a significantly longer period of time to relapse compared with placebo (102 days v. 85 days) | Two new trials found quetiapine superior to placebo as augmentation for citalopram, according to Y-BOCS and CGI-I scores. | Quetiapine and risperidone may be efficacious as augmentation to citalopram in OCD patients.
Post traumatic stress disorder | Moderate – risperidone Olanzapine – Low Quetiapine – very low | Four trials of risperidone and two trials of olanzapine, each of at least 6 week duration, treated patients with PTSD. Three trials enrolled men with combat-related PTSD; these showed a benefit in sleep quality, depression, anxiety, and overall symptoms when risperidone or olanzapine was used to augment therapy with antidepressants or other psychotropic medication. Three trials of olanzapine or risperidone as monotherapy for abused women with PTSD were inconclusive regarding efficacy. | Three new trials of risperidone were found, allowing us to conduct a meta-analysis using the Clinician Administered PTSD Scale (CAPS) as outcome. Risperidone was superior to placebo. There were too few olanzapine studies (two) to pool; one reported olanzapine superior to placebo, while one did not. A new trial found a 3-fold decline in CAPS scores in patients treated with quetiapine monotherapy compared with placebo. Exact scores were not reported. We also conducted a meta-analysis by condition; atypicals were efficacious for combat-related PTSD but not PTSD in abused women. | Risperidone is efficacious in reducing combat-related PTSD symptoms when used as an adjunct to primary medication.
Personality disorders - borderline | Low – aripiprazole Very low – quetiapine, olanzapine | Three trials provide evidence that olanzapine is superior to placebo & may be superior to fluoxetine. The benefit of adding olanzapine to dialectical therapy in one trial was small. Aripiprazole was superior to placebo in one small trial. | One new trial found aripiprazole superior to placebo in improving SCL-90, HAM-D, and HAM-A scores at 8 months and less self-injury at 18 months. One new trial of ziprasidone found no significant difference in CGI-BPD, depressive, anxiety, psychotic or impulsive symptoms compared with placebo at 12 weeks. Two new trials of olanzapine found no difference from placebo in any outcomes, while another new trial of olanzapine found greater change in ZAN-BPD scores at 12 weeks, compared with placebo. One new trial found quetiapine superior to placebo on BPRS, PANSS scales. Due to heterogeneity of outcomes, we could not perform a meta-analysis. | Olanzapine had mixed results in 7 trials, aripiprazole was found efficacious in two trials, quetiapine was found efficacious in one trial, and ziprasidone was found not efficacious in one trial.
Personality disorders - schizotypal | Low | Risperidone was superior to placebo in one small trial. | One new small trial of risperidone found no difference from placebo on a cognitive assessment battery. | Risperidone had mixed results when used to treat schizotypal personality disorder in two small trials.
Tourette's syndrome | Low | Risperidone was superior to placebo in one small trial, and it was at least as effective as pimozide or clonidine for 8 to 12 weeks of therapy in the three other trials. One trial of ziprasidone showed variable efficacy compared with placebo. | No additional trials. | Same as 2006: Risperidone is at least as efficacious as pimozide or clonidine for Tourette's syndrome.
Anxiety | Moderate | Not covered. | Three placebo-controlled trials of quetiapine as monotherapy for Generalized Anxiety Disorder (GAD) could be pooled; relative risk of responding on HAM-A favored the quetiapine group. One head to head trial showed no difference between risperidone and paroxetine on HAM-A score improvement. One trial each found quetiapine equally effective as paroxetine and escitalopram. | Quetiapine has efficacy as treatment for Generalized Anxiety Disorder
Attention deficit / hyperactivity disorder – no co-occurring disorders | Low | Not covered. | One trial showed risperidone superior to placebo in reducing scores on the Children's Aggression Scale – Parent version (CAS-P). | Risperidone may be efficacious in treating children with ADHD with no serious co-occurring disorders.
Attention deficit / hyperactivity disorder - mentally retarded children | Low | Not covered. | One trial showed risperidone led to greater reduction in SNAP-IV (Swanson, Nolan, and Pelham teacher & parent rating scale) scores than methylphenidate. | Risperidone may be superior to methylphenidate in treating ADHD symptoms in mentally retarded children.
Attention deficit / hyperactivity disorder - bipolar children | Low | Not covered. | Two trials of aripiprazole showed no effect on SNAP-IV (Swanson, Nolan, and Pelham teacher & parent rating scale) scores than placebo. | Aripiprazole is inefficacious in reducing ADHD symptoms in children with bipolar disorder.
Eating disorders | Moderate – olanzapine Low - quetiapine | Not covered. | Five trials of olanzapine were found; three reporting Body Mass Index (BMI) could be pooled. There was no difference in change in BMI at either one or three months compared with placebo. One trial of quetiapine reported no statistical difference from placebo in BMI increase at three months. | Olanzapine and quetiapine have no efficacy in increasing body mass in eating disorder patients.
Insomnia | Very low. | Not covered. | In one small trial (N=13) of quetiapine, sleep outcomes were not statistically different from placebo. | Quetiapine may be inefficacious in treating insomnia.
Substance abuse - alcohol | Moderate – aripiprazole Low – quetiapine | Not covered. | Two trials of aripiprazole and one of quetiapine reported % of patients completely abstinent during follow-up. In our pooled analysis, the effect versus placebo was insignificant. | Aripiprazole is inefficacious in treating alcohol abuse / dependence. Quetiapine may also be inefficacious.
Substance abuse - cocaine | Low | Not covered. | Two trials of olanzapine and one of risperidone reported there was no difference in efficacy versus placebo as measured by the Addiction Severity Index (ASI). | Olanzapine is inefficacious in treating cocaine abuse / dependence. Risperidone may also be inefficacious.
Substance abuse – methamphetamine | Low | Not covered. | One trial found aripiprazole inefficacious in reducing use of intravenous amphetamine, as measured by urinalysis. Another trial found aripiprazole inefficacious in reducing craving for methamphetamine. | Aripiprazole is inefficacious in treating methamphetamine abuse / dependence.
Substance abuse – methadone clients | Low | Not covered. | One trial of methadone clients found no difference between risperidone and placebo in reduction of cocaine or heroin use. | Risperidone is an inefficacious adjunct to methadone maintenance.

ADHD = attention-deficit hyperactivity disorder; BEHAVE-AD = Behavioral Pathology in Alzheimer's Disease Scale; BMI = body mass index; BPRS = Brief Psychiatric Rating Scale; CAPS = Clinician-Administered PTSD Scale; CAS-P = Children's Aggression Scale-Parent Version; CGI-I = Clinical Global Impression Improvement; CGI-S = Clinical Global Impression-Severity; CMAI = Cohen-Mansfield Agitation Inventory; HAM-A = Hamilton Anxiety Scale; HAM-D = Hamilton Depression Rating Scale; MADRS = Montgomery-Asberg Depression Rating Scale; MDD = major depressive disorder; NPI = Neuropsychiatric Inventory; PANSS = Positive and Negative Syndrome Scale; PCT = placebo-controlled trial; PTSD = post-traumatic stress disorder; SNAP-IV = Swanson, Nolan, and Pelham Rating Scale; SSRI = selective serotonin reuptake inhibitor; SNRI = serotonin-norepinephrine reuptake inhibitors; Yale-Brown Obsessive-Compulsive Scale

Table 31 Summary update: safety of atypical antipsychotics for off-label use

Adverse Event | Head to Head Comparisons | Active Comparisons | Placebo Comparisons
Weight gain – Elderly patients | In one large trial (CATIE-AD) patients who were treated with olanzapine, quetiapine, or risperidone averaged a monthly gain of 1.0, 0.7, and 0.4 lbs respectively, compared with a monthly weight loss of 0.9 lbs for placebo patients. | More common in patients taking olanzapine than risperidone or conventional antipsychotics, particularly if their BMI was less than 25 at baseline, according to a large cohort study. | More common in patients taking olanzapine and risperidone than placebo according to our meta-analysis.
Weight gain – Adults 18 - 64 | More common in olanzapine patients than ziprasidone patients in one trial. | More common among patients taking olanzapine than patients taking conventional antipsychotics in three trials. More common in patients taking aripiprazole than patients taking conventional antipsychotics in one trial. More common among patients taking olanzapine than patients taking mood stabilizers in two trials. | More common in patients taking aripiprazole, olanzapine, quetiapine, and risperidone than placebo according to our meta-analysis.
Weight gain – Children & adolescents | No head-to-head studies | No difference between clonidine and risperidone in one trial. | More common in patients taking risperidone in two PCTs. No difference in one small PCT of ziprasidone.
Mortality - Elderly patients | No difference between olanzapine and risperidone according to a meta-analysis of six trials of olanzapine published in 2006. | Six large cohort studies compared mortality in elderly patients taking atypical and conventional antipsychotics. Four of these studies found a significantly higher rate of death with conventional antipsychotics, while two found no statistical difference in mortality between the drug classes | The difference in risk for death was small but statistically significant for atypicals, according to a 2006 meta-analysis which remains the best available estimate. Sensitivity analyses found no difference between drugs in the class. Patients taking atypicals had higher odds of mortality than those taking no antipsychotics in the two cohort studies that made that comparison. There are no trials or large observational studies of ziprasidone in this population; therefore, we can not make conclusions regarding safety here.
Endocrine / diabetes – Elderly patients | No evidence reported. | No evidence reported. | No difference in endocrine events in risperidone patients in one PCT. Regarding diabetes, risk was elevated but not statistically significant in one industry-sponsored cohort study of olanzapine patients.
Endocrine / diabetes – Adults 18 - 64 | Diabetes more common in patients taking olanzapine than patients taking risperidone in one trial. | No evidence reported. | Endocrine events more common in patients taking quetiapine, risperidone, and ziprasidone in one PCT each. More common in olanzapine in two pooled PCTs. Diabetes more common in patients taking quetiapine in six pooled PCTs; however, the pooled odds ratio was elevated at 1.47 but not statistically significant. More common in olanzapine patients in one PCT; the odds ratio of 5.14 was not statistically significant, with very wide confidence intervals (0.6 to 244). Lower odds of diabetes in risperidone patients in one large observational study
CVA - Elderly patients | No evidence reported. | Hospitalization for CVA was increased in the first week after initiation of conventional antipsychotics, but not for initiation of atypicals in a large cohort study. | More common in risperidone patients than placebo according to four PCTs pooled by the manufacturer. In our new meta-analysis of PCTs, risperidone was the only drug associated with an increase. More common in olanzapine than placebo according to five PCTs pooled by the manufacturer.
EPS - Elderly patients | More common in patients taking aripiprazole and risperidone patients than patients taking quetiapine in one large trial (CATIE-AD). | No evidence reported. | More common in patients taking risperidone, according to our meta-analysis. Quetiapine and aripiprazole were not associated with an increase. More common in olanzapine in one PCT.
EPS – Adults 18 - 64 | No evidence reported | Less likely in patients taking quetiapine than mood stabilizers in one small trial. Less likely in patients taking olanzapine or aripiprazole than patients taking conventional antipsychotics in one trial each. | More common in patients taking aripiprazole, quetiapine, and ziprasidone than placebo according to our meta-analysis.
Sedation – Elderly patients | More common in elderly patients taking olanzapine or quetiapine than risperidone according to our analysis, but not quite statistically significant. | No difference in one trial of olanzapine versus benzodiazepines. No difference in three trials of olanzapine and three of risperidone versus conventional antipsychotics. | More common in patients taking aripiprazole, olanzapine, quetiapine, and risperidone than placebo according to our meta-analysis.
Sedation – Children and adolescents | No head-to-head trials. | No difference in one small trial of clonidine versus risperidone. More patients on haloperidol than risperidone reported sleep problems in one trial. | Less common in aripiprazole patients than placebo patients in one PCT. No difference from placebo in one small PCT of ziprasidone.
Sedation – Adults 18-64 | More common in patients taking quetiapine than risperidone in two trials. No difference in one trial of risperidone versus olanzapine. | Olanzapine patients had higher odds than mood stabilizer patients in two trials. More common in olanzapine and quetiapine patients than SSRIs patients in three and two trials respectively. Olanzapine patients had lower odds than patients taking conventional antipsychotics in our pooled analysis of three trials. | More common in patients taking aripiprazole, olanzapine, quetiapine, risperidone, and ziprasidone than placebo in our meta-analysis.

CATIE-AD = Clinical Antipsychotic Trials of Intervention Effectiveness-Alzheimer's Disease; CVA = cerebrovascular accident; EPS = extrapyramidal symptoms; PCT = placebo-controlled trial

## Future Research

The overarching finding of this review is that although atypical antipsychotic medications are being used for a large number of off-label uses, we were able to find moderate to strong evidence to support efficacy for only a few of the drugs and only a few of the off-label uses. Most of the evidence is concentrated in the drugs risperidone, olanzapine, and quetiapine, and the conditions dementia, depression, and obsessive-compulsive disorder. For the newly approved atypicals (asenapine, iloperidone, and paliperidone), we found no clinical trials assessing their use for any off-label condition, and for some off-label uses, we found no or only a small number of trials. Head-to-head comparisons of atypical antipsychotic drugs for off-label uses are few, and evidence from placebo-controlled trials for off-label uses suggests that efficacy differs between drugs, meaning that the assumption of a “class effect” for atypical antipsychotics may be unwarranted. This means that each drug is going to require its own evaluation of efficacy for each off-label indication, which is a large task; and then drugs demonstrated to be efficacious will need to be tested head-to-head in trials of comparative effectiveness.

With respect to use in individual off-label conditions, we offer the following thoughts.

ADHD. We found three placebo-controlled trials and one active-control trial. Two of these studied risperidone and two studied aripiprazole. Though these did find some efficacy for ADHD, the trials utilized differing outcome measures and the patient populations differed in severity of illness and comorbid conditions. For these reasons, the trials could not be pooled and overall efficacy in ADHD still needs to be established for each medication. Future research should utilize one standard measure of ADHD in order for them to be compared. In addition, we learned from utilization studies that other atypical antipsychotic medications, such as quetiapine and olanzapine are being used frequently for ADHD. As we found no trials of their efficacy, future research should include studies of these medications.

Anxiety. Though there were many placebo-controlled trials of atypicals for anxiety symptoms, only three were clinically similar enough to pool. These trials used quetiapine for generalized anxiety disorder. There were mixed reports of efficacy for the other atypicals and there were no studies of anxiety treatment with aripiprazole. Future research needs to include additional studies of the various atypical agents. As the Hamilton Anxiety Rating Scale (HAM-A) was the most commonly used measure, if these future trials utilized the HAM-A, it will be possible to compare across trials.

Dementia. Given the concern over serious adverse events such as mortality, knowledge of the efficacy of atypical antipsychotics in the demented elderly is of paramount importance. We found evidence that aripiprazole, olanzapine and risperidone were superior to placebo in treating agitation, psychosis, and behavioral symptoms. We found no trials of ziprasidone in dementia. An assessment of the net efficacy compared with the side effect burden would be useful in future studies.

Depression. There were enough trials of quetiapine and risperidone to pool to show efficacy when used an augmentation agent. Olanzapine augmentation was shown to be superior to placebo but there were only two trials. There was only one placebo-controlled trial of ziprasidone in depression. Though it was found to be superior, further studies to confirm this finding are required.

Eating Disorders. As weight gain is a common side effect experienced during treatment of other conditions with olanzapine, the assumption has been that this side effect could be exploited for therapeutic benefit as a treatment for eating disorders. Though commonly used clinically, the four trials of olanzapine in eating disorders found that it led to no statistically significant difference in body mass index. Mechanistic studies to explain differences in those with eating disorders from those with other psychiatric conditions may elucidate why weight gain occurs in some populations but not others.

Insomnia. Insomnia is another condition where the side effects of atypical antipsychotics are exploited for treatment. Atypicals, particularly olanzapine and quetiapine, are commonly sedating. Clinical trials are needed to rigorously test the conclusions from observational studies that olanzapine and quetiapine are useful in promoting sleep quality and sleep onset. Placebo controlled trials confirming their efficacy are necessary before reaching any conclusions.

OCD. Several trials reported the efficacy of quetiapine as an augmentation agent in OCD along with a few of risperidone. Further studies of olanzapine and aripiprazole are required in order to assess their efficacy. In addition, further trials comparing the atypical antipsychotic agents to the current standards of treatment would be helpful in order to know at which point of treatment failure there benefit is greatest. For example, one trial found that quetiapine had greater efficacy in reducing the Yale-Brown Obsessive-Compulsive Scale (Y-BOCS) score than clomipramine, though clomipramine is currently a more widely recommended treatment for resistant OCD. If further trials confirmed this result, atypical antipsychotics could be placed higher on an algorithm for recommended treatment.

Personality Disorders. Personality disorders have remained a difficult area for clinicians, leading to continued exploration for successful treatments. Unfortunately, our ability to reach strong conclusions is hindered by the heterogeneity of the trials reviewed. Future research should have standard outcomes so that results across trials can be compared. In our review, olanzapine and risperidone had mixed results, and quetiapine and aripiprazole were found to have some efficacy while ziprasidone did not. However, there were too few trials to allow for clinicians to predict the effect of a particular agent for a particular patient. Before reaching conclusions regarding clinical use further research, with comparable outcomes, is necessary.

Post-Traumatic Stress Disorder. Some studies found efficacy for risperidone, olanzapine and quetiapine for the symptoms of post-traumatic stress disorder (PTSD). An issue in PTSD is the question of whether the results are affected by gender. Our review found that the atypicals showed efficacy in male combat veterans but not female victims of civilian trauma. Whether this signifies that efficacy differs by gender or rather that combat trauma is more amenable to treatment with atypicals than civilian trauma requires further research to elucidate.

Substance Abuse. Trials of atypical antipsychotic treatment for substance abuse did not find them superior to placebo on substance use measures. Future research is needed to establish a role, if any, in the use of atypical antipsychotic drugs in the treatment of substance abuse.

Tourette's Syndrome. Other than efficacy demonstrated with risperidone, there is only one placebo-controlled trial of another atypical antipsychotic, ziprasidone, as a treatment for Tourette's syndrome. Additional trials are needed before any conclusions can be reached regarding the other atypicals.

In addition to the research recommended above, there is almost no evidence about how treatment efficacy may vary within populations, including variations due to gender, race, ethnicity, or other comorbidities. In addition, existing evidence about the effect of baseline severity of disease is too heterogeneous to allow us to draw conclusions. In future research, standardized measures of disease severity might allow for greater knowledge of the patient populations who would benefit from treatment with atypical agents.

Regarding adverse effects of the atypical antipsychotics, existing evidence varies by drug and by description of the adverse event. It would facilitate assessments if future studies contained a standardized list of assessed side effects. As many trials report only those effects observed, we are unable to compare between trials for many of the side effects.

Two of the adverse events deserve further comment, because they potentially differ from the perception of clinical psychiatrists. In four studies including 1,387 nonelderly patients, aripiprazole was associated with weight gain, and in seven studies including 2,566 nonelderly patients quetiapine was associated with extrapyramidal symptoms. We consider these findings to be a signal deserving of further investigation.

Another area where clinical guidance is needed is in the dosages required to achieve effects in off-label indications. The dosages used off-label varied from those used for on-label indications. There were a few trials that compared dosage efficacy, but most used flexible dosing. Thus, a dosage comparison across trials was generally not possible. More research examining differing dosages within the same population is required in order to guide clinicians in the appropriate doses to prescribe. A similar issue is that of treatment length. More research reporting responses at various time points would be helpful in determining how long treatment is required. Given the risk of side effects when using these agents, clinicians need to know when a result is expected to prevent continuing an ineffective agent, unnecessarily.

Newer agents, such as asenapine, iloperidone and paliperidone cannot be assumed to have efficacy and harms similar to the older atypical antipsychotics, since the evidence does not support that there is a general “class effect” in terms of either efficacy or harm for most off-label indications. Trials assessing the newer agents' efficacy and safety are necessary in each of the treatment areas if they are to be prescribed for off-label use.