# Results

In total, EPC reviewers selected 1,144 relevant titles for abstract review out of 9,414 titles. Electronic literature searches identified 9,207 titles, 216 were identified from reference mining, and 23 others not found in the electronic searches were included in Scientific Information Packets sent by drug manufacturers (Figure 2). Eighty-one were rejected through our abstract review, and 15 could not be obtained. Thus, 1,048 full-text articles/reports were available for short form screening.

Figure 2 Literature flow

* Where trials did not exist, we described observational studies.

AP1=Evidence Report 2006, AP2=Updated 2011 Evidence Report

Figure 2 is a literature flow diagram depicting each stage of our literature search, screening, and data abstraction process. The first page of “Chapter 3: Results” describes the information in the figure.

Screening of retrieved articles resulted in further exclusion of 663. Reasons for exclusion include: no psychiatric condition of interest (i.e., not off-label conditions: 300 articles), study design (108 nonsystematic reviews, 60 case reports, 50 observational studies, 56 descriptive papers, and four other design), no drug/topic of interest (30 articles), foreign language (27 articles), no efficacy, effectiveness, safety, or utilization outcomes (6 articles), no human cases included (1 article), and 21 articles containing duplicate data, most of the duplicates were conference abstracts of studies that were later published as journal articles. We also identified 54 systematic reviews.

Among the 331 individual studies accepted based on short form review, there are 128 controlled trials (of which 122 reported efficacy outcomes) and 297 studies reporting adverse events (in our adverse event analysis, we focused on 129 studies which were either controlled trials or large observational studies). Eighteen articles contain information on utilization/prescription patterns in the United States.

The second page of Figure 2 displays the 122 new controlled trials that reported efficacy results along with 55 trials included in our 2006 Comparative Effectiveness Review (CER). Among these trials, seven reported duplicate data, and one had no comparison of interest; these were excluded. This left us 169 studies in total for our efficacy synthesis, with some studies contributing evidence to multiple conditions. The bottom of the second page of Figure 2 displays number of studies for each individual condition.

## Key Question 1 What are the leading off-label uses of atypical antipsychotics in utilization studies? How have trends in utilization changed in recent years, including inpatient versus outpatient use? What new uses are being studied in trials?

### Key Points

Off-label use of atypical antipsychotics in various settings increased rapidly after their introduction in the 1990s.

Use of atypical antipsychotics for the following off-label conditions has been documented in the scientific literature: attention-deficit hyperactivity disorder (ADHD), anxiety, dementia in elderly patients, depression, eating disorders, insomnia, obsessive compulsive disorder, personality disorder, post-traumatic stress disorder (PTSD), substance use disorders, and Tourette's syndrome.

Risperidone, quetiapine, and olanzapine are the most common atypicals prescribed for off-label use.

We found no reports describing off-label use of asenapine, iloperidone, and paliperidone.

According to a 2007 study, the use of atypical antipsychotics in the elderly is much higher in long-term care settings than in the community.

In 2004, nearly 25 percent of the elderly nursing home population received antipsychotics, with most receiving atypicals; males were more likely than females to receive them.

One year after the 2005 Food and Drug Administration (FDA) advisory warning, no state had actually changed its prior authorization policy in response to limit the use of atypicals in dementia. However, a more recent study concluded that the FDA advisory decreased the use of atypical antipsychotics in the U.S., especially among elderly dementia patients.

In 2003–2004, antipsychotics were prescribed in only 1 percent of overall mental health visits by children and adolescents, with most (99 percent) of these visits involving prescribing of atypicals.

Male children/adolescents were more likely than females to be prescribed atypical antipsychotics. Risperidone was the atypical most commonly prescribed to children.

At one large acute-care psychiatric hospital, quetiapine was used extensively for off-label conditions, and in a variety of off-label doses: only a quarter of patients had one of the diagnoses for which quetiapine is approved, and only a third received quetiapine in a standing dose regimen. Depression and substance-use disorders were found to be the most common associated diagnoses.

Atypicals are frequently prescribed to treat PTSD in the U.S. Department of Veterans Affairs (VA) health system.

### Detailed Analysis

Overall utilization/prescription patterns in the United States. Our search identified 39 papers describing utilization/prescription patterns of antipsychotics (including atypical antipsychotics) in the United States. The majority examined conventional antipsychotics, atypical antipsychotics, and other agents simultaneously. Many of them investigated both on-label and off-label uses of atypicals. Table 2 presents information about settings, dates, sample size, drugs, conditions, and findings from large U.S. utilization studies with representative populations.

Table 2 Large utilization studies in the United States

Author/ Year | Setting | Dates Covered by the Data | Sample Size | How Utilization Assessed | Sample Representative | Drug | Conditions | Findings
ADULTS
Alexander, 2011^37^ | Outpatient | 1995-2008 | 4,800 MDs | IMS Health National Disease and Therapeutic Index physician survey | Nationally representative | Olanzapine, Quetiapine, Risperidone, Ziprasidone, Aripiprazole, Paliperidone | On-label uses, depression, anxiety, ADHD, dementia | In 1995, 84% of antipsychotic visits involved conventional agents; by 2008 93% of visits involved atypicals. In 2008, 14% of atypicals were prescribed for depression.
Aparasu, 2005^33^ | Outpatient | 2003 - 2004 | 2,860 | Survey data analysis | Nationally representative | Olanzapine, Quetiapine, Risperidone, Ziprasidone, Aripiprazole | Depression, anxiety, dementia | Extensive concomitant antipsychotic therapy (simultaneous use of two or more antipsychotic agents) was found in outpatient settings. Risperidone, olanzapine, and quetiapine were commonly used in concomitant therapy and monotherapy.
Chen, 2006^75^ | All | 2001 | 33,406 | Claim data analysis | Georgia | Olanzapine, Quetiapine, Risperidone | All off-label conditions; not specified | The off-label use of antipsychotics is highly prevalent.
Dorsey, 2010^43^ | Physician Office | 2003 - 2008 | 4,800 | Drug prescribing data analysis | Nationally representative | Olanzapine, Quetiapine, Risperidone, Ziprasidone, Aripiprazole, Paliperidone | Dementia | The FDA Black Box advisory was associated with decrease in the use of atypical antipsychotics (fell 2% overall), especially among the elderly with dementia (fell 19%). Both on-label and off-label uses declined through 2008.
Gruber-Baldini, 2007^39^ | Nursing homes and community-dwelling | 2002 | 12,697 | Survey data analysis | Nationally representative | Olanzapine, Quetiapine, Risperidone | Dementia, Alzheimer's | Use of atypical antipsychotics, especially olanzapine, quetiapine, and risperidone, was much higher in long-term care settings than in the community.
Jano, 2008^41^ | Community -dwelling | 1996 - 2004 | 32,737 | Survey data analysis | Nationally representative | Olanzapine, Quetiapine, Risperidone, Ziprasidone, Aripiprazole | Anxiety, dementia | The most common diagnoses for antipsychotics use were dementia, anxiety, and schizophrenia; roughly the same proportion received typicals and atypicals; the most frequently used atypicals were risperidone, olanzapine, and quetiapine. After 1998, atypical use was over ten times more than in 1996 – 1998. Elderly patients with poorer perceived mental health were more likely to receive atypicals rather than typicals.
Kamble, 2008^40^ | Nursing homes | 2004 | 11,939 | Survey data analysis | Nationally representative | Olanzapine, Quetiapine, Risperidone, Ziprasidone, Aripiprazole | Dementia, depression, anxiety | Wide off-label use in conditions such as dementia, anxiety, depression was found among the elderly. Nearly 25% of nursing home elderly received antipsychotics, with most receiving atypicals. Males were more likely than females to receive atypicals.
Leslie, 2009^57^ | Veterans Administration | 2007 | 279,778 | Administrative Database | Nationally representative | Aripiprazole, Olanzapine, Quetiapine, Risperidone, Ziprasidone | Depression, anxiety, dementia, PTSD, substance abuse | 60% of individuals who received an antipsychotic had no record of FDA- approved diagnosis. 79.5% of prescriptions were for atypicals (as opposed to conventional agents).
Morrato, 2007^59^ | All | 1998 - 2003 | 55,481 | Medicaid claim data analysis | Multistate | Olanzapine, Quetiapine, Risperidone | Depression, substance abuse | The mean prevalence of long-term antipsychotic polypharmacy in the year after initiating antipsychotics was 6.4%. Antipsychotic polypharmacy was more common in patients with more severe mental illness.
Rosenheck, 2001^56^ | Veterans Administration | 1999 | 73,981 | Chart review | Nationally representative | Olanzapine, Quetiapine, Risperidone | Depression, PTSD, Alzheimer's, dementia | Substantial off-label use of atypicals (42.8%) was evidenced, although a majority of patients were diagnosed with schizophrenia.
Sankaranarayanan, 2007^36^ | Emergency department (ED) | 2000 - 2004 | 2 million visits | Survey data analysis | Nationally representative | All; not specified | Depression, anxiety, substance use disorder | 55% and 8% psychiatric ED visits involved atypical and typical-atypical combination prescriptions, respectively; there were 8-fold and 3.5-fold increase in ED visits with combination and atypical prescriptions, respectively. Patients with depression were more likely to receive atypical versus typical antipsychotics in the ED settings.
Sankaranarayanan, 2007^35^ | Outpatient | 1996 - 2003 | 356,885 | Survey data analysis | Nationally representative | Olanzapine, Quetiapine, Risperidone, Ziprasidone | Depression, anxiety, dementia | From 1996/1997 to 2002/2003, visits involving atypical and combination antipsychotics saw large increases: 195% and 149%, respectively, while visits involving typicals decreased by 71%. More atypicals than typicals and combinations were used at US ambulatory care visits by patients with mental health disorders. Atypicals were less likely involved with visits by adults aged 41 to 64 years old and those with public insurance, but more likely by those with depression.
CHILDREN/ADOLESCENTS
Aparasu, 2007^47^ | Outpatient | 2003 - 2004 | 2.08 million visits | Survey data analysis | Nationally representative | Olanzapine, Quetiapine, Risperidone, Ziprasidone, Aripiprazole | Depression, anxiety | Atypical antipsychotics are being extensively prescribed to children and adolescents: in total, antipsychotics were prescribed in 1% of overall visits by children and adolescents in 2003 - 2004; most (99%) of these visits involved prescribing of atypicals. The most frequently used atypicals were risperidone, quetiapine, and aripiprazole; males and whites were more likely to use these drugs.
Cooper, 2004^48^ | All | 1996 - 2001 | 6,803 | Cohort study | Tennessee | All; not specified | Tourette's, ADHD | New users of antipsychotics nearly doubled from 1996 to 2001; new users of atypicals increased from 6.8% in 1996 to 95.9% in 2001. New use for ADHD increased 2.5-fold, while new use for Tourette and autism remained stable.
Halloran, 2010 50 | Inpatient and Outpatient | 2002 - 2005 | 172,766 | Private insurance claim data analysis | Nationally representative | All | Anxiety | The one-year prevalence of atypical antipsychotics use in children increased persistently, from 7.9 per 1,000 in 2002 to 9.0 per 1,000 in 2005. Boys were 2 times more likely than girls to receive atypical antipsychotics. The most common conditions were disruptive behavior disorders, mood disorders, and anxiety. Most children had more than one psychiatric diagnosis.
Olfson, 2006^46^ | Outpatient | 1993 - 2002 | 1,224,000 visits | Survey data analysis | Nationally representative | All; not specified | All; not specify off-label | Atypical antipsychotics are widely prescribed among children and adolescents; a sharply increased use of atypical antipsychotics was found from 2000 to 2002, composing 92.3% of the antipsychotics prescribed in office-based practice.
Patel, 2006^76^ | Outpatient | 1998 - 2001 | 7,353 | Drug claims review | Texas | All; not specified | Anxiety, depression, ADHD, substance use disorder | Disruptive behavioral disorders, depressive disorders, and bipolar disorders accounted for the top three conditions associated with children and adolescents receiving antipsychotics.
Pathak, 2010 49 | Outpatient | 2001 - 2005 | 11,700 | Medicaid claim data analysis | Arkansas | Aripiprazole, Olanzapine, Quetiapine, Risperidone, Ziprasidone | ADHD, depression, anxiety, eating disorders, OCD, personality disorders, PTSD, tic disorders, substance abuse | The number of children receiving atypical antipsychotics doubled during the study period, and the prescriptions were largely unsupported by evidence from clinical studies. The most common condition was ADHD, followed by depression, conduct disorder, oppositional defiant disorder, and adjustment reactions.

ADHD = attention-deficit hyperactivity disorder; ED = emergency department; FDA = Food and Drug Administration; MD = doctor; OCD = obsessive-compulsive disorder; PTSD = post-traumatic stress disorder

Note: In the table, we excluded five articles that examined mainly adverse events, and eight articles that focused on either utilization of other drugs such as typicals/antidepressants or utilization for on-label conditions or both. We did not include articles examining utilization patterns in countries other than the United States.

Reports have shown widespread off-label use of atypical antipsychotics in various settings since their introduction in the 1990s,31-37 and such use has increased significantly in the past decade. The following conditions related to off-label use of atypical antipsychotics have been documented: ADHD, autism, anxiety, dementia, depression, eating disorders, insomnia, obsessive compulsive disorder, personality disorder, PTSD, substance-use disorders, and Tourette's syndrome. Risperidone, quetiapine, and olanzapine have been identified as the most commonly prescribed agents.

Utilization/prescription patterns among the elderly. Compared with other populations, use of atypical antipsychotics among the elderly has been given more attention, probably due to the widespread use of these drugs in dementia and Alzheimer's38 and the fatal risk reported with this use. Studies have examined utilization patterns in both long-term care and in community settings in the United States.

Prescription of atypicals to treat dementia differs by gender and setting. One study39 found that use of atypical antipsychotics—especially risperidone, olanzapine, and quetiapine—was much higher in long-term care settings (21.0 percent, 11.9 percent, and 7.1 percent, respectively) than in the community (5.1 percent, 4.0 percent, and 2.3 percent, respectively). Another study40 used the 2004 National Nursing Home Survey data and found widespread off-label use of antipsychotic drugs for conditions such as dementia, anxiety, and depression. Nearly 25 percent of the elderly nursing home population received antipsychotics, with most receiving atypicals. Males were more likely than females to receive atypicals. However, data from another nationally representative survey41 concluded that among community-dwelling elderly, gender was not significantly associated with atypical antipsychotics use. The authors also found significantly increasing use of atypicals among this population: after 1998, atypical use was more than 10 times as great as in 1996–1998. Elderly patients with poorer perceived mental health were more likely to receive atypicals rather than conventional antipsychotics. This is consistent with earlier findings.40

When increasing evidence showed serious adverse events associated with the use of atypical antipsychotics among elderly people with dementia, regulatory warnings were issued. In both the United States and Canada, regulatory agencies (FDA and Health Canada) issued advisory warnings to health care professionals in 2005, describing increased mortality among elderly people with dementia who were taking atypical antipsychotics. Four studies examined the impact of these warnings. In the United States, Polinski42 found that more than one year after the FDA advisory warning, no state had actually changed its prior authorization policy in response to limit the use of atypicals in dementia. A more recent study 43 compared atypical antipsychotics use before and after the FDA advisory and concluded that the FDA advisory was associated with decreases in both on-label and off-label uses of atypical antipsychotics. The decrease was more rapid among elderly patients with dementia. In contrast, Saad and colleagues44 conducted a survey of health care professionals and found that although most were aware of the FDA warning, only half (49 percent) reported that they changed the way of prescribing based on this notification. Reasons why they did not respond to the warning include: no alternative treatment available, lack of guidance, lack of evidence, and poor data availability. The authors concluded that antipsychotics continued to be prescribed for dementia among older adults. Finally, in Canada, Valiyeva45 found that regulatory warnings were associated with small relative decrease (3 percent–5 percent) in the use of atypicals among elderly patients with dementia, but they did not reduce the overall prescription rate. Despite these decreases, atypical antipsychotics continued to be a common treatment option used among elderly dementia patients.

Utilization/prescription patterns among children and adolescents. Several studies examined prescription patterns of atypical antipsychotics among children and adolescents, indicating wide prescription and recent growth in the treatment of depression, anxiety, and other mental health problems.

Some studies discussed utilization in general, without focusing on off-label conditions. Olfson46 examined national trends in the outpatient treatment of children and adolescents with antipsychotics from 1993 to 2002. Although not focusing on off-label uses of the drugs, they found that atypical antipsychotics were being widely prescribed to children and adolescents: a sharp increase was found from 2000 to 2002, when atypicals composed 92.3 percent of the antipsychotics prescribed in office-based practice. Aparasu47 found that atypical antipsychotics were extensively prescribed to children and adolescents in 2003–2004: in total, antipsychotics were prescribed in 1 percent of overall visits by children and adolescents, with most (99 percent) of these visits involving prescribing of atypicals. The most frequently used atypicals were risperidone, quetiapine, and aripiprazole; males and whites were more likely to these drugs.

Other studies provided details on specific conditions targeted. Cooper48 conducted a cohort study to identify new use of antipsychotics among patients aged 2 to 18 years enrolled in Tennessee's managed care program for Medicaid enrollees and the uninsured (TennCare). They found that new users of antipsychotics nearly doubled from 1996 to 2001. The proportion of new users prescribed atypicals increased from 6.8 percent in 1996 to 95.9 percent in 2001. New use for ADHD increased 2.5-fold, while new use for Tourette's and autism remained stable. More recently, Pathak and colleagues49 examined prescription trend of atypical antipsychotics among 11,700 Arkansas Medicaid-covered children under age 18 who were newly treated with atypical antipsychotics from 2001 through 2005. They found the number of children receiving the medications doubled during this period, increasing from 1,482 in 2001 to 3,110 in 2005; roughly 431 children each year initiated treatment with atypical antipsychotics. The most common condition was ADHD, followed by depression, conduct disorder, oppositional defiant disorder, and adjustment reactions. Most new users were given an initial prescription for risperidone. According to the authors, 41.3 percent of the new users had no diagnosis for which such treatment was supported by any published study, and 77.1 percent of aripiprazole use was not supported by any published evidence. Halloran and colleagues50 examined prescription patterns of atypical antipsychotics among 172,766 privately insured children aged 2 to 18 in the United States between 2002 and 2005. Their findings also suggested a persistent trend in this population: the 1-year prevalence of atypical antipsychotics use increased from 7.9 (per 1,000) in 2002 to 8.1 in 2003, 8.6 in 2004, and 9.0 in 2005. The prevalence was generally lower in girls than boys, with boys almost two times as likely as girls to receive atypical antipsychotics. The most common condition was disruptive behavior disorder (67 percent), followed by mood disorders (65 percent), and anxiety disorder (43 percent). Risperidone (53 percent) was the most commonly prescribed atypical antipsychotic, followed by quetiapine (33 percent). A large proportion (75 percent) of children on these drugs had more than one psychiatric diagnosis during the study period.

Other relevant utilization findings. Seven papers51-57 examined treatment of PTSD, mostly among VA populations; only one of them specifically focused on atypical antipsychotics. They documented that antipsychotics (including atypicals) have been frequently used in treatment of PTSD and comorbid disorders. One study55 found that among a group of Medicaid recipients in New Hampshire atypical antipsychotics were more frequently prescribed when PTSD co-occurred with major depression.

A recent national study of VA records57 indicates that quetiapine and risperidone were the atypicals most frequently prescribed off-label. PTSD was the most common off-label diagnosis, followed by “minor depression.”

Philip58 investigated 2-year trends of off-label prescribing practices of quetiapine at an acute-care psychiatric hospital. They found that quetiapine was used extensively for off-label conditions, and in a variety of off-label doses: only a quarter of patients had one of the diagnoses for which quetiapine is approved, and only a third received quetiapine in a standing dose regimen. Depression and substance use disorders were found to be the most common associated diagnoses.

Antipsychotic monotherapy (use of only one antipsychotic agent), concomitant therapy (simultaneous use of two or more antipsychotic agents), and combination of antipsychotics and other agents have been studied.33,35,36,59 Their findings supported an increasing prevalence of atypical antipsychotics prescription.

Utilization/prescription patterns in other countries. Seventeen papers discussed utilization/prescription patterns of atypical antipsychotics in countries other than the United States: five in Canada, three in the United Kingdom, two each in France, Australia, and Turkey, and one each in Germany, New Zealand, and Italy. The studies documented widespread off-label uses of atypical antipsychotics in treating anxiety,60-64 ADHD,63,65 personality disorder,64 depression,63,64,66 dementia,67-72 eating disorders73 and other conditions. Like in the United States, common off-label use of atypicals and significant increase in such use have been seen in other countries64,69,71,74 risperidone, quetiapine, and olanzapine were the most frequently used atypicals.61,63,69

### Discussion

Most of the utilization studies used national representative survey data or claim data, and their findings reflect national trends. Various settings were covered, including long-term care facilities, communities, inpatient and outpatient settings, VA, and emergency department. We found more studies on some drugs (e.g., risperidone, quetiapine, and olanzapine) than others (we found none on recently approved atypicals asenapine, iloperidone, and paliperidone), more studies on some conditions (e.g., dementia, depression, PTSD and anxiety) than others (e.g., insomnia, eating disorder, and obsessive-compulsive disorder [OCD]), and more studies on the elderly than other populations.

The majority of these studies also investigated the utilization/prescription patterns of other drugs (e.g., conventional antipsychotics, antidepressants, other neuroleptics) simultaneously, and many of them did not distinguish on-label and off-label uses. Still, a high prevalence and a rapid increase in off-label use of the atypical agents have been observed, both in the United States and internationally. Importantly, a study of over 350,000 records indicated that more atypicals than conventional antipsychotics and combinations were used at U.S. ambulatory care visits35 by patients with mental health disorders in the period from 1996 to 2003. Some articles pointed out that despite the scarce evidence supporting efficacy of such uses, the atypicals had been widely prescribed among different populations.

Only a handful of articles examined prescription patterns by gender and by racial/ethnic group. Although a couple of them found that males and whites were more likely to receive off-label prescription of atypicals, the lack of information could not lead to a solid conclusion on whether or not there exist sociodemographic disparities.

The utilization studies covered mostly 1996 to 2004; only a few were conducted after the 2005 FDA and Health Canada warnings on possible severe adverse events in the elderly. One recent study indicated that the 2005 regulatory warning was associated with decreases in the overall use of atypical antipsychotics, especially among elderly dementia patients. However, the prevalence of off-label use of atypical drugs remains high. We conclude that more studies are needed to document the most recent off-label prescription patterns of atypical antipsychotics, especially the newly approved ones, ideally by different sociodemographic populations and by individual off-label indications.

## Key Question 2 What does the evidence show regarding the efficacy and comparative effectiveness of atypical antipsychotics for off-label indications?

### Sub-Key Question 2 How do atypical antipsychotic medications compare with other drugs, including first generation antipsychotics, for treating off-label indications?

#### Key Points

We found no trials of paliperidone, asenapine, or iloperidone for off-label uses.

Attention deficit-hyperactivity disorder (ADHD). This off-label use was not included in our 2006 evidence report.

We found three placebo controlled trials (PCTs) and one active-control trial for ADHD.

One trial found risperidone superior to placebo in reducing scores on the Children's Aggression Scale–Parent version (CAS-P) in children with no serious co-occurring disorders.

Two trials of aripiprazole showed no effect on SNAP-IV (Swanson, Nolan, and Pelham teacher & parent rating scale) scores compared with placebo in children with bipolar disorder and ADHD.

One trial found risperidone led to greater reduction in SNAP-IV scores than methylphenidate in mentally retarded children with ADHD.

There were no trials of quetiapine, olanzapine, or ziprasidone for ADHD.

Anxiety. This off-label use was not included in our 2006 evidence report.

One recently published systematic review found quetiapine monotherapy superior to placebo for generalized anxiety disorder (GAD), as measured by improvement in the Hamilton Anxiety Scale (HAM-A).

We found 14 PCTs of atypicals for anxiety. Three trials of quetiapine monotherapy for GAD were clinically similar enough to pool; relative risk of responding on the HAM-A favored quetiapine over placebo. There were not enough trials of olanzapine, risperidone, or ziprasidone to pool; these trials had mixed results.

One trial showed no difference between risperidone and paroxetine on HAM-A score improvement. One trial each showed no difference in efficacy between quetiapine and paroxetine or escitalopram.

There were no trials of aripiprazole for anxiety disorders.

Dementia. Our 2006 CER focused on two published meta-analyses on use of atypicals in elderly patients with dementia. They found small but statistically significant effects for treatment with risperidone and aripiprazole, and trends toward efficacy of olanzapine and quetiapine.

The number of new trials published since 2006 justified conducting our own new meta-analyses.

In our pooled analysis of efficacy in treating overall behavioral symptoms such as aggression, motor activity and hostility, aripiprazole, olanzapine, and risperidone were superior to placebo as measured by total scores on BEHAVE-AD, Brief Psychiatric Rating Scale (BPRS), and Neuropsychiatric Inventory Scale (NPI).

Risperidone (six PCTs) was superior to placebo in decreasing psychosis symptoms such as delusions and hallucinations in elderly patients with dementia. Results for aripiprazole (three PCTs) did not meet conventional levels of statistical significance.

In our pooled analysis on agitation outcomes, aripiprazole (two PCTs), olanzapine (four PCTs), and risperidone (six PCTs) were superior to placebo.

There were no trials of ziprasidone in dementia patients.

Three head-to-head trials compared atypicals for dementia; none was found superior.

We pooled five head-to-head trials of atypicals versus haloperidol; there was no statistical difference in effect. There were too few trials to pool by specific atypical. One trial found no difference in effect between risperidone and topiramate.

Depression—major depressive disorder (MDD). Our 2006 CER reported that atypicals were not more effective as augmentation to selective serotonin reuptake inhibitors than placebo at 8 weeks. However, in some trials they led to more rapid improvement (2 to 4 weeks).

Meta-analyses published in 2007 and 2009 found atypicals superior to placebo in increasing response and remission rates, and found no statistical difference between specific atypicals.

By 2011, new trials augmenting selective serotonin reuptake inhibitors/serotonin-norepinephrine reuptake inhibitors (SSRIs/SNRIs) with atypicals had been conducted and published. We conducted new meta-analyses that showed that several atypicals have efficacy in treatment of depression when used as augmentation and that quetiapine is effective as monotherapy.

In our pooled analysis, the relative risk of responding on Hamilton depression (HAM-D) scores for participants taking quetiapine (three PCTs) or risperidone (three PCTs) as augmentation was significantly higher than for those taking placebo.

Other trials reported the Montgomery-Asberg Depression Rating Score (MADRS); the relative risk of responding for participants taking aripiprazole (three PCTs) was significantly higher than for placebo. Risperidone was only included in one PCT that reported MADRS; the drug was statistically superior to placebo. One PCT of ziprasidone reported MADRS outcomes; results were statistically superior to placebo.

The three olanzapine PCTs (included in our original 2006 report) found the drug inefficacious as monotherapy for MDD. Since then, five trials of quetiapine monotherapy have been reported. We conducted a meta-analysis of these trials; the relative risk of remitting on the MADRS was statistically superior for quetiapine compared with placebo.

One trial found quetiapine superior to lithium to HAM-D and MADRS scores.

No head-to-head trials of atypicals for MDD were found.

Eating disorders. This off-label use was not included in our 2006 report.

Five trials of olanzapine were found; three reporting body mass index (BMI) outcomes could be pooled. There was no difference in BMI increase at 1e or 3 months between participants taking olanzapine and those taking placebo. One trial of quetiapine also reported no statistical difference in BMI increase at three months.

There were no trials of aripiprazole, risperidone, or ziprasidone for treatment of eating disorders.

Insomnia. This off-label use was not included in our 2006 report.

We found only one small trial of quetiapine for this use; difference in sleep outcomes was not statistically different from placebo.

Two observational studies of olanzapine and four of quetiapine found promising improvements in sleep quality and sleep onset.

No studies of aripiprazole, risperidone, or ziprasidone for insomnia were found.

Obsessive Compulsive Disorder (OCD). Our 2006 meta-analysis found atypicals had a clinically important benefit when used as augmentation to SSRIs.

Three published meta-analyses reported similar findings.

Our 2011 analysis of PCTs reporting Y-BOCS (Yale-Brown Obsessive Compulsive Scale) outcomes showed significant effects for risperidone (three PCTs) as augmentation in treatment of refractory patients. There were too few trials (two) to permit separate pooling for olanzapine; difference in effect versus placebo was statistically insignificant in both studies.

Two new trials found quetiapine superior to placebo as augmentation to citalopram according to Y-BOCS and Clinical Global Impression Scale - Improvement subscale (CGI-I) scores.

No trials of aripiprazole for OCD were found.

One new trial found quetiapine augmentation of an SSRI superior to augmentation with clomipramine.

One head-to-head trial found no difference in effect between olanzapine and risperidone as SSRI augmentation for OCD. Another head-to-head trial found quetiapine had greater efficacy than ziprasidone for this purpose.

Personality Disorders. Our 2006 CER found three trials of olanzapine and one of aripiprazole for borderline personality disorder (BPD); all reported efficacy of the drug.

Since the original CER was published, PCTs using atypicals for treatment of BPD have shown mixed results. Due to heterogeneity of outcomes, we could not perform a meta-analysis.

Overall, olanzapine had mixed results in seven trials, aripiprazole showed efficacy in two trials, quetiapine had efficacy in one trial, and ziprasidone was found inefficacious in one trial.

Risperidone had mixed results when used to treat schizotypal personality disorder in one small trial.

No head-to-head trials of atypicals for personality disorder were found.

Post-traumatic Stress Disorder (PTSD). Our 2006 CER reported on three PCTs of atypicals as augmentation for PTSD in male veterans and three PCTs as monotherapy in abused women. We had insufficient trials to conduct meta-analysis. The trials for combat-related PTSD had beneficial results, while the other trials had mixed results.

One published meta-analysis of risperidone and olanzapine studies found atypicals superior to placebo as measured by change in CAPS score. Results were not separated by drug.

Another review which included open label trials found small positive effects for risperidone and quetiapine compared with placebo.

In 2011, five PCTs were clinically similar enough to pool using the change in Clinician Administered PTSD Scale (CAPS) as outcome. Risperidone (four trials) was superior to placebo. The other trial found olanzapine superior to placebo.

We also found a trial that reported a 3-fold decline in CAPS scores in patients treated with quetiapine monotherapy compared with patients treated with placebo. (This study did not report exact scores, so could not be pooled.)

In our meta-analysis of risperidone treatment by trial length, pooled results from at least 12 weeks followup were not statistically different from those reported at less than 12 weeks.

In our meta-analysis by condition, atypicals showed efficacy in treatment of combat-related PTSD but not PTSD in abused women.

No trials of aripiprazole, or ziprasidone for PTSD were found.

No head-to-head trials of atypicals for PTSD were found.

Substance abuse. This off-label use was not included in our 2006 CER.

We found two PCTs of aripiprazole and one of quetiapine that reported the percent of alcohol abusers completely abstinent during followup period. In our pooled analysis, the drugs had insignificant efficacy compared with placebo.

We pooled two PCTs of olanzapine and one of risperidone in cocaine users. There was no difference in efficacy versus placebo as measured by change in Addiction Severity Index (ASI).

One PCT found aripiprazole inefficacious in reducing use of intravenous amphetamine, as measured by urinalysis. Another PCT found aripiprazole inefficacious in reducing craving for methamphetamine.

One PCT of methadone clients found no difference between risperidone and placebo in reduction of cocaine or heroin use.

One trial of aripiprazole versus naltrexone in alcohol abusers found no difference in either mean number of days abstinent or percentage of participants completely abstinent.

One trial augmenting naltrexone with quetiapine found no difference from placebo augmentation in any alcohol use outcomes.

One trial of risperidone versus pergolide found neither more efficacious than placebo in reducing cocaine use.

There were no head-to-head trials of atypicals for substance abuse.

Tourette's syndrome. No new trials of atypicals have been published since our 2006 CER reported that risperidone was superior to placebo in one small PCT, and it was at least as efficacious as pimozide or clonidine for 8 to 12 weeks of therapy in the three other trials. One PCT of ziprasidone showed variable efficacy compared with placebo.

#### Detailed Analysis

ADHD. This off-label use was not included in our 2006 systematic review. In 2011 we found no prior meta-analyses or systematic reviews on atypical antipsychotics for ADHD. There were four randomized controlled trials (RCTs); two reported on risperidone and two on aripiprazole. The trials lasted either 4 or 6 weeks. Sample sizes were small, ranging from 16 to 45 participants. Trial quality was adequate; the mean Jadad score was 3.5. We were unable to conduct a meta-analysis due to heterogeneity of the outcomes and populations. The studies are displayed in Table 3.

Table 3 Atypical antipsychotics for ADHD

Study/Type | Treatment | N | Dose/Duration | ADHD-Measures | Effects
Armenteros, 2007^77^/RCT | Risperidone vs Placebo | 25 | 1.08 mg (mean) + psychostimulant/ 4 weeks | CAS-P CAS-T | 100% of risperidone patients improved 30% over baseline in CAS-P compared with only 77% of placebo. No change in CAS-T
CorreiaFilho, 2005^78^/RCT | Risperidone vs methylphenidate (ADHD+Mental retardation) | 45 | 2.9 mg (mean)/ 4 weeks | SNAP-IV | Reduced ADHD symptoms in both per SNAP-IV, greater in risperidone than methylphenidate
Tramontina, 2009^79^/RCT | Aripiprazole vs. Placebo (ADHD+Bipolar) | 43 | 6 weeks | SNAP-IV | No difference in ADHD symptoms
Zeni, 2009^80^/RCT | Aripiprazole + methylphenidate or placebo (ADHD+Bipolar) | 16 | 2+2 week crossover | SNAP-IV | No improvement in ADHD symptoms

ADHD = attention-deficit hyperactivity disorder; CAS-P = Children's Aggression Scale-Parent Version; CAS-T = Children's Aggression Scale-Teacher Version; RCT = randomized controlled trial; SNAP-IV = Swanson, Nolan, and Pelham rating scale

One risperidone study showed that 100 percent of the patients “responded,” as defined by improving at least 30 percent on CAS-P. This compares WITH 77 percent of the placebo patients.77 The other risperidone study78 compared risperidone to methylphenidate in children and adolescents with both ADHD and moderate mental retardation. Using SNAP-IV, they found reduced ADHD symptoms with both treatments, with a greater reduction of symptoms with risperidone than methylphenidate. They also found adverse effects of weight gain with risperidone, whereas the other risperidone study had found no weight difference from placebo.78

The two studies of aripiprazole involved children with both ADHD and bipolar disorder. Neither showed a difference in ADHD symptoms per the SNAP-IV. One study looked at aripirazole versus placebo and listed adverse events of somnolence and sialorrhea.79 The other compared aripiprazole plus placebo versus aripiprazole plus methylphenidate and included the adverse effect of one patient experiencing a severe bipolar mixed episode while on aripiprazole and methylphenidate.80

Anxiety. Anxiety is also a new clinical topic not included in our 2006 review. We found two prior meta-analyses on use of atypicals for this condition.81 One combined OCD trials with trials for GAD; thus, we have excluded it. Another found quetiapine monotherapy significantly better than placebo for for treatment of generalized anxiety disorder.82

Our literature search identified 18 reports of trials that evaluated the use of olanzapine,83,84 quetiapine,85-95 risperidone,96-99 or ziprasidone100 for the treatment of anxiety. Jadad scores ranged from 2 to 5; mean score was 3.1. Sample sizes varied widely, from 7 to 873. Followup time ranged from same day (for public speaking anxiety) to 1 year. One trial had no placebo comparison group and is discussed under active controlled trials.96 Two trials assessed anxiety outcomes in bipolar patients92,97 so are considered beyond the scope of this report.

Of the remaining 15 PCTs, all but three83,89,95 reported an outcome measure based on the HAM-A. These three trials studied social anxiety. The first of these trials found olanzapine superior to placebo in the treatment of social anxiety disorder;83 the other two studied quetiapine and did not find it superior to placebo.89,95

The remaining 12 PCTs ranged from 6 to 18 weeks in duration. One small pilot of quetiapine augmentation of SSRI/venlafaxine versus placebo augmentation was not considered further for analysis due to heterogeneity. This study86 included patients with major depression and co-morbid anxiety.

Six remaining PCTs assessed quetiapine or quetiapine augmentation, two evaluated risperidone or risperidone augmentation,98,99 one assessed olanzapine84 and one studied ziprasidone.100 These trials either reported the mean score on the HAM-A or the percent of participants that responded to treatment as measured by the HAM-A. Since trials did not consistently report the information needed to calculate a weighted mean difference for pooling of the HAM-A total score, we used the number of participants that responded to treatment as the outcome to pool. The trials defined ‘responders’ as participants who decreased their HAM-A score by at least 50 percent.

The one ziprasidone PCT100 and two PCTs of quetiapine85,93 did not report the percent or count of participants that responded to treatment and thus could not be pooled. The first of these quetiapine trials used the drug as augmentation of paroxetine for the treatment of refractory generalized anxiety disorder. This study did not find a significant benefit for quetiapine over placebo augmentation.85 The second studied quetiapine monotherapy for maintenance treatment of generalized anxiety disorder and found a reduced risk of relapse of anxiety events compared with placebo.93 The ziprasidone PCT100 reported no difference in HAM-A score at 8 weeks, compared with placebo.

We separated the augmentation studies from studies of monotherapy. One small (N=20) study found quetiapine augmentation of SSRI resulted in more responders on the HAM-A than placebo augmentation (60 percent versus 30 percent) but this difference was not statistically significant.90 A similar larger study (N=409) found no statistical difference in HAM-A response rate at eight weeks.91 The remaining three trials of quetiapine monotherapy versus placebo listed in Table 4, were pooled.87,88,94 The trials were similar in size, ranging from 710 to 873 participants, and all had a quetiapine 150mg comparison group that was used in the analysis. The results are displayed in Figure 3, along with the olanzapine and risperidone PCTs. The pooled estimate of the relative risk of responding on the HAM-A was 1.26 (95% confidence interval [CI] 1.02, 1.56) in favor of the quetiapine groups. Resulting NNT (number needed to treat) is eight for one responder as measured by HAM-A. The I-squared statistic was 74.4 percent, indicating heterogeneity. Neither Begg's nor Egger's test for publication bias indicated the presence of bias (p=0.462, p=0.239, respectively).

Table 4 Generalized anxiety disorder—PCTs contributing to meta-analysis

Author, Year | Subjects | N | Treatments | Duration | Outcomes
Pollack et al. 2006^84^ | 18-72 years old, DSM-IV GAD comorbid depression, dysthymia, and other anxiety disorders except for PTSD and OCD, if GAD was considered primary by the clinician and patient based on disorder severity and associated distress | 24 | Placebo Olanzapine 2.5-20 mg/day | 6 weeks | % Responders on HAM-A: Olanzapine vs Placebo – RR = 6.67 (0.93, 47.59)
Bandelow et al. 2009^88^ | 18-65 years old, diagnosed GAD, HAM-A total score >= 20 with item 1 and 2 scores >= 2, MADRS total score <= 16, CGI-S score >=4 at enrolment and randomization | 873 | Placebo Quetiapine 50-150 mg/day Quetiapine 50 mg/day Paroxetine 20 mg/day | 8 weeks | % Responders on HAM-A: Quetiapine vs Placebo - RR = 1.36 (1.17, 1.59)
Joyce et al. 2008^94^ | Diagnosed GAD | 710 | Placebo Quetiapine 50 mg/day Quetiapine 150 mg/day | 8 weeks | % Responders on HAM-A: Quetiapine vs Placebo - RR = 1.02 (0.85, 1.21)
Merideth et al. 2008^87^ | DSM-IV diagnosis of GAD, HAM-A total score >=20 with item 1 and item 2 scores >=2, CGI-S >=4, MADRS <=16 | 854 | Placebo Escitalopram 10 mg/day Quetiapine 150 mg/day Quetiapine 300 mg/day | 8 weeks | % Responders on HAM-A: Quetiapine vs Placebo - RR = 1.46 (1.21, 1.76)
Pandina et al. 2007^99^ | 15-65 years old, diagnosed GAD, CGI-S >=4, antidepressant, benzodiazepine, buspirone or a combination of an antidepressants plus benzodiazepine or buspirone for at least 8 weeks prior and stable × 4 weeks | 417 | Placebo 0.25-2 mg/day Risperidone 0.25-2 mg/day | 4 weeks | % Responders on HAM-A: Risperidone vs Placebo - RR = 0.99 (0.78, 1.25)

CGI-S = Clinical Global Impression Scale-Severity Subscale; DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, 4th edition; GAD = generalized anxiety disorder; HAM-A = Hamilton Anxiety Rating Scale; MADRS = Montgomery-Asberg Depression Rating Scale; RR = relative risk

Figure 3 Anxiety % responders on Hamilton Anxiety Scale

Figure 3 is a forest plot depicting our meta-analysis of placebo controlled trials on generalized anxiety disorder. Three large trials of quetiapine 150 mg/day monotherapy were pooled. The pooled estimate of the relative risk of responding (defined as at least 50% improvement on the Hamilton Anxiety Scale [HAM-A]), was 1.26, and statistically significant. The figure also includes one placebo controlled trial of olanzapine and one of risperidone. Results of these two trials were not statistically significant.

Active Controlled Trials. An 8-week head-to-head trial of risperidone and paroxetine for panic attacks found statistically significant improvements in the HAM-A for both groups and no difference between treatment groups on several other anxiety measures.96

Two of the trials in our meta-analysis also had “active” arms. One trial found 50 or 150 mg/day quetiapine as effective at 8 weeks as paroxetine 20 mg/day, but with fewer sexual side effects.88 Another trial87 found 150 or 300 mg/day quetiapine as effective as 10 mg/day escitalopram at eight weeks.

Dementia. Our 2006 systematic review reported on two published meta-analyses assessing risperidone, quetiapine, and olanzapine for symptoms of dementia in the elderly,101,102 and one additional meta-analysis solely on risperidone.103 In summary, they found small but statistically significant effects for treatment with risperidone and aripiprazole, and trends toward efficacy of olanzapine and quetiapine. Since 2006, one new meta-analysis104 found no statistically or clinically significant difference between atypicals and placebo. In 2010, we were able to conduct new meta-analyses that included all trials from the previously published analyses plus several newer trials.

We reviewed 38 total trials on dementia. Twenty-seven trials compared an atypical to placebo: five aripiprazole,105-109 ten olanzapine,110-119 six quetiapine,119-124 and eight risperidone.115,116,119,125-129 One trial120 was later determined to be a duplicate report of a published article124 and thus excluded, leaving 37 trials total. Thirteen trials compared an atypical to another active drug.112,121,124,125,130-138 Two compared atypical in general to placebo.139,140 Four trials compared one atypical drug to another;116,119,141,142 two are also included in our PCT analyses. Two compared the continuation of an atypical to a cessation group.143,144 The quality of the trials varied widely, with Jadad scores ranging from zero to five; mean score was 3.0. Mean sample size was 242; range was 16 to 815. Most studies employed flexible dosing, as displayed in Figure 4 to 6. Followup times ranged from same day to 1 year.

Figure 4 Dementia placebo comparisons—total/global scores

Figure 4 is a forest plot depicting our meta-analysis on improvement in total /global scores in dementia. Three placebo controlled trials of aripiprazole were pooled, resulting in a statistically significant standardized effect size of .20. Four placebo controlled trials of olanzapine were pooled, resulting in a statistically significant standardized effect size of .12. Four placebo controlled trials of quetiapine were pooled, resulting in an effect size of .11; however, 95% confidence intervals were -.02 to 0.24, which is not quite statistically significant. Finally, six placebo controlled trials of risperidone were pooled, resulting in a statistically significant standardized effect size of .19.

Figure 5 Dementia placebo comparisons—psychosis

Figure 5 is a forest plot depicting our meta-analysis on improvement in psychosis in dementia. Three placebo controlled trials of aripiprazole were pooled, resulting in a standardized effect size of .20; however, 95% confidence intervals were -.02 to 0.42, which is not quite statistically significant. Five placebo controlled trials of olanzapine were pooled, results were not statistically significant. Three placebo controlled trials of quetiapine were pooled, results were not statistically significant. Finally, five placebo controlled trials of risperidone were pooled, resulting in a statistically significant standardized effect size of .20.

Figure 6 Dementia placebo comparisons—agitation

Figure 6 is a forest plot depicting our meta-analysis on improvement in agitation in dementia. Two placebo controlled trials of aripiprazole showed a statistically significant effect size of about .30 each. Four placebo controlled trials of olanzapine were pooled, resulting in a statistically significant effect size of .19. Five placebo controlled trials of quetiapine were pooled, results were not statistically significant. Finally, six placebo controlled trials of risperidone were pooled, resulting in a statistically significant standardized effect size of .22.

Seventeen PCTs reported outcomes between 6 and 12 weeks; this range was considered sufficiently clinically similar to pool. These PCTs are described in detail in Table 5. We grouped study outcomes into three categories: total/global scores, psychosis, and agitation.

Table 5 Dementia—PCTs contributing to meta-analyses

Author, Year | Subjects | N | Treatments | Duration | Outcomes
Breder et al. 2004^146^ | Psychosis/psychotic features, Nursing home resident, NPI or NPI/NH >= 6 sum of hallucinations and delusional items, Age 55-95, MMSE = 6-22 | 487 | Placebo Aripiprazole 5 mg/day Aripiprazole 2 mg/day Aripiprazole 10 mg/day | 10 weeks | Total/Global Scores: Aripiprazole vs. Placebo-SMD =0.15 (-0.06, 0.36) Psychosis score: Aripiprazole vs Placebo-SMD = 0.20 (-0.01, 0.41) Agitation score: Aripiprazole vs Placebo-SMD = 0.27 (0.05, 0.48)
DeDeyn et al. 2003^102^ | AD with psychosis | 208 | Placebo Aripiprazole 2–15 mg/day | 10 weeks | Total/Global Scores Aripiprazole vs Placebo - SMD =0.06 (-0.21, 0.34) Psychosis score: Aripiprazole vs Placebo-SMD = 0.16 (-0.12, 0.43)
Mintzer et al. 2007^107^ | Diagnosed with AD and delusions / hallucinations. Institutionalized, capable of self-locomotion, MMSE 6-22. NPI-NH score >=6 | 487 | Placebo Aripiprazole 2 mg/day Aripiprazole 5 mg/day Aripiprazole 5-10 mg/day | 10 weeks | Total/Global Scores Aripiprazole vs Placebo - SMD = 0.16 (-0.05, 0.37) Psychosis score: Aripiprazole vs Placebo-SMD =0.24 (0.03, 0.45) Agitation score: Aripiprazole vs Placebo-SMD = 0.31 (0.10, 0.52)
Streim et al. 2004^147^ Streim et al. 2008^108^ | AD with psychosis, Age 55-95, MMSE = 6-22, NPI or NPI/NH ≥ 6 sum of hallucinations and delusional items, hallucinations and delusions >=1 month | 256 | Placebo Aripiprazole 8.6 mg/day | 10 weeks | Total/Global Scores Aripiprazole vs Placebo - SMD =0.36 (0.11, 0.61) Psychosis score: Aripiprazole vs Placebo-SMD = -0.02 (-0.27, 0.23) Agitation score: Aripiprazole vs Placebo-SMD = 0.30 (0.05, 0.55)
DeDeyn et al. 2004^111^ | Age >= 40, Hospitalized/ institutionalized, Psychosis/psychotic features, MMSE = 5-26 | NR | Placebo Olanzapine 1.0 mg/day Olanzapine 2.5 mg/day Olanzapine 5.0 mg/day Olanzapine 7.5 mg/day | 10 weeks | Total/Global Scores Olanzapine vs Placebo - SMD = 0.14 (-0.05, 0.34) Psychosis score: Olanzapine vs Placebo-SMD = 0.17 (-0.02, 0.37) Agitation score: Olanzapine vs Placebo-SMD =0.14 (-0.05, 0.33)
Deberdt et al. 2004^116^ | Age >= 40, AD, vascular or mixed dementia, NPI or NPI/NH >= 6 sum of hallucinations and delusional items | 494 | Placebo Olanzapine 5.2 mg Risperidone 1.0 mg | 10 weeks | Total/Global Scores Olanzapine vs Placebo - SMD = -0.02(-0.27, 0.23) Total/Global Scores Risperidone vs Placebo - SMD =-0.13 (-0.38, 0.12) Psychosis score: Olanzapine vs Placebo-SMD =-0.12 (-0.36, 0.13) Risperidone vs Placebo-SMD =-0.03 (-0.34, 0.16) Agitation score: Olanzapine vs Placebo-SMD =0.09 (-0.16, 0.34) Risperidone vs Placebo-SMD =0.14 (-0.11, 0.39)
Kennedy et al. 2005^118^ | Age ≥ 40, MMSE 14-26 | 268 | Placebo Olanzapine 2.5-7.5 mg/day | 26 weeks | Psychosis score: Olanzapine vs Placebo-SMD =-0.07 (0.33, 0.18)
Schneider, et al. 2006^148^ Sultzer et al. 2008^119^ | AD or probable AD, MMSE 5-26, psychosis, aggression, or agitation previous week or at least intermittently for 4 weeks, had a severity rating of at least “moderate” for conceptual disorganization, suspiciousness, or hallucinatory behavior on (BPRS), ambulatory and living at home or in an assisted-living facility | 421 | Placebo Olanzapine 5.5mg/day Quetiapine 56.5 mg/day Risperidone 1.0 mg/day | 12 weeks | Total/Global Scores Olanzapine vs Placebo - SMD =0.15 (-0.11, 0.40) Quetiapine vs Placebo - SMD = 0.15 (-0.11, 0.40) Risperidone vs Placebo - SMD =0.40 (0.13, 0.68) Psychosis score: Olanzapine vs Placebo-SMD =0.07 (-0.19, 033) Quetiapine vs Placebo- SMD =0.16 (-0.10, 0.42) Risperidone vs Placebo- SMD =0.38 (0.11, 0.66) Agitation score: Olanzapine vs Placebo- SMD =0.28 (0.02, 0.53) Quetiapine vs Placebo- SMD =0.20 (-0.06, 0.46) Risperidone vs Placebo- SMD =0.10 (-0.17, 0.37)
Street et al. 2000^110^ | Possible or probable AD, NPI/NH ≥ 3 | 206 | Placebo Olanzapine 5 mg/day Olanzapine 10 mg/day Olanzapine 15 mg/day | 6 weeks | Total/Global Scores Olanzapine vs Placebo - SMD = 0.30 (-0.03, 0.63) Psychosis score: Olanzapine vs Placebo- SMD =0.17 (-0.17, 0.50) Agitation score at 9 weeks: Olanzapine vs Placebo- SMD =0.39 (0.05, 0.72)
Ballard et al. 2005^121^ | CMAI >= 39,Age >= 60, NPI >= 4 | 93 | Placebo Rivastigmine min 9 mg/day Quetiapine 100 mg/day | 26 weeks | Agitation score: Quetiapine vs Placebo- SMD =-0.13 (-0.66, 0.39)
Paleacu et al. 2008^123^ | AD with BPSD, age > 50, MMSE < 24, NPI > 6 on any item | 40 | Placebo Quetiapine 50-300 mg/day | 6 weeks | Agitation score: Quetiapine vs Placebo- SMD =-0.48 (-1.11, 0.15)
Tariot et al. 2006^124^ | Diagnosed with DSM-IV AD, > 64 years old, not bedridden, nursing home residents for >= 2 weeks, presence of psychosis, BPRS scores >=24, CGI-S scores >=4, scores of >= 3 on two or more BPRS items, frequency scores of >= 3 on at least one of the two psychosis items of the NPI-NH, scores of >= 5 on MMSE | 284 | Placebo Haloperidol 0.5-12 mg/day Quetiapine 25-600 mg/day | 10 weeks | Total/Global Scores Quetiapine vs Placebo - SMD =0.22 (-0.07, 0.28) Agitation score: Quetiapine vs Placebo- SMD =0.24 (-0.05, 0.54) Psychosis score: Quetiapine vs. Placebo – SMD = 0.00 (-0.29, 0.30)
Zhong et al. 2004^149^ Zhong et al. 2007^122^ | Institutionalized, diagnosed possible AD or vascular dementia, age >= 55, ambulatory, agitation that didn't result directly from participants medical condition, PANSS-EC total >= 14, one of the 5 PANSS-EC items >= 4. | 333 | Placebo Quetiapine 100 mg/day Quetiapine 200 mg/day | 10 weeks | Total/Global Scores Quetiapine vs Placebo - SMD =0.04 (-0.21, 0.28) Psychosis score: Quetiapine vs Placebo - SMD =-0.03 (-0.27, 0.21) Agitation score: Quetiapine vs Placebo - SMD =-0.03 (-0.27, 0.21)
Brodaty et al. 2003^126^ Brodaty et al. 2005^150^ | Age >= 55, FAST > = 4,MMSE< = 23, CMAI score of >= 4 on at least 1 aggressive item or a score of 3 on at least 2 aggressive items, or a score of 2 on at least 3 aggressive items, or 2 aggressive items occurring at a frequency of 2 and 1 at a frequency of 3, Nursing home resident, Resident >= 1 month prior to enrollment | 345 | Placebo 1.06 mg/day Risperidone 0.95 mg/day | 12 weeks | Total/Global Scores Risperidone vs Placebo - SMD = 0.46 (0.23, 0.69) Psychosis score: Risperidone vs Placebo- SMD =0.36 (0.13, 0.59) Agitation score: Risperidone vs Placebo- SMD =0.37 (0.14, 0.59)
Dedeyn et al. 1999^125^ | Age >= 55, Hospitalized/institutionalized, FAST >= 4, MMSE <= 23, BEHAVE-AD behavior pathology > 1, BEHAVE-AD >= 8 | 344 | Placebo Haloperidol 1.2 mg/day Risperidone 1.1 mg/day | 12 weeks | Total/Global Scores Risperidone vs Placebo - SMD =0.12 (-0.14, 0.38) Agitation score: Risperidone vs Placebo- SMD =0.31 (0.05, 0.57)
Katz et al. 1999^127^ | Age >= 55, FAST >= 4, MMSE <= 23, BEHAVE-AD >= 8, BEHAVE-AD global rating >= 1 | 625 | Placebo Risperidone 0.5 mg/day Risperidone 1 mg/day Risperidone 2 mg/day | 12 weeks | Total/Global Scores Risperidone vs Placebo - SMD = 0.32 (0.11, 0.53) Psychosis score: Risperidone vs Placebo- SMD =0.20 (-0.01, 0.41) Agitation score: Risperidone vs Placebo- SMD =0.38 (0.17, 0.60)
Mintzer et al. 2006^129^ | >= 55 years old, residents of nursing homes or long-term care facilities, mobile, met the criteria for psychosis of AD, in need of treatment with an atypical antipsychotic, scored >=2 on any item of the BEHAVE-AD psychosis subscale, MMSE 5-23 | 473 | Placebo Risperidone 0.5-2.5 mg/day | 8 weeks | Total/Global Scores: Risperidone vs Placebo - SMD =-0.01 (-0.21, 0.18) Psychosis score: Risperidone vs Placebo- SMD =0.17 (-0.02, 0.36) Agitation score: Risperidone vs Placebo- SMD =0.04 (-0.16, 0.23)

AD = Alzheimer's disease; BEHAVE-AD = Behavioral Pathology in Alzheimer's Disease Scale; BPRS = Brief Psychiatric Rating Scale; BPSD = Behavioral and Psychological Symptoms of Dementia; DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, 4^th^ edition; FAST = ; MMSE = Mini Mental Status Exam; PANSS-EC = Positive and Negative Syndrome Scale-Excited Component; SMD = standardized mean difference

Total global score includes psychiatric symptoms of delusions, suspiciousness, dysphoria, anxiety, motor agitation, agression, hostility, euphoria, disinhibition, irritability and apathy, as measured by the NPI. Psychosis was measured by subscales of the Behavioral Pathology in Alzheimer's Disease Rating Scale (BEHAVE-AD), BPRS, and NPI, which focus primarily on delusions and hallucinations. Agitation was measured by subscales of the BEHAVE-AD, BPRS, NPI, and Cohen-Mansfield Agitation Inventory, and included the symptoms physical aggression, verbal aggression, excitability, oppositional behaviors, and excessive motor ability.

Several PCTs contained more than one treatment arm; these studies compared different doses of atypicals. For our main efficacy analyses, we pooled these arms together and present one resulting intervention outcome for each trial. This was most often done for aripiprazole trials that included a 2, 5, and 10 mg arm. We present the results by dosage later in the relevant section (Key Question 5).

There was a positive, significant difference between the atypicals as a class and placebo for all three outcome measures: total/global scores (standardized mean difference [SMD] 0.17 [95% CI 0.08, 0.25]), psychosis (SMD 0.12 [95% CI 0.04, 0.19]), and agitation (SMD 0.20 [95% CI 0.12, 0.27]). While the minimum clinically important difference is not known, these effect sizes are generally considered “small” in magnitude. The I-squared values indicated moderate heterogeneity (range 30.3 percent–53.1 percent). Results are displayed in Figures 4 to 6.

For aripiprazole, olanzapine, and risperidone, the pooled estimate of effect on the total/global score was statistically significant, with an effect size of between 0.12 and 0.20. The pooled estimate of effect for quetiapine was similar (0.13) but this was not statistically different from zero. This effect size is “small.” Corroborating this conclusion is the observation that the mean difference in the pooled NPI total score between treatment and placebo was 3.41 points, which is close to the minimum clinically observable change of 4 points.145 Individual studies suggested that higher dose of aripiprazole (10mg/day)107 or risperidone (2mg/day)127 were possibly more effective than lower doses, although these findings have not been replicated, dose effects are not addressed in many trials, and dose-response trends across studies are inconsistent. Only the pooled analysis for risperidone had substantial heterogeneity (I-squared = 74.6 percent). There was no evidence of publication bias. Only risperidone had enough studies to conduct a sensitivity analysis based on quality; no difference was found. For treatment of psychosis, results favored risperidone when compared with placebo. As measured by the psychosis subscale of the NPI, pooled estimate of SMD in effect size was 0.20 (95% CI 0.05, 0.36) for risperidone (five trials). Results for aripiprazole (three trials), olanzapine (five trials), and quetiapine (three trials) did not meet conventional levels of statistical significance. Standardized mean difference for aripiprazole was 0.14 (95% CI -0.02, 0.29), for olanzapine was 0.05 (95% CI -0.07, 0.17) and for quetiapine 0.04 (95% CI -0.11, 0.18).

Pooled estimates of SMD in effect size for agitation were 0.19 (95% CI 0.07, 0.31) for olanzapine (four trials), and 0.22 (95% CI 0.09, 0.35) for risperidone (six trials); once again these trials are generally considered “small” effects. Two trials of aripripazole reported positive results. Results for quetiapine (five studies) were not significant.

Active Controlled Trials. We conducted a meta-analysis by pooling five trials that compared atypicals to haloperidol on total score.124,125,132,133,136 Information from these trials is displayed in Table 6. Difference between atypicals and haloperidol was not significant. There were too few trials to pool results separately by drug. Regarding psychosis symptoms, we found one trial which showed no difference in efficacy between olanzapine and haloperidol. Results are displayed in Figures 7 and 8. We also found one trial of risperidone versus olanzapine138 for dementia. Differences in total/global score and agitation score were not statistically significant.

Table 6 Dementia atypical versus haloperidol—PCTs contributing to analysis

Author, Year | Subjects | N | Treatments | Duration | Outcomes
Moretti et al. 2005^132^ | DSM-IV for dementia, MMSE>=14, probable VaD, 71-92 | 256 | Typical antipsychotics 10 drops/day Olanzapine 2.5-7.5 mg/day | 12 months | Total/Global score: Olanzapine vs Haloperidol – SMD = 0.38 (0.17, 0.60)
Verhey et al. 2006^136^ | Age >= 60 years, diagnosis of dementia according to DSM-IV, agitation level requiring antipsychotic treatment, no use of antipsychotic treatment within 3 days of inclusion CMAI score >=45 | NR | Haloperidol 1-3 mg/day Olanzapine 2.5-7.5 mg/day | 5 weeks | Total/Global score: Olanzapine vs Haloperidol – SMD = -0.18 (-0.77, 0.41) Agitation score: Olanzapine vs Haloperidol – SMD = -0.21 (-0.73, 0.31)
Savaskan et al. 2006^133^ | AD, behavioral symptoms > 65 | NR | Haloperidol 0.5-4 mg/day Quetiapine 25-200 mg/day | 5 weeks | Total/Global score: Quetiapine vs Haloperidol – SMD = 0.99 (0.10, 1.88) Agitation score: Quetiapine vs Haloperidol – SMD = 0.06 (-0.78, 0.89)
Tariot et al. 2006^124^ | > 64 years old, not bedridden, nursing home residents for >= 2 weeks, diagnosed with DSM-IV AD, presence of psychosis, BPRS scores >=24, CGI-S scores >=4, scores of >= 3 on two or more BPRS items, frequency scores of >= 3 on at least one of the two psychosis items of the NPI-NH, scores of >= 5 on MMSE | 284 | Placebo Haloperidol 0.5-12 mg/day Quetiapine 25-600 mg/day | 10 weeks | Total/Global score: Quetiapine vs Haloperidol – SMD = 0.16 (-0.16, 0.47) Agitation score: Quetiapine vs Haloperidol – SMD = 0.04 (-0.26, 0.34)
Dedeyn et al. 1999^125^ | Age >= 55, Hospitalized/institutionalized, FAST >= 4, MMSE <= 23, BEHAVE-AD behavior pathology > 1, BEHAVE-AD >= 8 | 344 | Placebo Haloperidol 1.2 mg/day Risperidone 1.1 mg/day | 12 weeks | Total/Global score: Risperidone vs Haloperidol – SMD = -0.19 (-0.45,0.07) Agitation score: Risperidone vs Haloperidol – SMD = -0.07 (-0.19,-0.33)

AD = Alzheimer's disease; BEHAVE-AD = Behavioral Pathology in Alzheimer's Disease Rating Scale; BPRS = Brief Psychiatric Rating Scale; CGI-S = Clinical Global Impression Scale - Severity Subscale; CMAI = Cohen-Mansfield Agitation Inventory; DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, 4th edition; FAST = Functional Assessment Staging scale; MMSE = Mini Mental Status Exam; NPI-NH = Neuropsychiatric Inventory, Nursing Home; NR = not reported; SMD = standardized mean difference

Figure 7 Dementia: atypical versus haloperidol—total/global scores

Figure 7 is a forest plot depicting our meta-analysis on improvement in total/global scores in dementia for trials of any atypical antipsychotic versus haloperidol, a conventional antipsychotic. Two trials of 2.5 to 7.5 mg/day of olanzapine had conflicting results. One had a significant effect of 0.38 for olanzapine, while the other had statistically insignificant results. Regarding quetiapine, one trial found quetiapine statistically superior to haloperidol, while the other found the opposite. One trial of risperidone versus haloperidol found statically insignificant results.

Figure 8 Dementia: atypical versus haloperidol—agitation

Figure 8 is a forest plot depicting our meta-analysis on improvement in agitation in dementia for trials of any atypical antipsychotic versus haloperidol, a conventional antipsychotic. One trial of 2.5 to 7.5 mg/day of olanzapine showed no statistical difference between the two drugs. Two trials of quetiapine, one using 25 to 200 mg/day and the other using 25 to 600 mg/day, showed no statistical difference between the drugs. One trial of 1.1 mg/day risperidone versus haloperidol found statically insignificant results.

Head-to-head Trials. Three head-to-head trials, described in Table 7, compared atypicals on total/global scores and psychosis outcomes.116,119,142 None was found superior. Results are displayed in Figures 9 to 11.

Table 7 Dementia head-to-head studies contributing to analysis

Author, Year | Subjects | N | Treatments | Duration | Outcomes
Deberdt et al. 2004^116^ | Age >= 40, AD, vascular or mixed dementia, NPI or NPI/NH >= 6 sum of hallucinations and delusional items | 494 | Placebo Olanzapine-5.2 mg Risperidone-1.0 mg | 10 weeks | Total/Global score: Olanzapine vs Risperidone-SMD = 0.10 (-0.10, 0.30) Psychosis score: Olanzapine vs Risperidone-SMD = -0.03 (-0.23, 0.17) Agitation score: Olanzapine vs Risperidone-SMD = -0.04 (-0.24, 0.16)
Schneider, et al. 2006^148^ Sultzer et al. 2008^119^ | AD or probable AD, MMSE 5-26, psychosis, aggression, or agitation previous week or at least intermittently for 4 weeks, had a severity rating of at least “moderate” for conceptual disorganization, suspiciousness, or hallucinatory behavior on (BPRS), ambulatory and living at home or in an assisted-living facility | 421 | Placebo Olanzapine 5.5mg/day Quetiapine 56.5 mg/day Risperidone 1.0 mg/day | 12 weeks | Total/Global score: Olanzapine vs Risperidone-SMD = -0.27 (-0.56, 0.02) Quetiapine vs Risperidone-SMD = -0.24 (-0.53, 0.06) Psychosis score: Olanzapine vs Risperidone-SMD = -0.27 (-0.56, 0.02) Quetiapine vs Risperidone-SMD = -0.24 (-0.54, 0.05) Agitation score: Olanzapine vs Risperidone-SMD = -0.17 (-0.12, 0.16) Quetiapine vs Risperidone-SMD = 0.10 (-0.20, 0.39)
Rainer et al. 2007^142^ | 55-85 years old, dementia, MMSE score 10-26, have an NPI part I score in sub-items relating to delusions, hallucinations, agitation / aggression | 72 | Quetiapine 50-400 mg/day Risperidone 0.5-4 mg/day | 8 weeks | Total/Global score: Quetiapine vs Risperidone-SMD = -0.06 (-0.55, 0.43) Agitation score: Quetiapine vs Risperidone-SMD = -0.17 (-0.66, 0.32)

AD = Alzheimer's disease; BPRS = Brief Psychiatric Rating Scale; MMSE = ; NPI = Neuropsychiatric Inventory; SMD = standardized mean difference

Figure 9 Dementia head-to-head studies olanzapine or quetapine versus risperidone—total/global scores

Figure 9 is a forest plot depicting improvement in total/global scores in dementia in trials of one atypical antipsychotic versus another atypical. One study of olanzapine versus risperidone showed no statistical difference in this outcome. One study of quetiapine versus risperidone also showed no statistical difference. The federally-funded CATIE-AD trial reported a trend toward superiority of risperidone over olanzapine and quetiapine, but this did not meet traditionally accepted levels of statistically significance.

Figure 10 Head-to-head studies: olanzapine or quetapine versus risperidone—psychosis

Figure 10 is a forest plot depicting on improvement in psychosis in dementia in trials of one atypical antipsychotic versus another atypical. One study of olanzapine versus risperidone showed no statistical difference in outcome. The federally-funded CATIE-AD trial reported a trend toward superiority of risperidone over olanzapine and quetiapine, but this did not meet traditionally accepted levels of statistically significance.

Figure 11 Dementia head-to-head studies: olanzapine or quetapine versus risperidone—agitation

Figure 11 is a forest plot depicting improvement in agitation in dementia in trials of one atypical antipsychotic versus another atypical. One study of olanzapine versus risperidone showed no statistical difference in outcome. Another study of quetiapine versus risperidone showed no statistical difference in outcome. The federally-funded CATIE-AD trial showed no statistical difference between olanzapine, quetiapine, and risperidone for this outcome.

Depression. This section focuses on MDD; we excluded other types of depression, including bipolar depression or depression with psychotic features. For MDD, our 2006 CER reported that atypicals were not superior to placebo as augmentation to SSRIs at 8 weeks. However, in some trials they led to more rapid improvement (2 to 4 weeks). Since then, Papakostas published a meta-analysis on MDD in 2007^151^ and updated it in 2009.^152^ Both versions found atypicals superior to placebo in increasing response and remission rates, and found no statistical difference between the specific atypicals. Both versions included olanzapine, risperidone, and quetiapine; the most recent version added aripiprazole.

Our literature search identified 26 new studies of atypical antipsychotics as monotherapy or augmentation for MDD published since our original CER, 18 of which were not in the prior systematic reviews. Quality of trials ranged from 1 to 5 on the Jadad scale; mean score was 2.7. Sample sizes were usually large, with the mean close to 200. Followup times ranged from 4 weeks to 1 year.

The majority of the trials studied augmentaition of SSRIs in treatment refractory patients: four of these were PCTs of aripiprazole,153-156 seven were PCTs of quetiapine,86,157-162 and five were PCTs of risperidone.163-167 One quetiapine PCT augmented treatment with cognitive behavioral therapy (CBT).158 The results of this trial were suggestive of an added benefit of quetiapine over placebo. However, it was not considered for further analysis as it was deemed to be insufficiently clinically similar to the other studies. There were also six PCTs of quetiapine extended release (ER) as monotherapy.168-173 Four other trials were not placebo controlled174-177 and thus could not be included in our pooled analyses. They will be discussed later under “active controlled trials.”

Outcomes consistently reported in the PCTs included the HAM-D total score, percent responders and percent remitted, and the MADRS total score, percent responders and percent remitted. Several trials reported both HAM-D and MADRS outcomes.156,161,162,165,168,169,171,172. Since the information needed to calculate an effect size for the mean MADRS and HAM-D total scores was not consistently reported, we pooled the percent responded and remitted on each scale. The patient populations were reviewed by a psychiatrist to determine level of severity, age, comorbid illness and other factors to verify that these populations were similar enough to pool. The outcomes were measured between 4 and 8 weeks, considered sufficiently clinically similar to pool. Several PCTs contained more than one treatment arm; these studies compared the effects of different doses of atypicals. For our main efficacy analyses, we pooled these arms together and present one resulting intervention outcome per trial. We present the results by dosage later in the relevant section (Key Question 5).

Three trials only reported continuous outcomes, thus they were not included in pooled analyses, which used binary outcomes (e.g., percent responding or percent remitted).153,164,173 The first of these studied risperidone augmentation of antidepressant medication and found a significant decrease in suicidal ideation with risperidone versus placebo.164 The second compared quetiapine monotherapy with placebo and found that quetiapine significantly increased the time to a depressed event, compared with placebo.173 The third compared aripiprazole augmentation of an antidepressant to placebo augmentation. They reported a significantly greater change in MADRS total score in those receiving aripiprazole.153 Additionally, one study did not report outcome data by arm, only overall, so was not included in pooled analysis.163 In that study, risperidone augmentation of antidepressant therapy was reported to result in symptomatic remission in a substantial number of patients with chronic resistant depression, compared with placebo.

We conducted six meta-analyses with data from the remaining PCTs:

- Percent remitted on the HAM-D, augmentation.
- Percent responded on the HAM-D, augmentation.
- Percent remitted on the MADRS, augmentation.
- Percent responded on the MADRS, augmentation.
- Percent remitted on the MADRS, monotherapy.
- Percent responded on the MADRS, monotherapy.

HAM-D meta-analyses, augmentation trials. A person was considered remitted if their HAM-D score was less than or equal to 7 (on the HAM-D 17) or a less than or equal to 8 (on the HAM-D 24) for two consecutive visits. Two trials (from one article178) from our 2006 systematic review reported percent responded and percent remitted on the HAM-D; we include them in the current meta-analyses. The eight total trials that reported the number of participants classified as remitters using the HAM-D ranged in duration from 4 to 8 weeks.86,157,161,165-167,178 As displayed in Table 8, the size of these trials ranged from 34 to 274 patients. Only quetiapine and risperidone had a sufficient number of studies to pool estimate of effect by drug. As displayed in Figure 12, the random effects pooled estimate of the relative risk of remitting on the HAM-D for those treated with quetiapine versus placebo was 2.76 (95% CI 1.21, 6.28), and for those taking risperidone was 2.10 (95% CI 1.43, 3.09). This is equivalent to a NNT (number needed to treat) of five for quetiapine and eight for risperidone.

Table 8 Depression—placebo-controlled augmentation trials contributing to HAM-D meta-analysis

Author, Year | Subjects | N | Augmentation | Duration | Outcomes
Rothschild et al. 2004^178^ | MDD, Age ≥ 18, HAM-D ≥ 20 | 124 | Placebo Olanzapine 5-20 mg/day | 8 weeks | HAM-D % Remitted: Olanzapine vs Placebo – RR=1.45 (0.42, 5.07) HAM-D % Responded: Olanzapine vs Placebo – RR= 1.25 (0.68, 2.28)
Rothschild et al. 2004^178^ | MDD, Age ≥ 18, HAM-D ≥ 20 | 125 | Placebo Olanzapine 5-20 mg/day | 8 weeks | HAM-D % Remitted: Olanzapine vs Placebo – RR= 1.09 (0.40, 3.00) HAM-D % Responded: Olanzapine vs Placebo – RR= 1.14 (0.64, 2.02)
Mattingly et al. 2006^161^ | Outpatients aged 18-65 years old, a primary diagnosis of MDD who were not psychotic, baseline HAM-D 17 >= 20 following a >= 6 weeks SSRI or SNRI treatment, HAM-D item I score >= 2 had failed >= 1 r-week trial of clinically appropriate dose of another antidepressant | 40 | Placebo Quetiapine 200-400 mg/day | 8 weeks | HAM-D % Remitted: Quetiapine vs Placebo – RR = 2.83 (0.73, 10.98) HAM-D % Responded: Quetiapine vs Placebo – RR = 2.12 (0.89, 5.05)
McIntyre et al. 2007^86^ | 18-65, MDD, HAM-D 17 >= 18, CGI-S >=4, HAM-A >= 14, treated with single SSRI/venlafaxine at a therapeutic dose >= 6 weeks | 58 | Placebo Quetiapine 50-600 mg/day | 8 weeks | HAM-D % Remitted: Quetiapine vs Placebo – RR = 1.78 (0.53, 5.97) HAM-D % Responded: Quetiapine vs Placebo – RR = 2.00 (0.76, 5.26)
Zheng et al. 2007^157^ | Diagnosed with MDD without psychotic symptoms, HAM-D score >= 18, BPRS item 4 score <= 4, item 11 score <=3, had been treated unsuccessfully with >= 2 different types of antidepressants for >= 6 weeks | NR | Placebo Quetiapine 50-200 mg/day | 4 weeks | HAM-D % Remitted: Quetiapine vs Placebo – RR = 8.44 (1.17, 60.94) HAM-D % Responded: Quetiapine vs Placebo – RR = 2.90 (1.13, 7.47)
Gharabawi et al. 2006^167^ | Adult outpatients with DSM-IV MDD, had an incomplete response to >= 8 weeks of antidepressant treatment | 274 | Placebo Risperidone 0.25-2 mg/day | 6 weeks | HAM-D % Remitted: Risperidone vs Placebo – RR = 2.03 (1.10, 3.75) HAM-D % Responded: Risperidone vs Placebo – RR = 1.44 (1.03, 2.01)
Keitner et al. 2009^165^ | Depressed, failed current antidepressant trial. MADRS >=15, 18-65 | 97 | Placebo Risperidone 0.5-3 mg/day | 4 weeks | HAM-D % Remitted: Risperidone vs Placebo – RR = 1.95 (0.88, 4.33) HAM-D % Responded: Risperidone vs Placebo – RR = 1.49 (0.83, 2.68)
Mahmoud et al. 2007^166^ | 18-65, antidepressant monotherapy >= 4 weeks, MDD, CGI-S >=4 | 274 | Placebo Risperidone 0.25-2 mg/day | 6 weeks | HAM-D % Remitted: Risperidone vs Placebo – RR = 2.29 (1.22, 4.30) HAM-D % Responded: Risperidone vs Placebo – RR = 1.57 (1.20, 1.87)

BPRS = Brief Psychiatric Rating Scale; CGI-S = Clinical Global Impression-Severity; HAM-A = Hamilton Anxiety Scale; HAM-D = Hamilton Depression Rating Scale; MADRS = Montgomery-Asberg Depression Rating Scale; MDD = major depressive disorder; RR = relative risk; SSRI = selective serotonin reuptake inhibitor

Figure 12 Depression—HAM-D % remitted, augmention

Figure 12 is a forest plot depicting our meta-analysis on the percent of patients achieving “remission” as measured by the Hamilton depression scale (HAM-D), for depression augmentation studies. Two placebo controlled trials of 5 to 20 mg/ day olanzapine augmentation by the same authors had statistically insignificant results. Three placebo controlled trials of augmentation with quetiapine at various doses showed a statistically significant pooled estimate of the relative risk of remission of 1.76. Three placebo controlled trials of augmentation with risperidone at various doses showed a statistically significant pooled estimate of the relative risk of remission of 2.10.

Responders on the HAM-D were identified in the same eight trials. A responder was defined as someone who had at least a 50 percent reduction in HAM-D score from randomization to followup. We were only able to calculate a pooled estimate of effect for quetiapine and risperidone, as olanzapine had only two trials. As displayed in Figure 13, the random effects pooled estimate of the relative risk of responding on the HAM-D for participants taking quetiapine compared with placebo was 2.30 (95% CI 1.35, 3.92), while for risperidone it was 1.50 (95% CI 1.20, 1.87). This is equivalent to an NNT of three for quetiapine and seven for risperidone. The overall I-squared statistic for these eight trials indicated no heterogeneity (0.0 percent). Neither Begg's nor Egger's test were statistically significant (p=0.711,p=0.245, respectively).

Figure 13 Depression—HAM-D % responded, augmentation

Figure 13 is a forest plot depicting our meta-analysis on the percent of patients achieving “response” as measured by the Hamilton depression scale (HAM-D), for depression augmentation studies. Two placebo controlled trials of 5 to 20 mg/ day olanzapine augmentation by the same authors had statistically insignificant results. Three placebo controlled trials of augmentation with quetiapine at various doses showed a statistically significant pooled estimate of the relative risk of response of 2.30. Three placebo controlled augmentation trials of risperidone at various doses showed a statistically significant pooled estimate of the relative risk of response of 1.50.

MADRS meta-analyses, augmentation trials. On the MADRS scale, the definition of a remitted participant differed slightly between trials. A person was considered remitted if their MADRS score was from 8 to 10, depending on the study. The seven trials that reported the number of participants classified as remitters ranged in duration from 4 to 8 weeks.154-156,159,160,162,165 As displayed in Table 9, the size of these trials ranged from 97 to 493. Only aripiprazole and quetiapine had a sufficient number of studies to report the pooled estimate of effect per drug. As displayed in Figure 14, the random effects pooled estimate of the relative risk of remitting on the MADRS for those treated with aripiprazole versus placebo was 1.57 (95% CI 1.24, 2.00); for those taking quetiapine it was 1.24 (95% CI 0.82, 1.88). The I-squared statistics for these two analyses were 0 and 82.8, respectively. Begg's test approached significance (p = .072) and Egger's test was significant (p = .018) indicating possible publication bias.

Table 9 Depression—placebo-controlled augmentation trials contributing to MADRS meta-analysis

Author, Year | Subjects | N | Augmentation | Duration | Outcomes
Berman et al. 2007^155^ | Diagnosed MDD >=8 weeks, inadequate response to antidepressant, (<50% reduction in depressive symptoms severity), HAM-D-17 >=18 | 362 | Placebo Aripiprazole 2-20 mg/day | 6 weeks | MADRS % Remitted: Aripiprazole vs Placebo - RR =1.65 (1.08, 2.53) MADRS % Responded: Aripiprazole vs Placebo – RR = 1.41 (1.01, 1.98)
Berman et al. 2009^156^ | 18-65 years old, diagnosed major depressive episode >= 8weeks, inadequate response to previous antidepressants | 349 | Placebo Aripiprazole 2-20 mg/day | 8 weeks | MADRS %: Aripiprazole vs Placebo - RR = 1.43 (0.96, 2.12) MADRS % Responded: Aripiprazole vs Placebo – RR = 1.75 (1.30, 2.35)
Marcus et al. 2008^154^ | 18-65 years old, major depressive episode > = 8weeks, inadequate response to previous antidepressants | 382 | Placebo Aripiprazole 2-20 mg/day | 6 weeks | MADRS % Remitted: Aripiprazole vs Placebo - RR = 1.67 (1.10, 2.54) MADRS % Responded: Aripiprazole vs Placebo – RR = 1.86 (1.37, 2.01)
Bauer et al. 2009^162^ | 18-65 yrs old, diagnosed MDD, outpatients, HAM-D total score >= 20. HAM-D item I score >= 2, inadequate response during current episode to antidepressants. | 493 | Placebo Quetiapine 50-150 mg/day Quetiapine 50-300 mg/day | 6 weeks | MADRS % Remitted: Quetiapine vs Placebo - RR = 1.42 (1.03, 1.94) MADRS % Responded: Quetiapine vs Placebo – RR = 1.22 (1.01, 1.48)
El-Khalili,2010^159^ | 18-65 years old, DSM-IV diagnosis of MDD, confirmed by MINI, have been on treatment with an antidepressant >=6 weeks, HAM-D total score >= 20, HAM-D item 1 score >= 2 at both enrollment and randomization. | 446 | Placebo Quetiapine 50-150 mg/day Quetiapine 50-300 mg/day | 6 weeks | MADRS % Remitted: Quetiapine vs Placebo – RR = 1.58 (1.15, 2.19) MADRS % Responded: Quetiapine vs Placebo – RR = 1.20 (0.98, 1.47)
Garakani et al. 2008^160^ | 18-65 years old, diagnosis of unipolar major depression without psychotic features, MADRS score > 15 at both screen and baseline | 114 | Placebo 25-100 mg/day Quetiapine 25-100 mg/day | 8 weeks | MADRS % Remitted: Quetiapine vs Placebo – RR = 0.87 (0.67, 1.13)
Keitner et al. 2009^165^ | Depressed, failed current antidepressant trial. MADRS >=15, 18-65 | 97 | Placebo Risperidone 0.5-3 mg/day | 4 weeks | MADRS % Remitted: Risperidone vs Placebo - RR = 2.13 (1.11, 4.08) MADRS % Responded: Risperidone vs Placebo - RR = 1.65 (0.97, 2.80)

HAM-D = Hamilton Depression Rating Scale; MADRS = Montgomery-Asberg Depression Rating Scale; MDD = major depressive disorder; RR = relative risk

Figure 14 Depression—MADRS % remitted, augmentation

Figure 14 is a forest plot depicting our meta-analysis on the percent of patients achieving “remission” as measured by the MADRS instrument, for depression augmentation studies. Three placebo controlled trials of augmentation with aripiprazole showed a statistically significant pooled estimate of the relative risk of remission of 1.57. Three placebo controlled trials of augmentation with quetiapine showed statistical insignificant results. One placebo controlled trial of augmentation with risperidone showed a statistically significant estimate of 2.13 for the relative risk of remitting.

Responders on the MADRS were identified in all but one trial160 that reported remitters. A responder was defined as someone who had at least a 50 percent reduction in MADRS score from randomization to followup. We were able to calculate a pooled estimate of effect for aripiprazole, which had three trials. Quetiapine was included in two trials, while risperidone was included in only one. As displayed in Figure 15, the random effects pooled estimate of the relative risk of responding on the MADRS for those participants taking aripiprazole compared with placebo was 1.66 (95% CI 1.37, 2.01); for an NNT of seven. The I-squared statistic for this analysis was 0.0. Begg's test was not significant (p = 0.260), while Egger's test approached significance (p = .069).

Figure 15 Depression—MADRS % responded, augmentation

Figure 15 is a forest plot depicting our meta-analysis on the percent of patients achieving “response” as measured by the MADRS instrument, for depression augmentation studies. Three placebo controlled trials of augmentation with aripiprazole showed a statistically significant pooled estimate of the relative risk of response of 1.66. There were two trials of augmentation with quetiapine that had a relative risk of responding of about 1.2, one of which was a statistically significant result. One trial of augmentation with risperidone did not result in a statistically significant estimate of relative risk of responding.

MADRS meta-analyses, monotherapy trials. The five monotherapy trials for MDD ranged in length from 6 to 9 weeks.168-172 The number of enrollees ranged from 310 to 723; all studied quetiapine and reported both on both remitters and responders. Details of the studies are displayed in Table 10. As displayed in Figure 16, the random effects pooled estimate of remitting on the MADRS for those treated with quetiapine versus placebo was 1.43 (95% CI 1.07, 191). Begg's and Egger's tests were not statistically significant (p = 0.86, p = .142, respectively). Figure 17 presents the results using percent of patients responding. Quetiapine patients were significantly more likely to respond (OR 1.49, 95 percent CI 1.23, 1.81) than placebo patients. Begg's and Egger's test were both statistically significant (p = .027 each) indicating the possibility of publication bias. The I-squared statistic for each analysis was 70.7 percent and 72 percent respectively.

Table 10 Placebo-controlled monotherapy trials contributing to MADRS meta-analyses

Author, Year | Subjects | N | Augmentation | Duration | Outcomes
AstraZeneca 2007^168^ | 18-65 years old, DSM-IV diagnosis of MDD, HAM-D score >=22, HAM-D item 1 score >=2 | 471 | Placebo Quetiapine 50-300 mg/day Escitalopram 10-20 mg/day | 9 weeks | MADRS % Remitted: Quetiapine vs Placebo - RR = 1.01 (0.75, 1.37) MADRS % Responded: Quetiapine vs Placebo – RR = 1.18 (0.97, 1.45)
AstraZeneca 2008^169^ | Age >=66, DSM-IV diagnosis of MDD confirmed by MINI. HAM-D total score >=22, HAM-D item 1 score >=2 at both enrollment and randomization. | 338 | Placebo 50-300 mg/day Quetiapine 50-300 mg/day | 9 weeks | MADRS % Remitted: Quetiapine vs Placebo - RR = 2.48 (1.70, 3.62) MADRS % Responded: Quetiapine vs Placebo - RR = 2.11 (1.63, 2.71)
Bortnick, 2011^170^ | 18 -65 years old, MDD confirmed by the MINI and DSM-IV, have a HAM-D >= 22, HAM-D item1 score >= 2 at both enrollment and randomization | 310 | Placebo 50-300 mg/day Quetiapine 50-300 mg/day | 8 weeks | MADRS % Remitted: Quetiapine vs Placebo - RR = 1.39 (0.97, 1.98) MADRS % Responded: Quetiapine vs Placebo - RR = 1.29 (1.05, 1.59)
Cutler et al. 2009^171^ | 18-65 years old, diagnosed MDD, HAM-D total score >=22, HAM-D item 1 score >=>= at enrollment and randomization | 612 | Placebo Quetiapine 50-150 mg/day Quetiapine 50-300 mg/day Duloxetine 60 mg/day | 6 weeks | MADRS % Remitted: Quetiapine vs Placebo - RR = 1.43 (1.03, 2.06) MADRS % Responded: Quetiapine vs Placebo - RR = 1.51 (1.20, 1.91)
Weisler et al. 2009^172^ | 18-65, output, MDD, HAM-D item 17>=22, HAM-D item 1>=2 | 723 | Placebo Quetiapine 50 mg/day Quetiapine 50-150 mg/day Quetiapine 50-300 mg/day | 6 weeks | MADRS % Remitted: Quetiapine vs Placebo - RR = 1.27 (0.89, 1.82) MADRS % Responded: Quetiapine vs Placebo – RR = 1.58 (1.24, 2.02)

DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, 4th editon; HAM-D = Hamilton Depression Rating Scale; MADRS = Montgomery-Asberg Depression Rating Scale; MDD = major depressive disorder

Figure 16 Depression—MADRS % remitted, monotherapy

Figure 16 is a forest plot depicting our meta-analysis on percent of patients achieving “remission” as measured by the MADRS instrument, for depression monotherapy studies. Five placebo controlled monotherapy studies of quetiapine were pooled, resulting in a statistically significant pooled estimate of relative risk of responding of 1.43.

Figure 17 Depression—MADRS % responded, monotherapy

Figure 17 is a forest plot depicting our meta-analysis on the likelihood of “response,” as measured by the MADRS instrument, for depression monotherapy studies. Five placebo controlled monotherapy studies of quetiapine were pooled, resulting in a statistically significant pooled estimate of relative risk of response of 1.49.

Active Controlled Trials. There were four active controlled trials of atypicals for the treatment of MDD. One study included two parallel 8-week double-blind trials comparing treatment with a combination of olanzapine and fluoxetine versus olanzapine alone versus fluoxetine alone.174 The authors report that the pooled results of the two studies found significant differences in mean change of MADRS scores for the olanzapine/fluoxetine combination, compared with either fluoxetine or olanzapine alone. Another trial evaluated quetiapine versus lithium for 56 days and found greater improvement with quetiapine, according to HAM-D, MADRS, and Wildlocher Psychomotor Retardation Scales scores.175 An 8-week trial compared zisprasidone at differing levels augmenting sertraline to sertraline alone.176 This trial found a greater improvement in CGI-S and MADRS scores augmenting with ziprasidone at 160mg than either augmentation with ziprasidone at 80mg or sertraline alone. However, there was no significant difference in HAM-D 17, CGI-I, or HAM-A scores. The final non –placebo-controlled trial compared quetiapine as augmentation of paroxetine or venlafaxine to venlafaxine or paroxetine alone.177 This 12-week trial found an improvement in HAMD-17 scores for all groups, with the quetiapine- paroxetine combination showing the greatest improvement, followed by the quetiapine-venlafaxine combination, then paroxetine only and finally venlafaxine only.

Head-to-Head Trials. No trials comparing specific atypical antipsychotics for MDD were found.

Eating Disorder. This off-label use was not included in our 2006 systematic review. We found one systematic review on this topic; it included RCTs, observational studies, and case reports.179 The review found evidence of improvement in psychological symptoms, but not in weight gain. Our literature search identified five trials that assessed olanzapine for this use180-184 and one of quetiapine.185 Mean quality score was 2.0 on the Jadad scale. Trials ranged in length from 2 to 3 months. Sample sizes were small, with 15 to 45 participants, per trial. All of the RCTs were placebo controlled except for one small head-to-head trial that compared olanzapine to a conventional antipsychotic, chlorpromazine,181 in which the olanzapine group had a significant reduction in anorexic rumination. This trial was excluded from quantitative analysis, which included only placebo comparisons.

Four of five remaining studies reported BMI at times between 1 and 13 weeks. One study that only reported weight gain per week was excluded from further analysis.184 In that study, there were no differences in weight gain by whether they were treated with olanzapine.

The sample size of the four remaining trials ranged from 20 to 34. These trials were deemed clinically similar to justify meta-analysis at 1 and 3 months; their results are displayed in Table 11.^180,182,183,185^ (BMI is measured such that the desired effect is an increase.)

Table 11 Eating disorder—PCTs contributing to meta-analysis

Author, Year | Subjects | N | Treatments | Duration | Outcomes
Bissada et al. 2008^180^ | DSM-IV criteria for anorexia nervosa (restricting or binge / purge subtype) including a body index <= 17.5 kg/m2 | 34 | Placebo Olanzapine 2.5-10 mg/day | 10 weeks | Change in BMI at 4 weeks: Olanzapine vs. Placebo– WMD = 0.11 (-0.77, 0.99) Change in BMI at 12 weeks: Olanzapine vs. Placebo - WMD = 0.15 (-0.80, 1.10)
Brambilla et al. 2007^182^ | Anorexia nervosa per DSM-IV, restricted or binging-purging type | 30 | Placebo Olanzapine 2.5-5 mg/day | 12 weeks | Change in BMI at 4 weeks: Olanzapine vs. Placebo - WMD = -0.00 (-0.91, 0.91) Change in BMI at 12 weeks: Olanzapine vs. Placebo - WMD = 0.60 (-0.55, 1.75)
Brambilla et al. 2007^183^ | Anorexia nervosa according to DSM-IV | 20 | Placebo Olanzapine 2.5-5 mg | 12 weeks | Change in BMI at 4 weeks: Olanzapine vs. Placebo - WMD = -0.20 (-1.44, 1.04) Change in BMI at 12 weeks: Olanzapine vs. Placebo - WMD = 0.20 (-1.05, 1.45)
Court,2010^185^ | Anorexia nevosa per DSM-IV | 27 | Placebo Quetiapine 100-400mg/day | 12 weeks | Change in BMI at 12 weeks: Quetiapine vs. Placebo - WMD = -0.10 (-1.74, 1.54)

BMI = body mass index; DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, 4th edition; WMD = weighted mean difference

The random effects pooled weighted mean difference in BMI from baseline to 1 month of treatment with olanzapine was .004 (95% CI -0.56, 0.57). At 3 months the random effects pooled estimate was 0.25 (95% CI -0.34, 0.84) (Figure 18). The I-squared statistic for each time point indicated low heterogeneity. Neither Begg's or Egger's test for publication bias were statistically significant at either time point (1 month p=0.30, p=0.21 respectively; 3 months p=0.73, p=0.68 respectively).

Figure 18 Eating disorders—BMI

Figure 18 is a forest plot depicting our meta-analysis on improvement in eating disorders, as measured by increase in Body Mass Index (BMI). Three studies of olanzapine measured BMI at one and three months. The pooled effect sizes for the three olanzapine studies at one and three months were not statistically significant. One study of quetiapine also showed insignificant results.

Active Controlled Trials. There were no active controlled trials of atypicals for eating disorders.

Head-to-Head Trials. There were no head-to-head trials of atypicals for eating disorder.

Insomnia. This off-label use was not included in our 2006 CER. We found no meta-analyses or systematic reviews on the use of atypical antipsychotics for insomnia treatment. We found only one small RCT conducted in Thailand. Although the quetiapine group increased total sleep time by 125 minutes, compared with an increase of 72 minutes in the placebo group, the difference was not statistically significant, due to small sample size (N=13). Because of the paucity of information on this use, we describe six observational studies identified in our literature search; two utilized olanzapine while four utilized quetiapine. Study characteristics are displayed in Table 12 and 13.

Table 12 Atypical antipsychotics for insomnia, observational studies—olanzapine

Study/Type | Insomnia Type | N | Dosage/Duration | Measures | Effects/AEs
Estivill, 2004^187^ Case series | Unspecified | 9 | 2.5mg-10mg/ Up to 3 years | Polysomnogram (8/9) | Improved sleep latency (3), feeling of good sleep (2), total sleep time (3). Decreased nightmares (1). Unspecified improvement (3). No improvement (1)
Sharpley, 2005^186^ Open label | Insomnia in major depressive disorder unresponsive to SSRI treatment | 12 | 2.5-10mg (mean 4.8mg)/ 3 weeks | Polysomnogram | Improved sleep efficiency, subjective sleep quality, slow wave sleep

AE = adverse effect; SSRI = selective serotonin reuptake inhibitor

Table 13 Atypical antipsychotics for insomnia, observational studies—quetiapine

Study/Type | Insomnia Type | N | Dosage/Duration | Measures | Effects/AEs
Juri, 2005^191^ Case series | Insomnia of Parkinson's Disease | 14 | 12.5-50mg (mean 31.9mg)/ Up to 3 months | Pittsburgh Sleep Quality Inventory, Epworth Sleep Scale | All aspects of sleep improved, greatest improvement in sleep onset, daytime sleepiness improved
Pasquini, 2009^190^ Case series | Tamoxifen-related insomnia | 6 | 25-100mg/ 6 weeks | Insomnia Severity Index- Italian version | “prompt improvement”
Teran, 2008^189^ Chart review | Insomnia as main symptom of withdrawal syndrome | 52 | 25-225mg (mean 50mg)/ Up to 60 days | Speigal Sleep Questionnaire | “greatest improvements in overall quality of sleep and time to falling asleep
Wiegand, 2008^188^ Open label pilot study | Primary insomnia | 18 | 25-75mg/ 6 weeks | Polysomnogram, PSQI | Improved total sleep time and sleep efficiency

AE = adverse effect

One olanzapine study treated 12 patients with insomnia related to major depressive disorder for three weeks. These patients experienced improvements in sleep efficiency, subjective sleep quality and slow wave sleep.186 The other olanzapine study included case reports of nine patients with different sleep disorders followed for up to 3 years. Eight patients experienced improvements in sleep including sleep latency, total sleep time, decreased nightmares and unspecified improvements.187 In both studies, the dosages ranged from 2.5mg to 10mg each night and measurements were done both subjectively and per polysomnogram.

Quetiapine was used to treat insomnia of various causes including: primary insomnia,188 insomnia of drug withdrawal,189 tamoxifen- related insomnia190 and insomnia of Parkinson's disease.191 The dosages ranged from 12.5mg to 225mg each night, and the patients were treated from 6 weeks to 3 months. Sleep was measured both objectively using a polysomnogram188 and subjectively using the Pittsburgh Sleep Quality Inventory,188,191 the Italian version of the Insomnia Severity Index Scale,190 Speigal Sleep Questionnaire,189 and the Epworth Sleep Scale.191 All studies showed improvements in sleep including total sleep time, sleep efficiency,188 overall quality of sleep,189 all aspects of sleep,191 and unspecified improvements.190 Of note, one study did not show an improvement in sleep latency188 while two others did.189,191

Obsessive-Compulsive Disorder. Our 2006 CER concluded that atypicals have a clinically meaningful benefit when used as augmentation therapy in patients with OCD. That report included a meta-analysis we conducted using the Yale-Brown Obsessive Compulsive Scale (Y-BOCS) as outcome; both quetiapine and risperidone augmentation increased the odds of response, when compared with augmentation with placebo. (At that time, there were too few trials of olanzapine to permit pooling.) Three other meta-analyses assessing atypical antipsychotics as augmentation for treatment-resistant OCD patients were published around the time of our first evidence report. Two192,193 included trials of risperidone, quetiapine, and olanzapine. They both found the atypicals have efficacy in increasing the number of responders on the Y-BOCS. Risperidone was statistically significant, while quetiapine and olanzapine had a trend toward efficacy that was not statistically significant. The other meta-analysis included only quetiapine; the authors pooled two trials and found the drug superior to placebo, as measured by changed in total Y-BOCS score.194

Our literature search identified eight reports of trials published after our 2006 CER.195-202 Trials were relatively small compared with trials for dementia, anxiety, and depression; sample sizes ranged from 18 to 66. Four were controlled trials of an atypical antipsychotic versus another drug, with no placebo group. These will be discussed below in the section on active controlled and head to head trials.

The other five trials reported on PCTs of augmentation. These trials ranged in duration from 8 to 12 weeks and measured the change in Y-BOCS as the primary outcome measure. Three evaluated the treatment of OCD with quetiapine plus citalopram or placebo plus citalopram,199,201,202 in patients with OCD who were currently not taking any pharmacotherapy. All three of these studies are related and may in fact be from one trial: they are from the same group of authors using nearly identical protocols, and two studies report on 76 patients while one study reports on 82 patients. These papers report that in treatment-naïve patients quetiapine augmentation was superior to placebo according to improvement in both Y-BOCS and CGI-I scores. The final two studies evaluated quetiapine plus serotonin reuptake inhibitor (SRI) or placebo plus SRI treatment.196,197 One of these reported duplicate data to an already-included study203 and was therefore excluded from our pooled analysis.

These final two new RCTs that evaluated quetiapine augmentation versus placebo196,197 along with four RCTs identified in our original report that evaluated the same treatment,204-206 two from the original report that evaluated olanzapine augmentation versus placebo,207,208 and three from the original report that assessed risperidone augmentation versus placebo209-211 were deemed sufficiently clinically similar to justify meta-analysis. These trials are displayed in Table 14.

Table 14 OCD—PCTs contributing to meta-analysis

Author, Year | Subjects | N | Treatments | Duration | Outcomes
Bystritsky et al., 2004^207^ | Age 18-65, OCD | 26 | Placebo-16.9 mg/day Olanzapine-11.2 mg/day | 6 weeks | Responders improving 25-35% on Y-BOCS: Olanzapine vs Placebo-RR = 13.00 (0.81, 209.42)
Shapira et al. 2004^208^ | Age 14-70, 1 year duration primary OCD, CGI >= moderate severity, Y-BOCS >= 19 | 44 | Placebo-5.9 mg/day Olanzapine-6.1 mg/day | 6 weeks | Responders improving 25-35% on Y-BOCS: Olanzapine vs Placebo-RR = 1.00 (0.49, 2.03)
Atmaca et al. 2002^204^ | Y-BOCS >= 18, OCD, CGI-I minimal improvement | 27 | Placebo Quetiapine-91.1 mg/day | 8 weeks | Responders improving 25-35% on Y-BOCS: Quetiapine vs Placebo- RR = 19.60 (1.26, 304.14)
Carey et al. 2005^205^ | Age 18-65, Y-BOCS < 25% improvement > 12 wks of SRI treatment at maximum tolerated dose, CGI-I minimal improvement, CGI = worse | 42 | Placebo - 228.57 mg/day Quetiapine - 168.75 mg/day | 6 weeks | Responders improving 25-35% on Y-BOCS: Quetiapine vs Placebo- RR = 0.84 (0.42, 1.69)
Denys et al. 2004^203^ | Age 18-65, Y-BOCS >= 18, Y-BOCS >=12, if only obsessions or compulsions were present, Refractory to SRI therapy | 40 | Placebo Quetiapine-150 mg/day | 8 weeks | Responders improving 25-35% on Y-BOCS: Quetiapine vs Placebo-RR = 4.00 (0.97, 16.55)
Fineberg et al. 2005^206^ | Y-BOCS < 25% improvement > 12 wks of SRI treatment at maximum tolerated dose, Y-BOCS >=18 | 21 | Placebo Quetiapine - 215 mg/day | 16 weeks (12 week outcome pooled) | Responders improving 25-35% on Y-BOCS: Quetiapine vs Placebo-RR = 2.73 (0.34, 22.16)
Kordon et al. 2008^197^ | Aged 18-65, diagnosis of OCD, Y-BOCS >= 18, treated with an SRI >= 12 weeks and non-responders (< 25% improvement in Y-BOCS) | 40 | Placebo 100-600 mg/day Quetiapine 100-600 mg/day | 12 weeks | Responders improving 25-35% on Y-BOCS: Quetiapine vs Placebo-RR = 2.11 (0.61, 7.24)
Erzegovesi et al. 2005^209^ | Age 18-65, 1 year duration primary condition, Drug-free within 3 weeks, Drug-free for at least 3 wks prior to study entry | 45 | Placebo Risperidone-0.5 mg/day | 6 weeks | Responders improving 25-35% on Y-BOCS: Risperidone vs Placebo-RR = 2.50 (0.63, 10.00)
Hollander et al. 2003^210^ | CGI >= 3,SRI therapy >= 12 weeks, >=2 SRI trials of adequate dose and duration | 16 | Placebo 2.75 mg/day Risperidone 2.25 mg/day | 8 weeks | Responders improving 25-35% on Y-BOCS: Risperidone vs Placebo-RR = 5.73 (0.36, 90.83)
McDougle et al. 2000^211^ | 1 year duration primary OCD, CGI >= moderate severity, Refractory to SRI therapy | 36 | Placebo Risperidone-2.2 mg/day | 6 weeks | Responders improving 25-35% on Y-BOCS: Risperidone vs Placebo-RR = 3.92 (1.26, 12.13)

CGI-I = Clinical Global Impression Scale-Improvement Subscale; OCD = obsessive-compulsive disorder; RR = relative risk; SRI = serotonin reuptake inhibitor; Y-BOCS = Yale-Brown Obsessive-Compulsive Scale

These 10 trials used the Y-BOCS as the primary outcome, classifying “responders” as those achieving a 25 to 35 percent improvement on the Y-BOCS total score. The sample sizes ranged from 16 to 45. The outcome “responders” on the Y-BOCS was measured at 6 to 12 weeks. A few PCTs204,207,210 reported very wide confidence intervals; these trials were published earlier (2002 to 2004) than the rest.

The meta-analysis results are displayed in Figure 19. There were enough studies to calculate a pooled estimate of relative risk for risperidone and quetiapine. The relative risk of “responding” on the Y-BOCS for those in the quetiapine augmentation arm versus those in the placebo arm was 2.36 (95% CI 0.85, 6.57). The relative risk of “responding” on the Y-BOCS for those in the risperidone augmentation arm was 3.92 (95% CI 1.27, 12.13). This results in an NNT (number needed to treat) of four for quetiapine and five for risperidone. The I-squared statistic was 56.1 percent, indicating some heterogeneity. Both Begg's and Eggar's test indicated the possibility of publication bias (p=0.002,p=0.002 respectively).

Figure 19 OCD—responders improving 25–35% on Y-BOCS

Figure 19 is a forest plot depicting our meta-analysis on percent of patients achieving “response,” defined as at least 25% to 35% improvement on the Yale–Brown Obsessive Compulsive Scale (Y-BOCS). Two placebo controlled trials evaluated the use of olanzapine as augmentation to treat OCD and neither found a statistically significant effect. Five placebo controlled trials of quetiapine augmentation were pooled, results were not significant. Three placebo controlled trials of augmentation with risperidone were pooled, resulting in a statistically significant pooled estimate of the relative risk of responding of 3.92.

Active Controlled Trials. One trial compared an atypical antipsychotic plus SSRI plus CBT to SSRI alone plus CBT for the treatment of OCD.198 These receiving the atypical were treatment resistant and therefore sicker than the other group, but did have a mean reduction in Y-BOCS of 10 points. Another trial evaluated quetiapine plus an SSRI compared with clomipramine plus an SSRI.200 Quetiapine augmentation produced a significant reduction in the Y-BOCS score, while clomipramine augmentation did not.

Head-to-Head Trials. One trial evaluated the treatment of OCD with olanzapine versus risperidone;195 it found no statistically significant differences between treatment groups. Another trial evaluated the treatment of OCD with quetiapine versus ziprasidone both adjunctive with an SRI.212 This trial reported a 80 percent improvement in Y-BOCS score for the quetiapine group and a 44.4 percent improvement for the ziprasidone group.

Personality Disorder. Our 2006 CER found promising results for this off-label use. Three PCTs of olanzapine and one of aripiprazole reported efficacy compared with placebo. Since 2006, several additional trials have been published showing mixed results. These studies are displayed in Table 15.

Table 15 PCTs for personality disorder

Study/Type | Disorder/ Treatment | N | Dosage/Duration | Measures | Effects/AEs
Nickel, 2006^218^/ RCT | Borderline PD/ aripiprazole | 52 | 15mg/ 8 weeks | SCL-90-R, HAM-D, HAM-A, STAXI | Significant changes on most scales of SCL-90-R, HAM-D, HAM-A and all scales of STAXI/
Nickel, 2007^219^/ Follow-up observation of RCT above | Borderline PD/ aripiprazole | 52 | 15mg / 18 months | SCL-90-R, HAM-D, HAM-A, STAXI | Greater changes on all SCL-90-R scores, less self-injury
Pascual, 2008^222^/ RCT | Borderline PD/ ziprasidone | 60 | 40-200mg (mean 84.1mg)/ 12 weeks | CGI-BPD, HAM-D-17, HAM-A, BPRS, SCL-90-R, Barratt Impulsiveness scale, Buss-Durkee Inventory | No significant difference in CGI-BPD, depressive, anxiety, psychotic or impulsive symptoms
Schulz, 2008^223^/ RCT | Borderline PD/ olanzapine | 314 | 2.5-10mg (mean 7.09mg)/ 12 weeks | ZAN-BPD, SCL-90-R, GAF, SDS, OAS-M, MADRS | No significant difference from placebo
Linehan, 2008^224^/ RCT | Borderline PD/ olanzapine | 24 | 2.5-15mg (mean 4.46mg) + DBT therapy/ 6 months | OAS-M, TMR, HAM-D, Somatic Symptom Scale | No significant difference from placebo
Zanarini, 2007^220^/ RCT of dose response. | Borderline PD/ olanzapine | 451 (150 @2.5m148@ 5-10mg) | 2.5-10mg/ 12 weeks | ZAN-BPD | Greater change in ZAN-BPD with 5-10mg of olanzapine
VanDenBroek,2008^221^/ RCT | Borderline PD (psychotic symptoms)/ quetiapine | 24 | 200-600mg/ 8 weeks | BPRS, PANSS, DIS-Q | Superior to placebo on BPRS, PANSS
McClure, 2009^227^/ RCT | Schizotypal PD (cognitive symptoms)/ risperidone | 31 | 0.25-2mg/ 10 weeks | Cognitive assessment battery | No significant difference from placebo

BPRS = Brief Psychiatric Rating Scale; CGI-BPD = Clinical Global Impression Scale-Borderline Personality Disorder; DIS-Q = Dissociation Questionnaires; GAF = Global Assessment of Functioning Scale; HAM-A = Hamilton Anxiety Rating Scale; HAM-D = Hamilton Depression Rating Scale; MADRS = Montgomery-Asberg Depression Rating Scale; OAS-M = Overt Aggression Scale-Modified; PANSS = Positive and Negative Symptom Scale; PD = personality disorder; RCT = randomized controlled trial; SCL-90-R = Symptom Checklist 90-revised; SDS = Sheehan Disability Scale; STAXI = State-Trait Anger Expression Inventory; TMR = therapist monitoring record; ZAN-BPD = Zanarini Rating Scale for Borderline Personality Disorder

In 2010, a meta-analysis on the efficacy of antipsychotics in treatment of personality disorders213 was published. It included three studies of olanzapine214-216 and one each of risperidone217 and aripiprazole.218 It also included several studies of conventional antipsychotics, and pooled all the antipsychotics together, without separating out the effects of atypicals. Therefore, we will not report the results of this analysis.

Borderline Personality Disorder (BPD). Since our initial CER, eight placebo-controlled trials of personality disorders have been published; seven were on BPD. Four of these studies showed an improvement with treatment. Two of these studies involved the same population of patients, first reporting after 8 weeks of treatment and then again after 18 months. In those studies, aripiprazole was the treatment used.218,219

Another study showed improvement when 5–10mg olanzapine was used each day but no change from placebo when 2.5mg was used.220 A study reporting only the psychotic symptoms associated with BPD found an improvement with quetiapine.221

Of note, the three studies that did not show an improvement used ziprasidone or olanzapine and, though there was no difference in response from placebo, both groups of patients in each study showed improvement overall with the treated patients showing a faster time to response.222-224 Studies were too heterogeneous to perform meta-analyses.

Active Controlled Trials. One small RCT of olanzapine versus haloperidol for borderline personality disorders in female inpatients,225 reported patients in both groups improved considerably regarding hostility, depressive mood, and anxiety. However, differences between groups were not statistically significant.

Observational Study. Our search found only one small pilot study of paliperidone for off-label conditions.226 Although it is a very small observational study, we include here due to lack of any other relevant data on this drug.

There were eight patients with borderline personality disorder and no other current interfering psychiatric disorder such as psychotic disorders, bipolar disorder, cognitive disorder, major depression or substance abuse. The patients were given paliperidone ER for 12 weeks in a dose of 3–6mg per day. Of the six patients who completed the study, the publication lists that paliperidone was efficacious in reducing global symptoms and “a few core symptoms” of borderline personality disorder. However, there is no specific data regarding these results. There were reports of adverse effects including extrapyramidal symptoms (EPS), insomnia, and agitation, and two patients dropped out of the study, one for noncompliance and the other for gastrointestinal adverse effects.

Schizotypal Personality Disorder. One study measured cognitive symptoms in schizotypal personality disorder and found no significant difference from placebo in those treated with risperidone.227

Post Traumatic Stress Disorder(PTSD). Our 2006 CER found six PCTs of atypicals for PTSD. Due to heterogeneity, we could not conduct meta-analysis. Trials for combat-related PTSD reported benefits, while trials in abused woman reported mixed results.

Two systematic reviews on use of atypical antipsychotics as monotherapy or medication augmentation for patients with PTSD228,229 were published after our original evidence report. One included five studies of risperidone230-234 and two studies of olanzapine.235,236 It found that atypicals have benefit (compared with placebo) as measured by the change in CAPS score. The publication did not report separate results by drug or clinical subtype. Another review229 included 10 double-blind RCTs and eight open-label trials. Small positive effects were found for risperidone and quetiapine. Results for olanzapine were mixed.

Our literature search identified three new placebo-controlled trials that assessed risperidone for the treatment of PTSD233,237,238 and two of quetiapine.239,240 Combined with the studies included in the original CER, there were eight studies of risperidone230-234,237,238,241 two studies of olanzapine235,236 and two for quetiapine239,240 for PTSD. Trials were small, ranging from 15 to 94 participants. Quality scores ranged from two to four on the Jadad scale.

Two trials identified in the new literature search reported on the same trials we included in our previous report.233,238 We selected the most current article to include in our new CER.233,234 This left 10 trials varying in duration from 5 to 16 weeks. All but two of these trials measured the CAPS. One that did not utilize the CAPS studied showed no difference in improvement between the olanzapine and placebo group.236 The other found risperidone superior to placebo in reducing irritability and intrusive thought symptoms of PTSD.232 One risperidone PCT233 reported that the treated population showed a significant difference in the CAPS score at endpoint, compared with placebo, but did not report the exact numbers. Similarly, one study reported a 3-fold decline in CAPS scores in patients treated with quetiapine monotherapy compared with placebo.239 This study did not report exact scores, so could not be pooled in our meta-analysis. Another study found quetiapine/setraline combination superior to setraline plus placebo according to decrease in CAPS score from baseline to 8 weeks.240

Thus, the five remaining PCTs, which were clinically comparable, were pooled in our meta-analyses.230,231,234,235,237 The trials are displayed on Table 16. The sample sizes ranged from 19 to 65, while the duration ranged from 5 to 16 weeks, with three trials reporting results at eight weeks. Risperidone dose ranged from 0.5mg to 3mg daily. The one trial of olanzapine used 15mg daily dose.

Table 16 PTSD—PCTs contributing to meta-analyses

Author, Year | Subjects | N | Treatments | Duration | Outcomes
Stein et al. 2002^235^ | PTSD diagnosis, Refractory to SRI therapy | 19 | Placebo 20.00 mg/day Olanzapine 15.00 mg/day | 8 weeks | Difference in CAPS score: Olanzapine vs. Placebo –WMD = 12.13 (0.97, 23.29)
Bartzokis et al. 2005^230^ | Proof of military service, CAPS ≥ 65 | 65 | Placebo Risperidone 3 mg/day | 16 weeks | Difference in CAPS score: Risperidone vs. Placebo – WMD = 9.70 (1.01, 18.39)
Hamner et al. 2003^234^ | Age >= 18, Psychosis/psychotic features, PANSS >= 60, PANSS with score ≥ 4 on at least 1 item on positive symptoms subscale | 40 | Placebo Risperidone-2.5 mg/day | 5 weeks | Difference in CAPS score: Risperidone vs. Placebo – WMD = -1.10 (-14.37, 12.17)
Reich et al. 2004^231^ | CAPS-1 >= 50, PTSD related to childhood physical, sexual, emotional or verbal abuse, | 21 | Placebo Risperidone-1.41 mg/day | 8 weeks | Difference in CAPS score: Risperidone vs. Placebo – WMD = 11.00 (-8.55, 30.55)
Rothbaum et al. 2008^237^ | 18-65, PTSD due to civilian trauma, CAPS >=50 | 25 | Placebo Risperidone 0.5-3 mg/day | 8 weeks | Difference in CAPS: Risperidone vs. Placebo – WMD = 4.08 (-10.17, 18.34)

CAPS = Clinician-Administered PTSD Scale; PANSS = Positive and Negative Symptom Scale; PTSD = post-traumatic stress disorder; SRI = serotonin reuptake inhibitor; WMD = weighted mean difference

The similar outcome across these five trials was the CAPS total score. A lower CAPS score indicates fewer PTSD symptoms. Thus, we calculated a weighted mean difference for each study and a positive weighted mean difference means an improvement in CAPS total score from baseline to follow up.

We stratified our analyses first by drug (Figure 20). Only risperidone had enough eligible studies to calculate a pooled estimate.230,231,234,237 The random effects pooled estimate for risperidone was 6.47 (95% CI 0.32, 12.61). The one olanzapine study235 had an effect size of 12.13 (95% CI 0.97, 23.29). The overall random effects pooled estimate for risperidone and the one olanzapine study was 7.79 (95% CI 2.40, 13.17), with an I-squared = 0.0 percent. The clinical importance of this 6- or 12-point weighted mean difference needs to be considered in the context that the range of this instrument is 0–136 points, and the standardized mean differences are 0.40, which is normally considered “moderate” in size.

Figure 20 PTSD—by drug–difference in CAPS score

Figure 20 is a forest plot depicting our meta-analysis on improvement in Clinician Administered PTSD Scale (CAPS). One placebo controlled trial of olanzapine for PTSD showed a weighted mean difference in CAPS score of 12.1, which was statistically significant. Four placebo controlled trials of risperidone were pooled resulting in a statistically significant weighted mean difference of 6.47. The overall pooled result of the one olanzapine and four risperidone trials was a statistically significant weighted mean difference of 7.79 in CAPS score.

We also performed a meta-analysis stratified on combat status (Figure 21). We included three studies that included patients with PTSD from combat situations,230,234,235 and two studies that primarily included abused women with PTSD.231,237 We only had a sufficient number of studies to perform pooled analysis on the combat studies. We found a random effects pooled estimate of 7.95 (95% CI 1.06, 14.84).

Figure 21 PTSD—by combat status–difference in CAPS score

Figure 21 is a forest plot depicting our meta-analysis on improvement in CAPS score for PTSD by combat status. Three placebo controlled trials of patients from combat situations were pooled resulting in a statistically significant weighted mean difference of 7.95. Two placebo controlled trials of non-combat, mainly abused women, did not show a statistically significant effect. The overall pooled result of the five placebo controlled trials was a statistically significant weighted mean difference of 7.79.

Finally, we performed a meta-analysis of the risperidone studies stratified by followup time (Figure 22) divided the studies in to durations greater than or equal to 12 weeks or less than 12 weeks. One study reported outcomes in both time frames,237 one additional study reported outcomes at 12 weeks or more230 and two additional studies reported outcomes at less than 12 weeks.231,234 We only had a sufficient number of studies to report a pooled effect for the less than 12 week outcomes. The random effects pooled estimate for these three studies was not statistically significant (3.23, 95% CI -5.47, 11.93), indicating that we did not find an improvement in CAPS scores for risperidone treatment over placebo at less than 12 weeks.

Figure 22 PTSD—by time–difference in CAPS score

Figure 22 is a forest plot depicting our meta-analysis on improvement in CAPS score for PTSD by follow-up time. Three placebo controlled trials that reported CAPS scores at less than 12 weeks were pooled, results were not statistically significant. Two placebo controlled trials reported CAPS score at 12 weeks or more; one reported a significant improvement compared to placebo, while the other did not.

Active Controlled Trials. We found no active controlled trials of atypicals for PTSD.

Head-to-Head Trials. We found no head-to-head trials of atypicals for PTSD.

Substance Abuse. This off-label use was not included in our 2006 CER. Our literature search identified 33 studies that evaluated the use of atypical antipsychotics for use in alcohol or drug abuse. Nine trials were excluded from further analysis because they included patients with schizophrenia or schizophrenia-related psychosis 242-249 or bipolar disorder.250

Of the remaining 24 trials, ten evaluated aripiprazole,251-254 olanzapine,255-258 and quetiapine259,260 treatment for alcohol abuse and dependence. Ten trials assessed aripiprazole,261,262 olanzapine,263-265 and risperidone266-270 treatment for cocaine abuse and dependence. The quality and size of trials varied widely; Jadad scores ranged from 0 to 5, and sample size ranged from 3 to 262 participants.

Two trials assessed aripiprazole versus placebo for amphetamine/methamphetamine abuse271,272 and one trial evaluated olanzapine versus an SSRI and benzodiazepine for the treatment of heroin abuse and dependence.273 The two amphetamine/methamphetamine treatment trials found aripiprazole not likely to be an efficacious treatment.271,272 The heroin treatment trial found olanzapine did not improve addictive behavior or relapse.273 Another trial assessed treatment of concurrent cocaine and heroin dependence with the combination of methadone with risperidone at 2 or 4mg or placebo. This trial found no difference in reduction of cocaine or opiate use, between the three groups.274

Alcohol. The 10 trials that evaluated treatment of alcohol abuse ranged in duration from a few hours to 16 weeks. Two trials reporting on outcomes only after a specified number of drinks or several hours were not included.255,258

The most commonly reported outcome was drinking abstinence, which was reported in seven of the remaining eight trials. The one trial257 that did not report on abstinence compared olanzapine and placebo's effects on alcohol craving. After 2 weeks of treatment, they found that those participants with the longer repeat allele of the DRD4 VNTR gene responded to olanzapine with reduced craving and alcohol use whereas the participants with the shorter alleles did not.

Of the seven trials that reported on abstinence, two did not report sufficient data to calculate an effect size to use in further analyses.254,260 In one study,254 aripiprazole was found no better than placebo on the main outcome of percentage of days abstinent. In another study260 there were statistically significant differences for any primary drinking outcomes between patients treated with quetiapine plus naltrexone versus placebo plus naltrexone. Of the remaining trials, two reported only the number or percentage of patients that were completely abstinent at 12 weeks,252,259 one reported the number of patients that were completely abstinent and the number or percentage of days abstinent,252 and one trial reported the number of days abstinent.256

We performed meta-analysis for percentage of patients completely abstinent. Results are displayed in Figure 23. Three trials reported the number or percentage of patients completely abstinent during the followup period, which ranged from 8 days to 16 weeks. Two evaluated aripiprazole252,253 and one assessed quetiapine.259 The trials are displayed in Table 17. The size of these trials ranged from 30 to 288 participants. The overall random effects pooled estimate of the relative risk of remaining completely abstinent was 1.42 (95% CI 0.36, 5.67). The overall I-squared statistic was 80.4 percent. Neither Begg's nor Eggar's test indicated publication bias (p = .296, p = .308, respectively).

Figure 23 Substance abuse—alcohol complete abstinence

Figure 23 is a forest plot depicting our meta-analysis on complete abstinence from alcohol. There were two placebo controlled trials of aripiprazole, one reported a statistically significant effect that favored the placebo group and the other did not report a statistically significant effect. One placebo controlled trial of quetiapine had a statistically significant relative risk of complete abstinence of 4.97. The overall pooled estimate of the relative risk of complete abstinence was not statistically significant.

Table 17 Alcohol abuse—PCTs contributing to meta-analyses

Author, Year | Subjects | N | Treatments | Duration | Outcomes
Anton et al. 2008 252 | 21-65 years old, alcohol dependence, present at 3 visits with negative breathalyzer results and abstain from alcohol before randomization Score < 8 on Clinical Institute Withdrawal Assessment for Alcohol Revised | 295 | Placebo 27.4 mg/day Aripiprazole 2-30 mg/day | 12 weeks | Alcohol complete abstinence: Aripiprazole vs Placebo – RR = 0.50 (0.29, 0.88) Abstinent days: Aripiprazole vs Placebo – SMD=-0.13(-0.36, 0.10)
Voronin et al. 2008 253 | Aged 21-65, alcohol dependence, non treatment seeking | 30 | Placebo Aripiprazole 5-15 mg/day | 8 days | Alcohol complete abstinence: Aripiprazole vs Placebo - RR= 1.67 (0.48, 5.76)
Kampman et al. 2007 259 | Aged >= 18 years old, alcohol dependence, have a consecutive 30 days period drinking at least 48 standard drinks, >= 2 days of heavy drinking, >= 3 consecutive days of abstinence, Clinical Institutes Withdrawal Assessment for Alcohol score < 8 | 61 | Placebo 50-400 mg/day Quetiapine 50-400 mg/day | 12 weeks | Alcohol complete abstinence: Quetiapine vs Placebo - RR = 4.97 (1.17, 21.11)

RR = relative risk; SMD = standardized mean difference

Active Controlled Trials. One study compared naltrexone with aripiprazole; there was no difference in either mean number of days abstinent or percentage of group completely abstinent.251

Cocaine. One published meta-analysis275 assessed use of atypicals in treatment of cocaine dependence. It included three trials of risperidone268,270,274 and three of olanzapine.245,264,265 Outcome was rate of dropout from residential and outpatient substance abuse treatment programs. The analysis found no significant difference bteween atypicals and placebo; effect was not reported separately by medication.

Ten trials with placebo comparisons reported on the treatment of cocaine abuse or dependence with aripiprazole,261,262 olanzapine,263-265 and risperidone.266-270 These trials ranged from several days to 20 weeks. Outcomes reported varied greatly; most consistently reported outcomes were the Cocaine Craving Questionnaire (CCQ) and the ASI-drug. Two trials reported neither the CCQ or the ASI;267,268 they were not considered for further analysis. The first reported that risperidone improved neuropsychological impairment in cocaine-withdrawn patients. 267 One was an active-control trial that will be discussed below.

Five of the remaining eight cocaine abuse PCTs reported the CCQ.261-263,265,270 None reported usable CCQ data that would allow us to calculate an effect size estimate; thus, we could not use the CCQ as a poolable outcome. Five of the eight trials reported the ASI-drug composite score, two of which had no usable data.263,266 The first of these compared olanzapine to placebo for 16 weeks. They found that olanzapine was not superior to placebo in decreasing use, cravings, or addiction severity.263 The second of these compared risperidone to placebo in the treatment of cocaine dependence. There was no reduction in cocaine use after 12 weeks of treatment.266 The remaining three trials were considered comparable enough to justify meta-analysis, pooling on the continuous ASI-drug composite score outcome.264,265,269 The trials are listed in Table 18; meta-analyses results are displayed in Figure 24.

Table 18 Cocaine—PCTs contributing to meta-analysis

Author, Year | Subjects | N | Treatments | Duration | Outcomes
Kampman et al. 2003^264^ | $100 worth of cocaine use in prior month, age 18-60, cocaine dependency | 30 | Placebo 2.5-10 mg/day Olanzapine 2.5-10 mg/day | 11 weeks | Change in ASI: Olanzapine vs Placebo – WMD = 0.03 (-0.03, 0.09)
Reid et al. 2005^265^ | Standardized CREST study inclusion criteria | 68 | Placebo 2 tablets/day Olanzapine 5-10 mg/day Valproate 800-1500 mg/day Carnitine + CoQ 10 200+500 mg/day | 8 weeks | Change in ASI: Olanzapine vs Placebo - WMD = 0.02 (-0.23, 0.27)
Loebl et al. 2008^269^ | Men, 18-60, cocaine dependence, using cocaine >=1 every other week | 31 | Placebo Risperidone 1-2 mg daily / 0-3 weeks utilized only during initiation of risperidone longacting injection Risperidone long-acting injection 25mg every two weeks | 12 weeks | Change in ASI: Risperidone vs Placebo - WMD = -0.03 (-0.09, 0.03)

ASI = Addiction Severity Index; CREST = Cocaine Rapid Efficacy Screening Trial; WMD = weighted mean difference

Figure 24 Cocaine—ASI drug composite

Figure 24 is a forest plot depicting our meta-analysis on the Addiction Severity Index (ASI) drug composite score for cocaine use. Two placebo controlled trials evaluated olanzapine for treatment of cocaine use and the results for this outcome were not statistically significant. One placebo controlled trial of risperidone did not report statistically significant results. The overall pooled result of the three trials was not statistically significant.

These trials of olanzapine264,265 and risperidone269 treatment for cocaine abuse ranged in size from 30 to 68 participants and lasted from 8 to 12 weeks. We calculated a weighted mean difference for the effect size estimate in which a positive weighted mean difference favors the treatment arm. The overall random effects pooled estimate for the difference in ASI-drug composite score was 0.001 (95% CI -0.41, 0.043). The I-squared statistic indicated no heterogeneity. Neither Begg's nor Eggar's test indicated publication bias (p=1.00,p=0.928 respectively).

Active Controlled Trials. We found one trial that compared risperidone with pergolide.268 There was no statistical difference from placebo in reducing cocaine use.

Tourette's. We found no new clinical trials that studied atypical antipsychotics for Tourrette's syndrome published after our original CER. That CER reported risperidone was superior to placebo in one small trial, and it was at least as effective as pimozide or clonidine for 8 to 12 weeks of therapy in the three other trials. One trial of ziprasidone showed variable efficacy compared with placebo.

There were two observational studies276,277 of aripiprazole that reported effectiveness data after our 2006 CER; information is displayed in Table 19. One was a retrospective observational study for the treatment of tics with or without comorbid explosive disorder. Thirty-seven patients aged 8–18 years old were treated with aripiprazole 2.5-40 mg for 12 weeks. All of the 29 subjects who completed the trial experienced a reduction in their tic severity. However, eight subjects discontinued early due to inability to tolerate the medication.276

Table 19 Atypical antipsychotics for Tourette's syndrome

Study/Type | Patients/Age | Dosage/Duration | Measures | Effects
Budman, 2008^276^/ Retrospective observational study | 37 patients (29 completed, 8 withdrew for inability to tolerate)/ 8-18 years | 2.5-40mg (mean 11.69)/ 12 weeks | CGI- Tics | Reduction in tic severity in 100% of subjects
Yoo, 2007^277^/ Open-label, flexible dosing | 24 patients (18 completed, 6 withdrew for adverse effects)/ 7-18 years | 9.8 mg (+/- 4.8)/ 8 weeks | YGTSS, CGI-I, CGI-S, adverse effects checklist, EPS rating scale, height and weight, labs, ecg | 52.8% reduction in mean YGTSS scores overall CGI-I much improved or very much improved in 19/24

CGI-I = Clinical Global Impression Scale-Improvement Subscale; CGI-S = Clinical Global Impression Scale-Severity Subscale; EPS = extrapyramidal symptoms; YGTSS = Yale Global Tic Severity Scale

The other study treated 24 patients, aged 7–18 years old with a mean aripiprazole dose of 9.8mg for eight weeks. Overall, there was a 52.8 percent reduction in Yale Global Tic Severity Scale scores, and 19 of the 24 were described as “much” or “very much” improved per CGI-I. Six of the patients discontinued due to adverse effects.277

#### Discussion

We conducted an extensive literature search, data abstraction, and meta-analyses whenever possible to assess the efficacy and comparative effectiveness of atypical antipsychotics for off-label use. Since the publication of our original CER in 2006, many new high-quality controlled trials have been published; we were able to add many to our prior quantitative analyses. Our results are summarized in Table 20. It is important to note that we found no trials of the three newest atypicals—asenapine, iloperidone, and paliperidone—for off-label uses.

Table 20 Summary of strength of evidence of efficacy, by drug and condition

| Aripiprazole | Olanzapine | Quetiapine | Risperidone | Ziprasidone
Anxiety
– generalized anxiety disorder | ○ | - | ++ | - | -
Anxiety
– social phobia | ○ | + | - | ○ | ○
Attention Deficit/Hyperactivity Disorder
-no co-occurring disorders | ○ | ○ | ○ | + | ○
Attention Deficit/Hyperactivity Disorder
-bipolar children | - | ○ | ○ | ○ | ○
Attention Deficit/Hyperactivity Disorder
-mentally retarded children | ○ | ○ | ○ | + | ○
Dementia overall | ++ | + | + | ++ | ○
Dementia psychosis | + | +- | +- | ++ | ○
Dementia agitation | + | ++ | +- | ++ | ○
Depression
-MDD augmentation of SSRI / SNRI | [image] | [image] | [image] | ++ | +
Depression
-MDD: Monotherapy | ○ | - | ++ | ○ | ○
Eating Disorders | ○ | -- | - | ○ | ○
Insomnia | ○ | ○ | - | ○ | ○
Obsessive Compulsive Disorder
-augmentation of SSRI | ○ | + | -- | ++ | -
Obsessive Compulsive Disorder
-augmentation of citalopram | ○ | ○ | + | + | ○
Personality Disorder
-borderline | + | +- | + | ○ | -
Personality Disorder
-schizotypal | ○ | ○ | ○ | +- | ○
Post Traumatic Stress Disorder | ○ | +- | + | ++ | ○
Substance Abuse alcohol | -- | - | - | ○ | ○
Substance Abuse cocaine | ○ | - | ○ | - | ○
Substance Abuse methamphetamine | - | ○ | ○ | ○ | ○
Substance Abuse methadone clients | ○ | ○ | ○ | - | ○
Tourette's Syndrome | ○ | ○ | ○ | + | -

[image] moderate or high evidence of efficacy

[image] low or very low evidence of efficacy

[image] mixed results

[image] low or very low evidence of inefficacy

[image]moderate or high evidence of inefficacy

○ : no trials

[image]: Approved by FDA for the indication

MDD = major depressive disorder; SNRI = serotonin-norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor

Note: Symbols denote strength of evidence, not size of potential effect. For example in dementia “++” indicates moderate-to-high strength of evidence that there is a beneficial effect, however the size of the effect is small.

We found that aripiprazole, olanzapine, and risperidone had small but statistically significant effects in treating agitation, psychosis, and behavioral symptoms of dementia. Because of the plethora of trials, the large sample sizes enrolled in each trial (usually 300 or more), the quality of trials (mean Jadad score 3.2) and the consistency of the results, the strength of the evidence is high. However, the clinical benefits must be balanced against significant side effects and potential harms. (See results of Key Question 4, later in this report.) In addition, most trials used flexible dosing, so we were unable to determine the most appropriate dosage.

Moderate strength evidence suggests efficacy of aripiprazole, quetiapine, and risperidone as augmentation in treatment of MDD in patients who respond inadequately to SSRIs/SNRIs. Effect sizes are moderate to large, with patients one and a half to two times as likely to respond as with SSRIs alone. Also, a few trials found efficacy for ziprasidone and olanzapine; the strength of evidence is low for these two drugs, but this rating could change with the publication of additional successful trials. Quetiapine is also effective as monotherapy for MDD; strength of evidence is moderate. Strength could increase to high if non–industry-funded studies are published with similar results.

We found moderate strength evidence of efficacy of risperidone as augmentation therapy for OCD. Trials for OCD tend to be much smaller than those for dementia and depression; sample sizes ranged from 15 to 45 for the 10 trials contributing to our efficacy meta-analysis. The mean quality of trials is lower (2.2 on Jadad scale). Results are also less consistent. For example, in the only two PCTs of olanzapine, percentage of participants responding as measured by Y-BOCS did not differ from placebo. In contrast, a head-to-head trial (with no placebo) found no difference in efficacy between olanzapine and risperidone, a drug with moderate evidence of efficacy.

There is also moderate strength evidence of efficacy in reducing symptoms of combat-related PTSD from several small trials of risperidone. We also found two studies of olanzapine for PTSD; they reported conflicting results. There is low strength of evidence based on two positive trials of quetiapine. Trials of PTSD tend to be of lower quality and smaller size than the depression augmentation and dementia trials. Mean Jadad score was 2.7; only two PTSD trials had over 40 participants. New, preferably larger trials must be conducted before the strength of evidence can be increased.

Regarding borderline personality disorder, strength of evidence of efficacy is low or very low for all atypicals other than risperidone, where we found no trials. Olanzapine had the most trials (seven) but results were inconsistent. Of note, however, in the olanzapine studies that showed no difference between drug and placebo groups at 12-week followup, both groups of patients showed improvement overall, with the treated patients showing a faster time to response.

We added eating disorders, anxiety, insomnia, and substance abuse to our 2011 report. With the exception of generalized anxiety disorder, there is little scientific evidence that atypicals are useful in addressing symptoms of these conditions. Moderate evidence suggests that olanzapine, risperidone, and aripiprazole have no efficacy in substance abuse treatment, and that olanzapine treatment does not lead to weight increase in eating disorder patients, compared with placebo. We did find moderate evidence of efficacy of quetiapine in treating generalized anxiety disorder. There were too few trials of olanzapine, risperidone or ziprasidone for anxiety to pool; these trials had mixed results. Importantly, anxiety trials had larger samples (mean N = 122) and higher quality (mean Jadad score = 3.1) than most trials for OCD, PTSD, substance abuse, and eating disorders.

Finally, we reviewed trials of children and adolescents with Tourette's syndrome or ADHD; evidence of efficacy was low for use of atypicals for these conditions. No Tourette's trials have been published since our 2006 CER which reported that risperidone is at least as effective as pimozide or clonidine. Only one small trial has studied atypicals for ADHD in children with no major co-occurring disorders; risperidone users were more likely to respond than placebo patients.

These findings are valuable and can help psychiatrists make better clinical decisions based on the latest evidence. Findings are summarized in Table 20. The symbol “O” below indicates areas where we found no clinical trials of a particular atypical for that condition, while “-” indicates evidence of inefficacy for a condition, according to the psychometric measures our team considered most important. In summary, ziprasidone has no evidence of efficacy for any off-label use other than depression. The four other atypicals have shown efficacy in treating dementia, depression, and a few other conditions, depending on drug.

Our literature search procedures were extensive and included canvassing experts from academia and industry regarding studies we may have missed. However, the possibility of publication bias still exists. Table 21 below displays our assessment of heterogeneity by condition and outcome. For the most part, our assessment did not yield evidence of unexplained heterogeneity. Two exceptions include the MADRS for depression and the Y-BOCS (percent of participants responded) outcome used in our OCD meta-analysis. In our analysis of atypicals as augmentation and monotherapy in treatment of major depressive disorder (MDD), possible publication bias appeared in studies reporting the MADRS (Begg's p=.072, Egger's p=.019 for augmentation, percent remitted; Begg's p=.027, Egger's p=.027, for monotherapy, percent responded). We conducted additional augmentation meta-analyses using HAM-D outcomes; efficacy results were similar, but no heterogeneity was detected. Thus, our confidence that some atypicals have efficacy in treating depression remains. Heterogeneity was also evident in studies assessing the efficacy of atypicals for OCD (Begg's p=0.002, Egger's p=0.001). This heterogeneity was likely due to patient enrollment criteria; studies used different definitions of “refractory” and “treatment resistant.” Another published meta-analysis of atypicals for OCD192 found similar efficacy results but no heterogeneity according to statistical tests.

Table 21 Analysis of publication bias

Condition | Outcome | Begg's Test P-Value^*^ | Egger's Test P-Value
Anxiety | HAM-A % Responded | 0.462 | 0.239
Dementia | Total/Global Scores | 0.837 | 0.790
Dementia | Psychosis | 0.558 | 0.429
Dementia | Agitation | 0.544 | 0.178
Depression, Augmentation | HAM-D % Remitted | 0.771 | 0.245
Depression, Augmentation | HAM-D % Responded | 0.711 | 0.245
Depression, Augmentation | MADRS % Remitted | 0.072 | 0.019
Depression, Augmentation | MADRS % Responded | 0.260 | 0.069
Depression, Monotherapy | MADRS % Remitted | 0.860 | 0.142
Depression, Monotherapy | MADRS % Responded | 0.027 | 0.027
Eating Disorders | BMI | 0.730 | 0.680
OCD | Y-BOCS % Responded | 0.002 | 0.001
PTSD | CAPS | 0.806 | 0.608
Substance Abuse | Alcohol Complete Abstinence | 0.296 | 0.308
Substance Abuse | ASI Drug Composite | 1.000 | 0.928

* Continuity Corrected

ASI = Addiction Severity Index; BMI = body mass index; CAPS = Clinician-Administered PTSD Scale; HAM-A = Hamilton Anxiety Rating Scale; HAM-D = Hamilton Depression Rating Scale; MADRS = Montgomery-Asberg Depression Rating Scale; OCD = obsessive-compulsive disorder; PTSD = post-traumatic stress disorder; Y-BOCS = Yale-Brown Obsessive-Compulsive Scale

An important limitation common to systematic reviews is the quality of the original studies included. In order to measure the quality of clinical trials we used the Jadad scale.17 As empirical evidence regarding other study characteristics and their relationship to bias is lacking, we did not attempt to use other criteria. However, other aspects of the design and execution of a trial may be related to bias, but we do not yet have good measures of these elements. In our 2006 CER on off-label use of atypicals, we conducted a sensitivity analysis on the relationship between trial quality and effect size; the better quality trials reported an effect size 25 percent smaller than did lower quality trials. This finding increases the likelihood that a synthesis of results of all studies—whether narrative or quantitative—may produce inflated estimates of efficacy. As stated above, the higher general quality of the dementia and depression augmentation studies led to a greater strength of evidence rating for those uses.

Applicability of research to the larger treatment population is important in interpreting the results of the included studies. The participation rate, the intended target population, representativeness of the setting, and representativeness of the individuals must be known to assess applicability. Such data were reported unevenly in the studies we reviewed. The dementia trials were most often conducted in nursing homes, hospitals, or assisted living facilities. According to our review on utilization patterns, these settings represent where atypicals are most often used in the elderly. Studies for other conditions were not particularly representative. For example, three of the four trials for ADHD were conducted in children with severe co-occurring conditions, such as bipolar disorder or mental retardation. Subjects in substance abuse trials were usually enrolled in outpatient or residential treatment programs. However, there was one trial of non–treatment-seeking subjects;253 it is unlikely that atypicals would be used in the real world without some initial detoxification or simultaneous treatment program.

In the studies of atypicals as augmentation for SSRI or SNRI patients with MDD, it was often unclear whether patients were simultaneously undergoing psychotherapy. One article165 specifically stated that subjects were prohibited from initiating such therapy during the trial, but other articles were unclear on the issue. Thus, we don't know whether treatment over and above the medication influenced the study results. It is important to note that subjects in depression trials were recruited from both primary care and mental health centers, as depression patients have been increasingly treated in primary care settings.

We found only one small trial (N=13) of atypicals for treatment of insomnia. Observational studies of Insomnia included patients with Parkinson's disease, MDD, polysubstance abuse withdrawal symptoms, and tamoxifen-induced insomnia. Thus, the results of these studies should not be applied to the general population.

## Key Question 3 What subset of the population would potentially benefit from off-label uses? Do effectiveness and harms differ by race/ethnicity, gender, and age group? By severity of condition and clinical subtype?

### Key Points

There was no difference in effect by gender in one study of aripiprazole for MDD. No other studies stratified results by gender.

Atypicals may have greater efficacy in male combat veterans than in civilian women with PTSD.

There are insufficient data to make conclusions regarding differences in efficacy by patient age. Two studies of atypicals for MDD in older adults found them at least as efficacious as in studies conducted in the non-elderly.

There are insufficient data to make statements regarding treatment effects by race/ethnicity, as no studies reported stratified results.

Differing measures of disease severity preclude overall conclusions about the effects of atypical antipsychotics by severity.

### Detailed Analysis

There was only one study that conducted subgroup analysis by gender. In that trial, aripiprazole was used as an adjunct in treatment of major depressive disorder. Regarding mean change in MADRS total score, there were no statistically significant interaction effects for gender.154

Trials of PTSD were conducted in male and female populations. In the male trials 230,234,235 PTSD was combat-related, while the female trials 231,237 were conducted on civilian women whose PTSD was abuse-related. In pooled analysis of the three combat studies, mean difference in CAPS was 7.95 (95% CI 1.06, 14.84) compared with placebo. Although we could not pool the results of the two trials in abused women, we note that the results of both trials were not statistically different from placebo.

There were no trials that stratified by race; therefore evidence about the differing benefits by race was not obtained.

Regarding age, as expected, most participants in ADHD and Tourette's trials were children or adolescents, while trials for dementia were conducted in the elderly. As these conditions are heterogeneous and use different measures of efficacy, it is not possible to compare efficacy by age group. There were no trials that specifically stratified effects by age; however, there were two depression trials conducted in an older population. One studied risperidone augmentation in patients >/= 55 years old.278 The authors found a suggestion towards greater symptom resolution with risperidone (compared with placebo augmentation) but no significant difference in time to relapse. Reported side effects included headache, dizziness and dry mouth. The other trial studied quetiapine monotherapy in patients with depression >65 years old.169 The relative risk of remitting on the MADRS for those participants taking quetiapine compared with placebo was 2.48 (95% CI 1.70, 3.62); the relative risk of responding on the MADRS for those patients in the quetiapine arm versus the placebo arm was 2.11 (95% CI 1.63, 2.71). These estimates of effect size were larger than all other studies included in our depression meta-analyses (see Key Question 2). Reported side effects included somnolence, headache, dry mouth, dizziness, fatigue, insomnia, constipation, diarrhea, nausea, weight increase, sedation, asthenia, extrapyramidal disorder, upper abdominal pain, back pain and dysgeusia.

There was insufficient data to conduct analyses by disease subtype, other than the PTSD analysis on combat versus civilian trauma noted above.

Studies differed in the psychometrics used to measure severity of illness, making comparisons across studies difficult. This may reflect the differing definition of disease severity seen clinically.

### Discussion

In summary, there are insufficient data regarding efficacy, effectiveness, and harms to determine what subset of the population would potentially benefit from off-label uses of atypical antipsychotic medications. Only one study conducted a subgroup analysis by gender; there were no studies that stratified by racial or ethnic group. Although many studies specified age in their inclusion criteria, no studies stratified results by age. Unfortunately, this limits the conclusions that can be determined.

Examination of the literature for differing effects of atypical antipsychotic medications by clinical subsets did not reveal studies reporting subgroup analyses. Our own meta-analysis found efficacy for combat-related PTSD in men but not for PTSD in civilian women. Due to the varying measures utilized in determining severity of illness, it was not possible to analyze treatment effects by severity of illness across any condition.

Overall, there are not enough data to suggest that a particular subset of the clinical populations, whether by demographic or illness characteristics, will show differing benefit in treatment with atypical antipsychotic treatment. More research in this area is needed.

## Key Question 4 What are the potential adverse effects and/or complications involved with off-label prescribing of atypical antipsychotics? How do they compare within the class and with other drugs used for the conditions?

### Key Points

We found no trials or large observational studies of asenapine, iloperidone, or paliperidone for off-label uses.

Elderly patients—dementia studies. Our 2006 systematic review discussed a published meta-analysis of atypicals and death in Alzheimer's disease patients which included both published and unpublished trials. Death occurred in 3.5 percent of patients randomized to receive atypical antipsychotics compared with 2.3 percent of patients randomized to receive placebo. The difference in risk for death was small but statistically significant.

We found six large high-quality cohort studies that compared mortality in elderly patients taking atypical and conventional antipsychotics. Four of these studies found a significantly higher rate of death with conventional antipsychotics, while two found no statistical difference in mortality. Patients taking atypicals had higher odds of mortality than those taking no antipsychotics in the cohort studies that made that comparison.

We used data from PCTs to conduct a meta-analysis on symptoms we categorized as cardiovascular (including “cardiovascular symptoms,” “edema,” and “vasodilatation”). These events were reported significantly more often in patients taking olanzapine and risperidone than in those taking placebo. Quetiapine and aripiprazole were not statistically associated with these symptoms.

We conducted a specific analysis on cerebrovascular accident (CVA); risperidone was the only drug associated with an increase. However, as mentioned in our 2006 report, an industry-sponsored analysis of five RCTs of olanzapine in elderly dementia patients found the incidence of cerebrovascular adverse events three times as high in olanzapine patients as in placebo patients.

Our meta-analysis of PCTs found olanzapine and risperidone statistically associated with increases in appetite/weight. As reported in 2006, in one large head-to-head trial, Clinical Antipsychotic Trials of Intervention Effectiveness-Alzheimer's Disease (CATIE-AD), elderly patients with dementia who were treated with olanzapine, quetiapine, or risperidone averaged a monthly weight gain of 1.0, 0.7 and 0.4 pounds while on treatment, compared with a weight loss among placebo-treated patients of 0.9 pounds per month.

Olanzapine was associated with unspecified anticholinergic events in one trial.

Our meta-analysis of PCTs also found that aripiprazole, olanzapine, quetiapine, and risperidone were each associated with both sedation and fatigue in dementia patients. Risperidone was associated with an increase in EPS; aripiprazole and quetiapine were not. These findings echo those of our prior analyses and the CATIE-AD trial results. In the one PCT of olanzapine that reported EPS, subjects in the drug group were more likely to report these symptoms.

Endocrine adverse events are a new focus. Only one trial in elderly dementia patients reported these outcomes; there was no difference in diabetes onset or prolactin measures between patients taking risperidone and those taking placebo. One cohort study followed elderly patients enrolled in olanzapine trials; the authors found that the risk of diabetes was not significantly associated with antipsychotic treatment, but rather depended on having an elevated glucose at baseline. Olanzapine, quetiapine and risperidone were associated with urinary symptoms.

We found no trials or large observational studies of ziprasidone for dementia in older adults; therefore, we can not make conclusions regarding safety of ziprasidone in this population.

In head-to-head trials of atypicals, olanzapine patients had higher odds of neurological symptoms, such as headaches and dizziness, than those taking risperidone. A recent publication from the CATIE-AD trial reported cognitive decline in elderly dementia patients treated with olanzapine, quetiapine, or risperidone.279 There was a trend toward greater odds of sedation with olanzapine and quetiapine compared with risperidone. In one trial more risperidone patients than quetiapine patients reported musculoskeletal problems.

We found one new trial comparing adverse events in elderly patients taking either risperidone or SSRIs for depression. There was no difference in adverse events. As reported in our 2006 evidence review, one trial of olanzapine versus benzodiazepines in 205 patients also showed no significant difference in adverse events.

Adults (Age 18 to 64)—studies of anxiety, depression, eating disorders, OCD, PTSD, personality disorders and substance abuse. The only significant difference in cardiovascular symptoms between atypicals and placebo involved blood pressure changes in patients taking quetiapine. No studies of any drug or condition reported CVA.

Our analysis of PCTs found that aripiprazole, olanzapine, quetiapine, and risperidone were each associated with increases in appetite/weight gain. Ziprasidone was not significantly associated with weight gain in two trials. We also found a recently published cohort study of depression treatment which reported risperidone, quetiapine, olanzapine, and ziprasidone, but not aripiprazole, were associated with an increase in the risk of incident hyperlipidemia. In our analysis of three quetiapine PCTs which reported abnormalities in triglycerides, they were more common in patients taking the drug than those taking placebo.

Endocrine and diabetes are a new focus. Two PCTs of olanzapine reported endocrine adverse events; patients taking the drug had increased odds. One PCT each of quetiapine, risperidone, and ziprasidone also reported these events. We were unable to conduct meta-analysis; however, the events were always more prevalent in the atypical group. Six PCTs of quetiapine reported diabetes outcomes; in our pooled analysis there was no statistical difference between patients taking quetiapine and those taking placebo. In the one PCT of olanzapine that reported diabetes outcomes, 5 of the 370 intervention patients became diabetic, compared with only one of the 377 patients taking placebo. In one head-to-head trial, olanzapine had a higher risk for precipitating diabetes than did risperidone. As reported in our 2006 evidence review, one large observational study reported lower odds of diabetes in risperidone subjects than in placebo.

Our analyses indicate that all atypical antipsychotics are associated with an increase in at least some symptoms categorized as neurological (“confusion,” “dizziness,” “headaches,” “lightheadedness,” “orthostatic dizziness,” “seizure,” and “tinnitus”) when compared with placebo. All but risperidone were associated with increased fatigue; all were associated with sedation. Aripiprazole was associated with increased odds of akathisia, while the other drugs were not. Aripiprazole, quetiapine, and ziprasidone were associated with increased odds of EPS.

Quetiapine patients had higher odds of decreased salivation, neurological events, sedation, and agitation, compared with risperidone patients in two head-to-head trials. Another head-to-head trial reported higher odds of weight gain with olanzapine when compared with ziprasidone.

We found two trials of olanzapine versus a mood stabilizer. Olanzapine patients had lower GI adverse effects, low platelets and mania, but higher odds of weight gain, dry mouth, liver function test abnormality, EPS, and sedation. We found one small trial of quetiapine versus a mood stabilizer: quetiapine patients were less likely to experience EPS.

Two trials of quetiapine, one of risperidone and three of olanzapine reported adverse events compared with SSRIs. Although there were no differences in diabetes rates, higher rates of metabolic lab abnormalities were reported in one trial of quetiapine versus SSRI. Fatigue was more common in olanzapine, quetiapine, and ziprasidone than in SSRIs, and sedation was more common in olanzapine and quetiapine patients. Olanzapine and risperidone patients also had higher odds of cardiovascular adverse events.

Four trials of olanzapine and one of aripiprazole compared adverse events in conventional versus atypical antipsychotics. Weight gain was more common among both olanzapine and aripiprazole patients than those taking conventional antipsychotics. In one trial, olanzapine patients were less likely to observe cardiovascular symptoms, fever/infection, gastrointestinal, and musculoskeletal problems fatigue, akathisia, EPS, and sedation. The four olanzapine trials were pooled; patients were less likely to experience EPS than patients on conventional antipsychotics. In the one aripiprazole trial, fewer aripiprazole patients experienced akathisia and EPS than those on conventional antipsychotics.

Two of the findings potentially differ from the perceptions of psychiatrics. In four studies containing 1,387 patients, aripiprazole was associated with increased appetite/weight gain, and in seven studies including 2,566 patients, quetiapine was associated with EPS. We consider these findings to be a signal deserving of further investigation.

Children & adolescents—studies of ADHD and Tourette's syndrome. There were no trials or large cohort studies of olanzapine or quetiapine for ADHD or Tourette's syndrome in children/adolescents, nor were there any head-to-head trials of atypicals for these uses.

Maximum trial length was 6 weeks, and adverse events were few. Weight gain was more common in patients taking risperidone than those taking placebo in two PCTs. In one small PCT, EPS was less common in aripiprazole patients than placebo patients.

In one small PCT of ziprasidone, there were no significant differences in adverse events between groups. In one small trial of clonidine versus risperidone there were no significant differences in adverse events between groups. In one trial of haloperidol versus risperidone significantly more patients on the conventional antipsychotic reported sleep problems.

### Detailed Analysis

One of the major rationales for preferring treatment with atypical antipsychotics over conventional antipsychotics is potentially greater safety. To assess this, we abstracted adverse event data from all RCTs of atypicals for off-label conditions, plus observational studies with more than 1,000 subjects. We conducted separate analyses for placebo comparisons, active comparisons (comparing atypical antipsychotics to acetyl cholinesterase inhibitors, benzodiazepines, clonidine, conventional antipsychotics, mood-stabilizers, SRIs, and tricyclic antidepressants), head-to-head trials of atypicals, and observational studies. Of the 128 RCTs published since our 2006 CER, 115 reported adverse events. We pooled the new data with data from the 65 RCTs included in our 2006 adverse events analyses.

As in the 2006 analyses, we identified and grouped adverse events into clinically relevant categories. These categories were then pooled within three condition categories, based on patient age. Patient age was a proxy measure for the baseline likelihood of adverse events; in other words, children, non-elderly adults, and older adults are expected to have different types of risks for adverse events. Thus, we analyzed studies of dementia patients separately (mean age = 81.5 years); pooled ADHD and Tourette's patients together; and pooled studies of the remaining conditions together (mean ages from 24.3 years for eating disorders to 47.4 years for depression). We did not pool different atypicals together; instead, we generated separate estimates for each of the five atypical antipsychotics: aripiprazole, olanzapine, quetiapine, risperidone, and ziprasidone. Again, we found no trials of the three newer drugs (asenpine, iloperidone, paliperidone) for off-label uses.

The complete results of the adverse event analyses are presented in Appendix G. Number needed to harm (NNH) is presented where applicable. For many of the comparisons, the numbers of trials are few and the number of enrolled patients is small, resulting in wide 95 percent confidence intervals and the inability to draw conclusions. However, even with this limitation, many observations are worth noting.

Dementia. Data from trials: There were no trials or large observational studies of ziprasidone in dementia; thus, we have no data on ziprasidone's safety in the elderly.

In 2005, the FDA issued a Public Health Advisory for treatment of dementia with atypical antipsychotics after studies reported increased risk of death compared with placebo. Our 2006 CER discusses a published meta-analysis of atypical antipsychotic medication use and death in Alzheimer's disease patients which included both published and unpublished trials. Fifteen RCTs were included (eight were cited only as abstracts): four trials of risperidone, five of olanzapine, three of quetiapine, and two trials of aripiprazole. In all, 3,353 patients received an atypical antipsychotic, and 1,757 received placebo. With one exception, trials lasted from 6-12 weeks. (The one exception was 26 weeks.) Death occurred in 118 or 3.5 percent of patients randomized to receive atypical antipsychotics versus 40 or 2.3 percent of patients randomized to receive placebo. The odds ratio for death using a fixed effects model was 1.54, with a 95 percent confidence interval of 1.06 to 2.23. The difference in risk for death was small but statistically significant (p = .01). In other words, the number needed to harm was 100, although the 95 percent confidence intervals were broad. Pooled data from two trials containing a haloperidol treatment arm indicated that treatment with this conventional antipsychotic was also associated with a similar, albeit not statistically significant, increase in death. The authors concluded that atypical antipsychotic drugs may be associated with a small increased risk for death compared with placebo. As this meta-analysis was well-conducted and included more trials that were available to us, we did not conduct our own meta-analysis of mortality and atypical antipsychotic use for dementia.

In this update, we conducted a meta-analysis on the group of symptoms we categorized as cardiovascular (including “cardiovascular symptoms,” “edema,” and “vasodilatation”). They were reported significantly more often in patients taking olanzapine and risperidone than in those taking placebo (OR of 2.33, and 2.08, respectively). The number needed to harm (see Table 22) was 48 for olanzapine and 34 for risperidone. Aripiprazole and quetiapine were not statistically associated with these symptoms. We conducted a specific analysis on CVA; risperidone was the only drug associated with an increase. The pooled odds ratio was 3.12 (95% CI 1.32, 8.21); number needed to harm was 53.

Table 22 Cardiovascular adverse events among dementia patients—atypical antipsychotics compared with placebo

| | | Placebo | | Intervention Groups
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI | NNH
Cardiovascular/CVA | Olanzapine | 2 | 4 | 232 | 6 | 278 | 1.46 | 0.33, 7.44 | NC
Cardiovascular/CVA | Risperidone | 4 | 8 | 753 | 24 | 1099 | 3.12 | 1.32, 8.21 | 53
Cardiovascular/CVA | Aripiprazole | 3 | 2 | 253 | 2 | 340 | 0.70 | 0.05, 10.48 | NC
Cardiovascular/CVA | Quetiapine | 2 | 6 | 241 | 3 | 185 | 0.65 | 0.10, 3.08 | NC
Cardiovascular – other | Olanzapine | 5 | 9 | 440 | 40 | 778 | 2.33 | 1.08, 5.61 | 48
Cardiovascular – other | Risperidone | 6 | 34 | 1010 | 119 | 1757 | 2.08 | 1.38, 3.22 | 34
Cardiovascular – other | Aripiprazole | 1 | 12 | 121 | 42 | 366 | 1.18 | 0.58,2.55 | NC
Cardiovascular – other | Quetiapine | 3 | 15 | 254 | 29 | 355 | 1.08 | 0.53, 2.30 | NC

CVA = cerebrovascular accident; NC = not calculated; NNH = number needed to harm

In the PCTs, olanzapine and risperidone were statistically associated with increases in appetite/weight (OR 4.69, 95% CI 1.87, 14.14; OR 3.40, 95% CI 1.08, 12.75; respectively) while olanzapine was associated with unspecified anticholinergic events in one study (OR 3.29, 95% CI 1.62, 7.17, NNH = 6). As reported in our 2006 evidence report, the CATIE-AD trial found that patients with dementia who were treated with olanzapine, quetiapine or risperidone averaged a monthly weight gain of 1.0, 0.7 and 0.4 pounds while on treatment, compared with a weight loss among placebo-treated patients of 0.9 pounds per month.

Table 23 displays our current analyses on neurological side effects. Aripiprazole, olanzapine, quetiapine, and risperidone were each associated with sedation in dementia patients. The NNH ranged from 7 to 10. Each of these drugs was also statistically associated with an increase in fatigue; NNH ranged from 18 to 21 (not shown). To analyze EPS, we were able to pool four PCTs of aripiprazole, five PCTs of risperidone, and three of quetiapine. Risperidone was associated with an increase in EPS compared with placebo; the NNH was 20, while the odds ratio was 3.00. In the one PCT of olanzapine which reported EPS, subjects in the drug group were more likely to report these symptoms (odds ratio of 15.21, NNH=10). A recent publication from the CATIE-AD trial reported cognitive decline in elderly dementia patients treated with olanzapine, quetiapine, or risperidone279 (not shown).

Table 23 Neurological adverse events among dementia patients—atypical antipsychotics compared with placebo

| | | Placebo | | Intervention Groups
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI | NNH
Neuro/Sedation | Aripiprazole | 4 | 22 | 374 | 116 | 706 | 2.62 | 1.57, 4.54 | 16
Neuro/Sedation | Olanzapine | 5 | 25 | 440 | 158 | 778 | 4.58 | 2.87, 7.55 | 9
Neuro/Sedation | Quetiapine | 4 | 18 | 353 | 84 | 446 | 5.16 | 2.93, 9.51 | 8
Neuro/Sedation | Risperidone | 6 | 102 | 922 | 265 | 1260 | 2.33 | 1.79, 3.05 | 10
Neuro/Movement Disorder/EPS | Aripiprazole | 4 | 16 | 374 | 39 | 706 | 1.29 | 0.68, 2.57 | NC
Neuro/Movement Disorder/EPS | Olanzapine | 1 | 2 | 142 | 18 | 100 | 15.21 | 3.50, 138.55 | 10
Neuro/Movement Disorder/EPS | Quetiapine | 3 | 9 | 254 | 18 | 355 | 1.15 | 0.46, 3.08 | NC
Neuro/Movement Disorder/EPS | Risperidone | 5 | 31 | 916 | 130 | 1561 | 3.00 | 1.96, 4.70 | 20
Neuro/Movement Disorder/Gait | Olanzapine | 4 | 15 | 373 | 79 | 641 | 2.75 | 1.52, 5.79 | 21
Neuro/Movement Disorder/Gait | Aripiprazole | 1 | 1 | 121 | 16 | 366 | 5.47 | 0.83, 231.93 | NC
Neuro/Movement Disorder/Gait | Quetiapine | 3 | 6 | 333 | 18 | 426 | 2.36 | 0.85, 7.59 | NC
Neuro/Movement Disorder/Gait | Risperidone | 3 | 8 | 406 | 32 | 448 | 3.04 | 1.32, 7.84 | 33

CI = confidence interval; EPS = extrapyramidal symptoms; NC = not calculated; NNH = number needed to harm; OR = odds ratio

Our expert panel reported cases of diabetes onset in elderly patients taking atypicals; thus, we were encouraged to conduct an analysis on endocrine outcomes. Only one trial, of risperidone, reported this category of adverse events; there was no difference between patients taking the drug and those taking placebo, although the confidence intervals are wide. Results are displayed in Table 24 below.

Table 24 Endocrine adverse events among dementia patients – atypical antipsychotics compared with placebo

| | | Placebo | | Intervention Groups
Adverse Events | Drug | # of Studies | # Adverse Events | Sample Size | # Adverse Events | Sample Size | Pooled OR | 95% CI | NNH
Diabetes | Risperidone | 1 | 5 | 238 | 4 | 235 | 0.81 | 0.16, 3.80 | NC
Prolactin | Risperidone | 1 | 0 | 238 | 0 | 235 | NC | NC | NC

CI = confidence interval; NC = not calculated; NNH = number needed to harm; OR = odds ratio

As displayed in Table 25, urinary symptoms were significantly more common in dementia patients treated with olanzapine, quetiapine, and risperidone than with placebo; NNH ranged from 16 to 36. Confidence intervals were very wide for olanzapine.

Table 25 Urinary symptoms among dementia patients—atypical antipsychotics compared with placebo

| | Placebo | | Intervention Groups
Drug | # of Studies | # Adverse Events | Sample Size | # Adverse Events | Sample Size | Pooled OR | 95% CI | NNH
Aripiprazole | 3 | 44 | 348 | 115 | 603 | 1.37 | 0.92, 2.09 | NC
Olanzapine | 1 | 1 | 94 | 19 | 204 | 9.51 | 1.47, 401.07 | 36
Quetiapine | 2 | 12 | 191 | 44 | 332 | 2.37 | 1.16, 5.15 | 16
Risperidone | 4 | 71 | 665 | 164 | 1060 | 1.55 | 1.13, 2.13 | 21

CI = confidence interval; NC = not calculated; NNH = number needed to harm; OR = odds ratio

We found six head-to-head trials of atypicals for dementia that reported adverse events, including the CATIE-AD trial mentioned earlier. Subjects taking olanzapine had greater odds of having a neurological symptom such as “confusion,” “dizziness,” “headaches,” “lightheadedness,” “orthostatic dizziness,” “seizure,” or “tinnitus” than those taking risperidone (OR 1.54, 95% CI 1.02, 2.34). There also was a trend toward greater odds of sedation with olanzapine (OR 1.40, 95% CI 0.96, 2.05) and quetiapine (OR 1.93, 95% CI 0.97, 3.97) than risperidone, but the results do not meet traditional levels of statistical significance. In one head-to-head trial, a risperidone subject reported a pulmonary adverse event, compared with no subjects in the olanzapine group. In one trial of risperidone versus quetiapine, five of the 34 risperidone subjects reported musculoskeletal problems, compared with none of the 38 quetiapine patients.

We found one new trial comparing adverse events in elderly patients taking either risperidone or SSRIs for depression. There was no difference in adverse events. As reported in our 2006 evidence review, one trial of olanzapine versus benzodiazepines in 205 patients also showed no significant difference in adverse events.

Data from cohort studies. There were also twelve large high-quality cohort studies that reported adverse effects occurring within elderly population taking atypicals for symptoms of dementia; they are displayed in Table 26. Six examined mortality. Populations ranged in size from 9,700 to over 37,000. All were conducted in the United States or Canada. The first found an increased risk of death with atypical antipsychotic use, compared with not using antipsychotics. However, the risk of death with conventional antipsychotics was greater than that with atypicals.68 Another study found that patients taking atypicals had a similar adjusted mortality risk to those taking conventional antipsychotics. Both types of antipsychotics had a higher mortality risk than that associated with taking a no antipsychotics.280 A more recent study found that those exposed to haloperidol, olanzapine, or risperidone had a higher risk of death than those not taking any antipsychotics. This study did not find an increased risk of death with the use of quetiapine.281 These findings echo another study that found the greatest increase in mortality occurring in those who took higher than the median dose. However, the dosage risk was for conventional antipsychotic therapy. The authors found that the risk of death was higher with conventional versus atypical antipsychotics and the highest risk was during the first 40 days after starting the drug therapy.67

Table 26 Adverse events in large observational studies of elderly patients

Reference | Sample | Treatment | Outcomes Measured | Findings
Barnett, 2007^287^ | n= 14,029 >65 yo with dementia Data per Veterans Administration and Medicare databases Followed 18 months (2002-2003) | olanzapine, risperidone, quetiapine Or conventional agents | Inpatient admission with a primary or principal diagnosis of cerebrovascular event (CVE) as identified by ICD-9-CM codes from administrative data | CVE risk did not differ in users of atypicals, conventionals or no antipsychotic
Gill, 2007^68^ | n= 27,259 propensity score-matched pairs Ontario, Canada residents >66 yo dementia per Ontario Health Insurance Plan or Discharge Abstract Database 4/1/97-3/31/02. Community dwelling and long-term care | New users of antipsychotics per Ontario Drug Benefit program after cohort entry atypicals: olanzapine, quetiapine, risperidone Or conventional agents | All-cause mortality as recorded in the Registered Persons Database or the Discharge Abstract Database | New use of atypical antipsychotic associated with statistically significant increase in the risk of death compared with nonuse (community dwelling- adjusted hazard ratio, 1.31 [95% CI, 1.02-1.7]; absolute risk difference 0.2 percentage point. Long-term care 1.55 [CI, 1.15-2.07]; 1.2 percentage points) Conventional antipsychotic use associated with higher risk of death than use of atypicals
Huybrechts, 2011^283^ | n=10,900 British Columbia nursing home patients 1996-2006 | Atypical antipsychotics Or conventional agents Or benzodiazepines Or antidepressants | Death and rates of hospital admission within 180 days after treatment initiation | Risk of death associated with conventional antipsychotics, antidepressants and benzodiazepines are comparable or greater than that for atypical antipsychotics.
Kales, 2007^280^ | n= 10,615 patients US residents >65 yo dementia per Department of Veteran Affairs national data 2001-2005 outpatient | New users of psychiatric medication after cohort entry atypicals: aripiprazole, clozapine, quetiapine, risperidone, ziprasidone Or conventional agents | 12 month mortality rates | Higher mortality rates in users of antipsychotics than nonantipsychotics (22.6-29.1% vs 14.6%) No significant difference in mortality rates between users of atypical vs conventional antipsychotics
Liperoti, 2009^282^ | n= 9,729 >65 yo with dementia Data per Systematic Assessment of Geriatric drug use via Epidemiology (SAGE) 1998-2000 | New users of antipsychotics In Medicare or Medicaid certified nursing homes in Kansas, Maine, Mississippi, Ohio, South Dakota risperidone, olanzapine, quetiapine, clozapine Or conventional agents | All-cause mortality | Higher rate of death in users of conventional vs atypical agents (hazard ratio 1.26; 95% CI, 1.13-1.42)
Lipkovich, 2007^288^ | n= 1,267 >65 yo with dementia and behavioral disturbances Data per olanzapine clinical trial database | olanzapine | Weight change patterns after 20 weeks of treatment | Estimated probability of gaining more than 7% of initial body weight was significantly greater with olanzapine vs placebo (P< .001)
Micca, 2006^289^ | n= 1,398 >65 yo with dementia Data per olanzapine clinical trial database | olanzapine | Treatment-emergent diabetes (TED): defined as 2 casual glucose values >200mg/dL at any time after baseline or 1 casual glucose >200mg/dL at the final visit, initiation of antidiabetic medication or new clinical diagnosis of diabetes. | Antipsychotic treatment was not significantly associated with increased risk of TED (HR=1.36)
Pratt, 2010^285^ | n= 10,638 (of which 514 were initiated on typical and 564 on atypical antipsychotic) >65, hospitalized for stroke Self-controlled case series, 4 year period from 1/1/03-12/31/06 Australian Government Dept of Veterans' Affairs administrative claims dataset. | Atypical antipsychotics Or conventional agents | Risk of hospitalization for stroke | Hospitalization for stroke was increased in the first week after initiation of conventional antipsychotics (IRR 2.3; 95% CI 1.3, 3.8). No evidence for increased risk of hospitalization for stroke after initiation of atypical.
Rochon, 2008^290^ | n= 20,682 community dwelling and 20,559 nursing home dwelling >66 yo with dementia Data per Ontario, Canada administrative health care data 30 day f/u between 4/1/97- 3/31/04 | olanzapine, quetiapine, risperidone Or conventional agents | Any serious adverse event as defined by the International Conference on Harmonization Clinical Safety Data Management: Definitions and Standards for Expedited Reporting guidelines (i.e.-results in death, is life-threatening, requires inpatient hospital admission or prolongation of existing hospital stay, or results in persistent or significant disability/incapacity | Compared with patients not using antipsychotics, users of atypicals were 3.2 times more likely (95% CI, 2.77-3.68) to develop a serious adverse event whereas users of conventionals were 3.8 times more likely (95% CI, 3.31-4.39)
Rossom, 2010^281^ | n= 18,127 5 year retrospective study of veterans national healthcare data Predominantly male, > 65 Dementia 10/99 – 9/05 | olanzapine, quetiapine, risperidone Or haloperidol | Mortality during antipsychotic use | Compared with controls not using antipsychotics, during the first 30 days of use, a greater percentage of those exposed to haloperidol (5.4% vs 1.7%, unadjusted HR= 1.4), olanzapine (2.7% vs 1.7%, unadjusted HR=1.6), or risperidone (2.8% vs 2.0%, unadjusted HR=1.4) died. There was no difference between deaths among quetiapine users and controls (1.7% vs 1.7%, unadjusted HR=1.4) and deaths were not greater after the initial 30-day period in any of the cohorts exposed to antipsychotics.
Sacchetti, 2010^284^ | n=128,308 >50 years old Health Search Database, Primary Care Patients, Italy | Antipsychotics (does not specify conventional vs atypical) | Time to first ever stroke in elderly primary care people | The cumulative proportion surviving (free from stroke) at the end of the first month was 0.9921 (95% CI 0.9899-0.9943) in subjects exposed to antipsychotics and 0.9995 (95% CI 0.9979-0.9983) in unexposed. At 6 months, figures were 0.9819 (95% CI 0.9761-0.9879) in exposed and 0.9964 (95% CI 0.9960-0.9968) in unexposed. Overall, the risk of stroke was 12.4 times higher in antipsychotic users in the first month but decreased to mostly insignificant within the following months.
Schneeweiss, 2007^67^ | n= 37,241 users of antipsychotics >65 yo British Columbia Ministry of Health data 1/1/96- 12/31/04 | Per PharmaNet Database risperidone, quetiapine, olanzapine, clozapine Or conventional agents | All-cause mortality per BC Vital Statistics Agency | Risk of death was comparable and possibly greater with conventional (14.1% died) compared with atypical agents (9.6% died). Mortality ratio 1.47, 95% CI 1.39-1.56

CI = confidence interval; CVE = cerebrovascular event; HR = hazard ratio; SAGE = Systematic Assessment of Geriatric Drug Use via Epidemiology; TED = treatment-emergent diabetes

Two studies followed new users of antipsychotic medications in nursing home residents282,283 over 6 months. Both found a higher rate of death for users of conventional antipsychotics compared with users of atypicals. There were also two studies that examined the risk of stroke with antipsychotic medications in older individuals. Both combined atypical and conventional antipsychotics as one group. One found the risk of stroke to be 12.4 times as high within the first month of antipsychotic use as not using an antipsychotic, but this risk decreased to mostly insignificant during the following months.284 The other found that hospitalization was increased in the first week after initiation of a conventional antipsychotic but did not find an increased risk of stroke after the initiation of an atypical agent.285 Finally, one study looked at venous thromboembolism (including pulmonary embolus and deep vein thrombosis) across all ages. For those age 65 and older, there were 10 excess cases of venous thromboembolism per year per 10,000 treated with an antipsychotic (either atypical or conventional) compared with four excess cases in those younger than 65.^286^

Other cohort studies focused on diabetes, weight gain, cerebrovascular events, and any serious event, in general. Regarding diabetes, one industry-sponsored and conducted study focused specifically on elderly subjects enrolled in olanzapine trials and found that the risk of diabetes was elevated (hazard ratio = 1.36) but this association was not statistically significant. These authors concluded that the risk of diabetes was more dependent on having an elevated glucose at baseline.289

A cohort study of mostly underweight or normal weight patients with dementia found a greater probability of gaining weight with olanzapine versus other agents, particularly if their BMI was less than 25 at baseline.288

A large study evaluating information from the Veterans Affairs and Medicare databases observed patients with dementia who used antipsychotics over an 18-month period. They found no difference between risk of cerebrovascular event by whether the patient used a conventional, atypical, or no antipsychotic therapy. The only altered risk was in patients with the vascular dementia subtype who received risperidone. They had a decreased risk of cerebrovascular event compared with haloperidol, whereas olanzapine and quetiapine did not.287

One study examined serious adverse events among older adults with dementia living in the community versus in a nursing home. Researchers monitored for any event that resulted in death, was life threatening, required an inpatient hospital admission or prolongation of an existing hospital stay, or resulted in persistent or significant disability incapacity. Patients receiving either an atypical or conventional antipsychotic agent were more than three times more likely to develop a serious event during the 30 days of followup. 290

Children/adolescents with ADHD or Tourette's syndrome. Our 2006 CER did not include studies of ADHD. Instead, our 2006 analyses of adverse events in children and adolescents included studies of Tourette's syndrome and autism. Autism is beyond the scope of the current report; thus, those trials are not included in the current analysis.

Data from trials. Our adverse events analyses for Tourette's syndrome and ADHD patients included four PCTs. There were no trials of olanzapine or quetiapine in this population, nor were there any head-to-head trials of atypicals.

Results showed several differences between atypical antipsychotics and placebo. In two trials of risperidone, no placebo patients gained weight, compared with eight of 28 patients on the drug. In another small trial, 32.0 percent of patients on aripiprazole reported EPS, compared with 83.3 percent of placebo patients. The one PCT of ziprasidone had only 28 patients; there were no significant difference in adverse events between groups. Of note, these trials were in general of modest duration, from 4 to 6 weeks.

We found one small trial of clonidine versus risperidone; there were no significant differences in adverse events. We also found 1 trial of haloperidol versus risperidone; 7 of the 24 patients on the conventional antipsychotic reported sleep problems, compared with only 1 of the 26 patients on risperidone.

Data from cohort studies. We did not identify any cohorts of sample sizes of 1,000 patients or greater for the conditions of ADHD or Tourette's syndrome.

Other conditions. Data from trials: Our final adverse events analysis combined trials for anxiety, eating disorders, depression, OCD, PTSD, personality disorders, insomnia, and substance abuse. As displayed in Table 27, in the PCTs, aripiprazole, olanzapine, quetiapine, and risperidone were each statistically associated with increases in appetite/weight gain (OR 4.18, 11.30, 2.71, and 3.78, respectively) compared with placebo, with olanzapine having the largest association by more than a factor of two. Ziprasidone was not significantly associated with weight gain in two trials.

Table 27 Appetite or weight increase in other conditions—atypical antipsychotics compared with placebo

| | Placebo | | Intervention Groups
Drug | # of Studies | # Adverse Events | Sample Size | # Adverse Events | Sample Size | Pooled OR | 95% CI | NNH
Aripiprazole | 4 | 8 | 686 | 35 | 701 | 4.18 | 1.88, 10.56 | 35
Olanzapine | 11 | 103 | 819 | 382 | 818 | 11.30 | 8.22, 15.74 | 3
Quetiapine | 13 | 90 | 1846 | 279 | 2887 | 2.71 | 2.07, 3.58 | 16
Risperidone | 4 | 5 | 197 | 24 | 237 | 3.78 | 1.35, 13.09 | 21
Ziprasidone | 2 | 2 | 113 | 5 | 251 | 1.24 | 0.19, 13.59 | NC

CI = confidence interval; NC = not calculated; NNH = number needed to harm; OR = odds ratio

Death were reported only in two trials of quetiapine; there was no difference between drug and placebo groups. No studies reported CVA. The only significant difference in cardiovascular symptoms between atypicals and placebo involved blood pressure changes in patients taking quetiapine. Strangely, the drug was associated with both decrease (OR 2.01, 95 percent CI 1.25, 3.30) and increase (OR 1.71, 95 percent CI 1.22, 2.39) in blood pressure, casting doubt on this being a causal relationship.

As displayed in Table 28 below, we conducted a meta-analysis on metabolic outcomes, as experts informed us of recent reports of increases in diabetes rates among some patients taking certain atypicals. Results should be interpreted with caution, as we found only one study each of quetiapine, risperidone, and ziprasidone that reported endocrine abnormalities. The risperidone and ziprasidone groups were very small, and only one or two subjects, respectively, had endocrine abnormalities, as compared with no one in either placebo group. “Endocrine abnormalities” in this analysis were a collection of endocrine events other than diabetes (which is reported separately in Table 28), including laboratory abnormalities such as hyperprolactinemia, elevated thyroid stimulating hormone levels, and hypothyroidism, as well as clinical findings commonly due to endocrine abnormalities, such as gynecomastia and amenorrhea. Regarding quetiapine, 5 of the 298 subjects had endocrine adverse events, compared with only 1 of 148 subjects in the placebo group. In two PCTs of olanzapine, the drug was significantly associated with endocrine adverse events (OR 2.37, 95% CI 1.18, 4.94).

Table 28 Endocrine and other metabolic lab abnormalities in other conditions—atypical antipsychotics compared with placebo

| | | Placebo | | Intervention Groups
Adverse Events | Drug | # of Studies | # Adverse Events | Sample Size | # Adverse Events | Sample Size | Pooled OR | 95% CI | NNH
Endocrine | Olanzapine | 2 | 15 | 190 | 31 | 184 | 2.37 | 1.18, 4.94 | 12
Endocrine | Quetiapine | 1 | 1 | 148 | 5 | 298 | 2.50 | 0.28, 119.45 | NC
Endocrine | Risperidone | 1 | 0 | 12 | 1 | 19 | NA | NA | NC
Endocrine | Ziprasidone | 1 | 0 | 30 | 2 | 30 | NA | NA | NC
Diabetes | Olanzapine | 1 | 1 | 377 | 5 | 370 | 5.14 | 0.57, 244.28 | NC
Diabetes | Quetiapine | 6 | 11 | 1073 | 32 | 1753 | 1.47 | 0.71, 3.28 | NC
Prolactin | Risperidone | 1 | 0 | 10 | 1 | 15 | NA | NA | NC
Metabolic lab abnormality | Quetiapine | 3 | 32 | 537 | 108 | 903 | 2.20 | 1.43, 3.47 | 18

CI = confidence interval; NA = not available; NC = not calculated; NNH = number needed to harm; OR = odds ratio

Six PCTs of quetiapine reported diabetes outcomes; the pooled odds ratio was elevated at 1.47 but this was not statistically significant compared with placebo. In the one PCT of olanzapine that reported diabetes, 5 of the 370 intervention patients became diabetic, compared with only one of the 377 patients taking placebo, an odds ratio of 5.14, but this was not statistically significant, with very wide confidence intervals (0.6 to 244). In our analysis of three quetiapine PCTs that reported metabolic lab abnormalities (clinically important increases in triglycerides), they were more common in patients taking the drug than those taking placebo (OR 2.20, 95% CI 1.43, 3.47).

As displayed in Table 29, olanzapine, quetiapine, and ziprasidone were associated with an increase in at least some symptoms categorized as neurological (“confusion,” “dizziness,” “headaches,” “lightheadedness,” “orthostatic dizziness,” “seizure,” and “tinnitus”) when compared with placebo. All drugs but risperidone were statistically associated with increased fatigue compared with placebo. NNH ranged from 14 to 19. Aripiprazole was associated with increased odds of akathisia (OR 11.78, 95% CI 7.40, 19.61), while the other drugs were not. Aripiprazole, quetiapine, and ziprasidone were associated with increased odds of EPS. NNH was 11 for aripiprazole, 36 for quetiapine and 24 for ziprasidone. All atypicals were associated with increased odds of sedation. NNH ranged from three for quetiapine to 11 for risperidone.

Table 29 Neurological adverse events in other conditions—atypical antipsychotics compared with placebo

| | | Placebo | | Intervention Groups
Adverse Events | Drug | # of Studies | # Adverse Events | Sample Size | # Adverse Events | Sample Size | Pooled OR | 95% CI | NNH
Neuro | Aripiprazole | 6 | 127 | 795 | 111 | 805 | 0.83 | 0.62, 1.12 | NC
Neuro | Olanzapine | 8 | 56 | 377 | 74 | 369 | 1.55 | 1.00, 2.42 | 17
Neuro | Quetiapine | 19 | 508 | 2305 | 881 | 3,551 | 1.24 | 1.09, 1.43 | 22
Neuro | Risperidone | 6 | 63 | 261 | 54 | 301 | 0.72 | 0.45, 1.15 | NC
Neuro | Ziprasidone | 5 | 18 | 212 | 58 | 404 | 1.95 | 1.06, 3.72 | 16
Fatigue | Aripiprazole | 4 | 31 | 686 | 82 | 701 | 2.86 | 1.83, 4.55 | 15
Fatigue | Olanzapine | 7 | 43 | 737 | 80 | 720 | 2.06 | 1.37, 3.12 | 19
Fatigue | Quetiapine | 13 | 74 | 2010 | 289 | 3072 | 2.94 | 2.20, 3.97 | 18
Fatigue | Risperidone | 4 | 9 | 233 | 9 | 274 | 0.83 | 0.28, 2.41 | NC
Fatigue | Ziprasidone | 2 | 0 | 69 | 8 | 111 | NA | NA | 14
Akathisia | Aripiprazole | 5 | 24 | 769 | 190 | 779 | 11.78 | 7.40, 19.61 | 7
Akathisia | Olanzapine | 1 | 7 | 25 | 9 | 23 | 2.04 | 0.50, 8.92 | NC
Akathisia | Quetiapine | 4 | 5 | 488 | 10 | 632 | 1.31 | 0.38, 5.07 | NC
Akathisia | Risperidone | 1 | 0 | 18 | 1 | 19 | NA | NA | NC
Akathisia | Ziprasidone | 3 | 9 | 161 | 36 | 321 | 2.11 | 0.96, 5.15 | NC
EPS | Aripiprazole | 5 | 43 | 605 | 99 | 610 | 2.75 | 1.83, 4.19 | 11
EPS | Olanzapine | 3 | 18 | 65 | 17 | 71 | 0.87 | 0.25, 2.97 | NC
EPS | Quetiapine | 7 | 35 | 1100 | 87 | 1466 | 2.62 | 1.72, 4.06 | 36
EPS | Risperidone | 1 | 1 | 10 | 0 | 15 | 0.00 | 0.00, 26.00 | NC
EPS | Ziprasidone | 3 | 6 | 161 | 28 | 321 | 3.12 | 1.15, 10.62 | 24
Sedation | Aripiprazole | 7 | 73 | 810 | 160 | 820 | 3.03 | 2.15, 4.32 | 8
Sedation | Olanzapine | 14 | 127 | 904 | 279 | 901 | 2.95 | 2.29, 3.82 | 6
Sedation | Quetiapine | 18 | 373 | 2285 | 1668 | 3531 | 5.54 | 4.78, 6.43 | 3
Sedation | Risperidone | 8 | 25 | 290 | 54 | 336 | 2.43 | 1.39, 4.34 | 11
Sedation | Ziprasidone | 5 | 21 | 212 | 95 | 392 | 3.90 | 2.15, 7.44 | 6

CI = confidence interval; EPS = extrapyramidal symptoms; NC = not calculated; NNH = number needed to harm; OR = odds ratio

Patients taking atypicals other than aripiprazole had greater odds of decreased salivation (dry mouth) than patients taking placebo. NNH ranged from 7 for quetiapine to 25 for ziprasidone (not shown).

Regarding adults aged 18 to 65, we found one head-to-head trial of olanzapine versus ziprasidone and two head-to-head trials comparing quetiapine to risperidone. Olanzapine was associated with higher odds of weight gain (OR 4.02, 95% CI 2.25, 7.48) when compared with ziprasidone. When compared with risperidone, quetiapine had higher odds of decreased salivation, neurological events, sedation, and agitation.

There were two trials of olanzapine versus a mood stabilizer. Olanzapine patients had lower odds of gastrointestinal side effects, low platelet count and mania. Olanzapine patients had higher odds of weight gain, dry mouth, liver function test abnormality, EPS, sedation, speech disorder, and depression. We found one small trial of quetiapine versus a mood stabilizer: the only difference in adverse effects (AEs) involved EPS, with quetiapine patients less likely to experience them.

A handful of trials compared AEs between an atypical antipsychotic arm and an SSRI arm. Olanzapine and quetiapine patients had greater odds of weight gain than placebo patients, while risperidone patients did not. Olanzapine and risperidone patients also had higher odds of cardiac events. Olanzapine, quetiapine and ziprasidone patients had higher odds of dry mouth, while risperidone patients did not. Although there was no difference in diabetes rates, higher rates of metabolic lab abnormalities were reported in one trial of quetiapine versus SSRI. Fatigue was more common in olanzapine, quetiapine, and ziprasidone than in SSRIs, and sedation was more common in olanzapine and quetiapine patients.

We were able to compare adverse events in conventional versus atypical antipsychotics in four trials of olanzapine and one of aripiprazole. Weight gain was more common among both olanzapine and aripiprazole patients than those taking conventional antipsychotics (OR 2.72 and 1.61 respectively). In one trial, olanzapine patients were less likely to observe cardiovascular symptoms, fever/infection, gastrointestinal, and musculoskeletal problems. In four pooled trials of olanzapine, patients were less likely (OR 0.28, 95% CI 0.23, 0.33) to experience EPS than patients on conventional antipsychotics. In one trial of aripiprazole versus conventional antipsychotics, fewer aripiprazole patients experienced akathisia (OR 0.44, 95% CI 0.33, 0.60) and EPS (OR 0.24, 95% CI 0.18, 0.32).

Schizophrenia. Because of the paucity of head-to-head data directly comparing adverse events among atypical antipsychotics prescribed for off-label uses in the non-elderly, we reviewed the results of the CATIE trial, a multicenter study at 57 U.S. sites that randomized 1,493 patients with schizophrenia (the indicated condition for these drugs) to receive either olanzapine, quetiapine, risperidone, ziprasidone, or the conventional antipsychotic perphenazine. This study found that risperidone had the lowest rate of treatment discontinuation due to intolerable side effects (10 percent), whereas olanzapine had the highest rate (18 percent). More patients treated with perphenazine discontinued treatment due to extrapyramidal effects than did those treated with any of the atypical antipsychotics (8 percent vs. 2–4 percent). However, there were no significant differences among the groups in the incidence of EPS, akathisia, or movement disorders, as measured by the AIMS Global Severity Score, the Barnes Akathisia Rating Scale, or the Simpson-Angus Extrapyramidal Signs Scale. Weight gain was more common in patients treated with olanzapine (average weight gain of 2 lbs. per month) than in other patients. Two to three times as many patients in the olanzapine-treated group gained 7 percent or more of their baseline body weight as those in the other groups. More patients discontinued therapy with olanzapine due to weight gain or metabolic effects than those treated with other drugs (9 percent vs. 1–4 percent). Adverse changes in glycosylated hemoglobin, cholesterol, and triglycerides were also more likely in olanzapine-treated patients than in those treated with the other drugs, while changes in blood glucose level were also greater in olanzapine-treated patients, but the difference did not reach statistical significance. Only risperidone was associated with increasing prolactin levels. Quetiapine treated patients had higher rates of anticholinergic effects (such as dry mouth) than the other drugs, whereas patients treated with olanzapine or quetiapine had lower rates of insomnia than did patients in the other groups. Although the CATIE trial has been criticized for the dropout rate and the perception that the dose of olanzapine used was comparatively higher than the dose for the other atypical antipsychotics, these data support the findings from the clinical trials of atypical antipsychotics for off-label indications that olanzapine causes the most weight gain but is associated with lower rates of insomnia and that treatment with atypical antipsychotics results in fewer EPS and movement disorders than does treatment with conventional antipsychotics.

Data from cohort studies. As reported in our original evidence report, one large observational study reported lower odds of diabetes in risperidone subjects than in placebo subjects (OR= 0.21, 95% CI 0.07, 0.51).

One new cohort study investigated the risk of hyperlipidemia with antipsychotic treatment of depression. Treatment with risperidone, quetiapine, olanzapine and ziprasidone, but not aripiprazole, caused a significant increase in the risk of incident hyperlipidemia.291 One study of sudden cardiac death in patients aged 30 to 74 found that users of either conventional or atypical antipsychotics had a similar, dose-related increase compared with nonusers.292

### Discussion

In summary, there is consistent high strength evidence across multiple trials that olanzapine is associated with more weight gain than placebo, conventional antipsychotics, or other atypical antipsychotics. This was a conclusion from our 2006 report; that conclusion is unchanged in this update. Evidence about weight gain for other atypical antipsychotics is not as robust, but stronger in this update than in our earlier report. In nonelderly adults, olanzapine, risperidone, quetiapine and aripiprazole are all statistically significantly associated with weight gain compared with placebo. From limited data, ziprasidone was not associated with weight gain. The association of aripiprazole with weight gain was unexpected by a project psychiatrist.

There is an emerging signal that some atypical antipsychotics are associated with the development of metabolic laboratory abnormalities or overt diabetes. Again, olanzapine stands out from the other drugs with regard to this signal. The strength of evidence for this signal is low, meaning we expect further research to change our confidence in the estimate of the effect and is likely to change the effect.

Although the evidence from off-label use is insufficient to draw conclusions, limited evidence from patients with schizophrenia suggests that atypical antipyschotics are associated with less tardive dyskinesia than are high doses of haloperidol. The strength of evidence for this outcome is low. There is moderate strength evidence that olanzapine and risperidone are associated with an increase in extrapyramidal signs or symptoms (excluding tardive dyskinesia) relative to placebo. The CATIE-AD trial also concluded that EPS are more common with olanzapine and risperidone than quetiapine, and that all three drugs are associated with cognitive decline. Quetiapine was associated with EPS in our pooled analysis of seven studies of non-elderly adults; this finding was also surprising and warrants additional investigation. There is low strength evidence that, in nonelderly adults, the atypical antipsychotics aripiprazole and olanzapine are associated with a lower risk of side effects than are conventional antipsychotics.

There is high strength evidence from meta-analyses that the use of atypical antipsychotics is associated with an increased risk of death in elderly patients with dementia and agitation. For risperidone, this outcome may be related to an increased risk of stroke. New since our prior report is stronger evidence that conventional antipsychotics probably also increase the risk of death in similar patients, perhaps to the same or greater degree than atypical antipsychotics; however, the strength of evidence for this outcome is moderate, as data come primarily from high quality observational studies. Further research may change our confidence in the estimate or may change the estimate itself.

Other differences in adverse events/safety between atypical antipsychotics and conventional antipsychotics or placebo were either small or inconsistent. New since our prior report is one exception to this general conclusion: an emerging signal of an increase in urinary symptoms in older adults with dementia taking atypical antipsychotics relative to placebo.

## Key Question 5 What is the effective dose and time limit for off-label indications?

### Key Points

Dementia trials that included arms with different dosages usually reported a dose-response trend with higher doses resulting in higher efficacy; this trend was not statistically significant.

Our meta-analyses of MDD trials that compared quetiapine dosages found no statistical difference between 150 mg and 300 mg in percent of sample remitting or responding based on the MADRS.

One trial of the treatment of borderline personality disorder with olanzapine demonstrated improvement when 5-10 mg daily was used but no difference from placebo with 2.5 mg dose.

Our meta-analysis of olanzapine for eating disorders found no increase in BMI compared with placebo at either one or three months.

Our meta-analysis of PTSD trials found pooled results from at least 12 weeks followup were not statistically different from those reported at less than 12 weeks.

### Detailed Analysis

Dosage. Five of the dementia PCTs contained treatment arms for different doses. There were too few studies to pool dosage results by drug: we found one of aripiprazole,107 two of olanzapine,110,111 one of quetiapine,122 and one of risperidone.127 Each of these studies reported results per arm for total score agitation scale, and psychosis scales on the BEHAVE-AD, BPRS, or NPI. The results of these trials are displayed on Figures 25, 26, and 27. All but one study of olanzapine110 reported increased efficacy with increased dosage. However, this trend is not statistically significant, as the 95 percent confidence intervals for the treatment arms in each study overlap.

Figure 25 Dementia: PCTs—with dose comparisons—total/global scores

Figure 25 is a forest plot depicting our meta-analysis on improvement in total/global scores for dementia by drug and dose. One placebo controlled trial of aripiprazole evaluated three different doses, ranging from 2mg to 10mg. Only the 10mg dose reported a statistically significant effect size, at 0.28. The pooled result of these three dose groups for aripiprazole was a statistically significant standardized effect size of 0.17. Two placebo controlled trials of olanzapine evaluated its use at 6 differing dose levels. Doses ranged from 1mg to 15mg. One 5mg olanzapine group had a statistically significant standardized effect size of 0.44. The overall pooled result for the differing olanzapine dose groups was a statistically significant standardized effect size of 0.16. One placebo controlled trial of quetiapine reported two dose groups (100mg & 200mg), neither of which reported a statistically significant effect. One placebo controlled trial of risperidone reported on three dose groups ranging from 0.5mg to 2mg. The 1mg and 2mg group had a statistically significant standardized effect size of 0.32 and 0.49, respectively. The overall pooled result for risperidone was a statistically significant standardized effect size of 0.32.

Figure 26 Dementia: PCTs with dose comparisons—psychosis

Figure 26 is a forest plot depicting our meta-analysis on improvement in psychosis scores for dementia by drug and dose. One placebo controlled trial of aripiprazole evaluated three different doses, ranging from 2mg to 10mg. Only the 10mg dose reported a statistically significant effect size, at 0.39. The pooled result of these three dose groups for aripiprazole was a statistically significant standardized effect size of 0.25. Two placebo controlled trials of olanzapine evaluated its use at 6 differing dose levels. Doses ranged from 1mg to 15mg, results of the individual dose groups were not statistically significant. The overall pooled result for the differing olanzapine dose groups was a statistically significant standardized effect size of 0.16. One placebo controlled trial of quetiapine reported two dose groups (100mg & 200mg), neither of which reported a statistically significant effect. One placebo controlled trial of risperidone reported three dose groups ranging from 0.5mg to 2mg. The 2mg group had a statistically significant standardized effect size, at 0.34. The overall pooled result for risperidone was a statistically significant standardized effect size of 0.19.

Figure 27 Dementia: PCTs with dose comparisons—agitation

Figure 27 is a forest plot depicting our meta-analysis on improvement in agitation scores for dementia by drug and dose. One placebo controlled trial of aripiprazole evaluated three different doses, ranging from 2mg to 10mg. Both the 5mg and 10mg dose groups reported statistically significant effect sizes, at 0.43 and 0.34, respectively. The pooled result of these three dose groups for aripiprazole was a statistically significant standardized effect size of 0.31. Two placebo controlled trials of olanzapine evaluated its use at 6 differing dose levels. Doses ranged from 1mg to 15mg. One 5mg olanzapine group had a statistically significant standardized effect size of 0.48. The overall pooled result for the differing olanzapine dose groups was a statistically significant standardized effect size of 0.18. One placebo controlled trial of quetiapine reported two dose groups (100mg & 200mg), neither of which reported a statistically significant effect. One placebo controlled trial of risperidone reported three dose groups ranging from 0.5mg to 2mg. Both the 1mg and 2mg group had a statistically significant standardized effect size, at 0.32 and 0.57, respectively. The overall pooled result for risperidone was a statistically significant standardized effect size of 0.37.

We found four depression PCTs in the nonelderly population that contained treatment arms for different doses.159,162,171,172 All studied quetiapine and all contained both 150 mg and 300 mg arms. One also included a 50 mg arm.172 Results of our meta-analyses are presented in Figures 28 and 29; outcomes were percentage of patients remitted or responded according to the MADRS. (Please see Key Question 2 section for further description of these outcomes.) Though three of the PCTs reported the 300 mg arm slightly superior to the 150 mg arm, the results were not statistically significant. The relative risk (RR) of entering remission, versus patients taking placebo, were 1.36 (95% CI 1.12, 1.64) for patients taking 150 mg and 1.51 (95% CI 1.25, 1.81) for patients taking 300 mg. Patients in the one 50 mg group had RRs of 1.40 (95% CI 0.95, 2.07). The RRs of responding, versus patients taking placebo, were 1.42 (95% CI 1.22, 1.67) for patients taking 150 mg and 1.43 (95% CI 1.25, 163) for patients taking 300 mg. Patients in the one 50 mg group had an RR of 1.41 (95% CI 1.07, 1.85).

Figure 28 Depression—MADRS % remitted—dose

Figure 28 is a forest plot depicting our meta-analysis on the percent of patients achieving remission based on the MADRS for depression, by dose. Four placebo controlled trials that evaluated the use of quetiapine at 150mg were pooled, resulting in a statistically significant pooled estimate of the relative risk of remission of 1.36. These same four placebo controlled trials also reported the use of quetiapine at 300mg. The 300mg quetiapine trials were pooled, resulting in a statistically significant pooled estimate of the relative risk of remission of 1.51. One trial evaluated quetiapine at 50mg, results were not statistically significant.

Figure 29 Depression—MADRS % responded—dose

Figure 29 is a forest plot depicting our meta-analysis on percent of patients achieving “response” based on the MADRS for depression, by dose. Four placebo controlled trials that evaluated the use of quetiapine at 150mg were pooled, resulting in a statistically significant pooled estimate of the relative risk of response of 1.42. These same four placebo controlled trials also reported the use of quetiapine at 300mg. The 300mg quetiapine trials were pooled, resulting in a statistically significant pooled estimate of the relative risk of response of 1.43. One trial evaluated quetiapine at 50mg, results were statistically significant.

Finally, one trial of borderline personality disorder treatment with olanzapine demonstrated improvement when 5–10 mg was used each day but no difference from placebo when 2.5 mg was used.220

Timing. There were only enough studies to pool data by duration for PTSD and eating disorders. Forest plots are presented in Figures 20 and 16, respectively, in the results section for Key Question 2. For the PTSD studies, there was no statistically significant improvement in CAPS scores for risperidone treatment over placebo at less than 12 weeks.231,234,237 There were only two studies that reported improvement in CAPS scores for greater than 12 weeks, so those data could not be pooled. The one PTSD study that reported outcomes at both greater than and less than 12 weeks found risperidone not significantly different from placebo, regardless of time point.237

There were three eating disorder trials that measured changes in BMI with use of olanzapine at 1 and 3 months compared with placebo.180,182,183 There was no significant improvement, compared with placebo, at either of the time points.

There were two studies of the same population of BPD patients receiving treatment with aripiprazole.218,219 The first of these measured the population at 8 weeks and the second at 18 months. Both time points demonstrated improvement in Symptom Checklist 90-revised (SCL-90) scores.

### Discussion

For most conditions, there are too few studies comparing doses of atypical antipsychotic medications to draw a conclusion about a minimum effective dose. Most studies used flexible dosing, with patients on a wide range of doses. From limited data, it appears that 150 mg quetiapine daily augmentation is equally efficacious as augmentation with 300 mg for MDD patients who respond inadequately to SSRIs, as measured by the percentage of remitters and responders according to the MADRS. More trials comparing different doses of other atypicals for depression would help guide clinicians in treating this population. In addition, more dosage trials for treating conditions such as OCD, PTSD, and anxiety disorder would allow for pooling and comparison of results.

Though there is data regarding duration of treatment in PTSD, eating disorders, and BPD, the outcome of treatment appears to be the same regardless of time point.