# Peer Reviewers

Peter Rabins, M.D., M.P.H.

Johns Hopkins Hospital

Baltimore, MD

Julie Kreyenbuhl, Pharm.D., Ph.D.

University of Maryland School of Medicine

Baltimore, MD

Steven Bagley, M.D.

Palo Alto Veterans Administration Hospital

Palo Alto, CA

Mark Olfson, M.D.

Columbia University Medical Center

New York, NY

Daniel J. Safer, M.D.

Johns Hopkins Medicine

Baltimore, MD