# Introduction

## Background

Antipsychotics medications are approved by the U.S. Food and Drug Administration (FDA) for treatment of schizophrenia and bipolar disorder. These medications are commonly divided into two classes, reflecting two waves of historical development: the conventional antipsychotics and the atypical. The conventional antipsychotics served as the first successful pharmacologic treatment for primary psychotic disorders such as schizophrenia. Having been widely used for decades, the conventional antipsychotics also produced various side effects requiring additional medications, which spurred the development of the atypical antipsychotics.

Currently, nine atypical antipsychotic drugs have been approved by FDA: aripiprazole, asenapine, clozapine, iloperidone, olanzapine, paliperidone, quetiapine, risperidone, and ziprasidone. These drugs (except for the three recently approved ones—asenapine, iloperidone, and paliperidone) have been studied for off-label use in several conditions. A 2006 study1 on Efficacy and Comparative Effectiveness of Off-label Use of Atypical Antipsychotics reviewed the scientific evidence on the safety, efficacy, and effectiveness for off-label uses. Clozapine was excluded because of its association with a potentially fatal blood disorder of bone marrow suppression and requires frequent blood tests for safety monitoring. Rarely used, except for treatment of schizophrenia, the drug has proven refractory to other treatment. The 2006 study examined 84 published studies on atypical antipsychotics and found that the most common off-label uses of the drugs were treatment of depression, obsessive-compulsive disorder (OCD), post-traumatic stress disorder, personality disorders, Tourette's syndrome, autism, and agitation in dementia. It concluded that with few exceptions, there was insufficient high-quality evidence overall to reach conclusions about the efficacy of any off-label indications of these medications. It also found strong evidence that atypical antipsychotics can increase chances of adverse events such as significant weight gain, sedation, and gastrointestinal problems. Future research areas suggested by the study include safe treatment for agitation in dementia, association between the increased risk of death and antipsychotics drugs, and comparison of the development of adverse effects between patients taking atypical antipsychotics and those taking conventional antipsychotics.

Since publication of that report, important changes have occurred that could make it out of date. Studies have been published on new off-label uses, such as treatment of eating disorders, insomnia, attention-deficit hyperactivity disorder (ADHD), anxiety, and substance abuse. New or increased adverse effects of off-label indications have been observed and new atypicals (asenapine, iloperidone, and paliperidone) have been approved by FDA for the treatment of schizophrenia and bipolar disorder. In addition, the following previously off-label uses have been approved for on-label use by FDA:

- Quetiapine and quetiapine ER (extended release) as monotherapy in bipolar depression
- Quetiapine ER as augmentation for major depressive disorder (MDD)
- Aripiprazole as augmentation for MDD
- Olanzapine/fluoxetine combination for MDD
- Olanzapine/fluoxetine combination for bipolar depression
- Risperidone and aripiprazole for autism spectrum disorders.

An update is clearly needed to better understand the trend of off-label use and the risks and benefits associated with off-label use. Further, a number of issues remain unclear due to insufficient information in the previous report: subpopulations (i.e., race/ethnicity, gender) that would benefit most from atypical antipsychotics, appropriate dose, and time needed to see clinical improvement. This update will try to address these issues.

### Off-Label Conditions

The present study covers the following off-label uses of atypical antipsychotic medications: anxiety, ADHD, dementia and severe geriatric agitation, depression, eating disorder, insomnia, OCD, post-traumatic stress disorder (PTSD), personality disorders, substance abuse, and Tourette's syndrome. Autism (included in the original systematic review) will be reviewed in a study on the comparative effectiveness of typical and atypical antipsychotics for on-label indications, conducted by another EPC.

Anxiety. Anxiety disorders include a number of disorders where the primary feature is abnormal or pathological fear and anxiety. Major types of disorders in this category include acute stress disorder, agoraphobia (with or without a history of panic disorder), generalized anxiety disorder (GAD), OCD, panic disorder (with or without agoraphobia), specific and PTSD. We will report OCD and PTSD separately.

While anxiety is a normal reaction to stress, when it becomes an excessive, irrational dread of everyday situations, it is considered a disabling disorder.2 About 40 million American adults age 18 years and older (about 18 percent) suffer from anxiety disorders in a given year.3 Anxiety disorders can be treated with medication (e.g., antidepressants such as selective serotonin reuptake inhibitors or SSRIs, tricyclics), specific types of psychotherapy, or both.4

The most common anxiety disorder treated with atypicals is GAD. GAD is characterized by at least 6 months' persistent and excessive anxiety and worry. People with GAD cannot relax, cannot control the worry, startle easily, can be irritable, and have difficulty concentrating. GAD affects about 6.8 million American adults;3 and more women suffer from GAD than men.

Attention-Deficit Hyperactivity Disorder (ADHD). ADHD or AD/HD is a neurobehavioral developmental disorder. The Diagnostic and Statistical Manual of Mental Disorders, 4th. Edition, text revision (DSM-IV-TR) recognizes three major subtypes of ADHD: predominantly inattentive subtype, predominantly hyperactive-impulsive subtype, and combined inattentive/hyperactive-impulsive subtype. Inattention, hyperactivity, and impulsivity are the key features of ADHD. To be diagnosed, one must have six (or more) of the inattention symptoms or six (or more) of the hyperactivity-impulsivity symptoms that have persisted for at least 6 months; some impairment from the symptoms must be present in at least two settings (e.g., at home and at school/work); some symptoms that cause impairment must be present before age 7; the symptoms must be severe enough to be considered maladaptive, be inconsistent with the patient's level of development, and not be exclusively due to another condition.

Treatments for ADHD include medication, psychotherapy, educational interventions, or a combination of treatments. While ADHD is the most common disorder diagnosed in school-age children, it can continue through adolescence and adulthood, and is no longer considered only a childhood disorder.

Dementia and Severe Geriatric Agitation. Dementia is a disorder of acquired deficits in more than one domain of cognitive functioning. These domains are memory, language production and understanding, naming and recognition, skilled motor activity, and planning and executive functioning. The most common dementias—Alzheimer's and vascular dementia—are distinguished by their cause. Alzheimer's dementia occurs with an insidious onset and continues on a degenerative course to death after 8 to10 years;5 the intervening years are marked by significant disturbances of cognitive functioning and behavior, with severe debilitation in the ability to provide self-care. Vascular dementia refers to deficits of cognitive functioning that occur following either a cerebrovascular event—a stroke—leading to a macrovascular dementia, or, alternatively, more diffusely located changes in the smaller blood vessels, leading to a microvascular dementia. These (and other) dementia types commonly co-occur. Psychotic symptoms are frequent among dementia patients and include auditory hallucinations, believing that one's personal belongings have been stolen, or believing that unknown others are cohabiting with the patient (phantom boarders). Although the cognitive deficits can be severe, it is the behavioral disturbances (such as yelling or combativeness with caregivers) that typically interfere with independent living and necessitate placement in a nursing home.

Management of dementia patients includes both behavioral and psychopharmacologic interventions.6 Although behavioral interventions are commonly used with dementia patients, they require the presence of trained caregivers. Psychopharmacologic treatments developed specifically for dementia include acetylcholinesterase inhibitors, which attempt to compensate for the loss of neurons that produce the neurotransmitter acetylcholine by inhibiting the enzyme responsible for its degradation. Antipsychotics, including the atypicals, have been used to control both psychotic symptoms and severe behavioral agitation in dementia.

Depression. Depression refers to a potentially severe episodic disturbance of mood, with a constellation of low mood, inability to experience pleasure, sleep and appetite disturbances, loss of energy, difficulty concentrating, thoughts of guilt, worthlessness, and hopelessness, and suicidal ideation.7 Depression is best thought of as a symptom cluster that can appear in several different psychiatric disorders. These disorders are unipolar depression, bipolar depression, major depression with psychotic features, and depression occurring during psychotic disorders, such as schizophrenia or schizoaffective disorder. (Full descriptions of the diagnostic criteria for these disorders and others discussed in this report can be found in the latest edition of the Diagnostic and Statistical Manual of Mental Disorders, the DSM-IV-TR.)8

Unipolar depression refers to major depressive disorder and is defined by episodes of at least a majority of the above symptoms lasting at least two weeks. A particularly severe form of major depressive disorder occurs when the depression is accompanied by psychotic symptoms such as auditory hallucinations. Current treatment guidelines for the pharmacologic treatment of major depression are expressed algorithmically as a flowchart, with later steps tried after the failure of the earlier steps.9 Failure may occur for a variety of reasons, including intolerable side effects or lack of improvement after treatment of an appropriate duration. The mainstays of treatment are the antidepressants, including the serotonin reuptake inhibitors (SRIs), including citalopram, escitalopram, fluoxetine, paroxetine, and sertraline; the tricyclic antidepressants, including amitriptyline, imipramine, nortriptyline, and desipramine; and other drugs with dual reuptake inhibition or other mechanisms, including bupropion, duloxetine, mirtazapine, and venlafaxine. Other treatments used include augmenting agents, medications that are not themselves antidepressants, but that speed or improve the antidepressant activity; various psychotherapies; and electroconvulsive therapy. Because of their serotonergic effects, the atypical antipsychotics have been tested as augmenting agents. For depression with psychotic features, the recommended psychopharmacologic treatment, which consists of the simultaneous use of antidepressants and antipsychotics—most often atypical antipsychotics has been advocated.9,10

Eating Disorders. Eating disorders are a group of conditions characterized by severe disturbances in eating behavior. Disorders in this category include anorexia nervosa (refusing to maintain a minimally normal body weight) and bulimia nervosa (recurrent binge eating followed by compensatory behaviors such as self-induced vomiting).

DSM-IV-TR criteria8 for anorexia nervosa include a refusal to maintain body weight at or above a minimally normal weight for age and height, intense fear of gaining weight, three consecutive missed periods, and either refusal to admit the seriousness of the weight loss, or undue influence of shape or weight on one's self image, or a disturbed experience in one's shape or weight. Criteria for bulimia nervosa include recurrent binge eating and inappropriate compensatory behavior in order to prevent weight gain at least twice a week for 3 months, and self-evaluation unduly influenced by body shape and weight.

Causes of eating disorders are poorly understood. Eating disorders usually begin in late adolescence or early adult life, and affect both men and women, although women and girls are much more likely than men and boys to develop an eating disorder.11 Eating disorders are treatable with medications, nutritional counseling, and psychotherapy.11

Insomnia. Insomnia is one type of sleep disorder, characterized by persistent difficulty falling asleep and/or difficulty staying asleep. DSM-IV-TR8 organizes the sleep disorders into four major sections (primary sleep disorders, sleep disorder related to another mental disorder, sleep disorder due to a general medical condition, and substance-induced sleep disorder). This review defines insomnia broadly and covers all of the four types.

Causes of insomnia are various, including medications, pain from any injury, hormone shifts, mental disorders, restless legs syndrome, poor sleep hygiene (e.g., noise), medical conditions (e.g., hyperthyroidism), etc.12 Criteria for a diagnosis of primary insomnia include: difficulty initiating or maintaining sleep, or nonrestorative sleep for at least one month; the disturbance must cause significant distress or impairment in social, occupational, or other important functions; the disturbance does not occur exclusively during the course of another mental or medical disorder and is not due to the direct physiological effects of alcohol, medication, or other substances.8

Obsessive-Compulsive Disorder (OCD). The essential features of OCD are obsessions (repetitive, intrusive, unwanted thoughts, impulses, or images) and compensatory compulsive behaviors that reduce or remove the distress caused by the obsessions. A common example would involve obsessions about fears of contamination by dirt or germs, which give rise to compulsions to wash one's hands excessively.13 The distress caused by the obsessions, and the time devoted to, or the dysfunction caused by, the compulsions can lead to serious psychiatric morbidity. Standard treatments include psychopharmacologic approaches using SRIs, such as fluoxetine, and cognitive-behavioral therapy, which promotes a kind of learning through exposure to the feared or unpleasant stimulus and prevention of the compulsive response. Limited response to both treatments is common, and various psychopharmacologic agents, including the atypical antipsychotics, have been tested for their ability to augment SRIs.

Post-traumatic Stress Disorder (PTSD). PTSD describes the development of characteristic disabling symptoms following exposure to trauma such as war or rape. These symptoms are grouped into three clusters: re-experiencing (nightmares, flashbacks), avoidance and numbing (avoidance of reminders of the trauma, inability to recall the trauma, feelings of detachment, restriction of emotion), and increased arousal (anger, problems with concentration, hypervigilance, exaggerated startle response).14 The symptoms of PTSD span diverse psychiatric categories, and include mood, anxiety, and psychotic symptoms (including auditory hallucinations, suspicion, dissociation, and emotional withdrawal). Treatment of PTSD involves medications that address each of these classes of symptoms (including atypical antipsychotics) and cognitive-behavioral and other psychotherapies.

Personality Disorders. A personality disorder is “an enduring pattern of inner experience and behavior that deviates markedly from the expectations of the individual's culture, is pervasive and inflexible, has an onset in adolescence or early adulthood, is stable over time, and leads to distress or impairment.”8 The DSM-IV-TR defines 10 such disorders. Optimal treatment of such disorders is not well understood, although some of the disorders are the focus of active research. Because of the long-term nature of the disorders, they are often treated through psychotherapy in an attempt to facilitate long-term personality change, while psychiatric medications are thought to play a role in moderating some of the symptomatic manifestations. Only two personality disorders have been treated in clinical trials with atypical antipsychotics: schizotypal personality disorder (SPD) and borderline personality disorder (BPD).

SPD is defined by pervasive deficits in interpersonal relationships, cognitive and perceptual disturbances, and eccentric behavior. The perceptual and behavioral changes often appear similar to a mild form of schizophrenia, and there is some evidence of familial aggregation of SPD in relatives of those with schizophrenia.15 Because of this connection, treatment with atypical antipsychotics has been tried.

BPD's essential characteristic is instability in interpersonal relationships, self-image, and mood, along with impulsive behavior, intense anger, and recurrent suicidal gestures or attempts. There are often severe dissociative symptoms and paranoid ideation, which may occur or worsen with stress. BPD is a significant cause of psychiatric morbidity, and, because of the increased risk for suicide, mortality. Effective treatment of BPD is an area of active research. The cornerstone of treatment is psychotherapy of various kinds, with dialectical behavior therapy and mentalization-based therapy, among others, having shown some efficacy in clinical trials.16 Psychiatric medications are also commonly used, to treat both comorbid conditions, such as mood disorders, and the symptoms of BPD, although the evidence supporting such use is not strong. Because of the occurrence of psychotic symptoms, and because atypical antipsychotics have mood stabilizing properties, they have been tried in the treatment of BPD.

Substance Abuse. The present report covers the substance-use disorders (abuse and dependence). Substances reviewed in this report include alcohol, cocaine, marijuana, heroin, ecstasy, methamphetamine, and opioids. Caffeine or nicotine dependence is not included in the current review.

When the individual continues use of the substance despite significant problems related to the substance, substance dependence may be diagnosed. According to DSM-IV-TR,8 to be diagnosed as substance dependence, three (or more) of the following must be present within a 12-month period: (1) tolerance; (2) withdrawal; (3) the substance is often taken in larger amounts or over a longer period than was intended; (4) there is a persistent desire or unsuccessful efforts to cut down or control substance use; (5) a great deal of time is spent in activities necessary to obtain the substance, use the substance, or recover from its effects; (6) important social, occupational, or recreational activities are given up or reduced because of substance use; and (7) the substance use is continued despite knowledge of having a persistent or recurrent physical or psychological problem.

Substance abuse is a pattern of substance use leading to many adverse results from continual use. According to DSM-IV-TR,8 substance abuse involves one (or more) of the following within a 12-month period: (1) recurrent use resulting in a failure to fulfill major obligations at work, school, or home; (2) recurrent use in situations which are physically hazardous (e.g., driving while intoxicated); (3) legal problems resulting from recurrent use; or (4) continued use despite significant social or interpersonal problems caused by the substance use.

Tourette's Syndrome. Tourette's disorder refers to the condition of multiple motor and vocal tics, which are rapid, recurrent, stereotyped movements. Tics of Tourette's include eye blinking, facial grimacing, throat clearing, grunting, and, uncommonly, although most notably, coprolalia, the uttering of obscenities. The tics typically start around age 6 (the diagnosis requires that tics must appear by age 18). Pharmacologic treatments that have been tried include antipsychotic medications and medications from other classes, including clonidine, some of the tricyclic antidepressants, and benzodiazepines.

## Scope and Key Questions

### Key Questions

Key Question 1 What are the leading off-label uses of atypical antipsychotics in utilization studies? How have trends in utilization changed in recent years, including inpatient versus outpatient use? What new uses are being studied in trials?
Key Question 2 What does the evidence show regarding the efficacy and comparative effectiveness of atypical antipsychotics for off-label indications?
Sub-Key Question 2 How do atypical antipsychotic medications compare with other drugs, including conventional antipsychotics, for treating off-label indications?
Key Question 3 What subset of the population would potentially benefit from off-label uses? Do efficacy, effectiveness and harms differ by race/ethnicity, gender, and age group? By severity of condition and clinical subtype?
  Demographic subsets include different racial/ethnic groups, different age groups, and both genders. For clinical subsets, it is expected that only a small number of trials investigate specific subtypes (for example, inattentive vs. hyperactive-impulsive type ADHD) which makes a comparative study infeasible. When data are available, clinical subtypes of the conditions of interest will be examined (for instance, combat-related PTSD and non–combat-related PTSD). Severity subsets of population are categorized as groups with mild, moderate, or severe condition.
Key Question 4 What are the potential adverse effects and/or complications involved with off-label prescribing of atypical antipsychotics? How do they compare within the class and with other drugs used for the conditions?
Key Question 5 What is the effective dose and time limit for off-label indications?

### Scope

Study populations covered by the present review are adults, defined as being at least 18 years of age, with the following disorders: OCD, PTSD, personality disorders (primarily borderline), agitation in dementia (primarily in the elderly), anxiety, and major depressive disorder. The following disorders are also studied among children (younger than 12 years old) and adolescents (12 to 17 years old): eating disorders (including anorexia nervosa and bulimia), ADHD, Tourette's syndrome, and insomnia.

Interventions are the following atypical antipsychotics approved by FDA: aripiprazole, olanzapine, quetiapine, risperidone, ziprasidone, paliperidone, asenapine, and iloperidone. We included aripiprazole, olanzapine and quetiapine for depression, although these now are FDA approved for this indication, in order to provide readers with any potential direct or indirect evidence about comparative effectiveness with other atypical antipsychotics.

Four types of trials will be classified and examined:

1. “Head-to-head” trials: trials that compare one atypical antipsychotic to another and provide direct evidence of comparative efficacy;
2. “Active” controlled trials: trials that compare an atypical antipsychotic with another class of medication, often conventional antipsychotics;
3. “Placebo” controlled trials: trials that compare atypical antipsychotics with a placebo; and
4. “Augmentation” trials: trials that compare an antipsychotic taken with another medication with the other medication alone.

It is possible for a trial to include comparisons of more than one type; for example, a trial comparing risperidone, olanzapine, haloperidol, and placebo would include head-to-head, active, and placebo comparisons.

We will report efficacy and where available, effectiveness outcomes. For efficacy, we will report commonly used objective outcomes such as symptom scores, response rates, laboratory data, and time to disease recurrence; where effectiveness studies are available, we will report these outcomes plus general health outcomes (e.g., the SF-36) and quality of life.

All reported side effects and adverse events will be abstracted from clinical trials and large observational studies, regardless of study duration. The primary focus will be on the following adverse events: mortality, cardiovascular events (myocardial infarction, arrhythmia–tachycardia, and blood pressure increase/decrease), neurological events (cerebrovascular accident, akathisia, extrapyramidal symptoms, tardive dyskinesia, sedation, and dizziness), and metabolic disorders (weight gain/loss, hyperglycemia/diabetes, and hyperlipidemia).