# Adverse Events Analyses

Table F1 Children and adolescents—placebo controlled trials

| | | Placebo | | Atypicals
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI | NNH | 95% CI NNH
Appetite or Weight/Decrease | Aripiprazole | 1 | 15 | 25 | 13 | 18 | 1.71 | (0.40, 8.15) | NC | NC
Appetite or Weight/Decrease | Risperidone | 1 | 1 | 18 | 1 | 16 | 1.13 | (0.01, 94.13) | NC | NC
Appetite or Weight/Increase | Aripiprazole | 1 | 22 | 25 | 14 | 18 | 0.49 | (0.06, 3.35) | NC | NC
Appetite or Weight/Increase | Risperidone | 2 | 0 | 31 | 8 | 28 | +Inf | (2.52, Inf+ ) | 4.00 | (2.00, 8.00)
Cardiovascular | Aripiprazole | 1 | 10 | 25 | 9 | 18 | 1.49 | (0.37, 6.03) | NC | NC
Constitutional/Fever or Infection | Aripiprazole | 1 | 5 | 25 | 5 | 18 | 1.52 | (0.29, 8.12) | NC | NC
Dermatologic | Aripiprazole | 1 | 14 | 25 | 11 | 18 | 1.23 | (0.31, 5.11) | NC | NC
Endocrine | Ziprasidone | 1 | 0 | 12 | 1 | 16 | +Inf | (0.02, Inf+ ) | NC | NC
Endocrine/Prolactin | Ziprasidone | 1 | 0 | 12 | 5 | 16 | +Inf | (0.78, Inf+ ) | NC | NC
Gastrointestinal | Aripiprazole | 1 | 25 | 25 | 18 | 18 | NC | NC | NC | NC
Gastrointestinal | Risperidone | 2 | 5 | 31 | 6 | 28 | 1.45 | (0.28, 7.82) | NC | NC
HEENT | Aripiprazole | 1 | 25 | 25 | 18 | 18 | NC | NC | NC | NC
HEENT/Eye | Aripiprazole | 1 | 14 | 25 | 12 | 18 | 1.56 | (0.38, 6.81) | NC | NC
HEENT/Eye | Risperidone | 1 | 0 | 18 | 2 | 16 | +Inf | (0.21, Inf+ ) | NC | NC
Musculoskeletal | Aripiprazole | 1 | 6 | 25 | 3 | 18 | 0.64 | (0.09, 3.62) | NC | NC
Neuro | Aripiprazole | 1 | 25 | 25 | 18 | 18 | NC | NC | NC | NC
Neuro | Risperidone | 1 | 3 | 18 | 0 | 16 | 0.00 | (0.00, 2.64) | NC | NC
Neuro/Fatigue | Aripiprazole | 1 | 14 | 25 | 15 | 18 | 3.81 | (0.78, 25.71) | NC | NC
Neuro/Fatigue | Risperidone | 1 | 1 | 18 | 6 | 16 | 9.54 | (0.95, 496.02) | NC | NC
Neuro/Movement Disorder/Akathisia | Aripiprazole | 1 | 3 | 25 | 2 | 18 | 0.92 | (0.07, 9.02) | NC | NC
Neuro/Movement Disorder/Akathisia | Ziprasidone | 1 | 0 | 12 | 1 | 16 | +Inf | (0.02, Inf+ ) | NC | NC
Neuro/Movement Disorder/EPS | Aripiprazole | 1 | 8 | 25 | 15 | 18 | 9.96 | (2.03, 69.36) | 2.00 | (1.00, 4.00)
Neuro/Sedation | Aripiprazole | 1 | 25 | 25 | 18 | 18 | NC | NC | NC | NC
Neuro/Sedation | Risperidone | 2 | 3 | 31 | 4 | 28 | 1.53 | (0.24, 11.33) | NC | NC
Neuro/Sedation | Ziprasidone | 1 | 5 | 12 | 12 | 16 | 3.97 | (0.66, 28.56) | NC | NC
Neuro/Sensory | Aripiprazole | 1 | 13 | 25 | 8 | 18 | 0.74 | (0.18, 2.93) | NC | NC
Psychiatric | Risperidone | 1 | 0 | 18 | 2 | 16 | +Inf | (0.21, Inf+ ) | NC | NC
Psychiatric/Aggression | Aripiprazole | 1 | 9 | 25 | 10 | 18 | 2.18 | (0.55, 9.15) | NC | NC
Psychiatric/Agitation | Risperidone | 1 | 0 | 13 | 1 | 12 | +Inf | (0.03, Inf+ ) | NC | NC
Psychiatric/Anxiety | Aripiprazole | 1 | 25 | 25 | 18 | 18 | NC | NC | NC | NC
Psychiatric/Cognitive | Aripiprazole | 1 | 10 | 25 | 6 | 18 | 0.76 | (0.17, 3.13) | NC | NC
Psychiatric/Cognitive | Risperidone | 1 | 0 | 18 | 2 | 16 | +Inf | (0.21, Inf+ ) | NC | NC
Psychiatric/Depression | Aripiprazole | 1 | 14 | 25 | 8 | 18 | 0.64 | (0.16, 2.50) | NC | NC
Psychiatric/Mania | Aripiprazole | 1 | 8 | 25 | 5 | 18 | 0.82 | (0.17, 3.68) | NC | NC
Psychiatric/Sexual/Decreased Function | Risperidone | 1 | 0 | 18 | 2 | 16 | +Inf | (0.21, Inf+ ) | NC | NC
Psychiatric/Sleep | Risperidone | 1 | 1 | 18 | 1 | 16 | 1.13 | (0.01, 94.13) | NC | NC
Psychiatric/Suicidal Ideation | Aripiprazole | 1 | 5 | 25 | 5 | 18 | 1.52 | (0.29, 8.12) | NC | NC
Pulmonary | Aripiprazole | 1 | 9 | 25 | 7 | 18 | 1.13 | (0.27, 4.68) | NC | NC
Sweating | Aripiprazole | 1 | 11 | 25 | 10 | 18 | 1.57 | (0.40, 6.41) | NC | NC
Urinary | Aripiprazole | 1 | 2 | 25 | 1 | 18 | 0.68 | (0.01, 14.13) | NC | NC

CI = confidence interval; HEENT = head, eye, ear, nose, and throat; NC = not calculated; NNH = number needed to harm; OR = odds ratio

Table F2 Children and adolescents—atypical versus clonidine

| | | Clonidine | | Atypicals
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
HEENT/Decreased Salivation | Risperidone | 1 | 1 | 12 | 0 | 9 | 0.00 | (0.00, 52.00)
Neuro | Risperidone | 1 | 2 | 12 | 1 | 9 | 0.64 | (0.01, 14.44)
Neuro/Movement Disorder/EPS | Risperidone | 1 | 1 | 12 | 2 | 9 | 2.97 | (0.13, 201.94)
Neuro/Sedation | Risperidone | 1 | 5 | 12 | 1 | 9 | 0.19 | (0.00, 2.32)

CI = confidence interval; HEENT = head, eye, ear, nose, and throat; OR = odds ratio

Table F3 Children and adolescents—atypical versus conventionals

| | | Conventional | | Atypicals
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Increase | Risperidone | 1 | 20 | 24 | 22 | 26 | 1.10 | (0.18, 6.75)
Neuro/Fatigue | Risperidone | 1 | 9 | 24 | 10 | 26 | 1.04 | (0.29, 3.81)
Neuro/Headache | Risperidone | 1 | 2 | 24 | 5 | 26 | 2.57 | (0.37, 29.80)
Neuro/Movement Disorder | Risperidone | 1 | 5 | 24 | 2 | 26 | 0.32 | (0.03, 2.25)
Neuro/Movement Disorder/EPS | Risperidone | 1 | 8 | 24 | 4 | 26 | 0.37 | (0.07, 1.68)
Neuro/Sedation | Risperidone | 1 | 10 | 24 | 12 | 26 | 1.20 | (0.34, 4.25)
Psychiatric/Depression | Risperidone | 1 | 6 | 24 | 8 | 26 | 1.33 | (0.33, 5.68)
Psychiatric/Sleep | Risperidone | 1 | 7 | 24 | 1 | 26 | 0.10 | (0.00, 0.90)
Trauma | Risperidone | 1 | 6 | 24 | 1 | 26 | 0.12 | (0.00, 1.16)

CI = confidence interval; EPS = extrapyramidal symptoms; OR = odds ratio

Table F4 Non-elderly adults—placebo controlled trials

| | | Placebo | | Atypicals
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI | NNH
Accidental Overdose | Aripiprazole | 1 | 1 | 146 | 0 | 149 | 0.00 | (0.00, 38.21) | NC
Alcohol Related | Olanzapine | 1 | 0 | 159 | 1 | 155 | +Inf | (0.03, Inf+ ) | NC
Appetite or Weight/Decrease | Olanzapine | 1 | 1 | 159 | 0 | 155 | 0.00 | (0.00, 40.00) | NC
Appetite or Weight/Decrease | Quetiapine | 4 | 7 | 634 | 16 | 925 | 1.56 | (0.59, 4.56) | NC
Appetite or Weight/Decrease | Ziprasidone | 1 | 1 | 21 | 1 | 41 | 0.51 | (0.01, 41.19) | NC
Appetite or Weight/Increase | Aripiprazole | 4 | 8 | 686 | 35 | 701 | 4.18 | (1.88, 10.56) | 35
Appetite or Weight/Increase | Olanzapine | 11 | 103 | 819 | 382 | 818 | 11.30 | (8.22, 15.74) | 3
Appetite or Weight/Increase | Quetiapine | 13 | 90 | 1846 | 279 | 2887 | 2.71 | (2.07, 3.58) | 16
Appetite or Weight/Increase | Risperidone | 4 | 5 | 197 | 24 | 237 | 3.78 | (1.35, 13.09) | 21
Appetite or Weight/Increase | Ziprasidone | 2 | 2 | 113 | 5 | 251 | 1.24 | (0.19, 13.59) | NC
Cardiovascular | Olanzapine | 2 | 8 | 125 | 11 | 124 | 1.63 | (0.51, 5.57) | NC
Cardiovascular | Quetiapine | 2 | 4 | 192 | 1 | 186 | 0.26 | (0.01, 2.60) | NC
Cardiovascular | Risperidone | 1 | 1 | 133 | 4 | 141 | 3.84 | (0.37, 191.22) | NC
Cardiovascular | Ziprasidone | 1 | 0 | 48 | 2 | 91 | +Inf | (0.10, Inf+ ) | NC
Cardiovascular/BP/Decrease | Olanzapine | 3 | 22 | 433 | 20 | 422 | 1.02 | (0.44, 2.38) | NC
Cardiovascular/BP/Decrease | Quetiapine | 5 | 31 | 950 | 58 | 950 | 2.01 | (1.25, 3.30) | 27
Cardiovascular/BP/Decrease | Ziprasidone | 1 | 0 | 92 | 3 | 210 | +Inf | (0.18, Inf+ ) | NC
Cardiovascular/BP/Increase | Olanzapine | 1 | 6 | 377 | 2 | 370 | 0.34 | (0.03, 1.90) | NC
Cardiovascular/BP/Increase | Quetiapine | 3 | 81 | 568 | 122 | 568 | 1.71 | (1.22, 2.39) | 13
Cardiovascular/BP/Increase | Risperidone | 1 | 3 | 133 | 0 | 141 | 0.00 | (0.00, 2.27) | NC
Cardiovascular/Rhythm | Aripiprazole | 1 | 1 | 146 | 0 | 149 | 0.00 | (0.00, 38.21) | NC
Cardiovascular/Rhythm | Olanzapine | 1 | 1 | 377 | 1 | 370 | 1.02 | (0.01, 80.20) | NC
Cardiovascular/Rhythm | Quetiapine | 4 | 45 | 727 | 60 | 885 | 1.32 | (0.86, 2.03) | NC
Cardiovascular/Rhythm | Risperidone | 1 | 0 | 11 | 1 | 14 | +Inf | (0.02, Inf+ ) | NC
Cardiovascular/Rhythm | Ziprasidone | 1 | 0 | 21 | 1 | 41 | +Inf | (0.01, Inf+ ) | NC
Constitutional/Fever or Infection | Aripiprazole | 3 | 1 | 514 | 4 | 524 | 3.92 | (0.39, 193.38) | NC
Constitutional/Fever or Infection | Olanzapine | 1 | 5 | 16 | 2 | 18 | 0.29 | (0.02, 2.14) | NC
Constitutional/Fever or Infection | Quetiapine | 4 | 15 | 354 | 21 | 504 | 1.28 | (0.61, 2.75) | NC
Death | Quetiapine | 2 | 1 | 542 | 1 | 695 | 0.71 | (0.01, 58.88) | NC
Dermatologic | Olanzapine | 3 | 3 | 72 | 3 | 70 | 1.02 | (0.13, 7.90) | NC
Dermatologic | Quetiapine | 2 | 1 | 189 | 8 | 186 | +Inf | (1.51, Inf+ ) | 46
Dermatologic | Risperidone | 1 | 0 | 9 | 1 | 11 | +Inf | (0.02, Inf+ ) | NC
Dermatologic | Ziprasidone | 2 | 2 | 69 | 7 | 132 | 1.87 | (0.34, 18.94) | NC
Endocrine | Olanzapine | 2 | 15 | 190 | 31 | 184 | 2.37 | (1.18, 4.94) | 12
Endocrine | Quetiapine | 1 | 1 | 148 | 5 | 298 | 2.50 | (0.28, 119.45) | NC
Endocrine | Risperidone | 1 | 0 | 12 | 1 | 19 | +Inf | (0.02, Inf+ ) | NC
Endocrine | Ziprasidone | 1 | 0 | 30 | 2 | 30 | +Inf | (0.19, Inf+ ) | NC
Endocrine/Diabetes | Olanzapine | 1 | 1 | 377 | 5 | 370 | 5.14 | (0.57, 244.28) | NC
Endocrine/Diabetes | Quetiapine | 6 | 11 | 1073 | 32 | 1753 | 1.47 | (0.71, 3.28) | NC
Endocrine/Prolactin | Risperidone | 1 | 0 | 10 | 1 | 15 | +Inf | (0.02, Inf+ ) | NC
Gastrointestinal | Aripiprazole | 6 | 86 | 727 | 90 | 742 | 1.03 | (0.74, 1.43) | NC
Gastrointestinal | Olanzapine | 11 | 126 | 863 | 99 | 859 | 0.72 | (0.53, 0.98) | NC
Gastrointestinal | Quetiapine | 18 | 499 | 2291 | 785 | 3514 | 1.08 | (0.94, 1.24) | NC
Gastrointestinal | Risperidone | 5 | 44 | 253 | 34 | 290 | 0.62 | (0.36, 1.06) | NC
Gastrointestinal | Ziprasidone | 5 | 71 | 212 | 149 | 392 | 1.00 | (0.68, 1.48) | NC
HEENT | Olanzapine | 1 | 1 | 31 | 2 | 29 | 2.20 | (0.11, 136.07) | NC
HEENT | Quetiapine | 9 | 102 | 1634 | 112 | 2171 | 0.90 | (0.67, 1.20) | NC
HEENT | Risperidone | 1 | 8 | 133 | 5 | 141 | 0.58 | (0.14, 2.06) | NC
HEENT | Ziprasidone | 1 | 1 | 48 | 4 | 91 | 2.15 | (0.21, 108.65) | NC
HEENT/Decreased Salivation | Aripiprazole | 1 | 11 | 178 | 6 | 184 | 0.51 | (0.15, 1.55) | NC
HEENT/Decreased Salivation | Olanzapine | 8 | 59 | 826 | 126 | 810 | 2.64 | (1.86, 3.81) | 12
HEENT/Decreased Salivation | Quetiapine | 17 | 141 | 2084 | 961 | 3325 | 5.42 | (4.46, 6.61) | 7
HEENT/Decreased Salivation | Risperidone | 5 | 9 | 241 | 30 | 281 | 2.99 | (1.31, 7.54) | 17
HEENT/Decreased Salivation | Ziprasidone | 3 | 6 | 134 | 34 | 271 | 3.34 | (1.31, 10.20) | 15
HEENT/Eye | Aripiprazole | 2 | 6 | 350 | 25 | 361 | 4.25 | (1.68, 12.83) | 25
HEENT/Eye | Olanzapine | 1 | 5 | 100 | 1 | 101 | 0.19 | (0.00, 1.77) | NC
HEENT/Eye | Quetiapine | 4 | 9 | 467 | 29 | 769 | 2.09 | (0.94, 5.11) | NC
HEENT/Eye | Risperidone | 1 | 0 | 20 | 3 | 20 | +Inf | (0.43, Inf+ ) | NC
HEENT/Eye | Ziprasidone | 2 | 0 | 42 | 6 | 61 | +Inf | (1.07, Inf+ ) | NC
Heme | Quetiapine | 3 | 1 | 536 | 5 | 680 | 3.74 | (0.40, 180.66) | NC
Increased Cholesterol | Quetiapine | 3 | 73 | 528 | 149 | 1067 | 1.02 | (0.74, 1.40) | NC
Infections | Aripiprazole | 2 | 20 | 350 | 28 | 361 | 1.39 | (0.74, 2.65) | NC
Infections | Quetiapine | 4 | 42 | 722 | 46 | 1022 | 0.85 | (0.53, 1.38) | NC
Infections | Risperidone | 1 | 3 | 133 | 0 | 141 | 0.00 | (0.00, 2.27) | NC
Infections | Ziprasidone | 1 | 0 | 21 | 1 | 20 | +Inf | (0.03, Inf+ ) | NC
Liver Function Test Abnormality | Aripiprazole | 1 | 2 | 146 | 10 | 168 | 4.61 | (0.93, 44.57) | NC
Liver Function Test Abnormality | Olanzapine | 1 | 0 | 69 | 12 | 70 | +Inf | (3.16, Inf+ ) | NC
Liver Function Test Abnormality | Quetiapine | 1 | 2 | 216 | 0 | 216 | 0.00 | (0.00, 5.32) | NC
Liver Function Test Abnormality | Risperidone | 1 | 0 | 11 | 1 | 14 | +Inf | (0.02, Inf+ ) | NC
Liver Function Test Abnormality | Ziprasidone | 1 | 0 | 48 | 1 | 91 | +Inf | (0.01, Inf+ ) | NC
Metabolic Lab Abnormality | Quetiapine | 3 | 32 | 537 | 108 | 903 | 2.20 | (1.43, 3.47) | 18
Musculoskeletal | Aripiprazole | 1 | 1 | 178 | 0 | 184 | 0.00 | (0.00, 37.73) | NC
Musculoskeletal | Olanzapine | 3 | 14 | 59 | 14 | 59 | 1.01 | (0.18, 5.62) | NC
Musculoskeletal | Quetiapine | 5 | 29 | 748 | 60 | 906 | 1.86 | (1.16, 3.06) | 34
Musculoskeletal | Risperidone | 2 | 8 | 190 | 6 | 195 | 0.62 | (0.15, 2.21) | NC
Neuro | Aripiprazole | 6 | 127 | 795 | 111 | 805 | 0.83 | (0.62, 1.12) | NC
Neuro | Olanzapine | 8 | 56 | 377 | 74 | 369 | 1.55 | (1.00, 2.42) | 17
Neuro | Quetiapine | 19 | 508 | 2305 | 881 | 3551 | 1.24 | (1.09, 1.43) | 22
Neuro | Risperidone | 6 | 63 | 261 | 54 | 301 | 0.72 | (0.45, 1.15) | NC
Neuro | Ziprasidone | 5 | 18 | 212 | 58 | 404 | 1.95 | (1.06, 3.72) | 16
Neuro/Fatigue | Aripiprazole | 4 | 31 | 686 | 82 | 701 | 2.86 | (1.83, 4.55) | 15
Neuro/Fatigue | Olanzapine | 7 | 43 | 737 | 80 | 720 | 2.06 | (1.37, 3.12) | 19
Neuro/Fatigue | Quetiapine | 13 | 74 | 2010 | 289 | 3072 | 2.94 | (2.20, 3.97) | 18
Neuro/Fatigue | Risperidone | 4 | 9 | 233 | 9 | 274 | 0.83 | (0.28, 2.41) | NC
Neuro/Fatigue | Ziprasidone | 2 | 0 | 69 | 8 | 111 | +Inf | (1.59, Inf+ ) | NC
Neuro/Headache | Aripiprazole | 1 | 0 | 146 | 1 | 149 | +Inf | (0.03, Inf+ ) | NC
Neuro/Headache | Olanzapine | 3 | 94 | 506 | 68 | 495 | 0.69 | (0.48, 0.98) | NC
Neuro/Headache | Ziprasidone | 2 | 40 | 140 | 68 | 301 | 0.72 | (0.44, 1.17) | NC
Neuro/Movement Disorder | Olanzapine | 2 | 8 | 56 | 8 | 52 | 1.33 | (0.35, 5.13) | NC
Neuro/Movement Disorder | Quetiapine | 2 | 23 | 320 | 42 | 464 | 1.99 | (1.10, 3.66) | 16
Neuro/Movement Disorder | Ziprasidone | 1 | 0 | 30 | 0 | 30 | NC | NC | NC
Neuro/Movement Disorder/Akathisia | Aripiprazole | 5 | 24 | 769 | 190 | 779 | 11.78 | (7.40, 19.61) | 7
Neuro/Movement Disorder/Akathisia | Olanzapine | 1 | 7 | 25 | 9 | 23 | 2.04 | (0.50, 8.92) | NC
Neuro/Movement Disorder/Akathisia | Quetiapine | 4 | 5 | 488 | 10 | 632 | 1.31 | (0.38, 5.07) | NC
Neuro/Movement Disorder/Akathisia | Risperidone | 1 | 0 | 18 | 1 | 19 | +Inf | (0.02, Inf+ ) | NC
Neuro/Movement Disorder/Akathisia | Ziprasidone | 3 | 9 | 161 | 36 | 321 | 2.11 | (0.96, 5.15) | NC
Neuro/Movement Disorder/EPS | Aripiprazole | 5 | 43 | 605 | 99 | 610 | 2.75 | (1.83, 4.19) | 11
Neuro/Movement Disorder/EPS | Olanzapine | 3 | 18 | 65 | 17 | 71 | 0.87 | (0.25, 2.97) | NC
Neuro/Movement Disorder/EPS | Quetiapine | 7 | 35 | 1100 | 87 | 1466 | 2.62 | (1.72, 4.06) | 36
Neuro/Movement Disorder/EPS | Risperidone | 1 | 1 | 10 | 0 | 15 | 0.00 | (0.00, 26.00) | NC
Neuro/Movement Disorder/EPS | Ziprasidone | 3 | 6 | 161 | 28 | 321 | 3.12 | (1.15, 10.62) | 24
Neuro/Pain | Olanzapine | 2 | 5 | 85 | 13 | 88 | 2.74 | (0.86, 10.40) | NC
Neuro/Pain | Quetiapine | 7 | 65 | 1107 | 128 | 1609 | 1.59 | (1.13, 2.25) | 35
Neuro/Pain | Risperidone | 1 | 3 | 133 | 0 | 141 | 0.00 | (0.00, 2.27) | NC
Neuro/Pain | Ziprasidone | 2 | 12 | 140 | 26 | 301 | 1.02 | (0.48, 2.29) | NC
Neuro/Sedation | Aripiprazole | 7 | 73 | 810 | 160 | 820 | 3.03 | (2.15, 4.32) | 8
Neuro/Sedation | Olanzapine | 14 | 127 | 904 | 279 | 901 | 2.95 | (2.29, 3.82) | 6
Neuro/Sedation | Quetiapine | 18 | 373 | 2285 | 1668 | 3531 | 5.54 | (4.78, 6.43) | 3
Neuro/Sedation | Risperidone | 8 | 25 | 290 | 54 | 336 | 2.43 | (1.39, 4.34) | 11
Neuro/Sedation | Ziprasidone | 5 | 21 | 212 | 95 | 392 | 3.90 | (2.15, 7.44) | 6
Neuro/Sensory | Quetiapine | 1 | 2 | 157 | 4 | 157 | 2.02 | (0.29, 22.66) | NC
Neuro/Speech Disorder | Quetiapine | 1 | 0 | 21 | 1 | 21 | +Inf | (0.03, Inf+ ) | NC
Psychiatric | Aripiprazole | 1 | 1 | 146 | 0 | 149 | 0.00 | (0.00, 38.21) | NC
Psychiatric | Olanzapine | 4 | 27 | 313 | 16 | 303 | 0.58 | (0.27, 1.22) | NC
Psychiatric | Quetiapine | 1 | 1 | 21 | 1 | 21 | 1.00 | (0.01, 82.37) | NC
Psychiatric | Ziprasidone | 1 | 5 | 21 | 24 | 41 | 4.41 | (1.24, 18.48) | 3
Psychiatric/Aggression | Olanzapine | 3 | 16 | 288 | 8 | 280 | 0.49 | (0.17, 1.25) | NC
Psychiatric/Agitation | Aripiprazole | 7 | 28 | 803 | 108 | 813 | 4.26 | (2.75, 6.80) | 13
Psychiatric/Agitation | Olanzapine | 3 | 31 | 288 | 19 | 280 | 0.57 | (0.28, 1.11) | NC
Psychiatric/Agitation | Quetiapine | 3 | 3 | 521 | 13 | 671 | 3.35 | (0.90, 18.65) | NC
Psychiatric/Agitation | Ziprasidone | 3 | 16 | 161 | 27 | 321 | 0.84 | (0.42, 1.74) | NC
Psychiatric/Anxiety | Aripiprazole | 4 | 28 | 270 | 57 | 268 | 2.40 | (1.42, 4.12) | 9
Psychiatric/Anxiety | Olanzapine | 6 | 89 | 708 | 70 | 691 | 0.76 | (0.53, 1.09) | NC
Psychiatric/Anxiety | Quetiapine | 5 | 19 | 936 | 32 | 1314 | 1.36 | (0.73, 2.58) | NC
Psychiatric/Apathy | Quetiapine | 1 | 2 | 20 | 3 | 20 | 1.57 | (0.16, 20.98) | NC
Psychiatric/Cognitive | Aripiprazole | 1 | 3 | 146 | 14 | 149 | 4.92 | (1.33, 27.29) | 19
Psychiatric/Cognitive | Olanzapine | 1 | 1 | 25 | 5 | 23 | 6.51 | (0.64, 333.53) | NC
Psychiatric/Cognitive | Quetiapine | 4 | 9 | 226 | 18 | 378 | 1.56 | (0.64, 4.11) | NC
Psychiatric/Cognitive | Risperidone | 1 | 0 | 133 | 3 | 141 | +Inf | (0.39, Inf+ ) | NC
Psychiatric/Cognitive | Ziprasidone | 1 | 0 | 21 | 2 | 20 | +Inf | (0.20, Inf+ ) | NC
Psychiatric/Depression | Aripiprazole | 2 | 15 | 98 | 9 | 93 | 0.57 | (0.20, 1.54) | NC
Psychiatric/Depression | Olanzapine | 3 | 12 | 259 | 11 | 254 | 0.91 | (0.35, 2.38) | NC
Psychiatric/Depression | Quetiapine | 2 | 8 | 180 | 16 | 327 | 1.78 | (0.63, 5.52) | NC
Psychiatric/Depression | Ziprasidone | 1 | 0 | 21 | 4 | 41 | +Inf | (0.34, Inf+ ) | NC
Psychiatric/Irritability | Quetiapine | 7 | 50 | 1081 | 70 | 1739 | 0.82 | (0.55, 1.23) | NC
Psychiatric/Irritability | Risperidone | 1 | 0 | 57 | 1 | 54 | +Inf | (0.03, Inf+ ) | NC
Psychiatric/Mania | Aripiprazole | 1 | 11 | 83 | 5 | 78 | 0.40 | (0.09, 1.45) | NC
Psychiatric/Mania | Quetiapine | 1 | 7 | 181 | 9 | 361 | 0.63 | (0.21, 2.04) | NC
Psychiatric/Self-Injurious Behavior | Aripiprazole | 2 | 8 | 172 | 2 | 175 | 0.20 | (0.02, 1.16) | NC
Psychiatric/Self-Injurious Behavior | Olanzapine | 1 | 0 | 159 | 1 | 155 | +Inf | (0.03, Inf+ ) | NC
Psychiatric/Serious | Ziprasidone | 1 | 3 | 30 | 4 | 30 | 1.38 | (0.21, 10.33) | NC
Psychiatric/Sexual/Decreased Function | Olanzapine | 3 | 12 | 55 | 13 | 53 | 1.32 | (0.48, 3.68) | NC
Psychiatric/Sexual/Decreased Function | Quetiapine | 5 | 23 | 579 | 28 | 951 | 0.97 | (0.48, 1.98) | NC
Psychiatric/Sexual/Decreased Function | Risperidone | 3 | 4 | 28 | 1 | 37 | 0.19 | (0.00, 2.07) | NC
Psychiatric/Sexual/Decreased Function | Ziprasidone | 1 | 0 | 92 | 2 | 210 | +Inf | (0.08, Inf+ ) | NC
Psychiatric/Sleep | Aripiprazole | 2 | 24 | 98 | 25 | 93 | 1.21 | (0.56, 2.66) | NC
Psychiatric/Sleep | Olanzapine | 2 | 77 | 477 | 39 | 471 | 0.46 | (0.30, 0.71) | NC
Psychiatric/Sleep | Quetiapine | 6 | 46 | 607 | 34 | 906 | 0.57 | (0.35, 0.93) | NC
Psychiatric/Sleep | Ziprasidone | 3 | 15 | 161 | 28 | 342 | 0.82 | (0.40, 1.72) | NC
Psychiatric/Suicidal Ideation | Aripiprazole | 2 | 2 | 350 | 1 | 361 | 0.48 | (0.01, 9.32) | NC
Psychiatric/Suicidal Ideation | Olanzapine | 1 | 4 | 159 | 10 | 155 | 2.66 | (0.75, 11.90) | NC
Psychiatric/Suicidal Ideation | Quetiapine | 3 | 2 | 544 | 6 | 536 | 3.08 | (0.55, 31.38) | NC
Psychiatric/Suicidal Ideation | Risperidone | 2 | 0 | 22 | 2 | 34 | +Inf | (0.12, Inf+ ) | NC
Pulmonary | Quetiapine | 1 | 4 | 157 | 5 | 157 | 1.26 | (0.27, 6.46) | NC
Pulmonary | Ziprasidone | 1 | 2 | 48 | 8 | 91 | 2.21 | (0.42, 22.18) | NC
Sweating | Quetiapine | 6 | 31 | 524 | 28 | 828 | 0.75 | (0.41, 1.37) | NC
Thirst | Olanzapine | 1 | 0 | 5 | 1 | 7 | +Inf | (0.02, Inf+ ) | NC
Thirst | Quetiapine | 3 | 0 | 310 | 6 | 465 | +Inf | (0.97, Inf+ ) | NC
Trauma | Aripiprazole | 1 | 1 | 178 | 0 | 184 | 0.00 | (0.00, 37.73) | NC
Trauma | Quetiapine | 1 | 1 | 148 | 4 | 298 | 2.00 | (0.20, 99.16) | NC
Urinary | Quetiapine | 3 | 7 | 571 | 20 | 724 | 2.31 | (0.92, 6.59) | NC
Urinary | Risperidone | 1 | 0 | 8 | 1 | 8 | +Inf | (0.03, Inf+ ) | NC

CI = confidence interval; HEENT = head, eye, ear, nose, and throat; NC = not calculated; NNH = number needed to harm; OR = odds ratio

Table F5 Non-elderly adults—atypicals versus conventionals

| | | Conventional | | Atypicals
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Decrease | Olanzapine | 1 | 115 | 636 | 149 | 1306 | 0.58 | (0.44, 0.77)
Appetite or Weight/Increase | Aripiprazole | 1 | 14 | 431 | 44 | 859 | 1.61 | (0.85, 3.21)
Appetite or Weight/Increase | Olanzapine | 4 | 112 | 808 | 404 | 1486 | 2.72 | (2.13, 3.50)
Cardiovascular/BP/Decrease | Olanzapine | 1 | 1 | 7 | 0 | 8 | 0.00 | (0.00, 34.12)
Cardiovascular/Rhythm | Olanzapine | 1 | 63 | 636 | 86 | 1306 | 0.64 | (0.45, 0.92)
Constitutional | Olanzapine | 1 | 36 | 636 | 45 | 1306 | 0.59 | (0.37, 0.96)
Constitutional/Fever or Infection | Olanzapine | 1 | 48 | 636 | 56 | 1306 | 0.55 | (0.36, 0.84)
Endocrine/Diabetes | Olanzapine | 1 | 0 | 26 | 0 | 35 | NC | NC
Gastrointestinal | Olanzapine | 2 | 161 | 768 | 209 | 1437 | 0.60 | (0.48, 0.77)
HEENT/Decreased Salivation | Olanzapine | 1 | 103 | 636 | 290 | 1306 | 1.48 | (1.15, 1.91)
HEENT/Eye | Olanzapine | 1 | 96 | 636 | 139 | 1306 | 0.67 | (0.50, 0.90)
HEENT/Increased Salivation | Olanzapine | 1 | 124 | 636 | 113 | 1306 | 0.39 | (0.29, 0.52)
Heme | Olanzapine | 1 | 0 | 132 | 6 | 131 | +Inf | (1.22, Inf+ )
Musculoskeletal | Olanzapine | 1 | 16 | 132 | 4 | 131 | 0.25 | (0.06, 0.80)
Neuro | Aripiprazole | 1 | 38 | 431 | 65 | 859 | 0.85 | (0.55, 1.32)
Neuro/Fatigue | Olanzapine | 1 | 104 | 636 | 150 | 1306 | 0.66 | (0.50, 0.88)
Neuro/Movement Disorder | Olanzapine | 1 | 115 | 636 | 102 | 1306 | 0.38 | (0.29, 0.52)
Neuro/Movement Disorder/Akathisia | Aripiprazole | 1 | 108 | 431 | 111 | 859 | 0.44 | (0.33, 0.60)
Neuro/Movement Disorder/Akathisia | Olanzapine | 2 | 266 | 768 | 203 | 1437 | 0.31 | (0.25, 0.38)
Neuro/Movement Disorder/EPS | Aripiprazole | 1 | 171 | 431 | 118 | 859 | 0.24 | (0.18, 0.32)
Neuro/Movement Disorder/EPS | Olanzapine | 4 | 414 | 808 | 371 | 1486 | 0.28 | (0.23, 0.33)
Neuro/Movement Disorder/Gait | Olanzapine | 1 | 20 | 636 | 22 | 1306 | 0.53 | (0.27, 1.03)
Neuro/Sedation | Aripiprazole | 1 | 32 | 431 | 43 | 859 | 0.66 | (0.40, 1.09)
Neuro/Sedation | Olanzapine | 3 | 220 | 669 | 340 | 1349 | 0.69 | (0.56, 0.85)
Psychiatric | Olanzapine | 1 | 15 | 636 | 13 | 1306 | 0.42 | (0.18, 0.94)
Psychiatric/Agitation | Aripiprazole | 1 | 30 | 431 | 53 | 859 | 0.88 | (0.54, 1.45)
Psychiatric/Anxiety | Aripiprazole | 1 | 50 | 431 | 108 | 859 | 1.10 | (0.76, 1.60)
Psychiatric/Anxiety | Olanzapine | 1 | 51 | 132 | 27 | 131 | 0.41 | (0.22, 0.73)
Psychiatric/Lability | Olanzapine | 1 | 7 | 132 | 10 | 131 | 1.55 | (0.48, 5.45)
Psychiatric/Psychotic | Aripiprazole | 1 | 70 | 431 | 156 | 859 | 1.14 | (0.83, 1.58)
Psychiatric/Sleep | Aripiprazole | 1 | 88 | 431 | 185 | 859 | 1.07 | (0.80, 1.44)
Psychiatric/Sleep | Olanzapine | 1 | 632 | 636 | 1122 | 1306 | 0.03 | (0.01, 0.09)
Sweating | Olanzapine | 1 | 84 | 636 | 89 | 1306 | 0.48 | (0.35, 0.67)
Urinary | Olanzapine | 1 | 39 | 636 | 47 | 1306 | 0.57 | (0.36, 0.91)

CI = confidence interval; HEENT = head, eye, ear, nose, and throat; NC = not calculated; OR = odds ratio

Table F6 Dementia—placebo controlled trials

| | | Placebo | | Atypicals
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI | NNH
Anticholinergic Events | Olanzapine | 1 | 12 | 90 | 60 | 178 | 3.29 | (1.62, 7.17) | 6
Appetite or Weight/Decrease | Aripiprazole | 2 | 35 | 246 | 82 | 497 | 0.69 | (0.43, 1.14) | NC
Appetite or Weight/Decrease | Olanzapine | 2 | 15 | 141 | 32 | 363 | 0.75 | (0.38, 1.56) | NC
Appetite or Weight/Decrease | Quetiapine | 1 | 8 | 92 | 18 | 241 | 0.85 | (0.34, 2.34) | NC
Appetite or Weight/Decrease | Risperidone | 1 | 8 | 94 | 11 | 196 | 0.64 | (0.23, 1.90) | NC
Appetite or Weight/Increase | Aripiprazole | 2 | 10 | 223 | 23 | 472 | 1.02 | (0.44, 2.49) | NC
Appetite or Weight/Increase | Olanzapine | 3 | 6 | 326 | 34 | 482 | 4.69 | (1.87, 14.14) | 24
Appetite or Weight/Increase | Quetiapine | 1 | 4 | 142 | 5 | 94 | 1.93 | (0.40, 10.01) | NC
Appetite or Weight/Increase | Risperidone | 2 | 5 | 236 | 14 | 281 | 3.40 | (1.08, 12.75) | 24
Cardiovascular | Aripiprazole | 1 | 12 | 121 | 42 | 366 | 1.18 | (0.58, 2.55) | NC
Cardiovascular | Olanzapine | 5 | 9 | 440 | 40 | 778 | 2.33 | (1.08, 5.61) | 48
Cardiovascular | Quetiapine | 3 | 15 | 254 | 29 | 355 | 1.08 | (0.53, 2.30) | NC
Cardiovascular | Risperidone | 6 | 34 | 1010 | 119 | 1757 | 2.08 | (1.38, 3.22) | 34
Cardiovascular/BP/Increase | Aripiprazole | 1 | 5 | 102 | 4 | 106 | 0.76 | (0.15, 3.65) | NC
Cardiovascular/BP/Increase | Olanzapine | 1 | 1 | 67 | 2 | 137 | 0.98 | (0.05, 58.55) | NC
Cardiovascular/BP/Increase | Quetiapine | 1 | 0 | 20 | 1 | 20 | +Inf | (0.03, Inf+ ) | NC
Cardiovascular/Rhythm | Aripiprazole | 3 | 2 | 253 | 6 | 340 | 2.25 | (0.38, 23.74) | NC
Cardiovascular/Rhythm | Olanzapine | 2 | 6 | 209 | 3 | 237 | 0.37 | (0.06, 1.85) | NC
Cardiovascular/Rhythm | Quetiapine | 1 | 4 | 142 | 3 | 94 | 1.14 | (0.16, 6.89) | NC
Cardiovascular/Rhythm | Risperidone | 2 | 10 | 161 | 8 | 105 | 0.85 | (0.24, 2.83) | NC
Constitutional/Fever or Infection | Aripiprazole | 1 | 0 | 26 | 1 | 103 | +Inf | (0.01, Inf+ ) | NC
Constitutional/Fever or Infection | Olanzapine | 3 | 5 | 231 | 38 | 541 | 3.23 | (1.23, 10.71) | 34
Constitutional/Fever or Infection | Quetiapine | 1 | 6 | 99 | 3 | 91 | 0.53 | (0.08, 2.57) | NC
Constitutional/Fever or Infection | Risperidone | 3 | 19 | 427 | 59 | 825 | 1.41 | (0.80, 2.57) | NC
Death | Aripiprazole | 3 | 3 | 253 | 8 | 340 | 2.37 | (0.55, 14.18) | NC
Death | Olanzapine | 2 | 4 | 232 | 2 | 278 | 0.48 | (0.04, 3.62) | NC
Death | Quetiapine | 2 | 7 | 241 | 5 | 185 | 0.91 | (0.22, 3.41) | NC
Death | Risperidone | 5 | 17 | 916 | 39 | 1561 | 1.19 | (0.63, 2.31) | NC
Dermatologic | Aripiprazole | 2 | 76 | 246 | 136 | 497 | 0.93 | (0.65, 1.33) | NC
Dermatologic | Olanzapine | 1 | 7 | 47 | 19 | 159 | 0.78 | (0.29, 2.35) | NC
Dermatologic | Quetiapine | 1 | 13 | 99 | 12 | 91 | 1.00 | (0.39, 2.55) | NC
Dermatologic | Risperidone | 2 | 82 | 333 | 133 | 629 | 1.24 | (0.87, 1.79) | NC
Endocrine/Diabetes | Risperidone | 1 | 5 | 238 | 4 | 235 | 0.81 | (0.16, 3.80) | NC
Endocrine/Prolactin | Risperidone | 1 | 0 | 238 | 0 | 235 | NC | NC | NC
Gastrointestinal | Aripiprazole | 3 | 35 | 272 | 107 | 600 | 1.33 | (0.85, 2.12) | NC
Gastrointestinal | Olanzapine | 2 | 11 | 232 | 30 | 278 | 2.01 | (0.93, 4.64) | NC
Gastrointestinal | Quetiapine | 4 | 21 | 353 | 56 | 446 | 1.67 | (0.95, 3.05) | NC
Gastrointestinal | Risperidone | 2 | 66 | 312 | 40 | 252 | 0.54 | (0.33, 0.87) | NC
HEENT | Aripiprazole | 1 | 6 | 121 | 17 | 366 | 0.93 | (0.34, 2.96) | NC
HEENT | Olanzapine | 1 | 3 | 47 | 16 | 159 | 1.64 | (0.44, 9.17) | NC
HEENT | Quetiapine | 1 | 10 | 99 | 5 | 91 | 0.52 | (0.13, 1.75) | NC
HEENT | Risperidone | 2 | 27 | 333 | 80 | 629 | 1.27 | (0.78, 2.12) | NC
HEENT/Decreased Salivation | Quetiapine | 1 | 0 | 20 | 1 | 20 | +Inf | (0.03, Inf+ ) | NC
HEENT/Eye | Aripiprazole | 1 | 3 | 121 | 13 | 366 | 1.45 | (0.39, 8.05) | NC
HEENT/Eye | Olanzapine | 1 | 1 | 142 | 0 | 100 | 0.00 | (0.00, 55.38) | NC
HEENT/Eye | Quetiapine | 1 | 1 | 142 | 0 | 94 | 0.00 | (0.00, 58.92) | NC
HEENT/Eye | Risperidone | 2 | 19 | 312 | 20 | 252 | 1.10 | (0.53, 2.26) | NC
HEENT/Increased Salivation | Aripiprazole | 1 | 1 | 121 | 13 | 366 | 4.41 | (0.65, 189.35) | NC
Heme | Aripiprazole | 1 | 8 | 125 | 14 | 131 | 2.01 | (0.73, 6.11) | NC
Heme | Olanzapine | 1 | 1 | 142 | 1 | 100 | 1.42 | (0.02, 112.58) | NC
Heme | Quetiapine | 1 | 1 | 142 | 2 | 94 | 3.05 | (0.16, 182.09) | NC
Heme | Risperidone | 2 | 13 | 380 | 10 | 320 | 0.82 | (0.32, 2.08) | NC
Infections | Aripiprazole | 1 | 16 | 121 | 66 | 366 | 1.44 | (0.78, 2.79) | NC
Infections | Olanzapine | 1 | 5 | 90 | 10 | 178 | 1.01 | (0.30, 3.90) | NC
Infections | Quetiapine | 2 | 9 | 191 | 25 | 332 | 2.08 | (0.88, 5.32) | NC
Infections | Risperidone | 2 | 33 | 333 | 54 | 629 | 1.05 | (0.64, 1.75) | NC
Liver Function Test Abnormality | Aripiprazole | 1 | 1 | 102 | 0 | 106 | 0.00 | (0.00, 37.53) | NC
Musculoskeletal | Olanzapine | 1 | 3 | 90 | 0 | 178 | 0.00 | (0.00, 1.21) | NC
Neuro | Aripiprazole | 1 | 9 | 121 | 52 | 366 | 2.06 | (0.96, 4.91) | NC
Neuro | Olanzapine | 3 | 38 | 326 | 104 | 482 | 2.51 | (1.62, 3.96) | 8
Neuro | Quetiapine | 4 | 23 | 353 | 36 | 446 | 1.83 | (0.99, 3.45) | NC
Neuro | Risperidone | 2 | 29 | 236 | 53 | 281 | 1.93 | (1.12, 3.37) | 12
Neuro/CVA | Aripiprazole | 3 | 2 | 253 | 2 | 340 | 0.70 | (0.05, 10.48) | NC
Neuro/CVA | Olanzapine | 2 | 4 | 232 | 6 | 278 | 1.46 | (0.33, 7.44) | NC
Neuro/CVA | Quetiapine | 2 | 6 | 241 | 3 | 185 | 0.65 | (0.10, 3.08) | NC
Neuro/CVA | Risperidone | 4 | 8 | 753 | 24 | 1099 | 3.12 | (1.32, 8.21) | 53
Neuro/Fatigue | Aripiprazole | 3 | 11 | 272 | 47 | 600 | 2.44 | (1.19, 5.43) | 22
Neuro/Fatigue | Olanzapine | 3 | 9 | 326 | 36 | 482 | 2.37 | (1.08, 5.75) | 34
Neuro/Fatigue | Quetiapine | 2 | 5 | 234 | 25 | 335 | 2.92 | (1.03, 10.26) | 34
Neuro/Fatigue | Risperidone | 2 | 4 | 236 | 20 | 281 | 3.56 | (1.13, 14.96) | 34
Neuro/Headache | Olanzapine | 1 | 0 | 67 | 4 | 137 | +Inf | (0.32, Inf+ ) | NC
Neuro/Headache | Risperidone | 1 | 11 | 170 | 8 | 167 | 0.73 | (0.25, 2.05) | NC
Neuro/Movement Disorder | Olanzapine | 1 | 2 | 142 | 10 | 100 | 7.72 | (1.59, 74.05) | 15
Neuro/Movement Disorder | Quetiapine | 1 | 2 | 142 | 5 | 94 | 3.91 | (0.62, 41.89) | NC
Neuro/Movement Disorder | Risperidone | 1 | 2 | 142 | 7 | 85 | 6.23 | (1.15, 62.91) | 16
Neuro/Movement Disorder/Akathisia | Olanzapine | 1 | 0 | 142 | 1 | 100 | +Inf | (0.04, Inf+ ) | NC
Neuro/Movement Disorder/Akathisia | Quetiapine | 2 | 1 | 162 | 1 | 114 | 1.23 | (0.02, 98.52) | NC
Neuro/Movement Disorder/Akathisia | Risperidone | 1 | 0 | 142 | 0 | 85 | NC | NC | NC
Neuro/Movement Disorder/EPS | Aripiprazole | 4 | 16 | 374 | 39 | 706 | 1.29 | (0.68, 2.57) | NC
Neuro/Movement Disorder/EPS | Olanzapine | 1 | 2 | 142 | 18 | 100 | 15.21 | (3.50, 138.55) | 10
Neuro/Movement Disorder/EPS | Quetiapine | 3 | 9 | 254 | 18 | 355 | 1.15 | (0.46, 3.08) | NC
Neuro/Movement Disorder/EPS | Risperidone | 5 | 31 | 916 | 130 | 1561 | 3.00 | (1.96, 4.70) | 20
Neuro/Movement Disorder/Gait | Aripiprazole | 1 | 1 | 121 | 16 | 366 | 5.47 | (0.83, 231.93) | NC
Neuro/Movement Disorder/Gait | Olanzapine | 4 | 15 | 373 | 79 | 641 | 2.75 | (1.52, 5.29) | 21
Neuro/Movement Disorder/Gait | Quetiapine | 3 | 6 | 333 | 18 | 426 | 2.36 | (0.85, 7.59) | NC
Neuro/Movement Disorder/Gait | Risperidone | 3 | 8 | 406 | 32 | 448 | 3.04 | (1.32, 7.84) | 33
Neuro/Movement Disorder/Tardive Dyskinesia | Olanzapine | 1 | 4 | 142 | 3 | 100 | 1.07 | (0.15, 6.46) | NC
Neuro/Movement Disorder/Tardive Dyskinesia | Quetiapine | 1 | 4 | 142 | 2 | 94 | 0.75 | (0.07, 5.36) | NC
Neuro/Movement Disorder/Tardive Dyskinesia | Risperidone | 4 | 14 | 713 | 4 | 949 | 0.31 | (0.07, 1.03) | NC
Neuro/Pain | Aripiprazole | 1 | 11 | 121 | 49 | 366 | 1.54 | (0.76, 3.41) | NC
Neuro/Pain | Olanzapine | 2 | 10 | 137 | 36 | 337 | 1.31 | (0.60, 3.10) | NC
Neuro/Pain | Quetiapine | 1 | 11 | 99 | 12 | 91 | 1.21 | (0.46, 3.23) | NC
Neuro/Pain | Risperidone | 1 | 13 | 163 | 33 | 462 | 0.89 | (0.44, 1.89) | NC
Neuro/Sedation | Aripiprazole | 4 | 22 | 374 | 116 | 706 | 2.62 | (1.57, 4.54) | 16
Neuro/Sedation | Olanzapine | 5 | 25 | 440 | 158 | 778 | 4.58 | (2.87, 7.55) | 9
Neuro/Sedation | Quetiapine | 4 | 18 | 353 | 84 | 446 | 5.16 | (2.93, 9.51) | 8
Neuro/Sedation | Risperidone | 6 | 102 | 922 | 265 | 1260 | 2.33 | (1.79, 3.05) | 10
Psychiatric/Aggression | Olanzapine | 1 | 1 | 94 | 14 | 204 | 6.82 | (1.01, 292.81) | 41
Psychiatric/Aggression | Risperidone | 2 | 19 | 264 | 22 | 363 | 0.91 | (0.45, 1.85) | NC
Psychiatric/Agitation | Aripiprazole | 3 | 37 | 272 | 46 | 600 | 0.54 | (0.32, 0.89) | NC
Psychiatric/Agitation | Olanzapine | 4 | 36 | 373 | 76 | 641 | 1.19 | (0.76, 1.90) | NC
Psychiatric/Agitation | Quetiapine | 2 | 35 | 241 | 18 | 185 | 0.61 | (0.31, 1.16) | NC
Psychiatric/Agitation | Risperidone | 5 | 102 | 807 | 120 | 1145 | 0.84 | (0.62, 1.14) | NC
Psychiatric/Anxiety | Olanzapine | 4 | 19 | 373 | 40 | 641 | 1.04 | (0.57, 1.95) | NC
Psychiatric/Anxiety | Quetiapine | 1 | 3 | 142 | 0 | 94 | 0.00 | (0.00, 3.65) | NC
Psychiatric/Anxiety | Risperidone | 2 | 12 | 236 | 20 | 281 | 0.89 | (0.39, 2.12) | NC
Psychiatric/Cognitive | Aripiprazole | 1 | 0 | 26 | 3 | 103 | +Inf | (0.10, Inf+ ) | NC
Psychiatric/Cognitive | Olanzapine | 2 | 3 | 232 | 15 | 278 | 4.00 | (1.08, 22.38) | 38
Psychiatric/Cognitive | Quetiapine | 1 | 1 | 142 | 0 | 94 | 0.00 | (0.00, 58.92) | NC
Psychiatric/Cognitive | Risperidone | 1 | 1 | 142 | 1 | 85 | 1.67 | (0.02, 132.68) | NC
Psychiatric/Depression | Olanzapine | 2 | 4 | 232 | 16 | 278 | 3.05 | (0.94, 13.04) | NC
Psychiatric/Depression | Quetiapine | 1 | 2 | 142 | 2 | 94 | 1.52 | (0.11, 21.30) | NC
Psychiatric/Depression | Risperidone | 1 | 2 | 142 | 0 | 85 | 0.00 | (0.00, 8.90) | NC
Psychiatric/Psychotic | Olanzapine | 3 | 14 | 326 | 62 | 482 | 2.81 | (1.49, 5.64) | 18
Psychiatric/Psychotic | Quetiapine | 1 | 3 | 142 | 0 | 94 | 0.00 | (0.00, 3.65) | NC
Psychiatric/Psychotic | Risperidone | 2 | 13 | 236 | 32 | 281 | 1.35 | (0.65, 2.96) | NC
Psychiatric/Sleep | Olanzapine | 3 | 13 | 326 | 30 | 482 | 1.50 | (0.73, 3.26) | NC
Psychiatric/Sleep | Quetiapine | 1 | 5 | 142 | 5 | 94 | 1.54 | (0.34, 6.88) | NC
Psychiatric/Sleep | Risperidone | 2 | 10 | 236 | 15 | 281 | 1.17 | (0.46, 3.09) | NC
Pulmonary | Aripiprazole | 1 | 3 | 102 | 6 | 106 | 1.97 | (0.41, 12.54) | NC
Pulmonary | Olanzapine | 1 | 3 | 94 | 0 | 204 | 0.00 | (0.00, 1.10) | NC
Pulmonary | Risperidone | 1 | 3 | 94 | 6 | 196 | 0.96 | (0.20, 6.05) | NC
Trauma | Aripiprazole | 4 | 70 | 374 | 128 | 706 | 0.93 | (0.65, 1.33) | NC
Trauma | Olanzapine | 5 | 50 | 440 | 114 | 778 | 1.31 | (0.89, 1.96) | NC
Trauma | Quetiapine | 4 | 137 | 353 | 167 | 446 | 0.76 | (0.53, 1.09) | NC
Trauma | Risperidone | 5 | 289 | 807 | 403 | 1145 | 0.79 | (0.63, 0.99) | 19
Urinary | Aripiprazole | 3 | 44 | 348 | 115 | 603 | 1.37 | (0.92, 2.09) | NC
Urinary | Olanzapine | 1 | 1 | 94 | 19 | 204 | 9.51 | (1.47, 401.07) | 36
Urinary | Quetiapine | 2 | 12 | 191 | 44 | 332 | 2.37 | (1.16, 5.15) | 16
Urinary | Risperidone | 4 | 71 | 665 | 164 | 1060 | 1.55 | (1.13, 2.13) | 21

CI = confidence interval; HEENT = head, eye, ear, nose, and throat; NC = not calculated; NNH = number needed to harm; OR = odds ratio

Table F7 Dementia—active controlled trials versus acetylcholinesterase inhibitors

| | | Acetylcholinesterase Inhibitor | | Atypicals
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Decrease | Risperidone | 1 | 0 | 14 | 0 | 13 | NC | NC
Gastrointestinal | Risperidone | 1 | 10 | 14 | 2 | 13 | 0.10 | (0.01, 0.78)
Neuro/Fatigue | Risperidone | 1 | 2 | 14 | 1 | 13 | 1.09 | (0.01, 92.68)
Neuro/Movement Disorder/EPS | Risperidone | 1 | 0 | 14 | 2 | 13 | +Inf | (0.03, Inf+ )
Neuro/Sedation | Risperidone | 1 | 0 | 14 | 4 | 13 | +Inf | (0.88, Inf+ )
Psychiatric/Agitation | Risperidone | 1 | 1 | 14 | 1 | 13 | +Inf | (0.03, Inf+ )

CI = confidence interval; NC = not calculated; OR = odds ratio

Table F8 Dementia—active controlled trials versus benzodiazepines

| | | Benzodiazepine | | Atypicals
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Cardiovascular | Olanzapine | 1 | 0 | 68 | 2 | 137 | +Inf | (0.09, Inf+ )
Cardiovascular/BP/Increase | Olanzapine | 1 | 2 | 68 | 2 | 137 | 0.49 | (0.03, 6.91)
Cardiovascular/Rhythm | Olanzapine | 1 | 0 | 68 | 3 | 137 | +Inf | (0.20, Inf+ )
Neuro/Headache | Olanzapine | 1 | 1 | 68 | 4 | 137 | 2.01 | (0.19, 100.69)
Neuro/Sedation | Olanzapine | 1 | 7 | 68 | 5 | 137 | 0.33 | (0.08, 1.27)
Trauma | Olanzapine | 1 | 3 | 68 | 3 | 137 | 0.49 | (0.06, 3.74)

CI = confidence interval; OR = odds ratio

Table F9 Dementia—active controlled trials versus conventionals

| | | Conventional | | Atypicals
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Decrease | Olanzapine | 1 | 3 | 28 | 4 | 30 | 1.28 | (0.19, 9.61)
Appetite or Weight/Increase | Olanzapine | 3 | 19 | 221 | 28 | 223 | 1.53 | (0.79, 3.03)
Appetite or Weight/Increase | Risperidone | 1 | 0 | 20 | 0 | 20 | NC | NC
Cardiovascular | Olanzapine | 1 | 2 | 173 | 6 | 173 | 3.06 | (0.54, 31.45)
Cardiovascular/BP/Decrease | Olanzapine | 1 | 7 | 20 | 2 | 20 | 0.11 | (0.00, 1.01)
Cardiovascular/BP/Decrease | Risperidone | 1 | 7 | 20 | 4 | 20 | 0.47 | (0.08, 2.36)
Cardiovascular/BP/Increase | Quetiapine | 1 | 1 | 11 | 1 | 11 | 1.00 | (0.01, 86.25)
Cardiovascular/Rhythm | Olanzapine | 2 | 6 | 48 | 3 | 50 | 0.46 | (0.07, 2.29)
Cardiovascular/Rhythm | Risperidone | 1 | 5 | 20 | 2 | 20 | 0.17 | (0.00, 1.80)
Constitutional/Fever or Infection | Olanzapine | 1 | 3 | 173 | 0 | 173 | 0.00 | (0.00, 2.41)
Death | Olanzapine | 1 | 6 | 173 | 4 | 173 | 0.66 | (0.13, 2.84)
Dermatologic | Olanzapine | 1 | 12 | 28 | 7 | 30 | 0.41 | (0.11, 1.43)
Endocrine/Diabetes | Olanzapine | 2 | 2 | 193 | 3 | 193 | 1.50 | (0.17, 18.14)
Endocrine/Diabetes | Risperidone | 1 | 0 | 20 | 0 | 20 | NC | NC
Gastrointestinal | Olanzapine | 3 | 64 | 221 | 24 | 223 | 0.14 | (0.06, 0.30)
Gastrointestinal | Quetiapine | 1 | 0 | 11 | 1 | 11 | +Inf | (0.03, Inf+ )
Gastrointestinal | Risperidone | 2 | 10 | 49 | 6 | 49 | 0.43 | (0.10, 1.65)
HEENT/Decreased Salivation | Olanzapine | 2 | 10 | 48 | 3 | 50 | 0.25 | (0.04, 1.05)
HEENT/Decreased Salivation | Risperidone | 1 | 6 | 20 | 0 | 20 | 0.00 | (0.00, 0.72)
HEENT/Increased Salivation | Olanzapine | 1 | 7 | 28 | 4 | 30 | 0.47 | (0.09, 2.14)
Infections | Quetiapine | 1 | 1 | 11 | 0 | 11 | 0.00 | (0.00, 39.00)
Neuro | Olanzapine | 2 | 20 | 48 | 15 | 50 | 0.55 | (0.20, 1.47)
Neuro | Risperidone | 1 | 3 | 20 | 0 | 20 | 0.00 | (0.00, 2.34)
Neuro/Fatigue | Olanzapine | 2 | 22 | 48 | 18 | 50 | 0.42 | (0.11, 1.49)
Neuro/Fatigue | Risperidone | 1 | 0 | 20 | 2 | 20 | +Inf | (0.03, Inf+ )
Neuro/Movement Disorder | Olanzapine | 1 | 18 | 28 | 19 | 30 | 0.96 | (0.29, 3.20)
Neuro/Movement Disorder/Akathisia | Olanzapine | 2 | 6 | 48 | 5 | 50 | 0.57 | (0.10, 2.76)
Neuro/Movement Disorder/Akathisia | Risperidone | 1 | 0 | 20 | 0 | 20 | NC | NC
Neuro/Movement Disorder/EPS | Olanzapine | 2 | 24 | 48 | 17 | 50 | 0.37 | (0.12, 1.10)
Neuro/Movement Disorder/EPS | Quetiapine | 1 | 2 | 11 | 0 | 11 | 0.00 | (0.00, 5.24)
Neuro/Movement Disorder/EPS | Risperidone | 1 | 4 | 20 | 2 | 20 | 0.23 | (0.00, 2.65)
Neuro/Sedation | Olanzapine | 3 | 67 | 221 | 64 | 223 | 0.90 | (0.57, 1.42)
Neuro/Sedation | Risperidone | 3 | 25 | 163 | 18 | 164 | 0.68 | (0.33, 1.36)
Neuro/Sensory | Olanzapine | 1 | 2 | 28 | 2 | 30 | 0.93 | (0.06, 13.69)
Psychiatric/Apathy | Olanzapine | 1 | 16 | 28 | 10 | 30 | 0.38 | (0.11, 1.23)
Psychiatric/Cognitive | Olanzapine | 1 | 49 | 28 | 53 | 30 | NC | NC
Psychiatric/Depression | Olanzapine | 1 | 20 | 28 | 17 | 30 | 0.53 | (0.15, 1.77)
Psychiatric/Irritability | Olanzapine | 1 | 23 | 28 | 24 | 30 | 0.87 | (0.18, 3.97)
Psychiatric/Sexual | Olanzapine | 1 | 0 | 20 | 0 | 20 | NC | NC
Psychiatric/Sexual | Risperidone | 1 | 0 | 20 | 1 | 20 | NC | NC
Psychiatric/Sexual/Decreased Function | Olanzapine | 1 | 3 | 28 | 4 | 30 | 1.28 | (0.19, 9.61)
Psychiatric/Sleep | Olanzapine | 2 | 23 | 48 | 34 | 50 | NC | NC
Psychiatric/Sleep | Risperidone | 1 | 0 | 20 | 1 | 20 | NC | NC
Sweating | Olanzapine | 1 | 4 | 28 | 5 | 30 | 1.20 | (0.23, 6.79)
Trauma | Olanzapine | 1 | 13 | 173 | 1 | 173 | 0.07 | (0.00, 0.49)
Urinary | Olanzapine | 2 | 12 | 201 | 12 | 203 | 0.90 | (0.29, 2.80)
Urinary | Risperidone | 1 | 0 | 29 | 1 | 29 | +Inf | (0.03, Inf+ )

CI = confidence interval; HEENT = head, eye, ear, nose, and throat; NC = not calculated; OR = odds ratio

Table F10 Dementia—active controlled trials versus SRI

| | | SRI | | Atypicals
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Cardiovascular/BP/Decrease | Risperidone | 1 | 0 | 53 | 1 | 50 | +Inf | (0.03, Inf+ )
Constitutional/Fever or Infection | Risperidone | 1 | 0 | 53 | 2 | 50 | +Inf | (0.20, Inf+ )
Endocrine | Risperidone | 1 | 1 | 53 | 0 | 50 | 0.00 | (0.00, 41.34)
Gastrointestinal | Risperidone | 1 | 1 | 53 | 2 | 50 | 2.15 | (0.11, 130.24)
Infections | Risperidone | 1 | 2 | 53 | 0 | 50 | 0.00 | (0.00, 5.63)
Liver Function Test Abnormality | Risperidone | 1 | 0 | 53 | 1 | 50 | +Inf | (0.03, Inf+ )
Neuro | Risperidone | 1 | 1 | 53 | 0 | 50 | 0.00 | (0.00, 41.34)
Neuro/Movement Disorder/EPS | Risperidone | 1 | 1 | 53 | 3 | 50 | 3.28 | (0.25, 177.53)
Neuro/Movement Disorder/Gait | Risperidone | 1 | 1 | 53 | 3 | 50 | 3.28 | (0.25, 177.53)
Neuro/Sedation | Risperidone | 1 | 1 | 53 | 0 | 50 | 0.00 | (0.00, 41.34)
Psychiatric/Agitation | Risperidone | 1 | 12 | 53 | 7 | 50 | 0.56 | (0.17, 1.72)
Psychiatric/Depression | Risperidone | 1 | 1 | 53 | 0 | 50 | 0.00 | (0.00, 41.34)
Psychiatric/Psychotic | Risperidone | 1 | 1 | 53 | 1 | 50 | 1.06 | (0.01, 84.88)
Psychiatric/Serious | Risperidone | 1 | 2 | 53 | 3 | 50 | 1.62 | (0.18, 20.19)
Psychiatric/Suicide Attempt | Risperidone | 1 | 0 | 53 | 1 | 50 | +Inf | (0.03, Inf+ )
Trauma | Risperidone | 1 | 1 | 53 | 0 | 50 | 0.00 | (0.00, 41.34)

CI = confidence interval; OR = odds ratio

Table F11 Dementia—head-to-head trials

| | | | Risperidone | | Olanzapine or Quetiapine
Adverse Events | Risperidone | Olanzapine or Quetiapine | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Decrease | Risperidone | Olanzapine | 1 | 11 | 196 | 13 | 204 | 1.14 | (0.46, 2.90)
Appetite or Weight/Increase | Risperidone | Olanzapine | 3 | 14 | 301 | 27 | 324 | 1.87 | (0.92, 3.95)
Appetite or Weight/Increase | Risperidone | Quetiapine | 1 | 8 | 85 | 5 | 94 | 0.54 | (0.13, 1.97)
Cardiovascular | Risperidone | Olanzapine | 2 | 16 | 281 | 13 | 304 | 0.75 | (0.33, 1.70)
Cardiovascular | Risperidone | Quetiapine | 2 | 4 | 119 | 6 | 132 | 1.38 | (0.31, 6.89)
Cardiovascular/BP/Decrease | Risperidone | Olanzapine | 1 | 4 | 20 | 2 | 20 | 0.23 | (0.00, 2.65)
Cardiovascular/Rhythm | Risperidone | Olanzapine | 3 | 3 | 124 | 2 | 140 | 0.92 | (0.07, 12.95)
Cardiovascular/Rhythm | Risperidone | Quetiapine | 1 | 1 | 85 | 3 | 94 | 2.75 | (0.22, 147.08)
Constitutional/Fever or Infection | Risperidone | Olanzapine | 1 | 0 | 196 | 2 | 204 | +Inf | (0.18, Inf+ )
Death | Risperidone | Olanzapine | 1 | 1 | 85 | 1 | 100 | 0.85 | (0.01, 67.39)
Death | Risperidone | Quetiapine | 2 | 1 | 119 | 3 | 132 | 2.75 | (0.22, 147.08)
Dermatologic | Risperidone | Olanzapine | 1 | 0 | 19 | 1 | 20 | +Inf | (0.02, Inf+ )
Endocrine/Diabetes | Risperidone | Olanzapine | 1 | 0 | 20 | 1 | 20 | +Inf | (0.03, Inf+ )
Gastrointestinal | Risperidone | Olanzapine | 2 | 7 | 105 | 9 | 120 | 1.42 | (0.42, 5.18)
Gastrointestinal | Risperidone | Quetiapine | 2 | 8 | 119 | 3 | 132 | 0.31 | (0.05, 1.37)
HEENT/Decreased Salivation | Risperidone | Olanzapine | 1 | 0 | 20 | 0 | 20 | NC | NC
HEENT/Eye | Risperidone | Olanzapine | 1 | 0 | 85 | 0 | 100 | NC | NC
HEENT/Eye | Risperidone | Quetiapine | 2 | 2 | 119 | 0 | 132 | 0.00 | (0.00, 4.73)
Heme | Risperidone | Olanzapine | 1 | 2 | 85 | 1 | 100 | 0.42 | (0.01, 8.22)
Heme | Risperidone | Quetiapine | 1 | 2 | 85 | 2 | 94 | 0.90 | (0.06, 12.71)
Musculoskeletal | Risperidone | Quetiapine | 1 | 5 | 34 | 0 | 38 | 0.00 | (0.00, 0.92)
Neuro | Risperidone | Olanzapine | 3 | 53 | 301 | 81 | 324 | 1.54 | (1.02, 2.34)
Neuro | Risperidone | Quetiapine | 1 | 22 | 85 | 19 | 94 | 0.73 | (0.34, 1.55)
Neuro/CVA | Risperidone | Olanzapine | 2 | 2 | 104 | 4 | 120 | 1.75 | (0.25, 19.64)
Neuro/CVA | Risperidone | Quetiapine | 2 | 2 | 119 | 2 | 132 | 0.90 | (0.06, 12.71)
Neuro/Fatigue | Risperidone | Olanzapine | 3 | 22 | 301 | 18 | 324 | 0.80 | (0.39, 1.61)
Neuro/Fatigue | Risperidone | Quetiapine | 2 | 5 | 119 | 8 | 132 | 1.47 | (0.41, 5.88)
Neuro/Movement Disorder | Risperidone | Olanzapine | 1 | 7 | 85 | 10 | 100 | 1.24 | (0.40, 4.02)
Neuro/Movement Disorder | Risperidone | Quetiapine | 1 | 7 | 85 | 5 | 94 | 0.63 | (0.15, 2.40)
Neuro/Movement Disorder/Akathisia | Risperidone | Olanzapine | 2 | 0 | 105 | 2 | 120 | +Inf | (0.02, Inf+ )
Neuro/Movement Disorder/Akathisia | Risperidone | Quetiapine | 1 | 0 | 85 | 1 | 94 | +Inf | (0.02, Inf+ )
Neuro/Movement Disorder/EPS | Risperidone | Olanzapine | 3 | 19 | 124 | 18 | 140 | 0.84 | (0.38, 1.82)
Neuro/Movement Disorder/EPS | Risperidone | Quetiapine | 2 | 20 | 119 | 3 | 132 | 0.12 | (0.02, 0.41)
Neuro/Movement Disorder/Gait | Risperidone | Olanzapine | 3 | 22 | 300 | 26 | 324 | 1.13 | (0.60, 2.16)
Neuro/Movement Disorder/Gait | Risperidone | Quetiapine | 1 | 1 | 85 | 3 | 94 | 2.75 | (0.22, 147.08)
Neuro/Movement Disorder/Tardive Dyskinesia | Risperidone | Olanzapine | 1 | 3 | 85 | 3 | 100 | 0.85 | (0.11, 6.49)
Neuro/Movement Disorder/Tardive Dyskinesia | Risperidone | Quetiapine | 1 | 3 | 85 | 2 | 94 | 0.60 | (0.05, 5.34)
Neuro/Sedation | Risperidone | Olanzapine | 5 | 63 | 391 | 89 | 428 | 1.40 | (0.96, 2.05)
Neuro/Sedation | Risperidone | Quetiapine | 2 | 17 | 119 | 32 | 132 | 1.93 | (0.97, 3.97)
Psychiatric/Aggression | Risperidone | Olanzapine | 1 | 13 | 196 | 14 | 204 | 1.04 | (0.44, 2.47)
Psychiatric/Agitation | Risperidone | Olanzapine | 2 | 35 | 281 | 44 | 304 | 1.22 | (0.73, 2.04)
Psychiatric/Agitation | Risperidone | Quetiapine | 1 | 5 | 85 | 11 | 94 | 2.11 | (0.64, 8.11)
Psychiatric/Anxiety | Risperidone | Olanzapine | 2 | 20 | 281 | 19 | 304 | 0.90 | (0.44, 1.83)
Psychiatric/Anxiety | Risperidone | Quetiapine | 1 | 0 | 85 | 0 | 94 | NC | NC
Psychiatric/Cognitive | Risperidone | Olanzapine | 1 | 1 | 85 | 5 | 100 | 4.39 | (0.48, 211.54)
Psychiatric/Cognitive | Risperidone | Quetiapine | 1 | 1 | 85 | 0 | 94 | 0.00 | (0.00, 35.27)
Psychiatric/Depression | Risperidone | Olanzapine | 1 | 0 | 85 | 4 | 100 | +Inf | (0.57, Inf+ )
Psychiatric/Depression | Risperidone | Quetiapine | 1 | 0 | 85 | 2 | 94 | +Inf | (0.17, Inf+ )
Psychiatric/Psychotic | Risperidone | Olanzapine | 2 | 32 | 281 | 52 | 304 | 1.70 | (1.02, 2.85)
Psychiatric/Psychotic | Risperidone | Quetiapine | 2 | 1 | 119 | 0 | 132 | 0.00 | (0.00, 34.89)
Psychiatric/Sexual | Risperidone | Olanzapine | 1 | 1 | 20 | 0 | 20 | NC | NC
Psychiatric/Sleep | Risperidone | Olanzapine | 3 | 16 | 301 | 19 | 324 | 1.19 | (0.56, 2.57)
Psychiatric/Sleep | Risperidone | Quetiapine | 1 | 4 | 85 | 5 | 94 | 1.14 | (0.24, 5.93)
Pulmonary | Risperidone | Olanzapine | 1 | 6 | 196 | 0 | 204 | 0.00 | (0.00, 0.80)
Trauma | Risperidone | Olanzapine | 3 | 30 | 300 | 50 | 324 | 1.64 | (0.98, 2.76)
Trauma | Risperidone | Quetiapine | 2 | 10 | 119 | 12 | 132 | 1.09 | (0.41, 2.94)
Urinary | Risperidone | Olanzapine | 1 | 25 | 196 | 19 | 204 | 0.70 | (0.35, 1.38)
Urinary | Risperidone | Quetiapine | 1 | 0 | 34 | 2 | 38 | +Inf | (0.17, Inf+ )

CI = confidence interval; HEENT = head, eye, ear, nose, and throat; NC = not calculated; OR = odds ratio