# Excluded Studies

## Reject Descriptive

U.S. Food and Drug Administration. Postmarket Drug Safety Information for Patients and Providers, FDA Public Health Advisory. www.fda.gov/Drugs/DrugSafety/PostmarketDrugSafetyInformationforPatientsandProviders/ucm124830.htm. Cited. December. 12. 2009.
Alanen H HMF-S, Noro A, Leinonen E. Use of antipsychotic medications among elderly residents in long-term institutional care: a three-year follow-up. International Journal of Geriatric Psychiatry. 2006;21(3):288-95. [pmid: 16477588].
Alanen H HMF-S, Fialova D, Topinkova E, Jonsson PV, Soerbye LW, Bernabei R, Leinonen E. Use of antipsychotic medications in older home-care patients. Report from nine European countries. Aging Clin Exp Res. Jun. 2008;20(3):260-5. [pmid: 18594194].
Arbaizar B, Dierssen-Sotos T, Gomez-Acebo I, Llorca J. Comments on “Aripirazole in major depression and mania: Meta-analyses of randomized placebo-controlled trials” Author's response. Gen Hosp Psychiatry. 2010;32(4):449.
Bagepally O BSP. Nonsignificant weight gain with atypical antipsychotics in men with Alzheimer's Disease: an important result of the CATIE-Alzheimer's disease study. Am J Psychiatry. Sep. 2009;166(9):1063-4. author reply 4-5. [pmid: 19723796].
Barbarich-Marsteller NCK, Walter H. ‘An Open Trial of Olanzapine in Anorexia Nervosa’: Reply. Journal of Clinical Psychiatry. May. 2005. 2005;66(5):655-6.
Barbui A CC, Nosé M, Patten SB, Stegagno M, Burti L, Amaddeo F, Tansella M. Off-label and non-classical prescriptions of antipsychotic agents in ordinary in-patient practice. Acta Psychiatrica Scandinavica. 2004;109(4):275-8. [pmid: 15008801].
Blier P. Atypical antipsychotics for mood and anxiety disorders: safe and effective adjuncts?. J Psychiatry Neurosci. Jul. 2005;30(4):232-3. [pmid: 16049565].
Blier ST PS. Potential mechanisms of action of atypical antipsychotic medications in treatment-resistant depression and anxiety. J Clin Psychiatry. 8. 2005;66:30-40. [pmid: 16336034].
Bloch MH, Landeros-Weisenberger A, Kelmendi B, Coric V, Bracken MB, Leckman JF. A systematic review: Antipsychotic augmentation with treatment refractory obsessive-compulsive disorder: Corrigendum. Molecular Psychiatry. Aug. 2006. 2006;11(8):795.
Bronskill GM SEA, Sykora K, Wodchis WP, Gill S, Shulman KI, Rochon PA. Neuroleptic Drug Therapy in Older Adults Newly Admitted to Nursing Homes: Incidence, Dose, and Specialist Contact. Journal of the American Geriatrics Society. 2004;52(5):749-55. [pmid: 15086656].
Callaly Tom TT. Patterns of use of antipsychotic medication in a regional community mental health service. Australasian Psychiatry: Publication of The Royal Australian and New Zealand College of Psychiatrists. 2000;8(3):220-4.
Carroll BJ. Aripiprazole in refractory depression. J Clin Psychopharmacol. Feb. 2009;29(1):90-1. author reply 2-3. [pmid: 19142117].
Cleare A. Adjunctive aripiprazole improves symptoms in antidepressant refractory major depressive disorder. Evid Based Ment Health. Nov. 2008;11(4):111. [pmid: 18952960].
Dawes J. Chemical straightjackets in a care home near you. Br J Community Nurs. Jul. 4. 2008;13(7):301-Unknown. [pmid: 19057485].
Duggal Ira HSS. Letter to the Editor: Ziprasidone and Hypomania. CNS Spectrums. Aug. 2005. 2005;10(8):606. [pmid: 16173129].
Erman MK. Is it a sleeping pill?. Primary Psychiatry. Jan. 2008. 2008;15(1):34-6.
Gardner TR TJK. Human laboratory and neuroimaging studies in substance use disorders: developing new treatment approaches. Am J Drug Alcohol Abuse. 2007;33(6):765-7. [pmid: 17994472].
Gill Dallas Rochon SSS, Paula A. Atypical Antipsychotic Drugs, Dementia, and Risk of Death. JAMA. February. 1. 2006. 2006;295(5):495-a-6. [pmid: 16449609].
Haw J CS. A survey of off-label prescribing for inpatients with mild intellectual disability and mental illness. J Intellect Disabil Res. Nov. 2005;49(Pt 11):858-64. [pmid: 16207284].
Haw CY, Graeme Stubbs Jean. Guidelines on antipsychotics for dementia: Are we losing our minds?. Psychiatric Bulletin. Feb. 2009. 2009;33(2):57-60.
Health Canada CADRMP, Marketed Health Products Directorate. Important drug safety information:RISPERDAL(risperidone) and cerebrovascular adverse events in placebo-controlled dementia trials— Janssen-Ortho. 2002. www.hc-sc.gc.ca/dhp-mps/alt_formats/hpfb-dgpsa/pdf/medeff/risperdal_hpc-cps-eng.pdf. Cited. January. 20. 2010.
Jaffe AB, Levine Jerome. Antipsychotic medication coprescribing in a large state hospital system. Pharmacoepidemiology and Drug Safety. 2003;12(1):41-8. [pmid: 12616846].
Keenan K. Antipsychotics in disruptive behavior disorders and ADHD. J Am Acad Child Adolesc Psychiatry. Oct. 2005;44(10):969-70. author reply 70-1. [pmid: 16175099].
Keitner GI. Adding atypical antipsychotics to antidepressants increases response in treatment-resistant major depression but increases discontinuation as a result of adverse events. Evid Based Med. Feb. 2010;15(1):19-20. [pmid: 20176877].
Keks Kylie NAA, Hope Judy, Krapivensky Natalie, Culhane Christine, Tanaghow Amgad, Doherty Peter, Bootle Anne. Use of antipsychosis and adjunctive medications by an inner urban community psychiatric service. Australian and New Zealand Journal of Psychiatry. 1999;33(6):896-901. [pmid: 10619218].
Kerrsens YAL CJP. Vulnerability to neuroleptic side effects in frontotemporal dementia. European Journal of Neurology. Feb. 2008. 2008;15(2):111-2. [pmid: 18217880].
Khazaal A YC, Khan R, Zullino D. Quetiapine dosage across diagnostic categories. Psychiatr Q. Mar. 2009;80(1):17-22. [pmid: 19142727].
Kopecek P MM, Novak T. Sedative effects of low-dose risperidone in GAD patients and risk of drug interactions. J Clin Psychiatry. Aug. 2006;67(8):1307-8. author reply 8-9. [pmid: 16965213].
Kozaric-Kovacic D. Pharmacotherapy treatment of PTSD and comorbid disorders. Psychiatr Danub. Sep. 2009;21(3):411-4. [pmid: 19794366].
Kuehn BM. FDA panel issues mixed decision on quetiapine in depression and anxiety. JAMA. May. 27. 2009;301(20):2081-2. [pmid: 19470978].
Lakey Shelly L SLG, Sales Anne EB, Sullivan Jean, Hedrick Susan C. Psychotropic use in community residential care facilities: A prospective cohort study. The American Journal of Geriatric Pharmacotherapy. 2006;4(3):227-35. [pmid: 17062323].
Leiderman S DBS, Montgomery A, Bloch DA, Elkashef A, LoCastro J, Vocci F. Cocaine Rapid Efficacy Screening Trial (CREST): a paradigm for the controlled evaluation of candidate medications for cocaine dependence. Addiction. Mar. 1. 2005;100:1-11. [pmid: 15773068].
Liperoti R. Starting a conventional antipsychotic increases risk of death more than an atypical antipsychotic in elderly people with dementia. Evid Based Ment Health. May. 2009;12(2):58. [pmid: 19395617].
Mauri Francesca MCR, Beraldo Scilla, Volonteri Lucia S, Ferrari Veronica M, Fiorentini Alessio, Invernizzi Giordano. Patterns of clinical use of antipsychotics in hospitalized psychiatric patients. Progress in Neuro-Psychopharmacology and Biological Psychiatry. 2005;29(6):957-63. [pmid: 16051409].
Menaster M. Use of olanzapine in anorexia nervosa. J Clin Psychiatry. May. 2005;66(5):654-5. author reply 5-6. [pmid: 15889956].
Mintzer JE. ‘Significance of findings in aripiprazole for treatment of psychoses in Alzheimer dementia’: Reply. The American Journal of Geriatric Psychiatry. Jul. 2008;16(7):614. [pmid: 18591583].
Nakajima Takefumi SS, Watanabe Koichiro, Kashima Haruo, Uchida Hiroyuki. Potential risks of adjunctive use of atypical antipsychotic drugs for the treatment of depression. Progress in Neuro-Psychopharmacology and Biological Psychiatry. [doi: 10.1016/j.pnpbp.2009.12.023]. 2010;34(2):435-6.
Nishtala AJ PSM, Bell JS, Chen TF. Determinants of antipsychotic medication use among older people living in aged care homes in Australia. Int J Geriatr Psychiatry. 2009. Aug. 10.
No authorship i. International Addictions Infoline. Journal of Psychoactive Drugs. Sep. 2004. 2004;36(3):403-5.
Norris W MLS, Buchholz A, Henderson KA. Challenges Associated with Controlled Psychopharmacological Research Trials in Adolescents with Eating Disorders. J Can Acad Child Adolesc Psychiatry. Nov. 2007;16(4):167-72. [pmid: 18392169].
Nose M. No significant difference between olanzapine and placebo for improvement in borderline personality disorder symptoms. Evid Based Ment Health. Aug. 2009;12(3):89. [pmid: 19633257].
Nunes S EVD, Fischman MW. Risperidone for cocaine dependence: an early phase II clinical trial. 1999. http://clinicaltrials.gov/ct2/show/NCT00000317. Cited. April. 9. 2010.
Raivio Jouko V MML, Strandberg Timo E, Tilvis Reijo S, Pitkala Kaisu H. Neither Atypical Nor Conventional Antipsychotics Increase Mortality or Hospital Admissions Among Elderly Patients With Dementia: A Two-Year Prospective Study. [Article]. American Journal of Geriatric Psychiatry. 2007;15(5):416-24. [pmid: 17463191].
Rijcken GJ CAB, Slooff CJ, Beuger PJ, Tanja TA, de Jong-van den Berg LT. Off-label use of antipsychotics in the community pharmacy: the sex differences. Pharmacopsychiatry. Sep. 2003;36(5):187-91. [pmid: 14571353].
Rochon PA, Stukel TA, Bronskill SE, Gomes T, Sykora K, Wodchis WP, et al. Variation in Nursing Home Antipsychotic Prescribing Rates. Arch Intern Med. April. 9. 2007. 2007;167(7):676-83. [pmid: 17420426].
Rosenheck Douglas L RAL, Sindelar Jody L, Miller Edward A, Tariot Peter N, Dagerman Karen S, Davis Sonia M, Lebowitz Barry D, Rabins Peter, Hsiao John K, Lieberman Jeffery A, Schneider Lon S, for the Clinical Antipsychotic Trial of Intervention Effectiveness Alzheimer's Disease investigators. Cost-Benefit Analysis of Second-Generation Antipsychotics and Placebo in a Randomized Trial of the Treatment of Psychosis and Aggression in Alzheimer Disease. Arch Gen Psychiatry. November. 1. 2007. 2007;64(11):1259-68. [pmid: 17984395].
Spettigue Annick WB, Henderson Katherine, Feder Stephen, Moher David, Kourad Kader, Gaboury Isabelle, Norris Mark, Ledoux Sheila. Evaluation of the efficacy and safety of olanzapine as an adjunctive treatment for anorexia nervosa in adolescent females: a randomized, double-blind, placebo-controlled trial. BMC Pediatrics. 2008;8(1):4. [pmid: 18234120].
Spier SA. Use of atypical antipsychotics: observations from clinical practice. J Clin Psychiatry. Mar. 2006;67(3):490-1. [pmid: 16649838].
Suh GH. The use of atypical antipsychotics in dementia: rethinking Simpson's paradox. Int Psychogeriatr. Aug. 2009;21(4):616-21. [pmid: 19243653].
Traynor K. FDA advisers wary of expanding quetiapine use: clinicians air concerns about metabolic effects, tardive dyskinesia. Am J Health Syst Pharm. May. 15. 2009;66(10):880-2. [pmid: 19420301].
Trifiro E GS, Brignoli O, Sessa E, Caputi AP, Mazzaglia G. Antipsychotic prescribing pattern among Italian general practitioners: a population-based study during the years 1999-2002. Eur J Clin Pharmacol. Mar. 2005;61(1):47-53. [pmid: 15666172].
Tsai AC. Unclear clinical significance of findings in adjunctive aripiprazole for major depressive disorder: comments on article by Marcus et al. J Clin Psychopharmacol. Feb. 2009;29(1):91-2. author reply 2-3. [pmid: 19142118].
Westenberg HG. Recent advances in understanding and treating social anxiety disorder. CNS Spectr. Feb. 2009;14(2 Suppl 3):24-33. [pmid: 19238127].
Wheeler A. Atypical antipsychotic use for adult outpatients in New Zealand's Auckland and Northland regions. N Z Med J. 2006;119(1237):U2055. [pmid: 16862201].
Yatham SH LNK, Lam RW. Advances in treatment of mood and anxiety disorders: focus on atypical antipsychotics. Bipolar Disord. 2. 2003;5:5-6. [pmid: 14687068].

## Reject, Nonsystematic Review

Ahearn A EPK, Connor KM, Davidson JR. Pharmacologic treatment of posttraumatic stress disorder: a focus on antipsychotic use. Ann Clin Psychiatry. Sep-Dec. 2003;15(3-4):193-201. [pmid: 14971865].
Aman C MGB, Turgay A. Risperidone effects in the presence/absence of psychostimulant medicine in children with ADHD, other disruptive behavior disorders, and subaverage IQ. J Child Adolesc Psychopharmacol. Summer. 2004;14(2):243-54. [pmid: 15319021].
Asnis SR GMK, Henderson M, Brown NL. SSRIs versus non-SSRIs in post-traumatic stress disorder: an update with recommendations. Drugs. 2004;64(4):383-404. [pmid: 14969574].
Assal M FvdM. Pharmacological interventions in primary care: hopes and illusions. Front Neurol Neurosci. 2009;24:54-65. [pmid: 19182463].
Ballard A CC, Chitramohan R, Aarsland D. Management of agitation and aggression associated with Alzheimer's disease: controversies and possible solutions. Curr Opin Psychiatry. Nov. 2009;22(6):532-40. [pmid: 19696673].
Ballard S CGG, Cummings JL, Brodaty H, Grossberg GT, Robert P, Lyketsos CG. Management of agitation and aggression associated with Alzheimer disease. Nat Rev Neurol. May. 2009;5(5):245-55. [pmid: 19488082].
Bandelow B. The medical treatment of obsessive-compulsive disorder and anxiety. CNS Spectr. Sep. 2008;13(9 Suppl 14):37-46. [pmid: 18849910].
Baune BT. New developments in the management of major depressive disorder and generalized anxiety disorder: role of quetiapine. Neuropsychiatr Dis Treat. Dec. 2008;4(6):1181-91. [pmid: 19337458].
Bellino E SP, Bogetto F. Efficacy and tolerability of pharmacotherapies for borderline personality disorder. CNS Drugs. 2008;22(8):671-92. [pmid: 18601305].
Bishara D DT, Howard RJ, Abdel-Tawab R. Expert opinion on the management of behavioural and psychological symptoms of dementia (BPSD) and investigation into prescribing practices in the UK. Int J Geriatr Psychiatry. Sep. 2009;24(9):944-54. [pmid: 19156700].
Bobo RC WVS. Fluoxetine and olanzapine combination therapy in treatment-resistant major depression: review of efficacy and safety data. Expert Opin Pharmacother. Sep. 2009;10(13):2145-59. [pmid: 19640209].
Bobo RC WVS. Olanzapine and fluoxetine combination therapy for treatment-resistant depression: review of efficacy, safety, and study design issues. Neuropsychiatr Dis Treat. Jul. 2009;5(3):369-83. [pmid: 19590732].
Boulton A DB, Royzman K, Patel C, Berman R, Mallikaarjun S, Reeves R. The pharmacokinetics of standard antidepressants with aripiprazole as adjunctive therapy: studies in healthy subjects and in patients with major depressive disorder. J Psychopharmacol. 2008. Oct. 2.
Broadway Jacobo JM. The many faces of psychosis in the elderly. Current Opinion in Psychiatry. Nov. 2007;20(6):551-8. [pmid: 17921754].
Brooke M NSW, Salzman C. Atypical uses of atypical antipsychotics. Harv Rev Psychiatry. Nov-Dec. 2005;13(6):317-39. [pmid: 16373327].
Brown ES. Management of comorbid bipolar disorder and substance abuse. J Clin Psychiatry. Aug. 2006;67(8):e05. [pmid: 17107268].
Burke PN ADT. Atypical antipsychotics in the elderly: a review of therapeutic trends and clinical outcomes. Expert Opin Pharmacother. Oct. 2009;10(15):2407-14. [pmid: 19663744].
Carvalho JL AFC, Castelo MS, Lima MC. Augmentation strategies for treatment-resistant depression: a literature review. J Clin Pharm Ther. Oct. 2007;32(5):415-28. [pmid: 17875106].
Carvalho JR AFM, Cavalcante JL. Augmentation strategies for treatment-resistant depression. Curr Opin Psychiatry. Jan. 2009;22(1):7-12. [pmid: 19122528].
Cheng-Shannon JJ JM, Pataki C, McCracken JT. Second-generation antipsychotic medications in children and adolescents. J Child Adolesc Psychopharmacol. Fall. 2004;14(3):372-94. [pmid: 15650494].
Chouinard G. The search for new off-label indications for antidepressant, antianxiety, antipsychotic and anticonvulsant drugs. J Psychiatry Neurosci. May. 2006;31(3):168-76. [pmid: 16699602].
Citrome L. Quantifying risk: the role of absolute and relative measures in interpreting risk of adverse reactions from product labels of antipsychotic medications. Curr Drug Saf. Sep. 2009;4(3):229-37. [pmid: 19534647].
Conn R DKM. Use of sleep-promoting medications in nursing home residents : risks versus benefits. Drugs Aging. 2006;23(4):271-87. [pmid: 16732687].
Daiello MT LAB, Hoffmann VP, Kennedy JS. Pharmacotherapy of Behavioral and Psychological Symptoms of Dementia: A Review of Atypical Antipsychotics. Consult Pharm. February. 1. 2003;18(2):138-52. 55. 7. [pmid: 16563055].
Davidson JR. First-line pharmacotherapy approaches for generalized anxiety disorder. J Clin Psychiatry. 2. 2009;70:25-31. [pmid: 19371504].
Davidson JR. Pharmacologic treatment of acute and chronic stress following trauma: 2006. J Clin Psychiatry. 2. 2006;67:34-9. [pmid: 16602813].
Davidson JR. Pharmacotherapy of social anxiety disorder: what does the evidence tell us?. J Clin Psychiatry. 12. 2006;67:20-6. [pmid: 17092192].
De Lucas Taracena MTR, Montañés F. El uso de los nuevos antipsicóticos atípicos en el síndrome de Gilles de la Tourette Use of new atypical antipsychotics in Tourette's syndrome. Anales de Psiquiatría. Dec. 2005;21(7):331-9.
Deberdt Alan WGS, Ahl Jonna, Meyers Adam L, Landbloom Ronald. Effect of olanzapine on cognition during treatment of behavioral and psychiatric symptoms in patients with dementia: A post-hoc analysis. International Journal of Geriatric Psychiatry. Apr. 2008. 2008;23(4):364-9. [pmid: 17708584].
Denys D. Pharmacotherapy of obsessive-compulsive disorder and obsessive-compulsive spectrum disorders. Psychiatr Clin North Am. Jun. 2006;29(2):553-84. xi. [pmid: 16650723].
Denys N DF, Carey PD, Stein DJ. Quetiapine addition in obsessive-compulsive disorder: is treatment outcome affected by type and dose of serotonin reuptake inhibitors?. Biol Psychiatry. Feb. 1. 2007;61(3):412-4. [pmid: 17241831].
Diaz-Marsa S MGB, Tajima K, Garcia-Albea J, Navas M, Carrasco JL. Psychopharmacological treatment in borderline personality disorder. Actas Esp Psiquiatr. Jan-Feb. 2008;36(1):39-49. [pmid: 18286399].
Dodd M SB. Olanzapine/fluoxetine combination for treatment-resistant depression: efficacy and clinical utility. Expert Rev Neurother. Sep. 2008;8(9):1299-306. [pmid: 18759541].
Elkashef F AV, Hanson G, White J, Wickes W, Tiihonen J. Pharmacotherapy of methamphetamine addiction: an update. Subst Abus. 2008;29(3):31-49. [pmid: 19042205].
Fava SR MW, Thase ME, Baker RA, Tran QV, Pikalov A, Yang H, Marcus RN, Berman RM. Metabolic assessment of aripiprazole as adjunctive therapy in major depressive disorder: a pooled analysis of 2 studies. J Clin Psychopharmacol. Aug. 2009;29(4):362-7. [pmid: 19593176].
Finkel S. Pharmacology of Antipsychotics in the Elderly: A Focus on Atypicals. Journal of the American Geriatrics Society. Dec. 2004. 2004;52(12):S258-S65. [pmid: 15541166].
Frye IM MAS. Bipolar disorder and comorbid alcoholism: prevalence rate and treatment considerations. Bipolar Disord. Dec. 2006;8(6):677-85. [pmid: 17156154].
Gao K. Antipsychotics in the treatment of comorbid anxiety in bipolar disorder. Psychiatr Times. 2007;24(5):68-9.
Gao D KM, Gajwani P, Calabrese JR. Efficacy of typical and atypical antipsychotics for primary and comorbid anxiety symptoms or disorders: a review. J Clin Psychiatry. Sep. 2006;67(9):1327-40. [pmid: 17017818].
Gao DV KS, Calabrese JR. Atypical antipsychotics in primary generalized anxiety disorder or comorbid with mood disorders. Expert Rev Neurother. Aug. 2009;9(8):1147-58. [pmid: 19673604].
Gareri Pasquale PDF, De Fazio Salvatore, Marigliano Norma, Ferreri Ibbadu Guido, De Sarro Giovambattista. Adverse effects of atypical antipsychotics in the elderly: A review. Drugs and Aging. 2006. 2006;23(12):937-56. [pmid: 17154659].
Goodwin W GF, Arango C, Baumann P, Davidson M, de Hert M, Falkai P, Kapur S, Leucht S, Licht R, Naber D, O'Keane V, Papakostas G, Vieta E, Zohar J. Advantages and disadvantages of combination treatment with antipsychotics ECNP Consensus Meeting, March 2008, Nice. Eur Neuropsychopharmacol. Jul. 2009;19(7):520-32. [pmid: 19411165].
Green AI. Schizophrenia and comorbid substance use disorder: effects of antipsychotics. J Clin Psychiatry. 6. 2005;66:21-6. [pmid: 16107180].
Greenaway D ME. Focus on Aripiprazole: A Review of its use in Child and Adolescent Psychiatry. J Can Acad Child Adolesc Psychiatry. Aug. 2009;18(3):250-60. [pmid: 19718428].
Hamner S MBR. Emerging roles for atypical antipsychotics in chronic post-traumatic stress disorder. Expert Rev Neurother. Mar. 2005;5(2):267-75. [pmid: 15853496].
Hamner S MBR, Frueh BC. Treatment-resistant posttraumatic stress disorder: strategies for intervention. CNS Spectr. Oct. 2004;9(10):740-52. [pmid: 15448585].
Hanley GA MJK. Quetiapine: treatment for substance abuse and drug of abuse. Am J Health Syst Pharm. Apr. 1. 2008;65(7):611-8. [pmid: 18359967].
Hindmarch I. Cognitive toxicity of pharmacotherapeutic agents used in social anxiety disorder. Int J Clin Pract. Jul. 2009;63(7):1085-94. [pmid: 19570125].
Hoffman SJ EJM. Anxiety disorders: a comprehensive review of pharmacotherapies. Mt Sinai J Med. May-Jun. 2008;75(3):248-62. [pmid: 18704983].
Ishak MH WWR, Gotto JG. The effectiveness of atypical antipsychotic medications in depressive disorders. Curr Psychiatry Rep. Dec. 2004;6(6):422-4. [pmid: 15538989].
Ivanov A IC. Treating pediatric patients with antipsychotic drugs: Balancing benefits and safety. Mt Sinai J Med. May-Jun. 2008;75(3):276-86. [pmid: 18704980].
Jeste D DVB, Casey D, Meeks T, Salzman C, Schneider L, Tariot P, Yaffe K. ACNP White Paper: update on use of antipsychotic drugs in elderly persons with dementia. Neuropsychopharmacology. Apr. 2008;33(5):957-70. [pmid: 17637610].
Kalapatapu C RKS. Update on neuropsychiatric symptoms of dementia: antipsychotic use. Geriatrics. May. 2009;64(5):10-8. [pmid: 19435390].
Karila D LG, Weinstein A, Noble F, Benyamina A, Coscas S, Blecha L, Lowenstein W, Martinot JL, Reynaud M, Lepine JP. New treatments for cocaine dependence: a focused review. Int J Neuropsychopharmacol. May. 2008;11(3):425-38. [pmid: 17927843].
Kaufer DI. Pharmacologic treatment expectations in the management of dementia with Lewy bodies. Dement Geriatr Cogn Disord. 1. 2004;17:32-9. [pmid: 14676467].
Kenna GA. Rationale for use of aripiprazole for alcohol dependence treatment. Drugs Future. 2003;28:1227-35.
Kenna JE GAM, Swift RM. Pharmacotherapy, pharmacogenomics, and the future of alcohol dependence treatment, Part 2. Am J Health Syst Pharm. Nov. 15. 2004;61(22):2380-8. [pmid: 15581261].
Kenna DM GAN, Mello P, Schiesl A, Swift RM. Pharmacotherapy of dual substance abuse and dependence. CNS Drugs. 2007;21(3):213-37. [pmid: 17338593].
Khan A. Current evidence for aripiprazole as augmentation therapy in major depressive disorder. Expert Rev Neurother. Oct. 2008;8(10):1435-47. [pmid: 18928339].
Kirshner HS. Controversies in behavioral neurology: the use of atypical antipsychotic drugs to treat neurobehavioral symptoms in dementia. Curr Neurol Neurosci Rep. Nov. 2008;8(6):471-4. [pmid: 18957183].
Kohen I, Lester PE, Lam S. Antipsychotic treatments for the elderly: efficacy and safety of aripiprazole. Neuropsychiatr Dis Treat. 2010;6:47-58. [pmid: 20361061].
Kosten TA TRK. New medication strategies for comorbid substance use and bipolar affective disorders. Biol Psychiatry. Nov. 15. 2004;56(10):771-7. [pmid: 15556122].
Lee E JWB, Sherwood Perantie, Dana C, Bobadilla Leonardo. A comparison of single-item Visual Analog Scales with a multiitem Likert-type scale for assessment of cocaine craving in persons with bipolar disorder. Addictive Disorders & Their Treatment. 2002. 2002;1(4):140-2.
Littrell RG KHP, Wolf NM. Olanzapine: a 5-year perspective. Expert Rev Neurother. Jun. 2006;6(6):811-21. [pmid: 16784405].
Maina Umberto GA, Pessina Enrico, Salvi Virginio, Bogetto Filippo. Antipsychotics in obsessive-compulsive disorder. Current Psychiatry Reviews. Nov. 2005. 2005;1(3):293-301.
Mathew JD SJC, Gorman JM. Management of treatment-refractory panic disorder. Psychopharmacol Bull. Spring. 2001;35(2):97-110. [pmid: 12397890].
McIntyre RS, Muzina DJ, Adams A, Lourenco MT, Law CW, Soczynska JK, et al. Quetiapine XR efficacy and tolerability as monotherapy and as adjunctive treatment to conventional antidepressants in the acute and maintenance treatment of major depressive disorder: a review of registration trials. Expert Opin Pharmacother. Dec. 2009;10(18):3061-75. [pmid: 19954275].
McNeal RP KMM, Lukacs K, Senseney A, Mintzer J. Using risperidone for Alzheimer's dementia-associated psychosis. Expert Opin Pharmacother. Oct. 2008;9(14):2537-43. [pmid: 18778191].
Mendez MF. Frontotemporal dementia: therapeutic interventions. Front Neurol Neurosci. 2009;24:168-78. [pmid: 19182475].
Mitchell M JEdZ, Roerig JL. Drug therapy for patients with eating disorders. Curr Drug Targets CNS Neurol Disord. Feb. 2003;2(1):17-29. [pmid: 12769809].
Nelson R JCM, Baker RA, Carlson BX, Eudicone JM, Pikalov A, Tran QV, Berman RM. Effects of aripiprazole adjunctive to standard antidepressant treatment on the core symptoms of depression: A post-hoc, pooled analysis of two large, placebo-controlled studies. J Affect Disord. 2009. Aug. 4.
Nelson A JCP, Berman RM. Augmentation treatment in major depressive disorder: focus on aripiprazole. Neuropsychiatr Dis Treat. Oct. 2008;4(5):937-48. [pmid: 19183784].
Nemeroff CB. Use of atypical antipsychotics in refractory depression and anxiety. J Clin Psychiatry. 8. 2005;66:13-21. [pmid: 16336032].
Ostacher GS MJS. Update on bipolar disorder and substance abuse: recent findings and treatment strategies. J Clin Psychiatry. Sep. 2006;67(9):e10. [pmid: 17081077].
Pae A CUS, Patkar AA, Masand PS. Aripiprazole in the treatment of depressive and anxiety disorders: a review of current evidence. CNS Drugs. 2008;22(5):367-88. [pmid: 18399707].
Papakostas RC GIS. Use of atypical antipsychotics for treatment-resistant major depressive disorder. Curr Psychiatry Rep. Dec. 2008;10(6):481-6. [pmid: 18980731].
Pederson JL KJR, Mitchell JE. Towards the pharmacotherapy of eating disorders. Expert Opin Pharmacother. Oct. 2003;4(10):1659-78. [pmid: 14521477].
Philip LL NSC, Tyrka AR, Price LH. Augmentation of antidepressants with atypical antipsychotics: a review of the current literature. J Psychiatr Pract. Jan. 2008;14(1):34-44. [pmid: 18212601].
Pies R. Should psychiatrists use atypical antipsychotics to treat nonpsychotic anxiety?. Psychiatry (Edgmont). Jun. 2009;6(6):29-37. [pmid: 19724759].
Potvin E SS, Roy JY. Clozapine, quetiapine and olanzapine among addicted schizophrenic patients: towards testable hypotheses. Int Clin Psychopharmacol. May. 2003;18(3):121-32. [pmid: 12702890].
Powers H PSB. Pharmacotherapy for eating disorders and obesity. Child Adolesc Psychiatr Clin N Am. Jan. 2009;18(1):175-87. [pmid: 19014865].
Powers C PSS. Available pharmacological treatments for anorexia nervosa. Expert Opin Pharmacother. Nov. 2004;5(11):2287-92. [pmid: 15500375].
Preti A. New developments in the pharmacotherapy of cocaine abuse. Addict Biol. Jun. 2007;12(2):133-51. [pmid: 17508985].
Ravindran TL AVdS, Ravindran LN, Richter MA, Rector NA. Obsessive-compulsive spectrum disorders: a review of the evidence-based treatments. Can J Psychiatry. May. 2009;54(5):331-43. [pmid: 19497165].
Ravindran MB LNS. Pharmacotherapy of PTSD: premises, principles, and priorities. Brain Res. Oct. 13. 2009;1293:24-39. [pmid: 19332035].
Rosa C ARF, Torrent C, Comes M, Cruz N, Horga G, Benabarre A, Vieta E. Ziprasidone in the treatment of affective disorders: a review. CNS Neurosci Ther. Winter. 2008;14(4):278-86. [pmid: 19040553].
Rowe DL. Off-label prescription of quetiapine in psychiatric disorders. Expert Rev Neurother. Jul. 2007;7(7):841-52. [pmid: 17610391].
Sartorius WW NF, Gjerris A, Kern U, Knapp M, Leonard BE, Lieberman JA, Lopez-Ibor JJ, Van Raay B, Twomey E, Kupfer DJ, Angst J, Cassano GB, Crow TJ, Freeman H, Gelder MG, De Girolamo G, Katschnig H, Lader MH, Leon CA, Mak FL, Maj M, Metzler HY, Offord D, Okasha A, Parker G, Remschmidt H, Rutter M, Simon GE. The usefulness and use of second-generation antipsychotic medications: Preface. Current Opinion in Psychiatry. May. 7. 2002;15(SUPPL. 1):S1-S51.
Saunders KR EFS. Personality trait dimensions and the pharmacological treatment of borderline personality disorder. J Clin Psychopharmacol. Oct. 2009;29(5):461-7. [pmid: 19745646].
Scahill Gerald LE, Berlin Cheston M Jr, Budman Cathy, Coffey Barbara J, Jankovic Joseph, Kiessling Louise, King Robert A, Kurlan Roger, Lang Anthony, Mink Jonathan, Murphy Tanya, Zinner Samual, Walkup John. Contemporary Assessment and Pharmacotherapy of Tourette Syndrome. NeuroRX. 2006;3(2):192-206. [pmid: 16554257].
Schoevers HL RAV, Koppelmans V, Kool S, Dekker JJ. Managing the patient with co-morbid depression and an anxiety disorder. Drugs. 2008;68(12):1621-34. [pmid: 18681487].
Schruers K KK, Luermans J, Haack MJ, Griez E. Obsessive-compulsive disorder: a critical review of therapeutic perspectives. Acta Psychiatr Scand. Apr. 2005;111(4):261-71. [pmid: 15740462].
Schulz S. The promise of atypical anti psychotics for borderline disorders. Presented at the 155th annual meeting of the American Psychiatric Association. Philadelphia, Pa. May 18-23, 2002.
Shelton RC. Augmentation strategies to increase antidepressant efficacy. J Clin Psychiatry. 10. 2007;68:18-22. [pmid: 17900205].
Shelton RC. Treatment-resistant depression. Are atypical antipsychotics effective and safe enough?. Current Psychiatry Reviews. 2006;5(10):31-44.
Stigler Marc N KAP, Posey David J, McDougle Christopher J. Weight Gain Associated with Atypical Antipsychotic Use in Children and Adolescents: Prevalence, Clinical Relevance, and Management. Pediatric Drugs. 2004;6(1):33-44. [pmid: 14969568].
Thase MH MET, Nelson JC, Fava M, Swanink R, Tran QV, Pikalov A, Yang H, Carlson BX, Marcus RN, Berman RM. Examining the Efficacy of Adjunctive Aripiprazole in Major Depressive Disorder: A Pooled Analysis of 2 Studies. Prim Care Companion J Clin Psychiatry. 2008;10(6):440-7. [pmid: 19287552].
The Royal College of Psychiatrists. Atypical Antipsychotics and Behavioral and Psychiatric Symptoms of Dementia. 2007. http://www.rcpsych.ac.uk/pdf/BPSD.pdf. Cited. April. 9. 2010.
Trifiro E GS, Gambassi G. Use of antipsychotics in elderly patients with dementia: do atypical and conventional agents have a similar safety profile?. Pharmacol Res. Jan. 2009;59(1):1-12. [pmid: 18977443].
Trivedi ME MHT, Fava M, Nelson CJ, Yang H, Qi Y, Tran QV, Pikalov A, Carlson BX, Marcus RN, Berman RM. Adjunctive aripiprazole in major depressive disorder: analysis of efficacy and safety in patients with anxious and atypical features. J Clin Psychiatry. Dec. 2008;69(12):1928-36. [pmid: 19192475].
Trivedi ME MHT, Osuntokun O, Henley DB, Case M, Watson SB, Campbell GM, Corya SA. An integrated analysis of olanzapine/fluoxetine combination in clinical trials of treatment-resistant depression. J Clin Psychiatry. Mar. 2009;70(3):387-96. [pmid: 19284928].
Turgay A. Treatment of comorbidity in conduct disorder with attention-deficit hyperactivity disorder (ADHD). Essent Psychopharmacol. 2005;6(5):277-90. [pmid: 16222912].
Vollm B. Assessment and management of dangerous and severe personality disorders. Curr Opin Psychiatry. Sep. 2009;22(5):501-6. [pmid: 19424066].
Weber KA JL-W, Scott LJ. Aripiprazole: in major depressive disorder. CNS Drugs. 2008;22(10):807-13. [pmid: 18788833].
Wisniewski CC SRC, Kim E, Kan HJ, Guo Z, Carlson BX, Tran QV, Pikalov A. Global benefit-risk analysis of adjunctive aripiprazole in the treatment of patients with major depressive disorder. Pharmacoepidemiol Drug Saf. Oct. 2009;18(10):965-72. [pmid: 19662630].
Wood JL JGC, Delap CM, Heiskell KD. Beyond methylphenidate: nonstimulant medications for youth with ADHD. J Atten Disord. Nov. 2007;11(3):341-50. [pmid: 17932386].
Zhu B Timothy AJW. Pharmacologic Treatment of Eating Disorders. Canadian Journal of Psychiatry. 2002;47(3):227.

## Rejected, Case Report

Arana-Lechuga O YS-E, de Santiago-Trevino N, Castillo-Montoya C, Teran-Perez G, Velazquez-Moctezuma J. Risperidone treatment of sleep disturbances in Tourette's syndrome. J Neuropsychiatry Clin Neurosci. Summer. 2008;20(3):375-6. [pmid: 18806248].
Barzman Beth DG, Delbello Melissa. Quetiapine for chronic motor Tic disorder. The American Journal of Psychiatry. Jul. 2004. 2004;161(7):1307. [pmid: 15229071].
Ben Djebara Y MW, Schupbach M, Hartmann A. Aripiprazole: a treatment for severe coprolalia in “refractory” Gilles de la Tourette syndrome. Mov Disord. Feb. 15. 2008;23(3):438-40. [pmid: 18067182].
Berkowitz AL. Ziprasidone Therapy in Elderly Patients with Psychotic Mood Disorders and Parkinson's Disease. Psychiatry. Nov. 2006;3(11):59-63. [pmid: 20877519].
Cohen JM JAP. Adolescent weight loss during treatment with olanzapine. J Child Adolesc Psychopharmacol. Winter. 2004;14(4):617-20. [pmid: 15662155].
Cole Rehan SAS, Shea William P, Sedler Mark, Sablosky Marilyn, Jyringi Darlene, Smith Angela. Ziprasidone for agitation or psychosis in dementia: Four cases. International Journal of Psychiatry in Medicine. 2005. 2005;35(1):91-8. [pmid: 15977947].
Constant L ELB, Seghers A. Aripiprazole is effective in the treatment of Tourette's disorder. Int J Neuropsychopharmacol. Dec. 2006;9(6):773-4. [pmid: 16734937].
Curtis RW ARR. The treatment of psychogenic excoriation and obsessive compulsive disorder using aripiprazole and fluoxetine. Ann Clin Psychiatry. Jul-Sep. 2007;19(3):199-200. [pmid: 17729023].
Czarnecki N KK, Josephs KA. Parkinsonism and tardive antecollis in frontotemporal dementia--increased sensitivity to newer antipsychotics?. European Journal of Neurology. Feb. 2008;15(2):199-201. [pmid: 18217890].
da Rocha H FFC. Successful augmentation with aripiprazole in clomipramine-refractory obsessive-compulsive disorder. Prog Neuropsychopharmacol Biol Psychiatry. Oct. 1. 2007;31(7):1550-1. [pmid: 17692447].
Dennis D KLG, Bremer J. Olanzapine use in adolescent anorexia nervosa. Eat Weight Disord. Jun. 2006;11(2):e53-6. [pmid: 16809970].
Desseilles F MM. Aripiprazole diminishes cannabis use in schizophrenia. J Neuropsychiatry Clin Neurosci. Winter. 2008;20(1):117-8. [pmid: 18305305].
Duggal HS. Ziprasidone for maladaptive behavior and attention-deficit/hyperactivity disorder symptoms in autistic disorder. J Child Adolesc Psychopharmacol. Apr. 2007;17(2):261-3. [pmid: 17489724].
Ehrt Friederike UF, Aarsland Dag. Respiratory Dyskinesia as Discontinuation Effect of Risperidone. Journal of Clinical Psychopharmacology. Dec. 2005. 2005;25(6):609. [pmid: 16282850].
Fernando G AC. Chronic insomnia secondary to chronic pain responding to quetiapine. Australas Psychiatry. Mar. 2005;13(1):86. [pmid: 15777423].
Fountoulakis A KNI, Siamouli M, Koumaris V, Kaprinis GS. Successful treatment of anorexia with a combination of high-dose olanzapine, fluoxetine and mirtazapine. Int J Clin Pharmacol Ther. Sep. 2006;44(9):452-3. [pmid: 16995335].
Fountoulakis M KNS, Kantartzis S, Panagiotidis P, Iacovides A, Kaprinis GS. Acute dystonia with low-dosage aripiprazole in Tourette's disorder. Ann Pharmacother. Apr. 2006;40(4):775-7. [pmid: 16569800].
Friedman TA SA, Oumaya M, Rouillon F, Guelfi JD. Aripiprazole augmentation of clomipramine-refractory obsessive-compulsive disorder. J Clin Psychiatry. Jun. 2007;68(6):972-3. [pmid: 17592930].
Gentile S. Quetiapine-fluvoxamine combination during pregnancy and while breastfeeding. Arch Womens Ment Health. May. 2006;9(3):158-9. [pmid: 16683078].
Ginsberg DL. Aripiprazole Augmentation for Treatment-Resistant Depression. Primary Psychiatry. Jun. 2005. 2005;12(6):26-7.
Ginsberg DL. Quetiapine effective for chronic motor tics. Primary Psychiatry. Aug. 2004. 2004;11(8):22.
Gupta D NB. Does risperidone reduce concomitant substance abuse in cases of schizophrenia?. Can J Psychiatry. Nov. 2001;46(9):862-3. [pmid: 11761640].
Hansen L. Olanzapine in the treatment of anorexia nervosa. Br J Psychiatry. Dec. 1999;175:592. [pmid: 10789371].
Heinrich Lee A TWB, Schneider John. Torsades de Pointes Associated With Ziprasidone. Psychosomatics. June. 1. 2006. 2006;47(3):264-8. [pmid: 16684946].
Hounie A ADM, Sampaio AS, Mercadante MT. [Aripiprazole and Tourette syndrome]. Rev Bras Psiquiatr. Sep. 2004;26(3):213. [pmid: 15645072].
Huther C RG, Mirisch S, Bauml J, Forstl H. Choreatic symptoms during and after treatment with paliperidone and escitalopram. Pharmacopsychiatry. Sep. 2008;41(5):203-4. [pmid: 18763225].
Inoue Hisashi KT, Aoki Tatesuke, Kaiya Hisanobu, Nishimura Yukika, Nishida Atsushi, Kajiki Naomi, Yokoyama Chika, Takeda Masatoshi, Okazaki Yuji. The Report That Olanzapine had an Effect in PTSD. International Medical Journal. Dec. 2006. 2006;13(4):265-7.
Inta Susanne DE, Zink Mathias. Aripiprazole monotherapy for Tourette syndrome accompanied by obsessive-compulsive symptoms. German Journal of Psychiatry. 2008. 2008;11(3):123-5.
Karam-Hage N MG. Olanzapine in Tourette's disorder. J Am Acad Child Adolesc Psychiatry. Feb. 2000;39(2):139. [pmid: 10673819].
Kellner M. Aripiprazole in a therapy-resistant patient with borderline personality and post-traumatic stress disorder. Pharmacopsychiatry. Jan. 2007;40(1):41. [pmid: 17327963].
Kikukawa S. Effectiveness of aripiprazole in treatment of adults with attention deficit disorder and restless legs syndrome. Int J Neuropsychopharmacol. May. 2008;11(3):439-40. [pmid: 18208634].
Koelsch D. Olanzapine as an add-on therapy in post-traumatic stress disorder (PTSD). German Journal of Psychiatry. 2007. 2007;10(2):50-2.
Laks Roberto JM, Marinho Valeska, Engelhardt Eliasz. Use of aripiprazole for psychosis and agitation in dementia. International Psychogeriatrics. 2006;18(02):335-40. [pmid: 16255839].
Leey Belinda JS, Murphy Patrick, Antimisiaris Demetra, Miles Toni. Quetiapine-induced dystonia and agitation in Parkinson disease with dementia: A case report. Journal of the American Geriatrics Society. May. 2009. 2009;57(5):918-9. [pmid: 19470011].
Mehler-Wex M CR, Kirchheiner J, Schulze UM. Atypical antipsychotics in severe anorexia nervosa in children and adolescents--review and case reports. Eur Eat Disord Rev. Mar. 2008;16(2):100-8. [pmid: 18000964].
Misra L LKK, Fuller W. Treatment of inhalant abuse with risperidone. J Clin Psychiatry. Sep. 1999;60(9):620. [pmid: 10520984].
Mobascher J AM, Schlemper V, Winterer G, Malevani J. Aripiprazole Pharmacotherapy of Borderline Personality Disorder. Pharmacopsychiatry. 2006;39(03):111-2. [pmid: 16721700].
Ozbulut Murat OE, Guler Ozkan, Gecici Omer. Tardive dyskinesia with ziprasidone and citalopram use in an elderly female patient. Psychogeriatrics. Jun. 2008. 2008;8(2):96-7.
Padala D PRL, Petty F, Bhatia SC. Adjunctive aripiprazole in combat-related posttraumatic stress disorder. Ann Pharmacother. Oct. 2007;41(10):1744. [pmid: 17848426].
Pae CU. Potential utility of aripiprazole monotherapy for the treatment of major depressive disorder comorbid with obsessive-compulsive disorder. Psychiatry Clin Neurosci. Aug. 2009;63(4):593. [pmid: 19659566].
Peters L BdH. Remission of schizophrenia psychosis and strong reduction of obsessive-compulsive disorder after adding clozapine to aripiprazole. Prog Neuropsychopharmacol Biol Psychiatry. 2009. Sep. 18.
Prakash A RP, Munda S, Bagati D. Quetiapine effective in treatment of inappropriate sexual behavior of lewy body disease with predominant frontal lobe signs. Am J Alzheimers Dis Other Demen. Apr-May. 2009;24(2):136-40. [pmid: 19129547].
Preskorn SH. Multiple medication use presenting as Parkinson's dementia complex: A message from Titanic. Journal of Psychiatric Practice. Jan. 2008;14(1):45-54. [pmid: 18212602].
Ritchie ML BN. QTc Prolongation Associated With Atypical Antipsychotic Use in the Treatment of Adolescent-Onset Anorexia Nervosa. J Can Acad Child Adolesc Psychiatry. Feb. 2009;18(1):60-3. [pmid: 19270852].
Sarkar J RK, Kruger S. Aripiprazole augmentation in treatment-refractory obsessive-compulsive disorder. Psychopharmacology (Berl). May. 2008;197(4):687-8. [pmid: 18264798].
Sattar SC SPB. Olanzapine for cocaine cravings and relapse prevention. J Clin Psychiatry. Aug. 2003;64(8):969. [pmid: 12927016].
Sattar Kathleen SPG, Bhatia Subhash, Petty Frederick. Potential use of olanzapine in treatment of substance dependence disorders. Journal of Clinical Psychopharmacology. Aug. 2003. 2003;23(4):413-5. [pmid: 12920420].
Scahill J LB, Leckman JF, Martin A. Sudden death in a patient with Tourette syndrome during a clinical trial of ziprasidone. J Psychopharmacol. Mar. 2005;19(2):205-6. [pmid: 15728441].
Schmidt SK. Quetiapine: A New Adjunctive Medication in Addictions Treatment. Journal of Addictions Nursing. 2006;17(1):65.
Sokolski BJ KNB. Quetiapine for insomnia associated with refractory depression exacerbated by phenelzine. Ann Pharmacother. Mar. 2006;40(3):567-70. [pmid: 16478812].
Thomas P NS, Russell S, Angothu H. Tardive dyskinesia following risperidone treatment in Tourette's syndrome. Neurol India. Jan-Feb. 2009;57(1):94-5. [pmid: 19305093].
Tranulis S CP, Gourgue M, Leblanc G, Mancini-Marie A, Stip E. The paradox of quetiapine in obsessive-compulsive disorder. CNS Spectr. May. 2005;10(5):356-61. [pmid: 15858452].
Uzun O, Ozdemir B. Aripiprazole as an augmentation agent in treatment-resistant body dysmorphic disorder. Clin Drug Investig. 2010;30(10):707-10.
Valerius NC GB, Schaerer LO, Langosch JM. Quetiapine in the Treatment of Rapid-Cycling Bipolar II Disorder With Comorbid Anxiety and Social Phobia. Pharmacopsychiatry. Sep. 2005. 2005;38(5):225-6. [pmid: 16189752].
Van den Eynde KH FN, De Saedeleer S, van Heeringen C, Audenaert K. Olanzapine in Gilles de la Tourette syndrome: beyond tics. Acta Neurol Belg. Dec. 2005;105(4):206-11. [pmid: 16482870].
Wang YH TSC, Shiah IS. Combined treatment of olanzapine and mirtazapine in anorexia nervosa associated with major depression. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 2006;30(2):306-9. [pmid: 16314020].
Weintraub DH, Howard I. Presentation and management of psychosis in Parkinson's disease and dementia with Lewy bodies. The American Journal of Psychiatry. Oct. 2007. 2007;164(10):1491-8. [pmid: 17898337].
Yao PH YCC, Hsiao MC, Liu CY. Effective treatment of premenstrual violence in major depression: augmentation with aripiprazole. Chang Gung Med J. Jul-Aug. 2008;31(4):402-6. [pmid: 18935799].
Yasuhara T DN, Harada T, Inui A. Olanzapine-induced hyperglycemia in anorexia nervosa. Am J Psychiatry. Mar. 2007;164(3):528-9. [pmid: 17329484].
Yumru M, Eren Ozen M, Savas HA, Selek S. Long-acting injectable risperidone for control of agitation in dementia. J Clin Psychiatry. Oct. 2006;67(10):1651-2. [pmid: 17107263].

## Rejected, Observational Studies—Sample Size <1,000

Alessi-Severini S, Biscontri RG, Collins DM, Kozyrskyj A, Sareen J, Enns MW. Utilization and costs of antipsychotic agents: A Canadian population-based study, 1996-2006. Psychiatric Services. May. 2008. 2008;59(5):547-53. [pmid: 18451015].
Philip NS, Mello K, Carpenter LL, Tyrka AR, Price LH. Patterns of quetiapine use in psychiatric inpatients: An examination of off-label use. Annals of Clinical Psychiatry. Feb. 2008. 2008;20(1):15-20. [pmid: 18297582].
Taylor M, Shajahan P, Lawrie SM. Comparing the use and discontinuation of antipsychotics in clinical practice: An observational study. Journal of Clinical Psychiatry. Feb. 2008. 2008;69(2):240-5. [pmid: 18363452].
Ahearn M EPM, Johnson C, Krohn A, Krahn D. Quetiapine as an adjunctive treatment for post-traumatic stress disorder: an 8-week open-label study. Int Clin Psychopharmacol. Jan. 2006;21(1):29-33. [pmid: 16317314].
Aras S, Varol Tas F, Unlu G. Medication prescribing practices in a child and adolescent psychiatry outpatient clinic. Child Care Health Dev. Jul. 2007;33(4):482-90. [pmid: 17584405].
Atik L, Erdogan A, Karaahmet E, Saracli O, Atasoy N, Kurcer MA, et al. Antipsychotic prescriptions in a university hospital outpatient population in Turkey: a retrospective database analysis, 2005-2006. Prog Neuropsychopharmacol Biol Psychiatry. May. 15. 2008;32(4):968-74. [pmid: 18243462].
Bosanac G PB, Norman T. Olanzapine in anorexia nervosa. Aust N Z J Psychiatry. Aug. 2003;37(4):494. [pmid: 12873339].
Botvinik L, Ng C, Schweitzer I. Audit of antipsychotic prescribing in a private psychiatric hospital. Australas Psychiatry. Sep. 2004;12(3):227-33. [pmid: 15715780].
Doey T, Handelman K, Seabrook JA, Steele M. Survey of atypical antipsychotic prescribing by Canadian child psychiatrists and developmental pediatricians for patients aged under 18 years. Can J Psychiatry. Jun. 2007;52(6):363-8. [pmid: 17696022].
Etxebeste E MA, Malo P, Pacheco L. Olanzapine and panic attacks. Am J Psychiatry. Apr. 2000;157(4):659-60. [pmid: 10739446].
Kamble P, Chen H, Sherer JT, Aparasu RR. Use of antipsychotics among elderly nursing home residents with dementia in the US: an analysis of National Survey Data. Drugs Aging. 2009;26(6):483-92. [pmid: 19591523].
Khaldi C SK, Dan B, Pelc I. Usefulness of olanzapine in refractory panic attacks. J Clin Psychopharmacol. Feb. 2003;23(1):100-1. [pmid: 12544382].
Lenderts A SK. Treatment of depression: an update on antidepressant monotherapy and combination therapy. Psychiatry (Edgmont). Aug. 2009;6(8):15-7. [pmid: 19763202].
Mellman TA, Clark RE, Peacock WJ. Prescribing patterns for patients with posttraumatic stress disorder. Psychiatr Serv. Dec. 2003;54(12):1618-21. [pmid: 14645801].
Monnelly DA EPC, Knapp C, LoCastro J, Sepulveda I. Quetiapine for treatment of alcohol dependence. J Clin Psychopharmacol. Oct. 2004;24(5):532-5. [pmid: 15349010].
Radigan P ML, Roohan P, Gesten F. Medication patterns for attention-deficit/hyperactivity disorder and comorbid psychiatric conditions in a low-income population. J Child Adolesc Psychopharmacol. Feb. 2005;15(1):44-56. [pmid: 15741785].
Sagud A MM-P, Muck-Seler D, Jakovljevic M, Pivac N. Quetiapine augmentation in treatment-resistant depression: a naturalistic study. Psychopharmacology (Berl). Sep. 2006;187(4):511-4. [pmid: 16802162].
Sattar SK SPS, Arndt S, Soundy T, Petty F. Long-term adjunctive quetiapine may reduce substance use--a preliminary retrospective study. S D Med. Nov. 9. 2007;60(11):437-41. 43. passim. [pmid: 18196687].
Sharpley AL, Attenburrow ME, Hafizi S, Cowen PJ. Olanzapine increases slow wave sleep and sleep continuity in SSRI-resistant depressed patients. J Clin Psychiatry. Apr. 2005;66(4):450-4. [pmid: 15816787].
Todder S DC, Baune BT. Night locomotor activity and quality of sleep in quetiapine-treated patients with depression. J Clin Psychopharmacol. Dec. 2006;26(6):638-42. [pmid: 17110822].
Valiyeva E, Herrmann N, Rochon PA, Gill SS, Anderson GM. Effect of regulatory warnings on antipsychotic prescription rates among elderly patients with dementia: a population-based time-series analysis. CMAJ. Aug. 26. 2008;179(5):438-46. [pmid: 18725616].
Yang TP KCS, Chou YH. Effectiveness of aripiprazole in treating obsessive compulsive symptoms. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 15. 2008;32(2):585-6. [pmid: 18037548].
Harpaz-Rotem I, Rosenheck RA, Mohamed S, Desai RA. Pharmacologic treatment of posttraumatic stress disorder among privately insured Americans. Psychiatr Serv. Oct. 2008;59(10):1184-90. [pmid: 18832505].
Mohamed S, Rosenheck R. Pharmacotherapy for older veterans diagnosed with posttraumatic stress disorder in Veterans Administration. Am J Geriatr Psychiatry. Oct. 2008;16(10):804-12. [pmid: 18827226].
Mohamed S, Rosenheck RA. Pharmacotherapy of PTSD in the U.S. Department of Veterans Affairs: diagnostic- and symptom-guided drug selection. J Clin Psychiatry. Jun. 2008;69(6):959-65. [pmid: 18588361].
Yang JC MB, Worchel J. Factors related to antipsychotic oversupply among Central Texas Veterans. Clin Ther. Jun. 2007;29(6):1214-25. [pmid: 17692735].
Cascade E, Kalali AH, Cummings JL. Use of atypical antipsychotics in the elderly. Psychiatry (Edgmont). Jul. 2008;5(7):28-31.
Robinson M, Rowett D, Leverton A, Mabbott V. Changes in utilisation of anticholinergic drugs after initiation of cholinesterase inhibitors. Pharmacoepidemiol Drug Saf. Aug. 2009;18(8):659-64. [pmid: 19548222].
Monnelly Joseph S EPL, Gagnon David, Young Melissa, Fiore Louis D. Quetiapine versus trazodone in reducing rehospitalization for alcohol dependence: A large data-base study. Journal of Addiction Medicine. Sep. 2008. 2008;2(3):128-34. [pmid: 21768982].
Poling JK, Thomas R. Risperidone for Substance Dependent Psychotic Patients. Addictive Disorders & Their Treatment. 2005. 2005;4(1):1-3.
Ray Kent E LAH, Bryan Angela. Psychosocial predictors of treatment outcome, dropout, and change processes in a Pharmacological clinical trial for alcohol dependence. Addictive Disorders & Their Treatment. 2006. 2006;5(4):179-90.
De La Garza R 2nd, Newton TF, Kalechstein AD. Risperidone diminishes cocaine-induced craving. Psychopharmacology (Berl). Mar. 2005;178(2-3):347-50. [pmid: 15452684].
Green ES AIB, Dawson R, Zimmet SV, Strous RD. Alcohol and cannabis use in schizophrenia: effects of clozapine vs. risperidone. Schizophr Res. Mar. 1. 2003;60(1):81-5. [pmid: 12505141].
Longo LP. Olanzapine for cocaine craving and relapse prevention in 2 patients. J Clin Psychiatry. Jul. 2002;63(7):595-6. [pmid: 12143917].
Newton W TFL, Kalechstein AD, Uslaner J, Tervo K. Risperidone pre-treatment reduces the euphoric effects of experimentally administered cocaine. Psychiatry Res. Jul. 24. 2001;102(3):227-33. [pmid: 11440773].
Potvin E SS, Roy JY. The effect of quetiapine on cannabis use in 8 psychosis patients with drug dependency. Can J Psychiatry. Oct. 2004;49(10):711. [pmid: 15560324].
Roy M AR, Smelson DA. Risperidone, ERG and cocaine craving. Am J Addict. Winter. 1998;7(1):90. [pmid: 9522012].
Smelson MF DAL, Davis CW, Kaune M, Williams J, Ziedonis D. Risperidone decreases craving and relapses in individuals with schizophrenia and cocaine dependence. Can J Psychiatry. Sep. 2002;47(7):671-5. [pmid: 12355680].
Smelson A DAR, Roy M. Risperidone diminishes cue-elicited craving in withdrawn cocaine-dependent patients. Can J Psychiatry. Nov. 1997;42(9):984. [pmid: 9429074].
Stuyt TA EBS, Allen MH. Differing effects of antipsychotic medications on substance abuse treatment patients with co-occurring psychotic and substance abuse disorders. Am J Addict. Mar-Apr. 2006;15(2):166-73. [pmid: 16595355].
Tsuang T JWE, Marder S, Tucker D. Can risperidone reduce cocaine use in substance abusing schizophrenic patients?. J Clin Psychopharmacol. Dec. 2002;22(6):629-30. [pmid: 12454567].
Etxebeste Enrique MA, Malo Pablo, Pacheco Luis. Olanzapine and Panic Attacks. Am J Psychiatry. April. 1. 2000. 2000;157(4):659-a-60. [pmid: 10739446].
Polinski JM, Wang PS, Fischer MA. Medicaid's Prior Authorization Program And Access To Atypical Antipsychotic Medications. Health Aff. May. 1. 2007. 2007;26(3):750-60.
Cooper Patrick G WOA, Ding Hua, Hickson Gerald B, Fuchs D Catherine, Ray Wayne A. Trends in Prescribing of Antipsychotic Medications for US Children. Ambulatory Pediatrics. 2006;6(2):79-83. [pmid: 16530143].
Sernyak MJ, Kosten TR, Fontana A, Rosenheck R. Neuroleptic Use in the Treatment of Post-Traumatic Stress Disorder. Psychiatric Quarterly. 2001;72(3):197-213. [pmid: 11467155].
Fourrier A, Gasquet I, Allicar MP, Bouhassira M, Lépine JP, Bégaud B. Patterns of neuroleptic drug prescription: a national cross-sectional survey of a random sample of French psychiatrists. British Journal of Clinical Pharmacology. 2000;49(1):80-6. [pmid: 10606841].
Roy E JYS, Potvin S. The effect of quetiapine (seroquel) on cannabis use in 8 drug-dependent psychotic patients. Can J Psychiatry. submitted. 2003.
Leggero C, Masi G, Brunori E, Calderoni S, Carissimo R, Maestro S, et al. Low-dose olanzapine monotherapy in girls with anorexia nervosa, restricting subtype: focus on hyperactivity. J Child Adolesc Psychopharmacol. Apr. 2010;20(2):127-33. [pmid: 20415608].
Alexander GC, Gallagher SA, Mascola A, Moloney RM, Stafford RS. Increasing off-label use of antipsychotic medications in the United States, 1995-2008. Pharmacoepidemiol Drug Saf. Feb. 2011;20(2):177-84. [pmid: 21254289].
Leslie DL, Mohamed S, Rosenheck RA. Off-label use of antipsychotic medications in the department of Veterans Affairs health care system. Psychiatr Serv. Sep. 2009;60(9):1175-81. [pmid: 19723731].

## Rejected Due to Other Design (Open Label)

Rapaport GM MHG, Canuso CM, Mahmoud RA, Keller MB, Bossie CA, Turkoz I, Lasser RA, Loescher A, Bouhours P, Dunbar F, Nemeroff CB. Effects of Risperidone Augmentation in Patients with Treatment-Resistant Depression: Results of Open-Label Treatment Followed by Double-Blind Continuation. Neuropsychopharmacology. 2006;31(11):2505-13. [pmid: 16760927].
Saad M, Cassagnol M, Ahmed E. The Impact of FDA's Warning on the Use of Antipsychotics in Clinical Practice: A Survey. Consult Pharm. Nov. 2010;25(11):739-44. [pmid: 21138822].
Savas HA, Yumru M, Ã–zen ME. Quetiapine and Ziprasidone as Adjuncts in Treatment-Resistant Obsessive-Compulsive Disorder: A Retrospective Comparative Study. Clinical Drug Investigation. 2008;28(7):439. [pmid: 18544004].
Soares CN, Frey BN, Haber E, Steiner M. A pilot, 8-week, placebo lead-in trial of quetiapine extended release for depression in midlife women: impact on mood and menopause-related symptoms. J Clin Psychopharmacol. Oct. 2010;30(5):612-5. [pmid: 20814317].

## Rejected, Foreign Language

Baño JA MDM, Agujetas M, López ML, Guillén JL. Eficacia del antipsicótico olanzapina en el tratamiento del abuso de cocaína en pacientes en mantenimiento con metadona Interacción en los niveles plasmáticos Olanzapine efficacy in the treatment of cocaine abuse in methadone maintenance patients: Interaction with plasma levels. Actas Españolas de Psiquiatría. Jul-Aug. 2001;29(4):215-20.
Boulin S MM, Serot D, Martin P, Alizon B, Vailleau JL. [Prescribing practices of second generation antipsychotics in hospital units]. Therapie. 2005;60(6):567-72. [pmid: 16555494].
Bret F PB, Bret MC, Jaffre A. [Use of atypical antipsychotics in Charles Perrens psychiatric hospital (Bordeaux) analysis of prescribing practices for Amisulpride, Clozapine, Olanzapine and Risperidone]. Encephale. Jul-Aug. 2002;28(4):329-42. [pmid: 12232542].
Bret MC PB, Queuille E. [Prescribing patterns of antipsychotics in 13 French psychiatric hospitals]. Encephale. Apr. 2009;35(2):129-38. [pmid: 19393381].
Casas Brugué M MG, Gibert J, Bobes J, Roncero C, Octavio I. Risperidona en el tratamiento de pacientes psicóticos con abuso y dependencia de opiáceos Risperidone in the treatment of psychotic patients with opiate abuse and dependence. Actas Españolas de Psiquiatría 2001. Nov-Dec. 2001. 2001;29(6):380-5.
Cath G DCM, de Jonge JL, van Balkom AJ. [Antipsychotics in the treatment of Tourette disorder: a review]. Tijdschr Psychiatr. 2008;50(9):593-602. [pmid: 18785106].
Chitaya DS NND, Tiuvina NA. [Peculiarities of neuroleptic syndrome in women treated with typical and atypical neuroleptics]. Zh Nevrol Psikhiatr Im S S Korsakova. 2009;109(3):37-43.
Drozdov ES. [Rispolept (risperidone) efficacy in the treatment of patients with schizophrenia and psychoactive drug dependence]. Voen Med Zh. Jul. 2002;323(7):46-52. [pmid: 12192989].
Dulz Amelie BW. Zur medikamentösen Anxiolyse bei Borderline-Patienten About the treatment of borderline patients with neuroleptics: Effects and side effects. PTT: Persönlichkeitsstörungen Theorie und Therapie. Nov. 2003. 2003;7(4):253-62.
1Dumortier W GC, Stamatiadis L, Saba G, Benadhira R, Rocamora JF, Aubriot-Delmas B, Glikman J, Januel D. Tolérance hépatique des antipsychotiques atypiques Hepatic tolerance of atypical antipsychotic drugs. L'Encéphale: Revue de psychiatrie clinique biologique et thérapeutique. Nov-Dec. 2002. 2002;28(6):542-51.
Forlenza E OVC, Diniz BS. [The use of antipsychotics in patients with dementia]. Rev Bras Psiquiatr. Sep. 2008;30(3):265-70. [pmid: 18833428].
Fremaux JM TR, Chevreuil C, Bentue-Ferrer D. [Prescription of olanzapine in children and adolescent psychiatric patients]. Encephale. Mar-Apr. 2007;33(2):188-96. [pmid: 17675914].
Haupt A MS, Schwalen S. Behandlungseffekte auf Verhaltensstörungen, psychotische und somatische Symptome bei Patienten mit Demenz: Ein Vergleich zwischen Melperon und Risperidon Pharmacological effects in the treatment of behavioural and somatic symptoms of dementia: A comparison between risperidone and melperone. Nervenheilkunde: Zeitschrift für interdisziplinaere Fortbildung. 2004. 2004;23(9):539-44.
Iglesias Garcia S CSM, Alonso Villa MJ. [Ziprasidone as coadjuvant treatment in resistant obsessive-compulsive disorder treatment]. Actas Esp Psiquiatr. Jul-Aug. 2006;34(4):277-9. [pmid: 16823689].
Martinez Martinez MR LOF, Pineiro Corrales G. [Mortality in patients with dementia treateds with atypical antipsychotics (olanzapine, quetiapine and ziprasidone).]. Farm Hosp. Jul. 1. 2009;33(4):224-8. [pmid: 19712611].
Martinez Raga J JD-A, Job A, Knecht CC, Cepeda S, San L, Perez-Galvez B. [Post-traumatic stress disorder and substance use disorder: treatment intervention]. Vertex. Nov-Dec. 2005;16(64):412-7. [pmid: 16314894].
Mehler-Wex S CR, Warnke A. [Aatypical antipsychotics in child and adolescent psychiatry--indications apart from schizophrenia]. Z Kinder Jugendpsychiatr Psychother. Jul. 2005;33(3):159-68. [pmid: 16097264].
Montecchi M FM, Marinucci S, Gambarara M, Diamanti A. Risperidone nel controllo dei sintomi negativi nell'anoressia nervosa in adolescenza Risperidone in the control of negative symptoms in anorexia nervosa in adolescents. Minerva Psichiatrica. Dec. 1998. 1998;39(4):205-9.
Morant F AM, Hernandez S, Rosello B. [Pharmacological treatment with risperidone in children with behavior disorders]. Rev Neurol. Aug. 1-15. 2001;33(3):201-8. [pmid: 11588710].
Orlandi Camilla VOR, Bersani Giuseppe. L'impiego di neurolettici atipici in pazienti con doppia diagnosi di schizofrenia e abuso di cannabis: Dati clinici con olanzapina Atypical antipsycholics in patients with schizophrenia and comorbid cannabis abuse: Clinical data with olanzapine. Rivista di Psichiatria. Sep-Oct. 2004. 2004;39(5):356-64.
Pelland JF CT. [Atypical antipsychotic efficacy and safety in managing delirium: a systematic review and critical analysis]. Psychol Neuropsychiatr Vieil. Jun. 2009;7(2):109-19. [pmid: 19473954].
Scholten JP MRS. [Suicidal ideations and suicide attempts after starting on aripiprazole, a new antipsychotic drug]. Ned Tijdschr Geneeskd. Oct. 8. 2005;149(41):2296-8. [pmid: 16240856].
Vilalta-Franch S JL-P, Garre-Olmo J, Turon-Estrada A, Pericot-Nierga I. [Mortality rates in patients with Alzheimer's disease treated with atypical neuroleptic drugs]. Rev Neurol. Feb. 1-15. 2008;46(3):129-34. [pmid: 18297617].
Wittmann M, Hausner H, Hajak G, Haen E. Antipsychotic Treatment of Dementia After Publication of New Risks. Psychiatr Prax. 2009. Sep. 1.
Wobrock R TDA, Falkai P. [Pharmacotherapy of schizophrenia and comorbid substance use disorder. A systematic review]. Nervenarzt. Jan. 2008;79(1):17-8. 20. 2. 4-6 passim. [pmid: 17619840].
Yildiz A. [Benzodiazepines, typical and atypical antipsychotics in the management of acute agitation: a review]. Turk Psikiyatri Derg. Summer. 2003;14(2):134-44. [pmid: 12844280].
Zhao Ying HZ. [Untitled]. Risperidone in treatment of Tourette syndrome. Chinese Mental Health Journal. Jan. 2003. 2003;17(1):30.

## Reject Due to Focus

Angelucci S FB, Gravina P, Bellincampi L, Trequattrini A, Di Iulio F, Vanni D, Federici G, Caltagirone C, Bossu P, Spalletta G. Delusion symptoms and response to antipsychotic treatment are associated with the 5-HT2A receptor polymorphism (102T/C) in Alzheimer's disease: a 3-year follow-up longitudinal study. J Alzheimers Dis. May. 2009;17(1):203-11. [pmid: 19494443].
Bergh Knut SE. The withdrawal of antipsychotics and antidepressants from patients with dementia and BPSD living in nursing homes--An open pilot study. International Journal of Geriatric Psychiatry. Aug. 2008. 2008;23(8):877-9. [pmid: 18655022].
Coley TJ KCF, Kim E, Ammerman DK, Scipio TM, Saul MI, Kim MS, Whitehead R, Ganguli R. Predictors of aripiprazole treatment continuation in hospitalized patients. J Clin Psychiatry. Sep. 2008;69(9):1393-7. [pmid: 19012819].
Ruths Jørund SS, Nygaard Harald A, Aarsland Dag. Stopping antipsychotic drug therapy in demented nursing home patients: A randomized, placebo-controlled study--The Bergen District Nursing Home Study (BEDNURS). International Journal of Geriatric Psychiatry. Sep. 2008. 2008;23(9):889-95. [pmid: 18306150].
Segal-Trivitz Y YB, Goldburt Y, Sobol-Havia D, Levkovitch Y, Ratzoni G. Comparison of symptoms and treatments of adults and adolescents with borderline personality disorder. Int J Adolesc Med Health. Apr-Jun. 2006;18(2):215-20. [pmid: 16894860].
Ballard Marisa Margallo CL, Theodoulou Megan, Douglas Simon, McShane Rupert, Jacoby Robin, Kossakowski Katja, Yu Ly-Mee, Juszczak Edmund, on behalf of the Investigators, Dart Ad. A Randomised, Blinded, Placebo-Controlled Trial in Dementia Patients Continuing or Stopping Neuroleptics (The DART-AD Trial). PLoS Med. 2008;5(4):e76. [pmid: 18384230].

## Rejected Due to Topic (Not Off-Label Use of Atypicals)

Becker PM. Treatment of sleep dysfunction and psychiatric disorders. Curr Treat Options Neurol. Sep. 2006;8(5):367-75. [pmid: 16901376].
Becker M PMS. Treatment of sleep dysfunction and psychiatric disorders. Curr Treat Options Neurol. Sep. 2009;11(5):349-57. [pmid: 19744401].
Brown VA ESN, Perantie DC, Rajan Thomas N, Rush AJ. Cocaine and amphetamine use in patients with psychiatric illness: a randomized trial of typical antipsychotic continuation or discontinuation. J Clin Psychopharmacol. Aug. 2003;23(4):384-8. [pmid: 12920415].
Citrome L, Jaffe A, Levine J. Datapoints: depot antipsychotic use in New York State hospitals, 1994 to 2009. Psychiatr Serv. Jan. 2010;61(1):9. [pmid: 20044411].
DelBello S MG. Phenomenology and epidemiology of childhood psychiatric disorders that may necessitate treatment with atypical antipsychotics. J Clin Psychiatry. 6. 2004;65:12-9. [pmid: 15104522].
Dresser J RF. Off-label prescribing: a call for heightened professional and government oversight. J Law Med Ethics. Fall. 2009;37(3):476-86. 396. [pmid: 19723258].
Fossey C JB, Juszczak E, James I, Alder N, Jacoby R, Howard R. Effect of enhanced psychosocial care on antipsychotic use in nursing home residents with severe dementia: cluster randomised trial. BMJ. Apr. 1. 2006;332(7544):756-61. [pmid: 16543297].
Gruber-Baldini Bruce ALS, Zuckerman Ilene H, Simoni-Wastila Linda, Miller Ram. ‘Treatment of dementia in community-dwelling and institutionalized Medicare beneficiaries’: Erratum. Journal of the American Geriatrics Society. Oct. 2007;55(10):1697.
Haliburn J. Australian and New Zealand clinical practice guidelines for the treatment of anorexia nervosa. Australian and New Zealand Journal of Psychiatry. Jul. 2005;39(7):639-40. [pmid: 15996147].
Hansen Gerald RAG, Lohr Kathleen N, Gaynes Bradley N, Carey Timothy S. Efficacy and Safety of Second-Generation Antidepressants in the Treatment of Major Depressive Disorder. Annals of Internal Medicine. September. 20. 2005;143(6):415-26. [pmid: 16172440].
Hay P. Australian and New Zealand clinical practice guidelines for the treatment of anorexia nervosa. Australian and New Zealand Journal of Psychiatry. Sep. 2004. 2004;38(9):659-70. [pmid: 15324328].
Huang I Shin C-CS, Chen Hsing-Kang, Mao Wei-Chung, Yeh Yi-Wei. Adjunctive use of methylphenidate in the treatment of psychotic unipolar depression. Clinical Neuropharmacology. Jul-Aug. 2008. 2008;31(4):245-7. [pmid: 18670250].
Huang IC WFL. Patterns of sleep-related medications prescribed to elderly outpatients with insomnia in Taiwan. Drugs Aging. 2005;22(11):957-65. [pmid: 16323972].
Jindal Michael E RDT. Treatment of insomnia associated with clinical depression. Sleep Medicine Reviews. [doi: 10.1016/S1087-0792(03)00025-X]. 2004;8(1):19-30. [pmid: 15062208].
Kenna JE GAM, Swift RM. Pharmacotherapy, pharmacogenomics, and the future of alcohol dependence treatment, part 1. Am J Health Syst Pharm. Nov. 1. 2004;61(21):2272-9. [pmid: 15552634].
Kerssens YAL CJP. ‘Vulnerability to neuroleptic side effects in frontotemporal dementia’: Erratum. European Journal of Neurology. Jun. 2008. 2008;15(6):640.
Lenze BG EJP, Shear MK, Mulsant BH, Bharucha A, Reynolds CF 3rd. Treatment considerations for anxiety in the elderly. CNS Spectr. Dec. 2003;8(12 Suppl 3):6-13. [pmid: 14978458].
McKeith DW IGD, Lowe J, Emre M, O'Brien JT, Feldman H, Cummings J, Duda JE, Lippa C, Perry EK, Aarsland D, Arai H, Ballard CG, Boeve B, Burn DJ, Costa D, Del Ser T, Dubois B, Galasko D, Gauthier S, Goetz CG, Gomez-Tortosa E, Halliday G, Hansen LA, Hardy J, Iwatsubo T, Kalaria RN, Kaufer D, Kenny RA, Korczyn A, Kosaka K, Lee VM, Lees A, Litvan I, Londos E, Lopez OL, Minoshima S, Mizuno Y, Molina JA, Mukaetova-Ladinska EB, Pasquier F, Perry RH, Schulz JB, Trojanowski JQ, Yamada M. Diagnosis and management of dementia with Lewy bodies: third report of the DLB Consortium. Neurology. Dec. 27. 2005;65(12):1863-72. [pmid: 16237129].
Mitchell CB JEP, Myers T, Wonderlich S. Combining pharmacotherapy and psychotherapy in the treatment of patients with eating disorders. Psychiatr Clin North Am. Jun. 2001;24(2):315-23. [pmid: 11416931].
MTACooperativeGroup. A 14-Month Randomized Clinical Trial of Treatment Strategies for Attention-Deficit/Hyperactivity Disorder. Arch Gen Psychiatry. December. 1. 1999. 1999;56(12):1073-86. [pmid: 10591283].
Pascual JC, Martin-Blanco A, Soler J, Ferrer A, Tiana T, Alvarez E, et al. A naturalistic study of changes in pharmacological prescription for borderline personality disorder in clinical practice: from APA to NICE guidelines. Int Clin Psychopharmacol. Nov. 2010;25(6):349-55. [pmid: 20838221].
Roberts Gary DCSV. Atypical neuroleptics increase self-administration of cocaine: An evaluation of a behavioural screen for antipsychotic activity. Psychopharmacology. [doi: 10.1007/BF00426397]. 1983;82(1):135-9. [pmid: 6141584].
Trivedi Maurizio MHF, Wisniewski Stephen R, Thase Michael E, Quitkin Frederick, Warden Diane, Ritz Louise, Nierenberg Andrew A, Lebowitz Barry D, Biggs Melanie M, Luther James F, Shores-Wilson Kathy, Rush A John, the, Star D. Study Team. Medication Augmentation after the Failure of SSRIs for Depression. N Engl J Med. March. 23. 2006;354(12):1243-52. [pmid: 16554526].
Uthman Jibril OAA. Comparative efficacy and acceptability of pharmacotherapeutic agents for anxiety disorders in children and adolescents: a mixed treatment comparison meta-analysis. Current Medical Research and Opinion. 2010;26(1):53-9. [pmid: 19905879].
Valenstein JF MM, Austin KL, Greden JF, Young EA, Blow FC. What happened to lithium? Antidepressant augmentation in clinical settings. Am J Psychiatry. Jul. 2006;163(7):1219-25. [pmid: 16816227].
Vandereycken W. Neuroleptics in the short-term treatment of anorexia nervosa. A double- blind placebo-controlled study with sulpiride. The British Journal of Psychiatry. March. 1. 1984. 1984;144(3):288-92. [pmid: 6367876].
Voyer René PV, Mengue Pamphile, Nkogho Laurin, Danielle Rochette, Louis Martin, Lori Schindel, Baillargeon Lucie. Determinants of Neuroleptic Drug Use in Long-Term Facilities for Elderly Persons. Journal of Applied Gerontology. Sep. 2005. 2005;24(3):179-95.
Wurthmann Eckhard CK, Lehmann Erlo. Side effects of low dose neuroleptics and their impact on clinical outcome in generalized anxiety disorder. Progress in Neuro-Psychopharmacology and Biological Psychiatry. [doi: 10.1016/S0278-5846(97)00035-3]. 1997;21(4):601-9. [pmid: 9194143].
Zerbe KJ. Eating disorders over the life Cycle: Diagnosis and treatment. Primary Psychiatry. Jun. 2003. 2003;10(6):28-9.
Ziedonis David DMS, Rosenthal Richard N, Batki Steven L, Green AlanI, Henry Renata J, Montoya Ivan, Parks Joseph, Weiss Roger D. Improving the Care of Individuals with Schizophrenia and Substance Use Disorders: Consensus Recommendations. Journal of Psychiatric Practice. 2005;11(5):315-39. [pmid: 16184072].

## Rejected Due to Condition

First drug to treat irritability associated with autism. FDA Consum. Jan-Feb. 2007;41(1):4.
Risperidone treatment of autistic disorder: longer-term benefits and blinded discontinuation after 6 months. Am J Psychiatry. Jul. 2005;162(7):1361-9. [pmid: 15994720].
Accardo P. Risperidone in children with autism and serious behavioral problems. J Pediatr. Jan. 2003;142(1):86-7. [pmid: 12569906].
Adetunji M BM, Osinowo T, Williams A. Risperidone for the core symptom domains of autism. Am J Psychiatry. Mar. 2006;163(3):551. author reply -2. [pmid: 16513891].
Adli Katja MW, Baethge Christopher, Pfennig Andrea, Stamm Thomas, Bauer Michael. Olanzapine in the treatment of depression with psychotic features: A prospective open-label study. International Journal of Psychiatry in Clinical Practice. Sep. 2008. 2008;12(3):202-9.
Ahuja N NN, Mackin P, Lloyd AJ. Olanzapine-induced hyperglycaemic coma and neuroleptic malignant syndrome: case report and review of literature. J Psychopharmacol. January. 1. 2010. 2010;24(1):125-30. [pmid: 18801826].
Akhondzadeh H ST, Mohammadi MR, Mohammadi M, Nouroozinejad GH, Shabstari OL, Ghelichnia HA. A double-blind placebo controlled trial of piracetam added to risperidone in patients with autistic disorder. Child Psychiatry Hum Dev. Sep. 2008;39(3):237-45. [pmid: 17929164].
Alessi NE. Ziprasidone in autism. J Am Acad Child Adolesc Psychiatry. Jun. 2003;42(6):622-3. [pmid: 12921465].
Alexander W. American psychiatric association. P T. Jun. 2008;33(6):364-7. [pmid: 19561800].
Alptekin K, Hafez J, Brook S, Akkaya C, Tzebelikos E, Ucok A, et al. Efficacy and tolerability of switching to ziprasidone from olanzapine, risperidone or haloperidol: an international, multicenter study. Int Clin Psychopharmacol. Sep. 2009;24(5):229-38. [pmid: 19531959].
Aman J MB, Smedt GD, Wapenaar R, Binder C. Pharmacotherapy of disruptive behavior and item changes on a standardized rating scale: pooled analysis of risperidone effects in children with subaverage IQ. J Child Adolesc Psychopharmacol. Apr. 2005;15(2):220-32. [pmid: 15910206].
Aman MG. Management of hyperactivity and other acting-out problems in patients with autism spectrum disorder. Semin Pediatr Neurol. Sep. 2004;11(3):225-8. [pmid: 15575418].
Aman LE MGA, McDougle CJ, Vitiello B, Scahill L, Davies M, McCracken JT, Tierney E, Nash PL, Posey DJ, Chuang S, Martin A, Shah B, Gonzalez NM, Swiezy NB, Ritz L, Koenig K, McGough J, Ghuman JK, Lindsay RL. Acute and long-term safety and tolerability of risperidone in children with autism. J Child Adolesc Psychopharmacol. Dec. 2005;15(6):869-84. [pmid: 16379507].
Aman JA MGH, McDougle CJ, Scahill L, Tierney E, McCracken JT, Arnold LE, Vitiello B, Ritz L, Gavaletz A, Cronin P, Swiezy N, Wheeler C, Koenig K, Ghuman JK, Posey DJ. Cognitive effects of risperidone in children with autism and irritable behavior. J Child Adolesc Psychopharmacol. Jun. 2008;18(3):227-36. [pmid: 18582177].
Andersohn Niklas, Weinmann Stefan, Willich Stefan N, Garbe Edeltraut. Priapism Associated With Antipsychotics: Role of [alpha]1 Adrenoceptor Affinity. [Report]. J Clin Psychopharmacol. 2010;30(1):68-71. [pmid: 20075651].
Anderson L GMS, McCracken JT, McDougle CJ, Aman MG, Tierney E, Arnold LE, Martin A, Katsovich L, Posey DJ, Shah B, Vitiello B. Effects of short- and long-term risperidone treatment on prolactin levels in children with autism. Biol Psychiatry. Feb. 15. 2007;61(4):545-50. [pmid: 16730335].
Aparasu RR, Bhatara V, Gupta S. U.S. national trends in the use of antipsychotics during office visits, 1998-2002. Ann Clin Psychiatry. Jul-Sep. 2005;17(3):147-52. [pmid: 16433056].
Aparasu Vinod RRB. Datapoints: Antipsychotic Prescribing Trends Among Youths, 1997-2002. Psychiatr Serv. August. 1. 2005;56(8):904. [pmid: 16088004].
Ashcroft Martin DMF, Lockett Joanne, Chapman Stephen R. Variations in prescribing atypical antipsychotic drugs in primary care: cross-sectional study. Pharmacoepidemiology and Drug Safety. 2002;11(4):285-9. [pmid: 12138596].
Barnett T MA, Alexander B, Perry P. A regional comparison of developing diabetes among VA patients exposed to typical and atypical antipsychotics relative to corticosteroids and proton pump inhibitors. Ann Clin Psychiatry. 2006. Jan-Mar. 18(1):1-7. [pmid: 16517447].
Barnett PJ MJP, Alexander B, Kaboli PJ. Risk of mortality associated with antipsychotic and other neuropsychiatric drugs in pneumonia patients. J Clin Psychopharmacol. Apr. 2006;26(2):182-7. [pmid: 16633149].
Berk S MB, Trandafir AI. A comparison of olanzapine with haloperidol in cannabis-induced psychotic disorder: a double-blind randomized controlled trial. Int Clin Psychopharmacol. May. 1999;14(3):177-80. [pmid: 10435771].
Berwaerts A JC, Herben V, van de Vliet I, Chang I, van Hoek P, Eerdekens M. The effects of paroxetine on the pharmacokinetics of paliperidone extended-release tablets. Pharmacopsychiatry. Jul. 2009;42(4):158-63. [pmid: 19585395].
Boaz TL, Constantine RJ, Robst J, Becker MA, Howe AM. Risperidone long-acting therapy prescribing patterns and their impact on early discontinuation of treatment in a large medicaid population. J Clin Psychiatry. 2010. Oct. 19.
Bogart B GTC. Safety and Efficacy of Quetiapine in Bipolar Depression (November) (CE). Ann Pharmacother. 2009. Oct. 6.
Bondolfi CB GE, Bertschy G, Zullino D, Vermeulen A, Baumann P. The effect of fluoxetine on the pharmacokinetics and safety of risperidone in psychotic patients. Pharmacopsychiatry. Mar. 2002;35(2):50-6. [pmid: 11985287].
Boon-Yasidhi J VT, Suwanwattana C, Soising L. Risperidone in the treatment of autistic Thai children under 4 years of age. J Med Assoc Thai. Aug. 2. 2002;85:S784-9. [pmid: 12403261].
Bostwick SK JRG, Ellingrod VL. Antipsychotic-induced hyperprolactinemia. Pharmacotherapy. Jan. 2009;29(1):64-73. [pmid: 19113797].
Briskman R ID, Barak Y. Treating delirium in a general hospital: a descriptive study of prescribing patterns and outcomes. Int Psychogeriatr. Sep. 2009;29:1-4.
Brown DL ED, McElroy SL, Keck PE, Adams DH, Degenhardt E, Tohen M, Houston JP. Olanzapine/fluoxetine combination vs. lamotrigine in the 6-month treatment of bipolar I depression. Int J Neuropsychopharmacol. Jul. 2009;12(6):773-82. [pmid: 19079815].
Bushe Michael CS, Peveler Robert C. A review of the association between antipsychotic use and hyperprolactinaemia. Journal of Psychopharmacology. Mar. 2008. 2008;22(2):46-55. [pmid: 18477620].
Caicedo SH CW. Risperidone improves behavior in children with autism. J Fam Pract. Nov. 2002;51(11):915. [pmid: 12485538].
Campbell Malaz NB, Ayub Amir, Fox George, Munger Stephanie, Ott Carol, Guzman Oscar, Farber Mark, Ademuyiwa Adetayo, Singh Ranjeet. Pharmacological Management of Delirium in Hospitalized Adults – A Systematic Evidence Review. Journal of General Internal Medicine. [doi: 10.1007/s11606-009-0996-7]. 2009;24(7):848-53. [pmid: 19424763].
Canitano R. Self injurious behavior in autism: clinical aspects and treatment with risperidone. J Neural Transm. Mar. 2006;113(3):425-31. [pmid: 16075185].
Canitano V RS. Risperidone in the treatment of behavioral disorders associated with autism in children and adolescents. Neuropsychiatr Dis Treat. Aug. 2008;4(4):723-30. [pmid: 19043516].
Capone Parag GTG, Grados Marco, Smith Brandon, Kammann Heather. Risperidone use in children with Down syndrome, severe intellectual disability, and comorbid autistic spectrum disorders: A naturalistic study. Journal of Developmental and Behavioral Pediatrics. Apr. 2008. 2008;29(2):106-16. [pmid: 18349709].
Cascade A EK, Findling R. Use of antipsychotics in children. Psychiatry (Edgmont). Jun. 2009;6(6):21-3. [pmid: 19724757].
Castberg E IS, Spigset O. Quetiapine and drug interactions: evidence from a routine therapeutic drug monitoring service. J Clin Psychiatry. Oct. 2007;68(10):1540-5. [pmid: 17960969].
Centorrino F, Ventriglio A, Vincenti A, Talamo A, Baldessarini RJ. Changes in medication practices for hospitalized psychiatric patients: 2009 versus 2004. Hum Psychopharmacol. Mar. 2010;25(2):179-86. [pmid: 20196186].
Centorrino Stephanie L FC, Talamo Alessandra, Fogarty Kate V, Guzzetta Francesca, Saadeh Mark G, Salvatore Paola, Baldessarini Ross J. Hospital use of antipsychotic drugs: Polytherapy. Comprehensive Psychiatry. Jan-Feb. 2008. 2008;49(1):65-9. [pmid: 18063043].
Chavez M BC-B, Sopko MA Jr, Rey JA. Atypical antipsychotics in children with pervasive developmental disorders. Paediatr Drugs. 2007;9(4):249-66. [pmid: 17705564].
Chavez M BC-B, Rey JA. Role of risperidone in children with autism spectrum disorder. Ann Pharmacother. May. 2006;40(5):909-16. [pmid: 16684811].
Chen CC CHC, Huang MC. Dose-related exacerbation of obsessive-compulsive symptoms with quetiapine treatment. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1. 2008;32(1):304-5. [pmid: 17826882].
Chue R PE. Long-acting formulations of atypical antipsychotics: time to reconsider when to introduce depot antipsychotics. CNS Drugs. 2007;21(6):441-8. [pmid: 17521224].
Çitil Engin DYS, Karlidağ Rifat, Unal Süheyla. Ziprasidone-induced hyperprolactinemia: A case report. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Apr. 2008. 2008;32(3):905-6. [pmid: 18276052].
Citrome L. Paliperidone: quo vadis?. Int J Clin Pract. Apr. 2007;61(4):653-62. [pmid: 17343660].
Citrome A LJ, Levine J, Allingham B, Robinson J. Relationship between antipsychotic medication treatment and new cases of diabetes among psychiatric inpatients. Psychiatr Serv. Sep. 2004;55(9):1006-13. [pmid: 15345760].
Cobaugh AR DJE, Booze LL, Scharman EJ, Christianson G, Manoguerra AS, Caravati EM, Chyka PA, Woolf AD, Nelson LS, Troutman WG. Atypical antipsychotic medication poisoning: an evidence-based consensus guideline for out-of-hospital management. Clin Toxicol (Phila). Dec. 2007;45(8):918-42. [pmid: 18163235].
Cobo Gomez G JVF, Coronas R, Benito N, Barbero JD, Domenech C, Garcia-Pares G. Combination of aripiprazole and other psychopharmacological treatments in resistant and multi-resistant patients. Curr Drug Saf. Sep. 2008;3(3):210-5. [pmid: 18691004].
Cohen BJ SAF, Khan SR, Khan A. The effect of a switch to ziprasidone in an adult population with autistic disorder: chart review of naturalistic, open-label treatment. J Clin Psychiatry. Jan. 2004;65(1):110-3. [pmid: 14744179].
Cohrs A SM, Neumann AC, Jordan W, Ruther E, Rodenbeck A. Improved sleep continuity and increased slow wave sleep and REM latency during ziprasidone treatment: a randomized, controlled, crossover trial of 12 healthy male subjects. J Clin Psychiatry. Aug. 2005;66(8):989-96. [pmid: 16086613].
Cohrs A SR, Guan Z, Pohlmann K, Jordan W, Meier A, Ruther E. Sleep-promoting properties of quetiapine in healthy subjects. Psychopharmacology (Berl). Jul. 2004;174(3):421-9. [pmid: 15029469].
Conley DL RRK. Drug-drug interactions associated with second-generation antipsychotics: considerations for clinicians and patients. Psychopharmacol Bull. 2007;40(1):77-97. [pmid: 17285099].
Conley DL RRKK, Gale EA. Olanzapine response in treatment-refractory schizophrenic patients with a history of substance abuse. Schizophr Res. Sep. 7. 1998;33(1-2):95-101. [pmid: 9783349].
Corbett L RG, Shipley JE, Shukla U, Strupczewski JT, Szczepanik AM, Szewczak MR, Turk DJ, Vargas HM, Kongsamut S, Iloperidone Project, Team. Iloperidone: Preclinical profile and early clinical evaluation. CNS Drug Reviews. Sum. 1997;3(2):120-47.
Correll CU. Antipsychotic use in children and adolescents: Minimizing adverse effects to maximize outcomes. Journal of the American Academy of Child & Adolescent Psychiatry. Jan. 2008. 2008;47(1):9-20. [pmid: 18174821].
Correll JM CUK. One-year incidence rates of tardive dyskinesia in children and adolescents treated with second-generation antipsychotics: a systematic review. J Child Adolesc Psychopharmacol. Oct. 2007;17(5):647-56. [pmid: 17979584].
Correll John M CUK, Malhotra Anil K. Risks From Antipsychotic Medications in Children and Adolescents--Reply. JAMA. February. 24. 2010. 2010;303(8):730.
Corson JE AHB, Posey DJ, Stigler KA, McDougle CJ. A retrospective analysis of quetiapine in the treatment of pervasive developmental disorders. J Clin Psychiatry. Nov. 2004;65(11):1531-6. [pmid: 15554768].
Crockford G DNF, Barker P. Risperidone, weight gain, and bulimia nervosa. Can J Psychiatry. Apr. 1997;42(3):326-7. [pmid: 9114956].
Cubells JF. Beyond irritability and aggressive behavior: does risperidone improve adaptive behavior in autistic spectrum disorders?. Curr Psychiatry Rep. Apr. 2007;9(2):132-3. [pmid: 17389123].
Curtis Leah E LHM, Ostbye Truls, Hutchison Steve, Dans Peter E, Wright Alan, Krishnan Ranga R, Schulman Kevin A. Prevalence of Atypical Antipsychotic Drug Use Among Commercially Insured Youths in the United States. Arch Pediatr Adolesc Med. April. 1. 2005. 2005;159(4):362-6. [pmid: 15809391].
Dan Rahul AB, Grover Sandeep. Neuroleptic malignant syndrome with use of quetiapine in mental retardation. Psychiatry and Clinical Neurosciences. Apr. 2009. 2009;63(2):255-6. [pmid: 19335404].
de MiIlas Christian WH. Treatment of alcohol hallucinosis with risperidone. The American Journal on Addictions. May-Jun. 2007. 2007;16(3):249-50. [pmid: 17612834].
Dean BM AJM, Marshall RT. PRN sedation-patterns of prescribing and administration in a child and adolescent mental health inpatient service. Eur Child Adolesc Psychiatry. Aug. 2006;15(5):277-81. [pmid: 16583125].
Deeks Gillian M EDK. Spotlight on olanzapine/fluoxetine in acute bipolar depression. CNS Drugs. 2008. 2008;22(9):793-5. [pmid: 18698877].
Del Paggio D. Psychotropic medication abuse in correctional facilities. The Bay Area Psychopharmacology Newsletter. 2005;8(1).
DelBello K MPC, Welge JA, Adler CM, Rana M, Howe M, Bryan H, Vogel D, Sampang S, Delgado SV, Sorter M, Strakowski SM. A double-blind, placebo-controlled pilot study of quetiapine for depressed adolescents with bipolar disorder. Bipolar Disord. Aug. 2009;11(5):483-93. [pmid: 19624387].
Devlin JW, Roberts RJ, Fong JJ, Skrobik Y, Riker RR, Hill NS, et al. Efficacy and safety of quetiapine in critically ill patients with delirium: a prospective, multicenter, randomized, double-blind, placebo-controlled pilot study. Crit Care Med. Feb. 2010;38(2):419-27. [pmid: 19915454].
Dew D REH. Acute dystonic reaction with moderate-dose ziprasidone. J Clin Psychopharmacol. Oct. 2004;24(5):563-4. [pmid: 15349021].
Dinca M OP, Spencer NJ. Systematic review of randomized controlled trials of atypical antipsychotics and selective serotonin reuptake inhibitors for behavioural problems associated with pervasive developmental disorders. J Psychopharmacol. Sep. 2005;19(5):521-32. [pmid: 16166190].
Dlugosz HA HN. Paliperidone: a new extended-release oral atypical antipsychotic. Expert Opin Pharmacother. Oct. 2007;8(14):2307-13. [pmid: 17927485].
Dopheide JA. Paliperidone: An improvement over risperidone?. Am J Health Syst Pharm. Mar. 1. 2008;65(5):401. [pmid: 18281730].
Duggal HS. Letter to the editor: Ziprasidone for maladaptive behavior and attention-deficit/hyperactivity disorder symptoms in autistic disorder. Journal of Child and Adolescent Psychopharmacology. May. 2007. 2007;17(2):261-3. [pmid: 17489724].
Duggal HS. Possible neuroleptic malignant syndrome associated with paliperidone. J Neuropsychiatry Clin Neurosci. Fall. 2007;19(4):477-8. [pmid: 18070861].
DuMouchel David WF, Yang Xionghu, Mahmoud Ramy A, Grogg Amy L, Engelhart Luella, Ramaswamy Krishnan. Antipsychotics, Glycemic Disorders, and Life-Threatening Diabetic Events: A Bayesian Data-Mining Analysis of the FDA Adverse Event Reporting System (1968-2004). Annals of Clinical Psychiatry: The official Journal of the American Academy of Clinical Psychiatrists. 2008;20(1):21-31.
Einarson Rada AB. Use and safety of antipsychotic drugs during pregnancy. Journal of Psychiatric Practice. May. 2009. 2009;15(3):183-92. [pmid: 19461391].
Endicott B JP, Gustafsson U, Schioler H, Hassan M. Quetiapine monotherapy in the treatment of depressive episodes of bipolar I and II disorder: Improvements in quality of life and quality of sleep. J Affect Disord. Dec. 2008;111(2-3):306-19. [pmid: 18774180].
Endicott K JR, Minkwitz M, Macfadden W. A randomized, double-blind, placebo-controlled study of quetiapine in the treatment of bipolar I and II depression: improvements in quality of life. Int Clin Psychopharmacol. Jan. 2007;22(1):29-37. [pmid: 17159457].
Englisch C SE, Inta D, Weinbrenner A, Peus V, Gutschalk A, Schirmbeck F, Zink M. Clozapine-induced obsessive-compulsive syndromes improve in combination with aripiprazole. Clin Neuropharmacol. Jul-Aug. 2009;32(4):227-9. [pmid: 19644230].
Feldman LK PDH, Deberdt W, Kennedy JS, Hutchins DS, Hay DP, Hardy TA, Hoffmann VP, Hornbuckle K, Breier A. Retrospective cohort study of diabetes mellitus and antipsychotic treatment in a geriatric population in the United States. J Am Med Dir Assoc. Jan-Feb. 2004;5(1):38-46. [pmid: 14706127].
Feroz-Nainar M CR. Risperidone and late onset tics. Autism. May. 2006;10(3):302-7. [pmid: 16682400].
Feroz-Nainar P CS, Roy M. Risperidone induced oedema in a child with learning disability and autism. Autism. May. 2006;10(3):308-10. [pmid: 16682401].
Fido S AA-S. Olanzapine in the treatment of behavioral problems associated with autism: an open-label trial in Kuwait. Med Princ Pract. 2008;17(5):415-8. [pmid: 18685284].
Findling RL. Atypical antipsychotic treatment of disruptive behavior disorders in children and adolescents. J Clin Psychiatry. 4. 2008;69:9-14. [pmid: 18533763].
Findling NK RLM, Gracious BL, O'Riordan MA, Reed MD, Demeter C, Blumer JL. Quetiapine in nine youths with autistic disorder. J Child Adolesc Psychopharmacol. Summer. 2004;14(2):287-94. [pmid: 15319025].
Findling Ralph E RLMDK, M. D., Sallee Floyd R M. D. PhD, Carson William H M. D., Nyilas Margaretta M. D., Mallikaarjun Suresh PhD F. C. P, Shoaf Susan E PhD, Forbes Robert A PhD, Boulton David W PhD, Pikalov Andrei M. D. PhD. Tolerability and Pharmacokinetics of Aripiprazole in Children and Adolescents With Psychiatric Disorders: An Open-Label, Dose-Escalation Study. Journal of Clinical Psychopharmacology. 2008;28(4):441-6. [pmid: 18626272].
Findling MD RLR, O'Riordan MA, Demeter CA, Stansbrey RJ, McNamara NK. A 26-week open-label study of quetiapine in children with conduct disorder. J Child Adolesc Psychopharmacol. Feb. 2007;17(1):1-9. [pmid: 17343549].
Flanagan EP SRE, Sandel E. Managing agitation associated with traumatic brain injury: behavioral versus pharmacologic interventions?. PM R. Jan. 2009;1(1):76-80. [pmid: 19627876].
Fombonne E. Risperidone improves restricted, repetitive, and stereotyped behaviour in autistic children and adolescents. Evid Based Ment Health. Feb. 2006;9(1):6. [pmid: 16436546].
Fountoulakis Heinz KNG, Panagiotidis Panagiotis, Kaprinis George. Treatment of bipolar depression: An update. Journal of Affective Disorders. Jul. 2008. 2008;109(1):21-34. [pmid: 18037498].
Gabriel A. Changes in plasma cholesterol in mood disorder patients: does treatment make a difference?. J Affect Disord. Apr. 2007;99(1-3):273-8. [pmid: 16979243].
Gagliano E AG, Pustorino G, Impallomeni C, D'Arrigo C, Calamoneri F, Spina E. Risperidone treatment of children with autistic disorder: effectiveness, tolerability, and pharmacokinetic implications. J Child Adolesc Psychopharmacol. Spring. 2004;14(1):39-47. [pmid: 15142390].
Gencer FN OE, Miral S, Baykara B, Baykara A, Dirik E. Comparison of long-term efficacy and safety of risperidone and haloperidol in children and adolescents with autistic disorder. An open label maintenance study. Eur Child Adolesc Psychiatry. Jun. 2008;17(4):217-25. [pmid: 18026891].
Ghanizadeh A. Does risperidone improve hyperacusia in children with autism?. Psychopharmacol Bull. 2009;42(1):108-10. [pmid: 19204655].
Gimenez S SC, Romero S, Grasa E, Morte A, Barbanoj MJ. Effects of olanzapine, risperidone and haloperidol on sleep after a single oral morning dose in healthy volunteers. Psychopharmacology (Berl). Mar. 2007;190(4):507-16. [pmid: 17205319].
Gjerden L PS, Bramness JG. Prescription persistence and safety of antipsychotic medication: a national registry-based 3-year follow-up. Eur J Clin Pharmacol. 2010. Jun. 3.
Gobert W MDh. Prevalence of psychotropic drug use in nursing homes for the aged in Quebec and in the French-speaking area of Switzerland. International Journal of Geriatric Psychiatry. 2005;20(8):712-21. [pmid: 16035123].
Goodnick PJ. Higher than Physician's Desk Reference (US) doses on atypical antipsychotics. Expert Opinion on Drug Safety. 2005;4(4):653-68. [pmid: 16011445].
Gorwood P. Meeting everyday challenges: antipsychotic therapy in the real world. Eur Neuropsychopharmacol. Sep. 3. 2006;16:S156-62. [pmid: 16872807].
Goto Reiji MY, Kakihara Shingo, Koji Shinkai, Yamada Yasuhisa, Kaji Kyoko, Ueda Nobuhisa, Nakamura Jun. Risperidone in the treatment of psychotic depression. Progress in Neuro-Psychopharmacology and Biological Psychiatry. 2006;30(4):701-7. [pmid: 16580110].
Haberfellner EM, Rittmannsberger H. Weight gain during long-term treatment with olanzapine: a case series. International Clinical Psychopharmacology. 2004;19(4):251-3. [pmid: 15201573].
HALL PINKY DAA, GRIFFITH ALIDA, SEGRO VICKI, SEEBERGER LAUREN C. MOVEMENT DISORDERS ASSOCIATED WITH ARIPIPRAZOLE USE: A CASE SERIES. International Journal of Neuroscience. 2009;119(12):2274-9. [pmid: 19916856].
Hamann Andras J, Auby Philippe, Pugner Klaus, Kissling Werner. b, c, d, a. Antipsychotic prescribing patterns in Germany: a retrospective analysis using a large outpatient prescription database. International Clinical Psychopharmacology. 2003;18(4):237-42. [pmid: 12817158].
Haney R MS. Controversies in translational research: drug self-administration. Psychopharmacology (Berl). Aug. 2008;199(3):403-19. [pmid: 18283437].
Hasnain WV MV, Baron MS, Beatty-Brooks M, Fernandez A, Pandurangi AK. Pharmacological management of psychosis in elderly patients with parkinsonism. Am J Med. Jul. 2009;122(7):614-22. [pmid: 19559160].
Hazell P. Drug therapy for attention-deficit/hyperactivity disorder-like symptoms in autistic disorder. J Paediatr Child Health. Jan-Feb. 2007;43(1-2):19-24. [pmid: 17207050].
Henderson PM DCC, Borba CP, Daley TB, Nguyen DD, Cagliero E, Evins AE, Zhang H, Hayden DL, Freudenreich O, Cather C, Schoenfeld DA, Goff DC. Glucose metabolism in patients with schizophrenia treated with olanzapine or quetiapine: a frequently sampled intravenous glucose tolerance test and minimal model analysis. J Clin Psychiatry. May. 2006;67(5):789-97. [pmid: 16841629].
Hien L TT, Cumming Robert G, Cameron Ian D, Chen Jian S, Lord Stephen R, March Lyn M, Schwarz Jennifer, Le Couteur David G, Sambrook Philip N. Atypical Antipsychotic Medications and Risk of Falls in Residents of Aged Care Facilities. Journal of the American Geriatrics Society. 2005;53(8):1290-5. [pmid: 16078953].
Hirschfeld RMA. ‘Does olanzapine have any antidepressant effect?’: Dr Hirschfeld replies. The American Journal of Psychiatry. Oct. 2006. 2006;163(10):1839.
Hollander S EW, Swanson EN, Chaplin W, Schapiro ML, Zagursky K, Novotny S. A double-blind placebo-controlled pilot study of olanzapine in childhood/adolescent pervasive developmental disorder. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):541-8. [pmid: 17069543].
Hollingworth SA, Siskind DJ, Nissen LM, Robinson M, Hall WD. Patterns of antipsychotic medication use in Australia 2002-2007. Aust N Z J Psychiatry. Apr. 2010;44(4):372-7. [pmid: 20307170].
Hollis David JMBBSG, Ph D, Forrester Loelle, Brodaty Henry D. Sc, Touyz Stephen Ph D, Cumming Robert Ph D. Antipsychotic Medication Dispensing and Risk of Death in Veterans and War Widows 65 Years and Older. American Journal of Geriatric Psychiatry. 2007;15(11):932-41. [pmid: 17974865].
Howland RH. Paliperidone extended-release tablets: a new atypical antipsychotic. Journal of Psychosocial Nursing & Mental Health Services. 2007;45(5):15-8.
Hutchison MC KER, Niaura R, Swift RM, Pickworth WB, Sobik L. Olanzapine attenuates cue-elicited craving for tobacco. Psychopharmacology (Berl). Oct. 2004;175(4):407-13. [pmid: 15042276].
Jarema M. Atypical antipsychotics in the treatment of mood disorders. Current Opinion in Psychiatry. Jan. 2007. 2007;20(1):23-9. [pmid: 17143078].
Jesner M OSA-A, Coren E. Risperidone for autism spectrum disorder. Cochrane Database Syst Rev. 2007;(1):CD005040. [pmid: 17253538].
Jeste H DVJ, Golshan S, Mudaliar S, Glorioso D, Fellows I, Kraemer H, Arndt S. Discontinuation of quetiapine from an NIMH-funded trial due to serious adverse events. Am J Psychiatry. Aug. 2009;166(8):937-8. [pmid: 19651757].
Jha H AF. Risperidone treatment of amphetamine psychosis. Br J Psychiatry. Apr. 1999;174:366. [pmid: 10533557].
Johnsen E, Kroken RA, Wentzel-Larsen T, Jorgensen HA. Effectiveness of second-generation antipsychotics: a naturalistic, randomized comparison of olanzapine, quetiapine, risperidone, and ziprasidone. BMC Psychiatry. 2010;10:26. [pmid: 20334680].
Johnsen EJHA, Svingen GF. Practice regarding antipsychotic therapy: A cross-sectional survey in two Norwegian hospitals. Nordic Journal of Psychiatry. 2004;58(4):313-7. [pmid: 15370781].
Kang HJ SGL, Kim L. Restless legs syndrome and periodic limb movements during sleep probably associated with olanzapine. J Psychopharmacol. Jul. 2009;23(5):597-601. [pmid: 18562412].
Kaptsan Tzvi AD, Lerner Vladimir. Ziprasidone-associated depressive state in schizophrenic patients. Clinical Neuropharmacology. Nov-Dec. 2007. 2007;30(6):357-61. [pmid: 18090461].
Keltner DE NLV. Biological perspectives incarcerated care and quetiapine abuse. Perspect Psychiatr Care. Jul. 2008;44(3):202-6. [pmid: 18577126].
Kemner SH CW-S, de Jonge M, Tuynman-Qua H, van Engeland H. Open-label study of olanzapine in children with pervasive developmental disorder. J Clin Psychopharmacol. Oct. 2002;22(5):455-60. [pmid: 12352267].
Kennedy A AT, Kelly WS, Kilzieh N, Wood AE. Abstinence, anticipation, reduction, and treatment (AART): a stepwise approach to the management of atypical antipsychotic side effects. Essent Psychopharmacol. 2006;7(1):1-14. [pmid: 16989288].
Kennedy J, Tien YY, Cohen LJ, Sclar DA, Liu D, Blodgett EG, et al. The association between class of antipsychotic and rates of hospitalization: results of a retrospective analysis of data from the 2005 Medicare current beneficiary survey. Clin Ther. Dec. 2009;31(12):2931-9. [pmid: 20110033].
King JQ BHB. An update on pharmacologic treatments for autism spectrum disorders. Child Adolesc Psychiatr Clin N Am. Jan. 2006;15(1):161-75. [pmid: 16321729].
Kinon Ilya BJL, Edwards S Beth, Adams David H, Ascher-Svanum Haya, Siris Samuel G. A 24-week randomized study of olanzapine versus ziprasidone in the treatment of schizophrenia or schizoaffective disorder in patients with prominent depressive symptoms. Journal of Clinical Psychopharmacology. Apr. 2006. 2006;26(2):157-62. [pmid: 16633144].
Kleijer RJ BvM, Egberts ACG, Jansen PAF, Knol W, Heerdink ER. Risk of cerebrovascular events in elderly users of antipsychotics. J Psychopharmacol. November. 1. 2009;23(8):909-14. [pmid: 18635700].
Knapp J ML, Jarbrink K. Impact of psychotic relapse definitions in assessing drug efficacy and costs: comparison of quetiapine XR, olanzapine and paliperidone ER. Curr Med Res Opin. Jul. 2009;25(7):1593-603. [pmid: 19469696].
Knol Rob J WvM, Jansen Paul AF, Souverein Patrick C, Schobben Alfred FAM, Egberts Antoine CG. Antipsychotic Drug Use and Risk of Pneumonia in Elderly People. Journal of the American Geriatrics Society. 2008;56(4):661-6. [pmid: 18266664].
Kogut F SJY, Dufresne R. Prescribing of antipsychotic medication in a medicaid population: use of polytherapy and off-label dosages. J Manag Care Pharm. Jan-Feb. 2005;11(1):17-24. [pmid: 15667230].
Kohen A IS. Central sleep apnea in a geriatric patient treated with aripiprazole. Am J Ther. Mar-Apr. 2009;16(2):197-8. [pmid: 19300045].
Konstantinidis W AH, Nirnberger G, Windhager E, Lehofer M, Aschauer H, Kasper S. Quetiapine in combination with citalopram in patients with unipolar psychotic depression. Progress in Neuro-Psychopharmacology and Biological Psychiatry. 2007;31(1):242-7. [pmid: 16962224].
Kornreich Bernard CD, Verbanck Paul, Pelc Isy. Treating Charles Bonnet syndrome: Understanding inconsistency. Journal of Clinical Psychopharmacology 2000 Jun. Jun. 2000. 2000;20(3):396.
Kranzler Jonathan HRC, Pierucci-Lagha Amira, Chan Grace, Douglas Kara, Arias Albert J, Oncken Cheryl. Effects of aripiprazole on subjective and physiological responses to alcohol. Alcoholism: Clinical and Experimental Research. Apr. 2008. 2008;32(4):573-9.
Kreyenbuhl M JAV, McCarthy JF, Ganoczy D, Blow FC. Long-term antipsychotic polypharmacy in the VA health system: patient characteristics and treatment patterns. Psychiatr Serv. Apr. 2007;58(4):489-95. [pmid: 17412850].
Kuehn BM. Studies shed light on risks and trends in pediatric antipsychotic prescribing. JAMA. May. 19. 2010;303(19):1901-3. [pmid: 20483961].
Lautenschlager A MH. Paliperidone-ER: first atypical antipsychotic with oral extended release formulation. Expert Rev Neurother. Feb. 2008;8(2):193-200. [pmid: 18271706].
LeBlanc CE JCB, Armenteros JL, Aman MG, Wang JS, Hew H, Kusumakar V. Risperidone reduces aggression in boys with a disruptive behaviour disorder and below average intelligence quotient: analysis of two placebo-controlled randomized trials. Int Clin Psychopharmacol. Sep. 2005;20(5):275-83. [pmid: 16096518].
Lee YW KUJ, Lee HK, Jun TY. Efficacy and safety of quetiapine for depressive symptoms in patients with schizophrenia. Hum Psychopharmacol. Aug. 2009;24(6):447-52. [pmid: 19606454].
Lee WY KUW, Lee HK, Kweon YS, Lee CT, Pae CU, Bahk WM. Amisulpride versus quetiapine for the treatment of delirium: a randomized, open prospective study. Int Clin Psychopharmacol. Nov. 2005;20(6):311-4. [pmid: 16192839].
Lerner Emi AGS, Kodesh Arad, Rudinski Dmitri, Kretzmer Gavin, Sigal Mircea. Risperidone-associated, benign transient visual disturbances in schizophrenic patients with a past history of LSD abuse. Israel Journal of Psychiatry and Related Sciences. 2002. 2002;39(1):57-60. [pmid: 12013711].
Leslie RA DLR. From conventional to atypical antipsychotics and back: dynamic processes in the diffusion of new medications. Am J Psychiatry. Sep. 2002;159(9):1534-40. [pmid: 12202274].
Libby HD AMO, Valuck RJ. Persisting decline in depression treatment after FDA warnings. Arch Gen Psychiatry. Jun. 2009;66(6):633-9. [pmid: 19487628].
Liebowitz E MRS, Mech A, Dunner D, Johnson AE, Akhtar J, Pratap R. Ziprasidone monotherapy in bipolar II depression: an open trial. J Affect Disord. Nov. 2009;118(1-3):205-8. [pmid: 19264363].
Lile WW JAS, Vansickel AR, Glaser PE, Hays LR, Rush CR. Aripiprazole attenuates the discriminative-stimulus and subject-rated effects of D-amphetamine in humans. Neuropsychopharmacology. Nov. 2005;30(11):2103-14. [pmid: 15988473].
Lim DY MP, Kwon JS, Joo YH, Hong KS. Prevalence and clinical characteristics of obsessive-compulsive symptoms associated with atypical antipsychotics. J Clin Psychopharmacol. Dec. 2007;27(6):712-3. [pmid: 18004145].
Lindberg M NV, Tani P, Appelberg B, Virkkala J, Rimon R, Porkka-Heiskanen T. Effect of a single-dose of olanzapine on sleep in healthy females and males. Int Clin Psychopharmacol. Jul. 2002;17(4):177-84. [pmid: 12131601].
Lindsay L RLEA, Aman MG, Vitiello B, Posey DJ, McDougle CJ, Scahill L, Pachler M, McCracken JT, Tierney E, Bozzolo D. Dietary status and impact of risperidone on nutritional balance in children with autism: a pilot study. J Intellect Dev Disabil. Dec. 2006;31(4):204-9. [pmid: 17178532].
Liu HQ YS, Bao YP, Li SX, Beveridge TJ, Di XL, Yang FD, Lu L. Subjective, cognitive/psychomotor, and physiological effects of aripiprazole in Chinese light and heavy smokers. Drug Alcohol Depend. Apr. 1. 2009;101(1-2):42-52. [pmid: 19070440].
Lofthouse MA NF, Splaingard M, Kelleher K, Hayes J, Resko S. Web-survey of pharmacological and non-pharmacological sleep interventions for children with early-onset bipolar spectrum disorders. J Affect Disord. 2009. Sep. 7.
Lu R BB, Parthasarathy S. Sedating medications and undiagnosed obstructive sleep apnea: physician determinants and patient consequences. J Clin Sleep Med. Oct. 15. 2005;1(4):367-71. [pmid: 17564403].
Luby C JM, Stalets MM, Belden A, Heffelfinger A, Williams M, Spitznagel E. Risperidone in preschool children with autistic spectrum disorders: an investigation of safety and efficacy. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):575-87. [pmid: 17069546].
Luthringer L RS, Noel N, Muzet M, Gassmann-Mayer C, Talluri K, Cleton A, Eerdekens M, Battisti WP, Palumbo JM. A double-blind, placebo-controlled, randomized study evaluating the effect of paliperidone extended-release tablets on sleep architecture in patients with schizophrenia. Int Clin Psychopharmacol. Sep. 2007;22(5):299-308. [pmid: 17690599].
Macfadden JR WC, McCoy R, et al. Antianxiety effects analysis of quetiapine in bipolar depression. [abstract]. The 157th Annual Meeting of the American Psychiatric Association. New York, NY, USA. May 1-6. 2004.
Madhusoodanan P SS. Management of psychosis in patients with Alzheimer's disease: focus on aripiprazole. Clin Interv Aging. 2008;3(3):491-501. [pmid: 18982919].
Malhi Danielle GSA, Berk Michael. Medicating mood with maintenance in mind: Bipolar depression pharmacotherapy. Bipolar Disorders. Jun. 2009. 2009;11(2):55-76. [pmid: 19538686].
Byrne Simon, Soh Nerissa, Walter Garry, Hunt Glenn, Cleary Michelle, Malhi Gin. Observations from postal research involving families of young people taking antipsychotic medication. Acta Neuropsychiatrica. 2010;22(2):102.
Malone RP. Discontinuing risperidone results in relapse in children with autism spectrum disorders. Evid Based Ment Health. May. 2006;9(2):56. [pmid: 16638905].
Malone MA RPD, Hyman SB, Cater JR. Ziprasidone in adolescents with autism: an open-label pilot study. J Child Adolesc Psychopharmacol. Dec. 2007;17(6):779-90. [pmid: 18315450].
Malone SS RPG, Delaney MA, Hyman SB. Advances in drug treatments for children and adolescents with autism and other pervasive developmental disorders. CNS Drugs. 2005;19(11):923-34. [pmid: 16268664].
Malone G RPM, Choudhury MS, Gifford C, Delaney MA. Risperidone treatment in children and adolescents with autism: short- and long-term safety and effectiveness. J Am Acad Child Adolesc Psychiatry. Feb. 2002;41(2):140-7. [pmid: 11837403].
Malone A RPW. The role of antipsychotics in the management of behavioural symptoms in children and adolescents with autism. Drugs. 2009;69(5):535-48. [pmid: 19368416].
Mancini Cristina FT, Martignoni Emilia, Moglia Arrigo, Nappi Giuseppe, Cristina Silvano, Pacchetti Claudio. Long-Term Evaluation of the Effect of Quetiapine on Hallucinations, Delusions and Motor Function in Advanced Parkinson Disease. [Article].
Mandalos BL GES. New-onset panic attacks in a patient treated with olanzapine. J Clin Psychopharmacol. Apr. 1999;19(2):191. [pmid: 10211927].
Mangurian C, Fuentes-Afflick E, Newcomer JW. Risks from antipsychotic medications in children and adolescents. JAMA. Feb. 24. 2010;303(8):729. author reply 30. [pmid: 20179279].
Marcus R RNO, Kamen L, Manos G, McQuade RD, Carson WH, Aman MG. A Double-Blind, Randomized, Placebo-Controlled Study of Fixed-Dose Aripiprazole in Children and Adolescents With Autistic Disorder. J Am Acad Child Adolesc Psychiatry. 2009. Sep. 30.
Marder SR, Sorsaburu S, Dunayevich E, Karagianis JL, Dawe IC, Falk DM, et al. Case reports of postmarketing adverse event experiences with olanzapine intramuscular treatment in patients with agitation. J Clin Psychiatry. Apr. 2010;71(4):433-41. [pmid: 20156413].
Marder M SRK, Ford L, Eerdekens E, Lim P, Eerdekens M, Lowy A. Efficacy and safety of paliperidone extended-release tablets: results of a 6-week, randomized, placebo-controlled study. Biol Psychiatry. Dec. 15. 2007;62(12):1363-70. [pmid: 17601495].
Martin L AS, Anderson GM, Aman M, Arnold LE, McCracken J, McDougle CJ, Tierney E, Chuang S, Vitiello B. Weight and leptin changes among risperidone-treated youths with autism: 6-month prospective data. Am J Psychiatry. Jun. 2004;161(6):1125-7. [pmid: 15169706].
Martin SE SDL, Pratt DJ, Brewin JS, Huq ZU, Saleh BT. Clinical experience with the long-acting injectable formulation of the atypical antipsychotic, risperidone. Curr Med Res Opin. 2003;19(4):298-305. [pmid: 12841922].
Masi A GC, Mucci M, Brovedani P. A 3-year naturalistic study of 53 preschool children with pervasive developmental disorders treated with risperidone. J Clin Psychiatry. Sep. 2003;64(9):1039-47. [pmid: 14628979].
Masi A GC, Millepiedi S, Muratori F, Pari C, Salvadori F. Aripiprazole monotherapy in children and young adolescents with pervasive developmental disorders: a retrospective study. CNS Drugs. 2009;23(6):511-21. [pmid: 19480469].
Masi S GM, Perugi G, Pfanner C, Berloffa S, Pari C, Mucci M. Pharmacotherapy in paediatric obsessive-compulsive disorder: a naturalistic, retrospective study. CNS Drugs. 2009;23(3):241-52. [pmid: 19320532].
Matthews C JDS, Dording C, Denninger JW, Park L, van Nieuwenhuizen AO, Sklarsky K, Hilliker S, Homberger C, Rooney K, Fava M. An open study of aripiprazole and escitalopram for psychotic major depressive disorder. J Clin Psychopharmacol. Feb. 2009;29(1):73-6. [pmid: 19142112].
McAllister TW. Risperidone for autistic disorder. Curr Psychiatry Rep. Oct. 2005;7(5):369-70.
McConville L BC, Sweitzer D, Potter L, Chaney R, Foster K, Sorter M, Friedman L, Browne K. Long-term safety, tolerability, and clinical efficacy of quetiapine in adolescents: an open-label extension trial. J Child Adolesc Psychopharmacol. Spring. 2003;13(1):75-82. [pmid: 12804128].
McDougle KA CJS, Erickson CA, Posey DJ. Atypical antipsychotics in children and adolescents with autistic and other pervasive developmental disorders. J Clin Psychiatry. 4. 2008;69:15-20. [pmid: 18533764].
McDougle L CJS, Aman MG, McCracken JT, Tierney E, Davies M, Arnold LE, Posey DJ, Martin A, Ghuman JK, Shah B, Chuang SZ, Swiezy NB, Gonzalez N, Hollway J, Koenig K, McGough JJ, Ritz L, Vitiello B. Risperidone for the core symptom domains of autism: results from the study by the autism network of the research units on pediatric psychopharmacology. Am J Psychiatry. Jun. 2005;162(6):1142-8. [pmid: 15930063].
McGlashan Robert B THZ, Perkins Diana, Addington Jean, Miller Tandy, Woods Scott W, Hawkins A Keith, Hoffman E Ralph, Preda Adrian, Epstein Irvin, Addington Donald, Lindborg Stacy, Trzaskoma Quynh, Tohen Mauricio, Breier Alan. Randomized, Double-Blind Trial of Olanzapine Versus Placebo in Patients Prodromally Symptomatic for Psychosis. Am J Psychiatry. Jun. 2006. 1. 2006;163(5):790-9. [pmid: 16648318].
McIntyre RS. The role of aripiprazole in Canada: A review of clinical and drug discontinuation data. Foreword. Clin Ther. 1. 2010;32:S1-2. [pmid: 20152548].
Meyers AJ BSF, Rothschild AJ, Mulsant BH, Whyte EM, Peasley-Miklus C, Papademetriou E, Leon AC, Heo M. A double-blind randomized controlled trial of olanzapine plus sertraline vs olanzapine plus placebo for psychotic depression: the study of pharmacotherapy of psychotic depression (STOP-PD). Arch Gen Psychiatry. Aug. 2009;66(8):838-47. [pmid: 19652123].
Miller DD. Atypical antipsychotics: sleep, sedation, and efficacy. Prim Care Companion J Clin Psychiatry. 2004;6(Suppl 2):3-7. [pmid: 16001094].
Miral O SG, Inal-Emiroglu FN, Baykara B, Baykara A, Dirik E. Risperidone versus haloperidol in children and adolescents with AD : a randomized, controlled, double-blind trial. Eur Child Adolesc Psychiatry. Feb. 2008;17(1):1-8. [pmid: 18080171].
Mirandola Margherita MA, Corbari Letizia, Sorio Adriano, Nosè Michela, Barbui Corrado. Prevalence, incidence and persistence of antipsychotic drug prescribing in the Italian general population: retrospective database analysis, 1999-2002. Pharmacoepidemiology and Drug Safety. 2006;15(6):412-20. [pmid: 16287199].
Misra L LK. Risperidone treatment of methamphetamine psychosis. Am J Psychiatry. Aug. 1997;154(8):1170. [pmid: 9247413].
Misra L LKK, Oesterheld JR, Richards GA. Olanzapine treatment of methamphetamine psychosis. J Clin Psychopharmacol. Jun. 2000;20(3):393-4. [pmid: 10831035].
Moeller S OE, Deckert J, Baune BT, Dannlowski U, Nguyen DH, Arolt V, Hetzel G. The impact of ziprasidone in combination with sertraline on visually-evoked event-related potentials in depressed patients with psychotic features. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Oct. 2007;31(7):1440-3. [pmid: 17669572].
Mond Rodney JM, Owen Cathy. Use of antipsychotic medications in Australian States and Territories between July 1995 and December 2001. Australasian Psychiatry: Publication of The Royal Australian and New Zealand College of Psychiatrists. 2003;11(3):267-72.
Monshat K, Carty B, Olver J, Castle D, Bosanac P. Trends in antipsychotic prescribing practices in an urban community mental health clinic. Australas Psychiatry. Jun. 2010;18(3):238-41. [pmid: 20482426].
Morgan E ST. Antipsychotic drugs in children with autism. BMJ. May. 26. 2007;334(7603):1069-70. [pmid: 17525405].
Morrato EH, Druss B, Hartung DM, Valuck RJ, Allen R, Campagna E, et al. Metabolic testing rates in 3 state Medicaid programs after FDA warnings and ADA/APA recommendations for second-generation antipsychotic drugs. Arch Gen Psychiatry. Jan. 2010;67(1):17-24. [pmid: 20048219].
Mouaffak T FG, Bayle FJ, Olie JP, Baup N. Worsening of obsessive-compulsive symptoms after treatment with aripiprazole. J Clin Psychopharmacol. Apr. 2007;27(2):237-8. [pmid: 17414263].
Myers SM. The status of pharmacotherapy for autism spectrum disorders. Expert Opin Pharmacother. Aug. 2007;8(11):1579-603. [pmid: 17685878].
Nagaraj P RS, Malhi P. Risperidone in children with autism: randomized, placebo-controlled, double-blind study. J Child Neurol. Jun. 2006;21(6):450-5. [pmid: 16948927].
Nakaaki Y SM, Furukawa TA. Efficacy of olanzapine augmentation of paroxetine therapy in patients with severe body dysmorphic disorder. Psychiatry Clin Neurosci. Jun. 2008;62(3):370. [pmid: 18588607].
Nasrallah Donald W HAB, Goldberg Joseph F, Muzina David J, Pariser Stephen F. Issues associated with the use of atypical antipsychotic medications. Annals of Clinical Psychiatry. Dec. 2008. 2008;20(4):S24-S9.
Navari MC RMB. Treatment of cancer-related anorexia with olanzapine and megestrol acetate: a randomized trial. Support Care Cancer. 2009. Sep. 11.
Nunes PA JVB. Novel research translates to clinical cases of schizophrenic and cocaine psychosis. Neuropsychiatr Dis Treat. Aug. 2007;3(4):475-85. [pmid: 19300576].
Olgun O HS, Karacan M, Ceviz N. An unreported side effect of risperidone in children: sinus arrest with long pauses causing syncope. Pediatr Emerg Care. Jul. 2009;25(7):465-6. [pmid: 19606005].
Önder ÜTE. Clinical and pharmacologic risk factors for neuroleptic malignant syndrome and their association with death. Psychiatry and Clinical Neurosciences. 2010;64(1):79-87. [pmid: 20416027].
Osuntokun B OOM, Xu WI, Kryzhanovskaya LA, Robertson-Plouch C, Carlson JL, Acharya N, Corya SA. Metabolic parameters in patients treated with olanzapine or other atypical antipsychotics. J Psychopharmacol. 2010. May. 24.
Owen RT. Extended-release paliperidone: efficacy, safety and tolerability profile of a new atypical antipsychotic. Drugs Today (Barc). Apr. 2007;43(4):249-58. [pmid: 17460786].
Pae CU. A review of the safety and tolerability of aripiprazole. Expert Opin Drug Saf. May. 2009;8(3):373-86. [pmid: 19505266].
Pandina CA GJB, Youssef E, Zhu Y, Dunbar F. Risperidone improves behavioral symptoms in children with autism in a randomized, double-blind, placebo-controlled trial. J Autism Dev Disord. Feb. 2007;37(2):367-73. [pmid: 17019624].
Pani G LM. Expected clinical benefits of paliperidone extended-release formulation when compared with risperidone immediate-release. Expert Opin Drug Deliv. Mar. 2009;6(3):319-31. [pmid: 19317589].
Pappadopulos S EW, Chait A, Perkins M, Connor DF, Jensen PS. Pharmacotherapy of aggression in children and adolescents: efficacy and effect size. J Can Acad Child Adolesc Psychiatry. Feb. 2006;15(1):27-39. [pmid: 18392193].
Patel M Lynn NCC, Hoagwood Kimberly, Johnsrud Michael T, Rascati Karen L, Wilson James P. Physician Specialty Associated With Antipsychotic Prescribing for Youths in the Texas Medicaid Program. Medical Care. 2006;44(1):87-90. [pmid: 16365617].
Patel M Lynn NCC, Hoagwood Kimberly, Johnsrud Michael T, Rascati Karen L, Wilson James P, Jensen Peter S. Trends in the Use of Typical and Atypical Antipsychotics in Children and Adolescents. Journal of the American Academy of Child & Adolescent Psychiatry. 2005;44(6):548-56. [pmid: 15908837].
Patel Robert J NCS, Johnsrud Michael T, Crismon M Lynn. Trends in Antipsychotic Use in a Texas Medicaid Population of Children and Adolescents: 1996 to 2000. Journal of Child and Adolescent Psychopharmacology. 2002;12(3):221-9. [pmid: 12427295].
Pettinati H, Stedman M, Brown ES, Kotz M, Calabrese J, Borsody M, et al. A double-blind, placebo-controlled study of quetiapine adjunct therapy with traditional mood stabilizers in bipolar I patients with alcohol dependence [abstract]. Alcohol Clin Exp Res. 2008;32(6 suppl. 1):260A. Abs 998.
Posey CA DJE, McDougle CJ. Developing drugs for core social and communication impairment in autism. Child Adolesc Psychiatr Clin N Am. Oct. 2008;17(4):787-801. viii. ix. [pmid: 18775370].
Posey KA DJS, Erickson CA, McDougle CJ. Antipsychotics in the treatment of autism. J Clin Invest. Jan. 2008;118(1):6-14. [pmid: 18172517].
Potkin PT SGT, Alva G, Bera R, Yeh C, Arvanitis LA. The safety and pharmacokinetics of quetiapine when coadministered with haloperidol, risperidone, or thioridazine. J Clin Psychopharmacol. Apr. 2002;22(2):121-30. [pmid: 11910256].
Potvin E SK, Lipp O, Bouchard RH, Roy MA, Demers MF, Gendron A, Astarita G, Piomelli D, Stip E. Endogenous cannabinoids in patients with schizophrenia and substance use disorder during quetiapine therapy. J Psychopharmacol. May. 2008;22(3):262-9. [pmid: 18308802].
Preval SG HK, Southard R, Francis A. Rapid-acting IM ziprasidone in a psychiatric emergency service: a naturalistic study. Gen Hosp Psychiatry. Mar-Apr. 2005;27(2):140-4. [pmid: 15763126].
Procyshyn B RMT. Patterns of Antipsychotic Utilization in a Tertiary Care Psychiatric Institution. Pharmacopsychiatry. 2004;38(01):12-7. [pmid: 14750043].
Radley DC, Finkelstein SN, Stafford RS. Off-label prescribing among office-based physicians. Arch Intern Med. May. 8. 2006;166(9):1021-6. [pmid: 16682577].
Rao Jennifer R VS, Handel Sharon, Onyike Chiadi U. Clinical correlates of personality changes associated with traumatic brain injury. The Journal of Neuropsychiatry and Clinical Neurosciences. Win. 2008. 2008;20(1):118-9. [pmid: 18305306].
Rapoport M MM, Shulman KI, Herrmann N, Rochon PA. Antipsychotic use in the elderly: shifting trends and increasing costs. International Journal of Geriatric Psychiatry. 2005;20(8):749-53. [pmid: 16035128].
Rausch EL JLS, Londino DL, Johnson ME, Carr BM, Bhatia R, Miller S. Open-label risperidone for Asperger's disorder: negative symptom spectrum response. J Clin Psychiatry. Dec. 2005;66(12):1592-7. [pmid: 16401163].
Reeves Herbert RK, Lieberman Jordan, Vyas Rajiv. Creation of a Metabolic Monitoring Program for Second-Generation (Atypical) Antipsychotics. Journal of Correctional Health Care. October. 1. 2009. 2009;15(4):292-301. [pmid: 19622845].
Reeves JC RRB. Additional evidence of the abuse potential of quetiapine. South Med J. Aug. 2007;100(8):834-6. [pmid: 17713313].
Reyes Jan MB, Toren Paz, Augustyns Ilse, Eerdekens Marielle. A Randomized, Double-Blind, Placebo-Controlled Study of Risperidone Maintenance Treatment in Children and Adolescents With Disruptive Behavior Disorders. Am J Psychiatry. March. 1. 2006. 2006;163(3):402-10. [pmid: 16513860].
Riedel MJ MS, Strassnig M, Spellmann I, Muller-Arends A, Weber K, Zach J, Muller N, Moller HJ. Risperidone plasma levels, clinical response and side-effects. Eur Arch Psychiatry Clin Neurosci. Aug. 2005;255(4):261-8. [pmid: 15565299].
Rishi MA, Shetty M, Wolff A, Amoateng-Adjepong Y, Manthous CA. Atypical antipsychotic medications are independently associated with severe obstructive sleep apnea. Clin Neuropharmacol. May. 2010;33(3):109-13. [pmid: 20502129].
Rishi M MAS, Wolff A, Amoateng-Adjepong Y, Manthous CA. Atypical antipsychotic medications are independently associated with severe obstructive sleep apnea. Clin Neuropharmacol. May. 2010;33(3):109-13. [pmid: 20502129].
Rizos DV VPESCLCG. Atypical antipsychotics in the treatment of delirium. Psychiatry and Clinical Neurosciences. 2009;63(5):623-31. [pmid: 19674385].
Roerig James E JLM, M. D., de Zwaan Martina, Crosby Ross D, Gosnell Blake A, Steffen Kristine J, Wonderlich Stephen A PhD. A Comparison of the Effects of Olanzapine and Risperidone Versus Placebo on Eating Behaviors. Journal of Clinical Psychopharmacology. 2005;25(5):413-8. [pmid: 16160615].
Rohsenow JW DJT, Miranda R, McGeary JE, Swift RM, Hutchison KE, Sirota AD, Monti PM. Olanzapine reduces urge to smoke and nicotine withdrawal symptoms in community smokers. Exp Clin Psychopharmacol. Jun. 2008;16(3):215-22. [pmid: 18540781].
Sacher Nilufar JM, Spindelegger Christoph, Klein Nikolas, Geiss-Granadia Thomas, Sauermann Robert, Lackner Edith, Joukhadar Christian, Muller Markus, Kasper Siegfried. Effects of Olanzapine and Ziprasidone on Glucose Tolerance in Healthy Volunteers. Neuropsychopharmacology. 2007;33(7):1633-41. [pmid: 17712347].
Sandler L. Risperidone in children with autism and serious behavioral problems. N Engl J Med. Dec. 5. 2002;347(23):1890-1. author reply -1. [pmid: 12466518].
Sanfelix-Gimeno P GC-C, Peiro S, Lopez-Valcarcel BG, Blazquez A, Barbera T. Effectiveness of safety warnings in atypical antipsychotic drugs: an interrupted time-series analysis in Spain. Drug Saf. 2009;32(11):1075-87. [pmid: 19810779].
Scahill L. How do I decide whether or not to use medication for my child with autism? should I try behavior therapy first?. Journal of Autism and Developmental Disorders. Jul. 2008. 2008;38(6):1197-8. [pmid: 18463973].
Scahill K LK, Carroll DH, Pachler M. Risperidone approved for the treatment of serious behavioral problems in children with autism. J Child Adolesc Psychiatr Nurs. Aug. 2007;20(3):188-90. [pmid: 17688557].
Schneider MH RAL. Apparent seizure and atrial fibrillation associated with paliperidone. Am J Health Syst Pharm. Nov. 15. 2008;65(22):2122-5. [pmid: 18997140].
Schwam E JSK, Alonso C, Perry R. Risperidone and refusal to eat. J Am Acad Child Adolesc Psychiatry. Jun. 1998;37(6):572-3. [pmid: 9628075].
Scott S LJD. Risperidone: a review of its use in the treatment of irritability associated with autistic disorder in children and adolescents. Paediatr Drugs. 2007;9(5):343-54. [pmid: 17927305].
Scott S LJD. Spotlight on risperidone in irritability associated with autistic disorder in children and adolescents. CNS Drugs. 2008;22(3):259-62. [pmid: 18278980].
Setoguchi PS SW, Alan Brookhart M, Canning CF, Kaci L, Schneeweiss S. Potential causes of higher mortality in elderly users of conventional and atypical antipsychotic medications. J Am Geriatr Soc. Sep. 2008;56(9):1644-50. [pmid: 18691283].
Sharp C BP. Abnormal motor movements associated with combining psychostimulants and atypical antipsychotics in children. CNS Spectr. Sep. 2007;12(9):659-62. [pmid: 17918663].
Shepherd VM JG, De Leon OA. Waxing-and-waning catatonia after intermittent exposure to aripiprazole in a case of autism and bipolar disorder. J Clin Psychopharmacol. Oct. 2009;29(5):503-4. [pmid: 19745656].
Shoptaw U SJK, Ling W. Treatment for amphetamine psychosis. Cochrane Database Syst Rev. 2009;(1):CD003026. [pmid: 19160215].
Silver N HA, Schwartz M. Attention deficit-hyperactivity disorder may be a risk factor for treatment-emergent tardive dyskinesia induced by risperidone. J Clin Psychopharmacol. Feb. 2000;20(1):112-4. [pmid: 10653224].
Smith Anthony J ER, Heo Moonseong, Peasley-Miklus Catherine, Caswell Melynda, Papademetriou Eros, Flint Alastair J, Mulsant Benoit H, Meyers Barnett S. Weight gain during olanzapine treatment for psychotic depression: Effects of dose and age. International Clinical Psychopharmacology. May. 2008. 2008;23(3):130-7. [pmid: 18408527].
Snoeck A EVP, Sack M, Horton M, Mannens G, Woestenborghs R, Meibach R, Heykants J. Influence of age, renal and liver impairment on the pharmacokinetics of risperidone in man. Psychopharmacology (Berl). Dec. 1995;122(3):223-9. [pmid: 8748391].
Snyder A RT, Aman M, Binder C, Fisman S, Carroll A. Effects of risperidone on conduct and disruptive behavior disorders in children with subaverage IQs. J Am Acad Child Adolesc Psychiatry. Sep. 2002;41(9):1026-36. [pmid: 12218423].
Soorya J LK, Hollander E. Psychopharmacologic interventions for repetitive behaviors in autism spectrum disorders. Child Adolesc Psychiatr Clin N Am. Oct. 2008;17(4):753-71. viii. [pmid: 18775368].
Soyka U MW, Moeller HJ. Risperidone in treatment-refractory chronic alcohol hallucinosis. Pharmacopsychiatry. Jul. 1997;30(4):135-6. [pmid: 9271781].
Stachnik C JMN-T. Use of atypical antipsychotics in the treatment of autistic disorder. Ann Pharmacother. Apr. 2007;41(4):626-34. [pmid: 17389666].
Stahl MM SMG. A critical review of atypical antipsychotic utilization: comparing monotherapy with polypharmacy and augmentation. Curr Med Chem. Feb. 2004;11(3):313-27. [pmid: 14965234].
Stephens C RJB, Sandor P. Olanzapine in the treatment of aggression and tics in children with Tourette's syndrome--a pilot study. J Child Adolesc Psychopharmacol. 2004;14(2):255-66. [pmid: 15319022].
Stigler JT KAD, Kohn AE, Li L, Erickson CA, Posey DJ, McDougle CJ. Aripiprazole in pervasive developmental disorder not otherwise specified and Asperger's disorder: a 14-week, prospective, open-label study. J Child Adolesc Psychopharmacol. Jun. 2009;19(3):265-74. [pmid: 19519261].
Stigler CJ KAM. Pharmacotherapy of irritability in pervasive developmental disorders. Child Adolesc Psychiatr Clin N Am. Oct. 2008;17(4):739-52. vii. viii. [pmid: 18775367].
Stoops WW. Aripiprazole as a potential pharmacotherapy for stimulant dependence: human laboratory studies with d-amphetamine. Exp Clin Psychopharmacol. Nov. 2006;14(4):413-21. [pmid: 17115868].
Stoops JA WWL, Glaser PE, Rush CR. A low dose of aripiprazole attenuates the subject-rated effects of d-amphetamine. Drug Alcohol Depend. Sep. 15. 2006;84(2):206-9. [pmid: 16540264].
Tahir TA, Eeles E, Karapareddy V, Muthuvelu P, Chapple S, Phillips B, et al. A randomized controlled trial of quetiapine versus placebo in the treatment of delirium. J Psychosom Res. Nov. 2010;69(5):485-90. [pmid: 20955868].
Tamayo Virginia K JMS, Mattei Manuel A, Diaz Barbara, Jamal Hassan H, Vieta Eduard, Zarate Carlos A Jr, Fumero Ileana, Tohen Mauricio. Effectiveness and safety of the combination of fluoxentine and olanzapine in outpatients with bipolar depression: An open-label, randomized, flexible-dose study in Puerto Rico. Journal of Clinical Psychopharmacology 2009 Aug. 2009. 2009;29(4):358-61.
Tamayo VK JMS, Mattei MA, Diaz B, Jamal HH, Vieta E, Zarate CA Jr, Fumero I, Tohen M. Effectiveness and safety of the combination of fluoxetine and olanzapine in outpatients with bipolar depression: an open-label, randomized, flexible-dose study in Puerto Rico. J Clin Psychopharmacol. Aug. 2009;29(4):358-61. [pmid: 19593175].
Tarsy RJ DB, Tarazi FI. Effects of newer antipsychotics on extrapyramidal function. CNS Drugs. 2002;16(1):23-45. [pmid: 11772117].
Taylor Catrin DMF, Sparshatt Anna, Thomas Arwel, Bishara Delia, Cornelius Victoria. Risperidone long-acting injection: A prospective 3-year analysis of its use in clinical practice. Journal of Clinical Psychiatry. Feb. 2009. 2009;70(2):196-200. [pmid: 19026261].
Tcheremissine OV. Is quetiapine a drug of abuse? Reexamining the issue of addiction. Expert Opin Drug Saf. Nov. 2008;7(6):739-48. [pmid: 18983220].
Thase ME. Quetiapine monotherapy for bipolar depression. Neuropsychiatric Disease and Treatment. 2008;4(1):21-31.
Thase ME. Reply to comments by Dr Rifkin and Dr Dawdy. Journal of Clinical Psychopharmacology. Jun. 2008. 2008;28(3):368.
Thase A MEJ, Khan A, Bowden CL, Wu X, McQuade RD, Carson WH, Marcus RN, Owen R. Aripiprazole monotherapy in nonpsychotic bipolar I depression: results of 2 randomized, placebo-controlled studies. J Clin Psychopharmacol. Feb. 2008;28(1):13-20. [pmid: 18204335].
Thase W MEM, Weisler RH, Chang W, Paulsson B, Khan A, Calabrese JR. Efficacy of quetiapine monotherapy in bipolar I and II depression: a double-blind, placebo-controlled study (the BOLDER II study). J Clin Psychopharmacol. Dec. 2006;26(6):600-9. [pmid: 17110817].
Theisen A FML, Konig IR, Martin M, Remschmidt H, Hebebrand J. Spectrum of binge eating symptomatology in patients treated with clozapine and olanzapine. J Neural Transm. Jan. 2003;110(1):111-21. [pmid: 12541016].
Thomsen PH. Risperidone augmentation in the treatment of severe adolescent OCD in SSRI-refractory cases: a case-series. Ann Clin Psychiatry. Oct-Dec. 2004;16(4):201-7. [pmid: 15702568].
Tierney M EA, Stout D, Pappas K, Arnold LE, Vitiello B, Scahill L, McDougle C, McCracken J, Wheeler C, Martin A, Posey D, Shah B. Parent satisfaction in a multi-site acute trial of risperidone in children with autism: a social validity study. Psychopharmacology (Berl). Mar. 2007;191(1):149-57. [pmid: 17123125].
Torgovnick JS, Nitin K. Arsura, Edward. Aripiprazole-induced orthostatic hypotension and cardiac arrhythmia. Psychiatry and Clinical Neurosciences. Aug. 2008. 2008;62(4):485. [pmid: 18778452].
Towbin KE. Gaining: pediatric patients and use of atypical antipsychotics. Am J Psychiatry. Dec. 2006;163(12):2034-6. [pmid: 17151148].
Turgay A. Psychopharmacological treatment of oppositional defiant disorder. CNS Drugs. 2009;23(1):1-17. [pmid: 19062772].
Uchida S HK, Mulsant BH, Graff-Guerrero A, Pollock BG, Mamo DC. Sensitivity of older patients to antipsychotic motor side effects: a PET study examining potential mechanisms. Am J Geriatr Psychiatry. Mar. 2009;17(3):255-63. [pmid: 19225277].
Ukaegbu J CB, Burton Carter, Nakia J. What drugs are best for bipolar depression?. The Journal of Family Practice. Sep. 2008. 2008;57(9):606-8. [pmid: 18786334].
Unwin Shoumitro GLD. Use of medication for the management of behavior problems among adults with intellectual disabilities: A clinicians' consensus survey. American Journal on Mental Retardation. 2008. 2008;113(1):19-31. [pmid: 18173296].
Ushijima Shin MY, Sugiyama Eiko, Amano Naoji. Contribution of perospirone and risperidone to reduce delirium in senile patients. Psychogeriatrics. Mar. 2008. 2008;8(1):4-7.
Valdovinos DA MGN, Zarcone JR, Hellings JA, Williams DC, Schroeder SR. Multimodal evaluation of risperidone for destructive behavior: functional analysis, direct observations, rating scales, and psychiatric impressions. Exp Clin Psychopharmacol. Aug. 2002;10(3):268-75. [pmid: 12233987].
Valiquette G. Risperidone in children with autism and serious behavioral problems. N Engl J Med. Dec. 5. 2002;347(23):1890-1. author reply -1. [pmid: 12472071].
Volavka L JC, Huertas D. Update on the biological treatment of aggression. Actas Españolas de Psiquiatría. Mar-Apr. 2006;34(2):123-35.
Wachtel Amanda SRO, De Wit Harriet. The effects of acute haloperidol or risperidone on subjective responses to methamphetamine in healthy volunteers. Drug and Alcohol Dependence. Sep. 2002. 2002;68(1):23-33. [pmid: 12167550].
Wagner KD. Medication and diagnostic issues. Journal of Clinical Psychiatry. Feb. 2009. 2009;70(2):238-9. [pmid: 19265642].
Wang HJ JSZ, Markowitz JS, Donovan JL, Yuan HJ, Devane CL. Antipsychotic drugs inhibit the function of breast cancer resistance protein. Basic Clin Pharmacol Toxicol. Oct. 2008;103(4):336-41. [pmid: 18834354].
Wang Sebastian PSS, Setoguchi Soko, Patrick Amanda, Avorn Jerry, Mogun Helen, Choudhry Niteesh K, Brookhart M Alan. Ventricular arrhythmias and cerebrovascular events in the elderly using conventional and atypical antipsychotic medications. Journal of Clinical Psychopharmacology. Dec. 2007. 2007;27(6):707-10. [pmid: 18004143].
Waters KG BMJ. Intravenous quetiapine-cocaine use (“Q-ball”). Am J Psychiatry. Jan. 2007;164(1):173-4. [pmid: 17202567].
West J LW, Brunssen S. Pharmacologic treatment for the core deficits and associated symptoms of autism in children. J Pediatr Health Care. Mar-Apr. 2009;23(2):75-89. [pmid: 19232924].
West J LW. Risperidone use in the treatment of behavioral symptoms in children with autism. Pediatr Nurs. Nov-Dec. 2006;32(6):545-9. [pmid: 17256292].
Wijkstra H JB, van den Broek WW, Birkenhager TK, Janzing JG, Boks MP, Bruijn JA, van der Loos ML, Breteler LM, Ramaekers GM, Verkes RJ, Nolen WA. Treatment of unipolar psychotic depression: a randomized, double-blind study comparing imipramine, venlafaxine, and venlafaxine plus quetiapine. Acta Psychiatr Scand. 2009. Aug. 19.
Wilhelm Alexander SS, Wagner Thomas. Use of antipsychotics and benzodiazepines in patients with psychiatric emergencies: Results of an observational trial. BMC Psychiatry. Jul. 2008. 2008;8. ArtID 61.
Williams L SKS, Vitiello B, Aman MG, Arnold LE, McDougle CJ, McCracken JT, Tierney E, Ritz L, Posey DJ, Swiezy NB, Hollway J, Cronin P, Ghuman J, Wheeler C, Cicchetti D, Sparrow S. Risperidone and adaptive behavior in children with autism. J Am Acad Child Adolesc Psychiatry. Apr. 2006;45(4):431-9. [pmid: 16601648].
Wilner RJ KDA, Johnson AC, Miceli JJ, Fricke JR, Titus CK. The anxiolytic effect of the novel antipsychotic ziprasidone compared with diazepam in subjects anxious before dental surgery. J Clin Psychopharmacol. Apr. 2002;22(2):206-10. [pmid: 11910268].
Wines JD Jr, Weiss RD. Opioid withdrawal during risperidone treatment. J Clin Psychopharmacol. Jun. 1999;19(3):265-7. [pmid: 10350033].
Winterfeld MF ULH, Acquaviva E, Mouren MC, Brion F, Bourdon O. [Off-label use of psychotropic medications in paediatric wards: a prospective study]. Arch Pediatr. Sep. 2009;16(9):1252-60. [pmid: 19640689].
Wright Luke POF. Antipsychotic drugs: Atypical advantages and typical disadvantages. Irish Journal of Psychological Medicine. Mar. 2003. 2003;20(1):24-7.
Yang Greg L LPHP. Paliperidone Extended Release. CNS Drugs. 2007;21(5):417-25. [pmid: 17447829].
Yood MU, DeLorenze G, Quesenberry CP Jr, Oliveria SA, Tsai AL, Willey VJ, et al. The incidence of diabetes in atypical antipsychotic users differs according to agent--results from a multisite epidemiologic study. Pharmacoepidemiol Drug Saf. Sep. 2009;18(9):791-9. [pmid: 19526626].
Yoshimura Masahiro AM, Imai Makoto, Yamada Naoto, Okawa Masako. Low-dose oral risperidone lengthened sleep duration in healthy participants. Sleep and Biological Rhythms. Oct. 2007. 2007;5(4):277-83.
Zito Daniel J JMS, Valluri Satish, Gardner James F, Korelitz James J, Mattison Donald R. Psychotherapeutic Medication Prevalence in Medicaid-Insured Preschoolers. Journal of Child and Adolescent Psychopharmacology. 2007;17(2):195-204. [pmid: 17489714].
Zito Daniel J JMS, dosReis Susan, Gardner James F, Magder Laurence, Soeken Karen, Boles Myde, Lynch Frances, Riddle Mark A. Psychotropic Practice Patterns for Youth: A 10-Year Perspective. Arch Pediatr Adolesc Med. January. 1. 2003. 2003;157(1):17-25. [pmid: 12517190].

## Rejected, Population Not Human

Bergman J. Medications for stimulant abuse: agonist-based strategies and preclinical evaluation of the mixed-action D-sub-2 partial agonist aripiprazole (Abilify). Exp Clin Psychopharmacol. Dec. 2008;16(6):475-83. [pmid: 19086768].

## Rejected, Duplicated Data

de Geus F, Denys D, Westenberg HG. Effects of quetiapine on cognitive functioning in obsessive-compulsive disorder. Int Clin Psychopharmacol. Mar. 2007;22(2):77-84. [pmid: 17293707].
Nickel MK, Muehlbacher M, Nickel C, et al. Aripiprazole in the treatment of patients with borderline personality disorder: a double-blind, placebo-controlled study. Am J Psychiatry. May. 2006;163(5):833-838. [pmid: 16648324].
Suh GH, Greenspan AJ, Choi SK. Comparative efficacy of risperidone versus haloperidol on behavioural and psychological symptoms of dementia. Int J Geriatr Psychiatry. Jul. 2006;21(7):654-660. [pmid: 16821257].
Alexopoulos GS, Canuso CM, Gharabawi GM, et al. Placebo-controlled study of relapse prevention with risperidone augmentation in older patients with resistant depression. American Journal of Geriatric Psychiatry. Jan. 2008. 2008;16(1):21-30. [pmid: 17928573].
Schneider LS, Tariot PN, Dagerman KS, et al. Effectiveness of Atypical Antipsychotic Drugs in Patients with Alzheimer's Disease. N Engl J Med. October. 12. 2006. 2006;355(15):1525-1538. [pmid: 17035647].
Montgomery A SC, Lazarus A, Schollin M, Brecher M. Extended release Quetiapine Fumarate (Quetiapine XR) monotherapy in the treatment of patients with major depressive disorder (MDD). European Psychiatry. 2008;23(Supplement 2):S259-S260.
Bandelow B, Bobes J, Ahohas A, Eggens I, Liu S, Brecher M. Results from a phase ii study of once-daily extended release quitiapine fumarate (quitiapine xr) monotherapy in patients with generalized anxiety disorder. Paper presented at the International Forum on Mood and Anxiety Disorders. 2007. Budapest, Hungary.
Katzman MA, Brawman-Mintzer O, Reyes E, et al. Extended release quetiapine fumarate (quetiapine XR) monotherapy in maintenance treatment of generalized anxiety disorder (GAD): efficacy and tolerability results from a randomized, placebo-controlled trial [poster]. Presented at the 161st annual meeting of the American Psychiatric Association. May 3-8, 2008. Washington, DC.
Datto C, Lam RW, Lepola U, et al. Double-blind study of extended release quetiapine fumarate (quetiapine XR) monotherapy for maintenance treatment of major depressive disorder (MDD) [poster]. Presented at the 161st annual meeting of the American Psychiatric Association. May 3-8, 2008. Washington, DC.
Chouinard G, Bandelow B, Ahokas A, et al. Once-daily extended release of quetiapine fumarate (quetiapine XR) monotherapy in generalized anxiety disorder: a phase Ill, double-blind, placebo-controlled study [poster]. presented at the annual meeting of the American College of Neuropsychopharmacology. Dec 9-13, 2007. Boca Raton, Fla.
El-Khalili N, Banov M, Bortnick B, et al. Efficacy and tolerability of extended release quetiapine fumarate (quetiapine XR) monotherapy in major depressive disorder (MDD): a randomized, placebo-controlled clinical trial (Study 003) [poster]. Presented at: the 63rd Annual Society of Biological Psychiatry. May 1-3, 2008. Washington, DC, USA.
AstraZeneca. A Multicenter, Double-blind, Randomized, Parallel-group, Placebo-controlled Phase III Study of the Efficacy and Safety of Quetiapine Fumarate Extended-release (SEROQUEL XR™) in Combination with an Antidepressant in the Treatment of Patients with Major Depressive Disorder with Inadequate Response to an Antidepressant Treatment (Pearl Study). Study code: D1448C0000610. December. 2007.
AstraZeneca. A Multicenter, Double-Blind, Randomized, Parallel-Group, Placebo-Controlled Phase III Study of the Efficacy and Safety of Quetiapine Fumarate Extended Release (SEROQUEL XR) as Mono-Therapy in the Treatment of Adult Patients with Major Depressive Disorder (OPAL STUDY). Study code: D1448C0000317. January. 2008.
Vulink NCC, Fluitman S, Meinardi JCM, Westenberg HGM, Denys D. Double-blind, randomized, placebo-controlled addition of quetiapine in non-refractory OCD patients. European Neuropsychopharmacology. 2007;17(Supplement 1):S86-S87.
Earley W, McIntyre A, Wang G, Raines S, Eriksson H, et al. Double-blind study of the efficacy and tolerability of extended release quetiapine fumarate (quetiapine XR) monotherapy in patients with major depressive disorder (MDD) [poster]. Presented at: the 8th International Forum on Mood and Anxiety Disorders. November 12-14, 2008. Vienna, Austria.
El-Khalili N, Joyce M, Atkinson S, et al. Adjunctive extended-release quetiapine fumarate (quetiapine XR) in patients with major depressive disorder and inadequate antidepressant response [poster]. Presented at: the 161st Annual Meeting of the American Psychiatric Association. May 3-8, 2008. Washington, DC, USA.
Katila H, Mezhebovsky I, Mulroy A, et al. Efficacy and tolerability of once-daily extended release quetiapine fumarate (quetiapine XR) monotherapy in elderly patients with major depressive disorder (MDD). Presented at: the 8th International Forum on Mood and Anxiety Disorders. 2008 November 12-14. 2008.
Hamner MB, Ulmer HG, Faldowski RA, et al. A randomized, controlled trial of risperidone for psychotic features in PTSD. Biological Psychiatry. 2000;47(8, Supplement 1):S158-S159.
Brodaty H, Ames D, Snowdon J, et al. Risperidone for psychosis of Alzheimer's disease and mixed dementia: results of a double-blind, placebo-controlled trial. Int J Geriatr Psychiatry. Dec. 2005;20(12):1153-1157. [pmid: 16315159].
Steffens DC, Nelson JC, Eudicone JM, et al. Efficacy and safety of adjunctive aripiprazole in major depressive disorder in older patients: a pooled subpopulation analysis. Int J Geriatr Psychiatry. Sep. 9. 2010.
Guardia J, Roncero C, Galan J, Barcons C, Casas M. Efficacy and tolerability of quetiapine, combined with naltrexone, in the treatment of alcohol dependence [abstract]. Eur Neuropsychopharm. 2007;17(suppl. 4):S545-S546. Abs. P.546.a.013.