# Evidence Tables

Head-to-Head Trials

Citation and Study Information | Eligibility, Interventions, Outcomes | Results, Adverse Events, and Withdrawals
Rainer et al. 2007^142^ Dementia/Agitation Quetiapine, Risperidone Location: Western Europe Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 55 Sex: Mixed Race: Not reported Screened: NR Eligible: 72 Entering: 72 Withdrawn: 6 Lost to follow-up: 1 Analyzed: 65 Method of AE assessment: Elicited by investigator, reported spontaneously by patient | Inclusion criteria: 55-85 years old, dementia, MMSE score 10-26, have a NPI part I score in sub-items relating to delusions, hallucinations, agitation/aggression Exclusion criteria: Participation in any other drug trial within 4 weeks, hypersensitive to study drugs, chronic disease, use of antipsychotics, seizure, severe cardiovascular disease, asthmatic condition, met NINCDS-ADRDA exclusion criteria. Interventions: Quetiapine 50-400 mg/days flexible dose for 8 weeks vs Risperidone 0.5-4 mg/days flexible dose for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 28, 56 days | Results: Dementia: Change in CMAI (Agitation) at 8 weeks: Risperidone vs Quetiapine - SMD = -0.17 ( -0.66 , 0.32 ) Dementia: Change in NPI total (Total) at 8 weeks: Risperidone vs Quetiapine - SMD = -0.06 ( -0.55 , 0.43 ) Adverse Events: Quetiapine vs Risperidone All Adverse Events: 57.9%(22/38) vs 44.1%(15/34) Asthenia: 2.6%(1/38) vs 5.9%(2/34) Cerebrovascular Adverse Events: 0.0%(0/38) vs 0.0%(0/34) Conjunctivitis: 0.0%(0/38) vs 5.9%(2/34) Constipation: 5.3%(2/38) vs 2.9%(1/34) Deaths: 0.0%(0/38) vs 0.0%(0/34) Diarrhea: 0.0%(0/38) vs 14.7%(5/34) Fall With Contusion: 2.6%(1/38) vs 0.0%(0/34) Falls Or Fractures Due To Somnolence Or Sedation: 0.0%(0/38) vs 0.0%(0/34) Fatigue: 7.9%(3/38) vs 0.0%(0/34) Femur Fracture: 5.3%(2/38) vs 0.0%(0/34) Insomnia: 5.3%(2/38) vs 2.9%(1/34) Muscle Rigidity: 0.0%(0/38) vs 14.7%(5/34) Sedation: 10.5%(4/38) vs 0.0%(0/34) Serious Adverse Events Of Hallucinations During Hospitalization For Hernia Surgery:0.0%(0/38) vs 2.9%(1/34) Significant Change From Baseline Blood Pressure Or Pulse Rate: 0.0%(0/38) vs 0.0%(0/34) Somnolence: 5.3%(2/38) vs 0.0%(0/34) Thigh Fracture: 5.3%(2/38) vs 0.0%(0/34) Total Serious Adverse Events: 7.9%(3/38) vs 2.9%(1/34) Treatment-Emergent Extrapyramidal Symptoms Reported As Adverse Events (Extrapyramidal Disorder And Muscle Rigidity): 0.0%(0/38) vs 17.6%(6/34) Urinary Incontinence: 5.3%(2/38) vs 0.0%(0/34) Withdrawals: Quetiapine vs Risperidone Withdrawals:10.5%(4/38) vs 8.8%(3/34) Withdrawals Due To Adverse Events:5.3%(2/38) vs 2.9%(1/34)
Sultzer et al. 2008^119^ Dementia/Agitation Olanzapine, Quetiapine, Risperidone Location: US Trial: CATIE-AD Funding source: Government Design: RCT only Setting: Multi-center Jadad: 1 Age: Mean: 78 Sex: Mixed Race: Caucasian, Other-NOS Screened: NR Eligible: NR Entering: 421 Withdrawn: 77-85% Lost to follow-up: NR Analyzed: NR Method of AE assessment: Not applicable | Inclusion criteria: Had dementia of the Alzheimer's type or probable Alzheimer's disease, delusions/hallucinations/agitation/ aggression, had occurred nearly every day over previous week or intermittently over 4 weeks, at least moderate in severity on BPRS, MMSE score 5-16 Exclusion criteria: Patients in skilled nursing homes, taking antidepressants or anticonvulsants for mood stabilization. Interventions: Placebo for 12 weeks vs Olanzapine 5.5 mg/days average final dose for 12 weeks vs Quetiapine 56.5 mg/days average final dose for 12 weeks vs Risperidone 1.0 mg/days average final dose for 12 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 14, 28, 56, 84 days | Results: Dementia: Change in NPI total (Total) at 12 weeks: Placebo vs Olanzapine - SMD = 0.15 ( -0.11 , 0.40 ) Dementia: Change in NPI total (Total) at 12 weeks: Placebo vs Risperidone - SMD = 0.40 ( 0.13 , 0.68 ) Dementia: Change in NPI total (Total) at 12 weeks: Placebo vs Quetiapine - SMD = 0.15 ( -0.11 , 0.42 ) Dementia: Change in NPI total (Total) at 12 weeks: Olanzapine vs Quetiapine - SMD = 0.02 ( -0.27 , 0.30) Dementia: Change in NPI total (Total) at 12 weeks: Risperidone vs Quetiapine - SMD = -0.24 ( -0.53 , 0.06) Dementia: Change in NPI total (Total) at 12 weeks: Risperidone vs Olanzapine - SMD = -0.27 ( -0.56 , 0.02) Dementia: Change in BPRS psy (Psychosis) at 12 weeks: Placebo vs Olanzapine - SMD = 0.07 ( -0.19 , 0.33 ) Dementia: Change in BPRS psy (Psychosis) at 12 weeks: Placebo vs Risperidone - SMD = 0.39 ( 0.11 , 0.66 ) Dementia: Change in BPRS psy (Psychosis) at 12 weeks: Placebo vs Quetiapine - SMD = 0.16 ( -0.10 , 0.42 ) Dementia: Change in BPRS psy (Psychosis) at 12 weeks: Olanzapine vs Quetiapine - SMD = 0.07 ( -0.21 , 0.35 ) Dementia: Change in BPRS psy (Psychosis) at 12 weeks: Risperidone vs Quetiapine - SMD = -0.24 ( -0.54 , 0.06 ) Dementia: Change in BPRS psy (Psychosis) at 12 weeks: Risperidone vs Olanzapine - SMD = -0.27 ( -0.56 , 0.02 ) Dementia: Change in BPRS agitation (Agitation) at 12 weeks: Placebo vs Olanzapine - SMD = 0.28 ( 0.02 , 0.54 ) Dementia: Change in BPRS agitation (Agitation) at 12 weeks: Placebo vs Risperidone - SMD = 0.10 ( -0.18 , 0.37 ) Dementia: Change in BPRS agitation (Agitation) at 12 weeks: Placebo vs Quetiapine - SMD = 0.20 ( -0.06 , 0.46 ) Dementia: Change in BPRS agitation (Agitation) at 12 weeks: Olanzapine vs Quetiapine - SMD = -0.09 ( -0.37 , 0.19 ) Dementia: Change in BPRS agitation (Agitation) at 12 weeks: Risperidone vs Quetiapine - SMD = 0.10 ( -0.20 , 0.39 )
Maina et al. 2008^195^ OCD Olanzapine, Risperidone Location: Western Europe Trial: Not reported Funding source: Not funded Design: RCT only Setting: Single setting Jadad: 3 Age: Mean: 35 Sex: Mixed Race: Not reported Screened: 110 Eligible: 50 Entering: 50 Withdrawn: 7 Lost to follow-up: 0 Analyzed: 43 Method of AE assessment: Monitored, reported spontaneously by patient | Inclusion criteria: Age >=18, primary diagnosis of OCD, OCD present for at least 1 year prior to study entry. VBOCS total score >=16, non-responders to SRIs Exclusion criteria: A current diagnosis of MDD and/or HAM-D score >=15, schizophrenia or organic brain syndrome or medical illness contra-indicate use of SRI and/or risperidone or olanzapine, pregnant or nursing women Interventions: Risperidone 1-3 mg/days fixed titration schedule for 8 weeks vs Olanzapine 2.5-10 mg/days fixed titration schedule for 8 weeks Run-in/wash-out period: Run-in: SRI monotherapy for 16 week(s). Patients resistant to SRI were randomized. Comorbidities: None Timing of outcome assessment: 14, 28, 42, 56 days | Results: OCD: Change in YBOCS (Total Score) at 8 weeks: Olanzapine vs Risperidone - WMD = -0.50 ( -3.81 , 2.81 ) Adverse Events: Risperidone vs Olanzapine Amenorrhoea: 24.0%(6/25) vs 4.0%(1/25) Any Adverse Events: 52.0%(13/25) vs 64.0%(16/25) Diminished Sexual Desire: 0.0%(0/25) vs 4.0%(1/25) Micturition Disturbances: 4.0%(1/25) vs 0.0%(0/25) Nausea/Vomiting: 8.0%(2/25) vs 0.0%(0/25) Orthostatic Dizziness: 12.0%(3/25) vs 8.0%(2/25) Rash: 4.0%(1/25) vs 0.0%(0/25) Rigidity: 8.0%(2/25) vs 0.0%(0/25) Tension/Inner Unrest: 24.0%(6/25) vs 0.0%(0/25) Weight Gain: 16.0%(4/25) vs 52.0%(13/25) Withdrawals: Olanzapine Diminished Sex Desire; Weight Gain Leading To Withdrawal:8.0%(2/25) Risperidone Tension/Inner Unrest; Nausea/Vomiting Leading To Withdrawal:8.0%(2/25) Risperidone vs Olanzapine Withdrawals:12.0%(3/25) vs 16.0%(4/25) Withdrawals Due To Adverse Events:8.0%(2/25) vs 8.0%(2/25)
Matsunaga et al. 2009^198^ OCD Olanzapine, Quetiapine, Risperidone Location: Asia Trial: Not reported Funding source: Government Design: RCT only Setting: Single setting Jadad: 1 Age: Mean: 30 Sex: Mixed Race: Not reported Screened: 137 Eligible: 44 Entering: 90 Withdrawn: NR Lost to follow-up: NR Analyzed: 46 Method of AE assessment: Monitored, reported spontaneously by patient | Inclusion criteria: Diagnosed OCD, received treatment >= 1 year at Osaka hospital. Exclusion criteria: Not reported Interventions: Olanzapine 1-10 mg/days frequency not reported for duration not reported vs Quetiapine 25-100 mg/days frequency not reported for variable duration vs Risperidone 1-5 mg/days frequency not reported for duration not reported vs Control Group Run-in/wash-out period: Run-in: Fluoxetine or paroxetine for 12 week(s). Non-responders were randomized. Comorbidities: Depression Timing of outcome assessment: 365 days | Results: OCD: Insufficient data to calculate an effect size Adverse Events: SSRI+olanzapine, quetiapine or risperidone Increased Appetite: 34.1%(15/44) Increased Body Weight: 27.3%(12/44) Sedation: 6.8%(3/44) Sleepiness: 11.4%(5/44) SSRI+olanzapine, quetiapine or risperidone vs SSRIs (fluvoxamine or paroxetine) BMI Increase > 10%: 50.0%(22/44) vs 15.2%(7/46) Withdrawals: SSRI+olanzapine, quetiapine or risperidone Withdrawals:0.0%(0/44) SSRI+olanzapine, quetiapine or risperidone vs SSRIs (fluvoxamine or paroxetine) Withdrawals Due To Adverse Events:0.0%(0/44) vs 0.0%(0/46)
Nejtek et al. 2008^250^ Substance abuse Quetiapine, Risperidone Location: US Trial: Not reported Funding source: Industry, Private Design: RCT only Setting: Multi-center Jadad: 4 Age: Mean: 36 Sex: Mixed Race: Caucasian, African Ancestry, Hispanic Screened: 651 Eligible: NR Entering: NR Withdrawn: NR Lost to follow-up: NR Analyzed: 14 Method of AE assessment: Monitored | Inclusion criteria: 20-50 years old, outpatients, bipolar disorder with or without psychotic features or bipolar II disorder, cocaine or methamphetamine dependence, experiencing hypomanic, manic, or mixed state episodes with YMRS >=9, craving score >-10 on SCQ - 10 Exclusion criteria: Inpatients, substance-induced mood disorder, pregnant, a history of special education / mental retardation / dementia, had HIV/AIDS, reactive hepatitis, hepatic cirrhosis or any active liver disease, diabetes, heart disease, central nervous system disease, allergic to study medications, receiving any antipsychotic drugs, had contraindications Interventions: Quetiapine 50-600 mg/days fixed titration schedule for 20 weeks vs Risperidone 0.5-6 mg/days fixed titration schedule for 20 weeks Run-in/wash-out period: Not reported Comorbidities: OCD, PTSD Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56 days | Results: Substance Abuse: Insufficient data to calculate an effect size Adverse Events: Quetiapine vs Risperidone Blurred Vision: 2.1%(1/48) vs 6.5%(3/46) Clumsiness: 4.2%(2/48) vs 4.3%(2/46) Constipation: 2.1%(1/48) vs 0.0%(0/46) Daytime Sleepiness: 12.5%(6/48) vs 10.9%(5/46) Decreased Appetite: 6.3%(3/48) vs 6.5%(3/46) Diarrhea: 2.1%(1/48) vs 2.2%(1/46) Difficulty Urinating: 0.0%(0/48) vs 0.0%(0/46) Dizziness: 4.2%(2/48) vs 2.2%(1/46) Dry Mouth: 6.3%(3/48) vs 2.2%(1/46) Headache: 6.3%(3/48) vs 6.5%(3/46) Increase 1.0 BMI Point (Approx 6 lbs): 41.7%(20/48) vs 23.9%(11/46) Increased Appetite: 12.5%(6/48) vs 4.3%(2/46) Increased Perspiration: 2.1%(1/48) vs 2.2%(1/46) Nausea Or Vomiting: 4.2%(2/48) vs 4.3%(2/46) Nervousness: 14.6%(7/48) vs 6.5%(3/46) Palpitations: 0.0%(0/48) vs 0.0%(0/46) Sexual Difficulties: 6.3%(3/48) vs 6.5%(3/46) Skin Rash: 0.0%(0/48) vs 0.0%(0/46) Tiredness, Fatigue: 18.8%(9/48) vs 13.0%(6/46) Tremor: 0.0%(0/48) vs 0.0%(0/46) Withdrawals: Quetiapine vs Risperidone Withdrawals:70.8%(34/48) vs 69.6%(32/46) Withdrawals Due To Adverse Events:0.0%(0/48) vs 0.0%(0/46)
Akerele et al. 2007^247^ Substance abuse Olanzapine, Risperidone Location: US Trial: Not reported Funding source: Government, Industry, Private Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 36 Sex: 80-99% Male Race: Caucasian, African Ancestry, Hispanic Screened: 76 Eligible: 29 Entering: 28 Withdrawn: 12 Lost to follow-up: 0 Analyzed: 16 Method of AE assessment: Monitored | Inclusion criteria: Diagnosis of schizophrenia or schizoaffective disorder, current cocaine and/or marijuana abuse/dependence, were using marijuana at least twice per week or cocaine at least once per week Exclusion criteria: Physiologically dependent on alcohol or other drugs, had unstable psychiatric symptomatology, unstable medical condition, enzyme function test greater than three times the upper limit of normal. A history of seizures/ neuroleptic malignant syndrome, not responded to either olanzapine or risperidone. Positive and negative symptom scale > 30. Interventions: Olanzapine 5-20 mg/days fixed titration schedule for 12 weeks vs Risperidone 3-9 mg/days fixed titration schedule for 12 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 21, 28, 35, 42, 49, 56, 63, 70 days | Results: Substance Abuse: Insufficient data to calculate an effect size Adverse Events: Olanzapine vs Risperidone Sedation: 57.1%(8/14) vs 78.6%(11/14) Worsening Of Abnormal Movements: 0.0%(0/14) vs 7.1%(1/14) Withdrawals: Olanzapine vs Risperidone Admitted To Inpatient Detox Unit Leading To Withdrawal:0.0%(0/14) vs 7.1%(1/14) Admitted To Inpatient Psych Unit Leading To Withdrawal:7.1%(1/14) vs 0.0%(0/14) Withdrawals:57.1%(8/14) vs 28.6%(4/14) Withdrawals Due To Adverse Events:0.0%(0/14) vs 0.0%(0/14)

AE=Adverse Event, NR=Not Reported

Quality of Head-to-Head Trials

Study | Treatment allocation | Groups similar at baseline? | Blinding | Dropouts | Other sources of potential bias
Rainer et al. 2007^142^ Dementia/Agitation Quetiapine, Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Single blind, outcome assessment If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Yes Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Sultzer et al. 2008^119^ Dementia/Agitation Olanzapine, Quetiapine, Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Single blind, patient If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? No Was the care provider masked? No Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Maina et al. 2008^195^ OCD Olanzapine, Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Single blind, outcome assessment If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Matsunaga et al. 2009^198^ OCD Olanzapine, Quetiapine, Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Not described If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Don't know Was the care provider masked? Don't know Were patients masked? Don't know | Was the dropout rate described and the reason given? Don't know Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Nejtek et al. 2008^250^ Substance abuse Quetiapine, Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Akerele et al. 2007^247^ Substance abuse Olanzapine, Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes

AE= Adverse Event, NR=Not Reported

Active-Controlled Trials

Citation and Study Information | Eligibility, Interventions, Outcomes | Results, Adverse Events, and Withdrawals
Correia Filho et al. 2005^78^ ADHD Risperidone Location: Latin America Trial: Not reported Funding source: Hospital, Industry Design: RCT only Setting: Not reported Jadad: 3 Age: Not reported Sex: Mixed Race: African Ancestry, Other-NOS Screened: NR Eligible: NR Entering: 46 Withdrawn: 5 Lost to follow-up: 0 Analyzed: 41 Method of AE assessment: Monitored | Inclusion criteria: 6-16, MMR and ADHD, good health Exclusion criteria: PDD, schizophrenia or other psychotic disorder, seizure disorder requiring meds, history of head injury, previous treatment with MPH or risperidone, use of any other psych meds 1 month prior Interventions: MPH dosage not reported for 4 weeks vs Risperidone 0.5-4 mg/days flexible dose for 4 weeks Run-in/wash-out period: Not reported Comorbidities: Anxiety, Depression Timing of outcome assessment: 7, 14, 21, 28 days | Results: ADHD: Change in SNAP-IV Total Score (Total Score) at 4 weeks: Risperidone vs Methylphenidate - WMD = -6.00 ( 14.75 , 2.75 ) ADHD: Change in SNAP-IV Inattention (Inattention) at 4 weeks: Risperidone vs Methylphenidate - WMD = 1.20 ( -1.91 , 4.31 ) ADHD: Change in SNAP-IV Hyperactivity (Hyperactivity) at 4 weeks: Risperidone vs Methylphenidate - WMD = -3.60 ( -6.89 , -0.31 ) ADHD: Change in SNAP-IV OCD (OCD) at 4 weeks: Risperidone vs Methylphenidate - WMD = -1.80 ( -5.02 , 1.42 ) Adverse Events: Methylphenidate Significant Difference Detected Between Baseline And End Point Scores In The SERs Total Scores: 0.0%(0/24) Risperidone Significant Difference Detected Between Baseline And End Point Scores On Any UKU Subscale Scores: 0.0%(0/22) Withdrawals: Methylphenidate vs Risperidone Galactorrhea (Led To withdrawal):0.0%(0/24) vs 4.5%(1/22) Vomiting (Led To withdrawal):4.2%(1/24) vs 0.0%(0/22) Withdrawals:8.3%(2/24) vs 13.6%(3/22) Withdrawals Due To Adverse Events:4.2%(1/24) vs 4.5%(1/22)
Prosser et al. 2009^96^ Anxiety Risperidone Location: US Trial: Not reported Funding source: Government Design: RCT only Setting: Multi-center Jadad: 3 Age: Not reported Sex: Mixed Race: Not reported Screened: NR Eligible: NR Entering: 56 Withdrawn: NR Lost to follow-up: NR Analyzed: 29 Method of AE assessment: Not reported | Inclusion criteria: 21-55, history of panic attacks, disorder with panic attacks, HAM-A >=17 Exclusion criteria: Other Axis I, history of alcohol and substance abuse 6 month prior, use of antipsychotics 2 month prior, changes in antidepressant or mood stabilizer 2 month prior, other psychoactive meds, a history of adverse reaction to either risperidone or paroxetine Interventions: Paroxetine 30-40 mg/days flexible dose for 8 weeks vs Risperidone 0.125-1 mg/days flexible dose for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 3, 7, 14, 21, 28, 35, 42, 49, 56, 63 days | Results: Anxiety: Change in HAM-D-17 at 8 weeks: Risperidone vs Paroxetine - WMD = 0.65 ( -4.73 , 6.03 ) Adverse Events: Paroxetine vs Risperidone Complained Of Adverse Events: 4.3%(1/23) vs 6.1%(2/33) Withdrawals: Paroxetine vs Risperidone Withdrawals:60.9%(14/23) vs 39.4%(13/33)
Moretti et al. 2005^132^ Dementia/Agitation Olanzapine Location: Western Europe Trial: Not reported Funding source: Not reported Design: CCT only Setting: Long-term care facilities Jadad: 0 Age: Not reported Sex: Mixed Race: Not reported Screened: NR Eligible: 356 Entering: 346 Withdrawn: NR Lost to follow-up: 0 Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: MMSE at least 14 and DSM-IV for dementia. Probable VaD in accordance with the NINDS-AIREN 71-92 Exclusion criteria: Normal pressure hydrocephalus. Previous psychiatric illness on central nervous system. Disorders and alcoholism Interventions: Typical antipsychotics 10 drops/day flexible dose for 12 months vs Olanzapine 2.5-7.5 mg/days flexible dose for 12 months Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 30, 91, 182, 274, 365 days | Results: Dementia: Change in NPI total (Total) at 52 weeks: Haloperidol or promazine (typical neuroleptic) vs Olanzapine flexible dose - SMD = 0.38 ( 0.17 , 0.60 ) Adverse Events: Typical neuroleptics (Group B) vs Olanzapine (Group A) Anger Episodes: 2.3%(4/173) vs 0.0%(0/173) Angina Pectoris Episode (Never Reported Before): 0.0%(0/173) vs 2.9%(5/173) Death From Complications Of A Thigh Bone Fracture Consequence Of A Fall: 0.6%(1/173) vs 0.0%(0/173) Death From Complications Of Pneumonia: 0.0%(0/173) vs 0.6%(1/173) Death From Myocardial Infarction: 0.6%(1/173) vs 0.6%(1/173) Death From Pulmonary Embolism (Had Suffered From Atrial Fibrillation): 0.6%(1/173) vs 0.0%(0/173) Diagnosed With Diabetes: 1.2%(2/173) vs 1.2%(2/173) Fall: 7.5%(13/173) vs 0.6%(1/173) Hospitalized For Myocardial Infarction: 1.2%(2/173) vs 0.0%(0/173) Inhalation Pneumonia: 1.7%(3/173) vs 0.0%(0/173) Nausea Associated With Anorexia: 19.7%(34/173) vs 0.0%(0/173) Oral Craving With A Weight Increase: 0.0%(0/173) vs 9.2%(16/173) Peripheral Arteriopathy: 0.0%(0/173) vs 0.6%(1/173) Renal Failure: 0.0%(0/173) vs 0.6%(1/173) Total Deaths: 1.7%(3/173) vs 1.2%(2/173) Transitory Sleepiness During Titration Phase: 24.9%(43/173) vs 23.1%(40/173) Weight Increase: 6.9%(12/173) vs 0.0%(0/173) Withdrawals: Typical neuroleptics (Group B) vs Olanzapine (Group A) Withdrawals:0.0%(0/173) vs 0.0%(0/173) Withdrawals Due To Adverse Events:0.0%(0/173) vs 0.0%(0/173)
Savaskan et al. 2006^133^ Dementia/Agitation Quetiapine Location: Western Europe Trial: Not reported Funding source: Government, Industry Design: RCT only Setting: Single setting, Inpatients, Hospitalized Jadad: 2 Age: Mean: 68 Sex: Mixed Race: Not reported Screened: NR Eligible: NR Entering: NR Withdrawn: 8 Lost to follow-up: 0 Analyzed: 22 Method of AE assessment: Not reported | Inclusion criteria: AD, behavioral symptoms > 65 Exclusion criteria: Sensitivity to study drugs, medical illness, other antipsychotic Interventions: Haldol 0.5-4 mg/days fixed titration schedule for 5 weeks vs Quetiapine 25-200 mg/days fixed titration schedule for 5 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 35 days | Results: Dementia: Change in NPI agitation (Agitation) at 5 weeks: Haloperidol vs Quetiapine - SMD = 0.06 ( -0.78 , 0.89 ) Dementia: Change in NPI total (Total) at 5 weeks: Haloperidol vs Quetiapine - SMD = 0.99 ( 0.10 , 1.88 ) Adverse Events: Haloperidol vs Quetiapine Arterial Hypertonia: 9.1%(1/11) vs 0.0%(0/11) EPS: 18.2%(2/11) vs 0.0%(0/11) Gastroenteritis: 0.0%(0/11) vs 9.1%(1/11) Infection Of Unknown Orgin: 9.1%(1/11) vs 0.0%(0/11) Reversible Syncope: 0.0%(0/11) vs 9.1%(1/11) Withdrawals: Haloperidol vs Quetiapine Withdrawals Due To Adverse Events:18.2%(2/11) vs 18.2%(2/11)
Pollock et al. 2007^135^ Dementia/Agitation Risperidone Location: Canada Trial: Not reported Funding source: Government, Private Design: RCT only Setting: Single setting Jadad: 5 Age: Not reported Sex: Mixed Race: Caucasian, Other-NOS Screened: 111 Eligible: 106 Entering: 103 Withdrawn: 58 Lost to follow-up: 0 Analyzed: 45 Method of AE assessment: Monitored | Inclusion criteria: AD, vascular dementia, dementia with Lewy bodies, mixed dementia or dementia not otherwise specified, need for hospitalization, >= 3 on agitation items and on psychosis items of NBRS Exclusion criteria: Schizophrenia, schizoaffective, delusional disorder, psychotic disorder, MR, cognitive deficits, delirium, Parkinson disease, substance dependence / abuse, MDD 6 month prior, >= 12 month CSDD, unstable physical illness, history of intolerance to citalopram or risperidone Interventions: Citalopram 10-40 mg/days flexible dose for 12 weeks vs Risperidone 0.5-2 mg/days flexible dose for 12 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 3 days | Results: Dementia: Change in NBRS psy (Psychosis) at 12 weeks: Citalopram vs Risperidone - SMD = 0.06 ( -0.33 , 0.44 ) Dementia: Change in NBRS ag (Agitation) at 12 weeks: Citalopram vs Risperidone - SMD = -0.11 ( -0.50 , 0.28 ) Withdrawals: Citalopram vs Risperidone Bruising Leading To Withdrawal:1.9%(1/53) vs 0.0%(0/50) Elevated Liver Function Tests Leading To Withdrawal:0.0%(0/53) vs 2.0%(1/50) Gait Disturbance Leading To Withdrawal:1.9%(1/53) vs 6.0%(3/50) Gastrointestinal Bleeding Leading To Withdrawal:0.0%(0/53) vs 2.0%(1/50) Hypoglycemia Leading To Withdrawal:1.9%(1/53) vs 0.0%(0/50) Hypotension Leading To Withdrawal:0.0%(0/53) vs 2.0%(1/50) Ileus Leading To Withdrawal:1.9%(1/53) vs 2.0%(1/50) Infection Leading To Withdrawal:3.8%(2/53) vs 0.0%(0/50) Intracranial Bleeding Leading To Withdrawal:0.0%(0/53) vs 2.0%(1/50) Other Extrapyramidal Symptoms (EPS) Leading To Withdrawal (Other Than Gait Disturbance):1.9%(1/53) vs 6.0%(3/50) Pneumonia Leading To Withdrawal:0.0%(0/53) vs 4.0%(2/50) Psychiatric Worsening: Increased Agitation Leading To Withdrawal:22.6%(12/53) vs 14.0%(7/50) Psychiatric Worsening: Onset Of Depression Leading To Withdrawal:1.9%(1/53) vs 0.0%(0/50) Psychiatric Worsening: Onset Of Psychosis Leading To Withdrawal:1.9%(1/53) vs 2.0%(1/50) Psychiatric Worsening: Readmission Leading To Withdrawal:3.8%(2/53) vs 6.0%(3/50) Psychiatric Worsening: Suicide Attempt Leading To Withdrawal:0.0%(0/53) vs 2.0%(1/50) Sedation Leading To Withdrawal:1.9%(1/53) vs 0.0%(0/50) Seizure Leading To Withdrawal:1.9%(1/53) vs 0.0%(0/50) Withdrawals:52.8%(28/53) vs 60.0%(30/50) Withdrawals Due To Adverse Events:7.5%(4/53) vs 18.0%(9/50)
Tariot et al. 2006^124^ Dementia/Agitation Quetiapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center, Long-term care facilities Jadad: 4 Age: Mean: 83 Sex: Mixed Race: Caucasian, Other-NOS Screened: 501 Eligible: 284 Entering: 284 Withdrawn: 103 Lost to follow-up: 1 Analyzed: 180 Method of AE assessment: Monitored | Inclusion criteria: > 64 years old, not bedridden, nursing home residents for >= 2 weeks, diagnosed with DSM-IV AD, presence of psychosis, BPRS scores >=24, CGI-S scores >=4, scores of >= 3 on two or more BPRS items, frequency scores of >= 3 on at least one of the two psychosis items of the NPI-NH, scores of >= 5 on MMSE Exclusion criteria: Other clinically significant medical conditions, history of drug-induced agranulocytosis, acute orthostasis, clinically significant abnormal electrocardiogram, or concurrent other Axis I DSM-IV diagnosis. Interventions: Placebo for 10 weeks vs Haloperidol 0.5-12 mg/days flexible dose for 10 weeks vs Quetiapine 25-600 mg/days flexible dose for 10 weeks Run-in/wash-out period: Wash-out: No drug for 48 hour(s). Patients still eligible after washout were randomized. Comorbidities: None Timing of outcome assessment: 14, 28, 42, 56, 70 days | Results: Dementia: Change in NPI agitation (Agitation) at 10 weeks: Placebo vs Quetiapine - SMD = 0.25 ( -0.05 , 0.54 ) Dementia: Change in NPI agitation (Agitation) at 10 weeks: Haloperidol vs Quetiapine - SMD = 0.04 ( -0.26 , 0.34 ) Dementia: Change in NPI total (Total) at 10 weeks: Placebo vs Quetiapine - SMD = 0.01 ( -0.29 , 0.30) Dementia: Change in NPI total (Total) at 10 weeks: Haloperidol vs Quetiapine - SMD = -0.31 ( -0.61 , -0.01) Adverse Events: Haloperidol vs Quetiapine vs Placebo Abnormal Gait: 10.6%(10/94) vs 3.3%(3/91) vs 3.0%(3/99) Accidental Injury Total: 45.7%(43/94) vs 40.7%(37/91) vs 42.4%(42/99) Agitation: 13.8%(13/94) vs 7.7%(7/91) vs 21.2%(21/99) Convulsion: 0.0%(0/94) vs 4.4%(4/91) vs 0.0%(0/99) Deaths: 7.4%(7/94) vs 2.2%(2/91) vs 4.0%(4/99) Dyspepsia: 4.3%(4/94) vs 0.0%(0/91) vs 4.0%(4/99) Falls: 28.7%(27/94) vs 28.6%(26/91) vs 28.3%(28/99) Fever: 11.7%(11/94) vs 3.3%(3/91) vs 6.1%(6/99) Fractures: 6.4%(6/94) vs 2.2%(2/91) vs 7.1%(7/99) Infection: 5.3%(5/94) vs 14.3%(13/91) vs 5.1%(5/99) Insomnia: 5.3%(5/94) vs 0.0%(0/91) vs 1.0%(1/99) Nonserious Cerebrovascular Event: 0.0%(0/94) vs 1.1%(1/91) vs 3.0%(3/99) Pain: 9.6%(9/94) vs 13.2%(12/91) vs 11.1%(11/99) Pallor: 4.3%(4/94) vs 0.0%(0/91) vs 0.0%(0/99) Pharyngitis: 4.3%(4/94) vs 5.5%(5/91) vs 10.1%(10/99) Rash: 12.8%(12/94) vs 13.2%(12/91) vs 13.1%(13/99) Serious AEs: 16.0%(15/94) vs 11.0%(10/91) vs 12.1%(12/99) Somnolence, All: 36.2%(34/94) vs 25.3%(23/91) vs 4.0%(4/99) Somnolence, Serious: 1.1%(1/94) vs 1.1%(1/91) vs 0.0%(0/99) Urinary Incontinence: 4.3%(4/94) vs 4.4%(4/91) vs 0.0%(0/99) Urinary Tract Infection: 10.6%(10/94) vs 12.1%(11/91) vs 5.1%(5/99) Vomiting: 6.4%(6/94) vs 12.1%(11/91) vs 5.1%(5/99) Withdrawals: Haloperidol vs Quetiapine vs Placebo Somnolence Leading To Withdrawal:3.2%(3/94) vs 1.1%(1/91) vs 0.0%(0/99) Withdrawals:41.5%(39/94) vs 31.9%(29/91) vs 36.4%(36/99) Withdrawals Due To Adverse Events:18.1%(17/94) vs 11.0%(10/91) vs 13.1%(13/99)
Verhey et al. 2006^136^ Dementia/Agitation Olanzapine Location: Western Europe Trial: Not reported Funding source: Not reported Design: RCT only Setting: Multi-center, Long-term care facilities Jadad: 3 Age: Mean: 70 Sex: Mixed Race: Not reported Screened: NR Eligible: NR Entering: NR Withdrawn: 9 Lost to follow-up: 0 Analyzed: NR Method of AE assessment: Monitored, reported spontaneously by patient | Inclusion criteria: Age >= 60 years, diagnosis of dementia according to DSM-IV, agitation level requiring antipsychotic treatment, no use of antipsychotic treatment within 3 days of inclusion CMAI score >=45 Exclusion criteria: Delirium, neurological conditions that could contribute to psychosis or dementia. Interventions: Haloperidol 1-3 mg/days flexible dose for 5 weeks vs Olanzapine 2.5-7.5 mg/days flexible dose for 5 weeks Run-in/wash-out period: Wash-out: No drug for 3-11 day(s). Patients still eligible after washout were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 21, 35 days | Results: Dementia: Change in CMAI (Agitation) at 5 weeks: Haloperidol vs Olanzapine - SMD = -0.21 ( -0.73 , 0.31 ) Dementia: Change in NPI psy (Psychosis) at 5 weeks: Haloperidol vs Olanzapine - SMD = -0.03 ( -0.57 , 0.50 ) Dementia: Change in NPI total (Total) at 5 weeks: Haloperidol vs Olanzapine - SMD = -0.18 ( -0.77 , 0.41 ) Adverse Events: Haloperidol vs Olanzapine Accommodation Disturbances: 25.0%(7/28) vs 10.0%(3/30) Akathisia: 21.4%(6/28) vs 13.3%(4/30) Asthenia/Lassitude/Fatigue: 78.6%(22/28) vs 60.0%(18/30) Changes Of Sexual Functions: 10.7%(3/28) vs 13.3%(4/30) Concentration Difficulties: 75.0%(21/28) vs 80.0%(24/30) Constipation: 32.1%(9/28) vs 20.0%(6/30) Depression: 71.4%(20/28) vs 56.7%(17/30) Diarrhea: 17.9%(5/28) vs 26.7%(8/30) Dystonia: 14.3%(4/28) vs 13.3%(4/30) Emotional Indifference: 57.1%(16/28) vs 33.3%(10/30) Failing Memory: 100.0%(28/28) vs 96.7%(29/30) Headache: 32.1%(9/28) vs 23.3%(7/30) Hyperkinesia: 14.3%(4/28) vs 20.0%(6/30) Hypokinesia/akinesia: 35.7%(10/28) vs 30.0%(9/30) Increased Dream Activity: 7.1%(2/28) vs 13.3%(4/30) Increased Duration Of Sleep: 42.9%(12/28) vs 63.3%(19/30) Increased Salivation: 25.0%(7/28) vs 13.3%(4/30) Increased Tendency To Sweating: 14.3%(4/28) vs 16.7%(5/30) Micturition Disturbances: 25.0%(7/28) vs 20.0%(6/30) Nausea/Vomiting: 28.6%(8/28) vs 23.3%(7/30) Orthostatic Dizziness: 28.6%(8/28) vs 16.7%(5/30) Palpitations/Tachycardia: 3.6%(1/28) vs 10.0%(3/30) Paraesthesias: 7.1%(2/28) vs 6.7%(2/30) Polyuria/Polydipsia: 17.9%(5/28) vs 16.7%(5/30) Pruritus: 21.4%(6/28) vs 10.0%(3/30) Rash: 21.4%(6/28) vs 13.3%(4/30) Reduced Duration Of Sleep: 32.1%(9/28) vs 36.7%(11/30) Reduced Salivation: 14.3%(4/28) vs 10.0%(3/30) Rigidity: 46.4%(13/28) vs 30.0%(9/30) Sleepiness/Sedation: 78.6%(22/28) vs 60.0%(18/30) Tension/Inner Unrest: 82.1%(23/28) vs 80.0%(24/30) Tremor: 25.0%(7/28) vs 26.7%(8/30) Weight Gain: 25.0%(7/28) vs 20.0%(6/30) Weight Loss: 10.7%(3/28) vs 13.3%(4/30) Withdrawals: Haloperidol vs Olanzapine Withdrawals:0.0%(0/28) vs 10.0%(3/30)
Holmes et al. 2007^137^ Dementia/Agitation Risperidone Location: Not reported Trial: Not reported Funding source: Not reported Design: RCT only Setting: Long-term care facilities Jadad: 3 Age: Not reported Sex: Mixed Race: Not reported Screened: 70 Eligible: 28 Entering: 27 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: Severe probable AD, MMSE <6, NINCDS-ADRDA and CMAI >3 p for at least 6 weeks, nursing home Exclusion criteria: Previous exposure at a cholinesterase inhibitor or had ever received psychotropic drugs of greater than 20mg thioridazine (or its equivalent). Interventions: Other, Rivastigmine 3-6 mg/days fixed titration schedule for 6 weeks vs Risperidone 0.5 mg/days fixed titration schedule for 6 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 14, 28, 42 days | Results: Dementia: Change in CMAI (Agitation) at 6 weeks: Rivastigmine vs Risperidone - SMD = 1.31 ( 0.47 , 2.15 ) Adverse Events: Risperidone vs Rivastigmine Any Adverse Event: 33.3%(4/12) vs 60.0%(9/15) Cellulitis: 8.3%(1/12) vs 0.0%(0/15) Chest Infection: 8.3%(1/12) vs 6.7%(1/15) Constipation: 8.3%(1/12) vs 6.7%(1/15) Nausea And Vomiting: 0.0%(0/12) vs 20.0%(3/15) Persistent Agitation: 8.3%(1/12) vs 20.0%(3/15) Skin Rash: 0.0%(0/12) vs 6.7%(1/15) Transient Ischemic Attack: 8.3%(1/12) vs 0.0%(0/15)
Mowla et al. 2010^138^ Dementia/Agitation Risperidone Location: Middle East Trial: Not reported Funding source: Not reported Design: RCT only Setting: Multi-center Jadad: 5 Age: Not reported Sex: Mixed Race: Not reported Screened: NR Eligible: NR Entering: 48 Withdrawn: 7 Lost to follow-up: 0 Analyzed: 41 Method of AE assessment: Elicited by investigator | Inclusion criteria: AD per DSM-IV of mild to moderate severity, behavioral disturbance, NPI part 1 > 1 in subitems related to delusions, hallucinations, agitation / aggression and irritability / liability. Exclusion criteria: Dementia of other etiology, organic disease, other psychiatric disorders, medication in past 4 weeks. Interventions: Other, 32 (Topiramate) 44.04 mg/days flexible dose for 8 weeks vs Risperidone 1.9 mg/days flexible dose for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 14, 28, 42, 56 days | Results: Dementia: Change in NPI total (Total) at 8 weeks: Topiramate vs Risperidone - SMD = 0.23 ( -0.38 , 0.85 ) Dementia: Change in CMAI (Agitation) at 8 weeks: Topiramate vs Risperidone - SMD = 0.06 ( -0.56 , 0.67 )
Doree et al. 2007^175^ Depression Quetiapine Location: Canada Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 2 Age: Not reported Sex: Mixed Race: Not reported Screened: NR Eligible: NR Entering: 20 Withdrawn: 3 Lost to follow-up: 0 Analyzed: 17 Method of AE assessment: Monitored | Inclusion criteria: 18 - 65, MDD without psychotic features, HAMD >= 20, CGI >= 4 despite antidepressants at max dose + >=4 weeks Exclusion criteria: Bipolar or other Axis I, substance dependence within 6 months, unstable medical condition Interventions: Lithium 600-vario mg/days flexible dose for 8 weeks vs Quetiapine 25-600 mg/days flexible dose for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 28, 42, 56 days | Results: Depression: Change in MADRS at 8 weeks: Quetiapine vs Lithium - WMD = -10.90 ( -16.47 , -5.33 ) Adverse Events: Lithium Tremor: 60.0%(6/10) Quetiapine Somnolence: 50.0%(5/10) Quetiapine vs Lithium Serious Adverse Event: 0.0%(0/10) vs 0.0%(0/10) Withdrawals: Quetiapine vs Lithium Mixed State Resulting In Withdrawal:0.0%(0/10) vs 10.0%(1/10) Tremor And Nausea Resulting In Withdrawal:0.0%(0/10) vs 10.0%(1/10) Withdrawals:0.0%(0/10) vs 30.0%(3/10) Withdrawals Due To Adverse Events:0.0%(0/10) vs 20.0%(2/10)
Hussain et al. 2005^177^ Depression Quetiapine Location: Canada Trial: Not reported Funding source: Not reported Design: RCT only Setting: Not reported Jadad: 1 Age: Not reported Sex: Race: NR Screened: NR Eligible: NR Entering: NR Withdrawn: 18 Lost to follow-up: 0 Analyzed: NR Method of AE assessment: NR | Inclusion criteria: Diagnosed with MDD using DSM-IV criteria Exclusion criteria: Not reported Interventions: Paroxetine dosage not reported for duration not reported vs Venlafaxine dosage not reported for duration not reported vs Quetiapine, Paroxetine dosage not reported for duration not reported vs Quetiapine, Venlafaxine dosage not reported for duration not reported Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 21, 42, 84, 182, 365, 730, 1094 days | Results: Depression: Insufficient data to calculate an effect size
Mondraty et al. 2005^181^ Eating disorder Olanzapine Location: Australia/New Zealand Trial: Not reported Funding source: Not reported Design: RCT only Setting: Single setting Jadad: 3 Age: Mean: 25 Sex: Race: Not reported Screened: 26 Eligible: 15 Entering: 15 Withdrawn: 0 Lost to follow-up: 0 Analyzed: 15 Method of AE assessment: Not reported | Inclusion criteria: Fulfilling DSM-IV criteria for anorexia nervosa Exclusion criteria: Not reported Interventions: Chlorpromazine 25-100 mg/days flexible dose for duration not reported vs Olanzapine 5-15 mg/days flexible dose for variable duration Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 46 days | Results: Eating Disorder: Change in BMI at 2 weeks: Olanzapine vs Chlorpromazine - WMD = 0.50 ( -1.49 , 2.49 ) Adverse Events: Chlorpromazine vs Olanzapine Blurring Of Vision And Postural Hypotension: 14.3%(1/7) vs 0.0%(0/8) Sedation: 42.9%(3/7) vs 12.5%(1/8)
Diniz et al. 2009^200^ OCD Quetiapine Location: Brazil Trial: Not reported Funding source: Government Design: RCT only Setting: Single setting Jadad: 2 Age: Mean: 20 Sex: Mixed Race: Not reported Screened: 48 Eligible: 35 Entering: 31 Withdrawn: 13 Lost to follow-up: NR Analyzed: 18 Method of AE assessment: Monitored | Inclusion criteria: 18-65, OCD, treatment failure to SSRI Exclusion criteria: Substance dependence or abuse, psychosis, suicide risk, pregnant / intending to become pregnant Interventions: Clomipramine 25-75 mg/days flexible dose for 12 weeks vs Quetiapine 50-200 mg/days flexible dose for 12 weeks Run-in/wash-out period: Run-in: Fluoxetine for 12 week(s). Non-responders were randomized. Comorbidities: None Timing of outcome assessment: 28, 56, 84 days | Results: OCD: Change in YBOCS (Total Score) at 12 weeks: Quetiapine vs Clomipramine - WMD = -3.60 ( 9.27 , 2.07 ) Adverse Events: Clomipramine vs Quetiapine Severe Adverse Events: 0.0%(0/15) vs 0.0%(0/16) Quetiapine 3 Symptoms Of Serotonergic Syndrome (Excessive Sweating, Tremors And Motor Agitation) Leading To Being Dropped: 0.0%(0/16) Withdrawals: Clomipramine 3 Symptoms Of Serotonergic Syndrome (Excessive Sweating, Tremors And Motor Agitation) Leading To Withdrawal:6.7%(1/15) Clomipramine vs Quetiapine Withdrawals:40.0%(6/15) vs 43.8%(7/16) Withdrawals Due To Adverse Events:40.0%(6/15) vs 43.8%(7/16)
Shafti et al. 2010^225^ Personality disorder Olanzapine Location: Middle East Trial: Not reported Funding source: Not reported Design: RCT only Setting: Not reported Jadad: 4 Age: Mean: 30 Sex: 100% Female Race: Not reported Screened: NR Eligible: NR Entering: 28 Withdrawn: 0 Lost to follow-up: 0 Analyzed: 28 Method of AE assessment: Monitored | Inclusion criteria: BPD per DSM-IV-TR Exclusion criteria: Prominent comorbid mental disorder Interventions: Other, Haldol 6.83 mg/days flexible dose for 8 weeks vs Olanzapine 7.08 mg/days flexible dose for 8 weeks Run-in/wash-out period: Wash-out: Psychotropics for 7 day(s) were randomized. Comorbidities: None Timing of outcome assessment: 56 days | Results: Personality Disorder: Change in BDHI at 8 weeks: Olanzapine vs Haliperidol - WMD = -3.79 ( -11.51 , 3.93 ) Personality Disorder: Change in BPRS at 8 weeks: Olanzapine vs Haliperidol - WMD = 5.31 ( -11.31 , 9.51 ) Personality Disorder: Change in CGI-S at 8 weeks: Olanzapine vs Haliperidol - WMD = 0.41 ( -0.97 , 0.65 ) Adverse Events: Haloperidol vs Olanzapine Extrapyramidal Symptoms Not Resulting In Prescription Of Anticholinergics: 0.0%(0/14) vs 14.3%(2/14) Extrapyramidal Symptoms Resulting In Prescription Of Anticholinergics: 50.0%(7/14) vs 0.0%(0/14) Tremor, Parkinsonism, And Akathisia: 57.1%(8/14) vs 0.0%(0/14) Weight Gain, Somnolence, Dizziness And Tremor: 0.0%(0/14) vs 42.9%(6/14) Withdrawals: Haloperidol vs Olanzapine Withdrawals:0.0%(0/14) vs 0.0%(0/14) Withdrawals Due To Adverse Events:0.0%(0/14) vs 0.0%(0/14)
Rubio et al. 2006^242^ Substance abuse Risperidone Location: Western Europe Trial: Not reported Funding source: Unclear Design: RCT only Setting: Multi-center Jadad: 2 Age: Not reported Sex: 100% Male Race: Not reported Screened: 124 Eligible: NR Entering: 66 Withdrawn: 4 Lost to follow-up: 0 Analyzed: 62 Method of AE assessment: Monitored | Inclusion criteria: Male, 18-65, schizophrenia and SUD for substances other than caffeine and nicotine. Exclusion criteria: Organic or neurological disorder, other psychotic disorder, abnormal labs on ECG Interventions: Other, Zuclopenthixol 10-100 mg/days frequency not reported for 6 months vs Risperidone 3-12 mg/days frequency not reported for 6 months Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42 days | Results: Substance Abuse: Cross over study
Gerra et al. 2006^273^ Substance abuse Olanzapine Location: Western Europe Trial: Not reported Funding source: Government, Professional association Design: CCT only Setting: Multi-center Jadad: 1 Age: Not reported Sex: 80-99% Male Race: Not reported Screened: NR Eligible: 67 Entering: 67 Withdrawn: 34 Lost to follow-up: 0 Analyzed: 33 Method of AE assessment: Not reported | Inclusion criteria: Heroin dependent patients entering methadone and buprenorphine, aggressive personality traits. Exclusion criteria: > 3 month of drugs other than heroin or > 6 month alcohol dependent, severe chronic liver illness, renal diseases, other chronic medical disorders, recent significant weight loss, obesity, endocrinotherapy, immune deficiency. A comorbidity of schizophrenia or bipolar disorder > 60 BDHI. Interventions: SRI and Antidepressant Fluoxetine mean 25.26 (SD 5.9); Paroxetine mean 22.5 (SD 6.8); Clonazepam mean 5.15 (SD 1.67) for 12 weeks vs Olanzapine mean 12.1 (SD 5.4) for 12 weeks Run-in/wash-out period: Not reported Comorbidities: OCD, Personality Disorder Timing of outcome assessment: 84 days | Results: Substance Abuse: Change in BDHI at 12 weeks: Olanzapine+Methadone/Buprenorphine vs SSRIs+Clonazepam+Methadone/Buprenerphine - WMD = -10.26 ( -11.00 , -9.52 ) Adverse Events: Fluoxetine/paroxetine and clonazepam vs Olanzapine Overt BDZs Abuse With Severe Sedation And Paradoxical Symptoms That Contributed To Drop-Out: 11.4%(4/35) vs 0.0%(0/32) Paradoxical Effects With Agitation, Increased Irritability, Negativism And The Tendency To Clonazepam Abuse: 20.0%(7/35) vs 0.0%(0/32) Significant Changes Of Glucose Plasma Levels: 0.0%(0/35) vs 0.0%(0/32) Olanzapine Weight Gain =7%: 12.5%(4/32) Withdrawals: Fluoxetine/paroxetine and clonazepam vs Olanzapine Withdrawals:45.7%(16/35) vs 46.9%(15/32)
Gerra et al. 2007^248^ Substance abuse Olanzapine Location: Western Europe Trial: Not reported Funding source: Not reported Design: CCT only Setting: Multi-center Jadad: 1 Age: Not reported Sex: 80-99% Male Race: Not reported Screened: NR Eligible: 61 Entering: 61 Withdrawn: 16 Lost to follow-up: 8 Analyzed: 35 Method of AE assessment: Not reported | Inclusion criteria: Heroin dependent, entering methadone and buprenorphine long-term treatment, SSDS (schizophrenia spectrum disorder) treated with olanzapine or haloperidol. Exclusion criteria: Long lasting period of consumption of drugs, other than heroin (3 months) or prolonged alcohol dependence (6 months), severe chronic liver illness, renal disease, other medial chronic disorders, recent significant weight loss / obesity endocrine and immune deficiency. Interventions: Haloperidol dosage not reported for 12 weeks vs Olanzapine dosage not reported for 12 weeks Run-in/wash-out period: Not reported Comorbidities: OCD, Personality Disorder Timing of outcome assessment: 84 days | Results: Substance Abuse: Change in Retention Rate at 12 weeks: olanzapine vs Haloperidol - RR = 2.72 ( 0.84 , 8.79 ) Adverse Events: Haloperidol vs Olanzapine Anticholinergic Drugs Prescribed To Treat This Many Pts With Extrapyramidal Symptoms: 15.4%(4/26) vs 0.0%(0/35) Extrapyramidal Symptoms (Akathisia, Dystonia, And Tardive Dyskinesia With Restlessness And Objective Motor Signs, Difficulty In Opening The Eyelids, Torticollis, And Oculogyric Crisis): 26.9%(7/26) vs 0.0%(0/35) Persistent Sedation And Tiredness: 69.2%(18/26) vs 0.0%(0/35) Significant Changes Of Glucose Plasma Levels: 0.0%(0/26) vs 0.0%(0/35) Weight Gain =7%: 0.0%(0/26) vs 17.1%(6/35) Withdrawals: Haloperidol vs Olanzapine Withdrawals:50.0%(13/26) vs 8.6%(3/35)
Green et al. 2004^249^ Substance abuse Olanzapine Location: US, Canada, Western Europe Trial: Not reported Funding source: Government, Industry Design: RCT only Setting: Multi-center Jadad: 2 Age: Mean: 16 Sex: 80-99% Male Race: Not reported Screened: NR Eligible: 263 Entering: NR Withdrawn: NR Lost to follow-up: 1 Analyzed: 262 Method of AE assessment: Monitored | Inclusion criteria: Schizophrenia, schizoaffective, disorder / schizophreniform disorder according to DSM-IV SCID-IV > 2 items of >= 4 or one >= 5 and CGI >= 4 / PANSS Exclusion criteria: Psychotic longer than 5 years. Recovery from initial episode for 6 months or longer. Treated with an injectable depot neuroleptic within 3 month. PSM-IV substance dependence within 1 month. Interventions: Haldol 2-20 mg/days flexible dose for 12 weeks vs Olanzapine 5-20 mg/days flexible dose for 12 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 56, 70 days | Results: Substance Abuse: Not all patients had Substance Use Disorder,
Hutchison et al. 2003^255^ Substance abuse Olanzapine Location: US Trial: Not reported Funding source: Government Design: RCT only Setting: Single setting Jadad: 4 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry, Hispanic, Asian/Pacific Islander, Other-NOS Screened: NR Eligible: 75 Entering: NR Withdrawn: 8 Lost to follow-up: 0 Analyzed: 67 Method of AE assessment: Monitored | Inclusion criteria: Excellent health, blood alcohol of 0, Audit >= 8, alcohol dependence Exclusion criteria: Pregnant, psychiatric diagnosis on treatment, use of illicit drugs other than MS Interventions: Cyproheptadine 4 mg/days fixed single dose for 4 days vs Olanzapine 5 mg/days fixed single dose for 4 days Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 5 days | Results: Substance Abuse: Insufficient data to calculate an effect size
Martinotti et al. 2009^251^ Substance abuse Aripiprazole Location: Western Europe Trial: Not reported Funding source: Not reported Design: RCT only Setting: Single setting Jadad: 3 Age: Mean: 40 Sex: 80-99% Male Race: Not reported Screened: 112 Eligible: 57 Entering: 57 Withdrawn: 3 Lost to follow-up: 11 Analyzed: 43 Method of AE assessment: Monitored | Inclusion criteria: Alcohol use disorders >= 3 years, daily alcohol intake >= 6 units, alcohol dependence, declared commitment to the goal of total abstinence Exclusion criteria: Severe physical illness or mental disorders, regularly taking anticonvulsants, antidepressants or antipsychotics, pregnant, history of severe AE to aripiprazole or naltrexone, previous treated with ARI or NAL. Interventions: Naltrexone 10-50 mg/days fixed titration schedule for 16 weeks vs Aripiprazole 5-15 mg/days flexible dose for 16 weeks Run-in/wash-out period: Not reported Comorbidities: Anxiety, Personality Disorder, Substance Abuse, Eating Disorder Timing of outcome assessment: 14, 56, 112 days | Results: Substance Abuse: Change in Complete Abstinence (Alcohol) at 16 weeks: Aripiprazole vs Naltexone - RR = 1.05 ( 0.56 , 1.98 ) Substance Abuse: Change in Abstinent Days (Alcohol) at 16 weeks: Aripiprazole vs Naltexone - SMD = 0.13 ( -0.39 , 0.65 ) Adverse Events: Aripiprazole vs Naltrexone Akathisia: 6.9%(2/29) vs 0.0%(0/28) Confusion: 3.4%(1/29) vs 0.0%(0/28) Dizziness: 0.0%(0/29) vs 7.1%(2/28) Euphoria: 6.9%(2/29) vs 0.0%(0/28) Hypothension: 0.0%(0/29) vs 10.7%(3/28) Nausea And Vomiting: 10.3%(3/29) vs 21.4%(6/28) Withdrawals: Aripiprazole vs Naltrexone Withdrawals:75.9%(22/29) vs 75.0%(21/28) Withdrawals Due To Adverse Events:6.9%(2/29) vs 17.9%(5/28)
Rubio et al. 2006^243^ Substance abuse Risperidone Location: Western Europe Trial: Not reported Funding source: Design: RCT only Setting: Multi-center Jadad: 1 Age: Mean: 35 Sex: 80-99% Male Race: Not reported Screened: 183 Eligible: 115 Entering: 115 Withdrawn: NR Lost to follow-up: NR Analyzed: 106 Method of AE assessment: Monitored | Inclusion criteria: 18-65, schizophrenia and SUD for substances other than caffeine and nicotine, according to DSM-IV. Exclusion criteria: Clinically significant organic or neurologic disorder, serious psychotic disorder other than schizophrenia, clinically relevant abnormalities Interventions: Other, Zuclopenthixol 10-50 mg/days flexible dose for 6 weeks vs Risperidone 2-6 mg/days flexible dose for 6 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56, 63, 70, 77, 84, 91, 98, 105, 112, 119, 126, 133, 140, 147, 154, 161, 168 days | Results: Substance Abuse: Change in Number of Positive Uring Tests at 24 weeks: Risperidone vs Zuclopenthixol - WMD = 1.69 ( 0.58 , 2.80 )
Sayers et al. 2005^244^ Substance abuse Olanzapine Location: US Trial: Not reported Funding source: Government Design: RCT only Setting: Single setting, VA Healthcare System Jadad: 2 Age: Not reported Sex: 80-99% Male Race: Caucasian, African Ancestry Screened: 170 Eligible: 24 Entering: 24 Withdrawn: NR Lost to follow-up: NR Analyzed: 14 Method of AE assessment: Monitored | Inclusion criteria: Schizophrenia and cocaine abuse in last 6 month. 18-60 Exclusion criteria: Use of depot meds within 6 month, history of sensitization to haldol or olanzapine or history of NMS, pregnant, lactating, unstable medical problems Interventions: Haldol 5-20 mg/days flexible dose for 26 weeks vs Olanzapine 5-20 mg/days flexible dose for 26 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56, 63, 70, 77, 84, 91, 98, 105, 112, 119, 126, 133, 140, 147, 154, 161, 168 days | Results: Substance Abuse: Insufficient data to calculate an effect size Withdrawals: Haloperidol Withdrawals:41.7%(5/12)
Smelson et al. 2006^245^ Substance abuse Olanzapine Location: US Trial: Not reported Funding source: Government, Industry Design: RCT only Setting: VA Healthcare System Jadad: 3 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: NR Entering: 31 Withdrawn: NR Lost to follow-up: NR Analyzed: 18 Method of AE assessment: Not applicable | Inclusion criteria: Cocaine dependence and schizophrenia, positive change in baseline craving after cocaine cues Exclusion criteria: Other AXIS I disorders, taking other CNS (central nervous system) meds (medications), history of seizures, pregnant, chronic CNS disease other than schizophrenia Interventions: Haldol 5-20 mg/days flexible dose for 6 weeks vs Olanzapine 5-20 mg/days flexible dose for 6 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 42 days | Results: Substance Abuse: Change in Voris Cocaine Craving Questionnaire (Craving Intensity Scor at 6 weeks: Olanzapine vs Haloperidol - WMD = -6.30 ( -17.35 , 4.75 )
Tsuang et al. 2002^246^ Substance abuse Olanzapine Location: US Trial: Not reported Funding source: Industry Design: CCT only Setting: VA Healthcare System Jadad: 2 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: 4 Entering: 23 Withdrawn: 1 Lost to follow-up: 1 Analyzed: 3 Method of AE assessment: Not reported | Inclusion criteria: Cocaine abusing outpatient with schizophrenia Exclusion criteria: Interventions: Olanzapine 15-20 mg/days frequency not reported for duration not reported vs Haldol 5-10 mg/days frequency not reported for duration not reported Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: days | Results: Substance Abuse: Insufficient data to calculate an effect size Withdrawals: Haloperidol Withdrawals:100.0%(2/2)

AE=Adverse Event, NR=Not Reported

Quality of Active-Controlled Trials

Study | Treatment allocation | Groups similar at baseline? | Blinding | Dropouts | Other sources of potential bias
Correia Filho et al. 2005^78^ ADHD Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Single blind, not described If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Don't know Was the care provider masked? Don't know Were patients masked? Don't know | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Prosser et al. 2009^96^ Anxiety Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Single blind, outcome assessment If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Yes Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Moretti et al. 2005^132^ Dementia/Agitation Olanzapine | Was the study described as randomized? No Was the method of randomization adequate? No Was the treatment allocation concealed? No | Were groups similar at baseline? Yes | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? No Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Don't know Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Savaskan et al. 2006^133^ Dementia/Agitation Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? No Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Pollock et al. 2007^135^ Dementia/Agitation Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Yes | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Tariot et al. 2006^124^ Dementia/Agitation Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Verhey et al. 2006^136^ Dementia/Agitation Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Holmes et al. 2007^137^ Dementia/Agitation Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Yes | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Mowla et al. 2010^138^ Dementia/Agitation Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Doree et al. 2007^175^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? No Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Hussain et al. 2005^177^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Not described If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Don't know Was the care provider masked? Don't know Were patients masked? Don't know | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Mondraty et al. 2005^181^ Eating disorder Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? No Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Don't know
Diniz et al. 2009^200^ OCD Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? No Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Shafti et al. 2010^225^ Personality disorder Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Rubio et al. 2006^242^ Substance abuse Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Yes Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Gerra et al. 2006^273^ Substance abuse Olanzapine | Was the study described as randomized? No Was the method of randomization adequate? No Was the treatment allocation concealed? No | Were groups similar at baseline? Yes | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? No Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Gerra et al. 2007^248^ Substance abuse Olanzapine | Was the study described as randomized? No Was the method of randomization adequate? No Was the treatment allocation concealed? No | Were groups similar at baseline? Yes | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? No Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Green et al. 2004^249^ Substance abuse Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Hutchison et al. 2003^255^ Substance abuse Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Yes | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Martinotti et al. 2009^251^ Substance abuse Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Rubio et al. 2006^243^ Substance abuse Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? No Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Yes Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Sayers et al. 2005^244^ Substance abuse Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Smelson et al. 2006^245^ Substance abuse Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Tsuang et al. 2002^246^ Substance abuse Olanzapine | Was the study described as randomized? No Was the method of randomization adequate? No Was the treatment allocation concealed? No | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Don't know | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? No Was the outcome assessment timing similar in all groups? No

AE=Adverse Events, NR=Not Reported

Augmentation Trials

Citation and Study Information | Eligibility, Interventions, Outcomes | Results, Adverse Events, and Withdrawals
Zeni et al. 2009^80^ ADHD Aripiprazole Location: Latin America Trial: Not reported Funding source: Government, Hospital Design: RCT only Setting: Not reported Jadad: 2 Age: Mean: 8 Sex: Mixed Race: Caucasian, Other-NOS Screened: 710 Eligible: 16 Entering: 16 Withdrawn: 1 Lost to follow-up: 0 Analyzed: 15 Method of AE assessment: Monitored, elicited by investigator | Inclusion criteria: Age 8-17, diagnosed borderline personality disorder co-morbid ADHD >= 30% improvement in mood symptoms in the previous trial of ARI, SNAP-IV score >=1.5 Exclusion criteria: IQ < 70, use of medication besides ARI 10 weeks before entering study, pervasive developmental disorder, schizophrenia, substance abuse, suicidal, hypersensitive to ARI / MPH, pregnancy, acute or chronic disease Interventions: Aripiprazole 5-20 mg/days fixed single dose for 2 weeks vs Aripiprazole, Methylphenidate 5-20 mg/days fixed single dose for 2 weeks Run-in/wash-out period: Run-in: Aripiprazole plus placebo for 12 week(s). Patients who met the study criteria were randomized. Comorbidities: Anxiety Timing of outcome assessment: 7, 14 days | Results: ADHD: Cross over study
Khan et al.91 Anxiety Quetiapine Location: US Trial: Paladum (D1440L00016) Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 2 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Other-NOS Screened: NR Eligible: NR Entering: 409 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored, reported spontaneously by patient | Inclusion criteria: 18-65 years old, GAD, HAM-A >= 20, HAM-A item 1 and 2 >= 2, CGI-S >= 4, inadequate response to SSRI Exclusion criteria: DSM-IV Axis disorders other than GAD, schizophrenia or other psychotic disorders, depression, MADRS item 10 score >= 4, substance abuse, pregnant, severe illness, ECG significant Interventions: Placebo for 8 weeks vs Quetiapine 174.3 mg/days flexible dose for 8 weeks Run-in/wash-out period: Run-in: Placebo for 1 week(s). Patients who met the study criteria were randomized. In Wash-out: Psychotropics for 28 day(s) were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 42, 56 days | Results: Anxiety: Change in HAM-A (% Responder) at 8 weeks: Quetiapine+SSRI vs Placebo + SSRI - RR = 2.00 ( 0.68 , 5.85) Adverse Events: Placebo + antidepressant Madrs Item 10 (Suicidal Thoughts) Score Of =5: 0.0%(0/200) Placebo + antidepressant vs Quetiapine XR + antidepressant Ae Potentially Related To Suicidality: 0.0%(0/200) vs 0.0%(0/209) Aes Potentially Related To Extrapyramidal Symptoms: 2.0%(4/200) vs 3.8%(8/209) Aes Potentially Related To Sexual Dysfunction: 0.0%(0/200) vs 2.9%(6/209) Aes Potentially Related To Somnolence/Sedation: 14.5%(29/200) vs 35.9%(75/209) Concomitant Anxiolytics: Snris: 27.5%(55/200) vs 26.3%(55/209) Concomitant Anxiolytics: Ssris: 73.5%(147/200) vs 76.6%(160/209) Constipation: 3.9%(8/207) vs 6.0%(13/216) Dizziness: 4.4%(9/204) vs 10.3%(22/213) Dry Mouth: 7.5%(15/200) vs 23.4%(49/209) Fatigue: 3.9%(8/205) vs 9.3%(20/214) Headache: 10.3%(21/203) vs 11.3%(24/212) Incidence Of Aes: 60.0%(120/200) vs 73.7%(154/209) Increased Qtc Interval: 0.0%(0/200) vs 0.0%(0/209) Insomnia: 1.5%(3/206) vs 7.0%(15/215) Insomnia During 8 Week F/Up Period: 0.0%(0/210) vs 4.6%(10/219) Nasopharyngitis: 8.1%(17/209) vs 3.2%(7/218) Nausea: 5.8%(12/208) vs 5.5%(12/217) Nausea During 8 Week F/Up Period: 0.9%(2/211) vs 2.3%(5/220) Patients Experiencing A =7% Increase In Weight: 1.0%(2/200) vs 4.3%(9/209) Saes: 0.0%(0/200) vs 0.0%(0/209) Sedation: 2.5%(5/202) vs 12.3%(26/211) Sedation Leading To Discontinuation: 0.0%(0/200) vs 5.3%(11/209) Somnolence: 11.9%(24/201) vs 22.4%(47/210) Somnolence Leading To Discontinuation: 0.0%(0/200) vs 2.9%(6/209) Quetiapine XR + antidepressant Madrs Item 10 (Suicidal Thoughts) Score Of =4: 0.0%(0/209) Withdrawals: Placebo + antidepressant vs Quetiapine XR + antidepressant Withdrawals Due To Adverse Events:2.0%(4/200) vs 11.5%(24/209)
McIntyre et al. 2007^86^ Anxiety, Depression Quetiapine Location: Canada Trial: Not reported Funding source: Industry Design: RCT only Setting: Single setting Jadad: 3 Age: Not reported Sex: Mixed Race: Not reported Screened: 73 Eligible: 58 Entering: 58 Withdrawn: 22 Lost to follow-up: 2 Analyzed: 34 Method of AE assessment: Monitored | Inclusion criteria: 18-65, major depression, HAM-D 17 >= 18, CGI-S >=4, HAM-A >= 14, treated with single SSRI/venlafaxine at a therapeutic dose >= 6 weeks Exclusion criteria: Substance abuse / dependence 6 month prior, antipsychotic or benzodiazepines 7 days prior, P450 inhibition / induces 14 days prior, pregnant, breast feeding, risk of suicide Interventions: Placebo for 8 weeks vs Quetiapine 50-600 mg/days flexible dose for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 28, 42, 56 days | Results: Anxiety: Insufficient data to calculate an effect size Depression: Change in HAM-D (% Remitted) at 8 weeks: Quetiapine vs Placebo - RR = 1.78 ( 0.53 , 5.97 ) Depression: Change in HAM-D (% Responder) at 8 weeks: Quetiapine vs Placebo - RR = 2.00 ( 0.76 , 5.26 ) Adverse Events: Quetiapine vs Placebo Anxiety: 0.0%(0/29) vs 10.3%(3/29) Constipation: 13.8%(4/29) vs 0.0%(0/29) Dizziness: 20.7%(6/29) vs 24.1%(7/29) Dry Mouth: 44.8%(13/29) vs 13.8%(4/29) Dysuria: 10.3%(3/29) vs 3.4%(1/29) Flu-Like Symptoms: 6.9%(2/29) vs 10.3%(3/29) Headache: 13.8%(4/29) vs 27.6%(8/29) Increased Appetite: 17.2%(5/29) vs 20.7%(6/29) Increased Dreaming/ Nightmares: 13.8%(4/29) vs 0.0%(0/29) Increased Weight (Based On Pt's Perception): 34.5%(10/29) vs 10.3%(3/29) Insomnia: 0.0%(0/29) vs 31.0%(9/29) Irritability/Restlessness: 13.8%(4/29) vs 17.2%(5/29) Nausea: 3.4%(1/29) vs 10.3%(3/29) Other AE: 41.4%(12/29) vs 41.4%(12/29) Pain: 10.3%(3/29) vs 13.8%(4/29) Sedation/ Somnolence/Lethargy: 86.2%(25/29) vs 48.3%(14/29) Withdrawals: Quetiapine vs Placebo Withdrawals:37.9%(11/29) vs 44.8%(13/29) Withdrawals Due To Adverse Events:27.6%(8/29) vs 6.9%(2/29) Withdrawals Due to Adverse Events: Increase Irritability:0.0%(0/29) vs 3.4%(1/29) Withdrawals Due to Adverse Events: Increased Appetite, Increased Irritability And Sedation/Somnolence/Lethargy:3.4%(1/29) vs 0.0%(0/29) Withdrawals Due to Adverse Events: Sedation/Somnolence/Lethargy:20.7%(6/29) vs 3.4%(1/29) Withdrawals Due to Adverse Events: Weight Gain And Fatigue:3.4%(1/29) vs 0.0%(0/29)
Keitner et al. 2009^165^ Depression Risperidone Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 2 Age: Mean: 20 Sex: Mixed Race: Caucasian, Other-NOS Screened: 246 Eligible: 97 Entering: 97 Withdrawn: NR Lost to follow-up: NR Analyzed: 94 Method of AE assessment: Monitored | Inclusion criteria: Depressed, failed current antidepressant trial. MADRS >=15, 18-65 Exclusion criteria: Bipolar I or II, psychotic features, suicide risk, substance abuse / dependence, mod illness or seizures, ECT, pregnant or breast feeding, taking herbal meds Interventions: Placebo for 4 weeks vs Risperidone 0.5-3 mg/days flexible dose for 4 weeks Run-in/wash-out period: Run-in: Antidepressants for 5 week(s). Non-responder or partial responders were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28 days | Results: Depression: Change in HAM-D (% Remitted) at 4 weeks: Risperidone vs Placebo - RR = 1.95 ( 0.88 , 4.33 ) Depression: Change in HAM-D (% Responder) at 4 weeks: Risperidone vs Placebo - RR = 1.49 ( 0.83 , 2.68 ) Depression: Change in MADRS (% Remitted) at 4 weeks: Risperidone vs Placebo - RR = 2.13 ( 1.11 , 4.08 ) Depression: Change in MADRS (% Responder) at 4 weeks: Risperidone vs Placebo - RR = 1.65 ( 0.97 , 2.80 ) Adverse Events: Placebo vs Risperidone >=7% Increase From Baseline Weight: 0.0%(0/33) vs 3.1%(2/64) Abdominal Gas: 6.1%(2/33) vs 0.0%(0/64) Any Adverse Events: 81.8%(27/33) vs 84.4%(54/64) Constipation: 9.1%(3/33) vs 12.5%(8/64) Dry Mouth: 3.0%(1/33) vs 14.1%(9/64) Fatigue: 6.1%(2/33) vs 0.0%(0/64) Headache: 15.2%(5/33) vs 9.4%(6/64) Increased Appetite: 0.0%(0/33) vs 15.6%(10/64) Insomnia: 9.1%(3/33) vs 3.1%(2/64) Tired: 6.1%(2/33) vs 0.0%(0/64) Weight Gain: 3.0%(1/33) vs 3.1%(2/64) Withdrawals: Placebo vs Risperidone Withdrawals:21.2%(7/33) vs 15.6%(10/64)
Mahmoud et al. 2007^166^ Depression Risperidone Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 5 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry, Hispanic, Other-NOS Screened: 463 Eligible: 274 Entering: 274 Withdrawn: 33 Lost to follow-up: 9 Analyzed: 232 Method of AE assessment: Elicited by investigator, reported spontaneously by patient | Inclusion criteria: 18-65, antidepressant monotherapy >= 4 weeks, MDD, CGI-S >=4 Exclusion criteria: Pregnancy, suicide risk, serious illness, active substance or alcohol use disorders, current TCA (tricyclic antidepressant), MAO-I (monoamine oxidase inhibitor), mood stabilizer, antiepileptic, ADHD or narcolepsy medications Interventions: Placebo for 6 weeks vs Risperidone 0.25-2 mg/days flexible dose for 6 weeks Run-in/wash-out period: Run-in: Antidepressants for 4 week(s). Comorbidities: None Timing of outcome assessment: 7, 14, 28, 42 days | Results: Depression: Change in HAM-D (% Remitted) at 6 weeks: Risperidone vs Placebo - RR = 2.29 ( 1.22 , 4.30 ) Depression: Change in HAM-D (% Responder) at 6 weeks: Risperidone vs Placebo - RR = 1.57 ( 1.10 , 2.23 ) Adverse Events: Placebo vs Risperidone Any Treatment-Emergent Adverse Event: 54.1%(72/133) vs 44.7%(63/141) Arthralgia: 2.3%(3/133) vs 1.4%(2/141) Back Pain: 2.3%(3/133) vs 0.0%(0/141) Constipation: 2.3%(3/133) vs 3.5%(5/141) Death During The Study: 0.0%(0/133) vs 0.0%(0/141) Diarrhea: 3.8%(5/133) vs 2.1%(3/141) Disturbance In Attention: 0.0%(0/133) vs 2.1%(3/141) Dizziness: 2.3%(3/133) vs 3.5%(5/141) Dry Mouth: 0.8%(1/133) vs 5.0%(7/141) Dyspepsia: 3.0%(4/133) vs 2.1%(3/141) Fatigue: 0.0%(0/133) vs 3.5%(5/141) Headache: 14.3%(19/133) vs 8.5%(12/141) Hypertension: 2.3%(3/133) vs 0.0%(0/141) Insomnia: 1.5%(2/133) vs 4.3%(6/141) Lethargy: 2.3%(3/133) vs 0.7%(1/141) Nasopharyngitis: 3.0%(4/133) vs 2.1%(3/141) Nausea: 4.5%(6/133) vs 1.4%(2/141) Peripheral Edema: 0.8%(1/133) vs 2.8%(4/141) Sinusitis: 3.0%(4/133) vs 1.4%(2/141) Somnolence: 1.5%(2/133) vs 5.0%(7/141) Upper Respiratory Tract Infection: 2.3%(3/133) vs 0.0%(0/141) Weight Gain: 1.5%(2/133) vs 4.3%(6/141) Withdrawals: Placebo vs Risperidone Withdrawals:12.0%(16/133) vs 18.4%(26/141) Withdrawals Due To Adverse Events:2.3%(3/133) vs 5.7%(8/141)
Bauer et al. 2009^162^ Depression Quetiapine Location: Canada, Western Europe, Eastern Europe, Australia/New Zealand, South Africa Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 18 Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Other-NOS Screened: 572 Eligible: NR Entering: 493 Withdrawn: 66 Lost to follow-up: 3 Analyzed: 424 Method of AE assessment: Monitored | Inclusion criteria: 18-65 yrs old, diagnosed MDD, outpatients, HAM-D total score >= 20. HAM-D item I score >= 2, inadequate response during current episode to antidepressants. Exclusion criteria: Any DSM-IV Axis disorder other than MDD. DSM-IV Axis II disorder, duration of current MDD episode > 12 month or < 4 weeks from enrollment, substance abuse, clinically significant medical illness, HAM-D item 3 score >= 3, require psychotherapy, received quetiapine > 25mg/day for insomnia within 7 days before randomization, lack of quetiapine response. Interventions: Placebo for 6 weeks vs Quetiapine 50-150 mg/days fixed titration schedule for 6 weeks vs Quetiapine 50-300 mg/days fixed titration schedule for 6 weeks Run-in/wash-out period: Wash-out: No drug for 14 day(s). Eligible patents were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 28, 42 days | Results: Depression: Change in MADRS (% Remitted) at 6 weeks: Quetiapine vs Placebo - RR = 1.42 ( 1.03 , 1.94 ) Depression: Change in MADRS (% Responder) at 6 weeks: Quetiapine vs Placebo - RR = 1.22 ( 1.01 , 1.48 ) Adverse Events: Placebo vs Quetiapine 150 mg/d vs Quetiapine 300 mg/d >=7% Increase In Body Weight At End of Treatment: 1.2%(2/163) vs 4.2%(7/167) vs 4.3%(7/163) Clinically Relevant HDL Shifts To Elevated Values (<=40): 4.3%(7/163) vs 1.8%(3/167) vs 6.1%(10/163) Clinically Relevant LDL Shifts To Elevated Values (=>160): 11.0%(18/163) vs 16.2%(27/167) vs 12.3%(20/163) Clinically Relevant Prolactin Shifts To Elevated Values (Males =>20, Females >30): 1.8%(3/163) vs 1.2%(2/167) vs 2.5%(4/163) Clinically Relevant Shifts Glucose To Elevated Values (=>126): 2.5%(4/163) vs 2.4%(4/167) vs 6.7%(11/163) Clinically Relevant Shifts Tot Cholesterol To Elevated Values (=>240): 8.6%(14/163) vs 21.0%(35/167) vs 15.3%(25/163) Clinically Relevant Triglycerides Shifts To Elevated Values (=>200): 3.1%(5/163) vs 11.4%(19/167) vs 12.9%(21/163) Constipation: 3.7%(6/163) vs 4.2%(7/167) vs 10.4%(17/163) Dizziness: 7.4%(12/163) vs 11.4%(19/167) vs 9.2%(15/163) Dry Mouth: 6.7%(11/163) vs 20.4%(34/167) vs 35.6%(58/163) Fatigue: 3.1%(5/163) vs 13.2%(22/167) vs 14.7%(24/163) Headache: 9.8%(16/163) vs 9.0%(15/167) vs 8.0%(13/163) Nasopharyngitis: 6.1%(10/163) vs 3.0%(5/167) vs 3.1%(5/163) Nausea: 6.1%(10/163) vs 5.4%(9/167) vs 5.5%(9/163) Sedation: 4.3%(7/163) vs 9.6%(16/167) vs 12.9%(21/163) Somnolence: 3.1%(5/163) vs 16.8%(28/167) vs 23.3%(38/163) Withdrawals: Placebo vs Quetiapine 150 mg/d vs Quetiapine 300 mg/d Withdrawals:11.0%(18/163) vs 12.6%(21/167) vs 18.4%(30/163) Withdrawals Due To Adverse Events:3.1%(5/163) vs 6.6%(11/167) vs 11.7%(19/163)
Garakani et al. 2008^160^ Depression Quetiapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 41 Sex: Mixed Race: Not reported Screened: NR Eligible: NR Entering: 114 Withdrawn: 29 Lost to follow-up: NR Analyzed: 87 Method of AE assessment: Monitored | Inclusion criteria: 18-65 years old, diagnosis of unipolar major depression without psychotic features, MADRS score > 15 at both screen and baseline Exclusion criteria: Received an antidepressant for the current episode or within 2 weeks of entering the study, a history of treatment -refractory depression (failure to respond to adequate trials), primary diagnosis of any eating disorder / psychotic disorder / delirium / dementia / bipolar / OCD, any Axis II disorder that would interfere with the study, substance abuse, positive urine toxicology screen. Interventions: Placebo 25-100 mg/days flexible dose for 8 weeks vs Quetiapine 25-100 mg/days flexible dose for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56 days | Results: Depression: Change in MADRS (% Remitted) at 8 weeks: Quetiapine vs Placebo - RR = 0.87 ( 0.67 , 1.13 ) Adverse Events: Fluoxetine + placebo vs Fluoxetine+ quetiapine Anxiety: 12.3%(7/57) vs 7.0%(4/57) Dizziness And Lightheadedness: 12.3%(7/57) vs 17.5%(10/57) Dry Mouth: 8.8%(5/57) vs 12.3%(7/57) Fatigue: 7.0%(4/57) vs 8.8%(5/57) Gastrointestinal Symptoms (Nausea, Diarrhea, And Constipation): 22.8%(13/57) vs 14.0%(8/57) Headache: 12.3%(7/57) vs 5.3%(3/57) Muscle And Joint Pain: 7.0%(4/57) vs 3.5%(2/57) Sedation: 7.0%(4/57) vs 26.3%(15/57) Withdrawals: Fluoxetine + placebo vs Fluoxetine+ quetiapine Withdrawals:19.3%(11/57) vs 28.1%(16/57)
Berman et al. 2009^156^ Depression Aripiprazole Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 45 Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Native American, Other-NOS Screened: 1147 Eligible: 349 Entering: 349 Withdrawn: 48 Lost to follow-up: 5 Analyzed: 296 Method of AE assessment: Monitored, reported spontaneously by patient | Inclusion criteria: 18-65 years old, diagnosed major depressive episode >= 8weeks, inadequate response to previous antidepressants Exclusion criteria: Had received antidepressant with an adjunctive antipsychotic for > 3 weeks, psychosis, previously not tolerate any study antidepressants Interventions: Placebo for 6 weeks vs Aripiprazole 2-20 mg/days flexible dose for 6 weeks Run-in/wash-out period: Run-in: Antidepressants for 8 week(s). Non-responders were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42 days | Results: Depression: Change in MADRS (% Remitted) at 6 weeks: Aripiprazole vs Placebo - RR = 1.43 ( 0.96 , 2.12 ) Depression: Change in MADRS (% Responder) at 6 weeks: Aripiprazole vs Placebo - RR = 1.75 ( 1.30 , 2.35 ) Adverse Events: Aripiprazole Akathisia: Mild: 11.3%(20/177) Akathisia: Moderate: 5.1%(9/177) Akathisia: Severe: 1.7%(3/177) Aripiprazole vs Placebo Akathisia: Total: 18.1%(32/177) vs 3.5%(6/172) Clinically Significant Weight Gain (=7%) At Endpoint: 4.5%(8/177) vs 1.2%(2/172) Constipation: 5.6%(10/177) vs 3.5%(6/172) Diarrhea: 5.6%(10/177) vs 7.6%(13/172) Dizziness: 5.1%(9/177) vs 2.9%(5/172) Fatigue: 9.0%(16/177) vs 4.7%(8/172) Headache: 8.5%(15/177) vs 8.1%(14/172) Insomnia: 8.5%(15/177) vs 5.2%(9/172) Nausea: 4.0%(7/177) vs 5.8%(10/172) Restlessness: 12.4%(22/177) vs 3.5%(6/172) Serious AE: Arterial Occlusive Disease: 0.0%(0/177) vs 0.6%(1/172) Serious AE: Suicidal Ideation: 0.6%(1/177) vs 0.0%(0/172) Somnolence: 5.6%(10/177) vs 0.6%(1/172) Upper Respiratory Tract Infection: 7.3%(13/177) vs 7.6%(13/172) Vision Blurred: 7.3%(13/177) vs 1.7%(3/172) Withdrawals: Aripiprazole Withdrawal Due To Akathisia:1.1%(2/177) Aripiprazole vs Placebo Withdrawals:16.9%(30/177) vs 13.4%(23/172) Withdrawals Due To Adverse Events:6.2%(11/177) vs 1.7%(3/172)
Reeves et al. 2008^164^ Depression Risperidone Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Single setting Jadad: 2 Age: Not reported Sex: Mixed Race: Not reported Screened: NR Eligible: NR Entering: 23 Withdrawn: 5 Lost to follow-up: NR Analyzed: 18 Method of AE assessment: Monitored, reported spontaneously by patient | Inclusion criteria: 19 - 60, MDD and suicidal ideation despite treatment with up to 2 antidepressants for >= 3 weeks. MADRS >= 25, suicidal subscore >=4 Exclusion criteria: Psychotic features, other major psychiatric diagnosis, pregnant or lactating Interventions: Placebo for 8 weeks vs Risperidone 0.5-2 mg/days flexible dose for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 4, 7, 14, 21, 28, 42, 56 days | Results: Depression: Change in MADRS (Total Score) at 8 weeks: Risperidone Augmentation vs Placebo Augmentation - WMD = -7.11 ( -9.88 , -4.34 ) Adverse Events: Placebo vs Risperidone Bad Taste: 0.0%(0/12) vs 25.0%(3/12) Delayed Ejaculation: 25.0%(3/12) vs 0.0%(0/12) Diarrhea: 25.0%(3/12) vs 16.7%(2/12) Dizziness: 8.3%(1/12) vs 16.7%(2/12) Dry Mouth: 0.0%(0/12) vs 58.3%(7/12) Headache: 91.7%(11/12) vs 16.7%(2/12) Heartburn: 16.7%(2/12) vs 8.3%(1/12) Increased Appetite: 16.7%(2/12) vs 8.3%(1/12) Insomnia: 25.0%(3/12) vs 8.3%(1/12) Nausea: 25.0%(3/12) vs 16.7%(2/12) Somnolence: 8.3%(1/12) vs 16.7%(2/12) Withdrawals: Placebo vs Risperidone Withdrawals:41.7%(5/12) vs 8.3%(1/12)
Marcus et al. 2008^154^ Depression Aripiprazole Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 44 Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Native American, Other-NOS Screened: 1151 Eligible: 381 Entering: 382 Withdrawn: 57 Lost to follow-up: 0 Analyzed: 324 Method of AE assessment: Monitored, reported spontaneously by patient | Inclusion criteria: 18-65 years old, major depressive episode > = 8weeks, inadequate response to previous antidepressants Exclusion criteria: Previously reported Berman 2007 Interventions: Placebo for 6 weeks vs Aripiprazole 2-20 mg/days flexible dose for 6 weeks Run-in/wash-out period: Run-in: Antidepressants for 8 week(s). Non-responders were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42 days | Results: Depression: Change in MADRS (% Remitted) at 6 weeks: Aripiprazole vs Placebo - RR = 1.67 ( 1.10 , 2.54 ) Depression: Change in MADRS (% Responder) at 6 weeks: Aripiprazole vs Placebo - RR = 1.86 ( 1.28 , 2.72 ) Adverse Events: Aripiprazole vs Placebo Akathisia: 25.7%(49/191) vs 4.2%(8/190) At Least 1 AE: 80.6%(154/191) vs 63.2%(120/190) Clinically Significant Weight Gain (=7% From Double-Blind Baseline): 3.1%(6/191) vs 0.0%(0/190) Constipation: 5.2%(10/191) vs 2.6%(5/190) Deaths: 0.0%(0/191) vs 0.0%(0/190) Fatigue: 9.9%(19/191) vs 3.7%(7/190) Headache: 8.9%(17/191) vs 10.5%(20/190) Insomnia: 7.3%(14/191) vs 1.6%(3/190) Nausea: 5.2%(10/191) vs 4.2%(8/190) Restlessness: 9.4%(18/191) vs 0.5%(1/190) Serious AE: Cellulitis (Deemed Not Related To Study Medication): 0.5%(1/191) vs 0.0%(0/190) Somnolence: 6.8%(13/191) vs 3.7%(7/190) Suicide-Related AE During Double-Blind Randomized Phase: 0.0%(0/191) vs 0.0%(0/190) Tremor: 6.3%(12/191) vs 2.6%(5/190) Withdrawals: Aripiprazole vs Placebo Withdrawals:15.2%(29/191) vs 14.7%(28/190) Withdrawals Due To Adverse Events:3.7%(7/191) vs 1.1%(2/190)
Dunner et al. 2007^176^ Depression Ziprasidone Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 2 Age: Not reported Sex: Mixed Race: Caucasian, Other-NOS Screened: 90 Eligible: 64 Entering: 64 Withdrawn: 29 Lost to follow-up: 0 Analyzed: 35 Method of AE assessment: Monitored | Inclusion criteria: 21-65, non response to at least 1 course of 4 weeks of antidepressants and MADRS >=20 Exclusion criteria: Psychotic disorder, PTSD, panic, OCD, substance abuse / dependence in past 3 month, history of treatment with atypical antipsychotic fluoxetine, MAO-1 or ECT 6 weeks prior, unstable medical illness, pregnant, breast feeding Interventions: Control Group vs Ziprasidone 40-80 mg/days flexible dose for 8 weeks vs Ziprasidone 80-160 mg/days flexible dose for duration not reported Run-in/wash-out period: Run-in: Sertraline for 6 week(s). Non-responders were randomized. Comorbidities: None Timing of outcome assessment: 56 days | Results: Depression: Change in MADRS at 8 weeks: Ziprasidone 80mg + Sertraline vs Sertraline - WMD = -1.53 ( -2.73 , -0.34 ) Depression: Change in MADRS at 8 weeks: Ziprasidone 160mg + Sertraline vs Sertraline - WMD = -3.82 ( -5.14 , -2.50 ) Adverse Events: Placebo vs Ziprasidone 160 mg vs Ziprasidone 80 mg Abnormal Thinking: 0.0%(0/21) vs 10.0%(2/20) vs 8.7%(2/23) Abnormal Vision: 0.0%(0/21) vs 20.0%(4/20) vs 4.3%(1/23) Agitation: 0.0%(0/21) vs 25.0%(5/20) vs 21.7%(5/23) Akathisia: 0.0%(0/21) vs 20.0%(4/20) vs 4.3%(1/23) Asthenia: 0.0%(0/21) vs 25.0%(5/20) vs 21.7%(5/23) At Least 1 Adverse Events: 38.1%(8/21) vs 80.0%(16/20) vs 95.7%(22/23) Constipation: 0.0%(0/21) vs 5.0%(1/20) vs 13.0%(3/23) Dizziness: 0.0%(0/21) vs 20.0%(4/20) vs 17.4%(4/23) Dry Mouth: 0.0%(0/21) vs 20.0%(4/20) vs 8.7%(2/23) Headache: 4.8%(1/21) vs 15.0%(3/20) vs 17.4%(4/23) Insomnia: 4.8%(1/21) vs 30.0%(6/20) vs 34.8%(8/23) Nausea: 0.0%(0/21) vs 20.0%(4/20) vs 4.3%(1/23) Required Dose Reduction Or Temporary Discontinuance Due To Adverse Events: 0.0%(0/21) vs 20.0%(4/20) vs 0.0%(0/23) Respiratory Infection: 0.0%(0/21) vs 5.0%(1/20) vs 17.4%(4/23) Somnolence: 9.5%(2/21) vs 15.0%(3/20) vs 21.7%(5/23) Tremor: 4.8%(1/21) vs 10.0%(2/20) vs 21.7%(5/23) Withdrawals: Placebo vs Ziprasidone 160 mg vs Ziprasidone 80 mg Withdrawals:28.6%(6/21) vs 55.0%(11/20) vs 52.2%(12/23) Withdrawals Due To Adverse Events:0.0%(0/21) vs 35.0%(7/20) vs 39.1%(9/23)
Berman et al. 2007^155^ Depression Aripiprazole Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 4 Age: Mean: 45 Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Native American, Eskimo/Inuit, Other-NOS Screened: 1044 Eligible: NR Entering: 362 Withdrawn: 31 Lost to follow-up: 7 Analyzed: 320 Method of AE assessment: Monitored, reported spontaneously by patient | Inclusion criteria: Diagnosed major depressive episode >=8 weeks, inadequate response to antidepressant, (<50% reduction in depressive symptoms severity), HAM-D-17 >=18 Exclusion criteria: Delirium, dementia, amnestic, cognitive disorder schizophrenia, bipolar disorders, OCD, PTSD, personality disorders, psychotic symptomatology, allergy, participated ARI trial within past month, drug abuse, received antipsychotic and antidepressant for >=3 weeks etc. Interventions: Placebo for 6 weeks vs Aripiprazole 2-20 mg/days flexible dose for 6 weeks Run-in/wash-out period: Run-in: Antidepressants for 8 week(s). Non-responders were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42 days | Results: Depression: Change in MADRS (% Remitted) at 6 weeks: Aripiprazole vs Placebo - RR = 1.65 ( 1.08 , 2.53 ) Depression: Change in MADRS (% Responder) at 6 weeks: Aripiprazole vs Placebo - RR = 1.41 ( 1.01 , 1.98 ) Adverse Events: Aripiprazole vs Placebo >=7% Weight Gain: 7.1%(13/184) vs 1.1%(2/178) Akathisia: 22.8%(42/184) vs 4.5%(8/178) At Least One AE: 81.0%(149/184) vs 61.8%(110/178) Continuing Akathisia: 10.3%(19/184) vs 0.0%(0/178) Diarrhea: 3.3%(6/184) vs 5.6%(10/178) Dry Mouth: 3.3%(6/184) vs 6.2%(11/178) EPS-Related AEs: 27.2%(50/184) vs 9.6%(17/178) Fatigue: 6.0%(11/184) vs 3.4%(6/178) Headache: 6.0%(11/184) vs 10.7%(19/178) Insomnia: 7.6%(14/184) vs 2.2%(4/178) Nausea: 2.7%(5/184) vs 5.1%(9/178) Non-Akathisia EPS-Related AEs: 4.3%(8/184) vs 5.1%(9/178) Restlessness: 14.1%(26/184) vs 3.4%(6/178) Serious AE: Cellulitis And Staphylococcal Abscess: 0.0%(0/184) vs 0.6%(1/178) Serious AE: Contusion And Physical Assault: 0.0%(0/184) vs 0.6%(1/178) Serious AE: Exostosis: 0.0%(0/184) vs 0.6%(1/178) Serious AE: Pneumonia: 0.5%(1/184) vs 0.0%(0/178) Serious AE: Staphylococcal Cellulitis: 0.5%(1/184) vs 0.0%(0/178) Serious AEs: 1.1%(2/184) vs 1.7%(3/178) Suicidal Ideation: 0.0%(0/184) vs 1.1%(2/178) Upper Respiratory Tract Infection: 8.2%(15/184) vs 3.9%(7/178) Vision Blurred: 6.5%(12/184) vs 1.7%(3/178) Withdrawals: Aripiprazole vs Placebo Withdrawals:13.0%(24/184) vs 10.1%(18/178) Withdrawals Due To Adverse Events:3.3%(6/184) vs 2.2%(4/178)
Zheng et al. 2007^157^ Depression Quetiapine Location: Asia Trial: Not reported Funding source: Not reported Design: RCT only Setting: Multi-center Jadad: 1 Age: Mean: 25 Sex: Mixed Race: Not reported Screened: NR Eligible: NR Entering: NR Withdrawn: NR Lost to follow-up: NR Analyzed: 37 Method of AE assessment: Monitored, reported spontaneously by patient | Inclusion criteria: Diagnosed with MDD without psychotic symptoms, HAM-D score >= 18, BPRS item 4 score <= 4, item 11 score <=3, had been treated unsuccessfully with >= 2 different types of antidepressants for >= 6 weeks Exclusion criteria: Not reported Interventions: Antidepressant 26.7-28 mg/days flexible dose for 4 weeks vs Quetiapine, Antidepressant 50-200 mg/days flexible dose for 4 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 56 days | Results: Depression: Change in HAM-D (% Remitted) at 4 weeks: Quetiapine vs Placebo - RR = 8.44 ( 1.17 , 60.94 ) Depression: Change in HAM-D (% Responder) at 4 weeks: Quetiapine vs Placebo - RR = 2.90 ( 1.13 , 7.47 ) Adverse Events: Quetiapine + antidepressants Somnolence: 25.0%(5/20) Quetiapine + antidepressants vs Antidepressants AEs: All Mild To Moderate In Intensity: 40.0%(8/20) vs 35.0%(7/20) Withdrawals: Quetiapine + antidepressants vs Antidepressants Withdrawals:10.0%(2/20) vs 5.0%(1/20) Withdrawals Due To Adverse Events:0.0%(0/20) vs 0.0%(0/20)
Mattingly et al. 2006^161^ Depression Quetiapine Location: US Trial: Not reported Funding source: Not reported Design: RCT only Setting: Not reported Jadad: 3 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: NR Entering: 40 Withdrawn: 8 Lost to follow-up: 0 Analyzed: 32 Method of AE assessment: Monitored, elicited by investigator | Inclusion criteria: Outpatients aged 18-65 years old, a primary diagnosis of major depression who were not psychotic, baseline HAM-D 17 >= 20 following a >= 6 weeks SSRI or SNRI treatment, HAM-D item I score >= 2 had failed >= 1 r-week trial of clinically appropriate dose of another antidepressant Exclusion criteria: Met DSM-IV criteria for substance abuse within 3 months, a history of clinically significant disease, had participated in a clinical trial in the past 90 days, had a known intolerance or lack of response to quetiapine, received mood stabilizers, other antipsychotics or antidepressants other than SSRIs or SNRIs >=2 weeks Interventions: Placebo 200-400 mg/days flexible dose for 8 weeks vs Quetiapine 200-400 mg/days flexible dose for 8 weeks Run-in/wash-out period: Run-in: SRI monotherapy for 8 week(s). Non-responders were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 42, 56 days | Results: Depression: Change in HAM-D (% Remitted) at 8 weeks: Quetiapine vs Placebo - RR = 2.83 ( 0.73 , 10.98 ) Depression: Change in HAM-D (% Responder) at 8 weeks: Quetiapine vs Placebo - RR = 2.12 ( 0.89 , 5.05 ) Adverse Events: Placebo vs Quetiapine Dry Mouth: 0.0%(0/14) vs 11.5%(3/26) Fatigue: 14.3%(2/14) vs 26.9%(7/26) Headache: 35.7%(5/14) vs 26.9%(7/26) Sedation/Insomnia: 7.1%(1/14) vs 7.7%(2/26) Withdrawals: Placebo vs Quetiapine Withdrawals:21.4%(3/14) vs 19.2%(5/26) Withdrawals Due To Adverse Events:14.3%(2/14) vs 0.0%(0/26)
Gharabawi et al. 2006^167^ Depression Risperidone Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 2 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: NR Entering: 274 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: Adult outpatients with DSM-IV MDD, had an incomplete response to >= 8 weeks of antidepressant treatment Exclusion criteria: Not reported Interventions: Placebo 0.25-2 mg/days average final dose for 6 weeks vs Risperidone 0.25-2 mg/days flexible dose for 6 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 42 days | Results: Depression: Change in HAM-D (% Remitted) at 6 weeks: Risperidone vs Placebo - RR = 2.03 ( 1.10 , 3.75 ) Depression: Change in HAM-D (% Responder) at 6 weeks: Risperidone vs Placebo - RR = 1.44 ( 1.03 , 2.01 )
Thase et al. 2007^174^ Depression Olanzapine Location: US, Canada Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 44 Sex: Mixed Race: Caucasian, Other-NOS Screened: 1313 Eligible: 605 Entering: 605 Withdrawn: 146 Lost to follow-up: 18 Analyzed: 441 Method of AE assessment: Not applicable | Inclusion criteria: Treatment resistant depression, 18-65 years old, HAM-D-17 >=22 Exclusion criteria: Current / post schizophrenia, other psychotic disorders, PTSD, pregnant or nursing females, post partum depression, MDD with atypical features, paranoid, schizoid, personality disorders, significant medical illness, concomitant medications with primary central nervous system activity except lorazepam with dose up to 4mg / week Interventions: Olanzapine, Naltrexone 6-18 mg/days flexible dose for 8 weeks vs Olanzapine 6-18 mg/days flexible dose for 8 weeks vs Naltrexone 50 mg/days flexible dose for 8 weeks Run-in/wash-out period: Run-in: Fluoxetine for 8 week(s). Non-responders were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56 days | Results: Depression: Change in MADRS at 8 weeks: Olanzapine+Fluoxetine vs Fluoxetine - WMD = -3.40 ( -5.35 , -1.45 ) Depression: Change in MADRS at 8 weeks: Olanzapine+Fluoxetine vs Olanzapine - WMD = -3.70 ( -5.60 , -1.80 ) Depression: Change in MADRS at 8 weeks: Olanzapine vs Fluoxetine - WMD = 0.30 ( -1.52 , 2.12 ) Adverse Events: Fluoxetine vs Olanzapine vs Olanzapine/fluoxetine Deaths: 0.0%(0/206) vs 0.0%(0/199) vs 0.0%(0/200) Dry Mouth: 8.7%(18/206) vs 31.7%(63/199) vs 28.5%(57/200) Fatigue: 7.8%(16/206) vs 14.1%(28/199) vs 14.0%(28/200) Headache: 19.4%(40/206) vs 13.1%(26/199) vs 12.5%(25/200) Hypersomnia: 2.4%(5/206) vs 11.1%(22/199) vs 10.5%(21/200) Increase In Nonfasting Glucose From 140 To <200 mg/dL At Baseline To =200 mg/dL At Endpoint: 0.5%(1/206) vs 1.5%(3/199) vs 2.5%(5/200) Increase In Nonfasting Glucose From <140 mg/dL At Baseline To =200 mg/dL At Endpoint: 3.4%(7/206) vs 3.5%(7/199) vs 1.5%(3/200) Increase In Total Cholesterol From <200 mg/dL At Baseline To =240 mg/dL At Endpoint: 1.5%(3/206) vs 2.5%(5/199) vs 3.5%(7/200) Increase In Triglycerides From <150 mg/dL At Baseline To =500 mg/dL At Endpoint: 0.0%(0/206) vs 0.5%(1/199) vs 0.0%(0/200) Increased Appetite: 5.8%(12/206) vs 30.7%(61/199) vs 32.0%(64/200) Peripheral Edema: 1.0%(2/206) vs 7.5%(15/199) vs 12.0%(24/200) Serious AEs: Bipolar Disorder: 0.0%(0/206) vs 0.0%(0/199) vs 0.5%(1/200) Serious AEs: Pyrexia: 0.0%(0/206) vs 0.0%(0/199) vs 0.5%(1/200) Somnolence: 5.3%(11/206) vs 12.1%(24/199) vs 17.5%(35/200) Tremor: 8.7%(18/206) vs 8.0%(16/199) vs 10.5%(21/200) Weight Increased: 6.8%(14/206) vs 39.7%(79/199) vs 35.0%(70/200) Withdrawals: Fluoxetine vs Olanzapine vs Olanzapine/fluoxetine Withdrawals:19.4%(40/206) vs 36.2%(72/199) vs 26.0%(52/200) Withdrawals Due To Adverse Events:2.4%(5/206) vs 16.1%(32/199) vs 13.5%(27/200)
Nemeroff et al. 2004^163^ Depression Risperidone Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 2 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: NR Entering: 241 Withdrawn: 23 Lost to follow-up: NR Analyzed: 218 Method of AE assessment: Not reported | Inclusion criteria: Inpatients or outpatients aged 18-85 years old, DSM-IV diagnosis of MDD, 17-item HAM-D score >= 20, failed to respond to 1-3 antidepressants other than citalopram or escitalopram given at least 6 weeks. Exclusion criteria: Not reported Interventions: Placebo for 24 weeks vs Risperidone dosage not reported for 24 weeks Run-in/wash-out period: Run-in: Citalopram for 4-6 week(s). Non-responders were randomized. Comorbidities: None Timing of outcome assessment: 168 days | Results: Depression: Change in Proportion of patients that relapsed at 24 weeks: Risperidone + Citalopram vs Placebo +Citalopram - RR = 1.04 ( 0.82 , 1.31 )
Kim et al. 2007^153^ Depression Aripiprazole Location: Not reported Trial: Not reported Funding source: Not reported Design: RCT only Setting: Not reported Jadad: 2 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: NR Entering: NR Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Not applicable | Inclusion criteria: MDD, incomplete response to at least one historical treatment and one prospective treatment Exclusion criteria: Not reported Interventions: Placebo for 6 weeks vs Aripiprazole 2-20 mg/days frequency not reported for 6 weeks Run-in/wash-out period: Run-in: Antidepressants plus placebo for 8 week(s). Comorbidities: None Timing of outcome assessment: 42 days | Results: Depression: Insufficient data to calculate an effect size
El-Khalili et al. 2010^159^ Depression Quetiapine Location: US Trial: PEARL-D1448C00006 Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 5 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Other-NOS Screened: 659 Eligible: NR Entering: 446 Withdrawn: 77 Lost to follow-up: 25 Analyzed: 344 Method of AE assessment: Monitored | Inclusion criteria: 18-65, MDD per DSM-IV, HAMD >=20 - item I >= 2, inadequate response to antidepressant Exclusion criteria: Axis I other than MDD within 6 month prior, significant Axis II, current MDD episode > 12 month or < 4 weeks, substance abuse or dependence 6 month prior, significant medical illness, suicide / homicide risk, HAMD item 3 >= 3, suicide attempt 6 months prior, requiring starting psychotherapy Interventions: Placebo 998 Not reported/days fixed titration schedule for 6 weeks vs Quetiapine 150 mg/days fixed titration schedule for 6 weeks vs Quetiapine 300 mg/days fixed titration schedule for 6 weeks Run-in/wash-out period: Wash-out: No drug for <=14 day(s). Patients who completed the wash-out period were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 28, 42, 56 days | Results: Depression: Change in MADRS (% Remitted) at 6 weeks: Quetiapine 150mg & 300mg vs Placebo - RR = 1.58 ( 1.15 , 2.19 ) Depression: Change in MADRS (% Responder) at 6 weeks: Quetiapine 150mg & 300mg vs Placebo - RR = 1.20 ( 0.98 , 1.47 )
Kordon et al. 2008^197^ OCD Quetiapine Location: Western Europe Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Not reported Sex: Mixed Race: Not reported Screened: NR Eligible: NR Entering: 40 Withdrawn: 10 Lost to follow-up: NR Analyzed: 30 Method of AE assessment: Reported spontaneously by patient, observed | Inclusion criteria: Aged 18-65, diagnosis of OCD, Y-BOCS >= 18, treated with an SRI >= 12 weeks and non-responders (< 25% improvement in Y-BOCS) Exclusion criteria: Known intolerance or lack of response to quetiapine, a psychotic disorder, substance abuse, organic brain disease, epilepsy, known HIV infection, significant and unstable venal, cardiovascular, hepatic, hematologic, or endocrine conditions. Interventions: Placebo 100-600 mg/days flexible dose for 12 weeks vs Quetiapine 100-600 mg/days flexible dose for 12 weeks Run-in/wash-out period: Not reported Comorbidities: Personality Disorder Timing of outcome assessment: 14, 28, 42, 56, 70, 84 days | Results: OCD: Change in YBOCS at 12 weeks: Quetiapine vs Placebo - RR = 2.11 ( 0.61 , 7.24 ) Adverse Events: Quetiapine vs Placebo Abdominal Pain Upper: 15.0%(3/20) vs 25.0%(5/20) Apathy: 15.0%(3/20) vs 10.0%(2/20) Constipation: 25.0%(5/20) vs 5.0%(1/20) Diarrhea: 5.0%(1/20) vs 25.0%(5/20) Disturbance In Attention: 25.0%(5/20) vs 5.0%(1/20) Dizziness: 15.0%(3/20) vs 5.0%(1/20) Dry Mouth: 50.0%(10/20) vs 15.0%(3/20) Dyspepsia: 35.0%(7/20) vs 5.0%(1/20) Fatigue: 85.0%(17/20) vs 65.0%(13/20) Headache: 35.0%(7/20) vs 55.0%(11/20) Hyperhidrosis: 30.0%(6/20) vs 50.0%(10/20) Increased Appetite: 15.0%(3/20) vs 15.0%(3/20) Influenza-Like Illness: 5.0%(1/20) vs 30.0%(6/20) Nasopharyngitis: 5.0%(1/20) vs 20.0%(4/20) Nausea: 10.0%(2/20) vs 20.0%(4/20) Nightmare: 10.0%(2/20) vs 10.0%(2/20) SAE: Cramps In Lower Abdomen: 0.0%(0/20) vs 5.0%(1/20) SAE: Headache: 0.0%(0/20) vs 5.0%(1/20) SAE: Increased Cardiac Enzymes: 5.0%(1/20) vs 0.0%(0/20) SAE: Orthostatic Collapse: 0.0%(0/20) vs 5.0%(1/20) Subjects With At Least 1 AE: 95.0%(19/20) vs 100.0%(20/20) Subjects With At Least 1 Drug-Related AE: 95.0%(19/20) vs 55.0%(11/20) Subjects With At Least 1 Drug-Related SAE: 5.0%(1/20) vs 10.0%(2/20) Subjects With At Least 1 SAE: 5.0%(1/20) vs 15.0%(3/20) Vertigo: 45.0%(9/20) vs 25.0%(5/20) Withdrawals: Quetiapine vs Placebo Withdrawals:30.0%(6/20) vs 15.0%(3/20) Withdrawals Due To Adverse Events:20.0%(4/20) vs 5.0%(1/20)
Vulink et al.2009^199^ OCD Quetiapine Location: Western Europe Trial: Not reported Funding source: Industry Design: RCT only Setting: Single setting Jadad: 4 Age: Not reported Sex: Mixed Race: Not reported Screened: 249 Eligible: 143 Entering: 76 Withdrawn: 0 Lost to follow-up: 0 Analyzed: 66 Method of AE assessment: Monitored, reported spontaneously by patient | Inclusion criteria: Age >= 18, OCD, YBOCS>=17 or 11 if only obsessions and compulsive were present Exclusion criteria: Use of antipsychotics or SRI's at effective dose for at least 8 weeks, MDD, or HAM-D 17>=17, pregnant or nursing, women not on contraception, organic mental disorder, epilepsy, central nervous system disorder or stroke within last year, bipolar, schizophrenia or other psychotic disorders, subrelated disorder within 6 months, personality disorder, tics or Tourette's, any clinically significant acute or unstable medical condition, allergy to quetiapine, behavioral or cognitive therapy 3 month prior, suicide risk Interventions: Placebo for 10 weeks vs Quetiapine 50-450 mg/days fixed titration schedule for 10 weeks Run-in/wash-out period: Not reported Comorbidities: Anxiety, Depression Timing of outcome assessment: 14, 21, 28, 42, 56, 70 days | Results: OCD: Change in YBOCS (Total Score) at 10 weeks: Quetiapine vs Placebo - WMD = -3.80 ( -6.72 , -0.88 ) Adverse Events: Placebo vs Quetiapine Concentration Problems: 10.8%(4/37) vs 7.7%(3/39) Dizziness: 10.8%(4/37) vs 23.1%(9/39) Dry Mouth: 13.5%(5/37) vs 33.3%(13/39) Headache: 35.1%(13/37) vs 25.6%(10/39) Increased Appetite: 10.8%(4/37) vs 17.9%(7/39) Muscular Pain: 16.2%(6/37) vs 5.1%(2/39) Nausea: 37.8%(14/37) vs 5.1%(2/39) Palpitations: 10.8%(4/37) vs 7.7%(3/39) Sexual Problems: 43.2%(16/37) vs 41.0%(16/39) Sleeplessness: 29.7%(11/37) vs 0.0%(0/39) Somnolence: 56.8%(21/37) vs 84.6%(33/39) Sweating: 27.0%(10/37) vs 12.8%(5/39) Tremor: 27.0%(10/37) vs 15.4%(6/39) Weight Gain: 21.6%(8/37) vs 53.8%(21/39) Withdrawals: Placebo vs Quetiapine Withdrawals:5.4%(2/37) vs 20.5%(8/39) Quetiapine Withdrawals Due To Adverse Events:17.9%(7/39)
Denys et al. 2006^201^ OCD Quetiapine Location: Not reported Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 2 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: NR Entering: NR Withdrawn: 9 Lost to follow-up: NR Analyzed: NR Method of AE assessment: Not reported | Inclusion criteria: Patients with primary OCD according to DSM-IV criteria Exclusion criteria: Not reported Interventions: Control Group vs Quetiapine dosage not reported for 10 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 70 days | Results: OCD: Insufficient data to calculate an effect size
Ozdemir et al.240 PTSD Quetiapine Location: Turkey Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 2 Age: Not reported Sex: Mixed Race: Not reported Screened: NR Eligible: NR Entering: 94 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: 18-55 years old, DSM-IV diagnosis of PTSD Exclusion criteria: Comorbid psychotic disorder, substance abuse, treated with SSRI previous 2 weeks, severe illness, abnormal lab test results, pregnant Interventions: Placebo for 8 weeks vs Quetiapine 166 (25-750) mg/days flexible dose for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 14, 28, 56 days | Results: PTSD: Change in CAPS (ITT Results) at 8 weeks: Quetiapine + SSRI vs Placebo + SSRI - WMD = -3.60 ( -16.83 , 9.63 ) PTSD: Change in CAPS (Per Protocol Results) at 8 weeks: Quetiapine + SSRI vs Placebo + SSRI - WMD = -17.00 ( -27.80 , -6.20 ) Adverse Events: Placebo + Sertraline vs Quetiapine + sertraline At Least 1 Ae: 66.0%(31/47) vs 59.6%(28/47) Dizziness: 17.0%(8/47) vs 4.3%(2/47) Drowsiness: 6.4%(3/47) vs 17.0%(8/47) Dry Mouth: 2.1%(1/47) vs 17.0%(8/47) Insomnia: 17.0%(8/47) vs 2.1%(1/47) Mild Aes: 25.5%(12/47) vs 31.9%(15/47) Moderate Aes: 44.7%(21/47) vs 48.9%(23/47) Nausea: 12.8%(6/47) vs 10.6%(5/47) Somnolence: 4.3%(2/47) vs 8.5%(4/47) Vertigo: 8.5%(4/47) vs 2.1%(1/47) Withdrawals: Placebo + Sertraline vs Quetiapine + sertraline Withdrawals Due To Adverse Events:21.3%(10/47) vs 17.0%(8/47)
Grabowski et al. 2004^274^ Substance abuse Risperidone Location: US Trial: Not reported Funding source: Government Design: RCT only Setting: Not reported Jadad: 3 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry, Hispanic Screened: 120 Eligible: NR Entering: 96 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: 18-50, dual dependent (cocaine and heroin) good medical health, without other psych diagnosis (except nicotine dependence) Exclusion criteria: Not reported Interventions: Placebo for 26 weeks vs Risperidone 2 mg/days frequency not reported for 26 weeks vs Risperidone 4 mg/days frequency not reported for 26 weeks Run-in/wash-out period: Wash-out: Risperidone stabilization for 2 weeks. Patients in symptomatic remission were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56, 63, 70, 77, 84, 91, 98, 105, 112, 119, 126, 133, 140, 147, 154, 161, 168 days | Results: Substance Abuse: Insufficient data to calculate an effect size Withdrawals: Placebo vs Risperidone 2mg vs Risperidone 4mg Withdrawals:78.8%(26/33) vs 65.6%(21/32) vs 54.8%(17/31)
Guardia et al. 2011^260^ Substance abuse Quetiapine Location: Western Europe Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 2 Age: Not reported Sex: 80-99% Male Race: Not reported Screened: NR Eligible: NR Entering: 62 Withdrawn: 15 Lost to follow-up: 0 Analyzed: 47 Method of AE assessment: Monitored | Inclusion criteria: 18-65, outpatient, alcohol dependence per DSM-IV Exclusion criteria: Pregnant, nursing, woman without contraception, severe medical or psychiatric disorders, renal failure or hepatic impairment, operates public transport vehicle or hazardous machinery, leukopenia, contraindication to study drug. Interventions: Placebo 172.5 mg/days flexible dose for 12 weeks vs Quetiapine 127.5 mg/days flexible dose for 12 weeks Run-in/wash-out period: Run-in: Naltrexone + placebo for 1 week(s). Patients who met the study criteria were randomized. Comorbidities: Anxiety, Depression Timing of outcome assessment: 7, 14, 21, 28, 56, 84, 112 days | Results: Substance Abuse: Change in Abstinent Days - Self Report at 12 weeks: Quetiapine + Naltrexone vs Placebo + Naltrexone - WMD = -1.30 ( -4.82 , 2.22 ) Adverse Events: Naltrexone + Placebo vs Naltrexone + Quetiapine Anxiety: 3.1%(1/32) vs 6.7%(2/30) Asthenia/Lassitude: 3.1%(1/32) vs 0.0%(0/30) Constipation: 0.0%(0/32) vs 3.3%(1/30) Decreased Libido: 0.0%(0/32) vs 3.3%(1/30) Dizziness: 3.1%(1/32) vs 0.0%(0/30) Dry Mouth: 3.1%(1/32) vs 6.7%(2/30) Dyspepsia: 3.1%(1/32) vs 0.0%(0/30) Sae: Tonsilitis Unrelated To Study Medication: 0.0%(0/32) vs 3.3%(1/30) Somnolence: 3.1%(1/32) vs 6.7%(2/30) Tension/Inner Unrest: 6.3%(2/32) vs 3.3%(1/30) Withdrawals: Naltrexone + Placebo vs Naltrexone + Quetiapine Withdrawals:12.5%(4/32) vs 36.7%(11/30) Withdrawals Due To Adverse Events:3.1%(1/32) vs 6.7%(2/30)

AE=Adverse Event, NR=Not Repoted

Quality of Augmentation Trials

Study | Treatment allocation | Groups similar at baseline? | Blinding | Dropouts | Other sources of potential bias
Zeni et al. 2009^80^ ADHD Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Not described If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Don't know Was the care provider masked? Don't know Were patients masked? Don't know | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Khan et al.91 Anxiety Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
McIntyre et al. 2007^86^ Anxiety, Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Keitner et al. 2009^165^ Depression Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Mahmoud et al. 2007^166^ Depression Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Yes | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Bauer et al. 2009^162^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Garakani et al. 2008^160^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Berman et al. 2009^156^ Depression Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Reeves et al. 2008^164^ Depression Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Don't know Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Marcus et al. 2008^154^ Depression Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Dunner et al. 2007^176^ Depression Ziprasidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Yes Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Berman et al. 2007^155^ Depression Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Zheng et al. 2007^157^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? No Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Mattingly et al. 2006^161^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Gharabawi et al. 2006^167^ Depression Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Thase et al. 2007^174^ Depression Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Nemeroff et al. 2004^163^ Depression Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Kim et al. 2007^153^ Depression Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Don't know Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
El-Khalili et al. 2010^159^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Kordon et al. 2008^197^ OCD Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Vulink et al. 2009^199^ OCD Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Denys et al. 2006^201^ OCD Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Ozdemir et al.240 PTSD Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Grabowski et al. 2004^274^ Substance abuse Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Guardia et al. 2011^260^ Substance abuse Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes

AE=Adverse Event, NR=Not Reported

Placebo-Controlled Trials

Citation and Study Information | Eligibility, Interventions, Outcomes | Results, Adverse Events, and Withdrawals
Armenteros et al. 2007^77^ ADHD Risperidone Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 4 Age: Not reported Sex: 80-99% Male Race: Caucasian, African Ancestry, Other-NOS Screened: NR Eligible: NR Entering: 25 Withdrawn: 2 Lost to follow-up: 0 Analyzed: 23 Method of AE assessment: Monitored | Inclusion criteria: ADHD, treated constant does of stimulant for 3 weeks prior, aggressive behavior, AQPA of <= 0, CGI-S >= 4, IQ >=75, normal physical and labs Exclusion criteria: Substance use disorder, unstable illness, history of intolerance or failure to respond to risperidone, suicidal or homicidal Interventions: Placebo for 28 days vs Risperidone 0.5-2 mg/days flexible dose for 28 days Run-in/wash-out period: Not reported Comorbidities: Anxiety Timing of outcome assessment: 7, 14, 21, 28 days | Results: ADHD: Change in CAS-P (improvement = >=30%) at 4 weeks: Risperidone vs Placebo - RR = 1.19 ( 0.89 , 1.59 ) Adverse Events: Placebo vs Risperidone Abdominal Pain: 7.7%(1/13) vs 25.0%(3/12) Agitation: 0.0%(0/13) vs 8.3%(1/12) At Least One Adverse Event: 76.9%(10/13) vs 58.3%(7/12) Increased Appetite: 0.0%(0/13) vs 8.3%(1/12) Somnolence: 15.4%(2/13) vs 8.3%(1/12) Vomiting: 23.1%(3/13) vs 16.7%(2/12) Withdrawals: Placebo vs Risperidone Withdrawals:7.7%(1/13) vs 8.3%(1/12) Withdrawals Due To Adverse Events:0.0%(0/13) vs 0.0%(0/12)
Tramontina et al. 2009^79^ ADHD Aripiprazole Location: Latin America Trial: Not reported Funding source: Government, Industry Design: RCT only Setting: Single setting Jadad: 5 Age: Mean: 12 Sex: Mixed Race: Caucasian, Other-NOS Screened: 710 Eligible: 43 Entering: 43 Withdrawn: 2 Lost to follow-up: 0 Analyzed: 41 Method of AE assessment: Monitored, elicited by investigator | Inclusion criteria: Age 8-17, bipolar I or II disorder comorbid ADHD acutely manic or mixed state, clear reports of ADHD symptom onset preceding any mood symptomatology Exclusion criteria: Estimated IQ < 70, use of any medication 4 weeks prior to entering the study, pervasive developmental disorder, schizophrenia, substance abuse, suicide risk, previous use of aripiprazole, pregnancy, chronic diseases Interventions: Placebo 2-20 mg/days flexible dose for 6 weeks vs Aripiprazole 2-20 mg/days flexible dose for 6 weeks Run-in/wash-out period: Not reported Comorbidities: Anxiety Timing of outcome assessment: 7, 14, 21, 28, 35, 42 days | Results: ADHD: Change in SNAP-IV Total Score (Total Score) at 6 weeks: Aripiprazole vs Placebo - WMD = 0.05 ( -0.34 , 0.44 ) Adverse Events: Excluded from analysis: Reflexes Change: 5.6%(1/18) vs 0.0%(0/25) Rhinitis: 27.8%(5/18) vs 64.0%(16/25) Sialorrhea: 72.2%(13/18) vs 52.0%(13/25) Skin Rash: 0.0%(0/18) vs 4.0%(1/25) Slowness Of Thought: 5.6%(1/18) vs 12.0%(3/25) Somnolence: 94.4%(17/18) vs 76.0%(19/25) Suicidal Ideation: 27.8%(5/18) vs 20.0%(5/25) Sweating: 55.6%(10/18) vs 44.0%(11/25) Tiredness: 83.3%(15/18) vs 56.0%(14/25) Tremors: 44.4%(8/18) vs 32.0%(8/25) Vomiting: 27.8%(5/18) vs 20.0%(5/25) Withdrawals: Aripiprazole vs Placebo Withdrawals:5.6%(1/18) vs 4.0%(1/25) Withdrawals Due To Adverse Events:5.6%(1/18) vs 0.0%(0/25)
Bandelow et al. 2009^88^ Anxiety Quetiapine Location: Canada, Western Europe, Eastern Europe, Latin America, South Africa Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 5 Age: Mean: 18 Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Other-NOS Screened: 1054 Eligible: NR Entering: 873 Withdrawn: 188 Lost to follow-up: 9 Analyzed: 473 Method of AE assessment: Monitored | Inclusion criteria: 18-65 years old, diagnosed GAD, HAM-A total score >= 20 with item 1 and 2 scores >= 2, MADRS total score <= 16, CGI-S score >=4 at enrollment and randomization. Exclusion criteria: Diagnosis of any DSM-IV-TR Axis I disorder other than GAD within 6 months or DSM -IV-TR Axis II disorder, MADRS item 10 score >=4, suicide attempt, alcohol abuse Interventions: Placebo for 8 weeks vs Quetiapine 50-150 mg/days fixed titration schedule for 8 weeks vs Quetiapine 50 mg/days fixed single dose for 8 weeks vs Paroxetine 20 mg/days fixed single dose for 8 weeks Run-in/wash-out period: Wash-out: No drug for 1-4 week(s). Eligible patents were randomized. Comorbidities: None Timing of outcome assessment: 1, 4, 7, 14, 21, 28, 42, 56 days | Results: Anxiety: Change in HAM-A (% Responder) at 8 weeks: Quetiapine vs Placebo - RR = 1.36 (1.17 , 1.59) Adverse Events: Paroxetine vs Placebo vs Quetiapine 150 mg vs Quetiapine 50mg >=7% Increase In Body Weight At End of Treatment: 4.6%(10/217) vs 2.3%(5/217) vs 6.9%(15/218) vs 4.5%(10/221) Anxiety: 5.1%(11/217) vs 0.5%(1/217) vs 1.4%(3/218) vs 1.4%(3/221) Constipation: 2.8%(6/217) vs 1.4%(3/217) vs 6.0%(13/218) vs 4.5%(10/221) Diarrhea: 5.5%(12/217) vs 4.6%(10/217) vs 3.7%(8/218) vs 3.2%(7/221) Dizziness: 13.4%(29/217) vs 6.0%(13/217) vs 15.6%(34/218) vs 11.8%(26/221) Dry Mouth: 9.7%(21/217) vs 6.0%(13/217) vs 25.7%(56/218) vs 15.8%(35/221) Extrapyramidal Adverse Events: 8.3%(18/217) vs 1.8%(4/217) vs 5.0%(11/218) vs 6.8%(15/221) Fasting HDL Cholesterol =40 mg/dL At End of Treatment: 1.4%(3/217) vs 5.5%(12/217) vs 3.7%(8/218) vs 2.7%(6/221) Fasting Total Cholesterol =240 mg/dL At End of Treatment: 6.5%(14/217) vs 3.2%(7/217) vs 5.0%(11/218) vs 4.1%(9/221) Fasting Triglycerides >=200 mg/dL At End of Treatment: 3.7%(8/217) vs 2.8%(6/217) vs 8.3%(18/218) vs 3.2%(7/221) Fatigue: 9.2%(20/217) vs 3.7%(8/217) vs 16.5%(36/218) vs 14.9%(33/221) Headache: 17.1%(37/217) vs 18.0%(39/217) vs 12.4%(27/218) vs 16.3%(36/221) Insomnia: 13.4%(29/217) vs 6.5%(14/217) vs 8.7%(19/218) vs 7.7%(17/221) Nasopharyngitis: 6.0%(13/217) vs 3.7%(8/217) vs 2.3%(5/218) vs 3.2%(7/221) Nausea: 24.4%(53/217) vs 9.2%(20/217) vs 11.9%(26/218) vs 11.3%(25/221) Overall Incidence Of Adverse Events: 72.8%(158/217) vs 55.8%(121/217) vs 76.1%(166/218) vs 71.0%(157/221) Sedation: 2.3%(5/217) vs 0.5%(1/217) vs 8.3%(18/218) vs 6.3%(14/221) Sexual Dysfunction: 7.4%(16/217) vs 2.3%(5/217) vs 1.8%(4/218) vs 0.9%(2/221) Somnolence: 11.1%(24/217) vs 4.6%(10/217) vs 25.2%(55/218) vs 21.7%(48/221) Treatment-Related Adverse Events: 58.5%(127/217) vs 34.6%(75/217) vs 65.6%(143/218) vs 58.8%(130/221) Paroxetine vs Placebo vs Quetiapine 50mg Fasting LDL Cholesterol = 160 mg/dL At End of Treatment: 6.5%(14/217) vs 3.7%(8/217) vs 3.2%(7/221) Quetiapine 150 mg Fasting LDL Cholesterol = >160 mg/dL At End of Treatment: 4.1%(9/218) Quetiapine 50mg vs Quetiapine 150 mg vs Placebo vs Paroxetine Fasting Glucose =>126 mg/dL At End of Treatment: 0.9%(2/221) vs 0.5%(1/218) vs 1.4%(3/217) vs 1.4%(3/217) Withdrawals: Paroxetine vs Placebo vs Quetiapine 150 mg vs Quetiapine 50mg Withdrawals:45.2%(98/217) vs 41.9%(91/217) vs 48.2%(105/218) vs 48.0%(106/221) Withdrawals Due To Adverse Events:7.8%(17/217) vs 4.1%(9/217) vs 16.1%(35/218) vs 11.8%(26/221)
Barnett et al. 2002^83^ Anxiety Olanzapine Location: Not reported Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 3 Age: Mean: 18 Sex: Race: Not reported Screened: NR Eligible: 12 Entering: 12 Withdrawn: 2 Lost to follow-up: 3 Analyzed: 7 Method of AE assessment: Monitored | Inclusion criteria: 18-65, social anxiety disorder, DSM-IV of social phobia of, brief social phobia scale (BSPS) >= 20 Exclusion criteria: NR Interventions: Placebo 5 mg/days flexible dose for 8 weeks vs Olanzapine 5-20 mg/days flexible dose for 8 weeks Run-in/wash-out period: Run-in: Placebo for 1 week(s). Comorbidities: None Timing of outcome assessment: 14, 21, 28, 42, 56 days | Results: Anxiety: Change in Brief Social Phobia Scale at 8 weeks: Olanzapine vs Placebo - WMD = -10.60 ( -26.09 , 4.89 ) Adverse Events: Olanzapine vs Placebo Constipation: 14.3%(1/7) vs 0.0%(0/5) Drowsiness: 57.1%(4/7) vs 0.0%(0/5) Dry Mouth: 42.9%(3/7) vs 0.0%(0/5) Headache: 0.0%(0/7) vs 20.0%(1/5) Significant Changes On The BAS Or AIMS: 0.0%(0/7) vs 0.0%(0/5) Thirst: 14.3%(1/7) vs 0.0%(0/5) Weight Gain: 0.0%(0/7) vs 20.0%(1/5) Withdrawals: Olanzapine vs Placebo Withdrawals:42.9%(3/7) vs 40.0%(2/5) Withdrawals Due To Adverse Events:14.3%(1/7) vs 20.0%(1/5)
Brawman-Mintzer et al. 2005^98^ Anxiety Risperidone Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 3 Age: Not reported Sex: 80-99% Female Race: Caucasian Screened: NR Eligible: NR Entering: 40 Withdrawn: NR Lost to follow-up: NR Analyzed: 31 Method of AE assessment: Monitored | Inclusion criteria: Age >=18, GAD, HAM-A >=18, CGI-S >=4, Covi > Raskin score despite adequate treatment >= 4 weeks Exclusion criteria: MDD 1 month prior, substance use disorder 6 month prior, bipolar or psychotic disorder Interventions: Placebo for 5 weeks vs Risperidone 0.5-1.5 mg/days flexible dose for 5 weeks Run-in/wash-out period: Not reported Comorbidities: Anxiety Timing of outcome assessment: 7, 14, 21, 28, 35 days | Results: Anxiety: Change in HAM-A (Total Score) at 5 weeks: Risperidone vs Placebo - WMD = -3.60 ( -6.88 , -0.32 ) Adverse Events: Placebo vs Risperidone Blurred Vision: 0.0%(0/20) vs 15.0%(3/20) Dizziness: 15.0%(3/20) vs 20.0%(4/20) Required Adjunctive Treatment With Anticholinergic Agents: 0.0%(0/20) vs 0.0%(0/20) Somnolence: 15.0%(3/20) vs 45.0%(9/20) Withdrawals: Placebo vs Risperidone Withdrawals:20.0%(4/20) vs 25.0%(5/20) Withdrawals Due To Adverse Events:5.0%(1/20) vs 15.0%(3/20)
Donahue et al. 2009^95^ Anxiety Quetiapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Single setting Jadad: 3 Age: Mean: 18 Sex: Mixed Race: Not reported Screened: 81 Eligible: 44 Entering: 24 Withdrawn: 3 Lost to follow-up: 1 Analyzed: NR Method of AE assessment: Monitored, elicited by investigator | Inclusion criteria: Diagnosis of SAD and clinically significant public speaking Exclusion criteria: Current contraindications or a history of sensitivity to quetiapine, current regular use of benzodiazepine, tranquilizer or antipsychotic medications, active psychotic/manic/depressed episode, unstable diabetes mellitus, heart disease, neurologic disorder, liver disease Interventions: Placebo for 1 hours vs Quetiapine 25 mg/days fixed single dose for 1 hours Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 1, 2, 3, 4 minutes | Results: Anxiety: Cross over study Adverse Events: Excluded from analysis: Sample size by group not reported
Hirschfeld et al. 2006^92^ Anxiety Quetiapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 37 Sex: Mixed Race: Not reported Screened: 838 Eligible: 542 Entering: 542 Withdrawn: 216 Lost to follow-up: NR Analyzed: 326 Method of AE assessment: Not reported | Inclusion criteria: Outpatients aged 18-65. bipolar I or II disorder, current episode depressed, with a duration between 4 weeks and1 year, HAM-D score >= 2, young mania rating scale score <= 12. Exclusion criteria: Diagnosed Axis I disorder other than bipolar disorder within 6 months, history of nonresponse to adequate trial during current episode, substance abuse within 12 months. Interventions: Placebo for 8 weeks vs Quetiapine 50-300 mg/days frequency not reported for 8 weeks vs Quetiapine 50-600 mg/days frequency not reported for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56 days | Results: Anxiety: Insufficient data to calculate an effect size
Pandina et al. 2007^99^ Anxiety Risperidone Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 5 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry, Hispanic, Other-NOS Screened: 453 Eligible: 417 Entering: 417 Withdrawn: 76 Lost to follow-up: 11 Analyzed: 303 Method of AE assessment: Monitored | Inclusion criteria: 15-65, GAD, CGI-S >=4, antidepressant, benzodiazepine, buspirone or a combination of an antidepressants plus benzodiazepine or buspirone for at least 8 weeks prior and stable × 4 weeks Exclusion criteria: Pregnancy, suicide risk, serious illness, active substance abuse disorder, history of clozapine, other agents to manage anxiety, other axis I Interventions: Placebo 0.25-2 mg/days flexible dose for 4 weeks vs Risperidone 0.25-2 mg/days flexible dose for 4 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42 days | Results: Anxiety: Change in HAM-A (% Responder) at 6 weeks: Risperidone vs Placebo - RR = 0.99 ( 0.78 , 1.25 ) Withdrawals: Placebo augmentation vs Risperidone augmentation Withdrawals:21.1%(41/194) vs 23.5%(46/196) Withdrawals Due To Adverse Events:5.2%(10/194) vs 10.7%(21/196)
Pollack et al. 2006^84^ Anxiety Olanzapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 2 Age: Not reported Sex: Mixed Race: Not reported Screened: 46 Eligible: 24 Entering: 24 Withdrawn: NR Lost to follow-up: NR Analyzed: 17 Method of AE assessment: Monitored | Inclusion criteria: 18-72 DSM-IV generalized anxiety disorder comorbid depression on dysthymia and other anxiety disorders except for PTSD and OCD if GAD was considered primary by the clinician and patient based on disorder severity and associated distress. Exclusion criteria: Bipolar or psychotic disorders, alcohol or substance abuse or dependence within the last 6 months or those receiving concurrent structured psychotherapies directed at the GAD. Interventions: Placebo for 6 weeks vs Olanzapine 2.5-20 mg/days flexible dose for 6 weeks Run-in/wash-out period: Run-in: Fluoxetine for 6 week(s). Symptomatic patients were randomized. Comorbidities: Depression Timing of outcome assessment: 42, 84 days | Results: Anxiety: Change in HAM-A (% Responder) at 6 weeks: Olanzapine vs Placebo - RR = 6.67 ( 0.93 , 47.59 ) Adverse Events: Olanzapine vs Placebo At Least One AE: 100.0%(12/12) vs 100.0%(12/12) Gained =7% Of Their Body Weight: 16.7%(2/12) vs 0.0%(0/12) Gastrointestinal Distress: 33.3%(4/12) vs 25.0%(3/12) Increased Appetite: 25.0%(3/12) vs 16.7%(2/12) Sedation: 91.7%(11/12) vs 41.7%(5/12) Sexual Dysfunction: 16.7%(2/12) vs 25.0%(3/12) Weight Gain: 58.3%(7/12) vs 16.7%(2/12) Withdrawals: Olanzapine vs Placebo Withdrawals:41.7%(5/12) vs 16.7%(2/12) Withdrawals Due To Adverse Events:33.3%(4/12) vs 8.3%(1/12) Withdrawals Due to Adverse Events: Sedation:33.3%(4/12) vs 8.3%(1/12)
Simon et al. 2008^85^ Anxiety Quetiapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry Screened: 101 Eligible: 24 Entering: 22 Withdrawn: 6 Lost to follow-up: NR Analyzed: 16 Method of AE assessment: Monitored, elicited by investigator | Inclusion criteria: Did not receive remission of GAD in >=18 Exclusion criteria: <= 7 HAM-A, pregnant / lactating, MD, dysthymia, panic, social phobia, bipolar, psychotic, PTSD, OCD, alcohol or substance abuse / dependence 6 month prior, unstable illness Interventions: Placebo for 8 weeks vs Quetiapine 25-400 mg/days flexible dose for 8 weeks Run-in/wash-out period: Run-in: SRI monotherapy for 10 week(s). Non-responders were randomized. Comorbidities: Anxiety, Depression Timing of outcome assessment: 56 days | Results: Anxiety: Change in HAM-A (Total Score) at 8 weeks: Quetiapine vs Placebo - WMD = -2.36 ( -7.99 , 3.27 ) Adverse Events: Placebo+Paroxetine vs Placebo+Paroxetine vs Quetiapine+Paroxetine vs Quetiapine+Paroxetine Diarrhea: 0.0%(0/11) vs 18.2%(2/11) vs 27.3%(3/11) vs 0.0%(0/11) Placebo+Paroxetine vs Quetiapine+Paroxetine Constipation: 18.2%(2/11) vs 0.0%(0/11) Dry Mouth: 0.0%(0/11) vs 27.3%(3/11) Insomnia: 27.3%(3/11) vs 0.0%(0/11) Nausea: 0.0%(0/11) vs 18.2%(2/11) Sedation: 0.0%(0/11) vs 54.5%(6/11) Sexual Dysfunction: 18.2%(2/11) vs 18.2%(2/11) Vivid Dreams: 27.3%(3/11) vs 0.0%(0/11) Weight Gain: 18.2%(2/11) vs 0.0%(0/11) Withdrawals: Placebo+Paroxetine vs Quetiapine+Paroxetine Withdrawals:9.1%(1/11) vs 45.5%(5/11) Withdrawals Due To Adverse Events:9.1%(1/11) vs 36.4%(4/11)
Vaishnavi et al. 2007^89^ Anxiety Quetiapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 4 Age: Not reported Sex: Mixed Race: Caucasian, Other-NOS Screened: NR Eligible: NR Entering: 15 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: 18-65, outpatients, social anxiety disorder, CGI-S>=4, –BSPS>=20, negative pregnancy test Exclusion criteria: Bipolar, schizophrenia or other psychotic disorder, mental retardation, pervasive developmental disorder, cognitive disorder due to general medical condition, other anxiety disorder, MDD, history of substance dependence 6 month prior, suicide risk, medical illness, psychotropic medication and history of hypersensitivity to quetiapine Interventions: Placebo 50-400 mg/days flexible dose for 8 weeks vs Quetiapine 50-400 mg/days flexible dose for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 21, 35, 56 days | Results: Anxiety: Change in BSPS at 8 weeks: Quetiapine vs Placebo - WMD = 30.50 ( 16.86 , 44.14 ) Adverse Events: Quetiapine vs Placebo Blurred Vision: 10.0%(1/10) vs 0.0%(0/5) Dizziness: 30.0%(3/10) vs 0.0%(0/5) Drowsiness: 50.0%(5/10) vs 0.0%(0/5) Headache: 10.0%(1/10) vs 0.0%(0/5) Nausea: 20.0%(2/10) vs 0.0%(0/5) Sweating: 10.0%(1/10) vs 0.0%(0/5) Swelling: 10.0%(1/10) vs 0.0%(0/5) Thirst: 10.0%(1/10) vs 0.0%(0/5) Tinnitus: 10.0%(1/10) vs 0.0%(0/5)
Merideth et al. 2008^87^ Anxiety Quetiapine Location: Not reported Trial: D1448C00010 Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 2 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: NR Entering: 854 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: DSM-IV diagnosis of GAD, HAM-A total score >=20 with item 1 and item 2 scores >=2, CGI- S >=4, MADRS <=16 Exclusion criteria: Not reported Interventions: Placebo for 8 weeks vs Escitalopram 10 mg/days frequency not reported for 8 weeks vs Quetiapine 150 mg/days frequency not reported for 8 weeks vs Quetiapine 300 mg/days frequency not reported for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 4, 56 days | Results: Anxiety: Change in HAM-A (% Responder) at 8 weeks: Quetiapine vs Placebo - RR = 1.46 ( 1.21 , 1.76 )
Joyce et al. 2008^94^ Anxiety Quetiapine Location: US Trial: D1448C00009 Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 2 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: NR Entering: 710 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: Not reported Exclusion criteria: Not reported Interventions: Placebo for 8 weeks vs Quetiapine 50 mg/days frequency not reported for 8 weeks vs Quetiapine 150 mg/days frequency not reported for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 56 days | Results: Anxiety: Change in HAM-A (% Responder) at 8 weeks: Quetiapine vs Placebo - RR = 1.02 ( 0.85 , 1.21 )
Lohoff et al. 2010^100^ Anxiety Ziprasidone Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Single setting Jadad: 4 Age: Not reported Sex: Race: Not reported Screened: 73 Eligible: NR Entering: 62 Withdrawn: 12 Lost to follow-up: 3 Analyzed: 47 Method of AE assessment: Monitored, elicited by investigator | Inclusion criteria: >18 years old, meet DSM-IV criteria for GAD, have treatment failure of >= 1 adequate trial of an SSRI, SNRI, BZ, or combination HAM-A total score >= 16, CGI-S score >=4 Exclusion criteria: Had a history of mania, bipolar disorder, schizophrenia, other psychotic disorders, had a history within 6 months of panic disorder, PTSD, major depression, OCD, social phobia, acute stress disorder, substance abuse, or other psychiatric diagnoses that may interfere with assessment, had clinical significant abnormalities, pregnant Interventions: Placebo 20-80 mg/days flexible dose for 8 weeks vs Ziprasidone 20-80 mg/days flexible dose for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56 days | Results: Anxiety: Change in HAM-A (Total Score) at 8 weeks: Ziprasidone vs Placebo - WMD = -2.80 ( -10.71 , 5.11 ) Anxiety: Change in HAM-A (Total Score) at 8 weeks: Ziprasidone vs Placebo - WMD = 2.83 ( -2.26 , 7.92 ) Adverse Events: Placebo vs Ziprasidone Any Adverse Event: 85.7%(18/21) vs 87.8%(36/41) Blurred Vision: 0.0%(0/21) vs 4.9%(2/41) Constipation: 14.3%(3/21) vs 9.8%(4/41) Depression: 0.0%(0/21) vs 9.8%(4/41) Dermatitis: 9.5%(2/21) vs 0.0%(0/41) Diarrhea: 14.3%(3/21) vs 7.3%(3/41) Dizziness: 4.8%(1/21) vs 17.1%(7/41) Drowsiness: 28.6%(6/21) vs 51.2%(21/41) Dry Mouth: 9.5%(2/21) vs 31.7%(13/41) Excitement: 4.8%(1/21) vs 14.6%(6/41) Headaches: 28.6%(6/21) vs 19.5%(8/41) Insomnia: 9.5%(2/21) vs 29.3%(12/41) Nausea: 9.5%(2/21) vs 14.6%(6/41) Stimulation: 19.0%(4/21) vs 43.9%(18/41) Tacchycardia: 0.0%(0/21) vs 2.4%(1/41) Vivid Dreams: 0.0%(0/21) vs 4.9%(2/41) Weight Gain: 9.5%(2/21) vs 7.3%(3/41) Weight Loss: 4.8%(1/21) vs 2.4%(1/41) Withdrawals: Placebo vs Ziprasidone Withdrawals:9.5%(2/21) vs 31.7%(13/41) Withdrawals Due To Adverse Events:0.0%(0/21) vs 12.2%(5/41)
Katzman et al. 2011^93^ Anxiety Quetiapine Location: US, Canada, Western Europe, Eastern Europe, Australia/New Zealand, Asia Trial: platinum (D1448C00012) Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 4 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Other-NOS Screened: NR Eligible: NR Entering: 432 Withdrawn: 53 Lost to follow-up: 14 Analyzed: 365 Method of AE assessment: Monitored, reported spontaneously by patient | Inclusion criteria: 18-65 years old, DSM-IV-TR diagnosis of GAD, HAM-A total >= 20, HAM-A item 1 and 2 >= 2, CGI-S >= 4 Exclusion criteria: MADRS total >= 17, DSM-IV Axis 1 disorder other than GAD within 6 months, schizophrenia and other psychotic disorders, substance abuse Interventions: Placebo 165.1 mg/days flexible dose for 69 days vs Quetiapine 162.8 (50-300) mg/days flexible dose for 107 days Run-in/wash-out period: Run-in: Quetiapine XR for 4-8 week(s). Patients who met the study criteria were randomized. In Wash-out: Psychotropics for 28 day(s) were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 28, 56, 364 days | Results: Anxiety: Change in HAM-A (Mean Change) at 12 weeks: Quetiapine (varied) vs Placebo - WMD = -2.04 ( -2.09 , -1.99 ) Adverse Events: Placebo Syncope: 0.5%(1/216) Placebo vs Quetiapine XR “treatment-Related Aes”: 22.2%(48/216) vs 24.1%(52/216) Aes “potentially Related To Qt Prolongation Or Agranulocytosis”: 0.0%(0/216) vs 0.0%(0/216) Fatal Saes: 0.0%(0/216) vs 0.0%(0/216) Insomnia: 13.9%(30/216) vs 3.2%(7/216) Neutropenia “possibly Tx Related”: 0.0%(0/216) vs 0.5%(1/216) Non-Fatal Saes: 1.4%(3/216) vs 1.4%(3/216) Saes Reported By >1 Pt: 0.0%(0/216) vs 0.0%(0/216) Sedation, Mild To Moderate In Intensity: 0.0%(0/216) vs 2.3%(5/216) Somnolence, Mild To Moderate In Intensity: 0.0%(0/216) vs 0.9%(2/216) Worsening In Aims Total Score (Items 1-7): 5.1%(11/216) vs 2.3%(5/216) Worsening In Bars Global Assessment Score During Randomized Period: 4.6%(10/216) vs 2.8%(6/216) Worsening In Sas Total Score During Randomized Period: 7.9%(17/216) vs 5.6%(12/216) Quetiapine XR Syncope During The Randomized Period: 0.0%(0/216) Withdrawals: Placebo vs Placebo vs Quetiapine XR vs Quetiapine XR Headache Leading To Withdrawal:12.5%(27/216) vs 0.5%(1/216) vs 8.8%(19/216) vs 0.0%(0/216) Placebo vs Quetiapine XR Akathisia, Not Serious, Did Not Lead To Withdrawal During Randomized Period:0.9%(2/216) vs 0.5%(1/216) Alanine Aminotransferase Increased Leading To Withdrawal:0.5%(1/216) vs 0.0%(0/216) Any Ae Leading To Withdrawal:51.4%(111/216) vs 51.9%(112/216) Aspartate Aminotransferase Increased Leading To Withdrawal:0.5%(1/216) vs 0.0%(0/216) Bladder Cancer Leading To Withdrawal:0.0%(0/216) vs 0.5%(1/216) Epilepsy Leading To Withdrawal:0.0%(0/216) vs 0.5%(1/216) Fatigue Leading To Withdrawal:0.5%(1/216) vs 0.0%(0/216) Glycosylated Hemoglobin Increased Leading To Withdrawal:0.0%(0/216) vs 0.5%(1/216) Insomnia Leading To Withdrawal:1.9%(4/216) vs 0.0%(0/216) Nasopharyngitis Leading To Withdrawal:3.2%(7/216) vs 5.1%(11/216) Nausea Leading To Withdrawal:14.8%(32/216) vs 3.7%(8/216) Non-Fatal Saes Leading To Withdrawal:0.5%(1/216) vs 0.9%(2/216) Pancreatitis Leading To Withdrawal:0.5%(1/216) vs 0.0%(0/216) Pruritus Generalized Leading To Withdrawal:0.5%(1/216) vs 0.0%(0/216) Restlessness, Not Serious, Did Not Lead To Withdrawal During Randomized Period:0.0%(0/216) vs 1.9%(4/216) Somnolence Leading To Withdrawal:0.0%(0/216) vs 0.5%(1/216) Suicidal Behavior Leading To Withdrawal:0.0%(0/216) vs 0.5%(1/216) Tremor, Not Serious, Did Not Lead To Withdrawal During Randomized Period:0.5%(1/216) vs 0.9%(2/216) Withdrawals:55.1%(119/216) vs 25.0%(54/216) Withdrawals Due To Adverse Events:2.8%(6/216) vs 2.3%(5/216)
Altamura et al. 2011^90^ Anxiety Quetiapine Location: Western Europe Trial: Not reported Funding source: Not reported Design: RCT only Setting: Single setting Jadad: 3 Age: Not reported Sex: Mixed Race: Not reported Screened: NR Eligible: NR Entering: 20 Withdrawn: 0 Lost to follow-up: 0 Analyzed: 20 Method of AE assessment: Not reported | Inclusion criteria: GAD per DSM-IV and SCID Exclusion criteria: Concomitant treatment with benzodiazepines, severe medical disease, pregnancy, breast feeding Interventions: Placebo for 8 weeks vs Quetiapine 50 (25-150) mg/days flexible dose for 8 weeks Run-in/wash-out period: Not reported Comorbidities: Depression, OCD, Personality Disorder Timing of outcome assessment: 56 days | Results: Anxiety: Change in HAM-A (% Responder) at 8 weeks: Quetiapine Augmentation vs Placebo - RR = 1.13 ( 0.88 , 1.45 )
Mintzer et al. 2007^107^ Dementia/Agitation Aripiprazole Location: US, Canada, Australia/New Zealand, Latin America, South Africa Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center, Long-term care facilities Jadad: 3 Age: Mean: 56 Sex: Mixed Race: Caucasian, African Ancestry, Hispanic, Asian/Pacific Islander, Other-NOS Screened: 654 Eligible: 487 Entering: 487 Withdrawn: 203 Lost to follow-up: 0 Analyzed: 284 Method of AE assessment: Monitored, other | Inclusion criteria: Diagnosed with AD and delusions / hallucinations. Institutionalized, capable of self-locomotion, MMSE 6-22. NPI-NH score >=6 Exclusion criteria: Delirium, amnestic disorder, bipolar disorder, schizophrenia, mood disorder, non-AD, depression with hallucinations / delusions, history of refractoriness to antipsychotics, suicidal ideation, previous participation in aripiprazole trials, pregnancy. Interventions: Placebo for 10 weeks vs Aripiprazole 2 mg/days fixed single dose for 10 weeks vs Aripiprazole 5 mg/days fixed single dose for 10 weeks vs Aripiprazole 5-10 mg/days fixed single dose for 10 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 42, 56, 70 days | Results: Dementia: Change in CMAI (Agitation) at 10 weeks: Placebo vs Aripriprazole (all doses combined) - SMD = 0.31 ( 0.10 , 0.52 ) Dementia: Change in NPI psy (Psychosis) at 10 weeks: Placebo vs Aripriprazole (all doses combined) - SMD = 0.24 ( 0.03 , 0.45 ) Dementia: Change in NPI total (Total) at 10 weeks: Placebo vs Aripriprazole (all doses combined) - SMD = 0.16 ( -0.05 , 0.37 ) Adverse Events: Aripiprazole 10 mg vs Aripiprazole 10 mg vs Aripiprazole 2 mg vs Aripiprazole 2 mg vs Aripiprazole 5 mg vs Aripiprazole 5 mg vs Placebo vs Placebo Infection: 5.6%(7/126) vs 5.6%(7/126) vs 7.6%(9/118) vs 7.6%(9/118) vs 4.9%(6/122) vs 4.9%(6/122) vs 4.1%(5/121) vs 4.1%(5/121) Aripiprazole 10 mg vs Aripiprazole 2 mg vs Aripiprazole 5 mg vs Placebo Abdominal Pain: 4.0%(5/126) vs 2.5%(3/118) vs 6.6%(8/122) vs 3.3%(4/121) Abnormal Gait: 4.0%(5/126) vs 1.7%(2/118) vs 7.4%(9/122) vs 0.8%(1/121) Accidental Injury: 19.8%(25/126) vs 29.7%(35/118) vs 23.8%(29/122) vs 19.0%(23/121) Agitation: 10.3%(13/126) vs 11.0%(13/118) vs 7.4%(9/122) vs 16.5%(20/121) Anorexia: 5.6%(7/126) vs 8.5%(10/118) vs 4.9%(6/122) vs 10.7%(13/121) Asthenia: 9.5%(12/126) vs 5.9%(7/118) vs 9.0%(11/122) vs 2.5%(3/121) Back Pain: 6.3%(8/126) vs 5.1%(6/118) vs 3.3%(4/122) vs 3.3%(4/121) Confusion: 4.8%(6/126) vs 2.5%(3/118) vs 7.4%(9/122) vs 4.1%(5/121) Conjunctivitis: 2.4%(3/126) vs 5.9%(7/118) vs 2.5%(3/122) vs 2.5%(3/121) Constipation: 3.2%(4/126) vs 5.1%(6/118) vs 4.9%(6/122) vs 5.0%(6/121) Coughing: 5.6%(7/126) vs 5.1%(6/118) vs 3.3%(4/122) vs 5.0%(6/121) Diarrhea: 8.7%(11/126) vs 5.9%(7/118) vs 6.6%(8/122) vs 5.8%(7/121) EPS: 7.1%(9/126) vs 7.6%(9/118) vs 7.4%(9/122) vs 5.8%(7/121) Ecchymosis: 8.7%(11/126) vs 8.5%(10/118) vs 4.9%(6/122) vs 9.9%(12/121) Edema: 1.6%(2/126) vs 5.1%(6/118) vs 3.3%(4/122) vs 1.7%(2/121) Edema, Peripheral: 8.7%(11/126) vs 10.2%(12/118) vs 5.7%(7/122) vs 8.3%(10/121) Extremity Pain: 9.5%(12/126) vs 6.8%(8/118) vs 9.0%(11/122) vs 5.8%(7/121) Headache: 7.1%(9/126) vs 4.2%(5/118) vs 4.1%(5/122) vs 3.3%(4/121) Incidence Of Clinically Significant Weight Gain: 4.0%(5/126) vs 6.8%(8/118) vs 4.1%(5/122) vs 5.8%(7/121) Incidence Of Clinically Significant Weight Loss: 11.1%(14/126) vs 10.2%(12/118) vs 13.1%(16/122) vs 14.9%(18/121) Increased Salivation: 1.6%(2/126) vs 1.7%(2/118) vs 7.4%(9/122) vs 0.8%(1/121) Insomnia: 4.8%(6/126) vs 9.3%(11/118) vs 5.7%(7/122) vs 8.3%(10/121) Lightheadedness: 3.2%(4/126) vs 5.1%(6/118) vs 4.1%(5/122) vs 0.0%(0/121) Rash: 7.9%(10/126) vs 9.3%(11/118) vs 9.0%(11/122) vs 8.3%(10/121) Skin Ulcer: 8.7%(11/126) vs 10.2%(12/118) vs 11.5%(14/122) vs 7.4%(9/121)
Mintzer et al. 2007^107^ Continued | | Somnolence: 7.1%(9/126) vs 3.4%(4/118) vs 9.8%(12/122) vs 3.3%(4/121) Upper Respiratory Infection: 4.8%(6/126) vs 8.5%(10/118) vs 4.9%(6/122) vs 5.0%(6/121) Urinary Incontinence: 5.6%(7/126) vs 1.7%(2/118) vs 9.8%(12/122) vs 1.7%(2/121) Urinary-Tract Infection: 19.8%(25/126) vs 16.1%(19/118) vs 18.9%(23/122) vs 13.2%(16/121) Vomiting: 6.3%(8/126) vs 11.0%(13/118) vs 9.0%(11/122) vs 6.6%(8/121) Weight Loss: 4.0%(5/126) vs 5.1%(6/118) vs 4.9%(6/122) vs 3.3%(4/121) Withdrawals: Aripiprazole 10 mg vs Aripiprazole 2 mg vs Aripiprazole 5 mg vs Placebo Withdrawals:45.2%(57/126) vs 34.7%(41/118) vs 40.2%(49/122) vs 46.3%(56/121) Withdrawals Due To Adverse Events:24.6%(31/126) vs 7.6%(9/118) vs 18.0%(22/122) vs 13.2%(16/121)
Naber et al. 2007^128^ Dementia/Agitation Risperidone Location: Not reported Trial: Not reported Funding source: Industry Design: RCT only Setting: Community practice Jadad: 3 Age: Mean: 49 Sex: Mixed Race: Not reported Screened: NR Eligible: NR Entering: 815 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Not reported | Inclusion criteria: >=55, ICD-10 diagnosis of unspecified organic personality and behavioral disorder due to brain disease, damage and dysfunction, specific symptoms on PANSS Exclusion criteria: Not reported Interventions: Placebo for 12 weeks vs Risperidone 0.5-4 mg/days flexible dose for 12 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56, 84 days | Results: Dementia: No data Adverse Events: Placebo vs Risperidone Aes “related To Study Medication”: 23.6%(48/203) vs 24.8%(152/612) Aes That Occurred In >5% Of Each Group: 0.0%(0/203) vs 0.0%(0/612) All Cardiovascular Adverse Events (Cae): 1.0%(2/203) vs 0.7%(4/612) Cardiovascular Adverse Event: Hospitalized After 74 D Treatment Due To Transient Speech Disorder And Disorientation; Diagnosed With Transient Ischemic Attack (Article Says “doubtful” It Was Related To Tx): 0.5%(1/203) vs 0.0%(0/612) Cardiovascular Adverse Event: Left Ventricular Failure And Acute Dextrocerebral Insult After 33 D Treatment; Died 2 D Later (Article Says Unrelated To Tx): 0.5%(1/203) vs 0.0%(0/612) Cardiovascular Adverse Event: Mild Unrest, Anxiety, Fear Of Drugs At End Of Week 3 Of Treatment; Could Not Speak For 1 D After 43 D Of Treatment; Suspected Transient Ischemic Attack; Medication Continued And Patient Completed Study (Article Says Unrelated To Tx): 0.0%(0/203) vs 0.2%(1/612) Cardiovascular Adverse Event: Mild Vertigo After 27 D Treatment, Diagnosed As Cerebral Circulatory Disorder With Suspicion Of Prolonged Reversible Ischemic Neurologic Deficit; Event Resolved After 6 D And Patient Continued Study (Article Says “possibly” Related To Tx): 0.0%(0/203) vs 0.2%(1/612) Cardiovascular Adverse Event: Paraesthesia In Extremities After 13 D Treatment, Transient Ischemic Attack Suspected And Patient, Hospitalized; Event Resolved After 36 D (Articles Says Unrelated To Tx): 0.0%(0/203) vs 0.2%(1/612) Cardiovascular Adverse Event: Transient Ischemic Attack After 89 D Treatment; Hospitalized For 6 D (Article Says Unrelated To Tx): 0.0%(0/203) vs 0.2%(1/612) Death During The Study Or Within 32 Days Of Study End (Article Says Unrelated To Study Medication): 2.5%(5/203) vs 0.8%(5/612) Eps Occurrence: 0.5%(1/203) vs 2.0%(12/612) Frequency Of Adverse Events: 31.5%(64/203) vs 35.0%(214/612) Withdrawals: Placebo vs Risperidone Withdrawals:10.3%(21/203) vs 9.8%(60/612) Withdrawals Due To Adverse Events:6.4%(13/203) vs 6.5%(40/612)
Zhong et al. 2007^122^ Dementia/Agitation Quetiapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center, Long-term care facilities Jadad: 5 Age: Mean: 56 Sex: Mixed Race: Caucasian, African Ancestry, Hispanic, Asian/Pacific Islander, Other-NOS Screened: 435 Eligible: NR Entering: 333 Withdrawn: 118 Lost to follow-up: NR Analyzed: 215 Method of AE assessment: Monitored | Inclusion criteria: Institutionalized, diagnosed possible AD or vascular dementia, age >= 55, ambulatory, agitation that didn't result directly from participants medical condition, PANSS-EC total >= 14, one of the 5 PANSS-EC items >= 4. Exclusion criteria: History of schizophrenia, schizoaffective or bipolar disorder, agitation not related to dementia, failure to respond to a prior adequate AAP trial for agitation, unstable medical illness, abnormal ECG results. Interventions: Placebo for 10 weeks vs Quetiapine 25-100 mg/days fixed titration schedule for 10 weeks vs Quetiapine 25-200 mg/days fixed titration schedule for 10 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 28, 42, 56, 70 days | Results: Dementia: Change in NPI agitation (Agitation) at 10 weeks: Placebo vs Quetiapine (all doses combined) - SMD = -0.03 ( -0.27 , 0.21 ) Dementia: Change in NPI psy (Psychosis) at 10 weeks: Placebo vs Quetiapine (all doses combined) - SMD = -0.03 ( -0.27 , 0.21 ) Dementia: Change in NPI total (Total) at 10 weeks: Placebo vs Quetiapine (all doses combined) - SMD = 0.04 ( -0.21 , 0.28 ) Adverse Events: Placebo vs Quetiapine 100 mg vs Quetiapine 200 mg Any Adverse Events: 80.4%(74/92) vs 80.6%(100/124) vs 84.6%(99/117) Cardiovascular: 4.3%(4/92) vs 1.6%(2/124) vs 5.1%(6/117) Constipation: 1.1%(1/92) vs 5.6%(7/124) vs 6.0%(7/117) Decreased Appetite: 3.3%(3/92) vs 1.6%(2/124) vs 6.0%(7/117) EPS: 5.4%(5/92) vs 4.8%(6/124) vs 6.8%(8/117) Fall: 26.1%(24/92) vs 25.8%(32/124) vs 26.5%(31/117) Gait Abnormalities: 0.0%(0/92) vs 4.8%(6/124) vs 5.1%(6/117) Headache: 3.3%(3/92) vs 5.6%(7/124) vs 3.4%(4/117) Lethargy: 3.3%(3/92) vs 6.5%(8/124) vs 11.1%(13/117) Nausea: 2.2%(2/92) vs 5.6%(7/124) vs 4.3%(5/117) Peripheral Edema: 6.5%(6/92) vs 7.3%(9/124) vs 5.1%(6/117) Sedation: 3.3%(3/92) vs 3.2%(4/124) vs 7.7%(9/117) Serious Adverse Events: 9.8%(9/92) vs 11.3%(14/124) vs 6.8%(8/117) Skin Laceration: 14.1%(13/92) vs 15.3%(19/124) vs 11.1%(13/117) Somnolence: 2.2%(2/92) vs 8.1%(10/124) vs 9.4%(11/117) Upper Respiratory Tract Infection: 4.3%(4/92) vs 4.8%(6/124) vs 5.1%(6/117) Urinary Tract Infection: 7.6%(7/92) vs 16.1%(20/124) vs 7.7%(9/117) Vomiting: 3.3%(3/92) vs 5.6%(7/124) vs 9.4%(11/117) Weight Decreased: 5.4%(5/92) vs 4.0%(5/124) vs 3.4%(4/117) Withdrawals: Placebo vs Quetiapine 100 mg vs Quetiapine 200 mg Withdrawals:34.8%(32/92) vs 34.7%(43/124) vs 36.8%(43/117) Withdrawals Due To Adverse Events:9.8%(9/92) vs 8.1%(10/124) vs 14.5%(17/117)
Streim et al. 2008^108^ Dementia/Agitation Aripiprazole Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center, Long-term care facilities Jadad: 3 Age: Mean: 59 Sex: Mixed Race: Caucasian, African Ancestry, Hispanic, Asian/Pacific Islander Screened: 330 Eligible: 256 Entering: 256 Withdrawn: 105 Lost to follow-up: 0 Analyzed: 151 Method of AE assessment: Monitored | Inclusion criteria: Age 55-95 with AD, had psychotic symptoms for greater than/equal to 1month, institutionalized for more than 4 weeks, have a MMSE score 6-22 and NPI-NH>=6 Exclusion criteria: Delirium or schizophrenia, mood disorder, continuous symptoms of psychosis before dementia, psychotic symptoms better accounted for any drug, depression with symptoms of psychosis, non-AD-type dementia, seizure, unstable thyroid pathology, suicide intention, potential to subject to AE, had participated in clinical study Interventions: Placebo for 10 weeks vs Aripiprazole 0.7-15 mg/days flexible dose for 10 weeks Run-in/wash-out period: Wash-out: No drug for 7 day(s). Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 42, 56, 70 days | Results: Dementia: Change in CMAI (Agitation) at 10 weeks: Placebo vs Aripriprazole flexible dose - SMD = 0.30 ( 0.05 , 0.55 ) Dementia: Change in NPI psy (Psychosis) at 10 weeks: Placebo vs Aripriprazole flexible dose - SMD = -0.02 ( -0.27 , 0.23 ) Dementia: Change in NPI total (Total) at 10 weeks: Placebo vs Aripriprazole flexible dose - SMD = 0.36 ( 0.11 , 0.61 ) Adverse Events: Aripiprazole vs Placebo Accidental Injury: 20.6%(27/131) vs 28.8%(36/125) Agitation: 7.6%(10/131) vs 12.0%(15/125) Asthenia: 12.2%(16/131) vs 6.4%(8/125) Cerebrovascular Accident: 0.0%(0/131) vs 0.8%(1/125) EPS-Related Adverse Events: 5.3%(7/131) vs 4.0%(5/125) Ecchymosis: 12.2%(16/131) vs 12.8%(16/125) Orthostatic Events (Hypotension Or Syncope): 3.1%(4/131) vs 4.8%(6/125) Potentially Clinically Significant Increases In QTc Interval: 1.5%(2/131) vs 0.8%(1/125) Potentially Significant Low Hemoglobin Levels: 10.7%(14/131) vs 6.4%(8/125) Rash: 9.9%(13/131) vs 12.0%(15/125) Serious Adverse Events Of Accidental Injury: 1.5%(2/131) vs 4.8%(6/125) Somnolence: 13.7%(18/131) vs 4.0%(5/125) Total Serious Adverse Events: 12.2%(16/131) vs 13.6%(17/125) Ulcer Skin: 9.2%(12/131) vs 12.0%(15/125) Urinary Tract Infection: 13.7%(18/131) vs 10.4%(13/125) Vomiting: 9.9%(13/131) vs 8.0%(10/125) Withdrawals: Aripiprazole vs Placebo Death During The Study Or Within 30 Days Of Withdrawal:2.3%(3/131) vs 2.4%(3/125) Withdrawals:33.6%(44/131) vs 48.8%(61/125) Withdrawals Due To Abnormal Lab Test Results:0.0%(0/131) vs 0.0%(0/125) Withdrawals Due To Adverse Events:13.0%(17/131) vs 8.0%(10/125) Withdrawals Due To ECG Abnormality Including Prolongation Of The QTc Interval:0.0%(0/131) vs 0.0%(0/125) Withdrawals Due To Weight Loss:0.0%(0/131) vs 0.0%(0/125)
Rappaport et al. 2009^109^ Dementia/Agitation Aripiprazole Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 80 Sex: Mixed Race: Caucasian, African Ancestry, Hispanic, Other-NOS Screened: 150 Eligible: 129 Entering: 116 Withdrawn: 2 Lost to follow-up: 0 Analyzed: 115 Method of AE assessment: Monitored | Inclusion criteria: Diagnosed with AD, vascular, or mixed dementia, in healthcare facilities, moderate to severe acute exacerbation of agitated behaviors, able to comply with protocol Exclusion criteria: Other major psychiatric disorders, history of neuroleptic malignant syndrome, seizure, stroke, severe head trauma Interventions: Placebo for 24 hours vs Aripiprazole 5 mg/Not reported average final dose for 24 hours vs Aripiprazole 10 mg/Not reported average final dose for 24 hours Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 2, 4, 6, 12, 24 hours | Results: Dementia: Change in ACES (Agitation) at 0.14 weeks: Placebo vs Aripriprazole (all doses combined) - SMD = 5.00 ( 4.24 , 5.76 ) Adverse Events: Aripiprazole 10 mg vs Aripiprazole 15 mg vs Aripiprazole 5 mg vs Placebo Agitation: 1.3%(1/78) vs 0.0%(0/13) vs 0.0%(0/12) vs 7.7%(2/26) Any Adverse Event: 52.6%(41/78) vs 69.2%(9/13) vs 50.0%(6/12) vs 30.8%(8/26) Cerebrovascular AE (Acute Stroke) 16 Days After Treatment (Judged Unlikely To Be Treatment-Related): 1.3%(1/78) vs 0.0%(0/13) vs 0.0%(0/12) vs 0.0%(0/26) Clinically Significant Vital Signs Or Electrocardiograms: 0.0%(0/78) vs 0.0%(0/13) vs 0.0%(0/12) vs 0.0%(0/26) Death 24 Days After Treatment (Not Reasonably Linked To Study Medication): 1.3%(1/78) vs 0.0%(0/13) vs 0.0%(0/12) vs 0.0%(0/26) Dementia: 0.0%(0/78) vs 0.0%(0/13) vs 25.0%(3/12) vs 0.0%(0/26) EPS: 0.0%(0/78) vs 0.0%(0/13) vs 0.0%(0/12) vs 0.0%(0/26) Electrocardiogram Change: 0.0%(0/78) vs 7.7%(1/13) vs 0.0%(0/12) vs 0.0%(0/26) Fall: 0.0%(0/78) vs 7.7%(1/13) vs 0.0%(0/12) vs 3.8%(1/26) Femoral Neck Fracture: 0.0%(0/78) vs 7.7%(1/13) vs 0.0%(0/12) vs 0.0%(0/26) Insomnia: 2.6%(2/78) vs 7.7%(1/13) vs 0.0%(0/12) vs 0.0%(0/26) Irregular Heart Rate: 0.0%(0/78) vs 7.7%(1/13) vs 0.0%(0/12) vs 0.0%(0/26) Lethargy: 0.0%(0/78) vs 7.7%(1/13) vs 0.0%(0/12) vs 0.0%(0/26) Pyrexia: 0.0%(0/78) vs 7.7%(1/13) vs 0.0%(0/12) vs 0.0%(0/26) Serious AE: 7.7%(6/78) vs 7.7%(1/13) vs 25.0%(3/12) vs 7.7%(2/26) Skin Laceration: 1.3%(1/78) vs 7.7%(1/13) vs 0.0%(0/12) vs 7.7%(2/26) Somnolence: 38.5%(30/78) vs 38.5%(5/13) vs 16.7%(2/12) vs 7.7%(2/26) Vomiting: 3.8%(3/78) vs 0.0%(0/13) vs 8.3%(1/12) vs 0.0%(0/26) Withdrawals: Aripiprazole 10 mg vs Aripiprazole 15 mg vs Aripiprazole 5 mg vs Placebo Femoral Neck Fracture Resulting From A Fall On Wet Floor And Leading To Withdrawal:0.0%(0/78) vs 7.7%(1/13) vs 0.0%(0/12) vs 0.0%(0/26) Withdrawals:0.0%(0/78) vs 7.7%(1/13) vs 0.0%(0/12) vs 3.8%(1/26) Withdrawals Due To Adverse Events:0.0%(0/78) vs 7.7%(1/13) vs 0.0%(0/12) vs 0.0%(0/26)
Paleacu et al. 2008^123^ Dementia/Agitation Quetiapine Location: Israel Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 3 Age: Not reported Sex: Mixed Race: Not reported Screened: 44 Eligible: 40 Entering: 40 Withdrawn: 12 Lost to follow-up: 1 Analyzed: 27 Method of AE assessment: Monitored, reported spontaneously by patient | Inclusion criteria: AD with BPSD, age > 50, MMSE < 24, NPI > 6 on any item Exclusion criteria: Other types of dementia, malignancy, heart disease, women of child-bearing potential, alcohol or drug abuse Interventions: Placebo for 6 weeks vs Quetiapine 50-300 mg/days flexible dose for 6 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42 days | Results: Dementia: Change in NPI agitation (Agitation) at 6 weeks: Placebo vs Quetiapine - SMD = -0.48 ( -1.11 , 0.15 ) Adverse Events: Quetiapine vs Placebo Akathisia: 0.0%(0/20) vs 5.0%(1/20) Confusion Urinary Tract Infection: 5.0%(1/20) vs 0.0%(0/20) Diarrhea: 0.0%(0/20) vs 5.0%(1/20) Dizziness: 0.0%(0/20) vs 5.0%(1/20) Dry Mouth: 5.0%(1/20) vs 0.0%(0/20) Edema: 0.0%(0/20) vs 5.0%(1/20) Elevated Systolic Bp (190/90): 5.0%(1/20) vs 0.0%(0/20) Falls: 0.0%(0/20) vs 10.0%(2/20) Headaches: 5.0%(1/20) vs 0.0%(0/20) Parkinsonism: 5.0%(1/20) vs 5.0%(1/20) Sedation: 5.0%(1/20) vs 0.0%(0/20) Tremor: 0.0%(0/20) vs 5.0%(1/20) Withdrawals: Quetiapine vs Placebo Withdrawals:40.0%(8/20) vs 25.0%(5/20) Withdrawals Due To Adverse Events:5.0%(1/20) vs 5.0%(1/20)
Mintzer et al. 2006^129^ Dementia/Agitation Risperidone Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center, Long-term care facilities Jadad: 3 Age: Mean: 83 Sex: Mixed Race: Caucasian, African Ancestry, Hispanic, Asian/Pacific Islander, Other-NOS Screened: 560 Eligible: 473 Entering: 473 Withdrawn: 117 Lost to follow-up: 1 Analyzed: 354 Method of AE assessment: Monitored | Inclusion criteria: >= 55 years old, residents of nursing homes or long-term care facilities, mobile, met the criteria for psychosis of AD, in need of treatment with an atypical antipsychotic, scored >=2 on any item of the BEHAVE-AD psychosis subscale, MMSE 5-23 Exclusion criteria: Recently treated with neuroleptic injections, had other medical conditions that diminish cognition, had other psychiatric disorders that produce psychotic symptoms, patients with epilepsy, cancer, unstable medical conditions Interventions: Placebo for 8 weeks vs Risperidone 0.5-2.5 mg/days flexible dose for 8 weeks Run-in/wash-out period: Run-in: Placebo for 1-16 day(s). Patients still eligible after washout were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 42, 56 days | Results: Dementia: Change in BEHAVE-AD agg (Agitation) at 8 weeks: Placebo vs Risperidone - SMD = 0.04 ( -0.16 , 0.23 ) Dementia: Change in BEHAVE-AD psy (Psychosis) at 8 weeks: Placebo vs Risperidone - SMD = 0.17 ( -0.02 , 0.36 ) Dementia: Change in BEHAVE-AD total (Total) at 8 weeks: Placebo vs Risperidone - SMD = -0.01 ( -0.21 , 0.18 ) Adverse Events: Placebo vs Risperidone Agitation: 6.7%(16/238) vs 8.1%(19/235) Any Adverse Event: 63.9%(152/238) vs 74.5%(175/235) Death: 0.0%(0/238) vs 0.9%(2/235) Edema-Related: 4.6%(11/238) vs 5.1%(12/235) Extrapyramidal Symptoms-Related: 3.4%(8/238) vs 8.5%(20/235) Fall: 12.6%(30/238) vs 11.1%(26/235) Glucose-Related: 2.1%(5/238) vs 1.7%(4/235) Hematoma: 5.0%(12/238) vs 3.4%(8/235) Injury: 10.5%(25/238) vs 9.4%(22/235) Insomnia: 5.9%(14/238) vs 5.5%(13/235) Potentially Prolactin-Related: 0.0%(0/238) vs 0.0%(0/235) Serious Adverse Event: 13.0%(31/238) vs 14.0%(33/235) Somnolence: 4.6%(11/238) vs 16.2%(38/235) Stroke: 0.4%(1/238) vs 0.4%(1/235) Tardive Dyskinesia: 0.0%(0/238) vs 0.0%(0/235) Transient Ischemic Attack: 0.0%(0/238) vs 1.3%(3/235) Urinary Tract Infection: 10.1%(24/238) vs 9.4%(22/235) Withdrawals: Placebo vs Risperidone Withdrawals:24.8%(59/238) vs 25.1%(59/235) Withdrawals Due To Adverse Events:10.1%(24/238) vs 10.6%(25/235)
Cutler et al. 2009^171^ Depression Quetiapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 5 Age: Mean: 18 Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Other-NOS Screened: 912 Eligible: NR Entering: 612 Withdrawn: 138 Lost to follow-up: 32 Analyzed: 370 Method of AE assessment: Monitored, elicited by investigator | Inclusion criteria: 18-65 years old, diagnosed MDD, HAM-D total score >=22, HAM-D item 1 score >=>= at enrollment and randomization Exclusion criteria: DSM-IV AXIS I/II disorders duration of current MDD >= 12 months or <=4 weeks, inadequate response to at least 6 weeks of treatment with 2 or more classes of antidepressants during current episode, clinically significant medical illness, psychotic feature Interventions: Placebo for 6 weeks vs Quetiapine 50-150 mg/days fixed titration schedule for 6 weeks vs Quetiapine 50-300 mg/days fixed titration schedule for 6 weeks vs Haldol 60 mg/days fixed single dose for 6 weeks Run-in/wash-out period: Wash-out: No drug for 7-28 day(s). Eligible patents were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 28, 42, 56 days | Results: Depression: Change in MADRS (% Remitted) at 6 weeks: Quetiapine vs Placebo - RR = 1.43 ( 1.03 , 2.06 ) Depression: Change in MADRS (% Responder) at 6 weeks: Quetiapine vs Placebo - RR = 1.51 ( 1.20 , 1.91 ) Adverse Events: Duloxetine 60 mg/d vs Placebo vs Quetiapine 150 mg/d vs Quetiapine 300 mg/d >= 7% Increase In Body Weight: 0.7%(1/151) vs 0.0%(0/157) vs 2.0%(3/152) vs 3.3%(5/152) Abnormal Dreams: 2.6%(4/151) vs 0.6%(1/157) vs 6.6%(10/152) vs 2.0%(3/152) Clinically Important Elevated Glucose (=126 mg/dL) at endpoint: 0.7%(1/151) vs 0.6%(1/157) vs 2.0%(3/152) vs 3.9%(6/152) Constipation: 11.3%(17/151) vs 6.4%(10/157) vs 5.9%(9/152) vs 8.6%(13/152) Decreased Appetite: 5.3%(8/151) vs 0.6%(1/157) vs 3.3%(5/152) vs 0.0%(0/152) Diarrhea: 10.6%(16/151) vs 6.4%(10/157) vs 4.6%(7/152) vs 2.6%(4/152) Dizziness: 16.6%(25/151) vs 10.8%(17/157) vs 14.5%(22/152) vs 19.1%(29/152) Dry Mouth: 18.5%(28/151) vs 8.9%(14/157) vs 33.6%(51/152) vs 38.2%(58/152) Dyspepsia: 5.3%(8/151) vs 3.2%(5/157) vs 3.9%(6/152) vs 5.3%(8/152) Fatigue: 6.6%(10/151) vs 0.0%(0/157) vs 2.6%(4/152) vs 5.3%(8/152) Headache: 17.9%(27/151) vs 10.2%(16/157) vs 10.5%(16/152) vs 9.2%(14/152) Hyperhidrosis: 7.3%(11/151) vs 0.6%(1/157) vs 0.0%(0/152) vs 0.0%(0/152) Increased Appetite: 2.0%(3/151) vs 1.9%(3/157) vs 5.9%(9/152) vs 3.9%(6/152) Insomnia: 14.6%(22/151) vs 7.0%(11/157) vs 1.3%(2/152) vs 1.3%(2/152) Irritability: 0.0%(0/151) vs 4.5%(7/157) vs 1.3%(2/152) vs 5.9%(9/152) Nausea: 35.8%(54/151) vs 9.6%(15/157) vs 10.5%(16/152) vs 5.3%(8/152) Pollakiuria: 5.3%(8/151) vs 1.3%(2/157) vs 3.3%(5/152) vs 2.0%(3/152) Sedation: 15.9%(24/151) vs 5.1%(8/157) vs 38.8%(59/152) vs 36.8%(56/152) Somnolence: 12.6%(19/151) vs 7.0%(11/157) vs 24.3%(37/152) vs 27.0%(41/152) Upper Respiratory Tract Infection: 4.0%(6/151) vs 7.0%(11/157) vs 2.0%(3/152) vs 2.6%(4/152) Vision Blurred: 2.6%(4/151) vs 1.9%(3/157) vs 5.3%(8/152) vs 5.3%(8/152) Withdrawals: Duloxetine 60 mg/d vs Placebo vs Quetiapine 150 mg/d vs Quetiapine 300 mg/d Withdrawals:30.5%(46/151) vs 21.0%(33/157) vs 34.2%(52/152) vs 25.7%(39/152) Withdrawals Due To Adverse Events:13.2%(20/151) vs 4.5%(7/157) vs 19.7%(30/152) vs 15.1%(23/152) Withdrawals Due To Of Death:0.0%(0/151) vs 0.0%(0/157) vs 0.7%(1/152) vs 0.0%(0/152)
Weisler et al. 2009^172^ Depression Quetiapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 5 Age: Mean: 18 Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Other-NOS Screened: 1075 Eligible: 723 Entering: 723 Withdrawn: 127 Lost to follow-up: 85 Analyzed: 511 Method of AE assessment: Monitored | Inclusion criteria: 18-65, output, MDD, HAM-D item 17>=22, HAM-D item 1>=2 Exclusion criteria: Other axis I disorders during prior 6 month, Axis II impacting status, current MDD episode > 12 months or <4 weeks, inadequate response to adequate antidepressants treatment with >= 2 classes of antidepressants, medical illness, suicide or homicide risk Interventions: Placebo for 6 weeks vs Quetiapine 50 mg/days fixed titration schedule for 6 weeks vs Quetiapine 50-150 mg/days fixed titration schedule for 6 weeks vs Quetiapine 50-300 mg/days fixed titration schedule for 6 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 4, 7, 14, 28, 42 days | Results: Depression: Change in MADRS (% Remitted) at 6 weeks: Quetiapine vs Placebo - RR = 1.27 ( 0.89 , 1.82 ) Depression: Change in MADRS (% Responder) at 6 weeks: Quetiapine vs Placebo - RR = 1.58 ( 1.24 , 2.02 ) Adverse Events: Placebo vs Quetiapine 150mg vs Quetiapine 300mg vs Quetiapine 50mg Any Adverse Event: 67.9%(125/184) vs 87.1%(155/178) vs 87.7%(157/179) vs 80.2%(146/182) Back Pain: 2.2%(4/184) vs 5.6%(10/178) vs 5.0%(9/179) vs 1.6%(3/182) Constipation: 2.7%(5/184) vs 8.4%(15/178) vs 8.9%(16/179) vs 7.1%(13/182) Death: 0.0%(0/184) vs 0.0%(0/178) vs 0.0%(0/179) vs 0.0%(0/182) Diarrhea: 8.7%(16/184) vs 6.2%(11/178) vs 3.4%(6/179) vs 6.6%(12/182) Dizziness: 5.4%(10/184) vs 10.7%(19/178) vs 10.6%(19/179) vs 8.8%(16/182) Dry Mouth: 8.7%(16/184) vs 37.1%(66/178) vs 41.3%(74/179) vs 22.0%(40/182) Dyspepsia: 2.7%(5/184) vs 5.6%(10/178) vs 2.8%(5/179) vs 2.2%(4/182) Fatigue: 4.3%(8/184) vs 7.9%(14/178) vs 6.1%(11/179) vs 6.0%(11/182) Headache: 14.7%(27/184) vs 13.5%(24/178) vs 14.5%(26/179) vs 12.1%(22/182) Increased Appetite: 3.8%(7/184) vs 5.1%(9/178) vs 4.5%(8/179) vs 4.4%(8/182) Insomnia: 7.6%(14/184) vs 6.7%(12/178) vs 6.7%(12/179) vs 4.9%(9/182) Irritability: 3.8%(7/184) vs 5.6%(10/178) vs 3.4%(6/179) vs 6.0%(11/182) Myalgia: 1.6%(3/184) vs 7.3%(13/178) vs 2.2%(4/179) vs 4.4%(8/182) Nausea: 6.0%(11/184) vs 8.4%(15/178) vs 8.9%(16/179) vs 7.7%(14/182) Sedation: 6.0%(11/184) vs 35.4%(63/178) vs 30.7%(55/179) vs 26.9%(49/182) Somnolence: 10.9%(20/184) vs 19.7%(35/178) vs 29.1%(52/179) vs 18.1%(33/182) Vomiting: 2.2%(4/184) vs 2.2%(4/178) vs 6.7%(12/179) vs 1.6%(3/182) Withdrawals: Placebo vs Quetiapine 150mg vs Quetiapine 300mg vs Quetiapine 50mg Withdrawals:27.2%(50/184) vs 30.9%(55/178) vs 33.0%(59/179) vs 26.4%(48/182) Withdrawals Due To Adverse Events:6.0%(11/184) vs 14.0%(25/178) vs 19.0%(34/179) vs 8.2%(15/182)
Chaput et al. 2008^158^ Depression Quetiapine Location: Canada Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 2 Age: Mean: 23 Sex: Mixed Race: Not reported Screened: 40 Eligible: 24 Entering: 22 Withdrawn: NR Lost to follow-up: NR Analyzed: 15 Method of AE assessment: Monitored | Inclusion criteria: MD, HRSD >= 20, CGI-S >=4, 2 classes of antidepressants Exclusion criteria: Suicide risk, pregnant, breast feeding, not on birth control for 3 month prior, bipolar, schizophrenia, personality disorder, panic, anxiety, OCD, somatoformor organic mental disorder, anorexia, bulimia, substance abuse, other psychotropics, unstable medical illness Interventions: Placebo 12.5-200 mg/days flexible dose for 12 weeks vs Quetiapine 12.5-200 mg/days flexible dose for 12 weeks Run-in/wash-out period: Run-in: Lithium for 3 week(s). Non-responders were randomized. In Wash-out: No drug for 8 day(s). Patients still eligible after washout were randomized. Comorbidities: None Timing of outcome assessment: 21, 28, 42, 56, 70, 84, 98 days | Results: Depression: Only data on placebo group reported Adverse Events: Quetiapine/CBT vs. Placebo/CBT Dry Mouth: 36.4%(4/11) vs 9.1%(1/11) Gastrointestinal Discomfort: 18.2%(2/11) vs 27.3%(3/11) Headache: 36.4%(4/11) vs 9.1%(1/11) Insomnia: 45.5%(5/11) vs 18.2%(2/11) Labile Hypertension: 9.1%(1/11) vs 9.1%(1/11) Mild Akathisia And Muscle Rigidity: 0.0%(0/11) vs 9.1%(1/11) Nausea: 18.2%(2/11) vs 18.2%(2/11) Somnolence: 63.6%(7/11) vs 9.1%(1/11) Withdrawals: Quetiapine/CBT vs Placebo/CBT Possible Anomaly Detected At The Week 10 Electrocardiogram That Was Ultimately Found To Be A False Positive Result Leading To Withdrawal:9.1%(1/11) vs 0.0%(0/11) Withdrawals:9.1%(1/11) vs 54.5%(6/11) Withdrawals Due To Adverse Events:0.0%(0/11) vs 0.0%(0/11)
AstraZeneca 2008^173^ Depression Quetiapine Location: US, Canada, Western Europe, South Africa Trial: AMETHYST Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 19 Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Other-NOS Screened: NR Eligible: NR Entering: 776 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: Age 18-65, with DSM-IV diagnosis of MDD together with an acute depressed episode confirmed by MINI, have a current episode of depression >=4 weeks and <12 months in duration, HAM-D total score >=20, HAM-D item 1 score >=2, MADRS score <=12, CGI-S score <=3 Exclusion criteria: Not reported Interventions: Placebo 50-300 mg/days flexible dose for 52 weeks vs Quetiapine 50-300 mg/days flexible dose for 52 weeks Run-in/wash-out period: Run-in: Antipsychotics for 26 week(s). Patients who met the study criteria were randomized. Comorbidities: None Timing of outcome assessment: 364 days | Results: Depression: Change in MADRS (Total) at 52 weeks: Quetiapine vs Placebo - WMD = -1.88 ( -1.91 , -1.85 ) Adverse Events: Placebo Serious AE Leading To Death (Hypertension): 0.3%(1/385) Placebo vs Quetiapine “drug-Related Ae”: 28.3%(109/385) vs 33.0%(129/391) >=15 bpm Increases In Heart Rate: 6.5%(25/385) vs 10.2%(40/391) >=7% Increase In Weight: 2.9%(11/385) vs 5.4%(21/391) AE Potentially Related To Neutropenia Or Agranulocytosis: 0.0%(0/385) vs 0.0%(0/391) AE Potentially Related To Qt Prolongation: 0.0%(0/385) vs 0.0%(0/391) AEs Potentially Related To Nausea And Vomiting: 10.9%(42/385) vs 4.9%(19/391) Anxiety: 2.6%(10/385) vs 1.3%(5/391) Any AE: 60.5%(233/385) vs 62.9%(246/391) Arthralgia: 2.3%(9/385) vs 4.9%(19/391) Back Pain: 2.6%(10/385) vs 3.8%(15/391) Blood Pressure Increased: 0.5%(2/385) vs 2.3%(9/391) Constipation: 0.3%(1/385) vs 2.0%(8/391) Decreases =20 Millimeters Of Mercury In Orthostatic Systolic Blood Pressure: 6.2%(24/385) vs 11.5%(45/391) Diarrhea: 6.8%(26/385) vs 5.4%(21/391) Disturbance In Attention: 0.0%(0/385) vs 0.0%(0/391) Dizziness: 4.4%(17/385) vs 6.6%(26/391) Dry Mouth: 1.6%(6/385) vs 3.6%(14/391) Dyspepsia: 0.0%(0/385) vs 0.0%(0/391) Edema Peripheral: 0.0%(0/385) vs 0.0%(0/391) Fatigue: 2.6%(10/385) vs 4.3%(17/391) Headache: 11.4%(44/385) vs 6.9%(27/391) Incidence Of Syncope: 0.0%(0/385) vs 0.8%(3/391) Increased Appetite: 0.0%(0/385) vs 0.0%(0/391) Increases =15 Bpm In Supine Pulse: 19.2%(74/385) vs 28.1%(110/391) Insomnia: 14.8%(57/385) vs 5.6%(22/391) Irritability: 3.1%(12/385) vs 0.8%(3/391) Lethargy: 0.0%(0/385) vs 0.0%(0/391) Musculoskeletal Pain: 1.3%(5/385) vs 2.0%(8/391) Myalgia: 1.3%(5/385) vs 2.3%(9/391) Nasopharyngitis: 6.5%(25/385) vs 7.2%(28/391) Nausea: 9.9%(38/385) vs 3.6%(14/391) Pain In Extremity: 2.1%(8/385) vs 1.5%(6/391) QTcF Values >=450ms: 2.6%(10/385) vs 2.6%(10/391) Restlessness: 0.0%(0/385) vs 0.0%(0/391) Sedation: 0.3%(1/385) vs 2.6%(10/391) Serious Ae, All: 2.1%(8/385) vs 2.0%(8/391) Sinusitis: 2.3%(9/385) vs 3.1%(12/391) Somnolence: 0.0%(0/385) vs 3.8%(15/391) Tx Emergent Shift From <3 To =3 Metabolic Risk Factors: 12.7%(49/385) vs 17.6%(69/391) Upper Respiratory Tract Infection: 4.2%(16/385) vs 3.8%(15/391) Urinary Tract Infection: 1.0%(4/385) vs 2.3%(9/391) Vision Blurred: 0.0%(0/385) vs 0.0%(0/391) Vomiting: 2.3%(9/385) vs 2.0%(8/391) Weight Increased: 1.6%(6/385) vs 9.7%(38/391) Quetiapine Serious Ae Leading To Death: 0.0%(0/391) Withdrawals: Placebo vs Quetiapine Withdrawals Due To Adverse Events:5.2%(20/385) vs 6.4%(25/391)
AstraZeneca 2008^169^ Depression Quetiapine Location: US, Eastern Europe, Latin America Trial: SAPPHIRE Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 66 Sex: Mixed Race: Caucasian, African Ancestry, Other-NOS Screened: NR Eligible: NR Entering: 338 Withdrawn: NR Lost to follow-up: NR Analyzed: 224 Method of AE assessment: Monitored | Inclusion criteria: Age >=66, DSM-IV diagnosis of MDD confirmed by MINI. HAM-D total score >=22, HAM-D item 1 score >=2 at both enrollment and randomization. Exclusion criteria: Not reported Interventions: Placebo 50-300 mg/days flexible dose for 9 weeks vs Quetiapine 50-300 mg/days flexible dose for 9 weeks Run-in/wash-out period: Wash-out: No drug for 28 day(s). Patients still eligible after washout were randomized. Comorbidities: None Timing of outcome assessment: 7, 63 days | Results: Depression: Change in MADRS (% Remitted) at 9 weeks: Quetiapine vs Placebo - RR = 2.48 ( 1.70 , 3.62 ) Depression: Change in MADRS (% Responder) at 9 weeks: Quetiapine vs Placebo - RR = 2.11 ( 1.63 , 2.71 ) Adverse Events: Placebo vs Quetiapine “drug-Related Ae”: 39.5%(68/172) vs 62.7%(104/166) >=7% Weight Decrease: 1.2%(2/172) vs 0.0%(0/166) >=7% Weight Increase: 0.6%(1/172) vs 0.0%(0/166) AE Potentially Related To Diabetes (Blood Glucose Increased In Patient Who Was Being Treated For Type II Diabetes Prior To And During The Study): 0.0%(0/172) vs 0.6%(1/166) AE Potentially Related To Suicidality: 0.6%(1/172) vs 0.6%(1/166) AEs Potentially Related To Qt Prolongation, Neutropenia/Agranulocytosis, Syncope, Sexual Dysfunction, Or Cerebrovascular Accidents (Eva): 0.0%(0/172) vs 0.0%(0/166) Abdominal Pain Upper: 2.3%(4/172) vs 3.0%(5/166) Any AE: 61.0%(105/172) vs 80.7%(134/166) Asthenia: 0.6%(1/172) vs 3.6%(6/166) Back Pain: 1.2%(2/172) vs 2.4%(4/166) Clinically Important Shift To Low Neutrophil Count At End of Treatment: 0.0%(0/172) vs 1.2%(2/166) Constipation: 2.3%(4/172) vs 6.0%(10/166) Diarrhea: 7.0%(12/172) vs 5.4%(9/166) Dizziness: 15.1%(26/172) vs 19.3%(32/166) Dry Mouth: 10.5%(18/172) vs 20.5%(34/166) Dysgeusia: 0.6%(1/172) vs 2.4%(4/166) Edema Peripheral: 2.3%(4/172) vs 0.0%(0/166) Extrapyramidal Disorder: 0.6%(1/172) vs 3.6%(6/166) Extrapyramidal Symptoms (EPS) Through The End Of The Study: 2.3%(4/172) vs 9.0%(15/166) Fatigue: 4.1%(7/172) vs 7.8%(13/166) Headache: 16.3%(28/172) vs 21.1%(35/166) Hypertension: 2.3%(4/172) vs 1.2%(2/166) Hypotension: 0.0%(0/172) vs 2.4%(4/166) Hypothyroidism: 0.0%(0/172) vs 0.0%(0/166) Insomnia: 5.8%(10/172) vs 7.8%(13/166) Nasopharyngitis: 3.5%(6/172) vs 1.2%(2/166) Nausea: 4.7%(8/172) vs 5.4%(9/166) Pain In Extremity: 1.2%(2/172) vs 2.4%(4/166) Sedation: 1.2%(2/172) vs 4.8%(8/166) Serious AE Leading To Death: 0.0%(0/172) vs 0.0%(0/166) Serious Ae, All: 1.2%(2/172) vs 2.4%(4/166) Somnolence: 8.1%(14/172) vs 33.1%(55/166) Tachycardia: 2.3%(4/172) vs 1.2%(2/166) Treatment-Emergent Clinically Important Triglyceride Values: 5.8%(10/172) vs 13.9%(23/166) Treatment-Emergent Hypothyroidism Based On Clinically Important High Thyroid-Stimulating Hormone (Tsh) Values In Combination With Clinically Important Low Thyroxine (T4) Values: 0.0%(0/172) vs 0.0%(0/166) Treatment-Emergent Shift From <3 To =3 Metabolic Risk Factors: 13.4%(23/172) vs 5.4%(9/166) Weight Increased: 4.1%(7/172) vs 5.4%(9/166) Worsening Of Aims Total Score: 4.7%(8/172) vs 9.0%(15/166) Worsening Of Bars Global Scores: 1.2%(2/172) vs 1.2%(2/166) Worsening Of Sas Total Score: 8.1%(14/172) vs 13.9%(23/166) Quetiapine Extrapyramidal Symptoms (EPS) Only During The Treatment Period: 7.2%(12/166) Withdrawals: Placebo vs Quetiapine Withdrawals:33.7%(58/172) vs 33.7%(56/166) Withdrawals Due To Adverse Events:4.1%(7/172) vs 9.6%(16/166)
AstraZeneca2007^168^ Depression Quetiapine Location: Canada, Western Europe, Asia, Latin America, South Africa Trial: AMBER D1448C00004 Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 18 Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Other-NOS Screened: NR Eligible: NR Entering: 471 Withdrawn: NR Lost to follow-up: NR Analyzed: 223 Method of AE assessment: Monitored | Inclusion criteria: 18-65 years old, DSM-IV diagnosis of MDD, HAM-D score >=22, HAM-D item 1 score >=2 Exclusion criteria: Not reported Interventions: Placebo for 9 weeks vs Quetiapine 50-300 mg/days flexible dose for 9 weeks vs Escitalopram 10-20 mg/days flexible dose for 9 weeks Run-in/wash-out period: Wash-out: No drug for 7-28 day(s). Patients still eligible after washout were randomized. Comorbidities: None Timing of outcome assessment: 14, 56, 70 days | Results: Depression: Change in MADRS (% Remitted) at 8 weeks: Quetiapine vs Placebo - RR = 1.01 ( 0.75 , 1.37 ) Depression: Change in MADRS (% Responder) at 8 weeks: Quetiapine vs Placebo - RR = 1.18 ( 0.97 , 1.45 ) Adverse Events: Escitalopram vs Placebo vs Quetiapine “drug-Related Ae”: 67.5%(106/157) vs 51.6%(81/157) vs 79.6%(125/157) Abdominal Distension: 3.2%(5/157) vs 2.5%(4/157) vs 2.5%(4/157) Abdominal Pain: 3.8%(6/157) vs 3.2%(5/157) vs 4.5%(7/157) Abdominal Pain Upper: 3.2%(5/157) vs 3.8%(6/157) vs 5.7%(9/157) Akathisia: 3.2%(5/157) vs 0.6%(1/157) vs 1.3%(2/157) Anxiety: 4.5%(7/157) vs 2.5%(4/157) vs 7.6%(12/157) Any AE: 80.9%(127/157) vs 72.6%(114/157) vs 86.6%(136/157) Arthralgia: 0.6%(1/157) vs 3.2%(5/157) vs 5.1%(8/157) Chills: 0.6%(1/157) vs 0.6%(1/157) vs 3.2%(5/157) Constipation: 8.3%(13/157) vs 4.5%(7/157) vs 12.7%(20/157) Cough: 3.2%(5/157) vs 1.3%(2/157) vs 3.2%(5/157) Deaths: 0.0%(0/157) vs 0.0%(0/157) vs 0.0%(0/157) Decreased Appetite: 3.2%(5/157) vs 1.9%(3/157) vs 2.5%(4/157) Diarrhea: 12.1%(19/157) vs 7.0%(11/157) vs 12.1%(19/157) Dizziness: 18.5%(29/157) vs 14.0%(22/157) vs 33.8%(53/157) Dry Mouth: 14.0%(22/157) vs 8.3%(13/157) vs 38.2%(60/157) Dyspepsia: 3.2%(5/157) vs 5.7%(9/157) vs 7.6%(12/157) Dyspnea: 0.6%(1/157) vs 2.5%(4/157) vs 3.2%(5/157) Extrapyramidal Disorder: 9.6%(15/157) vs 5.1%(8/157) vs 8.3%(13/157) Fatigue: 8.9%(14/157) vs 5.1%(8/157) vs 12.1%(19/157) Gastroenteritis: 0.6%(1/157) vs 3.2%(5/157) vs 1.9%(3/157) Headache: 31.2%(49/157) vs 31.2%(49/157) vs 26.1%(41/157) Hot Flush: 4.5%(7/157) vs 1.3%(2/157) vs 3.2%(5/157) Hyperhidrosis: 7.6%(12/157) vs 5.7%(9/157) vs 5.1%(8/157) Hypersomnia: 1.3%(2/157) vs 0.6%(1/157) vs 5.7%(9/157) Increased Appetite: 1.9%(3/157) vs 3.8%(6/157) vs 7.0%(11/157) Influenza: 1.9%(3/157) vs 2.5%(4/157) vs 5.1%(8/157) Insomnia: 14.6%(23/157) vs 14.0%(22/157) vs 14.0%(22/157) Irritability: 5.1%(8/157) vs 5.1%(8/157) vs 5.7%(9/157) Musculoskeletal Stiffness: 1.9%(3/157) vs 1.9%(3/157) vs 3.2%(5/157) Myalgia: 7.6%(12/157) vs 3.8%(6/157) vs 7.0%(11/157) Nasal Congestion: 0.0%(0/157) vs 0.6%(1/157) vs 2.5%(4/157) Nasopharyngitis: 4.5%(7/157) vs 5.7%(9/157) vs 1.3%(2/157) Nausea: 29.9%(47/157) vs 19.1%(30/157) vs 21.7%(34/157) Pain In Extremity: 3.8%(6/157) vs 0.6%(1/157) vs 1.9%(3/157) Palpitations: 5.1%(8/157) vs 3.8%(6/157) vs 3.8%(6/157) Paraesthesia: 2.5%(4/157) vs 1.3%(2/157) vs 2.5%(4/157) Rash: 0.6%(1/157) vs 0.0%(0/157) vs 3.2%(5/157) Restlessness: 1.9%(3/157) vs 0.6%(1/157) vs 2.5%(4/157) Sedation: 5.1%(8/157) vs 3.2%(5/157) vs 10.8%(17/157) Serious Ae Leading To Death: 0.0%(0/157) vs 0.0%(0/157) vs 0.0%(0/157) Serious Ae, All: 1.9%(3/157) vs 0.6%(1/157) vs 2.5%(4/157) Somnolence: 8.3%(13/157) vs 3.8%(6/157) vs 35.7%(56/157) Tachycardia: 0.6%(1/157) vs 0.6%(1/157) vs 4.5%(7/157) Thirst: 0.6%(1/157) vs 0.0%(0/157) vs 2.5%(4/157) Vision Blurred: 2.5%(4/157) vs 3.2%(5/157) vs 3.8%(6/157) Vomiting: 3.8%(6/157) vs 1.9%(3/157) vs 5.7%(9/157) Weight Increased: 1.3%(2/157) vs 0.0%(0/157) vs 3.8%(6/157) Withdrawals: Escitalopram vs Placebo vs Quetiapine Withdrawals:56.1%(88/157) vs 53.5%(84/157) vs 48.4%(76/157) Withdrawals Due To Adverse Events:7.0%(11/157) vs 4.5%(7/157) vs 15.9%(25/157)
Bortnick et al. 2011^170^ Depression Quetiapine Location: US Trial: Opal (D1448C00003) Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 4 Age: Mean: 18 Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Other-NOS Screened: 513 Eligible: 310 Entering: 310 Withdrawn: 68 Lost to follow-up: 23 Analyzed: 219 Method of AE assessment: Monitored, elicited by investigator | Inclusion criteria: 18-65 years old, DSM-IV diagnosis of MDD. HAM-D total score >= 22. HAM-D item I >=2 Exclusion criteria: DSM-IV Axis I disorder other than MDD within 6 months. DSM-IV Axis II disorder major impact, substance abuse, HAM-D item 3 >= 3, severe medical illness, ECG significant depression can be no longer than 12 months or less than 4 weeks. Interventions: Placebo for 8 weeks vs Quetiapine 50-300 mg/days flexible dose for 8 weeks Run-in/wash-out period: Wash-out: Psychotropics for 1-4 week(s) were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 28, 42, 56, 70 days | Results: Depression: Change in MADRS (% Remitted) at 8 weeks: Quetiapine vs Placebo - RR = 1.39 ( 0.97 , 1.98 ) Depression: Change in MADRS (% Responder) at 8 weeks: Quetiapine vs Placebo - RR = 1.29 ( 1.05 , 1.59 ) Adverse Events: Excluded from analysis: Constipation: 1.3%(2/156) vs 5.2%(8/154) Dizziness: 3.2%(5/156) vs 7.1%(11/154) Dry Mouth: 6.4%(10/156) vs 32.5%(50/154) Fatigue: 0.0%(0/156) vs 6.5%(10/154) Headache: 10.3%(16/156) vs 10.4%(16/154) Increased Appetite: 1.3%(2/156) vs 6.5%(10/154) Increased Qtc Interval: 0.0%(0/156) vs 0.0%(0/154) Madrs Item 10 (Suicidal Thoughts) Score =4: 0.6%(1/156) vs 2.6%(4/154) Nasal Congestion: 1.9%(3/156) vs 5.2%(8/154) Nasopharyngitis: 7.1%(11/156) vs 2.6%(4/154) Nausea: 5.8%(9/156) vs 4.5%(7/154) Patients Experiencing A =7% Increase In Weight: 1.3%(2/156) vs 2.6%(4/154) Sedation: 1.9%(3/156) vs 21.4%(33/154) Sedation Leading To Discontinuation: 0.6%(1/156) vs 3.9%(6/154) Somnolence: 5.1%(8/156) vs 20.1%(31/154) Somnolence Leading To Discontinuation: 0.0%(0/156) vs 2.6%(4/154) Quetiapine XR Clinically Relevant Differencesin The Mean Change From Baseline To Week 8 In Vital Signs, Hematology, Ecgs Or Clinical Laboratory Parameters.: 0.0%(0/154) Withdrawals: Placebo vs Quetiapine XR Withdrawals:28.8%(45/156) vs 29.9%(46/154) Withdrawals Due To Adverse Events:2.6%(4/156) vs 8.4%(13/154)
Bissada et al. 2008^180^ Eating disorder Olanzapine Location: Canada Trial: Not reported Funding source: Industry Design: RCT only Setting: Single setting Jadad: 3 Age: Not reported Sex: 100% Female Race: Not reported Screened: 147 Eligible: 76 Entering: 34 Withdrawn: 6 Lost to follow-up: 0 Analyzed: 28 Method of AE assessment: Not reported | Inclusion criteria: DSM-IV criteria for anorexia or nervosa (restricting or binge / purge subtype) including a body index <= 17.5 kg/m2 Exclusion criteria: Active suicidal intent, comorbid substance abuse disorder, bipolar disorder, schizophrenia or any other psychotic disorder, organic brain syndromes or dissociative disorders, pregnancy, and failure to use contraception if sexually active Interventions: Placebo for 10 weeks vs Olanzapine 2.5-10 mg/days flexible dose for 10 weeks Run-in/wash-out period: Run-in: No drug for 2 week(s). Comorbidities: Anxiety Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56 days | Results: Eating Disorder: Change in BMI (BMI) at 4 weeks: Olanzapine vs Placebo - WMD = 0.11 ( -0.77 , 0.99 ) Eating Disorder: Change in BMI (BMI) at 12 weeks: Olanzapine vs Placebo - WMD = 0.15 ( -0.80 , 1.10 ) Adverse Events: Olanzapine vs Placebo De Novo Development Of Diabetes Mellitus: 0.0%(0/16) vs 0.0%(0/18) Evidence Of Impaired Glucose Tolerance: 0.0%(0/16) vs 0.0%(0/18) Serious Adverse Events (Extrapyramidal Symptoms, Excessive Sleepiness, Dizziness Or Galactorrhea): 0.0%(0/16) vs 0.0%(0/18) Withdrawals: Olanzapine vs Placebo Withdrawals:12.5%(2/16) vs 22.2%(4/18)
Brambilla et al. 2007^182^ Eating disorder Olanzapine Location: Western Europe Trial: Not reported Funding source: Not reported Design: RCT only Setting: Multi-center Jadad: 2 Age: Not reported Sex: 100% Female Race: Not reported Screened: 35 Eligible: 30 Entering: NR Withdrawn: 5 Lost to follow-up: 0 Analyzed: 30 Method of AE assessment: Not reported | Inclusion criteria: Anorexia nervosa per DSM-IV restricted or binging-purging type Exclusion criteria: General medical impairments, endocrine, metabolic and immune alterations (other than those limited to anorexia nervosa), cerebral trauma, epilepsy Interventions: Placebo for 3 months vs Olanzapine 2.5-5 mg/days fixed titration schedule for 3 months Run-in/wash-out period: Not reported Comorbidities: Anxiety, Depression, OCD, Personality Disorder Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56 days | Results: Eating Disorder: Change in BMI (BMI) at 4 weeks: Olanzapine vs Placebo - WMD = -0.00 ( -0.91 , 0.91 ) Eating Disorder: Change in BMI (BMI) at 12 weeks: Olanzapine vs Placebo - WMD = 0.60 ( -0.55 , 1.75 )
Brambilla et al. 2007^183^ Eating disorder Olanzapine Location: Not reported Trial: Not reported Funding source: Hospital Design: RCT only Setting: Not reported Jadad: 2 Age: Not reported Sex: 100% Female Race: Not reported Screened: 20 Eligible: 20 Entering: 20 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Not reported | Inclusion criteria: Anorexia nervosa according to DSM-IV Exclusion criteria: General medical, neuroendorcine, metabolic, immunologic alterations other than these related to AN, axis axis I and II psychopathologies other than AN. Axis I and II psychopathologies other than AN Interventions: Placebo for 3 months vs Olanzapine 2.5-5 mg/days fixed titration schedule for 3 months Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 30, 61, 91 days | Results: Eating Disorder: Change in BMI (BMI) at 4 weeks: Olanzapine vs Placebo - WMD = -0.20 ( -1.44 , 1.04 ) Eating Disorder: Change in BMI (BMI) at 12 weeks: Olanzapine vs Placebo - WMD = 0.20 ( -1.05 , 1.45 )
Gaskill et al. 2001^184^ Eating disorder Olanzapine Location: US Trial: Not reported Funding source: Not reported Design: CCT only Setting: Single setting Jadad: 0 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: NR Entering: NR Withdrawn: NR Lost to follow-up: NR Analyzed: 46 Method of AE assessment: Not reported | Inclusion criteria: Not reported Exclusion criteria: Not reported Interventions: Control Group vs Olanzapine 1.25-15 mg/days flexible dose for duration not reported Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: days | Results: Eating Disorder: Insufficient data to calculate an effect size
Court et al. 2010^185^ Eating disorder Quetiapine Location: Australia/New Zealand Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Not reported Sex: 80-99% Female Race: Not reported Screened: NR Eligible: 33 Entering: 33 Withdrawn: 12 Lost to follow-up: 0 Analyzed: 21 Method of AE assessment: Monitored, elicited by investigator | Inclusion criteria: Diagnosis of AN per DSM-IV, no previous antipsychotic for > 1 week Exclusion criteria: Atypical antipsychotic >= 7 days, psychotic illness, history of brain infarct or brain surgery, diabetes, IQ < 70 Interventions: Other, Treatment as usual 998 Not reported/Not reported frequency not reported for 12 weeks vs Quetiapine 322.5 150-500 mg/days fixed titration schedule for 12 weeks Run-in/wash-out period: Not reported Comorbidities: Anxiety, Depression Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56, 63, 70, 77, 84, 182, 364 days | Results: Eating Disorder: Change in BMI at 12 weeks: Quetiapine vs TAU - WMD = -0.10 ( -1.74 , 1.54 ) Adverse Events: Quetiapine vs Usual tx Admitted As An Inpatient At A Hospital: 46.7%(7/15) vs 44.4%(8/18) Withdrawals: Quetiapine vs Usual tx Withdrawals:33.3%(5/15) vs 38.9%(7/18) Withdrawals Due To Adverse Events:13.3%(2/15) vs 0.0%(0/18)
Tassniyom et al. 2010^307^ Insomnia Quetiapine Location: Asia Trial: Not reported Funding source: Faculty of Medicine Khon Kean University Design: RCT only Setting: Single setting Jadad: 4 Age: Mean: 25 Sex: 80-99% Female Race: Not reported Screened: 25 Eligible: 16 Entering: 16 Withdrawn: 3 Lost to follow-up: 0 Analyzed: 13 Method of AE assessment: Monitored | Inclusion criteria: 16-65, primary insomnia per DSM-IV-TR Exclusion criteria: Other psychiatric diagnosis, receiving sedating meds, medical diseases, pregnant, unable to record sleep log, answer questionnaires, or refused Interventions: Placebo 25 mg/days fixed single dose for 2 weeks vs Quetiapine 25 mg/days fixed single dose for 2 weeks Run-in/wash-out period: Run-in: Psychotropics for 1 week(s). Patients who met the study criteria were randomized. Comorbidities: None Timing of outcome assessment: 14 days | Results: Insomnia: Change in SL at 2 weeks: Quetiapine vs Placebo - WMD = -72.43 ( -155.52 , 10.66 ) Insomnia: Change in Sleep Satisfaction at 2 weeks: Quetiapine vs Placebo - WMD = 5.70 ( -16.95 , 28.35 ) Insomnia: Change in TST at 2 weeks: Quetiapine vs Placebo - WMD = 52.68 ( -58.13 , 163.49 )
Padala et al. 2006^233^ PTSD Risperidone Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Single setting Jadad: 2 Age: Not reported Sex: 100% Female Race: Caucasian, African Ancestry, Mixed Screened: NR Eligible: NR Entering: 20 Withdrawn: NR Lost to follow-up: NR Analyzed: 15 Method of AE assessment: Monitored | Inclusion criteria: PTSD, female, 19-65 Exclusion criteria: Schizophrenia, bipolar I, unstable illness, suicidality, prior treatment with risperidone, pregnant, nursing, substance abuse / dependency in prior 2 month Interventions: Placebo for 10 weeks vs Risperidone 1-6 mg/days flexible dose for 10 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56, 63, 70, 77, 84, 91 days | Results: PTSD: Insufficient data to calculate an effect size Withdrawals: Placebo vs Risperidone Rash Leading To Withdrawal:0.0%(0/9) vs 9.1%(1/11) Withdrawals:33.3%(3/9) vs 18.2%(2/11) Withdrawals Due To Adverse Events:0.0%(0/9) vs 9.1%(1/11)
Rothbaum et al. 2008^237^ PTSD Risperidone Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 4 Age: Not reported Sex: 80-99% Female Race: Caucasian, African Ancestry, Other-NOS Screened: 91 Eligible: 25 Entering: 25 Withdrawn: 5 Lost to follow-up: 0 Analyzed: 20 Method of AE assessment: Monitored | Inclusion criteria: 18-65, PTSD due to civilian trauma, CAPS >=50 Exclusion criteria: Combat related events Interventions: Placebo for 8 weeks vs Risperidone 0.5-3 mg/days flexible dose for 8 weeks Run-in/wash-out period: Run-in: Sertraline for 8 week(s). Non-responders were randomized. Comorbidities: Anxiety, Depression Timing of outcome assessment: 56, 63, 70, 84, 98, 112 days | Results: PTSD: Change in CAPS at 8 weeks: Risperidone vs Placebo - WMD = 4.08 ( -10.17 , 18.34 ) PTSD: Change in CAPS at 16 weeks: Risperidone vs Placebo - WMD = -2.35 ( -18.69 , 13.99 ) Withdrawals: Placebo vs Risperidone Withdrawals:0.0%(0/11) vs 35.7%(5/14) Withdrawals Due To Adverse Events:0.0%(0/11) vs 28.6%(4/14) Withdrawals Due To Adverse Events Of Elevated Liver Enzyme Levels:0.0%(0/11) vs 7.1%(1/14) Withdrawals Due To Adverse Events Of Probable Dystonic Reaction Before Given Drug:0.0%(0/11) vs 7.1%(1/14) Withdrawals Due To Adverse Events Of Tachycardia:0.0%(0/11) vs 7.1%(1/14) Withdrawals Due To Adverse Events Of Visiting ER Twice With Unremitting Chest Pain:0.0%(0/11) vs 7.1%(1/14)
Hamner et al. 2009^239^ PTSD Quetiapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 2 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: NR Entering: NR Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: 18-65 years old, DSM-IV diagnosis of PTSD, CAPS symptom status version >=50 Exclusion criteria: A history of sensitivity to quetiapine, substance abuse, schizophrenia, schizoaffective disorder, bipolar disorder, dementia Interventions: Placebo for 12 weeks vs Quetiapine 258 (25-800) mg/days flexible dose for 12 weeks Run-in/wash-out period: Wash-out: Placebo for 1 week(s) were randomized. Comorbidities: None Timing of outcome assessment: 84 days | Results: PTSD: Insufficient data to calculate an effect size
Nickel et al. 2007^219^ Personality disorder Aripiprazole Location: Western Europe Trial: Not reported Funding source: Not funded Design: RCT only Setting: Not reported Jadad: 2 Age: Mean: 22 Sex: 80-99% Female Race: Not reported Screened: 52 Eligible: 52 Entering: 52 Withdrawn: 13 Lost to follow-up: 0 Analyzed: 39 Method of AE assessment: Not reported | Inclusion criteria: Same as ID 2754 Exclusion criteria: Schizophrenia, current use of psychotic medication in previous placebo group, termination of aripiprazole, current psychotherapy, pregnancy, suicide ideation, severe somatic illness, substance abuse Interventions: Placebo for 18 months vs Aripiprazole 15 mg/days fixed single dose for 18 months Run-in/wash-out period: Not reported Comorbidities: Anxiety, Depression, OCD Timing of outcome assessment: 182, 365, 547 days | Results: Personality Disorder: Change in SCL-90 (GSI) at 72 weeks: Aripiprazole vs Placebo - WMD = -16.50 ( -20.51 , -12.49 ) Adverse Events: Aripiprazole vs Placebo Anxiety: 15.4%(4/26) vs 19.2%(5/26) Constipation: 15.4%(4/26) vs 11.5%(3/26) Headache: 34.6%(9/26) vs 30.8%(8/26) Insomnia: 30.8%(8/26) vs 23.1%(6/26) Nausea: 15.4%(4/26) vs 15.4%(4/26) Numbness: 11.5%(3/26) vs 3.8%(1/26) Restlessness: 11.5%(3/26) vs 7.7%(2/26) Significant Weight Change: 0.0%(0/26) vs 0.0%(0/26) Withdrawals: Aripiprazole vs Placebo Withdrawals:15.4%(4/26) vs 34.6%(9/26)
Pascual et al. 2008^222^ Personality disorder Ziprasidone Location: Western Europe Trial: Not reported Funding source: Government, Industry, REM-TAP Network Design: RCT only Setting: Single setting Jadad: 3 Age: Not reported Sex: 80-99% Female Race: Not reported Screened: 127 Eligible: 65 Entering: 60 Withdrawn: NR Lost to follow-up: NR Analyzed: 29 Method of AE assessment: Monitored | Inclusion criteria: Borderline personality disorder, 18-45, CGI-5 >= 4, contraception in females Exclusion criteria: Comorbidity, schizophrenia, drug-induced psychosis, organic brain syndrome, alcohol or other substance dependence, bipolar, mental retardation, major depressive episode Interventions: Placebo for 12 weeks vs Ziprasidone 40-200 mg/days flexible dose for 12 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 14, 28, 42, 56, 70, 84 days | Results: Personality Disorder: Change in SCL-90-R (GSI) at 14 weeks: Ziprasidone vs Placebo - WMD = 0.18 ( -0.35 , 0.71 ) Adverse Events: Placebo vs Ziprasidone Dizziness: 0.0%(0/30) vs 13.3%(4/30) Gastrointestinal Symptoms: 6.7%(2/30) vs 0.0%(0/30) Headache: 3.3%(1/30) vs 0.0%(0/30) Hyperprolactinemia Not Clinically Relevant: 0.0%(0/30) vs 6.7%(2/30) Minor Sedation: 3.3%(1/30) vs 20.0%(6/30) Movement Disorders, Dystonia, Akathisia, Rigidity Or Hyperkinesia: 0.0%(0/30) vs 0.0%(0/30) Serious Adverse Events: 0.0%(0/30) vs 0.0%(0/30) Significant Changes In Weight Or Blood Pressure: 0.0%(0/30) vs 0.0%(0/30) Treatment-Emergent Adverse Events: 13.3%(4/30) vs 36.7%(11/30) Uneasy Feeling: 0.0%(0/30) vs 10.0%(3/30) Withdrawals: Placebo vs Ziprasidone Withdrawals:46.7%(14/30) vs 56.7%(17/30) Withdrawals Due To Adverse Events:0.0%(0/30) vs 30.0%(9/30) Withdrawals Due To Adverse Events Of Needed Psychiatric Hospitalization:10.0%(3/30) vs 13.3%(4/30) Withdrawals Due To Treatment-Emergent Adverse Events:0.0%(0/30) vs 13.3%(4/30)
McClure et al. 2009^227^ Personality disorder Risperidone Location: US Trial: Not reported Funding source: Government, Industry Design: RCT only Setting: Multi-center Jadad: 4 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: NR Entering: 31 Withdrawn: NR Lost to follow-up: NR Analyzed: 20 Method of AE assessment: Not reported | Inclusion criteria: 18-60, schizotypal personality disorder Exclusion criteria: Not reported Interventions: Placebo for 10 weeks vs Risperidone 0.25-2 mg/days fixed titration schedule for 10 weeks Run-in/wash-out period: Run-in: Placebo for 2 week(s). Symptomatically stable patients were randomized. Comorbidities: None Timing of outcome assessment: 42, 84 days | Results: Personality Disorder: Change in PANSS (negative) at 12 weeks: Risperidone vs Placebo - WMD = -1.00 ( -6.50 , 4.50 ) Personality Disorder: Change in PANSS (postive) at 12 weeks: Risperidone vs Placebo - WMD = -1.70 ( -5.80 , 2.40 ) Personality Disorder: Change in PANSS (general) at 12 weeks: Risperidone vs Placebo - WMD = -1.80 ( -9.68 , 6.08 ) Withdrawals: Placebo vs Risperidone Galactorrhea (Leading To Withdrawal):0.0%(0/12) vs 5.3%(1/19) Increase In Suicidal Ideation (Leading To Withdrawal):0.0%(0/12) vs 5.3%(1/19) Withdrawals:25.0%(3/12) vs 42.1%(8/19) Risperidone Withdrawals Due To Adverse Events:10.5%(2/19)
Schulz et al. 2008^223^ Personality disorder Olanzapine Location: US, UK, Western Europe Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Not reported Sex: Mixed Race: Caucasian, Other-NOS Screened: 385 Eligible: 314 Entering: 314 Withdrawn: 119 Lost to follow-up: 17 Analyzed: 175 Method of AE assessment: Monitored | Inclusion criteria: 18-65, DSM-IV for personality disorder and DSM-IV for borderline personality disorder by DIPD-IV, ZAN-BPD = q at randomization Exclusion criteria: Schizophrenia, schizoaffective disorder, schizophreniform disorder, bipolar I, delusional disorder by DSM-IV Axis I, major depressive disorder, bipolar II, substance dependence within 3 month, actively suicidal PTSD, panic disorder, OCD BMI < 17, cluster A personality disorder. Interventions: Placebo for 12 weeks vs Olanzapine 2.5-20 mg/days flexible dose for 12 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 28, 42, 56, 70, 84 days | Results: Personality Disorder: Change in SCL-90-R (GSI) at 12 weeks: Olanzapine vs Placebo - WMD = -0.04 ( -0.31 , 0.23 ) Adverse Events: Olanzapine vs Placebo Aggression: 0.6%(1/155) vs 1.3%(2/159) Agitation: 0.6%(1/155) vs 0.0%(0/159) Alcoholism: 0.6%(1/155) vs 0.0%(0/159) Anxiety: 4.5%(7/155) vs 5.0%(8/159) Appetite Increased: 17.4%(27/155) vs 7.5%(12/159) Deaths During Study: 0.0%(0/155) vs 0.0%(0/159) Depressed Mood: 0.0%(0/155) vs 0.6%(1/159) Drug Misuse: 0.6%(1/155) vs 0.0%(0/159) Dry Mouth: 7.1%(11/155) vs 3.8%(6/159) Exacerbation Of Borderline Personality Disorder Symptoms: 0.0%(0/155) vs 1.3%(2/159) Fatigue: 10.3%(16/155) vs 7.5%(12/159) Headache: 14.8%(23/155) vs 11.3%(18/159) Impulsive Behavior: 0.6%(1/155) vs 0.0%(0/159) Incidence Of Treatment-Emergent Abnormal High Levels Of Prolactin At Endpoint: 19.4%(30/155) vs 8.8%(14/159) Insomnia: 2.6%(4/155) vs 6.3%(10/159) Nausea: 4.5%(7/155) vs 7.5%(12/159) Participants With >=1 Treatment-Emergent Adverse Event: 65.8%(102/155) vs 56.6%(90/159) Sedation: 11.6%(18/155) vs 1.3%(2/159) Self-Injurious Ideation: 0.6%(1/155) vs 0.0%(0/159) Self-Mutilation: 0.6%(1/155) vs 0.0%(0/159) Serious AE: 3.9%(6/155) vs 5.7%(9/159) Somnolence: 12.9%(20/155) vs 4.4%(7/159) Suicidal Ideation: 5.8%(9/155) vs 2.5%(4/159) Treatment-Emergent Weight Gain =7% Of Baseline: 32.9%(51/155) vs 2.5%(4/159) Weight Decrease: 0.0%(0/155) vs 0.6%(1/159) Weight Increased: 17.4%(27/155) vs 2.5%(4/159) Withdrawals: Olanzapine vs Placebo Withdrawals:48.4%(75/155) vs 38.4%(61/159) Withdrawals Due To Adverse Events:11.0%(17/155) vs 11.3%(18/159)
Linehan et al. 2008^224^ Personality disorder Olanzapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 3 Age: Not reported Sex: 100% Female Race: Caucasian, African Ancestry, Hispanic, Native American, Other-NOS Screened: 44 Eligible: 24 Entering: 24 Withdrawn: 8 Lost to follow-up: 0 Analyzed: 16 Method of AE assessment: Not reported | Inclusion criteria: Borderline, personality disorder according to personality disorder and conducted clinical interview for DSM-IV (SCID-II), borderline personality disorder for inappropriate anger on the SCID II, OAS-M irritability subscale >=6. Exclusion criteria: Schizophrenia, bipolar I, schizoaffective disorder, major depressive disorder with psychotic features or other psychotic disorder, mental or seizure disorder, substance dependence in the past 6 month according to DSM-IV, self-inflicted injury in the 8 weeks prior, pregnant, breast feeding or planning to be pregnant. Interventions: Placebo 2.5-15 mg/days flexible dose for duration not reported vs Olanzapine 2.5-15 mg/days flexible dose for duration not reported Run-in/wash-out period: Not reported Comorbidities: Anxiety, Depression, Personality Disorder, Substance Abuse, Eating Disorder Timing of outcome assessment: 49, 98, 147 days | Results: Personality Disorder: Insufficient data to calculate an effect size Adverse Events: Olanzapine vs Placebo Dizziness: 133.3%(16/12) vs 66.7%(8/12) Muscle Stiffness: 166.7%(20/12) vs 83.3%(10/12) Severe Nervousness: 0.0%(0/12) vs 83.3%(10/12) Sexual Dysfunction: 66.7%(8/12) vs 0.0%(0/12) Significantly Distressing Or Incapacitating Sedation: 83.3%(10/12) vs 16.7%(2/12) Weight Gain: 183.3%(22/12) vs 116.7%(14/12) Withdrawals: Olanzapine vs Placebo Withdrawals:33.3%(4/12) vs 33.3%(4/12)
van den Broek et al. 2008^221^ Personality disorder Quetiapine Location: Western Europe Trial: Not reported Funding source: Not reported Design: RCT only Setting: Not reported Jadad: 1 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: NR Entering: 24 Withdrawn: 8 Lost to follow-up: NR Analyzed: 16 Method of AE assessment: Not reported | Inclusion criteria: DSM-IV diagnosis of borderline personality disorder Exclusion criteria: Schizophrenia, current major depression, bipolar disorder, substance dependence Interventions: Placebo for 8 weeks vs Quetiapine 200-600 mg/days flexible dose for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 28, 42, 56, 70 days | Results: Personality Disorder: Insufficient data to calculate an effect size
Zanarini et al. 2007^220^ Personality disorder Olanzapine Location: Not reported Trial: Not reported Funding source: Not reported Design: RCT only Setting: Not reported Jadad: 2 Age: Not reported Sex: Race: Not reported Screened: NR Eligible: NR Entering: 451 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Not reported | Inclusion criteria: 18-65 years old, diagnosis of DSM-IV BPD Exclusion criteria: Not reported Interventions: Placebo for 12 weeks vs Olanzapine 2.5 mg/days frequency not reported for 12 weeks vs Olanzapine 5-10 mg/days frequency not reported for 12 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 84 days | Results: Personality Disorder: Change in Zanarini Rating Scale (Response Rate) at 12 weeks: Olanzapine 2.5mg/d vs Placebo - RR = 1.04 ( 0.86 , 1.26 ) Personality Disorder: Change in Zanarini Rating Scale (Response Rate) at 12 weeks: Olanzapine 5-10mg/d vs Placebo - RR = 1.28 ( 1.08 , 1.51 )
Kampman et al. 2007^259^ Substance abuse Quetiapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Not reported Jadad: 3 Age: Mean: 47 Sex: Mixed Race: Caucasian, Other-NOS Screened: 87 Eligible: 72 Entering: 61 Withdrawn: 5 Lost to follow-up: 6 Analyzed: 61 Method of AE assessment: Monitored, elicited by investigator | Inclusion criteria: Aged >= 18 years old, alcohol dependence, have a consecutive 30 days period drinking at least 48 standard drinks, >= 2 days of heavy drinking, >= 3 consecutive days of abstinence, Clinical Institutes Withdrawal Assessment for Alcohol score < 8. Exclusion criteria: Diagnosis of any psychoactive substance dependence other than alcohol or nicotine, current use of psychoactive drugs, taking psychotropic medications, current, severe psychiatric symptoms, severe medical illness, history of seizures or severe head trauma. Interventions: Placebo 50-400 mg/days fixed titration schedule for 12 weeks vs Quetiapine 50-400 mg/days fixed titration schedule for 12 weeks Run-in/wash-out period: Not reported Comorbidities: Anxiety, Depression, OCD, Personality Disorder, PTSD Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56 days | Results: Substance Abuse: Change in Complete Abstinence (Alcohol) at 12 weeks: Quetiapine vs Placebo - RR = 4.97 ( 1.17 , 21.11 ) Adverse Events: Quetiapine vs Placebo Aches And Pains: 44.8%(13/29) vs 56.3%(18/32) Dry Mouth: 31.0%(9/29) vs 0.0%(0/32) Dysphoria: 31.0%(9/29) vs 21.9%(7/32) Gastrointestinal Complaints: 41.4%(12/29) vs 37.5%(12/32) Headache: 27.6%(8/29) vs 28.1%(9/32) Insomnia: 3.4%(1/29) vs 18.8%(6/32) Lightheaded: 17.2%(5/29) vs 12.5%(4/32) Sedation: 51.7%(15/29) vs 18.8%(6/32) Skin Rash: 10.3%(3/29) vs 3.1%(1/32) Upper Respiratory Tract Infection: 37.9%(11/29) vs 31.3%(10/32) Withdrawals: Quetiapine vs Placebo Withdrawals:20.7%(6/29) vs 25.0%(8/32) Withdrawals Due To Adverse Events:0.0%(0/29) vs 3.1%(1/32)
Loebl et al. 2008^269^ Substance abuse Risperidone Location: US Trial: Not reported Funding source: Government, Industry Design: RCT only Setting: Not reported Jadad: 3 Age: Not reported Sex: 100% Male Race: Caucasian, African Ancestry Screened: 89 Eligible: 31 Entering: 31 Withdrawn: NR Lost to follow-up: NR Analyzed: 14 Method of AE assessment: Monitored | Inclusion criteria: Men, 18-60, cocaine dependence, using cocaine >=1 every other week Exclusion criteria: Schizophrenia, bipolar disorder, MDD, HIV, head trauma with loss of consciousness, unstable medical condition Interventions: Placebo for 12 weeks vs Risperidone 1-2 mg pills daily fixed titration schedule and 25mg injection biweekly fixed dose for 12 weeks Run-in/wash-out period: Not reported Comorbidities: Anxiety, Depression, Substance Abuse Timing of outcome assessment: 7, 14, 21, 35, 49, 63, 77 days | Results: Substance Abuse: Change in ASI (Drug Composite) at 12 weeks: Risperidone vs Placebo - WMD = -0.03 ( -0.09 , 0.03 ) Withdrawals: Placebo vs Risperidone Withdrawals:60.0%(9/15) vs 50.0%(8/16) Withdrawals Due To Adverse Events:0.0%(0/15) vs 12.5%(2/16)
Anton et al. 2008^252^ Substance abuse Aripiprazole Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 47 Sex: Mixed Race: Caucasian, African Ancestry, Asian/Pacific Islander, Other-NOS Screened: 691 Eligible: 295 Entering: 295 Withdrawn: 75 Lost to follow-up: 25 Analyzed: 195 Method of AE assessment: Monitored | Inclusion criteria: 21-65 years old, alcohol dependence, presents at 3 visits with negative breathalyzer results and abstain from alcohol before randomization score < 8 on Clinical Institute Withdrawal Assessment for Alcohol Revised Exclusion criteria: Substance abuse on drugs other than cocaine and opiates with exception of marijuana abuse within past year, pregnant, axis I or II disorder, high suicidal risk, allergy to aripiprazole taking an investigational agent within past month. Interventions: Placebo 27.4 mg/days average final dose for 12 weeks vs Aripiprazole 2-30 mg/days fixed titration schedule for 12 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 28, 56, 84 days | Results: Substance Abuse: Change in Complete Abstinence (Alcohol) at 12 weeks: Aripiprazole vs Placebo - RR = 0.50 ( 0.29 , 0.88 ) Substance Abuse: Change in Abstinent Days (Alcohol) at 12 weeks: Aripiprazole vs Placebo - SMD = -0.13 ( -0.36 , 0.10 ) Adverse Events: Aripiprazole vs Placebo Anxiety: 12.8%(19/149) vs 2.7%(4/146) Clinically Significant Alt Elevations (Alt [sgpt]=3× Upper Limit Of Normal): 3.4%(5/149) vs 0.0%(0/146) Clinically Significant Ast Elevations (Ast [sgot]=3× Upper Limit Of Normal): 2.7%(4/149) vs 1.4%(2/146) Death: 0.0%(0/149) vs 0.0%(0/146) Diarrhea: 6.7%(10/149) vs 5.5%(8/146) Disturbance In Attention: 9.4%(14/149) vs 2.1%(3/146) Dizziness: 7.4%(11/149) vs 7.5%(11/146) EPS-Related AE: Akathisia: 6.0%(9/149) vs 0.7%(1/146) EPS-Related AE: Dyskinesia: 1.3%(2/149) vs 0.0%(0/146) EPS-Related AE: Tremor: 3.4%(5/149) vs 2.7%(4/146) EPS-Related AEs: 9.4%(14/149) vs 3.4%(5/146) Fatigue: 24.2%(36/149) vs 6.8%(10/146) Headache: 20.1%(30/149) vs 24.0%(35/146) Increased Appetite: 5.4%(8/149) vs 2.7%(4/146) Insomnia: 21.5%(32/149) vs 11.0%(16/146) Nausea: 6.7%(10/149) vs 6.8%(10/146) Restlessness: 18.1%(27/149) vs 2.7%(4/146) Serious AE: 2.7%(4/149) vs 2.7%(4/146) Serious AE: Accidental Overdose: 0.0%(0/149) vs 0.7%(1/146) Serious AE: Atrial Fibrillation: 0.0%(0/149) vs 0.7%(1/146) Serious AE: Cellulitis: 0.7%(1/149) vs 0.0%(0/146) Serious AE: Chest Pain: 0.7%(1/149) vs 0.0%(0/146) Serious AE: Migraine: 0.7%(1/149) vs 0.0%(0/146) Serious AE: Overdose (Not Accidental): 0.0%(0/149) vs 0.7%(1/146) Serious AE: Thrombosis: 0.7%(1/149) vs 0.0%(0/146) Serious AE: Worsening Alcoholism: 0.0%(0/149) vs 0.7%(1/146) Somnolence: 16.8%(25/149) vs 5.5%(8/146) Treatment Related AE: 81.2%(121/149) vs 61.6%(90/146) Used Anticholinergic For Potential EPS: 2.7%(4/149) vs 0.0%(0/146) Withdrawals: Aripiprazole Anxiety Leading To Withdrawal:3.4%(5/149) Insomnia Leading To Withdrawal:6.7%(10/149) Restlessness Leading To Withdrawal:2.7%(4/149) Aripiprazole vs Placebo Withdrawals:40.9%(61/149) vs 26.7%(39/146) Withdrawals Due To Adverse Events:14.1%(21/149) vs 0.7%(1/146)
Grabowski et al.2000^266^ Substance abuse Risperidone Location: US Trial: Not reported Funding source: Government Design: RCT only Setting: Not reported Jadad: 4 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry, Hispanic Screened: 193 Eligible: NR Entering: NR Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: Not reported Exclusion criteria: Not reported Interventions: Placebo for 12 weeks vs Risperidone 2 mg/days fixed single dose for 12 weeks vs Risperidone 4 mg/days fixed single dose for 12 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56, 63, 70, 77, 84 days | Results: Substance Abuse: Insufficient data to calculate an effect size
Grabowski et al. 2004^274^ Substance abuse Risperidone Location: US Trial: Not reported Funding source: Government Design: RCT only Setting: Not reported Jadad: 3 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry, Hispanic Screened: 120 Eligible: NR Entering: 96 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: 18-50, dual dependent (cocaine and heroin) good medical health, without other psych diagnosis (except nicotine dependence) Exclusion criteria: Not reported Interventions: Placebo for 26 weeks vs Risperidone 2 mg/days frequency not reported for 26 weeks vs Risperidone 4 mg/days frequency not reported for 26 weeks Run-in/wash-out period: Wash-out: Risperidone stabilization for 2 weeks. Patients in symptomatic remission were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56, 63, 70, 77, 84, 91, 98, 105, 112, 119, 126, 133, 140, 147, 154, 161, 168 days | Results: Substance Abuse: Insufficient data to calculate an effect size Withdrawals: Placebo vs Risperidone 2mg vs Risperidone 4mg Withdrawals:78.8%(26/33) vs 65.6%(21/32) vs 54.8%(17/31)
Guardia et al. 2004^256^ Substance abuse Olanzapine Location: Western Europe Trial: Not reported Funding source: Industry Design: RCT only Setting: Single setting Jadad: 5 Age: Not reported Sex: Mixed Race: Not reported Screened: NR Eligible: 60 Entering: 60 Withdrawn: 19 Lost to follow-up: 0 Analyzed: 41 Method of AE assessment: Monitored | Inclusion criteria: DSM-IV for alcohol dependence disorder age 18 - 60 Exclusion criteria: Pregnancy, breast feeding, severe organic disorder, AST or ALT > 150 units /l, severe psychiatric disorders or psychotic disorders, bipolar I, severe major depressive disorder with suicidal risk, severe personality disorder, other current substance abuse or dependence disorder (except for nicotine) that was not in sustained remission, and less than 5 or more than 30 days since the last drink. Interventions: Placebo for 12 weeks vs Olanzapine 5-15 mg/days flexible dose for 12 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 42, 56, 70, 84 days | Results: Substance Abuse: Change in Abstinent Days (Alcohol) at 12 weeks: Olanzapine vs Placebo - SMD = -0.35 ( -0.86 , 0.16 ) Adverse Events: Olanzapine vs Placebo Amenorrhea: 3.4%(1/29) vs 3.2%(1/31) Anxiety: 3.4%(1/29) vs 12.9%(4/31) Appetite Increase: 24.1%(7/29) vs 9.7%(3/31) Constipation: 10.3%(3/29) vs 9.7%(3/31) Decreased Sexual Desire: 3.4%(1/29) vs 12.9%(4/31) Delayed Ejaculation: 3.4%(1/29) vs 6.5%(2/31) Depression: 6.9%(2/29) vs 9.7%(3/31) Dizziness: 0.0%(0/29) vs 9.7%(3/31) Drowsiness: 17.2%(5/29) vs 16.1%(5/31) Dry Mouth: 10.3%(3/29) vs 6.5%(2/31) Erection Difficulty: 3.4%(1/29) vs 6.5%(2/31) Hypokinesia: 3.4%(1/29) vs 3.2%(1/31) Itching: 3.4%(1/29) vs 0.0%(0/31) Loss Of Energy: 6.9%(2/29) vs 12.9%(4/31) Motor Tension: 0.0%(0/29) vs 9.7%(3/31) Muscle Stiffness: 3.4%(1/29) vs 0.0%(0/31) Orthostatic Hypotension: 3.4%(1/29) vs 12.9%(4/31) Photosensitivity: 6.9%(2/29) vs 3.2%(1/31) Tremor: 3.4%(1/29) vs 3.2%(1/31) Weight Gain: 31.0%(9/29) vs 12.9%(4/31) Withdrawals: Olanzapine vs Placebo Withdrawals:41.4%(12/29) vs 22.6%(7/31) Withdrawals Due To Adverse Events:0.0%(0/29) vs 3.2%(1/31)
Hamilton et al. 2009^263^ Substance abuse Olanzapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Single setting Jadad: 4 Age: Mean: 33 Sex: 100% Male Race: Caucasian, African Ancestry Screened: NR Eligible: 48 Entering: 52 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: Age >= 18, cocaine dependence according to DSM-V, active use of cocaine within 30 days by urine test or self-report Exclusion criteria: Currently receiving antipsychotic medication, current DSM - IV diagnosis of schizophrenia, schizoaffective disorder, schizophreniform disorder, delusional disorder. current active psychotic symptoms, hallucinations, remarkably disorganized speech, history of bipolar disorder, major depressive disorder by hypersensitivity to olanzapine serious unstable medical illness. Interventions: Placebo 2.5-20 mg/days flexible dose for 16 weeks vs Olanzapine 2.5-20 mg/days flexible dose for 16 weeks Run-in/wash-out period: Not reported Comorbidities: Depression, OCD, PTSD Timing of outcome assessment: 7, 14, 21, 28, 42, 56, 70, 84 days | Results: Substance Abuse: Insufficient data to calculate an effect size Adverse Events: Olanzapine vs Placebo Abdominal Pain: 13.0%(3/23) vs 20.0%(5/25) Akathisia: 39.1%(9/23) vs 28.0%(7/25) Amnesia: 21.7%(5/23) vs 4.0%(1/25) Any Side Effect: 100.0%(23/23) vs 96.0%(24/25) Articulation Impairment: 17.4%(4/23) vs 20.0%(5/25) Asthenia: 26.1%(6/23) vs 16.0%(4/25) Blepharitis: 8.7%(2/23) vs 4.0%(1/25) Chest Pain: 8.7%(2/23) vs 28.0%(7/25) Constipation: 26.1%(6/23) vs 40.0%(10/25) Dizziness: 21.7%(5/23) vs 16.0%(4/25) Dry Mouth: 69.6%(16/23) vs 44.0%(11/25) Euphoria: 13.0%(3/23) vs 12.0%(3/25) Increased Appetite: 87.0%(20/23) vs 60.0%(15/25) Muscle Twitching: 30.4%(7/23) vs 28.0%(7/25) Neck Rigidity: 26.1%(6/23) vs 28.0%(7/25) Non-Aggressive Behavior Changes: 26.1%(6/23) vs 28.0%(7/25) Peripheral Edema: 8.7%(2/23) vs 4.0%(1/25) Postural Hypotension: 52.2%(12/23) vs 28.0%(7/25) Rash: 8.7%(2/23) vs 4.0%(1/25) Somnolence: 73.9%(17/23) vs 56.0%(14/25) Stuttering: 17.4%(4/23) vs 20.0%(5/25) Tachycardia: 8.7%(2/23) vs 20.0%(5/25) Tremor: 17.4%(4/23) vs 20.0%(5/25) Weight Gain: 69.6%(16/23) vs 64.0%(16/25)
Hutchison et al. 2006^257^ Substance abuse Olanzapine Location: US Trial: Not reported Funding source: Government, Industry Design: RCT only Setting: Single setting Jadad: 1 Age: Not reported Sex: Mixed Race: Caucasian Screened: 154 Eligible: 78 Entering: 64 Withdrawn: 13 Lost to follow-up: 0 Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: Excellent health - DSM - IV for alcohol dependence Exclusion criteria: Psychiatric diagnosis (bipolar disorder, schizophrenia, bulimia, anorexia nervosa) psychological disorder, recurring pharmacotherapy, endorsed current use of illicit drugs other than marijuana, or tested positive for the use of illicit drugs Interventions: Placebo 2.5-5 mg/days fixed single dose for 12 weeks vs Olanzapine 2.5-5 mg/days fixed titration schedule for 12 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 14, 28, 56, 84 days | Results: Substance Abuse: Insufficient data to calculate an effect size Withdrawals: Olanzapine vs Placebo Withdrawals:18.2%(6/33) vs 22.6%(7/31)
Kampman et al. 2003^264^ Substance abuse Olanzapine Location: US Trial: Not reported Funding source: Industry Design: RCT only Setting: Single setting Jadad: 4 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry, Native American Screened: NR Eligible: NR Entering: 30 Withdrawn: NR Lost to follow-up: NR Analyzed: 27 Method of AE assessment: Monitored | Inclusion criteria: $100 worth of cocaine use in prior month, age 18-60 cocaine dependency Exclusion criteria: Substance dependency besides nicotine and alcohol, severe alcohol dependence, psychosis, dementia, use of other psychotropic medications, unstable medical illness, history of hypersensitivity to olanzapine Interventions: Placebo 2.5-10 mg/days fixed titration schedule for 11 weeks vs Olanzapine 2.5-10 mg/days fixed titration schedule for 11 weeks Run-in/wash-out period: Run-in: Psychosocial treatment for 1 week(s). Eligible participants were randomized. Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56, 63, 70, 77, 84 days | Results: Substance Abuse: Change in ASI (Drug Composite) at 12 weeks: Olanzapine vs Placebo - WMD = 0.03 ( -0.03 , 0.09 ) Adverse Events: Olanzapine vs Placebo Medication Related Serious AE: 0.0%(0/15) vs 0.0%(0/15) Withdrawals: Olanzapine vs Placebo Withdrawals:13.3%(2/15) vs 6.7%(1/15)
Levin et al. 1999^268^ Substance abuse Risperidone Location: US Trial: Not reported Funding source: Government Design: RCT only Setting: Not reported Jadad: 3 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry, Hispanic Screened: NR Eligible: 14 Entering: 14 Withdrawn: 4 Lost to follow-up: 0 Analyzed: 10 Method of AE assessment: Monitored | Inclusion criteria: Cocaine dependence Exclusion criteria: Alcohol, opiate or sedative dependence, MD on dysthymia, axis I disorder requiring treatment Interventions: Placebo for 6 weeks vs Risperidone 1-6 mg/days frequency not reported for 12 weeks Run-in/wash-out period: Run-in: Placebo for 2 week(s). Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56, 63, 70, 77, 84, 3, 7 days | Results: Substance Abuse: Change in Reduction in Use (Urine) at 6 weeks: Risperidone vs Placebo - WMD = 0.10 ( -0.22 , 0.42 )
Lile et al. 2008^261^ Substance abuse Aripiprazole Location: US Trial: Not reported Funding source: Government Design: CCT only Setting: Single setting Jadad: 1 Age: Not reported Sex: 80-99% Male Race: Caucasian, African Ancestry Screened: 12 Eligible: 12 Entering: 24 Withdrawn: 6 Lost to follow-up: 0 Analyzed: 12 Method of AE assessment: Monitored | Inclusion criteria: Cocaine dependence, no other psychiatric diagnosis Exclusion criteria: Not reported Interventions: Placebo for 10 days vs Aripiprazole 15 mg/days fixed single dose for 10 days Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: days | Results: Substance Abuse: Insufficient data to calculate an effect size Adverse Events: Aripiprazole Extrapyramidal Symptoms During Maintenance: 8.3%(1/12) Withdrawals: Aripiprazole Withdrawals:50.0%(6/12) Withdrawals Due To Adverse Events:8.3%(1/12)
Newton et al. 2008^272^ Substance abuse Aripiprazole Location: US Trial: Not reported Funding source: Government Design: RCT only Setting: Multi-center Jadad: 3 Age: Mean: 30 Sex: 80-99% Male Race: Caucasian, African Ancestry, Hispanic Screened: NR Eligible: NR Entering: NR Withdrawn: NR Lost to follow-up: NR Analyzed: 16 Method of AE assessment: Monitored | Inclusion criteria: Methamphetamine dependent, not seeking treatment, aged 18-45, had normal physical examinations, EKG's and clinical lab assessments. Exclusion criteria: History of asthma, pregnancy, prior adverse reaction to methamphetamine or aripiprazole, history of seizure disorder, head trauma, dependent on other drugs (except nicotine), other axis I psychiatric disorder Interventions: Placebo for 14 days vs Aripiprazole 15 mg/days fixed single dose for 14 days Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 14 days | Results: Substance Abuse: Change in BDI at 2 weeks: Aripiprazole vs Placebo - WMD = 3.62 ( -4.29 , 11.53 ) Adverse Events: Aripiprazole vs Placebo At Least One AE: 87.5%(7/8) vs 75.0%(6/8) Restlessness: 37.5%(3/8) vs 0.0%(0/8) Severe AE: 25.0%(2/8) vs 12.5%(1/8) Tremor: 50.0%(4/8) vs 25.0%(2/8) Withdrawals: Aripiprazole vs Placebo Withdrawals:0.0%(0/8) vs 0.0%(0/8)
Reid et al. 2005^265^ Substance abuse Olanzapine Location: US Trial: Not reported Funding source: Government Design: RCT only Setting: Multi-center, VA Healthcare System Jadad: 1 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry, Hispanic, Other-NOS Screened: 135 Eligible: 68 Entering: NR Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: Standardized MDD CREST study inclusion criteria Exclusion criteria: Clinically significant medical condition, standardized MDD CREST study exclusion criteria Interventions: Placebo 2 tablets/days fixed single dose for 8 weeks vs Olanzapine 5-10 mg/days fixed titration schedule for 8 weeks vs Valproate 800-1500 mg/days fixed titration schedule for 8 weeks vs Other, Carnitine + Carnitine + CoQ 10 200+500 mg/days fixed single dose for 8 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14, 21, 28, 35, 42, 49, 56 days | Results: Substance Abuse: Change in ASI (Drug Composite) at 8 weeks: Olanzapine vs Placebo - WMD = 0.02 ( -0.23 , 0.27 ) Adverse Events: Carnitine+CoQ10 vs Olanzapine vs Placebo vs Valproate Abdominal Pain: 12.5%(2/16) vs 5.6%(1/18) vs 6.3%(1/16) vs 27.8%(5/18) Anxiety: 0.0%(0/16) vs 0.0%(0/18) vs 0.0%(0/16) vs 11.1%(2/18) Arthralgia: 6.3%(1/16) vs 5.6%(1/18) vs 6.3%(1/16) vs 11.1%(2/18) Asthenia: 12.5%(2/16) vs 5.6%(1/18) vs 12.5%(2/16) vs 11.1%(2/18) At Least One AE: 75.0%(12/16) vs 83.3%(15/18) vs 93.8%(15/16) vs 83.3%(15/18) Back Pain: 12.5%(2/16) vs 11.1%(2/18) vs 0.0%(0/16) vs 16.7%(3/18) Body Pain: 6.3%(1/16) vs 16.7%(3/18) vs 6.3%(1/16) vs 5.6%(1/18) Diarrhea: 6.3%(1/16) vs 5.6%(1/18) vs 25.0%(4/16) vs 33.3%(6/18) Dizziness: 6.3%(1/16) vs 16.7%(3/18) vs 31.3%(5/16) vs 5.6%(1/18) Dry Mouth: 18.8%(3/16) vs 0.0%(0/18) vs 0.0%(0/16) vs 11.1%(2/18) Dyspepsia: 0.0%(0/16) vs 5.6%(1/18) vs 18.8%(3/16) vs 11.1%(2/18) Ecchymosis: 12.5%(2/16) vs 0.0%(0/18) vs 12.5%(2/16) vs 0.0%(0/18) Fever: 0.0%(0/16) vs 0.0%(0/18) vs 12.5%(2/16) vs 11.1%(2/18) Flu Syndrome: 12.5%(2/16) vs 11.1%(2/18) vs 18.8%(3/16) vs 11.1%(2/18) Headache: 25.0%(4/16) vs 22.2%(4/18) vs 18.8%(3/16) vs 27.8%(5/18) Insomnia: 12.5%(2/16) vs 11.1%(2/18) vs 25.0%(4/16) vs 11.1%(2/18) Myalgia: 12.5%(2/16) vs 0.0%(0/18) vs 6.3%(1/16) vs 0.0%(0/18) Nausea: 12.5%(2/16) vs 0.0%(0/18) vs 31.3%(5/16) vs 5.6%(1/18) Somnolence: 18.8%(3/16) vs 44.4%(8/18) vs 25.0%(4/16) vs 38.9%(7/18) Thirst: 18.8%(3/16) vs 0.0%(0/18) vs 0.0%(0/16) vs 11.1%(2/18) Olanzapine vs Placebo vs Valproate Vomiting: 5.6%(1/18) vs 12.5%(2/16) vs 0.0%(0/18)
Smelson et al. 1997^267^ Substance abuse Risperidone Location: US Trial: Not reported Funding source: Not reported Design: CCT only Setting: Single setting Jadad: 0 Age: Not reported Sex: 100% Male Race: Not reported Screened: NR Eligible: NR Entering: NR Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Not reported | Inclusion criteria: Recently cocaine-withdrawn patients, met DSM-IV criteria for cocaine dependence, admitted to a locked inpatient substance abuse treatment program Exclusion criteria: History of opiate, barbiturate, benzodiazepine, marijuana or alcohol dependence, met DSM-IV criteria for a concurrent Axis I disorder, currently taking medication that could affect the central nervous system, history of seizures, cognitive impairment, head trauma, Beck Depression Inventory>16 Interventions: Control Group vs Risperidone 1-4 mg/days flexible dose for duration not reported Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7 days | Results: Substance Abuse: Change in Reduction in Use (Self Report) at 4 weeks: Risperidone vs Placebo - WMD = 4.40 ( -2.68 , 11.48 )
Smelson et al. 2004^270^ Substance abuse Risperidone Location: US Trial: Funding source: Government, Industry Design: RCT only Setting: Single setting, VA Healthcare System Jadad: 3 Age: Mean: 41 Sex: Race: Not reported Screened: NR Eligible: NR Entering: 35 Withdrawn: 3 Lost to follow-up: 0 Analyzed: 32 Method of AE assessment: Reported spontaneously by patient | Inclusion criteria: Met DSM-IV criteria for cocaine dependence, reported using at least 6g of cocaine in the past month, responded to cue-exposure with increased craving Exclusion criteria: Met DSM-IV criteria for an additional Axis I disorder, history of alcohol, opiate, barbiturate, benzodiazapine or marijuana dependence, taking medication that could affect central nervous system, history of seizures Interventions: Placebo for 2 weeks vs Risperidone 1-2 mg/days flexible dose for 2 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7, 14 days | Results: Substance Abuse: Insufficient data to calculate an effect size Withdrawals: Placebo vs Risperidone Withdrawals:12.5%(2/16) vs 5.3%(1/19) Withdrawals Due To Adverse Events:0.0%(0/16) vs 5.3%(1/19)
Stoops et al. 2007^262^ Substance abuse Aripiprazole Location: US Trial: Not reported Funding source: Government Design: CCT only Setting: Single setting Jadad: 2 Age: Not reported Sex: Mixed Race: Caucasian, African Ancestry Screened: NR Eligible: 8 Entering: NR Withdrawn: 0 Lost to follow-up: 0 Analyzed: NR Method of AE assessment: Monitored | Inclusion criteria: Current crack cocaine users Exclusion criteria: Not for any other current psychiatric diagnosis Interventions: Placebo for 7 days vs Aripiprazole 10 mg/days fixed single dose for 7 days Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 7 days | Results: Substance Abuse: Insufficient data to calculate an effect size
Tiihonen et al.2007^271^ Substance abuse Aripiprazole Location: Western Europe Trial: Not reported Funding source: Government, Hospital Design: RCT only Setting: Not reported Jadad: 1 Age: Mean: 36 Sex: Mixed Race: Caucasian Screened: NR Eligible: NR Entering: 53 Withdrawn: 2 Lost to follow-up: NR Analyzed: 17 Method of AE assessment: Not reported | Inclusion criteria: Aged 18 - 65, amphetamine/methamphetamine dependence recent and accustomed intravenous amphetamine / methamphetamine use. Exclusion criteria: Not reported Interventions: Placebo for 20 weeks vs Aripiprazole 15 mg/days fixed single dose for 20 weeks vs Other, Methylphenidate 18-54 mg/days fixed titration schedule for 20 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 140 days | Results: Substance Abuse: Change in Proportion of amphetamine-positive urine screens at 20 weeks: Methylphenidate vs Placebo - RR = 2.25 ( 0.85 , 5.92 ) Substance Abuse: Change in Proportion of amphetamine-positive urine screens at 20 weeks: Aripiprazole vs Placebo - RR = 0.11 ( 0.01 , 1.92 ) Adverse Events: Placebo vs Aripiprazole vs Methylphenidate Transient Ischemic Attack (Attributed To Continued Amphetamine Use): 0.0%(0/17) vs 5.3%(1/19) vs 0.0%(0/17) Withdrawals: Aripiprazole Withdrawals:10.5%(2/19) Placebo vs Aripiprazole vs Methylphenidate Ransient Increase Of Liver Enzymes (Attributed To Recently Started HIV Medications) And Withdrawn:0.0%(0/17) vs 5.3%(1/19) vs 0.0%(0/17) Withdrawals Due To Adverse Events:0.0%(0/17) vs 10.5%(2/19) vs 0.0%(0/17)
Voronin et al. 2008^253^ Substance abuse Aripiprazole Location: US Trial: Not reported Funding source: University Design: RCT only Setting: Not reported Jadad: 4 Age: Mean: 27 Sex: 80-99% Male Race: Caucasian, African Ancestry, Native American Screened: NR Eligible: NR Entering: 30 Withdrawn: 0 Lost to follow-up: 0 Analyzed: 30 Method of AE assessment: Elicited by investigator | Inclusion criteria: Aged 21-65, alcohol dependence, non treatment seeking. Exclusion criteria: Current DSM-IV criteria for drug dependence except nicotine, other major DSM-IV Axis I disorders, psychoactive medication or substance abuse (except marijuana), past history of alcohol-related medical illness, liver enzymes >= 2.5 times above normal, or significant health problems. Interventions: Placebo for 8 days vs Aripiprazole 5-15 mg/days fixed titration schedule for 8 days Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 6, 8 days | Results: Substance Abuse: Change in Complete Abstinence (Alcohol) at 0 weeks: Aripiprazole vs Placebo - RR = 1.67 ( 0.48 , 5.76 ) Adverse Events: Aripiprazole vs Placebo Constipation (Mild): 20.0%(3/15) vs 0.0%(0/15) Constipation (Moderate): 6.7%(1/15) vs 0.0%(0/15) Constipation (Severe): 0.0%(0/15) vs 0.0%(0/15) Day Time Sleepiness (Mild): 33.3%(5/15) vs 73.3%(11/15) Day Time Sleepiness (Moderate): 40.0%(6/15) vs 13.3%(2/15) Day Time Sleepiness (Severe): 26.7%(4/15) vs 0.0%(0/15) Feeling Depressed (Mild): 0.0%(0/15) vs 13.3%(2/15) Feeling Depressed (Moderate): 0.0%(0/15) vs 6.7%(1/15) Feeling Depressed (Severe): 0.0%(0/15) vs 0.0%(0/15) Nervousness (Mild): 40.0%(6/15) vs 0.0%(0/15) Nervousness (Moderate): 6.7%(1/15) vs 13.3%(2/15) Nervousness (Severe): 0.0%(0/15) vs 0.0%(0/15) Trouble Sleeping (Mild): 33.3%(5/15) vs 40.0%(6/15) Trouble Sleeping (Moderate): 46.7%(7/15) vs 0.0%(0/15) Trouble Sleeping (Severe): 6.7%(1/15) vs 6.7%(1/15) Withdrawals: Aripiprazole vs Placebo Withdrawals:0.0%(0/15) vs 0.0%(0/15) Withdrawals Due To Adverse Events:0.0%(0/15) vs 0.0%(0/15)
Hutchison et al. 2001^258^ Substance abuse Olanzapine Location: US Trial: Not reported Funding source: Government Design: RCT only Setting: Not reported Jadad: 3 Age: Mean: 23 Sex: Mixed Race: Not reported Screened: NR Eligible: 26 Entering: 26 Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Not reported | Inclusion criteria: Reported drinking >=2 times/week, >= 3 drinks / occasion (2 for women), age >= 21 years old Exclusion criteria: Reported ever having received treatment for alcohol problems, have history of cardiac illness, reported hearing loss, were taking medications contraindicated for concurrent use with olanzapine, breath alcohol level >0 Interventions: Placebo for 2 days vs Olanzapine 5 mg/days fixed single dose for 2 days Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 1, 7 days | Results: Substance Abuse: Insufficient data to calculate an effect size
Anton et al. 2006^254^ Substance abuse Aripiprazole Location: US Trial: Not reported Funding source: Not reported Design: RCT only Setting: Multi-center Jadad: 2 Age: Not reported Sex: Mixed Race: Not reported Screened: NR Eligible: NR Entering: NR Withdrawn: NR Lost to follow-up: NR Analyzed: NR Method of AE assessment: Not reported | Inclusion criteria: Medically stable, alcohol dependent, outpatients Exclusion criteria: Other substance abuse Interventions: Placebo for 12 weeks vs Aripiprazole <=30 mg/days frequency not reported for 12 weeks Run-in/wash-out period: Not reported Comorbidities: None Timing of outcome assessment: 84 days | Results: Substance Abuse: Insufficient data to calculate an effect size

AE=Adverse Event, NR=Not Reported

Quality of Placebo-Controlled Trials

Study | Treatment allocation | Groups similar at baseline? | Blinding | Dropouts | Other sources of potential bias
Armenteros et al. 2007^77^ ADHD Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Tramontina et al. 2009^79^ ADHD Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Yes | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Bandelow et al. 2009^88^ Anxiety Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Barnett et al. 2002^83^ Anxiety Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Don't know Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Brawman-Mintzer et al. 2005^98^ Anxiety Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Donahue et al. 2009^95^ Anxiety Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Hirschfeld et al. 2006^92^ Anxiety Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Pandina et al. 2007^99^ Anxiety Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Yes | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Pollack et al. 2006^84^ Anxiety Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Simon et al. 2008^85^ Anxiety Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Vaishnavi et al. 2007^89^ Anxiety Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Merideth et al. 2008^87^ Anxiety Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Joyce et al. 2008^94^ Anxiety Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Lohoff et al. 2010^100^ Anxiety Ziprasidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Katzman et al. 2011^93^ Anxiety Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? No | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? No
Altamura et al. 2011^90^ Anxiety Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Not described If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Don't know Was the care provider masked? Don't know Were patients masked? Don't know | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Mintzer et al. 2007^107^ Dementia/Agitation Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Naber et al. 2007^128^ Dementia/Agitation Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Zhong et al. 2007^122^ Dementia/Agitation Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Yes | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Streim et al. 2008^108^ Dementia/Agitation Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Rappaport et al. 2009^109^ Dementia/Agitation Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Paleacu et al. 2008^123^ Dementia/Agitation Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Mintzer et al. 2006^129^ Dementia/Agitation Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? No Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Cutler et al. 2009^171^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Weisler et al. 2009^172^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Chaput et al. 2008^158^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Not described If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Don't know Was the care provider masked? Don't know Were patients masked? Don't know | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
AstraZeneca 2008^173^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
AstraZeneca 2008^169^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
AstraZeneca 2007^168^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Bortnick et al. 2011^170^ Depression Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Bissada et al. 2008^180^ Eating disorder Olanzapine | Was the study described as randomized? No Was the method of randomization adequate? Yes Was the treatment allocation concealed? Yes | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Brambilla et al. 2007^182^ Eating disorder Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Brambilla et al. 2007^183^ Eating disorder Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Don't know Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Gaskill et al. 2001^184^ Eating disorder Olanzapine | Was the study described as randomized? No Was the method of randomization adequate? No Was the treatment allocation concealed? No | Were groups similar at baseline? No | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? No Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Don't know
Court et al. 2010^185^ Eating disorder Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? No Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Tassniyom et al. 2010^307^ Insomnia Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Padala et al. 2006^233^ PTSD Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Rothbaum et al. 2008^237^ PTSD Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Hamner et al. 2009^239^ PTSD Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Nickel et al. 2007^219^ Personality disorder Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Open If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? No Was the care provider masked? No Were patients masked? No | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Pascual et al. 2008^222^ Personality disorder Ziprasidone | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
McClure et al. 2009^227^ Personality disorder Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Schulz et al. 2008^223^ Personality disorder Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Linehan et al. 2008^224^ Personality disorder Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
van den Broek et al. 2008^221^ Personality disorder Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Not described If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Don't know Was the care provider masked? Don't know Were patients masked? Don't know | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Zanarini et al. 2007^220^ Personality disorder Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Kampman et al. 2007^259^ Substance abuse Quetiapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Loebl et al. 2008^269^ Substance abuse Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Anton et al. 2008^252^ Substance abuse Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Grabowski et al. 2000^266^ Substance abuse Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Grabowski et al. 2004^274^ Substance abuse Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Guardia et al. 2004^256^ Substance abuse Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Yes | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? No Was the outcome assessment timing similar in all groups? Yes
Hamilton et al. 2009^263^ Substance abuse Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Yes | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? No Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Hutchison et al. 2006^257^ Substance abuse Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Single blind, patient If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Kampman et al. 2003^264^ Substance abuse Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Yes Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Levin et al. 1999^268^ Substance abuse Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Lile et al. 2008^261^ Substance abuse Aripiprazole | Was the study described as randomized? No Was the method of randomization adequate? No Was the treatment allocation concealed? No | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Don't know Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Newton et al. 2008^272^ Substance abuse Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Don't know Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Reid et al. 2005^265^ Substance abuse Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Not described If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Smelson et al. 1997^267^ Substance abuse Risperidone | Was the study described as randomized? No Was the method of randomization adequate? No Was the treatment allocation concealed? No | Were groups similar at baseline? Don't know | How is blinding described? Single blind, outcome assessment If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Yes Was the care provider masked? Don't know Were patients masked? No | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Smelson et al. 2004^270^ Substance abuse Risperidone | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Stoops et al. 2007^262^ Substance abuse Aripiprazole | Was the study described as randomized? No Was the method of randomization adequate? No Was the treatment allocation concealed? No | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Tiihonen et al. 2007^271^ Substance abuse Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? No | How is blinding described? Not described If reported, was the method of double-blinding appropriate? Not applicable Was the outcome assessor masked? Don't know Was the care provider masked? Don't know Were patients masked? Don't know | Was the dropout rate described and the reason given? Don't know Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes
Voronin et al. 2008^253^ Substance abuse Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Yes Was the dropout rate acceptable? Yes Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Hutchison et al. 2001^258^ Substance abuse Olanzapine | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Yes | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Yes Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? Don't know Was the dropout rate acceptable? Don't know Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Yes Was the compliance acceptable in all groups? Yes Was the outcome assessment timing similar in all groups? Yes
Anton et al. 2006^254^ Substance abuse Aripiprazole | Was the study described as randomized? Yes Was the method of randomization adequate? Don't know Was the treatment allocation concealed? Don't know | Were groups similar at baseline? Don't know | How is blinding described? Double blind If reported, was the method of double-blinding appropriate? Not described Was the outcome assessor masked? Yes Was the care provider masked? Yes Were patients masked? Yes | Was the dropout rate described and the reason given? No Was the dropout rate acceptable? No Were all randomized participants analyzed? Yes | Were cointerventions avoided or similar? Don't know Was the compliance acceptable in all groups? Don't know Was the outcome assessment timing similar in all groups? Yes

AE=Adverse Event, NR=Not Reported