# Previously Published Meta-Analyses

## Depression

Aripiprazole Efficacy

RCTs (Author, year) | Meta-analysis (Aripiprazole)
RCTs (Author, year) | Arbaizar, 2009^301^ | Nelson, 2009^152^
Berman, 2007^155^ | X | X
Marcus, 2008^154^ | X | X
Berman, 2008: same study as156 | | X

Olanzapine Efficacy

RCTs (Author, year) | Meta-analysis (Olanzapine)
RCTs (Author, year) | Nelson, 2009^152^ | Papakostas, 2007^151^
Shelton, 2001^302^ | X | X
Shelton, 2005^303^ | X | X
Corya, 2006^304^ | X | X
Thase, 2007^174^ | X
Thase, 2006 same study as174 | | X

Risperidone Efficacy

RCTs (Author, year) | Meta-analysis (Risperidone)
RCTs (Author, year) | Nelson, 2009^152^ | Papakostas, 2007^151^
Mahmoud, 2007^166^ | X
Reeves, 2008^164^ | X
Keitner, 2009^165^ | X
Keitner, 2006 not included | | X
Gharabawi, 2006 same study as167 | | X

Quetiapine Efficacy

RCTs (Author, year) | Meta-analysis (Quetiapine)
RCTs (Author, year) | Nelson, 2009^152^ | Papakostas, 2007^151^
Mattingly, 2006^161^ | X | X
McIntyre, 2007^86^ | X
El-Khalili, 2008^305^ | X
Khullar, 2006 not included | X | X
Earley, 2007 same study as306 | X
McIntyre, 2006 same study as86 | | X

## PTSD

Risperidone Efficacy

RCTs (Author, year) | Meta-analysis (Risperidone)
RCTs (Author, year) | Pae, 2008^228^
Bartzokis, 2005^230^ | X
Reich, 2004^231^ | X
Monnelly, 2003^232^ | X
Padala, 2006^233^ | X
Hamner, 2003^234^ | X

Olanzapine Efficacy

RCTs (Author, year) | Meta-analysis (Olanzapine)
RCTs (Author, year) | Pae, 2008^228^
Stein, 2002^235^ | X
Butterfield, 2001^236^ | X

Risperidone AE

RCTs (Author, year) | Meta-analysis (Risperidone)
RCTs (Author, year) | Pae, 2008^228^
Bartzokis, 2005^230^ | X
Reich, 2004^231^ | X
Monnelly, 2003^232^ | X
Padala, 2006^233^ | X
Hamner, 2003^234^ | X

Olanzapine AE

RCTs (Author, year) | Meta-analysis (Olanzapine)
RCTs (Author, year) | Pae, 2008^228^
Stein, 2002^235^ | X
Butterfield, 2001^236^ | X

## Personality Disorder

Olanzapine Efficacy

RCTs (Author, year) | Meta-analysis (Olanzapine)
RCTs (Author, year) | Ingenhoven, 2010^213^
Zanarini, 2001^214^ | X
Soler, 2005^215^ | X
Bogenschutz, 2004^216^ | X

Risperidone Efficacy

RCTs (Author, year) | Meta-analysis (Risperidone)
RCTs (Author, year) | Ingenhoven, 2010^213^
Koenigsberg, 2003^217^ | X

Aripiprazole Efficacy

RCTs (Author, year) | Meta-analysis (Aripiprazole)
RCTs (Author, year) | Ingenhoven, 2010^213^
Nickel, 2006^218^ | X

## Substance Abuse

Risperidone Efficacy

RCTs (Author, year) | Meta-analysis (Aripiprazole)
RCTs (Author, year) | Amato, 2007^275^
Grabowski, 2004^274^ | X
Levin, 1999^268^ | X
Smelson, 2004^270^ | X

Olanzapine Efficacy

RCTs (Author, year) | Meta-analysis (Aripiprazole)
RCTs (Author, year) | Amato, 2007^275^
Kampman, 2003^264^ | X
Reid, 2005^265^ | X
Smelson, 2006^245^ | X

## Anxiety

Quetiapine Efficacy

RCTs (Author, year) | Meta-analysis (Quetiapine)
RCTs (Author, year) | Depping, 2010^82^
Bundelow, 2007^88^ | X
Eriksson, 2008 | X
Joyce, 2008^94^ | X
Merideth, 2008 87 | X