# Data Collection Forms

Short Form Screener

Detailed Abstraction Form