# Literature Search Strategies

SEARCH #1 (Drug Utilization):

DATABASE & TIME PERIOD COVERED:

PubMed – 6/1/2008-9/9/2009

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR “Risperidone”[MeSH] OR “olanzapine”[Substance Name] OR “quetiapine”[Substance Name] OR “aripiprazole”[Substance Name] OR “ziprasidone”[Substance Name]

AND

drug utilization OR pharmacoepidemiolog* OR utiliz*[tiab] OR utilis* OR use[ti] OR uses[ti]

NUMBER OF RESULTS: 34

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #2 (Drug Utilization):

DATABASE & DATES OF COVERAGE:

PubMed – 1966-9/10/2009

paliperidone

AND

drug utilization OR pharmacoepidemiolog* OR utiliz*[tiab] OR utilis* OR use[ti] OR uses[ti]

NUMBER OF RESULTS: 10

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #3 (Drug Utilization):

DATABASE & DATES OF COVERAGE:

PsycINFO – 2008-9/24/2009

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR paliperidone

AND

KW OR TI ( drug utilization OR utiliz* OR utilis* OR use OR uses OR pharmacoepidemiolog* )

Search modes - Phrase Searching (Boolean)

NUMBER OF RESULTS: 366

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #4a (Anxiety)

DATABASE & DATES OF COVERAGE:

PubMed – 1966-9/24/2009

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR “Risperidone”[MeSH] OR “olanzapine”[Substance Name] OR “quetiapine”[Substance Name] OR “aripiprazole”[Substance Name] OR “ziprasidone”[Substance Name] OR atypical antipsychotic* OR atypical anti-psychotic*

AND

(“Anxiety”[Mesh] OR “Anxiety Disorders”[Mesh] OR “Anti-Anxiety Agents”[Mesh] OR “Anti-Anxiety Agents ”[Pharmacological Action]) OR anxiety[tiab] OR anxious*[tiab] OR anti-anxiety[tiab] OR antianxiety[tiab]

NUMBER OF RESULTS: 1098

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #4b (Insomnia)

DATABASE & DATES OF COVERAGE:

PubMed – 1966-9/24/2009

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR “Risperidone”[MeSH] OR “olanzapine”[Substance Name] OR “quetiapine”[Substance Name] OR “aripiprazole”[Substance Name] OR “ziprasidone”[Substance Name] OR atypical antipsychotic* OR atypical anti-psychotic*

AND

“Sleep Initiation and Maintenance Disorders”[Mesh] OR insomni*[tiab] OR sleep*[tiab]

NUMBER OF RESULTS: 370

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #4c (Autism):

DATABASE & DATES OF COVERAGE:

PubMed – 1966-9/24/2009

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR “Risperidone”[MeSH] OR “olanzapine”[Substance Name] OR “quetiapine”[Substance Name] OR “aripiprazole”[Substance Name] OR “ziprasidone”[Substance Name] OR atypical antipsychotic* OR atypical anti-psychotic*

AND

autism OR autistic

NUMBER OF RESULTS: 202

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #4d (ADHD):

DATABASE & DATES OF COVERAGE:

PubMed – 1966-9/24/2009

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR “Risperidone”[MeSH] OR “olanzapine”[Substance Name] OR “quetiapine”[Substance Name] OR “aripiprazole”[Substance Name] OR “ziprasidone”[Substance Name] OR atypical antipsychotic* OR atypical anti-psychotic*

AND

“Attention Deficit Disorder with Hyperactivity”[Mesh] OR attention deficit disorder[tiab] OR adhd

NUMBER OF RESULTS: 158

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #4e (Anorexia/Bulimia):

DATABASE & DATES OF COVERAGE:

PubMed – 1966-9/24/2009

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR “Risperidone”[MeSH] OR “olanzapine”[Substance Name] OR “quetiapine”[Substance Name] OR “aripiprazole”[Substance Name] OR “ziprasidone”[Substance Name] OR atypical antipsychotic* OR atypical anti-psychotic*

AND

“Anorexia Nervosa”[Mesh] OR “Anorexia”[Mesh] OR (“Bulimia”[Mesh] OR “Bulimia Nervosa”[Mesh]) OR anorexi*[tiab] OR bulimi*[tiab]

NUMBER OF RESULTS: 86

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #4f (Tourette Syndrome):

DATABASE & DATES OF COVERAGE:

PubMed – 1966-9/24/2009

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR “Risperidone”[MeSH] OR “olanzapine”[Substance Name] OR “quetiapine”[Substance Name] OR “aripiprazole”[Substance Name] OR “ziprasidone”[Substance Name] OR atypical antipsychotic* OR atypical anti-psychotic*

AND

“Tourette Syndrome”[Mesh] OR tourette*[tiab]

NUMBER OF RESULTS: 127

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #5:

DATABASE & DATES OF COVERAGE:

PubMed – 1966-10/13/2009

“Related Article” search on the following:

Leslie, D. L., S. Mohamed, et al. (2009) “Off-label use of antipsychotic medications in the department of Veterans Affairs health care system.” Psychiatr Serv 60(9): 1175-81.

NUMBER OF RESULTS: 107

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #6 (Original Meds and Original Conditions):

DATABASE & DATES OF COVERAGE:

PubMed – 7/1/2008-10/13/2009

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR “Risperidone”[MeSH] OR “olanzapine”[Substance Name] OR “quetiapine”[Substance Name] OR “aripiprazole”[Substance Name] OR “ziprasidone”[Substance Name] OR atypical antipsychotic* OR atypical anti-psychotic*

AND

“Obsessive-Compulsive Disorder”[Mesh] OR “Obsessive Behavior”[Mesh] OR “Stress Disorders, Post-Traumatic”[Mesh] OR “Personality Disorders”[Mesh] OR “Dementia”[Mesh] OR “Depressive Disorder, Major”[Mesh] OR obsessive*[tiab] OR posttraumatic stress[tiab] OR post-traumatic stress[tiab] OR post traumatic stress[tiab] OR ptsd[tiab] OR personality disorder*[tiab] OR dementia[tiab] OR major depress*[tiab]

NUMBER OF RESULTS: 230

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #7 (Original Meds & Original Conditions):

DATABASE & DATES OF COVERAGE:

PsycINFO – 2008-11/13/2009

olanzapine OR quetiapine OR risperidone OR ziprasidone OR aripiprazole

AND

personality disorder* OR posttraumatic stress disorder OR post-traumatic stress OR ptsd or dementia OR “major depressive” OR obsessive-compulsive OR obsessive compulsive or dementia OR ((geriatric OR elderly) AND (agitation OR agitated))

Search modes - Phrase Searching (Boolean)

NUMBER OF RESULTS: 165

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #8 (Original Meds & New Conditions):

DATABASE & DATES OF COVERAGE:

PsycINFO –~1850-11/18/2009

olanzapine OR quetiapine OR risperidone OR ziprasidone OR aripiprazole

AND

anxiety OR anti-anxiety OR antianxiety OR insomnia OR sleep* OR anorexi* OR bulimi* OR tourett* OR attention deficit disorder OR adhd )

Search modes - Phrase Searching (Boolean)

NUMBER OF RESULTS: 895

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #9 (New Meds):

DATABASE & DATES OF COVERAGE:

PubMed – 7/1/2008-10/13/2009

paliperidone

NOT

animal* NOT (human OR humans)

NUMBER OF RESULTS: 209

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #10 (New Meds):

DATABASE & DATES OF COVERAGE:

PubMed – 1966-11/13/2009

iloperidone OR asenapine

NUMBER OF RESULTS: 80

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #11 (New Meds):

DATABASE & DATES OF COVERAGE:

PsycINFO – 2008-11/18/2009

paliperidone OR iloperidone OR asenapine

Search modes - Phrase Searching (Boolean)

NUMBER OF RESULTS: 85

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #12 (Depression):

DATABASE & DATES OF COVERAGE:

PsycINFO – 2008-11/20/2009

olanzapine OR quetiapine OR risperidone OR ziprasidone OR aripiprazole

AND

depression OR depressive

AND

human

NOT

personality disorder* OR posttraumatic stress disorder OR post-traumatic stress OR ptsd or dementia OR “major depressive” OR obsessive-compulsive OR obsessive compulsive or dementia OR ((geriatric OR elderly) AND (agitation OR agitated))

Search modes - Phrase Searching (Boolean)

NUMBER OF RESULTS: 137

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #13 (Substance Abuse):

DATABASE & DATES OF COVERAGE:

PsycINFO – ~1850-11/20/2009

olanzapine OR quetiapine OR risperidone OR ziprasidone OR aripiprazole

AND

substance abuse* OR drug abuse* OR alcohol abuse OR addict* OR drug dependen* OR cocaine OR heroin

AND

human

Search modes - Phrase Searching (Boolean)

NUMBER OF RESULTS: 326

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #14 (Substance Abuse):

DATABASE & DATES OF COVERAGE:

PubMed – 1966-11/20/2009

olanzapine OR quetiapine OR risperidone OR ziprasidone OR aripiprazole

AND

substance abuse* OR drug abuse* OR alcohol abuse OR addict* OR drug dependen* OR cocaine OR heroin OR “Substance-Related Disorders”[Mesh]

NOT

animal* NOT (human OR humans)

NUMBER OF RESULTS: 521

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #15 (Iloperidone & Asenapine):

DATABASE & DATES OF COVERAGE:

Embase – 1972-12/8/2009

iloperidone? or asenapine?

NUMBER OF RESULTS: 222

--------------------------------------------------------------------------------------------------------------

SEARCH ALERTS (Initiated 12/18/09)

PubMed

atypical antipsychotic* OR atypical anti-psychotic* OR olanzapine OR quetiapine OR risperidone OR ziprasidone OR aripiprazole OR paliperidone OR iloperidone OR asenapine

PsycINFO

atypical antipsychotic* OR atypical anti-psychotic* OR olanzapine OR quetiapine OR risperidone OR ziprasidone OR aripiprazole OR paliperidone OR asenapine OR iloperidone

Population Group: Human

Frequency: Monthly, Duration: Six months

Embase (updated 7/8/10 & alert set up)

‘atypical antipsychotic’/exp OR ‘atypical antipsychotic’ OR ‘atypical anti-psychotic’ OR ‘atypical anti psychotic’ OR ‘atypical anti-psychotics’ OR ‘atypical antipsychotics’/exp OR ‘atypical antipsychotics’ OR atypical AND antispsychotic AND agent OR ‘olanzapine’/exp OR ‘olanzapine’ OR ‘quetiapine’/exp OR ‘quetiapine’ OR ‘risperidone’/exp OR ‘risperidone’ OR ‘ziprasidone’/exp OR ‘ziprasidone’ OR ‘aripiprazole’/exp OR ‘aripiprazole’ OR ‘paliperidone’/exp OR ‘paliperidone’ OR ‘iloperidone’/exp OR ‘iloperidone’ OR ‘asenapine’/exp OR ‘asenapine’ AND ([article]/lim OR [article in press]/lim OR [conference abstract]/lim OR [conference paper]/lim OR [conference review]/lim OR [erratum]/lim OR [review]/lim OR [short survey]/lim) AND [humans]/lim AND [2010-2011]/py 988

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #16 (PubMed UPDATE – Drug Utilization):

DATABASE & DATES OF COVERAGE:

PubMed – 8/2009-1/2/2011

atypical antipsychotic* OR atypical anti-psychotic* OR olanzapine OR quetiapine OR risperidone OR ziprasidone OR aripiprazole OR paliperidone OR iloperidone OR asenapine OR “Risperidone”[MeSH] OR “olanzapine”[Substance Name] OR “quetiapine”[Substance Name] OR “aripiprazole”[Substance Name] OR “ziprasidone”[Substance Name]

AND

drug utilization OR pharmacoepidemiolog* OR utiliz*[tiab] OR utilis* OR use[ti] OR uses[ti] OR off-label OR “off label” OR offlabel

NUMBER OF RESULTS: 101

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #17 (PubMed UPDATE - Insomnia):

DATABASE & DATES OF COVERAGE:

PubMed – 8/2009-1/2/2011

“Antipsychotic Agents”[MeSH] OR “Antipsychotic Agents”[Pharmacological Action] OR aripiprazole OR olanzapine OR quetiapine OR risperidone OR ziprasidone)

AND

(“Sleep Initiation and Maintenance Disorders”[Mesh] OR insomni*[tiab] OR sleep*[tiab]

NUMBER OF RESULTS: 75

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #18 (PubMed UPDATE - Autism):

DATABASE & DATES OF COVERAGE:

PubMed – 8/2009-1/2/2011

“Antipsychotic Agents”[MeSH] OR “Antipsychotic Agents”[Pharmacological Action] OR aripiprazole OR olanzapine OR quetiapine OR risperidone OR ziprasidone)

AND

autism OR autistic

NUMBER OF RESULTS: 43

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #19 (PubMed UPDATE - ADHD):

DATABASE & DATES OF COVERAGE:

PubMed – 8/2009-1/2/2011

“Antipsychotic Agents”[MeSH] OR “Antipsychotic Agents”[Pharmacological Action] OR aripiprazole OR olanzapine OR quetiapine OR risperidone OR ziprasidone)

AND

“Attention Deficit Disorder with Hyperactivity”[Mesh] OR attention deficit disorder[tiab] OR adhd

NUMBER OF RESULTS: 38

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #20 (PubMed UPDATE – Eating Disorders):

DATABASE & DATES OF COVERAGE:

PubMed – 8/2009-1/2/2011

“Antipsychotic Agents”[MeSH] OR “Antipsychotic Agents”[Pharmacological Action] OR aripiprazole OR olanzapine OR quetiapine OR risperidone OR ziprasidone)

AND

“Anorexia Nervosa”[Mesh] OR “Anorexia”[Mesh] OR (“Bulimia”[Mesh] OR “Bulimia Nervosa”[Mesh]) OR anorexi*[tiab] OR bulimi*[tiab])

NUMBER OF RESULTS: 12

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #21 (PubMed UPDATE – Tourette Syndrome):

DATABASE & DATES OF COVERAGE:

PubMed – 8/2009-1/2/2011

“Antipsychotic Agents”[MeSH] OR “Antipsychotic Agents”[Pharmacological Action] OR aripiprazole OR olanzapine OR quetiapine OR risperidone OR ziprasidone)

AND

“Tourette Syndrome”[Mesh] OR tourette*[tiab]

NUMBER OF RESULTS: 16

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #22 (PubMed UPDATE – Substance Abuse):

DATABASE & DATES OF COVERAGE:

PubMed – 8/2009-1/2/2011

“Antipsychotic Agents”[MeSH] OR “Antipsychotic Agents”[Pharmacological Action] OR aripiprazole OR olanzapine OR quetiapine OR risperidone OR ziprasidone)

AND

substance abuse* OR drug abuse* OR alcohol abuse OR addict* OR drug dependen* OR cocaine OR heroin OR “Substance-Related Disorders”[Mesh]

NUMBER OF RESULTS: 173

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #23 (PubMed UPDATE – Personality Disorders):

DATABASE & DATES OF COVERAGE:

PubMed – 8/2009-1/2/2011

“Antipsychotic Agents”[MeSH] OR “Antipsychotic Agents”[Pharmacological Action] OR aripiprazole OR olanzapine OR quetiapine OR risperidone OR ziprasidone)

AND

“Obsessive-Compulsive Disorder”[Mesh] OR “Obsessive Behavior”[Mesh] OR “Stress Disorders, Post-Traumatic”[Mesh] OR “Personality Disorders”[Mesh] OR “Dementia”[Mesh] OR “Depressive Disorder, Major”[Mesh] OR obsessive*[tiab] OR posttraumatic stress[tiab] OR post-traumatic stress[tiab] OR post traumatic stress[tiab] OR ptsd[tiab] OR personality disorder*[tiab] OR dementia[tiab] OR major depress*[tiab]

NUMBER OF RESULTS: 225

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #24 (PubMed UPDATE – Anxiety):

DATABASE & DATES OF COVERAGE:

PubMed – 8/2009-1/2/2011

“Antipsychotic Agents”[MeSH] OR “Antipsychotic Agents”[Pharmacological Action] OR aripiprazole OR olanzapine OR quetiapine OR risperidone OR ziprasidone)

AND

“Anxiety”[Mesh] OR “Anxiety Disorders”[Mesh] OR “Anti-Anxiety Agents”[Mesh] OR “Anti-Anxiety Agents ”[Pharmacological Action]) OR anxiety[tiab] OR anxious*[tiab] OR anti-anxiety[tiab] OR antianxiety[tiab]

NUMBER OF RESULTS: 155

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #25 (PsycINFO UPDATE – Drug Utilization):

DATABASE & DATES OF COVERAGE:

PsycINFO – 8/2009-1/6/2011

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR paliperidone

AND

drug utilization OR utiliz* OR utilis* OR use OR uses OR Pharmacoepidemiolog*

Search modes - Phrase Searching (Boolean)

NUMBER OF RESULTS: 189

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #26 (PsycINFO UPDATE – Off-Label):

DATABASE & DATES OF COVERAGE:

PsycINFO – 8/2009-1/6/2011

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR paliperidone

AND

off-label OR “off label” OR offlabel

Search modes - Phrase Searching (Boolean)

NUMBER OF RESULTS: 4

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #27 (PsycINFO UPDATE – Personality Disorders):

DATABASE & DATES OF COVERAGE:

PsycINFO – 8/2009-1/6/2011

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR paliperidone

AND

personality disorder* OR posttraumatic stress disorder OR post-traumatic stress OR ptsd or dementia OR “major depressive” OR obsessive-compulsive OR obsessive compulsive or dementia OR ((geriatric OR elderly) AND (agitation OR agitated))

Search modes - Phrase Searching (Boolean)

NUMBER OF RESULTS: 111

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #28 (PsycINFO UPDATE – Other Disorders):

DATABASE & DATES OF COVERAGE:

PsycINFO – 8/2009-1/6/2011

risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone OR paliperidone

AND

anxiety OR anti-anxiety OR antianxiety OR insomnia OR sleep* OR anorexi* OR bulimi* OR tourett* OR attention deficit disorder OR adhd

Search modes - Phrase Searching (Boolean)

NUMBER OF RESULTS: 137

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #29 (PsycINFO UPDATE – Three specific drugs):

DATABASE & DATES OF COVERAGE:

PsycINFO – 8/2009-1/6/2011

iloperidone OR asenapine OR paliperidone

Search modes - Phrase Searching (Boolean)

NUMBER OF RESULTS: 60

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #30 (PsycINFO UPDATE – Depression):

DATABASE & DATES OF COVERAGE:

PsycINFO – 8/2009-1/6/2011

olanzapine OR quetiapine OR risperidone OR ziprasidone OR aripiprazole

AND

depression OR depressive

NOT

personality disorder* OR posttraumatic stress disorder OR post-traumatic stress OR ptsd or dementia OR “major depressive” OR obsessive-compulsive OR obsessive compulsive or dementia OR ((geriatric OR elderly) AND (agitation OR agitated))

Search modes - Phrase Searching (Boolean)

NUMBER OF RESULTS: 95

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #31 (PsycINFO UPDATE – Substance Abuse):

DATABASE & DATES OF COVERAGE:

PsycINFO – 8/2009-1/6/2011

olanzapine OR quetiapine OR risperidone OR ziprasidone OR aripiprazole

AND

substance abuse* OR drug abuse* OR alcohol abuse OR addict* OR drug dependen* OR cocaine OR heroin

Search modes - Phrase Searching (Boolean)

Population Group: Human

NUMBER OF RESULTS: 47

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #32 (PsycINFO UPDATE – General Atypical Antipsychotics):

DATABASE & DATES OF COVERAGE:

PsycINFO – 8/2009-1/6/2011

atypical antipsychotic* OR atypical anti-psychotic*

Population Group: Human

Search modes - Phrase Searching (Boolean)

NUMBER OF RESULTS: 326

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #33 (Embase UPDATE – Systematic Reviews, Meta-Analyses, Clinical Trials):

DATABASE & DATES OF COVERAGE:

Embase – 1999-5/12/2011

SEARCH STRATEGY:

‘olanzapine’/exp OR ‘quetiapine’/exp OR ‘risperidone’/exp OR ‘ziprasidone’/exp OR ‘aripiprazole’/exp OR ‘iloperidone’/exp OR ‘asenapine’/exp OR ‘paliperidone’/exp OR ‘atypical antipsychotic’/exp OR ‘atypical antipsychotics’/exp OR ‘atypical anti-psychotic’ OR ‘atypical anti-psychotics’ OR ‘atypical antipsychotic agent’/exp

AND

utilization OR utiliz* OR utilis* OR use OR uses OR pharmacoepidemiolog* OR ‘off-label’ OR ‘off label’ OR offlabel OR ‘personality disorder’/exp OR ‘personality disorders’/exp OR ‘posttraumatic stress’/exp OR ‘posttraumatic stress disorder’/exp OR ‘ptsd’/exp OR‘dementia’/exp OR ‘major depressive’ OR ‘major depression’/exp OR ‘obsessive compulsive’ OR ‘obsessive-compulsive disorder’/exp OR (geriatric OR ‘elderly’/exp) AND (‘agitation’/exp OR agitated) OR ‘anxiety’/exp OR ‘anti-anxiety’ OR antianxiety OR insomnia* OR sleep* OR anorexi* OR bulimi* OR tourett* OR ‘attention deficit disorder’/exp OR ‘adhd’/exp OR ‘depression’/exp OR depressive OR ‘alcohol abuse’/exp OR ‘alcoholism’/exp OR ‘substance abuse’/exp OR addict* OR ‘cocaine’/exp OR ‘heroin’/exp OR autism’/exp OR autistic

AND

[cochrane review]/lim OR [controlled clinical trial]/lim OR [meta analysis]/lim OR [randomized controlled trial]/lim OR [systematic review]/lim)

NUMBER OF RESULTS: 684

--------------------------------------------------------------------------------------------------------------

SEARCH STRATEGY #34 (Embase UPDATE – Observational Studies)

DATABASE & DATES OF COVERAGE:

Embase – 1999-5/12/2011

SEARCH STRATEGY:

‘olanzapine’/exp OR ‘quetiapine’/exp OR ‘risperidone’/exp OR ‘ziprasidone’/exp OR ‘aripiprazole’/exp OR ‘iloperidone’/exp OR ‘asenapine’/exp OR ‘paliperidone’/exp OR ‘atypical antipsychotic’/exp OR ‘atypical antipsychotics’/exp OR ‘atypical anti-psychotic’ OR ‘atypical anti-psychotics’ OR ‘atypical antipsychotic agent’/exp

AND

utilization OR utiliz* OR utilis* OR use OR uses OR pharmacoepidemiolog* OR ‘off-label’ OR ‘off label’ OR offlabel OR ‘personality disorder’/exp OR ‘personality disorders’/exp OR ‘posttraumatic stress’/exp OR ‘posttraumatic stress disorder’/exp OR ‘ptsd’/exp OR‘dementia’/exp OR ‘major depressive’ OR ‘major depression’/exp OR ‘obsessive compulsive’ OR ‘obsessive-compulsive disorder’/exp OR (geriatric OR ‘elderly’/exp) AND (‘agitation’/exp OR agitated) OR ‘anxiety’/exp OR ‘anti-anxiety’ OR antianxiety OR insomnia* OR sleep* OR anorexi* OR bulimi* OR tourett* OR ‘attention deficit disorder’/exp OR ‘adhd’/exp OR ‘depression’/exp OR depressive OR ‘alcohol abuse’/exp OR ‘alcoholism’/exp OR ‘substance abuse’/exp OR addict* OR ‘cocaine’/exp OR ‘heroin’/exp OR autism’/exp OR autistic

AND

observational

AND

[humans]/lim

NUMBER OF RESULTS: 111